# References

Abecassis M, McLoughlin M J, Langer B, et al. Serendipitous adrenal masses: prevalence, significance, and management. Am J Surg. Jun. 1985;149(6):783-8. [pmid: 4014556].
Abrams H L, Spiro R, Goldstein N. Metasteses in carcinoma: analysis of 1000 autopsied cases. Cancer. 1950;3:74-85. [pmid: 15405683].
Adams J E, Johnson R J, Rickards D, et al. Computed tomography in adrenal disease. Clin Radiol. Jan. 1983;34(1):39-49. [pmid: 6822035].
Aldrighetti L, Giacomelli M, Calori G, et al. Impact of minimally invasive surgery on adrenalectomy for incidental tumors: comparison with laparotomic technique. Int Surg. Apr. 1997;82(2):160-4. [pmid: 9331845].
Ambrosi B, Peverelli S, Passini E, et al. Abnormalities of endocrine function in patients with clinically “silent” adrenal masses. Eur J Endocrinol. Apr. 1995;132(4):422-8. [pmid: 7711879].
Aso Y, Homma Y. A survey on incidental adrenal tumors in Japan. J Urol. Jun. 1992;147(6):1478-81. [pmid: 1593668].
Aydintug S, Kocak S, Eraslan S. Primary non-functioning tumours of the adrenal cortex: an eight-year experience in Turkey. Eur J Surg. Apr. 1996;162(4):275-8. [pmid: 8739413].
Baba S, Ito K, Yanaihara H, et al. Retroperitoneoscopic adrenalectomy by a lumbodorsal approach: clinical experience with solo surgery. World J Urol. Feb. 1999;17(1):54-8. [pmid: 10096152].
Baker M E, Spritzer C, Blinder R, et al. Benign adrenal lesions mimicking malignancy on MR imaging: report of two cases. Radiology. Jun. 1987;163(3):669-71. [pmid: 3575711].
Bardet S, Rohmer V, Murat A, et al. 131I-6 beta-iodomethylnorcholesterol scintigraphy: an assessment of its role in the investigation of adrenocortical incidentalomas. Clin Endocrinol (Oxf). May. 1996;44(5):587-96. [pmcid: 298219]. [pmid: 8762736].
Barry M K, van Heerden J A, Farley D R, et al. Can adrenal incidentalomas be safely observed?. World J Surg. Jun. 1998;22(6):599-603. [pmid: 9597935].
Barzon L, Fallo F, Sonino N, et al. Adrenocortical carcinoma: experience in 45 patients. Oncology. Nov. 1997;54(6):490-6. [pmid: 9394846].
Barzon L, Scaroni C, Sonino N, et al. Incidentally discovered adrenal tumors: endocrine and scintigraphic correlates. J Clin Endocrinol Metab. Jan. 1998;83(1):55-62. [pmid: 9435416].
Barzon L, Scaroni C, Sonino N, et al. Risk factors and long-term follow-up of adrenal incidentalomas. J Clin Endocrinol Metab. Feb. 1999;84(2):520-6. [pmid: 10022410].
Bastounis E A, Karayiannakis A J, Anapliotou M L, et al. Incidentalomas of the adrenal gland: diagnostic and therapeutic implications. Am Surg. Apr. 1997;63(4):356-60. [pmid: 9124759].
Belldegrun A, Hussain S, Seltzer S E, et al. Incidentally discovered mass of the adrenal gland. Surg Gynecol Obstet. Sep. 1986;163(3):203-8. [pmid: 3750174].
Bencsik Z, Szabolcs I, Goth M, et al. Incidentally detected adrenal tumours (incidentalomas): histological heterogeneity and differentiated therapeutic approach. J Intern Med. Jun. 1995;237(6):585-9. [pmid: 7782731].
Berkman W A, Bernardino M E, Sewell C W, et al. The computed tomography-guided adrenal biopsy. An alternative to surgery in adrenal mass diagnosis. Cancer. May 15. 1984;53(10):2098-103. [pmid: 6704899].
Bernardino M E. Management of the asymptomatic patient with a unilateral adrenal mass. Radiology. Jan. 1988;166(1 Pt 1):121-3. [pmid: 3336671].
Bernardino M E, Walther M M, Phillips V M, et al. CT-guided adrenal biopsy: accuracy, safety, and indications. AJR Am J Roentgenol. Jan. 1985;144(1):67-9. [pmid: 3871150].
Bilbey J H, McLoughlin R F, Kurkjian P S, et al. MR imaging of adrenal masses: value of chemical-shift imaging for distinguishing adenomas from other tumors. AJR Am J Roentgenol. Mar. 1995;164(3):637-42. [pmid: 7863885].
Boland G W, Goldberg M A, Lee M J, et al. Indeterminate adrenal mass in patients with cancer: evaluation at PET with 2-[F-18]-fluoro-2-deoxy-D-glucose. Radiology. Jan. 1995;194(1):131-4. [pmid: 7997539].
Bondanelli M, Campo M, Trasforini G, et al. Evaluation of hormonal function in a series of incidentally discovered adrenal masses. Metabolism. Jan. 1997;46(1):107-13. [pmid: 9005978].
Bonjer H J, Lange J F, Kazemier G, et al. Comparison of three techniques for adrenalectomy. Br J Surg. May. 1997;84(5):679-82. [pmid: 9171764].
Bonjer H J, Sorm V, Berends F J, et al. Endoscopic retroperitoneal adrenalectomy: lessons learned from 111 consecutive cases. Ann Surg. Dec. 2000;232(6):796-803. [pmid: 11088074]. [pmcid: 1421272].
Bonjer H J, van der Harst E, Steyerberg E W, et al. Retroperitoneal adrenalectomy: open or endoscopic?. World J Surg. Dec. 1998;22(12):1246-9. [pmid: 9841752].
Borrelli D, Ingenito A, Cicchi P, et al. Surgical management of adrenal cortical carcinoma. Ital J Surg Sci. 1989;19(1):69-74. [pmid: 2745044].
Boscaro M, Fallo F, Barzon L, et al. Adrenocortical carcinoma: epidemiology and natural history. Minerva Endocrinol. Mar. 1995;20(1):89-94. [pmid: 7651287].
Bruining H A, Lamberts S W, Ong E G, et al. Results of adrenalectomy with various surgical approaches in the treatment of different diseases of the adrenal glands. Surg Gynecol Obstet. Apr. 1984;158(4):367-9. [pmid: 6710301].
Brunt L M, Doherty G M, Norton J A, et al. Laparoscopic adrenalectomy compared to open adrenalectomy for benign adrenal neoplasms. J Am Coll Surg. Jul. 1996;183(1):1-10. [pmid: 8673301].
Burt M, Heelan R T, Coit D, et al. Prospective evaluation of unilateral adrenal masses in patients with operable non-small-cell lung cancer. Impact of magnetic resonance imaging. J Thorac Cardiovasc Surg. Feb. 1994;107(2):584-8. [pmid: 8302078].
Caplan R H, Kisken W A, Huiras C M. Incidentally discovered adrenal masses. Minn Med. Aug. 1991;74(8):23-6. [pmid: 1921930].
Chang S Y, Lee S S, Ma C P, et al. Non-functioning tumours of the adrenal cortex. Br J Urol. May. 1989;63(5):462-4. [pmid: 2731004].
Chapuis Y, Azoulay D, Louvel A, et al. Adrenal gland incidentalomas. A review of thirty-four surgically treated cases. Sem Hop Paris. 1991;67(13):427-32.
Chezmar J L, Robbins S M, Nelson R C, et al. Adrenal masses: characterization with T1-weighted MR imaging. Radiology. Feb. 1988;166(2):357-9. [pmid: 3336711].
Clavien P A, Sanabria J R, Strasberg S M. Proposed classification of complications of surgery with examples of utility in cholecystectomy. Surgery. May. 1992;111(5):518-26. [pmid: 1598671].
Commons R, Callaway C. Adenomas of the adrenal cortex. Arch Intern Med. 1948;81:37-141.
Copeland P M. The incidentally discovered adrenal mass. Ann Intern Med. Jun. 1983;98(6):940-5. [pmid: 6344711].
Corsello S M, Della C S, Bollanti L, et al. Incidentally discovered adrenal masses: a functional and morphological study. Exp Clin Endocrinol. 1993;101(3):131-7. [pmid: 8223980].
Courtade A, Carnaille B, Ernst O, et al. Outcome of incidental adrenal masses not operated on: 44 cases over 7 years. Eur J Surg. Apr. 1997;163(4):315. [pmid: 9161832].
de Agustin P, Lopez-Rios F, Alberti N, et al. Fine-needle aspiration biopsy of the adrenal glands: A ten-year experience. Diagn Cytopathol. Aug. 1999;21(2):92-7. [pmid: 10425045].
de Canniere L, Michel L, Hamoir E, et al. Videoendoscopic adrenalectomy: multicentric study from the Belgian Group for Endoscopic Surgery (BGES). Int Surg. Jan. 1996;81(1):6-8. [pmid: 8803696].
Didolkar M S, Bescher R A, Elias E G, et al. Natural history of adrenal cortical carcinoma: a clinicopathologic study of 42 patients. Cancer. May 1. 1981;47(9):2153-61. [pmid: 7226109].
Dominguez-Gadea L, Diez L, Bas C, et al. Differential diagnosis of solid adrenal masses using adrenocortical scintigraphy. Clin Radiol. Nov. 1994;49(11):796-9. [pmid: 7955847].
Driver C P, Birch J, Gough D C, et al. Adrenal cortical tumors in childhood. Pediatr Hematol Oncol. Nov. 1998;15(6):527-32. [pmid: 9842646].
Dudley N E, Harrison B J. Comparison of open posterior versus transperitoneal laparoscopic adrenalectom. Br J Surg. May. 1999;86(5):656-60. [pmid: 10361189].
Duh Q Y, Siperstein A E, Clark O H, et al. Laparoscopic adrenalectomy. Comparison of the lateral and posterior approaches. Arch Surg. Aug. 1996;131(8):870-5. [pmid: 8712912].
Dusenbery D, Dekker A. Needle biopsy of the adrenal gland: retrospective review of 54 cases. Diagn Cytopathol. Mar. 1996;14(2):126-34. [pmid: 8964168].
Evans H L, Vassilopoulou-Sellin R. Adrenal cortical neoplasms. A study of 56 cases. Am J Clin Pathol. Jan. 1996;105(1):76-86. [pmid: 8561092].
Fahey T J III, Reeve T S, Delbridge L. Adrenalectomy: expanded indications for the extraperitoneal approach. ANZ J Surg. Jul. 1994;64(7):494-7.
Favia G, Lumachi F, Scarpa V, et al. Adrenalectomy in primary aldosteronism: a long-term follow-up study in 52 patients. World J Surg. Jul. 1992;16(4):680-3. [pmid: 1413836].
Fazeli-Matin S, Gill I S, Hsu T H, et al. Laparoscopic renal and adrenal surgery in obese patients: comparison to open surgery. J Urol. Sep. 1999;162(3 Pt 1):665-9. [pmid: 10458337].
Fernandez-Cruz L, Saenz A, Benarroch G, et al. Laparoscopic unilateral and bilateral adrenalectomy for Cushing's syndrome. Transperitoneal and retroperitoneal approaches. Ann Surg. Dec. 1996;224(6):727-34. [pmid: 8968227]. [pmcid: 1235468].
Fernandez-Cruz L, Saenz A, Taura P, et al. Retroperitoneal approach in laparoscopic adrenalectomy: is it advantageous?. Surg Endosc. Jan. 1999;13(1):86-90. [pmid: 9869699].
Fernandez-Cruz L, Taura P, Saenz A, et al. Laparoscopic approach to pheochromocytoma: hemodynamic changes and catecholamine secretion. World J Surg. Sep. 1996;20(7):762-8. [pmid: 8678948].
Filipponi S, Guerrieri M, Arnaldi G, et al. Laparoscopic adrenalectomy: a report on 50 operations. Eur J Endocrinol. May. 1998;138(5):548-53. [pmid: 9625367].
Fishman E K, Deutch B M, Hartman D S, et al. Primary adrenocortical carcinoma: CT evaluation with clinical correlation. AJR Am J Roentgenol. Mar. 1987;148(3):531-5. [pmid: 3492881].
Flecchia D, Mazza E, Carlini M, et al. Reduced serum levels of dehydroepiandrosterone sulphate in adrenal incidentalomas: a marker of adrenocortical tumour. Clin Endocrinol (Oxf). Feb. 1995;42(2):129-34. [pmcid: 298219]. [pmid: 7704956].
Fontana D, Porpiglia F, Destefanis P, et al. What is the role of ultrasonography in the follow-up of adrenal incidentalomas? The Gruppo Piemontese Incidentalomi Surrenalici. Urology. Oct. 1999;54(4):612-6. [pmid: 10510916].
Francis I R, Smid A, Gross M D, et al. Adrenal masses in oncologic patients: functional and morphologic evaluation. Radiology. Feb. 1988;166(2):353-6. [pmid: 3336710].
Gaboardi F, Carbone M, Bozzola A, et al. Adrenal incidentalomas: what is the role of fine needle biopsy?. Int Urol Nephrol. 1991;23(3):197-207. [pmid: 1889964].
Gagner M, Lacroix A, Prinz R A, et al. Early experience with laparoscopic approach for adrenalectomy. Surgery. Dec. 1993;114(6):1120-4. [pmid: 8256217].
Gagner M, Pomp A, Heniford B T, et al. Laparoscopic adrenalectomy: lessons learned from 100 consecutive procedures. Ann Surg. Sep. 1997;226(3):238-46. [pmid: 9339930]. [pmcid: 1191015].
Gasman D, Droupy S, Koutani A, et al. Laparoscopic adrenalectomy: the retroperitoneal approach. J Urol. Jun. 1998;159(6):1816-20. [pmid: 9598466].
Geelhoed G W, Druy E M. Management of the adrenal “incidentaloma”. Surgery. Nov. 1982;92(5):866-74. [pmid: 7135206].
Gill IS. Laparascopic vs. open adrenalectomy. J Urol 1999;161 (Suppl) A69:21.
Gill I S, Soble J J, Sung G T, et al. Needlescopic adrenalectomy--the initial series: comparison with conventional laparoscopic adrenalectomy. Urology. Aug. 1998;52(2):180-6. [pmid: 9697779].
Gillams A, Roberts C M, Shaw P, et al. The value of CT scanning and percutaneous fine needle aspiration of adrenal masses in biopsy-proven lung cancer. Clin Radiol. Jul. 1992;46(1):18-22. [pmid: 1643776].
Glazer H S, Weyman P J, Sagel S S, et al. Nonfunctioning adrenal masses: incidental discovery on computed tomography. AJR Am J Roentgenol. Jul. 1982;139(1):81-5. [pmid: 6979870].
Greenberg P H, Marks C. Adrenal cortical carcinoma: a presentation of 22 cases and a review of the literature. Am Surg. Feb. 1978;44(2):81-5. [pmid: 626440].
Grondal S, Cedermark B, Eriksson B, et al. Adrenocortical carcinoma. A retrospective study of a rare tumor with a poor prognosis. Eur J Surg Oncol. Dec. 1990;16(6):500-6. [pmid: 2253796].
Gross M D, Shapiro B, Francis I R, et al. Scintigraphic evaluation of clinically silent adrenal masses. J Nucl Med. Jul. 1994;35(7):1145-52. [pmid: 8014672].
Gross M D, Shapiro B, Francis I R, et al. Scintigraphy of incidentally discovered bilateral adrenal masses. Eur J Nucl Med. Apr. 1995;22(4):315-21. [pmid: 7607261].
Guazzoni G, Cestari A, Montorsi F, et al. Eight-year experience with transperitoneal laparoscopic adrenal surgery. J Urol. Sep. 2001;166(3):820-4. [pmid: 11490226].
Guazzoni G, Montorsi F, Bergamaschi F et al. Effectiveness and safety of laparoscopic adrenalectomy. J Urol 1994 Nov;152(5:Pt 1):t-8.
Guazzoni G, Montorsi F, Bocciardi A, et al. Transperitoneal laparoscopic versus open adrenalectomy for benign hyperfuncti adrenal tumors: a comparative study. J Urol. May. 1995;153(5):1597-600. [pmid: 7714980].
Guerrero L A. Diagnostic and therapeutic approach to incidental adrenal mass. Urology. Nov. 1985;26(5):435-40. [pmid: 4060383].
Hajjar R A, Hickey R C, Samaan N A. Adrenal cortical carcinoma. A study of 32 patients. Cancer. Feb. 1975;35(2):549-54. [pmid: 234292].
Halachmi S, Best L A, Moskovitz B, et al. Transthoracal approach for the removal of adrenal tumors. Early experience with 10 cases. Eur Urol. 1996;30(4):480-3. [pmid: 8977071].
Harrison L E, Gaudin P B, Brennan M F. Pathologic features of prognostic significance for adrenocortical carcinoma after curative resection. Arch Surg. Feb. 1999;134(2):181-5. [pmid: 10025460].
Hashimoto S, Midorikawa S, Sanada H et al. SSPG titer is a diagnostic marker for adrenocortical adenoma in patients with non-functioning adrenal incidentaloma. Biomed Pharmacother 2000 Jun;54:Suppl-177s.
Heaston D K, Handel D B, Ashton P R, et al. Narrow gauge needle aspiration of solid adrenal masses. AJR Am J Roentgenol. Jun. 1982;138(6):1143-8. [pmid: 6979217].
Hedeland H, Ostberg G, Hokfelt B. On the prevalence of adrenocortical adenomas in an autopsy material in relation to hypertension and diabetes. Acta Med Scand. Sep. 1968;184(3):211-4. [pmid: 5703975].
Henley D J, van Heerden J A, Grant C S, et al. Adrenal cortical carcinoma--a continuing challenge. Surgery. Dec. 1983;94(6):926-31. [pmid: 6648806].
Henry J F, Defechereux T, Gramatica L, et al. Should laparoscopic approach be proposed for large and/or potentially malignant adrenal tumors?. Langenbecks Arch Surg. Aug. 1999;384(4):366-9. [pmid: 10473857].
Henry J F, Defechereux T, Raffaelli M, et al. Complications of laparoscopic adrenalectomy: results of 169 consecutive procedures. World J Surg. Nov. 2000;24(11):1342-6. [pmid: 11038204].
Herrera M F, Grant C S, van Heerden J A, et al. Incidentally discovered adrenal tumors: an institutional perspective. Surgery. Dec. 1991;110(6):1014-21. [pmid: 1745970].
Hobart M G, Gill I S, Schweizer D, et al. Financial analysis of needlescopic versus open adrenalectomy. J Urol. Oct. 1999;162(4):1264-7. [pmid: 10492176].
Hobart M G, Gill I S, Schweizer D, et al. Laparoscopic adrenalectomy for large-volume (> or = 5 cm) adrenal masses. J Endourol. Mar. 2000;14(2):149-54. [pmid: 10772507].
Hogan T F, Gilchrist K W, Westring D W, et al. A clinical and pathological study of adrenocortical carcinoma: therapeutic implications. Cancer. Jun 1. 1980;45(11):2880-3. [pmid: 7379017].
Horgan S, Sinanan M, Helton W S, et al. Use of laparoscopic techniques improves outcome from adrenalectomy. Am J Surg. May. 1997;173(5):371-4. [pmid: 9168068].
Hussain S, Belldegrun A, Seltzer SE et al. Differentiation of malignant from benign adrenal masses: predictive indices on computed tomography. AJR 1985 Jan;American Journal of Roentgenology. 144(1):61–5.
Hussain S, Belldegrun A, Seltzer S E, et al. CT diagnosis of adrenal abnormalities in patients with primary non-adrenal malignancies. Eur J Radiol. May. 1986;6(2):127-31. [pmid: 3013634].
Huvos A G, Hajdu S I, Brasfield R D, et al. Adrenal cortical carcinoma. Clinicopathologic study of 34 cases. Cancer. Feb. 1970;25(2):354-61. [pmid: 5413506].
Icard P, Chapuis Y, Andreassian B, et al. Adrenocortical carcinoma in surgically treated patients: a retrospective study on 156 cases by the French Association of Endocrine Surgery. Surgery. Dec. 1992;112(6):972-9. [pmid: 1455322].
Imai T, Kikumori T, Ohiwa M, et al. A case-controlled study of laparoscopic compared with open lateral adrenalect. Am J Surg. Jul. 1999;178(1):50-3. [pmid: 10456703].
Inabnet W B, Pitre J, Bernard D, et al. Comparison of the hemodynamic parameters of open and laparoscopic adrenalectomy for pheochromocytoma. World J Surg. May. 2000;24(5):574-8. [pmid: 10787079].
Irvin G L III, Fishman L M, Sher J A, et al. Pheochromocytoma. Lateral versus anterior operative approach. Ann Surg. Jun. 1989;209(6):774-8. [pmid: 2730186]. [pmcid: 1494113].
Ishikawa T, Inaba M, Nishiguchi Y, et al. Laparoscopic adrenalectomy for benign adrenal tumors. Biomed Pharmacother. Jun. 2000;54 Suppl 1:183s-6s. [pmid: 10915020].
Ishikawa T, Sowa M, Nagayama M, et al. Laparoscopic adrenalectomy: comparison with the conventional approach. Surg Laparosc Endosc Percutan Tech. Aug. 1997;7(4):275-80.
Jacobs J K, Goldstein R E, Geer R J. Laparoscopic adrenalectomy. A new standard of care. Ann Surg. May. 1997;225(5):495-501. [pmid: 9193177]. [pmcid: 1190783].
Janetschek G, Altarac S, Finkenstedt G, et al. Technique and results of laparoscopic adrenalectomy. Eur Urol. 1996;30(4):475-9. [pmid: 8977070].
Jockenhovel F, Kuck W, Hauffa B, et al. Conservative and surgical management of incidentally discovered adrenal tumors (incidentalomas). J Endocrinol Invest. May. 1992;15(5):331-7. [pmid: 1506617].
Kane N M, Korobkin M, Francis I R, et al. Percutaneous biopsy of left adrenal masses: prevalence of pancreatitis after anterior approach. AJR Am J Roentgenol. Oct. 1991;157(4):777-80. [pmid: 1892034].
Karstrup S, Torp-Pedersen S, Nolsoe C, et al. Ultrasonically guided fine-needle biopsies from adrenal tumors. Scand J Urol Nephrol Suppl. 1991;137:31-4. [pmid: 1947837].
Kasperlik-Zaluska A A, Migdalska B, Jeske W, et al. Incidentally found adrenal tumours: results of investigation of the pituitary-adrenal axis. Endokrynol Pol. 1992;43(3):322-9. [pmid: 1345572].
Kasperlik-Zaluska A A, Migdalska B M, Zgliczynski S, et al. Adrenocortical carcinoma. A clinical study and treatment results of 52 patients. Cancer. May 15. 1995;75(10):2587-91. [pmid: 7736405].
Kasperlik-Zeluska A A, Roslonowska E, Slowinska-Srzednicka J, et al. Incidentally discovered adrenal mass (incidentaloma): investigation and management of 208 patients. Clin Endocrinol (Oxf). Jan. 1997;46(1):29-37. [pmcid: 298219]. [pmid: 9059555].
Katz R L, Patel S, Mackay B, et al. Fine needle aspiration cytology of the adrenal gland. Acta Cytol. May. 1984;28(3):269-82. [pmid: 6587703].
Katz R L, Shirkhoda A. Diagnostic approach to incidental adrenal nodules in the cancer patient. Results of a clinical, radiologic, and fine-needle aspiration study. Cancer. May 1. 1985;55(9):1995-2000. [pmid: 3978579].
Khorram-Manesh A, Ahlman H, Jansson S, et al. Adrenocortical carcinoma: surgery and mitotane for treatment and steroid profiles for follow-up. World J Surg. Jun. 1998;22(6):605-11. [pmid: 9597936].
King D R, Lack E E. Adrenal cortical carcinoma: a clinical and pathologic study of 49 cases. Cancer. Jul. 1979;44(1):239-44. [pmid: 455249].
Kobayashi S, Seki T, Nonomura K, et al. Clinical experience of incidentally discovered adrenal tumor with particular reference to cortical function. J Urol. Jul. 1993;150(1):8-12. [pmid: 8510281].
Kokko J P, Brown T C, Berman M M. Adrenal adenoma and hypertension. Lancet. Mar 4. 1967;1(7488):468-70. [pmid: 4164067].
Kologlu S, Akyar S, Baskal N, et al. Asymptomatic-nonfunctional adrenal masses detected by CT. Endocrinologie. Jul. 1988;26(3):173-8. [pmid: 3212380].
Kolomecki K, Pomorski L, Kuzdak K, et al. The surgical treatment of adrenal gland tumors--incidentaloma. Neoplasma. 1999;46(2):124-7. [pmid: 10466437].
Korman J E, Ho T, Hiatt J R, et al. Comparison of laparoscopic and open adrenalectomy. Am Surg. Oct. 1997;63(10):908-12. [pmid: 9322671].
Korobkin M, Brodeur F J, Francis I R, et al. Delayed enhanced CT for differentiation of benign from malignant adrenal masses. Radiology. Sep. 1996;200(3):737-42. [pmid: 8756924].
Krestin G P, Freidmann G, Fishbach R, et al. Evaluation of adrenal masses in oncologic patients: dynamic contrast-enhanced MR vs CT. J Comput Assist Tomogr. Jan. 1991;15(1):104-10. [pmid: 1987177].
Kudva A, Young W F Jr, Thompson G B, et al. Adrenal incidentaloma: an important component of the clinical presentation. Endocrinologist. 1999;9(2):77-80.
Lee J E, Berger D H, El Naggar A K, et al. Surgical management, DNA content, and patient survival in adrenal cortical carcinoma. Surgery. Dec. 1995;118(6):1090-8. [pmid: 7491528].
Lee M J, Hahn P F, Papanicolaou N, et al. Benign and malignant adrenal masses: CT distinction with attenuation coefficients, size, and observer analysis. Radiology. May. 1991;179(2):415-8. [pmid: 2014283].
Lee W C, Hsieh H H. Retroperitoneosconeoscopic adrenalectomy: Experience with thirty cases. Formos J Surg. 2000;33(1):3-7.
Lefevre M, Gerard-Marchant R, Gubler JP et al. Adrenal cortical carcinoma in children: 42 patients treated from 1958 to 1980 at Villejuif. In: Humphrey GB, Grindley GB, and Dehner LP, editors. Adrenal and Endocrine Tumors in Children. Boston: Martinus Nijhoff Publishers; 1983. p. 265–76.
Lezoche E, Guerrieri M, Paganini A M, et al. Laparoscopic adrenalectomy by the anterior transperitoneal approach: results of 108 operations in unselected cases. Surg Endosc. Oct. 2000;14(10):920-5. [pmid: 11080404].
Liessi G, Sandini F, Spaliviero B, et al. [CT-guided percutaneous biopsy of adrenal masses. Experience of the technic in 54 neoplasm patients]. [Italian]. Radiol Med (Torino). Apr. 1990;79(4):366-70. [pmcid: 358319]. [pmid: 2198625].
Linos D A, Stylopoulos N, Boukis M, et al. Anterior, posterior, or laparoscopic approach for the management of adrenal diseases?. Am J Surg. Feb. 1997;173(2):120-5. [pmid: 9074377].
Lipsett M B, Hertz R, Ross G. T. Clinical and pathophysiological aspects of adrenocortical carcinoma. Am J Med. 1963;35:374-83. [pmid: 14065877].
Lucas S W, Spitz J D, Arregui M E. The use of intraoperative ultrasound in laparoscopic adrenal surgery: the Saint Vincent experience. Surg Endosc. Nov. 1999;13(11):1093-8. [pmid: 10556445].
Lumb G, Mackenzie D H. The incidence of metastases in adrenal glands and ovaries removed for carcinoma of the breast. Cancer. 1959;12:521-6. [pmid: 13652099].
Luton J P, Cerdas S, Billaud L, et al. Clinical features of adrenocortical carcinoma, prognostic factors, and the effect of mitotane therapy. N Engl J Med. Apr 26. 1990;322(17):1195-201. [pmid: 2325710].
Luton J P, Martinez M, Coste J, et al. Outcome in patients with adrenal incidentaloma selected for surgery: an analysis of 88 cases investigated in a single clinical center. Eur J Endocrinol. Jul. 2000;143(1):111-7. [pmid: 10870039].
MacFarlane D A. Cancer of the adrenal cortex: The natural history, prognosis and treatment in a study of 55 cases. Ann R Coll Surg Engl. 1958;23:155-68. [pmid: 13571886].
MacGillivray D C, Shichman S J, Ferrer F A, et al. A comparison of open vs laparoscopic adrenalectomy. Surg Endosc. Oct. 1996;10(10):987-90. [pmid: 8864091].
Malmaeus J, Markaes A, Oberg K, et al. Adrenal gland surgery. Preoperative location of lesions, histologic findings and outcome of surgery. Acta Chir Scand. Oct. 1986;152:577-81. [pmid: 3811759].
Mantero F, Masini A M, Opocher G, et al. Adrenal incidentaloma: an overview of hormonal data from the National Italian Study Group. Horm Res. 1997;47(46):284-9. [pmid: 9167966].
Marescaux J, Mutter D, Wheeler M H. Laparoscopic right and left adrenalectomies. Surgical procedures. Surg Endosc. Sep. 1996;10(9):912-5. [pmid: 8703150].
Masumori N, Adachi H, Noda Y, et al. Detection of adrenal and retroperitoneal masses in a general health examination system. Urology. Oct. 1998;52(4):572-6. [pmid: 9763073].
Mayo-Smith W W, Lee M J, McNicholas M M, et al. Characterization of adrenal masses (< 5 cm) by use of chemical shift MR imaging: observer performance versus quantitative measures. AJR American Journal of Roentgenology. Jul. 1995;165(1):91-5. [pmid: 7785642].
McNicholas M M, Lee M J, Mayo-Smith W W, et al. An imaging algorithm for the differential diagnosis of adrenal adenomas and metastases. AJR Am J Roentgenol. Dec. 1995;165(6):1453-9. [pmid: 7484585].
Michalkiewicz E L, Sandrini R, Bugg M F, et al. Clinical characteristics of small functioning adrenocortical tumors in children. Med Pediatr Oncol. Mar. 1997;28(3):175-8. [pmid: 9024511].
Mitnick J S, Bosniak M A, Megibow A J, et al. Non-functioning adrenal adenomas discovered incidentally on computed tomography. Radiology. Aug. 1983;148(2):495-9. [pmid: 6867348].
Miyake O, Yoshimura K, Yoshioka T, et al. Laparoscopic adrenalectomy. Comparison of the transperitoneal and retroperito approach. Eur Urol. 1998;33(3):303-7. [pmid: 9555557].
Mody M K, Kazerooni E A, Korobkin M. Percutaneous CT-guided biopsy of adrenal masses: immediate and delayed complications. J Comput Assist Tomogr. May. 1995;19(3):434-9. [pmid: 7790554].
Montali G, Solbiati L, Bossi M C, et al. Sonographically guided fine-needle aspiration biopsy of adrenal masses. AJR Am J Roentgenol. Nov. 1984;143(5):1081-4. [pmid: 6385672].
Mugiya S, Suzuki K, Masuda H, et al. Laparoscopic adrenalectomy for nonfunctioning adrenal tumors. J Endourol. Dec. 1996;10(6):539-41. [pmid: 8972789].
Nader S, Hickey R C, Sellin R V, et al. Adrenal cortical carcinoma. A study of 77 cases. Cancer. Aug 15. 1983;52(4):707-11. [pmid: 6861107].
Nagesser S K, Kievit J, Hermans J, et al. The surgical approach to the adrenal gland: a comparison of the retroperitone and the transabdominal routes in 326 operations on 284 patients. Jpn J Clin Oncol. Feb. 2000;30(2):68-74. [pmid: 10768869].
Nakajo M, Nakabeppu Y, Yonekura R, et al. The role of adrenocortical scintigraphy in the evaluation of unilateral incidentally discovered adrenal and juxtaadrenal masses. Ann Nucl Med. Aug. 1993;7(3):157-66. [pmid: 8217490].
Nakano M. Adrenal cortical carcinoma. A clinicopathological and immunohistochemical study of 91 autopsy cases. Acta Pathol Jpn. Feb. 1988;38(2):163-80. [pmid: 3389147].
Nash P A, Leibovitch I, Donohue J P. Adrenalectomy via the dorsal approach: a benchmark for laparoscopic adrenalectomy. J Urol. Nov. 1995;154(5):1652-4. [pmid: 7563312].
O'Leary T J, Ooi T C. The adrenal incidentaloma. Can J Surg. Jan. 1986;29(1):6-8. [pmid: 3940589].
Padberg B C, Lauritzen I, Achilles E, et al. DNA cytophotometry in adrenocortical tumours: a clinicomorphological study of 66 cases. Virchows Arch A Pathol Anat Histopathol. 1991;419(3):167-70. [pmid: 1926757].
Pagani J J, Bernardino M E. Incidence and significance of serendipitous CT findings in the oncologic patient. J Comput Assist Tomogr. Apr. 1982;6(2):268-75. [pmid: 7200495].
Pisanu A, Jafari M, Pattou F, et al. Indications for adrenalectomy in the laparoscopic era. G Chir. Mar. 2001;22(3):101-6. [pmid: 11284165].
Pommier R F, Brennan M F. An eleven-year experience with adrenocortical carcinoma. Surgery. Dec. 1992;112(6):963-70. [pmid: 1455321].
Porpiglia F, Garrone C, Giraudo G, et al. Transperitoneal laparoscopic adrenalectomy: experience in 72 procedures. J Endourol. Apr. 2001;15(3):275-9. [pmid: 11339392].
Prinz R A. A comparison of laparoscopic and open adrenalectomies. Arch Surg. May. 1995;130(5):489-92. [pmid: 7748086].
Prinz R A, Brooks M H, Churchill R, et al. Incidental asymptomatic adrenal masses detected by computed tomographic scanning. Is operation required?. JAMA. Aug 13. 1982;248(6):701-4. [pmid: 7097921].
Proye C A, Huart J Y, Cuvillier X D, et al. Safety of the posterior approach in adrenal surgery: experience in 105 cases. Surgery. Dec. 1993;114(6):1126-31. [pmid: 8256218].
Pujol J, Viladrich M, Rafecas A, et al. Laparoscopic adrenalectomy. A review of 30 initial cases. Surg Endosc. May. 1999;13(5):488-92. [pmid: 10227949].
Rayan S S, Hodin R A. Short-stay laparoscopic adrenalectomy. Surg Endosc. Jun. 2000;14(6):568-72. [pmid: 10890967].
Reincke M, Winkelmann W, Jaursch-Hancke C, et al. [Diagnosis and therapy of asymptomatic adrenal tumors]. [German]. Dtsch Med Wochenschr. Jun 2. 1989;114(22):861-5. [pmid: 2721390].
Reinig J W, Doppman J L, Dwyer A J, et al. MRI of indeterminate adrenal masses. AJR Am J Roentgenol. Sep. 1986;147(3):493-6. [pmid: 3488652].
ReMine W H, Chong G C, van Heerden J A, et al. Current management of pheochromocytoma. Ann Surg. May. 1974;179(5):740-8. [pmid: 4823849]. [pmcid: 1356065].
Ribeiro R C, Sandrini Neto R S, Schell M J, et al. Adrenocortical carcinoma in children: a study of 40 cases. J Clin Oncol. Jan. 1990;8(1):67-74. [pmid: 2295912].
Rossi R, Tauchmanova L, Luciano A, et al. Subclinical Cushing's syndrome in patients with adrenal incidentaloma: clinical and biochemical features. J Clin Endocrinol Metab. Apr. 2000;85(4):1440-8. [pmid: 10770179].
Russell C F, Hamberger B, van Heerden J A, et al. Adrenalectomy: anterior or posterior approach?. Am J Surg. Sep. 1982;144(3):322-4. [pmid: 7114370].
Russi S, Blumentahl H T, Gray S H. Small adenomas of the adrenal cortex in hypertension and diabetes. Arch Intern Med. 1945;76:284-91.
Rutherford J C, Gordon R D, Stowasser M, et al. Laparoscopic adrenalectomy for adrenal tumours causing hypertension and for ‘incidentalomas’ of the adrenal on computerized tomography scanning. Clin Exp Pharmacol Physiol. Jun. 1995;22(67):490-2. [pmid: 8582113].
Sabbaga C C, Avilla S G, Schulz C, et al. Adrenocortical carcinoma in children: clinical aspects and prognosis. J Pediatr Surg. Jun. 1993;28(6):841-3. [pmid: 8331517].
Salomon L, Soule M, Mouly P, et al. Experience with retroperitoneal laparoscopic adrenalectomy in 115 procedures. J Urol. Jul. 2001;166(1):38-41. [pmid: 11435818].
Sand J, Saaristo J, Nordback I, et al. Posterior approach for adrenal surgery: experiences with 59 patients. Ann Chir Gynaecol. 1997;86(3):234-7. [pmid: 9435935].
Sandrini R, Ribeiro R C, DeLacerda L. Childhood adrenocortical tumors. J Clin Endocrinol Metab. Jul. 1997;82(7):2027-31. [pmid: 9215267].
Schell S R, Talamini M A, Udelsman R. Laparoscopic adrenalectomy for nonmalignant disease: improved safety, morbidity, and cost-effectiveness. Surg Endosc. Jan. 1999;13(1):30-4. [pmid: 9869684].
Schwartz L H, Panicek D M, Doyle M V, et al. Comparison of two algorithms and their associated charges when evaluating adrenal masses in patients with malignancies. AJR Am J Roentgenol. Jun. 1997;168(6):1575-8. [pmid: 9168729].
Seddon J M, Baranetsky N, Van Boxel P J. Adrenal “incidentalomas”. Need for surgery. Urology. Jan. 1985;25(1):1-7. [pmid: 3966274].
Shen W T, Lim R C, Siperstein A E, et al. Laparoscopic vs open adrenalectomy for the treatment of primary hyperaldosteronism. Arch Surg. Jun. 1999;134(6):628-31. [pmid: 10367872].
Shichman S J, Herndon C D, Sosa R E, et al. Lateral transperitoneal laparoscopic adrenalectomy. World J Urol. Feb. 1999;17(1):48-53. [pmid: 10096151].
Silverman S G, Mueller P R, Pinkney L P, et al. Predictive value of image-guided adrenal biopsy: analysis of results of 101 biopsies. Radiology. Jun. 1993;187(3):715-8. [pmid: 8497619].
Singer A A, Obuchowski N A, Einstein D M, et al. Metastasis or adenoma? Computed tomographic evaluation of the adrenal mass. Cleve Clin J Med. May. 1994;61(3):200-5. [pmid: 8026063].
Siren J, Tervahartiala P, Sivula A, et al. Natural course of adrenal incidentalomas: seven-year follow-up study. World J Surg. May. 2000;24(5):579-82. [pmid: 10787080].
Soares R L Jr, Monchik J, Migliori S J, et al. Laparoscopic adrenalectomy for benign adrenal neoplasms. Surg Endosc. Jan. 1999;13(1):40-2. [pmid: 9869686].
Soreide J A, Brabrand K, Thoresen S O. Adrenal cortical carcinoma in Norway, 1970-1984. World J Surg. Jul. 1992;16(4):663-7. [pmid: 1413834].
Souliq M, Mouly P, Caron P, et al. Retroperitoneal laparoscopic adrenalectomy: clinical experience in 52 procedures. Urology. Dec 20. 2000;56(6):921-5. [pmid: 11113731].
Sprung J, O'Hara J F Jr, Gill I S, et al. Anesthetic aspects of laparoscopic and open adrenalectomy for pheochromocytom. Urology. Mar. 2000;55(3):339-43. [pmid: 10699606].
Staren E D, Prinz R A. Adrenalectomy in the era of laparoscopy. Surgery. Oct. 1996;120(4):706-11. [pmid: 8862381].
Steiner PE. Cancer, race and geography. Baltimore: Williams and Wilkins; 1954
Subramaniam R, Pandit B, Sadhasivam S, et al. Retroperitoneoscopic excision of phaeochromocytoma--haemodynamic events, complications and outcome. Anaesth Intensive Care. Feb. 2000;28(1):49-53. [pmid: 10701037].
Sullivan M, Boileau M, Hodges C V. Adrenal cortical carcinoma. J Urol. Dec. 1978;120(6):660-5. [pmid: 731800].
Sutton M G, Sheps S G, Lie J T. Prevalence of clinically unsuspected pheochromocytoma. Review of a 50-year autopsy series. Mayo Clin Proc. Jun. 1981;56(6):354-60. [pmid: 6453259].
Suzuki K, Fujita K, Ushiyama T, et al. Efficacy of an ultrasonic surgical system for laparoscopic adrenalectomy. J Urol. Aug. 1995;154(2 Pt 1):484-6. [pmid: 7609111].
Suzuki K, Kageyama S, Hirano Y, et al. Comparison of 3 surgical approaches to laparoscopic adrenalectomy: a nonrandomized, background matched analysis. J Urol. Aug. 2001;166(2):437-43. [pmid: 11458043].
Suzuki K, Kageyama S, Ueda D, et al. Laparoscopic adrenalectomy: clinical experience with 12 cases. J Urol. Oct. 1993;150(4):1099-102. [pmid: 8371362].
Suzuki K, Ushiyama T, Ihara H, et al. Complications of laparoscopic adrenalectomy in 75 patients treated by the same surgeon. Eur Urol. 1999;36(1):40-7. [pmid: 10364654].
Szolar D H, Kammerhuber F. Quantitative CT evaluation of adrenal gland masses: A step forward int he differentiation between adenomas and nonadenomas?. Radiology. Feb. 1997;202:517-21. [pmid: 9015083].
Takeda M. Laparoscopic adrenalectomy: transperitoneal vs retroperitoneal approaches. Biomed Pharmacother. Jun. 2000;54 Suppl 1:207s-10s. [pmid: 10915026].
Takeda M, Go H, Imai T, et al. Experience with 17 cases of laparoscopic adrenalectomy: use of ultrasonic aspirator and argon beam coagulator. J Urol. Sep. 1994;152(3):902-5. [pmid: 8051749].
Takeda M, Go H, Imai T, et al. Laparoscopic adrenalectomy for primary aldosteronism: report of initial ten cases. Surgery. May. 1994;115(5):621-5. [pmid: 8178262].
Takeda M, Go H, Watanabe R, et al. Retroperitoneal laparoscopic adrenalectomy for functioning adrenal tumors: comparison with conventional transperitoneal laparoscopic adrenalectomy. J Urol. Jan. 1997;157(1):19-23. [pmid: 8976206].
Tanaka M, Tokuda N, Koga H, et al. Laparoscopic adrenalectomy for pheochromocytoma: comparison with open adrenalectomy and comparison of laparoscopic surgery for pheochromocytoma versus other adrenal tumors. J Endourol. Jun. 2000;14(5):427-31. [pmid: 10958565].
Teinturier C, Pauchard M S, Brugieres L, et al. Clinical and prognostic aspects of adrenocortical neoplasms in childhood. Med Pediatr Oncol. Feb. 1999;32(2):106-11. [pmid: 9950198].
Terachi T, Matsuda T, Terai A, et al. Transperitoneal laparoscopic adrenalectomy: experience in 100 patients. J Endourol. Oct. 1997;11(5):361-5. [pmid: 9355955].
Terachi T, Yoshida O, Matsuda T et al. Complications of laparoscopic and retroperitoneoscopic adrenalectomies in 370 cases in Japan: a multi-institutional study. Biomed Pharmacother 2000 Jun;54:Suppl-214s.
Terzolo M, Ali A, Osella G, et al. The value of dehydroepiandrosterone sulfate measurement in the differentiation between benign and malignant adrenal masses. Eur J Endocrinol. Jun. 2000;142(6):611-7. [pmid: 10822224].
Terzolo M, Osella G, Ali A, et al. Adrenal incidentaloma, a five year experience. Minerva Endocrinol. Mar. 1995;20(1):69-78. [pmid: 7651285].
Thompson G B, Grant C S, van Heerden J A, et al. Laparoscopic versus open posterior adrenalectomy: a case-control study of 100 patients. Surgery. Dec. 1997;122(6):1132-6. [pmid: 9426429].
Thompson N W, Cheung P S. Diagnosis and treatment of functioning and nonfunctioning adrenocortical neoplasms including incidentalomas. Surg Clin North Am. Apr. 1987;67(2):423-36. [pmid: 3551152].
Ting A C, Lo C Y, Lo C M. Posterior or laparoscopic approach for adrenalectomy. Am J Surg. Jun. 1998;175(6):488-90. [pmid: 9645778].
Tritos N A, Cushing G W, Heatley G, et al. Clinical features and prognostic factors associated with adrenocortical carcinoma: Lahey Clinic Medical Center experience. Am Surg. Jan. 2000;66(1):73-9. [pmid: 10651352].
Turton D B, O'Brian J T, Shakir K M. Incidental adrenal nodules: association with exaggerated 17-hydroxyprogesterone response to adrenocorticotropic hormone. J Endocrinol Invest. Dec. 1992;15(11):789-96. [pmid: 1337905].
Tutuncu N B, Gedik O. Adrenal incidentaloma: report of 33 cases. J Surg Oncol. Apr. 1999;70(4):247-50. [pmid: 10219021].
Valeri A, Borrelli A, Presenti L, et al. Laparoscopic adrenalectomy. Personal experience in 78 patients. G Chir. May. 2001;22(5):185-9. [pmid: 11443844].
Valli N, Catargi B, Ronci N, et al. Biochemical screening for subclinical cortisol-secreting adenomas amongst adrenal incidentalomas. Eur J Endocrinol. Apr. 2001;144(4):401-8. [pmid: 11275951].
van Erkel A R, van Gils A P, Lequin M, et al. CT and MR distinction of adenomas and nonadenomas of the adrenal gland. J Comput Assist Tomogr. May. 1994;18(3):432-8. [pmid: 8188912].
van Heerden J A, Young W F Jr, Grant C S, et al. Adrenal surgery for hypercortisolism--surgical aspects. Surgery. Apr. 1995;117(4):466-72. [pmid: 7716730].
Vargas H I, Kavoussi L R, Bartlett D L, et al. Laparoscopic adrenalectomy: a new standard of care. Urology. May. 1997;49(5):673-8. [pmid: 9145969].
Venkatesh S, Hickey R C, Sellin R V, et al. Adrenal cortical carcinoma. Cancer. Aug 1. 1989;64(3):765-9. [pmid: 2743269].
Virkkala A, Valimaki M, Pelkonen R, et al. Endocrine abnormalities in patients with adrenal tumours incidentally discovered on computed tomography. Acta Endocrinol (Copenh). Jul. 1989;121(1):67-72. [pmid: 2545064].
Walmsley D, McIntyre R, Sawers H A, et al. Laparoscopic trans-peritoneal adrenalectomy: a preliminary report of 14 adrenalectomies. Clin Endocrinol (Oxf). Aug. 1996;45(2):141-5. [pmcid: 298219]. [pmid: 8881445].
Walz M K, Peitgen K, Hoermann R, et al. Posterior retroperitoneoscopy as a new minimally invasive approach for adrenalectomy: results of 30 adrenalectomies in 27 patients. World J Surg. Sep. 1996;20(7):769-74. [pmid: 8678949].
Walz M K, Peitgen K, Walz M V, et al. Posterior retroperitoneoscopic adrenalectomy: lessons learned within five years. World J Surg. Jun. 2001;25(6):728-34. [pmid: 11376407].
Watson R G, van Heerden J A, Northcutt R C, et al. Results of adrenal surgery for Cushing's syndrome: 10 years' experience. World J Surg. Aug. 1986;10(4):531-8. [pmid: 3751085].
Weigel R J, Wells S A, Gunnells J C, et al. Surgical treatment of primary hyperaldosteronism. Ann Surg. Apr. 1994;219(4):347-52. [pmid: 8161259]. [pmcid: 1243150].
Weisnagel S, Gagner M, Breton G, et al. Laparoscopic adrenalectomy. Endocrinologist. 1996;6(3):169-78.
Welch T J, Sheedy P F, Stephens D H, et al. Percutaneous adrenal biopsy: review of a 10-year experience. Radiology. Nov. 1994;193(2):341-4. [pmid: 7972740].
Wells S A, Merke D P, Cutler G B Jr. et al. Therapeutic controversy: The role of laparoscopic surgery in adrenal disease. J Clin Endocrinol Metab. Sep. 1998;83(9):3041-9. [pmid: 9745398].
Winfield H N, Hamilton B D, Bravo E L, et al. Laparoscopic adrenalectomy: the preferred choice? A comparison to open adrenalectomy. J Urol. Aug. 1998;160(2):325-9. [pmid: 9679870].
Wood D E, Delbridge L, Reeve T S. Surgery for adrenal tumours: is operation for the small incidental tumour appropriate?. ANZ J Surg. Oct. 1987;57(10):739-42.
Xiao X R, Ye L Y, Shi L X, et al. Diagnosis and treatment of adrenal tumours: a review of 35 years' experience. Br J Urol. Aug. 1998;82(2):199-205. [pmid: 9722754].
Yoshimura K, Yoshioka T, Miyake O, et al. Comparison of clinical outcomes of laparoscopic and conventional open adrenalectomy. J Endourol. Dec. 1998;12(6):555-9. [pmid: 9895262].
Zografos G C, Driscoll D L, Karakousis C P, et al. Adrenal adenocarcinoma: a review of 53 cases. J Surg Oncol. Mar. 1994;55(3):160-4. [pmid: 8176925].
Zornoza J, Ordonez N, Bernardino M E, et al. Percutaneous biopsy of adrenal tumors. Urology. Oct. 1981;18(4):412-6. [pmid: 7292830].