# Future Research

## The Need to Understand Issues Related to the Diagnosis of Incidentaloma

Adrenal incidentaloma is neither a single pathological entity nor a disease. A strict definition of incidentaloma would aid in the interpretation of results from clinical studies; however, it will not be sufficient to address the diverse manifestations of this condition that are also clinically relevant. Future studies of incidentaloma need to broadly cover all possible scenarios but individual studies should apply rigorous inclusion criteria for each of these scenarios or provide careful analyses of well-defined subgroups.

Many studies assumed that the major reason for the further evaluation of adrenal incidentalomas is for the purpose of detecting adrenal carcinoma. Given the rarity of this tumor and the lack of effective therapy in the later stages, the overall benefit of detection is small. On the other hand, subclinical, biochemically active adrenal adenomas are common and need to be better understood regarding their prevalence and long-term clinical outcomes. Given their prevalence and the significance of hypertension and diabetes, these tumors may become the reason for aggressive intervention in adrenal incidentaloma.

Most of the studies we identified for this topic were retrospective. Like many retrospective studies, they suffered from inaccurate, incomplete, or inadequate definitions and descriptions of the population, reference standard for diagnosis, and follow-up. Future studies should provide more precise definitions of the conditions and standards of measurements, along with complete reporting of essential data.

## Diagnostic Tests to Evaluate Adrenal Mass

With few exceptions, the overall methodological quality of the studies we examined was poor to fair. Higher quality studies are needed to properly assess the clinical usefulness of various diagnostic tests for adrenal incidentalomas. In contrast to published studies, future studies should make a rigorous attempt to clearly define and report eligibility criteria, sample characteristics, test methodology, and the definitions of positive and negative tests. Reference standards should be clearly delineated, completely independent of the tests being investigated, and as much as possible, include well defined outcomes, such as surgical or autopsy diagnoses.

Given the heterogeneity of definitions for incidentaloma, it is important to define specific populations of patients. Many studies combined subjects whom had true incidentalomas, which are rarely malignant, with subjects who had adrenal masses found during cancer work-ups and who frequently have metastatic disease. Other studies failed altogether to report how the adrenal masses were discovered. Without a clearly defined population, studies of diagnostic test performance are difficult to interpret and have limited applicability. In addition, ROC curves should be drawn, and complete data reported whenever possible, so that the reader can determine the proper threshold to use for a given test.

More studies of FNA are required to determine the risks of both needle-tract metastases and major complications. Ideally, future studies should be large, with thorough data collection. Authors should report the following minimum components: patient demographics (e.g., age, body mass index, gender, reason for initial discovery of mass, mass size and location), all relevant aspects of biopsy technique (e.g., position, approach, organs transected, needle size and type, number of passes, radiological tools), biopsy results and final diagnoses, short- and long-term complications, and patient disposition. When appropriate, authors should perform statistical analyses to identify patient characteristics and biopsy techniques associated with an increased risk of complications.

## Assessment of Surgical Techniques for Adrenalectomy

Future research should concentrate on defining the best procedure for each indication, as well as identifying other factors, such as number of operations performed, which may predict surgical complications. In order to compare across series, it would be useful for authors to agree on standard definitions of such seemingly simple outcomes as operating time or post-operative length of stay. It would also be particularly useful to standardize the measurement and reporting of complications.

With regard to complications, almost all studies to date on adrenal surgery complication rates have been retrospective case series. Many contain unrepresentative samples of patients, and data reporting was typically incomplete. Statistical analyses of complication rates are uncommon in the literature. To properly assess the risks and benefits of different surgical approaches for adrenal mass excision, high quality studies are needed in the future. Ideally, these should be comparative, prospective studies of clearly defined populations; if possible, randomized controlled trials would provide the best evidence. Although conducting randomized surgical trials is difficult, at least one small study suggests that it is possible (Fernandez-Cruz, Saenz, Benarroch, et al., 1996). Otherwise, well-matched, prospective, comparative studies would have considerable value. All subjects should be categorized by well-defined risk factors, including co-morbid conditions. Studies should define a priori major and minor complications of interest and should follow subjects for a sufficient time post-operatively to assess long-term complications. Statistical analyses should be performed, when possible, with multivariate analysis. Given the generally low risk of major complications, the value of multivariate analysis, and the inherent variability of surgical techniques among surgeons and facilities, meaningful results will require large, multicenter trials.

## Follow up of Untreated Adrenal Masses

There is very sparse data to guide the management of untreated, incidentally discovered adrenal masses. Most of the available studies are either too small to provide meaningful results or suffer from methodological problems. Results from retrospective studies or studies without specific follow-up protocols are difficult to interpret. Variable definitions of incidentaloma further complicate the problem.

Future prospective studies should apply pre-specified protocols to clearly defined populations. Given the rarity of adrenocortical carcinoma and pheochromocytoma, assessing the usefulness of follow-up protocols will require a large number of subjects. If recent studies are confirmed, follow-up strategies that include biochemical evaluations for subclinical biochemically active adrenal masses will be useful.

## The Need for an International Registry of Adrenal Incidentaloma

Well-designed clinical trials will provide the most reliable evidence regarding the management of these patients, but these trials will take many years and may not always be feasible. An alternative approach would be to create an international registry of patients with well-documented adrenal incidentaloma. This registry should be established using standardized definitions and inclusion criteria. Investigators could then analyze individual patient data to understand the influence of specific factors such as tumor size, age, and inclusion criteria on the development of subsequent adrenal pathologies.