# Conclusions

Question 1. What are the causes and prevalence of clinically inapparent adrenal masses?

The pathologies found among adrenal incidentaloma are well known and include adrenal adenoma, pheochromocytomas, metastases of primary cancers to the adrenal gland, adrenocortical carcinomas, and benign lesions such as myelolipomas and adrenal cysts. Additional pathologies include: adrenal cyst, adrenal hyperplasia, angiomyelolipoma, ganglioneuroma, hematoma, hemorrhage, lymphoma, malignant epithelial carcinoma, metastases, myelolipoma, neurinoma, regenerative hepatic nodule, renal angiomyolipoma, and retroperitoneal fibrosis.

Because incidentaloma is not a disease entity, the prevalence of incidentaloma will vary with the definition applied. The prevalence of incidentaloma in the general healthy population is likely to be very low and higher when the imaging test is performed for specific indications. One study that used transabdominal US for general health examination reported 11 adrenal masses (verified clinically or with pathology) out of 41,357 subjects (prevalence 0.027 percent). The prevalence of incidentaloma has been reported to be 0.6 percent in a study of 2,200 patients undergoing upper abdominal CT for specific indications.

Combining retrospective patient series, the prevalence of adenoma among incidentalomas was 41 percent, metastases was 19 percent, adrenocortical carcinoma was 10 percent, myelolipoma was 9 percent, pheochromocytoma was 8 percent, and other mostly benign lesions comprised the remainder of the lesions. While adenoma is the most frequent cause, the likelihood of various adrenal pathologies is depending on the definition of incidentaloma and inclusion criteria of patients in the studies.

Sixty percent of the incidentalomas occur between the ages of 41 and 60 years. The majority of the incidentalomas, 90 percent, were found in patients between 31 to 70 years of age. The predominant diagnoses were adenomas and metastases at 45 and 20 percent, respectively. Overall, approximately 64 percent of adenomas cases and 70 percent of adrenal carcinomas cases were found in females whereas 60 percent of metastases cases were reported in males.

The limited data show that for small tumors, 4 cm or less, 65 percent were adenomas and approximately 21 percent were metastases. As tumors increased in size from 4 cm or less to greater than 6 cm, the number of adrenal carcinomas increased from 2.3 to 25 percent whereas, adenomas decreased from 65 to 18 percent. In addition, the percentage of metastases decreased slightly from 21 to 18 percent.

There is insufficient data to discern any differences in the rates of various pathologies among the initial diagnostic tests used. In most of the studies, the adrenal incidentalomas were discovered with CT. There were some studies that reported incidentalomas discovered with either US or MRI or CT, but most of the studies do not separately report the data that would allow meaningful subgroup analyses across studies.

The prevalence results we derived by combining data from case series should be interpreted carefully. As discussed in our paper, “Biases of Cases Series and Potential Hazards in Making Recommendations from Case Series Reports” (Appendix C), the lack of a uniform definition of incidentaloma (and because incidentaloma is not a single pathological entity), the selective sampling of patients and reporting of information, and retrospective nature of most of the studies may result in biased estimations of the prevalence of various pathologies.

Question 2. What is the diagnostic accuracy (sensitivity, specificity) of evaluation modalities (FNA/biopsy, CT, MRI, US, biochemical tests) used to differentiate adrenal masses (adrenal carcinoma, pheochromocytoma, adenoma, adrenal hyperplasia, etc.)?

With few exceptions, the overall methodological quality of the studies we examined was poor to fair. The evaluated studies examined multiple tests, used multiple variations of test (such as enhanced and unenhanced CT), used different definitions and thresholds for test results, and included a variety of different sample populations. Study size ranged from 16 to 270. The heterogeneity of the studies limits the ability to estimate the overall diagnostic performance of each of the evaluated tests. Although some studies reported that CT, MRI, scintigraphy, FNA and PET have good to excellent test performance for differentiating benign from malignant disease, others found only moderate to poor performance (except for PET, for which there was only one small study). US had poor performance in a single study. DHEAS had high sensitivity, but low specificity in detecting adrenal cancer, though the single study was small and of poor quality. High quality studies of well-defined diagnostic tests in well-defined populations (such as those with truly incidentally discovered adrenal masses) are required.

Twelve studies reported on complications due to FNA. Only two of these, involving 360 patients, explicitly reported the risk of metastatic spread along the needle tract. Only one patient was found to have metastatic spread. In a patient with metastatic lung cancer, metastatic seeds along the needle tract were found in the liver. No cases of metastatic spread of adrenal carcinoma were reported, although it is not clear how many of the 360 patients had adrenal carcinoma. While the evidence is limited, it appears that the risk of metastatic spread of adrenal cancers and metastases by FNA is very low. Further large, longitudinal studies of patients undergoing FNA for adrenal masses are required.

Question 3. What are the surgical complication rates for various approaches used to excise adrenal masses; specifically laparoscopic, transabdominal, and retroperitoneal approaches?

There are a number of surgical series, both reporting individual experience with a given adrenalectomy technique and comparing different techniques. Despite the large number of studies, involving thousands of patients, the quality of the evidence is poor. Randomized, controlled trials are lacking. Non-randomized series contain significant selection bias, as more difficult cases, larger tumors, and invasive cancers are routinely assigned to the control group as a result of surgeon preference. Nevertheless, the evidence consistently points in the same direction, at least for small, non-malignant tumors. The posterior approach appears to offer an advantage over the anterior approach in terms of surgical morbidity, as measured by post-operating hospital stay, and perhaps in terms of operating time and blood loss as well. Similarly, both RLA and TLA result in shorter hospital stays than PA or AA, and while PA is quicker, TLA and RLA result in less blood loss and perhaps fewer major complications. Although randomized, controlled trials would offer the best measure of the safety of laparoscopy versus open surgery, given the ostensible benefit seen in the non-randomized trials, and the current prevailing thought among surgeons, it is unlikely that such trials will ever be conducted.

When performing laparoscopic adrenalectomy, the lateral transperitoneal approach may be quicker and cause less blood loss than either RLA or anterior TLA, but in terms of hospital stay and complication rates, one approach does not appear to be superior to the others. In this area, more randomized, controlled trials are necessary.

Finally, TNA offers potentially the least morbid procedure, with the least blood loss, the shortest hospital stay, and a low complication rate. However, given that only 15 of these procedures have actually been reported, it is premature to assign needlescopic surgery a role in adrenalectomy. More trials are needed.

For pheochromocytomas, invasive carcinomas, and very large tumors, the best approach is still a matter of debate. There are few series looking at these indications alone, and many authors consider them contraindications to laparoscopy. However, others have challenged these limitations, operating on pheochromocytomas, large tumors, and potential carcinomas, though the latter are usually converted to open procedures once definitively identified. In these areas in particular, where there remains debate, randomized controlled trials are most needed and most appropriate.

Question 4. What are the patient outcomes after surgical excision of adrenocortical carcinoma (morbidity and mortality)?

There were 32 studies with a total of 1,684 patients that met the inclusion criteria. Fifteen of the 32 studies reported perioperative mortality data with an overall perioperative mortality rate of 4.6 percent. There were diverse methods of reporting the long-term survival. Seventeen studies reported 5-year survival data that ranged from 19 to 62 percent with a median of 34 percent (weighted average = 35 percent). There does not appear to be any important difference in the overall survival rates between the earlier and the more recent series. Most of the studies included patients over a wide range of years, making it difficult to discern any trend over time.

Question 5. What evidence is there to support the use of periodic biochemical and imaging studies to follow untreated adrenal masses?

Although many have proposed follow-up strategies for untreated adrenal incidentalomas, there are only a few studies that have evaluated these proposals. Only four studies used a pre-specified follow-up protocol in following up the patients. The studies were small and it is not surprising that few events were identified. If the goal of following small adrenal incidentalomas is the early detection of adrenal carcinomas and pheochromocytomas, prospective clinical trials designed to evaluate follow-up management strategies may not be practical. Given the rarity of these pathologies, large numbers of patients and a long duration of follow-up will be required.