# Results

## Findings for Specific Questions

### Question 1. What are the causes and prevalence of clinically inapparent adrenal masses? (Tables 1–6, Evidence Table 1)

### Question 1.1 What are the causes of clinically inapparent adrenal masses identified by CT, MRI, or ultrasound that are confirmed by histology?

Table 1 listed 42 studies from 13 countries that reported the prevalence and characteristic of the pathologies of adrenal incidentaloma. Table 2 listed the characteristics of the patients and their tumors from 14 studies that reported individual patient data. Pathologies that have been reported to be among incidentalomas include: adrenal adenoma, metastasis, adrenocortical carcinoma, pheochromocytoma, myelolipoma, adrenal cyst, adrenal hyperplasia, angiomyelolipoma, ganglioneuroma, hematoma, lymphoma, malignant epithelial carcinoma, neurinoma, regenerative hepatic nodule, renal angiomyolipoma, and retroperitoneal fibrosis.

Table 1. Prevalence and Characteristics of the Pathologies of Adrenal Incidentaloma

Author | Country | N | Cancer Patients Included? | Study Years | Mean Age, Years ±SD (Range) | Mean Tumor Size, cm±SD (Range) | % Adenoma ^a^ | % Pheo ^a^ | % Carcinoma ^a^
Glazer 1982 | U.S. | 16 | ND | 1979-81 | 57 | 2.4 | ND | ND | ND
Pagani 1982 | U.S. | 37 | yes | 1978-80 | ND | ND | 0 | 6 | 6
Abecassis 1985 | Canada | 19 | no | 1980-82 | 61 | 2.8 | ND | ND | ND
Guererro 1985 | U.S. | 13 | no | ND | 56 | ND | 62 | 0 | 0
Bernardino 1985 | U.S. | 53 | yes | ND | ND | (1.5–9) | ND | 0 | 0
Hussain 1986 | U.S. | 33 | yes | 1976-83 | ND | 3.6 | 21 | 0 | 0
Francis 1988 | U.S. | 28 | yes | ND | (54–75) | (1.2–10) | 57 | 0 | 0
Chang 1989 | Taiwan | 12 | yes | 1979-87 | (20–73) | 1–20 | 17 | 0 | 17
Virkkala 1989 | Finland | 20 | no | 1982-86 | 59 (44–74) | 2.3 | 70 | 0 | 0
Gaboardi 1991 | Italy | 13 | no | 1985-89 | 51 (12–71) | 6.0 | 15 | 15 | 15
Caplan 1991 | U.S. | 23 | no | 1976-88 | 56 (0–82) | ND | 54 | 0 | 6
Chapuis 1991 | France | 34 | no | 1981-90 | 58 (20–71) | 4.0 | 50 | 3 | 6
Herrera 1991 | U.S. | 342 | no | 1985-89 | 61±13 | 94% <5.0 | 96 | 1.5 | 1
Aso 1992 | Japan | 210 | yes | 1980-88 | 53 (4–82) | ~4.7 | 33 | 23 | 4
Gillams 1992 | Great Britain | 22 | yes | 1985-90 | 66 (51–74) | 2.6 | 23 | 0 | 0
Jockenhovel 1992 | Germany | 36 | ND | ND | 56 | 3.1 | 78 | 0 | 0
Turton 1992 | U.S. | 12 | no | ND | 55±7.3 | 2.0 | 100 | 0 | 0
Corsello 1993 | Italy | 17 | no | 1991-92 | 50 (20–66) | 4.8 | 76 | 18 | 6
Kobayashi 1993 | Japan | 23 | ND | ND | 57 | 2.5±1.1 | 55 | 0 | 0
Nakajo 1993 | Japan | 33 | no | 1986-91 | ND | ND | 3 | 6 | 9
Burt 1994 | U.S. | 27 | yes | ND | 58 (42–75) | 2.2 | 81 | 0 | 0
Boland 1995 | U.S. | 20 | yes | 1993 | 65 | 2.8 | ND | 0 | 0
Flecchia 1995 | Italy | 32 | yes | ND | 57 (20–96) | 3.7 | 69 | 0 | 6
Ambrosi 1995 | Italy | 32 | no | ND | 67 (28–74) | 2–6.3 | 57 | 0 | 14
Bencsik 1995 | Hungary | 63 | no | ND | (27–85) | (2–21) | 22 | 0 | 1.5
Terzolo 1995 | Italy | 45 | no | 1989-94 | 58 (19–79) | 3.7 | 18 | 4 | 7
Peltier 1996 | France | 46 | no | ND | 61 (29–77) | ND | 76 | 4 | 4
Aydintug 1996 | Turkey | 20 | ND | 1986-93 | 50 (24–67) | 3.7 | 85 | 0 | 10
Bastounis 1997 | Greece | 86 | no | 1985-95 | 61 (38–76) | 4.1 | 67 | 7 | 3
Bondanelli 1997 | Italy | 38 | yes | 1990-? | 58±2.3 | (2–12) | 33 | 13 | 7
Mantero 1997 | Italy | 1013 | no | 1980-95 | ND | ND | 81 | 3 | 3
Kasperlik 1997 | Poland | 208 | ND | 1986-96 | 52 | (0.8–21) | 82 | 15 | 20
Barzon 1998 | Italy | 202 | no | ND | 55 (14–77) | 3.6 | 21 | 5 | 11
Barry 1998 | U.S. | 231 | ND | 1985-89 | 64 (5-86) | 2.0 | 97 | 0 | 0
Xiao 1998 | China | 78 | yes | 1960-95 | 39 (1–77) | ND | 12 | 22 | 12
Masumori 1998 | Japan | 11 | no | 1991-96 | 53 | 2.9 | 72 | 9 | 0
Tütüncü 1999 | Turkey | 33 | no | 1985-? | 51 (23–79) | 5.2±4.0 | 21 | 18 | 6
Fontana 1999 | Italy | 208 | no | 1989-96 | 55±14 | (0.5–25) | 51 | 9 | 13
Kudva 1999 | U.S. | 15 | no | 1978-95 | 60±13 | 6.1 | 0 | 100 | 0
Rossi 2000 | Italy | 65 | yes | 1992-98 | 54 (27–78) | (1–6.5) | 77 | 8 | 3
Luton 2000 | France | 88 | no | 1978-96 | 53±14 | 5.0±3.0 | 41 | 11 | 2
Hashimoto 2000 | Japan | 11 | no | ND | ND | 3.2 | 73 | 0 | 0

N, number of subjects; SD, standard deviation; Pheo, pheochromocytoma; ND, no data

a Percentage may not add up to 100 because either multiple diagnoses or other pathologies not listed in the table.

Table 2. Studies that Reported Individual Patient Data

Study | Sex | Age | Mass Size (cm ^a^) | Reported Diagnosis | Revised Diagnoses ^b^ | Method of Diagnosis
Tütüncü 1999 ^c^ | ND | ND | 7.7 | adrenocortical carcinoma | adrenal carcinoma | histology
| ND | ND | 6.0 | adrenocortical adenoma: Cushing | adenoma | histology
| ND | ND | 5.9 | pheochromocytoma | pheochromocytoma | histology
| ND | ND | 4.5 | pheochromocytoma | pheochromocytoma | histology
| ND | ND | 4.0 | pheochromocytoma | pheochromocytoma | histology
| ND | ND | 5.6 | pheochromocytoma | pheochromocytoma | histology
| ND | ND | 5.0 | myelolipoma | myelolipoma | histology
| ND | ND | 9.2 | retroperitoneal fibrosis | retroperitoneal fibrosis | histology
| ND | ND | 4.0 | ganglioneuroma | ganglioneuroma | histology
| ND | ND | 7.0 | angiomyelolipoma | angiomyelolipoma | histology
| ND | ND | 11.5 | malignant epithelial carcinoma | malignant epithelial carcinoma | histology
| ND | ND | 15.0 | extraadrenal pheochromocytoma | pheochromocytoma | histology
| ND | ND | 4.2 | myelolipoma | myelolipoma | histology
| ND | ND | 7.0 | pheochromocytoma | pheochromocytoma | histology
| ND | ND | 4.3 | adrenocortical carcinoma | adrenal carcinoma | histology
Corsello 1993 | F | 65 | 4.5 | adrenocortical adenoma | adenoma | histology
| F | 20 | 6.0 | ganglioneuroma | ganglioneuroma | histology
| M | 52 | 3.0 | adrenocortical adenoma | adenoma | histology
| F | 52 | 5.0 | ganglioneuroma | ganglioneuroma | histology
| F | 46 | 5.0 | pheochromocytoma | pheochromocytoma | histology
| F | 35 | 12.0 | pheochromocytoma | pheochromocytoma | histology
| M | 66 | 5.0 | adrenocortical adenoma | adenoma | histology
| M | 52 | 16.0 | pheochromocytoma | pheochromocytoma | histology
| F | 30 | 6.0 | regenerative hepatic nodule | regenerative hepatic nodule | histology
| F | 62 | 3.0 | adrenocortical adenoma | adenoma | histology
| F | 48 | 4.5 | adrenocortical adenoma | adenoma | histology
Guerrero 1985 | F | 44 | 2.8 | adrenocortical adenoma | adenoma | histology
| F | 45 | 7.5 | adrenocortical adenoma | adenoma | histology
| F | 52 | 2.5 | adrenocortical adenoma | adenoma | histology
| M | 58 | 2.5 | adrenocortical adenoma | adenoma | histology
| F | 59 | 3.0 | adrenocortical adenoma | adenoma | histology
| M | 66 | 7.5 | myelolipoma | myelolipoma | histology
| M | 49 | 1.5 | adrenocortical adenoma | adenoma | histology
| F | 79 | 5.0 | adrenocortical adenoma | adenoma | histology
| F | 35 | 2.5 | adrenocortical adenoma | adenoma | histology
| F | 60 | 2.0 | metastatic small cell | metastasis | Histology
Gaboardi 1991 | F | 55 | 3.0 | metastatic small cell | metastasis | histology
| M | 56 | 11.0 | pheochromocytoma | pheochromocytoma | histology
| F | 49 | 5.0 | adenoma | adenoma | histology
| M | 52 | 9.0 | adenoma | adenoma | histology
| M | 45 | 8.0 | adrenal carcinoma | adrenal carcinoma | histology
| F | 45 | 4.0 | Lymphoma | lymphoma | histology
| F | 49 | 5.0 | pheochromocytoma | pheochromocytoma | histology
| M | 61 | 7.0 | myelolipoma | myelolipoma | histology
| M | 71 | 7.0 | myelolipoma | myelolipoma | histology
| M | 58 | 5.0 | adrenal carcinoma | adrenal carcinoma | histology
| F | 59 | 4.0 | metastatic small cell | metastasis | histology
| F | 55 | 6.0 | myelolipoma | myelolipoma | histology
Virkkala 1989 | M | 52 | 1.3 | micro-macronodular hyperplasia | adenoma | histology
| F | 66 | 2.0 | adenoma | adenoma | histology
| F | 75 | 2.5 | micro-macronodular hyperplasia | adenoma | histology
| M | 49 | 2.0 | adenoma | adenoma | histology
| F | 74 | 2.0 | renal angiomyolipoma | renal angiomyolipoma | histology
| F | 46 | 5.0 | atypical adenoma | adenoma | histology
| F | 57 | 6.0 | hematoma | hematoma | histology
| F | 60 | 4.0 | micro-macronodular hyperplasia | adenoma | histology
Andreis 1985 | M | 32 | 7.0 | adenoma | adenoma | histology
| F | 39 | 5.3 | adenoma | adenoma | histology
| F | 61 | 10.0 | carcinoma | adrenal carcinoma | histology
| F | 18 | 12.0 | carcinoma | adrenal carcinoma | histology
| F | 59 | 3.7 | carcinoma | adrenal carcinoma | histology
| M | 54 | 12.0 | carcinoma | adrenal carcinoma | histology
| M | 56 | 4.5 | mielolipoma | myelolipoma | histology
| M | 45 | 3.0 | fecromocitoma | pheochromocytoma | histology
| M | 62 | 10.0 | ganglioneuroma | ganglioneuroma | histology
| F | 60 | 9.0 | istiocitoma fibroso | istiocitoma fibroso | histology
| M | 47 | 5.5 | metastasis | metastasis | histology
| F | 64 | 2.0 | metastasis | metastasis | histology
| M | 48 | 7.0 | metastasis | metastasis | histology
| M | 74 | 13.0 | metastasis | metastasis | histology
| F | 40 | 4.0 | metastasis | metastasis | histology
| M | 51 | 5.5 | metastasis | metastasis | histology
| M | 44 | 8.3 | metastasis | metastasis | histology
| M | 45 | 5.0 | metastasis | metastasis | histology
| F | 50 | 8.0 | metastasis | metastasis | histology
| M | 50 | 6.0 | metastasis | metastasis | histology
| M | 42 | 3.5 | metastasis | metastasis | histology
| M | 72 | 6.6 | metastasis | metastasis | histology
| M | 59 | 2.0 | metastasis | metastasis | histology
| M | 56 | 4.4 | metastasis | metastasis | histology
| M | 45 | 4.2 | metastasis | metastasis | histology
| F | 48 | 4.0 | metastasis | metastasis | histology
Pfister 1987 | F | 59 | 2.5 | benign adrenal cortical mass | adenoma | histology
| F | 66 | 6.0 | myelolipoma | myelolipoma | histology
| F | 62 | 3.0 | cyst | adrenal cyst | histology
| F | 55 | 5.0 | benign adrenal cortical mass | adenoma | histology
| F | 51 | 5.0 | cyst | adrenal cyst | histology
| F | 61 | 2.5 | benign adrenal cortical mass | adenoma | histology
| F | 52 | 4.0 | benign adrenal cortical mass | adenoma | histology
| F | 59 | 5.0 | myelolipoma | myelolipoma | histology
| F | 42 | 2.0 | benign adrenal cortical mass | adenoma | histology
| F | 50 | 8.0 | benign adrenal cortical mass | adenoma | histology
| M | 70 | 6.5 | benign adrenal cortical mass | adenoma | histology
| F | 74 | 6.0 | ganglioneuroma | ganglioneuroma | histology
Flecchia 1995 ^d^ | F | 50 | 4.9 | adenoma | adenoma | histology
| M | 51 | 2.9 | adenoma | adenoma | histology
| M | 30 | 5.2 | adenoma | adenoma | histology
| F | 68 | 4.1 | adenoma | adenoma | histology
| F | 69 | 3.5 | adenoma | adenoma | histology
| M | 74 | 2.8 | adenoma | adenoma | histology
| F | 44 | 5.5 | adenoma | adenoma | histology
| M | 78 | 2.3 | adenoma | adenoma | histology
| F | 44 | 9.6 | adenocarcinoma | adrenal carcinoma | histology
| F | 55 | 5.6 | adenocarcinoma | adrenal carcinoma | histology
Ambrosi 1995 | F | 42 | 3.0 | adenoma | adenoma | histology
| M | 66 | 4.0 | adenoma | adenoma | histology
| F | 39 | 6.0 | carcinoma | adrenal carcinoma | histology
| F | 68 | 2.8 | adenoma | adenoma | histology
| M | 72 | 6.3 | hematoma | hematoma | histology
| M | 68 | 4.6 | myelolipoma | myelolipoma | histology
| M | 64 | 2.0 | adenoma | adenoma | Histology
Osella 1994 | M | 65 | 3.0 | adrenal adenoma | adenoma | histology
Terzolo 1995 | F | 61 | 5.0 | pheochromocytoma | pheochromocytoma | histology
| F | 45 | 15.0 | adrenal carcinoma | adrenal carcinoma | histology
| M | 67 | 4.4 | pheochromocytoma | pheochromocytoma | histology
| F | 49 | 2.5 | adrenal adenoma | adenoma | histology
| F | 55 | 4.0 | adrenal adenoma | adenoma | histology
| M | 76 | 10.0 | ganglionic neoplasia | ganglioneuroma | histology
| M | 46 | 3.0 | adrenal adenoma | adenoma | histology
| F | 69 | 3.5 | adrenal adenoma | adenoma | histology
| F | 60 | 7.0 | adrenal myelolipoma | myelolipoma | histology
| F | 60 | 5.5 | adrenal adenoma | adenoma | histology
| F | 65 | 3.0 | metastasis | metastasis | histology
| F | 79 | 8.0 | adrenal carcinoma | adrenal carcinoma | histology
| M | 49 | 2.0 | adrenal adenoma | adenoma | histology
| M | 59 | 4.0 | adrenal adenoma | adenoma | histology
| F | 19 | 13.0 | adrenal carcinoma | adrenal carcinoma | histology
| F | 42 | 3.7 | adrenal cyst | adrenal cyst | histology
Studies that excluded cancer cases
Terzolo 2000 | F | 61 | 5.0 | pheochromocytoma | pheochromocytoma | surgery/histology
| F | 81 | 6.0 | myelolipoma | myelolipoma | surgery/histology
| F | 60 | 7.0 | myeliolipoma | myelolipoma | surgery/histology
| F | 71 | 3.0 | pheochromocytoma | pheochromocytoma | surgery/histology
| F | 64 | 3.5 | cortical adenoma | adenoma | surgery/histology
| F | 69 | 3.5 | cortical adenoma | adenoma | surgery/histology
| F | 52 | 4.2 | cortical adenoma | adenoma | surgery/histology
| M | 46 | 3.0 | cortical adenoma | adenoma | surgery/histology
| F | 49 | 2.5 | cortical adenoma | adenoma | surgery/histology
| F | 60 | 5.5 | cortical adenoma | adenoma | surgery/histology
| M | 61 | 2.0 | cortical adenoma | adenoma | surgery/histology
| M | 47 | 3.0 | hemorrhagic cyst | adrenal cyst | surgery/histology
| M | 66 | 7.0 | pheochromocytoma | pheochromocytoma | surgery/histology
| F | 55 | 4.0 | cortical adenoma | adenoma | surgery/histology
| M | 65 | 3.0 | cortical adenoma | adenoma | surgery/histology
| F | 42 | 3.7 | cyst | adrenal cyst | surgery/histology
| F | 59 | 4.0 | cortical adenoma | adenoma | surgery/histology
| F | 19 | 13.0 | adrenocortical cancer | adrenal carcinoma | surgery/histology
| F | 45 | 15.0 | adrenocortical cancer | adrenal carcinoma | surgery/histology
| F | 65 | 3.0 | metastasis | metastasis | surgery/histology
Abecassis 1985 | M | 42 | 3.5 | black adenoma | adenoma | surgery
| F | 56 | 4.0 | adrenocortical adenoma | adenoma | surgery
| M | 37 | 4.0 | ganglioneuroma | ganglioneuroma | Surgery
Bondanelli 1997 | M | 55 | 4.2 | adrenal adenoma | adenoma | surgery/histology
| F | 33 | 5.0 | lymphangiomatous cyst | adrenal cyst | surgery/histology
| M | 56 | 4.3 | adrenal adenoma | adenoma | surgery/histology
| M | 50 | 2.1 | pheochromocytoma | pheochromocytoma | surgery/histology
| M | 47 | 2.6 | ganglioneuroma | ganglioneuroma | surgery/histology
| F | 58 | 4.5 | adrenal adenoma | adenoma | surgery/histology
| M | 38 | 3.5 | ganglioneuroma | ganglioneuroma | surgery/histology
| M | 69 | 3.8 | adrenal hyperplasia | adrenal hyperplasia | surgery/histology
| F | 55 | 2.5 | hemorrhage | hemorrhage | surgery/histology
| F | 37 | 4.5 | adrenal adenoma | adenoma | surgery/histology
| F | 46 | 12.0 | adrenal carcinoma | adrenal carcinoma | surgery/histology
| M | 51 | 8.0 | myelolipoma | myelolipoma | surgery/histology
| F | 75 | 10.0 | pheochromocytoma | pheochromocytoma | surgery/histology
| F | 66 | 2.5 | adrenal adenoma | adenoma | surgery/histology
Masumori 1998 | M | 47 | 2.7 | adrenocortical adenoma | adenoma | histology
| M | 56 | 2.5 | adrenocortical adenoma | adenoma | histology
| M | 41 | 8.2 | ganglioneuroma | ganglioneuroma | histology
| M | 46 | 2.2 | pheochromocytoma | pheochromocytoma | histology
| F | 66 | 7.0 | neurinoma | neurinoma | histology

ND = no data; F, female; M, male

a Includes the larger dimension for bilateral tumors; the smaller dimension if 2 dimensions used for singular tumor.

b For purposes of standardizing data for summary results in Tables 2-5.

c Inclusion criteria of masses ≥ 4 cm.

d Study did not include individual patient data for other diagnoses (8) than adrenal adenomas and adrenal cortical carcinomas.

### Question 1.2 What are the prevalence rates for the various causes of inapparent adrenal masses? Are there differences in the rates among the initial diagnostic tests used?

Because incidentaloma is not a disease entity, the prevalence of incidentaloma will vary according to the inclusion criteria of the study. In the general population setting, we found one study that used transabdominal US screening in general health examination and reported about 40 adrenal or retroperitoneal masses out of 41,357 subjects (prevalence of 0.1 percent) (Masumori, Adachi, Noda, et al., 1998). Eleven masses were confirmed to be adrenal origin with CT (prevalence of 0.027 percent). The prevalence of incidentaloma was reported to be 0.6 percent in a study of 2,200 patients undergoing upper abdominal CT for specific indications (Glazer, Weyman, Sagel, et al., 1982).

Tables 3–6 are summaries of data presented in Table 2 analyzed according to the distribution of diagnoses by tumor size, age, and sex. Table 3 incorporated data from the 14 studies that comprised a total of 170 diagnoses as determined by the histology. Six of these studies either have unusual inclusion/exclusion criteria, or missing data from certain diagnoses that would skew the distribution of diagnoses. Tütüncü and Gedik (1999) included only incidentalomas with size greater than or equal to 4 cm and did not report data on sex and age. Flecchia, Mazza, Carlini, et al. (1995) did not give data for eight patients but reported data for adenomas and adrenocortical carcinomas. Four studies (Abecassis, McLoughlin, Langer, et al., 1985; Bondanelli, Campo, Trasforini, et al., 1997; Masumori, Adachi, Noda, et al., 1998; Terzolo, Ali, Osella, et al., 2000) excluded patients with known extra-adrenal malignancies. By excluding the studies with more unusual inclusion criteria, Table 4 represents a more generalizable subset of all the studies. Comparing the distribution of pathologies analyzed in Table 3 with those in Table 4, the percentage of metastases from increased from 12 to 19 percent.

Table 3. Distribution of Diagnoses by Tumor Size - All Studies (from Table 2)

| Tumor Size
| < 2 – 4 cm | | 4.1 – 6 cm | | > 6 cm | | Total
Final Diagnosis | N | % | N | % | N | % | N | %
Adenoma | 45 | 62 | 20 | 38 | 5 | 11 | 70 | 41
Adrenal carcinoma | 1 | 1.4 | 4 | 8 | 12 | 27 | 17 | 10
Adrenal cyst | 4 | 5.5 | 2 | 4 | | | 6 | 3.5
Adrenal hyperplasia | 1 | 1.4 | | | | | 1 | 0.6
Angiomyelolipoma | | | | | 1 | 2 | 1 | 0.6
Ganglioneuroma | 4 | 5.5 | 3 | 6 | 3 | 7 | 10 | 5.9
Hematoma | | | 1 | 2 | 1 | 2 | 2 | 1.2
Hemorrhage | 1 | 1.4 | | | | | 1 | 0.6
Istiocitoma fibroso (Italian) | | | | | 1 | 2 | 1 | 0.6
Lymphoma | 1 | 1.4 | | 0 | | | 1 | 0.6
Malignant epithelial carcinoma | | | | | 1 | 2 | 1 | 0.6
Metastases | 10 | 14 | 6 | 11 | 5 | 11 | 21 | 12
Myelolipoma | | | 8 | 15 | 6 | 14 | 14 | 8.2
Neurinoma | | | | | 1 | 2 | 1 | 0.6
Pheochromocytoma | 5 | 6.8 | 8 | 15 | 7 | 16 | 20 | 12
Regenerative hepatic nodule | | | 1 | 2 | | | 1 | 0.6
Renal angiomyolipoma | 1 | 1.4 | | | | | 1 | 0.6
Retroperitoneal fibrosis | | | | | 1 | 2 | 1 | 0.6
Total | 73 | 43% | 53 | 31% | 44 | 26% | 170 | 100%

N, number of subjects

Table 4. Distribution of Diagnoses by Tumor Size - Generalizable Studies ^a^ (from Table 2)

| Tumor Size
| < 2 – 4 cm | | 4.1 – 6 cm | | > 6 cm | | Total
Final Diagnosis | N | % | N | % | N | % | N | %
Adenoma | 28 | 65 | 9 | 28 | 5 | 18 | 42 | 41
Adrenal carcinoma | 1 | 2.3 | 2 | 6.3 | 7 | 25 | 10 | 9.7
Adrenal cyst | 2 | 4.7 | 1 | 3.1 | | | 3 | 2.9
Ganglioneuroma | | | 3 | 9.4 | 2 | 7.1 | 5 | 4.9
Hematoma | | | 1 | 3.1 | 1 | 3.6 | 2 | 1.9
Istiocitoma fibroso (Italian) | | | | | 1 | 3.6 | 1 | 1.0
Lymphoma | 1 | 2.3 | | | | | 1 | 1.0
Metastases | 9 | 21 | 6 | 19 | 5 | 18 | 20 | 19
Myelolipoma | | | 5 | 16 | 4 | 14 | 9 | 8.7
Pheochromocytoma | 1 | 2.3 | 4 | 13 | 3 | 11 | 8 | 7.8
Regenerative hepatic nodule | | | 1 | 3.1 | | | 1 | 1.0
Renal angiomyolipoma | 1 | 2.3 | | | | | 1 | 1.0
Total | 43 | 42% | 32 | 31% | 28 | 27% | 103 | 100%

N, number of subjects

a Excluding studies with inclusion/exclusion criteria or missing data that limits generalixability: Tütüncü et. al., 1999 included mass ≥ 4 cm; Flecchia et. al., 1995 did not give individual patient data for cases (8) other than adenomas and adrenocortical carcinomas; four studies (Abecassis 1985, Bondanelli 1997, Masumori 1998, Terzolo 2000) with exclusion criteria of patients with known extra-adrenal malignancies.

Table 5. Distribution of Diagnoses by Age - Generalizable Studies^a^ (from Table 2)

| Age Ranges (Years)
| | | | | | | | Total
Final Diagnosis | 11–20 | 21–30 | 31–40 | 41–50 | 51–60 | 61–70 | 71+ | N | %
Adenoma | | | 3 | 13 | 13 | 11 | 2 | 42 | 41
Adrenal carcinoma | 2 | | 1 | 2 | 3 | 1 | 1 | 10 | 9.7
Adrenal cyst | | | | 1 | 1 | 1 | | 3 | 2.9
Ganglioneuroma | | 1 | | | 1 | 1 | 2 | 5 | 4.9
Hematoma | | | | 1 | | | 1 | 2 | 1.9
Istiocitoma fibroso | | | | | 1 | | | 1 | 1.0
Lymphoma | | | | 1 | | | | 1 | 1.0
Metastases | | | 1 | 9 | 6 | 2 | 2 | 20 | 19
Myelolipoma | | | | | 4 | 4 | 1 | 9 | 8.7
Pheochromocytoma | | | 1 | 3 | 2 | 2 | | 8 | 7.8
Regenerative hepatic nodule | | 1 | | | | | | 1 | 1.0
Renal angiomyolipoma | | | | | | | 1 | 1 | 1.0
Total, N | 2 | 2 | 6 | 30 | 31 | 22 | 10 | 103
% | 1.9% | 1.9% | 5.8% | 29% | 30% | 21% | 9.7% | | 100%

N, number of subjects

a Excluding studies with inclusion/exclusion criteria or missing data that limits generalixability: Tütüncü et. al., 1999 included mass ≥ 4 cm; Flecchia et. al., 1995 did not give individual patient data for cases (8) other than adenomas and adrenocortical carcinomas; four studies (Abecassis 1985, Bondanelli 1997, Masumori 1998, Terzolo 2000) with exclusion criteria of patients with known extra-adrenal malignancies.

Table 6. Distribution of Diagnoses by Sex - Generalizable Studies^a^ (from Table 2)

Final Diagnosis | Female | | Male | | Total | | Diagnoses in Females
| N | % | N | % | N | % | %
Adenoma | 27 | 44 | 15 | 36 | 42 | 41 | 64
Adrenal carcinoma | 7 | 12 | 3 | 7.1 | 10 | 9.7 | 70
Adrenal cyst | 3 | 4.9 | 0 | 0 | 3 | 2.9 | 100
Ganglioneuroma | 3 | 4.9 | 2 | 4.8 | 5 | 4.9 | 60
Hematoma | 1 | 1.6 | 1 | 2.4 | 2 | 1.9 | 50
Istiocitoma fibroso (Italian) | 1 | 1.6 | 0 | 0 | 1 | 1.0 | 100
Lymphoma | 1 | 1.6 | 0 | 0 | 1 | 1.0 | 100
Metastases | 8 | 13 | 12 | 29 | 20 | 19 | 40
Myelolipoma | 4 | 6.6 | 5 | 12 | 9 | 8.7 | 44
Pheochromocytoma | 4 | 6.6 | 4 | 9.5 | 8 | 7.8 | 50
Regenerative hepatic nodule | 1 | 1.6 | 0 | 0 | 1 | 1.0 | 100
Renal angiomyolipoma | 1 | 1.6 | 0 | 0 | 1 | 1.0 | 100
Total | 61 | 59% | 42 | 41% | 103 | 100% | 60%

N, number of subjects

a Excluding studies with inclusion/exclusion criteria or missing data that limits generalixability: Tütüncü et. al., 1999 included mass ≥ 4 cm; Flecchia et. al., 1995 did not give individual patient data for cases (8) other than adenomas and adrenocortical carcinomas; four studies (Abecassis 1985, Bondanelli 1997, Masumori 1998, Terzolo 2000) with exclusion criteria of patients with known extra-adrenal malignancies.

Using data in Table 4 as representative of studies with a more generalizable definition of incidentaloma, the prevalence of adenoma among incidentalomas was 41 percent, 19 percent for metastasis, 10 percent for adrenocortical carcinoma, 9 percent for myelolipoma, and 8 percent for pheochromocytoma. Adrenal cyst and other mostly benign tumors comprised the remainder of the pathologies.

The question about differences in the spectrum of pathologies identified by different imaging modalities cannot be answered with current data. In most of the studies, the adrenal incidentalomas were discovered with CTs. There were some studies that reported incidentalomas discovered with either US or MRI or CT, but most of the studies do not separately report the data that would allow meaningful subgroup analyses across studies.

### Question 1.3 What is the relationship of the age and sex of the patient with the likelihood of having a particular pathology?

Sixty percent of the incidentalomas occurred between the ages of 41 and 60 years (Table 5). In this age range, the predominant diagnoses were adenoma at 45 percent, followed by metastases at 21 percent. Ninety percent of the incidentalomas were found in patients between 31 to older than 70 years of age. The predominant diagnoses were basically the same with 45 percent with adenoma and 20 percent with metastases. Overall, approximately 64 percent of the adenomas cases and 70 percent of the adrenal carcinomas cases were found in females whereas 60 percent of metastases cases were reported in males (Table 6).

### Question 1.4 What is the relationship of the size of the mass with the likelihood of having a particular pathology?

Table 4 listed the studies with the most generalizable definition of incidentaloma. The limited data suggests that for tumors 4 cm or less, 65 percent were adenomas and approximately 21 percent were metastases. As tumors increased in size from 4 cm or less to greater than 6 cm, the number of adrenal carcinomas increased from 2.3 to 25 percent whereas, adenomas decreased from 65 to 18 percent, respectively. In addition, the percentage of metastases decreased slightly from 21 to 18 percent.

### Question 2. What is the diagnostic accuracy (sensitivity, specificity) of the evaluation modalities (FNA/biopsy, CT, MRI, US, biochemical tests) used to differentiate adrenal masses (adrenal carcinoma, pheochromocytoma, adenoma, adrenal hyperplasia, etc.)? (Tables 7–20, Evidence Table 2)

We reviewed 32 studies that reported diagnostic performance of tests to evaluate adrenal masses. These studies were limited to those that met our search criteria for this report. Ten of these evaluated CT, eight evaluated MRI, and six evaluated scintigraphy. One each evaluated US and positron emission tomography (PET), nine evaluated FNA, and four evaluated biochemical tests. There were four studies that reported on only subjects with adrenal incidentalomas. The remainder included subjects with adrenal incidentalomas, adrenal masses found during extraadrenal cancer evaluation, symptoms suggestive of adrenal disease, incidentally discovered adrenal adenomas only, or adrenal masses (no further description). In general, studies evaluated the diagnostic accuracy of tests to differentiate malignant disease from non-malignant disease. Studies did not separate out malignant adrenal disease (e.g., cortical cancer, malignant pheochromocytoma) from metastatic disease even though prior probability of malignancy and diagnostic performance may differ for these different patients. Furthermore, studies used a variety of reference standards to diagnose adrenal masses. Most studies used a combination of FNA, surgical biopsy, and follow-up imaging of varying durations. Histology was performed in about half the subjects overall. The details of the reference standard methods are provided in Evidence Table 2. There were no obvious associations between test performance and reference standard methodology. Overall, one study was graded good quality (A); 16 were graded fair (B); and 15 were graded poor (C).

Table 7. Unenhanced CT to Diagnose Adrenal Mass

Author, Year | Subjects (Masses), N | Incidentatloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Threshold / Definition of Positive Test | Test Performance | | Study Quality^a^
| | | | | | | | | Sens, % | Spec, %
Lee, 1991 ^b^ | (66) | | | • | | | 42 | 0 HU | 100 | 47 | B
McNicholas, 1995 | (37) | | • | | | | 51 | 0 HU | 100 | 72 | C
Lee, 1991 ^b^ | (66) | | | • | | | 42 | 10 HU | 96 | 79 | B
Szolar, 1997 | (78) | | | • | | | 47 ^c^ | 11 HU | 100 | 61 | C
van Erkel, 1994 ^d^ | (44) | | • | • | | | 45 ^c^ | 16.5 HU | 95 | 100 | B
Szolar, 1997 | (78) | | | • | | | 47 ^c^ | 18 HU | 92 | 93 | C
McNicholas, 1995 | (37) | | • | | | | 51 | 20 HU | 68 | 100 | C
Szolar, 1997 | (78) | | | • | | | 47 ^c^ | 21 HU | 89 | 100 | C
Lee, 1991 | (66) | | | • | | | 42 | Subjective criteria ^e^ | ~82 ^d^ | ~65 ^d^ | B
Lee, 1991 | (66) | | | • | | | 42 | Density | AUC = 0.91±0.04 | | B
van Erkel, 1994 | (44) | | • | • | | | 45 ^c^ | Density | AUC = 0.99 | | B
Lee, 1991 | (66) | | | • | | | 42 | Subjective ^e^ | AUC = 0.84±0.05 | | B

Studies listed in order of threshold value, then study size.

Studies with data on multiple thresholds are included for each threshold.

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity; HU, Hounsfield units; AUC, area under the receiver operating characteristics curve.

a See Methods, Question 2, Study Quality.

b Exact attenuation values reported graphically for all masses. The thresholds included in the table are those explicitly reported in the article as being “optimal”.

c Positive reference standard is non-adenoma, including other benign lesions.

d Exact attenuation values reported graphically for all masses. The threshold included in the table is the one explicitly reported in the article as being “optimal.”

e Masses were rated on a scale of 0 to 6 using subjective criteria based on size, presence of extraadrenal lesions, internal consistency of the lesion, local invasion, calcification, distinctness and smoothness of margins, and CT attenuation. Sensitivity and specificity for each grade were plotted on ROC curve. The values included in the table are approximations of the score with relatively high sensitivity and fair specificity.

Table 20. Summary of Diagnostic Tests to Diagnose Adrenal Mass

Diagnostic Test | Number of Studies | Number of Subjects | Incidentaloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Sensitivity Range, % | Specificity Range, % | Quality^a^
| | | | | | | | | | A | B | C
CT | 10 | 467 | • | • | • | | • | 32–100 | 13–100 | 0 | 5 | 5
Unenhanced (Density) | 4 | 197 | | • | • | | | 68–100 | 47–100 | 0 | 2 | 2
Enhanced (Density) | 3 | 116 | • | | • | | | 92–100 | 33–58 | 0 | 1 | 2
Delayed Enhanced | 2 | 67 | | | • | | | 83–100 | 91–100 | 0 | 0 | 2
Combined Enhanced / Unenhanced | 3 | 177 | • | • | | | • | 32–92 | 50–100 | 0 | 1 | 2
Size | 6 | 246 | | • | • | | | 64–100 | 13–100 | 0 | 3 | 3
MRI ^ b ^ | 8 | 302 | • | • | • | | • | 50–100 | 24–100 | 0 | 7 | 1
Unenhanced (Mass:Spleen) | 4 | 168 | • | • | | | • | 84–100 | 78–100 | 0 | 3 | 1
Unenhanced (Mass:Fat) | 3 | 109 | | • | • | | | 50–100 | 57–95 | 0 | 3 | 0
Unenhanced (Mass:Liver) | 3 | 103 | • | • | • | | • | 65–100 | 65–100 | 0 | 3 | 0
Unenhanced (Mass:Muscle) | 2 | 75 | • | • | • | | • | 90–100 | 71–89 | 0 | 2 | 0
Unenhanced (Combination) | 1 | 25 | | • | | | | 100 | 24 | 0 | 1 | 0
Combined Enhanced / Unenhanced | 1 | 44 | | • | | | | 75 | 75 | 0 | 1 | 0
Plain CT & MRI | 1 | 33 | | • | | | | 100 | 94 | 0 | 1 | 0
Scintigraphy | 6 | 387 | • | • | | | | 71–100 | 50–100 | 1 | 4 | 1
US | 1 | 54 | • | | | | | 67 | 52 | 0 | 0 | 1
PET | 1 | 20 | • | • | | | | 100 | 100 | 0 | 1 | 1
FNA | 9 | 515 | • | • | • | | • | 80–100 | 83–100 | 0 | 2 | 7
| | | | | | | | Accuracy: 90–100
Biochemistry ^ c ^ | 3 | 145 | • | | | • | | | | 0 | 1 | 2
DHEAS (Malignancy) | 1 | 84 | • | | | | | 100 | 38 | 0 | 0 | 1
DHEAS (UU ^d^) | 1 | 26 | | | | • | | 38 | 62 | 0 | 0 | 1
ACTH (UU ^d^) | 1 | 29 | | | | • | | 29 | 93 | 0 | 0 | 1
Urinary Free Cortisol (UU ^d^) | 1 | 35 | | | | • | | 0 | 79 | 0 | 0 | 1
O/N Dex Supp AM Cortisol (UU ^d^) | 2 | 61 | | | | • | | 31–100 | 67–94 | 0 | 0 | 2
Low-dose Dex Supp Day 2 Cortisol (UU ^d^) | 1 | 11 | | | | • | | 50 | 80 | 0 | 0 | 1
Low-dose Dex Supp Day 2 Urinary Free Cortisol (UU ^d^) | 1 | 15 | | | | • | | 33 | 83 | 0 | 0 | 1

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity; UU, unilateral uptake on scintigraphy;. O/N, overnight; Dex Supp, dexamethasone suppression test.

a See Methods, Question 2, Study Quality.

b Text in parentheses indicates which signal intensity ratio used

c Text in parentheses indicates outcome of interest (reference standard positive)

d DHEAS used to predict unilateral uptake (UU) on scintigraphy

Although the outcomes of interest for calculating sensitivity and specificity vary among studies, in this report sensitivity refers to the percentage of subjects with an adrenal malignancy (whether adrenal or metastatic in origin) with a positive test, and specificity refers to the percentage of subjects without adrenal malignancy with a negative test, except where noted.

#### Computed Tomography (Table 7–11)

There were ten studies that evaluated CT. Four of these evaluated unenhanced CT, three evaluated enhanced CT, two studies evaluated delayed enhanced CT, three studies evaluated combined enhanced and unenhanced CT, and six evaluated mass size on CT.

Table 11. CT (Size of Adrenal Mass) to Diagnose Adrenal Mass

Author, Year | Subjects (Masses), N | Incidentatloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Threshold / Definition of Positive Test | Test Performance | | Study Quality^a^
| | | | | | | | | Sens, % | Spec, %
Lee, 1991 ^c^ | (66) | | | • | | | 42 | >1.5 cm | 93 | 16 | B
Hussain, 1986 ^d^ | 26 (30) | | • | | | | 69 (73) | >1.5 cm | 83 (86) | 13 (13) | C
Szolar, 1997 | (78) | | | • | | | 47 ^e^ | 2.5 cm ^f^ | 84 | 66 | C
Lee, 1991 ^c^ | (66) | | | • | | | 42 | ≥2.5 cm | 79 | 84 | B
Singer, 1994 | (24) | | | • | | | 50 | 2.5 cm ^f^ | 100 | 58 | B
Hussain, 1986 ^d^ | 26 (30) | | • | | | | 69 (73) | >2.5 cm | 72 (73) | 75 (75) | C
Hussain, 1986 ^d^ | 26 (30) | | • | | | | 69 (73) | >3.0 cm | 64 (67) | 100 (100) | C
McNicholas, 1995 | (37) | | • | | | | 51 | ≥ 3 cm | 83 | 80 | B
van Erkel, 1994 ^g^ | (44) | | • | • | | | 45 ^e^ | 3.1 cm ^f^ | 85 | 83 | B
Lee, 1991 | (66) | | | • | | | 42 | Size | AUC = 0.84±0.05 | | B
Korobkin, 1996 | (51) | | | • | | | 20 | Size | AUC = 0.72±0.09 | | C
van Erkel, 1994 | (44) | | • | • | | | 45 ^e^ | Size | AUC = 0.90 | | B
Singer, 1994 | (24) | | | • | | | 50 | Size | AUC = 0.78±0.09 | | B

Studies listed in order of threshold value, then study size.

Study with data on multiple thresholds is included for each threshold.

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity; HU, Hounsfield units; AUC, area under the receiver operating characteristics curve.

a Range of sizes listed (greater than, or greater or equal to) is definition of positive test (for malignant mass), except where noted.

b See Methods, Question 2, Study Quality.

c Exact sizes were graphically reported for all masses. The thresholds included in the table are those explicitly reported in the article.

d Data reported for both subjects and masses (in parentheses). Sensitivity and specificity were calculated from figure at arbitrary thresholds. For subjects with two masses, only the larger mass was included when calculating subject-level test performance.

e Positive reference standard is non-adenoma, including other benign lesions.

f Unclear whether masses of exactly threshold level were considered positive or negative for malignant mass.

g Exact sizes were reported graphically for all masses. The threshold included in the table is the one explicitly reported in the article.

##### Unenhanced CT (Table 7)

Four studies evaluated unenhanced CT to differentiate adrenal masses using various definitions of a positive CT. Of these four, no study explicitly included only subjects with incidentalomas. Two included subjects with extraadrenal cancer; two included subjects with adrenal masses. One included subjects from both populations. Three studies used CT to differentiate malignant disease from benign; Two tested CT to differentiate adenomas from non-adenomas, including other benign lesions. Malignancy (or non-adenoma) prevalence ranged from 42 to 69 percent. Four studies used density measurements thresholds, in Hounsfield units (HU), but reported test performance data only for total adrenal masses, not for patients. One study defined positive CTs using morphological criteria (see Table 7, footnote e). Perfect specificity was achieved at higher HU thresholds (20 and 21 HU) with moderate sensitivity (68 and 89 percent). Two studies found that using thresholds of 16.5 and 18 HU achieved both high sensitivity and specificity (92 to 95 percent, and 93 to 100 percent, respectively). Three studies performed ROC analysis of different parameters to diagnose masses and compared the areas under the ROC curves. Lee, Hahn, Papanicolaou, et al. (1991) compared attenuation thresholds, subjective criteria, and size and concluded that attenuation thresholds had the best performance to diagnose adrenal malignancy. Likewise, McNicholas, Lee, Mayo-Smith, et al. (1995) compared attenuation thresholds and size and concluded that attenuation thresholds had the better performance to diagnose adrenal malignancy. Van Erkel, van Gils, Lequin, et al., (1994) concluded that attenuation thresholds had better test performance to diagnose non-adenomas than either size measurements or T2 measurements on MRI.

##### Enhanced CT (Table 8)

Three studies evaluated enhanced CT to differentiate malignant from benign adrenal masses, using various definitions of a positive CT. One study included only subjects with incidentalomas; two included all subjects with adrenal masses. Malignancy prevalence ranged from 20 to 50 percent. Two studies reported test performance based on total masses; the other reported test performance based on patients. Two studies found excellent sensitivity but poor specificity at low attenuation values. The study that used mass homogeneity had similar findings. Two studies compared the areas under ROC curves of attenuation values on enhanced CT to other parameters. Singer, Obuchowski, Einstein, et al. (1994) found that attenuation values on enhanced CT and mass size were both equally useful to diagnose adrenal malignancy. Korobkin, Brodeur, Francis, et al. (1996) found that attenuation values on enhanced CT were inferior to delayed enhanced CT.

Table 8. Enhanced CT to Diagnose Adrenal Mass

Author, Year | Subjects (Masses), N | Incidentatloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Threshold / Definition of Positive Test | Test Performance | | Study Quality^a^
| | | | | | | | | Sens, % | Spec, %
Singer, 1994 | (24) | | | • | | | 50 | 0 HU | 100 | 33 | B
Singer, 1994 | (24) | | | • | | | 50 | 10 HU | 92 | 58 | B
Korobkin, 1996 ^b^ | (51) | | | • | | | 20 | 38 HU ^b^ | 100 | 37 | C
Fontana, 1999 | 54 | • | | | | | 22 | Inhomogeneous ^c^ | 92 | 54 | C
Korobkin, 1996 | (51) | | | • | | | 20 | Density | AUC = 0.78±0.09 | | C
Singer, 1994 | (24) | | | • | | | 50 | Density | AUC = 0.83±0.10 | | B

Studies listed in order of threshold value, then definitions of positive test, then study size.

Study with data on multiple thresholds is included for each threshold.

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity; HU, Hounsfield units; AUC, area under the receiver operating characteristics curve.

a See Methods, Question 2, Study Quality.

b Complete attenuation data reported for all masses. Test performance data listed are those explicitly reported in article.

c Positive scans (for malignancy): inhomogeneous. Negative scans: hypodense. Based on radiologists' descriptions (retrospectively).

##### Delayed Enhanced CT (Table 9)

Two studies evaluated delayed enhanced CT to differentiate either malignant masses from benign or adrenal adenomas from non-adenomas. Both studies included patients with adrenal masses. Twenty percent of masses were malignant in the first study; 47 percent were non-adenomas in the second. Both reported test performance based on total masses. Szolar and Kammerhuber (1997) found that enhanced CT delayed 180 seconds after IV contrast injection yielded good to excellent test performance using thresholds between 64 and 70 HU. Sensitivity ranged from 83 to 100 percent; specificity ranged from 100 to 91 percent, respectively, to differentiate non-adenomas from adenomas. Enhanced CT delayed 30 minutes after IV contrast injection resulted in perfect test performance. Korobkin, Brodeur, Francis, et al. (1996) also found excellent test performance when CT was delayed 45 to 75 minutes after IV contrast injection. Sensitivity was 100 percent; specificity was 95 percent to differentiate malignant from benign masses. As noted above, this study also found that using delayed enhanced CT was superior to immediate enhanced CT in order to diagnose adrenal malignancy.

Table 9. Delayed Enhanced CT to Diagnose Adrenal Mass

Author, Year | Subjects (Masses), N | Incidentatloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Threshold / Definition of Positive Test | Test Performance | | Study Quality^a^
| | | | | | | | | Sens, % | Spec, %
Szolar, 1997 | (47) | | | • | | | 47 ^b^ | 64 HU (180 sec) | 100 ^b^ | 91 ^b^ | C
Szolar, 1997 | (47) | | | • | | | 47 ^b^ | 68 HU (180 sec) | 92 ^b^ | 96 ^b^ | C
Szolar, 1997 | (47) | | | • | | | 47 ^b^ | 70 HU (180 sec) | 83 ^b^ | 100 ^b^ | C
Szolar, 1997 | (43) | | | • | | | 47 ^b^ | 40 HU (30 min) | 100 ^b^ | 100 ^b^ | C
Korobkin, 1996 | (51) | | | • | | | 20 | 30 ^c^ (45–75 min) | 100 | 95 | C
Korobkin, 1996 | (51) | | | • | | | 20 | Density | AUC = 0.99±0.01 | | C

Studies listed in order of duration of delay, then by threshold

Study with data on multiple thresholds and methods is included for each threshold.

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity; HU, Hounsfield units; AUC, area under the receiver operating characteristics curve.

a See Methods, Question 2, Study Quality.

b Positive reference standard is non-adenoma, including other benign lesions.

c Complete attenuation data reported for all masses. Test performance data listed are those explicitly reported in article.

##### Combination Unenhanced and Enhanced CT (Table 10)

Three studies evaluated the combination of unenhanced and enhanced CT to differentiate malignant from benign adrenal masses. They evaluated 84 subjects with incidentalomas and 23 with clinically suspected adrenal masses. Using a definition of malignant CT pattern (see Table 10, footnote b), test performance was high. Krestin, Freidmann, Fishbach, et al. (1991) included subjects with extraadrenal cancer and evaluated test performance based on total masses. Using definitions of malignant and equivocal CT patterns (see Table 10, footnotes c, d), test performance was poor. Hussain, Belldegrun, Seltzer, et al. (1986), an older study that reported data on various morphological characteristics of masses (see Table 10, footnotes g,h), found that each set of criteria resulted in poor test performance.

Table 10. Combined Unenhanced and Enhanced CT to Diagnose Adrenal Mass

Author, Year | Subjects (Masses), N | Incidentaloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Definition of Positive Test | Test Performance | | Study quality^a^
| | | | | | | | | Sens, % | Spec, %
Terzolo, 2000 | 107 | • | | | | • | 11 | Malignant ^b^ | 92 | 89 | C
Krestin, 1991 | (52) | | • | | | | 54 | Malignant ^c^ or equivocal criteria ^d^ | 75 | 75 | B
Krestin, 1991 | (40) ^e^ | | • | | | | 60 | Malignant criteria ^c^ | 71 | 75 | B
Hussain, 1986 ^f^ | 26 (30) | | • | | | | 69 (73) | Heterogeneous ^g^ | 33 (32) | 100 (100) | C
Hussain, 1986 ^f^ | 26 (30) | | • | | | | 69 (73) | Hypodense or Heterogeneous ^g^ | 56 (50) | 50 (50) | C
Hussain, 1986 ^f^ | 26 (30) | | • | | | | 69 (73) | Increase ≥ 20 HU ^h^ | 44 (45) | 100 (100) | C

Studies listed in order of study size.

Study with data on multiple test criteria is included for each criterion.

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity.

a See Methods, Question 2, Study Quality.

b Malignant pattern defined as mass size > 4.0 cm, non-homogeneous content with irregular shape and margins, possibly with infiltration of surrounding tissues or distant metastases or both. Benign pattern defined as unenhanced attenuation ≤ 10 HU and enhanced attenuation ≤ 30 HU, size < 4.0 cm, round or oval shape, homogeneous content and well-defined margins. If not all characteristics of benign pattern were met, lesion described as inconclusive. Test performance based on malignant versus benign and inconclusive.

c Malignant criteria defined as 3 or more of: size > 3 cm, attenuation > 15 HU, blurred margins, irregular shape, and inhomogeneous enhancement.

d Equivocal criteria: Neither meets criteria for malignant criteria (footnote c) nor for benign criteria (3 or more of: size < 3 cm, attenuation < 10 HU on unenhanced CT, sharp borders, triangular or rounded shape, and homogeneous enhancement).

e Subjects with equivocal CT criteria excluded.

f Data reported for both subjects and masses (in parentheses).

g The numbers of subjects (and masses) with malignant and benign masses with different morphological features were listed, including no contrast enhancement, homogeneous contrast enhancement, and non-homogeneous contrast enhancement. Contrast enhancement was defined as an increase in attenuation values of at least 20 HU in enhanced compared to unenhanced CT. Explicit test performance values were not calculated in the study. Test performance values for both subjects and masses (in parentheses) listed in table are those calculated using enhancement (homogeneous or heterogenous) versus no enhancement.

h The numbers of subjects (and masses) with malignant and benign masses with different morphological features were listed, including uniform soft tissue mass density, uniform hypodense mass density, and non-uniform heterogeneous mass density. Explicit test performance values were not calculated in the study. Test performance values for both subjects and masses (in parentheses) listed in table are those calculated using different criteria.

##### Adrenal Mass Size Measured by CT (Table 11)

Six studies evaluated adrenal mass size on CT to differentiate adrenal masses using various size thresholds. No study explicitly included only subjects with incidentalomas. Two included subjects with extraadrenal cancer; three included subjects with adrenal masses. One included subjects from both populations. Two studies tested mass size on CT to differentiate non-adenomas, including other benign lesions, from adenomas. Malignancy (or non-adenoma) prevalence ranged from 42 to 69 percent. Five studies reported test performance based on total adrenal masses; one reported test performance data based on both subjects and masses. Smaller size thresholds corresponded to higher sensitivity and lower specificity, and vice versa. No study found a size threshold that yielded both high sensitivity and specificity. As noted above, Singer, Obuchowski, Einstein, et al. (1994) found size threshold and attenuation value on enhanced CT to be equally good parameters to diagnose malignancy. Lee, Hahn, Papanicolaou, et al. (1991) and McNicholas, Lee, Mayo-Smith, et al. (1995) and van Erkel, van Gils, Lequin, et al. (1994) found size measurement to be an inferior parameter to diagnose malignancy or non-adenomas, respectively.

#### Magnetic Resonance Imaging (Tables 12, 13)

There were eight studies that evaluated MRI, all of them unenhanced MRI. One study also evaluated combined unenhanced and enhanced MRI.

Table 12. Unenhanced MRI to Diagnose Adrenal Mass

Author, Year | Subjects (Masses), N | Incidentatloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Threshold / Definition of Positive Test | Test Performance | | Study Quality^a^
| | | | | | | | | Sens, % | Spec, %
Schwartz, 1997 | 54 | | • | | | | 43 | M:S 0.55 | 100 | 94 | B
McNicholas, 1995 | (37) | | • | | | | 51 | M:S 0.70 | 100 | 78 | C
Mayo-Smith, 1995 | (46) | | • | | | | 38 | T1 M:S 0.75 | 100 | 82 | B
McNicholas, 1995 | (37) | | • | | | | 51 | M:S 0.75 | 95 | 83 | C
Bilbey, 1995 | (41) | • | • | | | • | 54 ^d^ | T1 M:S 0.80 | 100 | 100 | B
McNicholas, 1995 | (37) | | • | | | | 51 | M:S 0.80 | 84 | 89 | C
Krestin, 1991 | (40) | | • | | | | 58 | M:F 2.0 ^c^ | 96 | 88 | B
Chezmar, 1988 | (35) | | | • | | | 34 | T1 M:F 0.42 | 100 | 57 | B
Chezmar, 1988 | (35) | | | • | | | 34 | T1 M:F 0.35 | 75 | 95 | B
Chezmar, 1988 | (17) | | | • | | | 47 | T2 M:F 0.63 | 100 | 67 | B
Chezmar, 1988 | (17) | | | • | | | 47 | T2 M:F 0.75 | 50 | 89 | B
van Erkel, 1994 ^e^ | (44) | | • | • | | | 45 ^d^ | T2 M:F 0.85 | 85 | 87 | B
Chezmar, 1988 | (35) | | | • | | | 34 | T1 M:L 0.78 | 100 | 65 | B
Chezmar, 1988 | (35) | | | • | | | 34 | T1 M:L 0.71 | 75 | 100 | B
Bilbey, 1995 | (41) | • | • | | | • | 54 ^d^ | T1 M:L 0.60 | 100 | 89 | B
van Erkel, 1994 ^e^ | (44) | | • | • | | | 45 ^d^ | T2 M:L 1.75 | 65 | 75 | B
Bilbey, 1995 | (41) | • | • | | | • | 54 ^d^ | T1 M:Ms 0.58 | 100 | 89 | B
van Erkel, 1994 ^e^ | (44) | | • | • | | | 45 ^d^ | T2 M:Ms 2.70 | 90 | 71 | B
Burt, 1994 | 25 | | • | | | | 19 | Combination ^f^ | 100 | 24 | B
Mayo-Smith, 1995 | (46) | | • | | | | 38 | T1 M:S | AUC = 0.97 | | B
Mayo-Smith, 1995 | (46) | | • | | | | 38 | T1 M:L | AUC = 0.81 | | B
Mayo-Smith, 1995 | (46) | | • | | | | 38 | T1 M:Ms | AUC = 0.91 | | B
van Erkel, 1994 | (44) | | • | • | | | 45 ^d^ | T2 M:F | AUC = 0.86 | | B
van Erkel, 1994 | (44) | | • | • | | | 45 ^d^ | T2 M:L | AUC = 0.67 | | B
van Erkel, 1994 | (44) | | • | • | | | 45 ^d^ | T2 M:Ms | AUC = 0.86 | | B

Studies organized by ratio measurement type, then listed in order of threshold, then study size.

Studies with data on multiple thresholds are included for each threshold.

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity; HU, Hounsfield units; AUC, area under the receiver operating characteristics curve.

a M:S = Adrenal mass to spleen signal intensity ratio

M:F = Adrenal mass to fat ratio

M:L = Adrenal mass to liver ratio

M:Ms = Adrenal mass to muscle ratio

b See Methods, Question 2, Study Quality.

c Positive test = ratio > 2.0; Negative test = ratio between 0.5 and 1.5; Equivocal not included

d Positive reference standard is non-adenoma, including other benign lesions.

g Exact signal intensity ratios were reported graphically for all masses. The thresholds included in the table are those explicitly reported in the article.

f Positive test = T1 and T2 mass to opposite adrenal ratio > 1.0, or T2 mass to liver ratio > 1.0

Table 13. Combined Unenhanced and Enhanced MRI to Diagnose Adrenal Mass

Author, Year | Subjects (Masses), N | Incidentatloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Threshold | Test Performance | | Study Quality^a^
| | | | | | | | | Sens, % | Spec, %
Krestin, 1991 | (52) | | • | | | | 54 | M:F 2.0 and signal increase ^c^ | 75 | 75 | B

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity.

a M:F = Adrenal mass to fat signal intensity ratio

b See Methods, Question 2, Study Quality.

c Positive test = Adrenal mass to fat signal intensity ratio > 2.0 on plain MRI and maximal signal intensity increase > 150% and increase > 75% after 10 minutes;

Negative test = Adrenal mass to fat ratio between 0.5 and 1.5 on plain MRI and maximal signal increase < 100% and increase < 30% after 10 minutes;

Equivocal not included.

##### Unenhanced MRI (Table 12)

Eight studies evaluated unenhanced MRI to differentiate adrenal masses. Bilbey, McLoughlin, Kurkjian, et al. (1995) included patients with incidentalomas, in addition to patients with cancer work ups and those with clinically suspected adrenal masses. Seven studies included patients with cancer work ups (Krestin, Freidmann, Fishbach, et al., 1991); one of these also included patients with incidentalomas and a few patients with clinically suspected adrenal masses; another included patients with other adrenal masses. One study included patients with adrenal masses. Two studies used MRI to differentiate adenomas from non-adenomas (including other benign lesions). The other studies used MRI to differentiate malignant masses from benign. Malignancy (or non-adenoma) prevalence ranged from 19 to 58 percent. Only two studies analyzed test performance based on patients instead of total masses.

Mass:spleen ratio. Four studies measured adrenal mass to spleen ratio. Two studies reported using T1 measurements; the others did not explicitly define which spin measurements were used. One study reported test performance at various thresholds. Bilbey, McLoughlin, Kurkjian, et al. (1995) found perfect test performance for MRI to differentiate non-adenomas (including other benign lesions) from adenomas; however, McNicholas, Lee, Mayo-Smith, et al. (1995) found much poorer test performance at the same threshold to diagnose adrenal malignancies. Overall, the studies found MRI had sensitivity of 84 to 100 percent with specificity of 78 to 94 percent to differentiate malignant from benign masses.

Mass:fat ratio. Three studies measured adrenal mass to fat ratio. One study evaluated T1 spin measurements, one evaluated both T1 and T2 spin measurements; the third did not explicitly report the type of spin measurement used. Using different thresholds and measurements, high sensitivity was achieved only with poorer specificity, and vice versa. To diagnose either adrenal malignancies or non-adenomas, sensitivity ranged from 50 to 100 percent and specificity ranged from 57 to 95 percent.

Mass:liver ratio. Three studies measured adrenal mass to liver ratio. One study evaluated MRI to diagnose adrenal malignancies; two diagnosed non-adenomas. Two studies used T1 spin measurements; one used T2 spin. Two studies found similar results with mass to liver ratios as with mass to fat ratios, where high sensitivity was achieved only with poorer specificity, and vice versa. Van Erkel, van Gils, Lequin, et al. (1994) found that T2 measurements achieved very poor test performance to diagnose non-adenomas.

Mass:muscle ratio. Two studies measured adrenal mass to muscle ratio to diagnose non-adenomas. Bilbey, McLoughlin, Kurkjian, et al. (1995) used T1 measurements and found that perfect sensitivity could be achieved with a specificity of 89 percent. Van Erkel, van Gils, Lequin, et al. (1994) found poorer test performance using T2 measurements.

Krestin, Freidmann, Fishbach, et al. (1991) compared MRI to CT qualitatively, and concluded that unenhanced MRI (mass:fat ratio) is somewhat superior to combined unenhanced and enhanced CT, based on overall test accuracy. McNicholas, Lee, Mayo-Smith, et al. (1995) performed a quantitative comparison of MRI to CT using area under the ROC curve; they concluded that unenhanced MRI (mass:spleen ratio) had similar test performance as unenhanced CT. Van Erkel, van Gils, Lequin, et al., (1994) found T2 spin measurements on MRI to be an inferior parameter to diagnose non-adenomas than CT.

Combination criteria. Burt, Heelan, Coit, et al. (1994) used both T1 and T2 weighted imaging. MRI positive for malignancy was defined as adrenal mass having a greater intensity than the opposite adrenal gland on both T1 and T2 weighted imaging, or having greater intensity than liver tissue on T2 weighted imaging. Sensitivity was 100 percent, however specificity was only 24 percent.

##### Combined Unenhanced and Enhanced MRI (Table 13)

Krestin, Freidmann, Fishbach, et al. (1991) evaluated combined plain and contrast enhanced MRI (Table 13, Evidence Table 2). This study reported only one set of definitions for positive and negative tests (see Table MR2, footnote c) and found sensitivity and specificity of 75 percent to differentiate malignant from benign masses. By a qualitative comparison of test accuracy, this study concluded that combined unenhanced and enhanced MRI was superior to both combined unenhanced and enhanced CT and unenhanced MRI alone.

#### Combined Unenhanced CT and MRI (Table 14)

McNicholas, Lee, Mayo-Smith, et al. (1995) evaluated a combination of unenhanced CT and MRI to diagnose adrenal malignancies in patients having cancer work ups (Table 14, Evidence Table 2). Using thresholds of mass density of 0 HU on CT and mass to spleen signal intensity ratio of 0.70 on MRI, the study found perfect sensitivity with specificity of 94 percent to diagnose metastases.

Table 14. Combined Unenhanced CT and MRI to Diagnose Adrenal Mass

Author, Year | Subjects (Masses), N | Incidentatloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Threshold | Test Performance | | Study Quality^a^
| | | | | | | | | Sens, % | Spec, %
McNicholas, 1995 | (37) | | • | | | | 51 | CT 0 HU MRI M:S 0.70 | 100 | 94 | B

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity; HU, Hounsfield untis.

a M:S = Adrenal mass to spleen signal intensity ratio

b See Methods, Question 2, Study Quality.

#### Scintigraphy (Table 15)

Six studies evaluated scintigraphy to differentiate adrenal malignancies from benign lesions. Two studies included patients with incidentalomas only; the other three included patients with either incidentalomas or cancer work ups. One included only patients with cancer work-ups. Gross, Shapiro, Francis, et al. (1994) included only subjects with unilateral masses; Gross, Shapiro, Francis, et al. (1995) included only subjects with bilateral masses. Malignancy prevalence ranged from 4 to 45 percent. Five studies evaluated ^131^ I-6β-iodomethyl-19-norcholesterol (NP-59) scintigraphy and analyzed test performance for patients; Dominguez-Gadea, Diez, Bas, et al. (1994) evaluated 75-Se-cholesterol scintigraphy and analyzed test performance for total masses. No study of subjects with incidentaloma evaluated ^123^ I-meta-iodobenzylguanidine (MIBG) scintigraphy in more than four subjects. Each study used different criteria to distinguish adrenal masses. One study categorized adrenal masses based on increased or decreased marker uptake. Another study categorized adrenal and juxtaadrenal masses based on nine different uptake patterns. Two studies categorized adrenal masses based on symmetry and uptake. Two studies compared concordance of scintigraphy to CT. Only largest study, comprising 229 subjects, explicitly calculated test performance results. Overall, the studies, using various definitions of positive scintigraphy, found that scintigraphy achieved high sensitivity (71 to 100 percent) with varying specificity (50 to 100 percent) to differentiate malignant from benign adrenal masses.

Table 15. Scintigraphy to Diagnose Adrenal Mass

Author, Year | Subjects (Masses), N | Incidentatloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Definition of Positive Test | Test Performance | | Study Quality^a^
| | | | | | | | | Sens, % | Spec, %
Gross, 1994 | 229 ^b^ | • | • | | | | 25 | Discordant with CT ^c^ | 71 | 100 | C
Dominguez-Gadea, 1994 | (49) | • | • | | | | 37 | Decreased uptake ^d^ | 94 | 90 | B
Nakajo, 1993 | 33 | • | | | | | 18 | Inhomogeneous uptake, partial or complete defect ^c^ | 100 | 74 | A
Gross, 1995 | 29 ^e^ | • | • | | | | 45 | Asymmetric or no uptake ^c^ | 100 | 50 | B
Francis, 1988 | 28 | | • | | | | 36 | Discordant w ith CT ^c^ | 90 | 89 | B
Bondanelli, 1997 | 26 | • | | | | | 4 | Cold lesion ^c^ | 100 | 88 | B

Studies listed in order of study size.

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity.

a See Methods, Question 2, Study Quality.

b Unilateral masses only.

131 I-6β-iodomethyl-19-norcholeterol (NP-59) scintigraphy.

d 75-Se-cholesterol scintigraphy.

e Bilateral masses only.

#### Ultrasonography (Table 16)

One study evaluated US to differentiate malignant from benign adrenal masses in patients with incidentalomas. Fontana, Porpiglia, Destefanis, et al. (1999) had a malignancy prevalence of 22 percent. Using a definition of positive test of inhomogeneous masses, this study found poor test performance for US to differentiate malignant from benign adrenal masses.

Table 16. Ultrasonography to Diagnose Adrenal Mass

Author, Year | Subjects (Masses), N | Incidentatloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Definition of Positive Test | Test Performance | | Study Quality^a^
| | | | | | | | | Sens, % | Spec, %
Fontana, 1999 | 54 | • | | | | | 22 | Inhomogeneous | 67 | 52 | C

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity.

a See Methods, Question 2, Study Quality.

#### Positron Emission Tomography (Table 17)

One small study of 20 subjects evaluated PET to differentiate malignant from benign adrenal masses in patients with either incidentalomas or cancer work ups. Boland, Goldberg, Lee, et al. (1995) had a malignancy prevalence of 55 percent. Using a definition of positive tests of increased uptake by the adrenal mass, this study found perfect test performance to differentiate malignant from benign adrenal masses.

Table 17. PET to Diagnose Adrenal Mass

Author, Year | Subjects (Masses), N | Incidentatloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Definition of Positive Test | Test Performance | | Study Quality^a^
| | | | | | | | | Sens, % | Spec, %
Boland, 1995 | 20 | • | • | | | | 55 | Increased uptake | 100 | 100 | B

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity.

a See Methods, Question 2, Study Quality.

#### Fine Needle Aspiration (Table 18)

Nine studies reported some measure of test performance for FNA to diagnose adrenal masses. There was no study which included patients with incidentalomas only, although five stated explicitly that these patients were included. Eight included patients with cancer work ups and one included patients with adrenal masses. Three studies also included some patients with symptoms suggestive of adrenal disease. Eight studies had a malignancy prevalence rate of 19 to 82 percent. One study did not report sufficient information to calculate a prevalence rate. This study and a second did not clearly define positive and negative biopsies. Six studies either did not clearly define the reference standard or, in part, used FNA as both test under investigation and reference standard (Berkman, Bernardino, Sewell, et al., 1984; Heaston, Handel, Ashton, et al., 1982; Katz, Patel, Mackay, et al., 1984; Montali, Solbiati, Bossi, et al., 1984; Welch, Sheedy, Stephens, et al., 1994). However, FNA was not always the primary test under investigation. Welch, Sheedy, Stephens, et al. (1994) provided test performance results but did not report complete data. Excluding biopsies that were inconclusive, eight studies showed that sensitivity for all patients (or masses) to diagnose malignancy ranged from 81 to 100 percent and specificity ranged from 83 to 100 percent. One study reported only that accuracy was 91 percent. In seven studies, between 6 and 50 percent of biopsies were inconclusive. One study also analyzed test performance based on mass size and needle size. The study found higher sensitivity and accuracy in masses larger than 3 cm than those that were smaller and also when 19 gauge or larger needles were used than smaller. Furthermore Welch, Sheedy, Stephens, et al. (1994) reported that “accuracy depended on the size of the needle used to perform biopsy but not on the size of the lesion.” The evidence is too sparse to draw conclusions about the test performance of different methods of adrenal biopsy (e.g., FNA versus coring biopsy).

Table 18. Fine Needle Aspiration to Diagnose Adrenal Mass

Author, Year Needle Size, Type ^a^ | Subjects (Masses), N | Incidentaloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Definition of Positive Test | Test Performance | | Study Quality ^b^
| | | | | | | | | Sens, % | Spec, %
Welch, 1994 | (277) ^c^ | | • | | | | ND | ND | 81 ^c,d^ | 99 ^c,d^ | C
16–22 G Multi
Silverman, 1993 | 83 ^e^ | • | • | | | | 51 | Malignant tissue | 93 ^e^ | 100 ^e^ | B
>19–22 G Bx
| 42 ≥ 3 cm ^f^ | • | • | | | | ND | Malignant tissue | 100 ^d^ | ND | B
| | | | | | | | | Accuracy = 100 ^d^
| 30 < 3 cm ^f^ | • | • | | | | ND | Malignant tissue | 80 ^d^ | ND | B
| | | | | | | | | Accuracy = 90 ^d^
| 58 20–22 G ^g^ | • | • | | | | ND | Malignant tissue | 91 ^d^ | ND | B
| | | | | | | | | Accuracy = 95 ^d^
| 11 ≤ 19 G ^g^ | • | • | | | | ND | Malignant tissue | 100 ^d^ | ND | B
| | | | | | | | | Accuracy = 100 ^d^
Bernardino, 1985 | 53 | • | • | | | | 34 | ND | Accuracy = 91 ^d^ | | C
18–22 Coring
Karstrup, 1991 | 24 ^h^ | • | • | | | • | 75 | Malignant tissue | 94 ^h^ | 83 ^h^ | B
ND Both
Katz, 1984 | 20 ^i^ | | • | | | • | 65 | Malignant tissue | 85 ^i^ | 100 ^i^ | C
18–22 G FNA
Burt, 1994 | 20 | | • | | | | 19 | Malignant tissue | 100 ^j^ | 100 ^j^ | C
ND
Montali, 1984 | 17 ^j^ | • | • | | | • | 82 | Malignant tissue | 100 ^k^ | 100 ^k^ | C
22 G FNA
Berkman, 1984 | 15 ^k^ | • | • | | | | 27 | Malignant tissue | 100 ^L^ | 100 ^L^ | C
18–22 G FNA
Heaston, 1982 | 13 ^L^ | | | • | | | 77 | Malignant tissue | 100 ^m^ | 100 ^m^ | C
20–22 G FNA

Studies listed by study size.

Study with data on multiple subgroups is included for each subgroup.

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity; ND, no data; G, gauge.

a Multi, multiple; Bx, biopsy (no further description).

Welch: Single-needle biopsy or coaxial technique. Cutting needles and biopsy guns. No data on number of passes.

Silverman: No data on type of needle. No data on number of passes.

Bernardino: Chiba, Menghini needle, Jamshidi needle; rotary coring needle motion; 3 excursions per needle placement. 2–3 needle placements.

Karstrup: Both histological and cytological fine needle biopsies. No data on number of passes.

Katz: Cutting type and other needles. No data on number of passes.

Montali: Chiba needles. 2 passes.

Berkman: Histological or cytological specimens dependent on needle size. 2–3 needle passes from different sites.

Heaston: Spinal or screw-type needles. 1–2 passes with either single or tandem needles.

b See Methods, Question 2, Study Quality.

c 277 biopsies performed in 270 subjects. Test performance based on biopsies.

d Incomplete data reported. Definition of true positive, true negative etc. not clear. Test performance value only reported in article.

e Excluding 14 (14%) with non-diagnostic biopsies. 2 patients had benign lesions. 12 had cancer.

f Subgroup with masses of noted size

g Subgroup biopsied with noted needle gauge

h Excluding 4 (14%) with inconclusive biopsies. 1 had adrenal cancer. 3 had benign adrenal neoplasms (unclear if adenoma, pheochromocytoma, or both).

i Excluding 2 (9%) with non-diagnostic biopsies. Both had benign lesions.

j Excluding 10 (50%) with inconclusive biopsy, one of whom had lung cancer metastasis.

k Excluding 1 (6%) with inconclusive biopsy. Patient had adrenal cancer.

L Excluding 1 (6%) with inconclusive biopsy. Patient had a benign lesion.

m Excluding 1 (7%) with inconclusive biopsy. Subject had presumed lung cancer metastasis.

#### Biochemical Tests (Table 19)

Three studies evaluated biochemical tests in patients with adrenal incidentalomas. One study included only patients with incidentalomas; two studies included only patients with incidentally discovered adrenal adenomas. A fourth study (Bondanelli, Campo, Trasforini, et al., 1997) reported biochemical test results in their sample of subjects with incidentalomas. Two subjects had pheochromocytoma, one had adrenal cancer. However, no attempt was made to determine the diagnostic accuracy of the biochemical tests. The study results are included in Evidence Table 2, but is not included in Table 19.

Table 19. Biochemical Tests to Diagnose Adrenal Mass

Author, Year | Subjects (Masses), N | Incidentatloma | Cancer w/up | Adrenal mass | Incid adenoma | Suspect mass | Malignancy Prevalence, % | Definition of Positive Test | Test Performance | | Study Quality^a^
| | | | | | | | | Sens, % | Spec, %
DHEAS at 8 am
Terzolo, 2000 | 84 | • | | | | | Malignancy (4) | High or Normal ^b^ | “100” ^c^ | “38” ^c^ | C
Bardet, 1996 | 26 | | | | • | | UU ^d^ (50) | Low^e^ | 38 | 62 | C
ACTH at 8 am
Bardet, 1996 | 29 | | | | • | | UU ^d^ (48) | < 2.2 pmol/L | 29 | 93 | C
Basal Urinary Free Cortisol
Bardet, 1996 | 35 | | | | • | | UU ^d^ (46) | > 300 nmol/24 hr | 0 | 79 | C
Overnight 1 mg Dexamethasone suppression test, Cortisol at 8 am
Valli, 2001 | 31 | | | | • | | UU ^d^ (61) | > 60 nmol/L | 100 | 67 | C
Bardet, 1996 | 30 | | | | • | | UU ^d^ (43) | > 100 nmol/L | 31 | 94 | C
Low dose (2 mg/day for 2 days) Dexamethasone suppression test, Cortisol on day 2
Bardet, 1996 | 11 | | | | • | | UU ^d^ (55) | > 55 nmol/L | 50 | 80 | C
Low dose (2 mg/day for 2 days) Dexamethasone suppression test, Urinary Free Cortisol on day 2
Bardet, 1996 | 15 | | | | • | | UU ^d^ (60) | > 55 nmol/24 hr | 33 | 83 | C

Ordered by test, then study size

Incidentaloma, explicitly included subjects with incidentaloma; Cancer w/up, included subjects with cancer work up; Adrenal mass, described subjects as having adrenal mass; Incid adenoma, included subjects with incidental adenoma only; Suspect mass, included subjects with clinically suspected adrenal mass.

Sens, sensitivity; Spec, specificity; UU, unilateral uptake on scintigraphy.

a See Methods, Question 2, Study Quality.

b Based on age- and gender-adjusted reference ranges

c Incomplete data reported. Definition of true positive, true negative etc. not clear.

d Unilateral uptake on scintigraphy

e DHEAS < 0.9 μmol/L (men and post-menopausal women); < 0.3 μmol/L (premenopausal women)

Terzolo, Ali, Osella, et al. (2000) is the only study that evaluated the test performance of a biochemical test to differentiate malignant disease from benign. In a study of 84 patients, three of whom had malignancies (4 percent), high or normal 8 a.m. DHEAS levels were 100 percent sensitive but only 38 percent specific. Thresholds for normal DHEAS levels were age- and gender-specific based on a control group. Test performance values were reported, but complete data were not reported.

Bardet, Rohmer, Murat, et al. (1996) and Valli, Catargi, Ronci, et al. (2001) evaluated the test performance of biochemical tests to predict unilateral uptake on NP-59 scintigraphy in patients with incidental adrenal adenomas. Unilateral uptake on scintigraphy was assumed to be a marker of subclinical autonomous activity of the adrenal mass. Neither study reported clinical outcomes nor final diagnoses. The prevalence of unilateral uptake was about 50 to 60 percent in the two studies. Not all subjects had all testing done, so prevalence varies from test to test. No test was found to discriminate well between unilateral and bilateral uptake on scintigraphy. One study found that low 8 a.m. DHEAS (see Table 19), low 8 a.m. adrenocorticotropic hormone (ACTH), basal urinary free cortisol, unsuppressed 8 a.m. serum cortisol after overnight 1 mg dexamethasone suppression, unsuppressed day 2 serum cortisol and unsuppressed day 2 urinary free cortisol after low dose dexamethasone suppression had low sensitivity (0 to 50 percent) and moderate specificity (79 to 94 percent) to differentiate unilateral from bilateral scintigraphy uptake. In contrast, the second study found that unsuppressed 8 a.m. cortisol after overnight dexamethasone suppression had 100 sensitivity and 67 percent specificity to predict unilateral uptake. However, the second study used a lower threshold for cortisol suppression than the first (60 nmol/L and 100 nmol/L, respectively).

#### Summary (Table 20)

Thirty-two studies were evaluated that tested the test performance of CT, MRI, scintigraphy, US, PET, FNA or biochemical tests (Table 20, Evidence Table 2). Only four reported data on only subjects with incidentalomas. Nine included only subjects with adrenal masses found during extraadrenal cancer work up; six included subjects with either incidentaloma or adrenal masses found during extraadrenal cancer work up; two included only subjects with incidentally found adrenal incidentalomas; six included subjects with adrenal masses (no further description reported); three included subjects with either incidentalomas, adrenal masses found during extraadrenal cancer work up, or clinically suspected adrenal masses; one included subjects with adrenal masses found during extraadrenal cancer work up or other adrenal masses; one included subjects with either adrenal masses found during extraadrenal cancer work up, or clinically suspected adrenal masses.

CT was evaluated in ten studies with 467 subjects, 138 of whom were reported to have incidentalomas. The rest had adrenal masses found during extraadrenal cancer work up and undefined adrenal masses; a small number had clinically suspected adrenal masses. Studies were generally small, ranging from 23 to 84 subjects, and were of fair to poor quality. In general, test performance was based on the total number of adrenal masses (as opposed to total number of subjects). The studies reported that CT has the potential to have good to excellent test performance to differentiate malignant from benign adrenal masses. Studies of unenhanced CT, immediate enhanced CT and combined unenhanced and enhanced CT generally found that high to excellent sensitivity can be achieved only with fair to good specificity. Two studies of delayed enhanced CT found excellent overall test performance. Size of adrenal mass on CT had generally poor test performance where high sensitivity was achieved only with low specificity, or vice versa. Four studies evaluated various morphological features of adrenal masses (other than size) using either unenhanced CT, enhanced CT, or a combination of the two. The morphological criteria were generally subjective, including such parameters as inhomogeneity, smoothness, shape, and extension of the mass; some objective parameters, such as size and attenuation, were used by some criteria. Only one study, using a variety of parameters on both unenhanced and enhanced CT to define a malignant pattern had good test performance (Terzolo, Ali, Osella, et al., 2000). The other studies found overall poor test performance for morphological or subjective CT interpretations. Four studies directly compared different CT measures to diagnose adrenal malignancy; one compared different CT measures to diagnose non-adenomas. Three concluded that attenuation on unenhanced CT was a superior measure to adrenal mass size; one of these also found that attenuation was superior to subjective criteria (Lee, Hahn, Papanicolaou, et al., 1991). One concluded that attenuation on enhanced CT and adrenal mass size were equivalent criteria (Singer, Obuchowski, Einstein, et al., 1994). One concluded that attenuation on delayed enhanced CT (approximately 1 hour after contrast injection) was superior to attenuation on immediate enhanced CT (Korobkin, Brodeur, Francis, et al., 1996).

MRI was evaluated in eight studies with 302 subjects, 38 of whom were reported to have incidentalomas. The rest had adrenal masses found during extraadrenal cancer work up, undefined adrenal masses, and a few with clinically suspected adrenal disease. The studies were small, ranging from 25 to 54 subjects and were generally of fair quality. The studies evaluated numerous methods of performing and analyzing MRIs. In general, test performance was based on the total number of adrenal masses (as opposed to total number of subjects). The studies reported that MRI has the potential to have excellent sensitivity, with fair to very good specificity, to diagnose adrenal malignancy. The best test performance was found using adrenal mass to spleen signal intensity ratio. One study found that MRI has excellent test performance to differentiate adrenal adenomas from non-adenomas. One study concluded that combined unenhanced and enhanced MRI was superior to both CT and unenhanced MRI alone. Two studies concluded that unenhanced MRI had similar, or somewhat superior, test performance as CT. One study concluded that unenhanced CT was superior to T2 measurements on MRI.

The only study that evaluated the combined use of CT and MRI to diagnose adrenal malignancy found near-perfect test performance in patients undergoing cancer work up, but the study was small, evaluating 37 masses in 33 subjects, and had fair quality.

The only study that evaluated US to diagnose adrenal malignancy found poor test performance in patients with incidentalomas. This study had 54 subjects and had poor quality.

The only study that evaluated PET to diagnose adrenal malignancy found perfect test performance. The study included only 20 subjects, some of whom had incidentalomas; others had adrenal masses found during cancer work ups. The study was of fair quality.

Scintigraphy was evaluated in six studies with 399 subjects, of whom about 210 had incidentalomas. The rest had adrenal masses found during cancer work ups. Studies were generally small, ranging from 28 to 229 subjects; five had fewer than 50 subjects. The studies were of variable quality and only one explicitly calculated test performance. The rest reported frequency of diagnoses with different scintigraphy patterns. Malignant masses generally had decreased or incomplete marker uptake, or had scintigraphy patterns that were discordant with CT. However, adenomas frequently had similar patterns. Sensitivity ranged from 71 to 100 percent; specificity ranged from 50 to 100 percent.

FNA was evaluated in nine studies with 515 subjects, of whom about 115 had incidentalomas. The rest had adrenal masses found during cancer work ups, undefined adrenal masses, and a few had clinically suspected adrenal disease. Studies were generally small, ranging from 15 to 270 subjects; six studies had fewer than 30 subjects. The studies all were of poor quality, some with major deficiencies. Some studies did not report sufficient data to confirm test performance or determine prevalence of malignancy. Some reported only test accuracy or sensitivity and accuracy. Five of the studies had either unclear reference standards or used FNA results also as a reference standard. Notwithstanding these caveats, sensitivity ranged from 80 to 100 percent and specificity ranged from 83 to 100 percent. Inconclusive biopsies occurred in six to 50 percent of samples, in both benign and malignant masses. One study found that FNA had higher sensitivity and accuracy in masses at least 3 cm in diameter and when 19 gauge or larger needles were used. There was insufficient evidence to draw conclusions about test performance of different needle biopsy techniques.

Three studies evaluated the test performance of biochemical tests in subjects with incidentalomas. One study included subjects with incidental adrenal adenomas only. The studies included 145 subjects and ranged in size from 31 to 84 subjects. The studies were of poor quality with regard to evaluating biochemical tests. One study found that DHEAS had excellent sensitivity but poor specificity to diagnose malignancy. However, only three subjects had malignancy. Two studies evaluated biochemical tests to predict unilateral uptake on scintigraphy in patients with incidental adenomas. It was implied that the scintigraphy was a marker for autonomous function of an adenoma, although neither study provided clinical results. One study tested six different biochemical tests and found poor sensitivity (0 to 50 percent) and fair to good specificity (62 to 94 percent). The other study found 100 percent sensitivity and 67 percent specificity for morning cortisol after an overnight suppression test. It is important to note that the second study used a lower threshold for lack of suppression.

Overall, CT and MRI have been shown to have the potential to be highly sensitive and specific to differentiate malignant disease from benign in patients with incidentally found adrenal masses. Scintigraphy may also show good test performance, although there was no consensus for what were appropriate definitions of positive and negative tests. FNA appears to be highly accurate to diagnose adrenal masses, although the rate of non-diagnostic biopsies was substantial. Furthermore, the poor quality of the studies and their small size make the conclusions dubious. US, PET and biochemical tests have been evaluated by too few studies to allow accurate conclusions.

With few exceptions, the overall methodological quality of the studies we examined was poor to fair. The heterogeneity of the studies limits the ability to estimate the overall diagnostic performance of each evaluated test. Future high quality studies are needed to properly assess the test performance of various diagnostic tests for adrenal incidentalomas. In contrast to published studies, future studies should clearly define and report eligibility criteria, sample characteristics, test methodology, and definitions of positive and negative tests. Reference standards should be clearly defined, should be completely independent of the tests being investigated, and should, as much as possible, include well defined outcomes, such as surgical or autopsy diagnoses. Given the heterogeneity of definitions of incidentally discovered adrenal masses, it is important to focus research on specific populations of patients. Many studies combined subjects with true incidentalomas (which have very low prevalence of malignancy and which tends to adrenal carcinoma) with subjects who had adrenal masses found during cancer work ups and who have a high prevalence of metastatic disease. Furthermore, many studies did not define how adrenal masses were initially discovered. It may also be of value for future studies to focus on test performance for specific outcomes, such as adrenal cortical cancer or metastasis, as opposed to all cancers combined. Studies of diagnostic test performance of clear, simple populations are much easier to interpret and should be more applicable to patients with the disease of interest. Finally, when possible, ROC curves should be drawn, and complete data reported, so that the reader can determine the proper threshold to use for a given test.

### Question 2.1 What is the risk of metastatic spread of adrenal carcinoma by FNA? (Table 21, Evidence Table 3)

Twelve studies reported complications due to FNA of adrenal masses. Only two explicitly reported data on metastatic spread of cancer along the needle tract. In three studies patients were accrued prospectively, and the remaining nine were retrospective chart reviews, including the two that reported metastatic spread. Seven studies were judged to be of fair quality (quality grade B). These studies either did not fully describe their population, did not fully report biopsy techniques, did not fully report complication definitions or results, or were retrospective. The remaining five studies were judged to be of poor quality (grade C). These studies were too limited in their descriptions of biopsy techniques and complications.

Table 21. Complications of Fine Needle Aspiration

Study Year | Needle Size, gauge | Biopsy Type^a^ | Number of Biopsies | Total Complications | Metastatic spread | Bacteremia | Bleed | Death | Hematuria | Hemothorax | Hypotension | Nausea | Pain | Pancreatitis | Pneumothorax | No Complications^b^ | Quality^c^ | Comments
Welch 1994 | 16–22 | Multi | 277 | 8 | 0 | 0 | 8 | 0 | | | | | | 0 | 0 | 97% | B | 7 adrenal bleed, 1 perirenal hematoma
de Agustin 1999 | 22 | FNA | 169 | 0 | ND | | | | | | | | | | | 100% | C | “No serious complications”
Silverman 1993 | >19–22 | Bx | 101 | 9 | ND | | | | 1 | 1 | 2 | 1 | 2 | | 2 | 91% | C | Pain, nausea, hematuria and hypotension all mild
Mody 1995 | 18–22 | Multi | 83 | 7 | 1 | | 2 | | | | | | 2 | | 2 | 92% | B | Lung cancer metastasis, 2 hematomas
Bernardino 1985 | 18–22 | Coring | 58 | 7 | ND | 1 | 5 | | | | 1 | | | | | 90% | B | 5 hematocrit drop, 1 subject had 2 complications
Schwartz 1997 | 22 | Bx | 54 | 2 | ND | | | | | | | | | | 2 | 96% | C
Kane 1991 | 20–22 | FNA | 48 | 2 | ND | | | | | | | | | 2 | | 96% | B
Karstrup 1991 | ND | Both | 28 | 0 | ND | | | | | | | | | | | 100% | C | “No complications”
Katz 1984 | 18–22 | FNA | 22 | 1 | ND | | | | | | | | | | 1 | 95% | C
Montali 1984 | 22 | FNA | 18 | 0 | ND | | | | | | | | | | | 100% | B | “No complications”
Berkman 1984 | 18–22 | Bx | 16 | 0 | ND | | | | | | | | | | | 100% | B | “No complications”
Heaston 1982 | 20–22 | FNA | 14 | 0 | ND | | 0 | | | | | | | | | 100% | B | “No major complications. No significant hemorrhage.”
TOTAL (N) | | | 888 | 36 | 1 | 1 | 15 | 0 | 1 | 1 | 3 | 1 | 4 | 2 | 7
Total (% of biopsies) | | | | 4.1 | 0.3 ^d^ | 0.1 | 2.6 | 0 | 0.1 | 0.1 | 0.3 | 0.2 | 0.5 | 0.2 | 0.7 | 96%

a Multi, multiple; Bx, biopsy (no further description).

Welch: Single-needle biopsy or coaxial technique. Cutting needles and biopsy guns. No data on number of passes.

de Agustin: No data on number of passes.

Silverman: No data on type of needle. No data on number of passes.

Mody: Chiba, spinal, and Franseen needles, a coaxial system and core needles; biopsy gun used in 2 cases where FNA failed to yield tissue. 1–7 passes.

Bernardino: Chiba, Menghini needle, Jamshidi needle; rotary coring needle motion; 3 excursions per needle placement. 2–3 needle placements.

Schwartz: No data on type of needle. No data on number of passes.

Kane: Chiba, Franseen needles. 1–6 passes.

Karstrup: Both histological and cytological fine needle biopsies. No data on number of passes.

Katz: Cutting type and other needles. No data on number of passes.

Montali: Chiba needles. 2 passes.

Berkman: Histological or cytological specimens dependent on needle size. 2–3 needle passes from different sites.

Heaston: Spinal or screw-type needles. 1–2 passes with either single or tandem needles.

b Percentage of patients with no complications. Patients who had more than 1 complication counted only once.

c See Methods, Question 2, Complications of Fine Needle Aspiration.

d Denominator includes only the 2 studies that specifically reported on metastatic spread (N=360).

Two studies reported data on metastatic spread. Welch, Sheedy, Stephens, et al. (1994) was the largest study found. In a retrospective analysis of patients with adrenal biopsy and one year follow-up, 277 biopsies had been performed in 270 patients with adrenal masses. No patient developed metastases along the needle tract. Mody, Kazerooni, and Korobkin (1995) performed a retrospective analysis of 83 percutaneous biopsies in 78 patients with adrenal masses. Needle tract metastasis of a lung cancer metastasis was detected in one patient who had two passes, by supine transhepatic approach, with a coaxial system using a 22 gauge inner needle and an outer 19 gauge needle. The metastases were in the liver. No other sites of metastases developed during seven months after adrenal biopsy, but no further follow-up data were provided. In both studies, various biopsy techniques, approaches and needle sizes were used, as listed in Table 21.

Twelve studies reported a total of 36 complications (including the metastatic spread) in 888 biopsies (866 patients). The overall complication rate was 4.1 percent. No deaths were reported.

The most frequent complication was bleeding (15 events) which comprised adrenal bleeds, hematomas, and hematocrit drops. One patient required adrenalectomy; one patient received a 2 unit blood transfusion (in the early 1980s). One patient had a left-sided adrenal mass that was biopsied with four passes of a 22 gauge needle from a posterior approach. One patient had a right-sided adrenal mass that was biopsied with seven passes of a 22 gauge needle from a transhepatic approach. Five other patients had biopsies done with 18–20 gauge needles. No other data were provided about biopsy technique.

Seven patients developed pneumothoraces, and two of these required chest tube placement. One additional patient developed a hemothorax which also required chest tube placement. Four patients had biopsies with 22 gauge needles. One of these patients had a right-sided mass that was biopsied posteriorly with three passes. Another had a left-sided mass that was biopsied posteriorly with 5 passes. No data were provided about biopsy technique in four patients.

Two patients developed pancreatitis. One was hospitalized for 11 days, the other for 13. One received 2 units of blood. One patient had two passes with a 20 gauge needle and one pass with a 22 gauge needle. One patient had six passes with a 20 gauge needle.

Four patients experienced unusual pain; one required overnight hospitalization. Two patients had hypotension; one was asymptomatic, one received 2 units of blood (though there was no drop in hematocrit). One patient each suffered mild nausea, mild hematuria, and transient bacteremia.

One study which reviewed 277 biopsies performed statistical analysis but found no significant difference in complication rates by either needle or lesion size (Welch, Sheedy, Stephens, et al., 1994).

No study compared complication rates by biopsy technique, including aspiration versus core needle biopsy. The three studies with the highest complication rates either did not describe needle type or biopsy technique, or used multiple needle types and biopsy techniques, including coring (Bernardino, Walther, Phillips, et al., 1985; Mody, Kazerooni, and Korobkin, 1995; Silverman, Mueller, Pinkney, et al., 1993). However, since different definitions of complications were used across studies, one should be cautious of direct comparisons.

In summary, only two studies (of 10 or more subjects) evaluated the risk of metastatic spread due to biopsy of adrenal masses. In these two studies, one of 360 patients (0.3 percent) had needle tract metastases due to adrenal biopsy. This patient had bronchogenic carcinoma. Neither paper provides data on the number of subjects with adrenal carcinoma, so no conclusions can be offered about the risk of needle track metastases from FNA biopsy of adrenal carcinoma. Twelve studies reported on 888 biopsies in 866 patients. A total of 36 complications (4.1 percent) were reported. There were 26 potentially serious complications (bleeding, pneumothorax, hemothorax, pancreatitis, bacteremia). Nine patients (1 percent) received in-hospital treatment for complications due to adrenal biopsy. Because of the wide variety of biopsy techniques (including position, approach, needle size, aspiration, and coring), the commonly unclear or incomplete reporting, and the small study sizes, no reliable estimates can be made about the relative safety of the different biopsy techniques. The largest study found no difference in risk of complication based on needle or lesion size. Overall, study quality was fair to poor.

Further studies are required to determine the risks of both needle tract metastases and major complications. Ideally, future studies should be larger and clearly and completely report patient demographics (e.g., age, body mass index, gender, reason for initial discovery of mass, mass size and location), all relevant aspects of biopsy technique (e.g., position, approach, organs transected, needle size and type, number of passes, radiological tool), biopsy results and final diagnoses, short- and long-term complications, and patient disposition. Statistical analyses should also be performed to determine which patient characteristics and which biopsy techniques are predictors of increased risk of complications.

### Question 3 What are the surgical complication rates for various approaches used to excise adrenal masses; specifically laparoscopic, transabdominal, and retroperitoneal approaches? (Tables 22–29, Evidence Tables 4–10)

To date, few randomized trials have ever been conducted comparing the various surgical approaches to adrenalectomy. Most centers perform only one or two approaches. Published data consists primarily of case series, mostly retrospective, sometimes with historical controls, occasionally matched for demographic variables. We have organized the cohort/case series by surgical approach, and the comparative studies (when done) according to the comparison being made.

Table 22. Cohort/Series of Surgical Complications of Open Transperitoneal Adrenalectomy

Study Year | Tumor Type, % ^a^ | Total, N | Mean Tumor Size, cm (Range) | Operative Time, Min (Range) | Mean Blood Loss, mL (Range) | Length of Stay, Days (Range) | Complications | | | Quality ^b^
| | | | | | | | Death | Major | Minor
Malmaeus 1986 | Pheo 38 | 55 | 4.7 ^c^ (0.7 – 8) | ND | ND | ND | 0 | 13 | 9 | B
| CA 0
| Met ND

N, number of subjects; Min, minutes; ND, no data

a Pheo, pheochromocytoma; CA, adrenal cortical cancer; Met, metastatic cancer

b See Methods, Question 3, Grading the methodological quality

c 37 cases

Table 29. Summaries of Surgical Approaches

Study, N | Patients, N | Tumor Type^a^, % | Mean Tumor Size, cm (Range) | Mean Surgery Time, Minutes (Range) | Mean Blood loss, mL (Range) | Mean Length of Stay, Days (Range) | Complications, % | | | Quality ^d^, N
| | | | | | | Death | Major | Minor | A | B | C | I
Open transperitoneal adrenalectomy case series
1 | 55 | Pheo 38 | 4.7 (0.7–8) | ND | ND | ND | 0 | 13 | 9 | 0 | 1 | 0 | 0
| | CA 0
| | Met ND
Open retroperitoneal adrenalectomy case series
8 | 470 | Pheo 0–41 | 1.5–4.3 (0.5–14) | 84–200 (45–355) | 232–237 (30–4500) | 4.3–8 (1–21) | 0–3 | 2–24 | 0–14 | 0 | 4 | 4 | 0
| | CA 0–13
| | Mets 0–6
Comparative studies of open adrenalectomy techniques
| AA 228 | Pheo 0–24 | 6.8 / 160 g | 95–160 | 405–1050 | 9–16 | 0–6.8 | 6–47 | 2–36 | 0 | 0 | 4 | 0
| | CA 0–48
4 | | Mets 0
| PA 338 | Pheo 0–17 | 7.0 / 12 g | 85–101 | 288–300 | 5–13 | 0–1.5 | 4–25 | 15–20
| | CA 0–6
| | Mets 0
Transperitoneal laparoscopic adrenalectomy case series
20 | 1189 | Pheo 0–38 | 2.0–5.1 (0.5–14) | 92–253 (70–360) | 49–216 (20–1300) | 2.0–11.6 (1–23) | 0–1 | 0–25 | 0–72 | 0 | 8 | 8 | 4
| | CA 0–4
| | Mets 0–19
Retroperitoneal laparoscopic adrenalectomy case series
10 | 537 | Pheo 0–22 | 1.7–3.4 (0.2–7) | 97–248 (45–419) | 44–240 (0–800) | 1.0–10.6 (1–21) | 0–1 | 0–10 | 0–63 | 1 | 6 | 3 | 0
| | CA 0–1
| | Mets 0–10
Open vs. endoscopic adrenalectomy techniques
28 | 1388 | See text for specific information | | | | | | | | 0 | 4 | 23 | 1
Comparative studies of endoscopic adrenalectomy techniques
9 | 866 | See text for specific information | | | | | | | | 1 | 4 | 3 | 1

N, number of subjects; ND, no data

a Pheo, pheochromocytoma; CA, adrenal cortical cancer; Met, metastatilefter

b See Methods, Question 3, Grading the methodological quality

Initially, all adrenalectomies were performed via the transabdominal route. In the 1980s the posterior approach was adopted by the majority of surgeons, because of a perceived decrease in surgical morbidity, at first for small tumors, and later for large tumors, pheochromocytomas and metastases. We found one study (Malmaeus, Markaes, Oberg, et al., 1986) documenting the open transabdominal approach (Table 22), eight case series for the open retroperitoneal approach (Table 23), and four studies comparing the two approaches using unmatched historical controls (Table 24).

Table 23. Cohort/Series of Surgical Complications of Open Retroperitoneal Adrenalectomy

Study Year | Tumor Type, % ^a^ | Total, N | Mean Tumor Size, cm (Range) | Operative Time, Min (Range) | Mean Blood Loss, mL (Range) | Length of Stay, Days (Range) | Complications | | | Quality ^b^
| | | | | | | Death | Major | Minor
Favia 1992 | Pheo 0 | 52 | ND | ND | ND | ND | 0 | 2 | 0 | C
| CA 0
| Met 0
Proye 1993 | Pheo ND | 105 | 3.8 (0.5–9.6) | 132 (45–260) | ND | 7.6 (1–21) | 1 | 12 | 14 | C
| CA ND
| Met ND
Weigel 1994 | Pheo 0 | 40 | 1.48 | ND | ND | 6 | 3 ^c^ | 3 | 3 | B
| CA 3
| Met 0
Fahey 1994 | Pheo 18 | 51 | ND | 84 | ND | ND | 2 ^d^ | 14 | 6 | B
| CA 8
| Met 6
van Heerden, 1995 | Pheo 0 | 91 | 4.3 | ND | ND | 6 | 2 ^e^ | 3 | 0 | C
| CA 4
| Met 0
Nash 1995 | Pheo 0 | 40 | 1.8 (0.7–2.5) | 200 (130–355) | 232 (30–600) | 4.3 (2–11) | 0 | 5 | 10 | B
| CA 0
| Met 0
Sand 1997 | Pheo 12 | 59 | Median 2.5 (1–7) | ND | 237 (30–4500) | Median 8 (5–21) | 0 | 24 | 3 | C
| CA 2
| Met 1
Kolomecki 1999 | Pheo 41 | 32 | (1.5–14.0) | 90 | ND | 7 | 0 | 3 | 0 | B
| CA 13
| Met 3

N, number of subjects; Min, minutes; ND, no data

a Pheo, pheochromocytoma; CA, adrenal cortical cancer; Mets, metastatic cancer

b See Methods, Question 3, Grading the methodological quality

c Aneurysm rupture 5 days post-operative

d Patient with severe coronary artery disease, considered high-risk

e Deaths occurred within 30 days, determined not to be related to surgery

Table 24. Surgical Complications in Comparative Studies of Open Adrenalectomy Techniques

Study Year | Procedure/approach^a^ | Total, N ^b^ | Tumor Type, % ^c^ | | | Mean Tumor Size, cm (Range) | Operative Time, Min (Range) | Mean Blood Loss, mL (Range) | Length of Stay, Days (Range) | Complications | | | Quality ^c^
| | | Pheo | CA | Met | | | | | Death | Major | Minor
Russell 1982 | AA | 64 (94) | 0 | 0 | 0 | ND | 95 | ND | 9.3 ^e^ | 2 | 15 | 2 | C
| PA | 39 (52) | 0 | 0 | 0 | | 85 | | 5.3 ^e^ | 0 | 4 | 19
Bruining 1984 | Laparotomy | 32 | ND | ND | ND | ND | 105 | 800 | ND | 0 | 38 | ND | C
| Lumbotomy | 56 | | | | | 111 | 405 | | 0 | 6 | ND
| Dorsal | 12 | | | | | 98 | 288 | | 0 | 25 | ND
Irvin 1989 | AA | 17 | 100 | 0 | 0 | 6.8 | ND | ND | 9.8 ^e^ | 0 | 47 | 24 | C
| PA | 20 | 100 | 0 | 0 | 7.0 | | | 6.1 ^e^ | 0 | 5 | 15
Nagesser 2000 | AA | 59 | 24 | 48 | 0 | 160 g ^e^ | 160±54 ^f^ | 1050 ^f^ | 15.6±8.8 ^f^ | 6.8% ^g^ | 17 | 36 | C
| PA | 267 | 17 | 6 | 0 | 12 g ^e^ | 101±44 ^f^ | 300 ^f^ (Median) | 12.8±6.7 ^f^ | 1.5% ^g^ | 10 | 20

N, number of subjects; Min, minutes; ND, no data

a AA, anterior adrenalectomy; PA, posterior adrenalectomy

b Number of procedures in parentheses.

c Pheo, pheochromocytoma; CA, adrenal cortical cancer; Met, metastatic cancer

d See Methods, Question 3, Grading the methodological quality

e Statistically significant difference

f Statistically significant difference in univariate analysis. In multivariate analysis, only blood loss was significantly correlated with operative approach. Operative time and length of stay were significantly correlated with tumor size only.

g Not significantly different (p = 0.06)

In the early 1990s, Gagner, Lacroix, Prinz, et al. (1993) applied the laparoscopic technique to the transperitoneal approach. As with the posterior approach, initial indications were limited due to concerns about bleeding, the safety of removing pheochromocytomas, especially under carbon dioxide insufflation which theoretically might trigger a hypertensive crisis, the inability to do en bloc resections of invasive tumors, and the fear that removing cancers laparoscopically could result in metastatic seeding along the trocar port. As surgeons gained experience, indications for laparoscopic adrenalectomy expanded to include large tumors, pheochromocytomas, and metastases.

There are numerous case series of laparoscopic adrenalectomy. Many studies, however, contain overlapping data, as authors presented their initial experience with the procedure, then included those same cases in larger (accrued) case series, or regional experiences. We found 20 case series of transperitoneal laparoscopic adrenalectomy (Table 25) and 10 studies of retroperitoneal laparoscopic adrenalectomy (Table 26). There were 28 studies that compared the laparoscopic approach to the open approach using historical controls (Table 27), and nine studies that compared the transperitoneal laparoscopy with retroperitoneal laparoscopy (Table 28).

Table 25. Surgical Complications of Transperitoneal Laparoscopic Adrenalectomy

Study Year | Tumor Type, % ^a^ | Total, N ^b^ | Mean Tumor Size, cm (Range) | Operative Time, Min (Range) | Mean Blood Loss, mL (Range) | Length of Stay, Days (Range) | Complications | | | Quality ^c^
| | | | | | | Death | Major | Minor
Takeda 1994 | Pheo 0 | 17 | 7.9 g | 253 | 216 | 12 | 0 | 0 | 6 | C
| CA 0
| Met 0
Rutherford 1995 | Pheo 5 | 60 | ND | 124 | ND | 5.1±0.2 | 0 | 2 | 2 | C
| CA 2 | | | 1993: 152
| Met 0 | | | 1994: 109
Janetschek 1996 | Pheo 33 | 18 | 4.2 (1–8) | 160 | 76 | 4.6 | 0 | 0 | 72 | C
| CA 0 | | | | | (2–7)
| Met 0
Marescaux 1996 | Pheo 0 | 27 | Median 2.0 | 140 | 100–300, 1 with 1000 | 5.3 | 0 | 11 | 19 | B
| CA 0 | | (0.5 – 8.0) | (70–240)
| Met 0
Walmsley 1996 | Pheo 16 | 12 | 4.6 | 120 | ND | 5.3 | 0 | 25 | 17 | C
| CA 0 | | | (60–225)
| Met 0
Fernandez-Cruz ^d^ 1996 | Pheo 38 | 31 | 3.8 | 137 | 217 | 3.5 | 0 | 0 | 6 | B
| CA 0
| Met 0
De Canniere 1996 | Pheo 25 | 16 | Median 3 | 132 | ND | 6 | 0 | 6 | 19 | B
| CA 0 | | (1.5–5) | (59–360) | | (2–13)
| Met 19
Gagner ^e^ 1997 | Pheo 25 | 88 | 4.95 | 123 | 70 | 2.4 | 0 | 11 | 2 | B
| CA 3 | | (0.7–12) | (80–360) | (<20–1300) | (1–6)
| Met 0
Horgan 1997 | Pheo 25 | 16 | ND | 174 unilateral; 480 bilateral (Median) | 15 patients <100 | 3.9 ^f^ | 0 | 19 | 19 | C
| CA 0 | (19)
| Met 0
Terachi 1997 | Pheo 8 | 99 | 1.0–7.0 | 240±76 | 68±80 | 7.2 | 0 | 7 | 8 | C
| CA 2 | (100)
| Met 0
Shichman 1999 | Pheo 14 | 47 | 7.1 (adrenal size) | Right 210 | 142 | 3 | 0 | 4 | 6 | C
| CA 0 | (50) | | Left 227
| Met 2
Pujol 1999 | Pheo 20 | 27 | 3.1 | 156 ^g^ | ND | 3 | 0 | 7 | 7 | C
| CA 0 | (30)
| Met 3
Lucas 1999 | Pheo 7 | 36 | 2.5 | 262 overall; 194 unilateral | 116 overall; 108 unilateral | 2.0 overall; 1.1 unilateral; 3.0 bilateral | 0 | 10 | 10 | B
| CA 0 | (42) | (1.0–8.0)
| Met 0
Henry 2000 | Pheo 17 | 159 | 3.2 | 129 | ND | 5.4 | 0 | 2.5 | 5 | I
| CA 2 | (169) | (0.7–11.0) | (48–300) | | (3–15)
| Met 3
Lezoche ^h^ 2000 | Pheo 12 | 102 | 5.1 right | 85 right | ND | 2.5 | 0 | 5 | 0 | B
| CA 0 | (108) | 5.8 left | 112 left | | (2–3)
| Met 3 | | (3.5–12)
Ishikawa 2000 | Pheo 5 | 55 | 3.0±1.6 | 143±42 | 49±50 | ND | 0 | 0 | 0 | I
| CA 0 | | (1.0–6.5) | 185 (first 14) | 92 (first 14)
| Met 0 | | | 120 (last 41) | 32 (last 41)
Guazzoni 2001 | Pheo 20 | 145 | 8 | 160 | ND | 2.8±0.9 | 0 | 5 | 0 | I
| CA 0 | (161) | (7–10)
| Met 3
Pisanu 2001 | Pheo 21 | 84 | | 147 | ND | 5.0 | 0 | ND | ND | I
| CA 0 | (91) | 0.5–7.0 | (55–310) | | (1–23)
| Met 0
Porpiglia 2001 | Pheo 11 | 72 | 5.0±2.3 | 135 | 80 | 4.3±2.0 | 1 | 17 | 3 | B
| CA 1 | (76) | (1.8–11.0) | (85–200) | (50–700)
| Met 0
Valeri 2001 | Pheo 12 | 78 | 4.0 cm | 120 | 200 | 3.5 | 1 | 5 | 1 | B
| CA 4 | | (1–10) | (60–210)
| Met 6

N, number of subjects; Min, minutes; ND, no data

a Pheo, pheochromocytoma; CA, adrenal cortical cancer; Mets, metastatic cancer

b Number of procedures in parentheses.

c See Methods, Question 3, Grading the methodological quality

d Compared mixed laparoscopic techniques for pheo and non-pheo. No difference was found in operating time or blood loss. Patients with Cushing's disease had longer operating times and more blood loss than other patients.

e Includes La Croix 1998, Weisnagel 1996 and Gagner 1993.

f With the exception of one outlier, the mean was only 2.5

g Includes time for other procedures.

h Includes Filipponi 1998

Table 26. Surgical Complications of Retroperitoneal Laparoscopic Adrenalectomy

Study Year | Tumor Type, % ^a^ | Total, N ^b^ | Mean Tumor Size, cm (Range) | Operative Time, Min (Range) | Mean Blood Loss, mL (Range) | Length of Stay, Days (Range) | Complications | | | Quality ^c^
| | | | | | | Death | Major | Minor
Takeda 1997 | Pheo 0 | 11 | 1.7 | 248 | 151 | ND | 0 | 0 | 63 | B
| CA 0
| Met 0
Gasman 1998 | Pheo 9 | 22 | 2.6 | 97 | 70 | 3.4 | 0 | 0 | 9 | B
| CA 0 | (23) | (1.0–4.0) | (45–160) | (0–450)
| Met 5
Baba 1999 | Pheo 1 | 68 | ND | 144 | 43.5 | ND | 0 | ND | ND | C
| CA 0
| Met 0
Fazeli-Matin 1999 | Pheo 10 | 10 | ND | 180 | 50 | <1.0 | 0 | 10 | 0 | C
| CA 0 | | | (150–270) | (20–390) | (<1–3)
| Met 10
Lee 2000 | Pheo 3 | 30 | 2.2 | 155 | <100 | 5.5 | 0 | 3 | 3 | C
| CA 0 | | (1–4) | | | (4 -8)
| Met 0
Subramaniam 2000 | Pheo 100 | 11 | ND | 210–240 ^d^ | 240±200 | ND | 0 | ND | ND | B
| CA 0 | (16)
| Met 0
Tanaka 2000 | Pheo 19 | 54 | 2.65 | 227 | 176 | 10.6 | 0 | ND | ND | B
| CA 0
| Met 0
Bonjer 2000 | Pheo 20 | 95 (111) | 3.4 (0.2–7.0) | 118 unilateral; 214+26 bilateral | 66 unilateral; 121±39 bilateral | 2.0 (1.5–5.0) unilateral; 12.5 (7.3–16) conversion; 2.7 combined | 1 | 2 | 7 | B
| CA 1
| Met 1
Salomon ^e^2001 | Pheo 18 | 106 (115) | 3.1 (1.0–6.2) | 118 (45–240) | 77 (0–550) | ND | 0 | 8 | 10 | A
| CA 0
| Met 3
Walz ^f^ 2001 | Pheo 22 | 130 (142) | 2.7±1.4 (0.5 – 7.0) | 101±44 ^g^ 78 (last 50) | 54±72 | Median 3 (1–21) | 0 | 0 | 19 | B
| CA 0
| Met 2

N, number of subjects; Min, minutes; ND, no data

a Pheo, pheochromocytoma; CA, adrenal cortical cancer; Mets, metastatic cancer

b Number of procedures in parentheses.

c See Methods, Question 3, Grading the methodological quality

d In successful laparotomies. In 3 cases converted to open procedure, blood loss averaged 2000±700

e Includes Souliq 2000

f Includes Walz 1996

g Conversions excluded

Table 27. Surgical Complications of Open vs. Endoscopic Adrenalectomy Techniques

Study Year | Procedure/ approach ^a^ | Total, N ^b^ | Tumor Type % ^c^ | | | Mean Tumor Size, cm (Range) | Operative Time, Min (Range) | Mean Blood Loss, mL (Range) | Length of Stay, Days (Range) | Complications | | | Quality ^d^
| | | Pheo | CA | Met | | | | | Death | Major | Minor
Prinz ^e^1995 | AA | 11 | 82 | 0 | 0 | 5.1 | 174±41 | 391±88 ^f^ | 6.4±1.5 ^f^ | 0 | ND | ND | C
| PA | 13 | 0 | 0 | 8 | 3.1 | 139±36 ^f^ | 288±118 | 5.5±2.9 ^f^ | 0
| LTLA | 10 | 40 | 0 | 0 | 4.8 | 212±77 ^f^ | 228±66 ^f^ | 2.1±0.9 ^f^ | 0
Guazzoni ^g^1995 | AA +PA | 20 | 50 | 0 | 0 | 3.0 | 145 | 450 | 9.0 | 0 | 30 | 25 | C
| LTLA | 20 | 35 | 0 | 0 | 3.0 | 170 | 100 | 3.4 | 0 | 5 | 0
Brunt 1996 | AA | 25 | 72 | 0 | 0 | 3.4 ^h^ | 142 ^f^ | 408 ^f^ | 8.7 ^f^ | 4 | 28 | 44 | C
| PA | 17 | 6 | 0 | 0 | 2.4 ^h^ | 136 ^f^ | 366 ^f^ | 6.2 | 0 | 12 | 41
| LTLA | 24 | 44 | 0 | 0 | 2.7 ^h^ | 183 ^f^ | 104 ^f^ | 3.2 ^f^ | 0 | 8 | 8
MacGillivray 1996 | AA + PA | 9 | 11 | 0 | 0 | ND | 201±108 ^f^ | 500±574 ^h^ | 7.9±4.9 ^f^ | 0 | 60 | 40 | C
| LTLA | 14 | 7 | 0 | 0 | ND | 289±86 ^f^ | 198±144 ^h^ | 3.0±1.6 ^f^ | | 14 | 7
Staren ^e^1996 | Open mixed | 19 | 63 | 21 | 0 | 9.2 (2–25) | 177 | ND | 6.1 (4–8) ^f^ | 0 | ND | ND | C
| Lap mixed | 20 | 35 | 0 | 0 | 3.8 (1–8) | 206 | | 2.2 (1–7) ^f^ | 0
Mugiya 1996 | Open | 7 | 0 | 0 | 14 | 3.9±1.4 | 131±50 | 251±213 | ND | 0 | ND | ND | I
| ATLA | 12 | 0 | 0 | 0 | 3.8±1.9 | 197±35 | 130±209 | ND | 0 | 8 | ND
Bonjer ^I^1997 | PA | 12 | 0 | 0 | 0 | 3.0 | 60 ^e^ | 175 ^f^ | 6 ^f^ | 0 | 16 | 0 | B
| ATLA | 9 | 0 | 0 | 0 | 3.0 | 150 ^e^ | 150 ^f^ | 6 ^f^ | 0 | 22 | 0
| RLA | 9 | 33 | 0 | 0 | 4.0 | 75 | 20 | 4 | 0 | 0 | 0
| | | | | | (median) | (median) | (median) | (median)
Linos 1997 | AA | 86 | 28 | 12 | 1 | 8.07 | 155.3 ^f^ | 8.1% | 8.0 ^f^ | 0 | 14 | 0 | C
| PA | 61 | 16 | 0 | 0 | 5.25 | 108.6 | 3.2% | 4.5 ^f^ | 0 | 8 | 2
| TLA | 18 | 17 | 0 | 11 | 4.03 | 116.1 | 5.5% | 2.3 | 0 | 6 | 0
| | | | | | | | (Transfusion)
Aldrighetti 1997 | AA | 12 | 0 | 0 | 0 | 4.6±0.3 ^f^ | 174±18 ^h^ | ND | 7.9±1.0 ^f^ | 0 | 16 | 0 | C
| TLA | 8 | 0 | 0 | 0 | 3.4±0.4 ^f^ | 150±18 ^h^ | ND | 5.3±0.4 ^f^ | 0 | 12 | 12
Vargas 1997 | Open | 20 | 30 | 3 | 0 | 11.5±4 ^h^ | 178±17 ^h^ | 283±62 ^h^ | 7.2±0.6 ^f^ | 0 | 25^ h^ | 0 | B
| LTLA | 20 | 30 | 3 | 0 | 13.9±6 ^h^ | 193±14 ^h^ | 245±52 ^h^ | 3.1±0.3 | 0 | 10^ h^ | 0
Jacobs 1997 | AA + PA | 19 | 26 | 0 | 10 | 3.3±1.9 ^f^ | 151±63 ^h^ | 263±242^ f^ | 5.1±1.7 ^f^ | 0 | 32^ f^ | 0 | B
| LTLA | 19 | 15 | 0 | 0 | 2.5±1.2 ^f^ | 164±107 ^h^ | 109±75 ^f^ | 2.3±0.9 ^f^ | 0 | 5^ f^ | 0
Ishikawa 1997 | PA | 9 | 0 | 0 | 0 | 2.1±0.5 | 99±29 ^f^ | 126±54 | ND | 0 | ND | ND | C
| AA | 10 | 60 | 0 | 0 | 4.2±1.5 ^f^ | 143±35 ^f^ | 407±285 ^f^ | ND | 0 | ND | ND
| LTLA | 14 | 0 | 0 | 0 | 2.6±1.3 ^f^ | 185±19 ^f^ | 92±46 ^f^ | ND | 0 | ND | ND
Korman 1997 | Open | 10 | 20 | 10 | 10 | 6.1±2.8 | 124±29 ^f^ | 210±173 ^h^ | 5.9±1.1 ^f^ | 0 | 20 | 0 | B
| ATLA | 10 | 50 | 0 | 10 | 2.9±2.0 | 164±47 ^f^ | 118±158 ^h^ | 4.1±2.5 ^f^ | 0 | 10 | 0
Thompson 1997 | PA | 50 | 14 | 0 | 0 | 2.9 | 127 ^f^ | ND | 5.7 ^f^ | 0 | 18 ^h, j^ | 58 ^f, j^ | C
| LTLA | 50 | 20 | 0 | 0 | 2.9 | 167^ f^ | | 3.1 ^f^ | 0 | 6^ h, j^ | 0 ^f, j^
Yoshimura ^k^1998 | Open | 25 | 28 | 4 | 0 | 3.7 | 133±1 ^f^ | 345±84 ^h^ | 18.2±3.5 ^f^ | 0 | 20 | 8 | C
| Lap | 28 | 4 | 0 | 0 | 1.9 | 376±30 ^f^ | 370±134 ^h^ | 12.0±0.7 ^f^ | 0 | 14 | 21
Ting 1998 | PA | 56 | 0 | 0 | 0 | 1.6 ^a^ | 120 ^f^ | 150 ^f^ | 5 (2–17) ^f^ | 0 | 4 | 6 | C
| TLA | 12 | 0 | 0 | 0 | 1.8 ^a^ | 160 ^f^ | 50^f^ | 3 (2–5) ^f^ | 0 | 0 | 0
| | | | | | | Median | Median | Median
Winfield 1998 | Open | 17 | 41 | 0 | 0 | 2.5 ^h, L^ | 233 ^f^ | 266 ^h^ | 6.2 ^f^ | 0 | 35 | 35 | C
| | | | | | | (165–310) | (100–600) | (4–10)
| LTLA | 21 | 0 | 0 | 10 | 1.8 ^h, L^ | 309 ^f^ | 183 ^h^ | 2.7 ^h^ | 0 | 19 | 10
| | | | | | | (185–480) | (30–500) | (2–9)
Bonjer ^I^1998 | PA | 30 | 19 | 0 | 0 | 3.0 | 60 ^f^ | 125 ^f^ | 7 ^f^ | 0 | 3 ^m^ | 7^ m^ | C
| RLA | 42 | 38 | 0 | 0 | 3.0 | 90 ^f^ | 20 ^f^ | 4 ^f^ | 0 | 12^ m^ | 7^ m^
Soares 1999 | Open | 8 | 38 | 0 | 0 | 6.4 ^f^ | 166 ^f^ | 278 ^f^ | 5.4 ^f^ | 0 | 0 | 0 | C
| LTLA | 11 | 9 | 0 | 0 | 2.0 ^f^ | 116 ^f^ | 132 ^f^ | 2.1 ^f^ | 0 | 9 | 0
Dudley 1999 | LTLA | 31 | 42 | 0 | 0 | (1.6–8.2) | 158 | ND | 3.5 | 3^ n^ | 6 | 0 | C
| PA | 15 | 7 | 0 | 0 | (1.0–5.0) | 85 | | 8.5 | 0 | 60 | 20
Schell 1999 | LTLA | 22 | 18 | 0 | 0 | ND | | ND | 1.7±1.0 ^f^ | 0 | 0 | 0 | C
| Open | 17 | 41 | 24 | 0 | | | | 7.8±6.7 ^f^ | 0 | 12 | 6
Imai 1999 | LTLA | 40 | 20 | 0 | 0 | 2.8±1.7 | 180 ^f, o^ | 40 ^f^ | 12 ^f^ | 0 | 5 | 0 | B
| PA | 40 | 18 | 0 | 0 | 2.7±1.4 | 127 ^f, o^ | 162 ^f^ | 18 ^f^ | 0 | 3 | 38
Hobart 1999 | Needlescopic | 15 | 20 | 0 | 0 | 3.0 | 163±39 ^h^ | ND | 1.0±0.3^ f^ | ND | ND | ND | C
| AA | 15 | 20 | 0 | 0 | 3.7 | 136±24 ^h^ | | 7.0±1.9 ^f^ | ND | ND | ND
Shen 1999 | Mixed open | 38 | 0 | 3 | 0 | ND | ND | ND | ND | 0 | 0 | 11 | C
| Mixed LA | 42 | 0 | 0 | 0 | | | | | 0 | 0 | 0
Inabnet 2000 | LTLA | 11 | 100 | 0 | 0 | 4.1±1.2 ^h^ | 146±36 ^h^ | ND | 5.5±2.2 ^h^ | 0 | 0 | 0 | C
| AA | 11 | 100 | 0 | 0 | 4.6±1.2 ^h^ | 153±55 ^h^ | | 6.1±1.6 ^h^ | 0 | 9 | 0
Hobart 2000 | TLA or RLA | 14 | 36 | 29 | 7 | 8.0^ f^ | 205 ^h^ | 400 ^f^ | 2.4 | 0 | 21 | 0 | C
| Open | 14 | 58 | 0 | 0 | 7.8 | 216 ^h^ | 584 | 7.7 ^f^ | 0 | 57 | 21
| TLA or RLA | 45 | 36 | 0 | 4 | 2.2^ f^ | 158 ^h^ | 113 ^f^ | 1.5 ^f^ | 0 | 7 | 2
Rayan 2000 | LTLA | 19 | 5 | 0 | 0 | 3.3±1.9 ^f^ | 198 ^h^ | ND | 1.5 ^f^ | 0 | 5 | ND | C
| Open | 48 | 40 | 0 | 0 | 5.2±2.9 ^f^ | 228 ^h^ | | 6.3 ^f^ | 0 | 29 | ND
Sprung 2000 | LTLA | 14 | 100 | 0 | 0 | ND | 177±59 ^h^ | 100 ^f^ | 3.0 ^f^ | 0 | ND | ND | C
| AA | 20 | 100 | 0 | 0 | ND | 196±69 ^h^ | 400 ^f^ | 7.5 ^f^ | 0 | ND | ND
| | | | | | | | (median)

N, number of subjects; Min, minutes; ND, no data

a AA, anterior adrenalectomy; PA, posterior adrenalectomy; TLA, transperitoneal laparoscopic adrenalectomy (approach mixed or not specified); ATLA, anterior transperitoneal laparoscopic adrenalectomy; LTLA, lateral transperitoneal laparoscopic adrenalectomy; RLA, retroperitoneal laparoscopic adrenalectomy.

b Number of procedures in parentheses.

c Pheo, pheochromocytoma; CA, adrenal cortical cancer; Met, metastatic cancer

d See Methods, Question 3, Grading the methodological quality

e There is considerable overlap between Prinz, 1995 and Staren, 1996

f Statistically significant

g Includes Guazzoni 1994

h Not significant

i There is considerable overlap between Bonjer, 1997 and Bonjer 1998

j Early and late complications, instead of major and minor

k See Miyake

L Mean weights (15.6 g vs. 45.5 g) were significantly different

m Significant difference for all complications combined

n Operation was uncomplicated. Patient had end-stage Cushing's disease and died at home on post-operative day 8. No cause of death was found.

o Skin-to-skin time (34 patients)

Table 28. Surgical Complications in Studies of Comparative Endoscopic Adrenalectomy Techniques

Study Year | Procedure/approach ^a^ | Total, N ^b^ | Tumor Type % ^c^ | | | Mean Tumor Size, cm (Range) | Operative Time, Min (Range) | Mean Blood Loss, mL (Range) | Length of Stay, Days (Range) | Complications | | | Quality ^d^
| | | Pheo | CA | Met | | | | | Death | Major | Minor
Fernandez-Cruz 1996 | LTLA | 7 (10) | 0 | 0 | 0 | 5.4 | 89±23 | 160±74 | 3.0±0.7 | 0 | 0 | 29 | A
| RLA | 8 (11) | 0 | 0 | 0 | 5.3 | 105±19 | 180±84 | 2.8±0.8 | 0 | 0 | 0
Duh 1996 | LTLA | 22(23) | 14 | 0 | 23 | 5.3 (1–13) | 226 | ND | 2.2 (1–5) | 3 ^e^ | 0 | 5 | B
| RLA | 14 | 7 | 0 | 7 | 2.6 (1–6) | 202 | | 1.5 (1–4) | | 14 | 0
Miyake 1998 | ATLA | 17 | 6 | 0 | 0 | 1.92±1.0 | 423±184 ^f^ | 406 ^f^ | 12.8±4.0 | 0 | 18 | 24 | C
| RLA | 12 | 0 | 0 | 0 | 1.96±0.6 | 300±73 ^f^ | 164 ^f^ | 10.3±3.7 | 0 | 8 | 8
Gill 1998 | TNA | 15 | 13 | 0 | 7 | 41.6 g ^f^ | 169 ^f^ | 61 ^f^ | 1.1 ^f^ | 0 | 0 | 8 | C
| LTLA | 21 | 0 | 0 | 10 | 15.7 g ^f^ | 220 ^f^ | 183 ^f^ | 2.7 ^f^ | 0 | 20 | 11
Fernandez-Cruz 1999 | LTLA | 19 | 0 | 0 | 0 | ND | 89±23 | 160 | 3.0±0.7 | 0 | 0 | 11 | B
| RLA | 17 | 0 | 0 | 0 | ND | 105±19 | 180 | 2.8±0.8 | 0 | 0 | 0
Henry 1999 | LTLA ^g^ | 102 | 11 | 0 | 0 | 2.1 | 131 ^h^ | ND | 5.6 | 0 | 3 | 4 | B
| LTLA ^g^ | 48 | 28 | 6 | 6 | 5.2 | 129 ^h^ | | 5.1 | 0 | 0 | 8
Terachi 2000 | TLA | 311 | 4 ^i^ | 0 ^i^ | 1 ^i^ | ND | ND | ND | ND | 0 | 6 | 9 | I
| RLA | 59 | | | | | | | | 0 | 5 | 10
Takeda 2000 | ATLA | 52 | 7 | 0 | 0 | ND | 206±81 ^h^ | 153±116 ^h^ | ND | 0 | 0 | ND | I
| RLA | 24 | 0 | 0 | 0 | | 260±79 ^h^ | 116±98 ^h^ | | 0 | 0 | ND
Suzuki 2001 ^j^ | ATLA | 46 | 6 | 0 | 0 | 3.8±0.4 ^f^ | 201.1 ^f^ | 147.0 ^f^ | ND | 0 | 0 | 25 | B
| LTLA | 32 | 0 | 0 | 0 | 3.5±0.4 ^f^ | 122.9 ^f^ | 68.1 ^f^ | | 0 | 4 | 20
| RLA | 40 | 0 | 0 | 0 | 2.3±0.2 ^f^ | 174.6 ^f^ | 60.7 ^f^ | | 0 | 0 | 11

N, number of subjects; Min, minutes; ND, no data

a TLA, transperitoneal laparoscopic adrenalectomy (approach mixed or not specified); ATLA, anterior transperitoneal laparoscopic adrenalectomy; LTLA, lateral transperitoneal laparoscopic adrenalectomy; RLA, retroperitoneal laparoscopic adrenalectomy; TNA, transperitoneal needlescopic adrenalectomy.

b Number of procedures in parentheses.

c Pheo, pheochromocytoma; CA, adrenal cortical cancer; Met, metastatic cancer

d See Methods, Question 3, Grading the methodological quality

e Combined mortality for both groups

f Statistically significant

g Subset of Henry 2000. Compares subsets with small and large tumors.

h Not statistically significant

i Overall-no breakdown available by approach.

j Includes Suzuki 1999, Suzuki 1995, and Suzuki 1993

#### Specific Measures Assessed in the Surgical Series

##### Tumor Size and Type

Most studies did not include any information on patient co-morbidities. However, almost all studies list the indication for surgery. Because adrenal tumors are rare, most series include a heterogeneous mixture of indications. It is important to note that series are not randomized and rarely include all adrenalectomies at an institution. Therefore, for the sake of comparing studies or arms within the same study, we list the major indications for surgery, as well as the mean tumor size and range, if reported. We list the percentage of tumors found to be pheochromocytomas, carcinomas and metastases, as these tumors would be expected to have the longest operating time and highest complication rates, independent of operating approach.

##### Operating Time

One initial concern about laparoscopy was the prolonged operating time, especially in the earliest studies. Although most studies report operating time, comparison between studies is complicated by the lack of a standard definition of operating time. Some authors report total operating room time, including induction of anesthesia and patient positioning, which may be time consuming in certain approaches. Others report skin-to-skin, while others, in an attempt to negate the effects of multiple simultaneous operations (e.g. adrenalectomy plus cholecystectomy), report skin-to-gland-removal. Finally, some series include bilateral adrenalectomy, which always takes longer and may skew the average upward, if not reported separately. Unfortunately, the vast majority of studies do not specify how operating time is reported, making meaningful comparison impossible.

##### Blood Loss

Most studies report mean blood loss during the operation, as well as the range. Although this is easy to measure, its clinical significance is unclear, especially as it does not take into account post-surgical bleeding which may be directly related to approach. A more meaningful measure might be post-op change in hematocrit or number of transfusions required. The former is never routinely reported. Number of transfusions is frequently reported; however, the decision to transfuse is not objective, but dependent on the surgeon. Moreover, the number of transfusions is so small that no study could demonstrate a significant difference between approaches.

##### Length of Stay

Length of stay (LOS) offers a convenient and objective measure of overall morbidity associated with the operating technique. Other measures, such as time to ambulation or time to full recovery are less clearly defined and not universally reported. In collecting such data retrospectively, errors may occur. However, comparing LOS among studies poses its own set of problems. LOS varies greatly from country to country as different health care systems have different cost structures and patient expectations. Hospital stays in Japan, for example, are particularly long compared to the United States. Japanese authors explain this discrepancy due to the low cost of a hospital day and the patient's expectation that he will leave the hospital completely well (Imai T, Kikumori T, Ohiwa M, et al, 1999). LOS may also be confounded in patients with biochemically active tumors that frequently require post-op medical therapy related to hormone replacement which may prolong the hospital stay beyond the time required for surgical recovery. Finally, LOS has been decreasing globally throughout the 1980s and 1990s, the period encompassing all these studies. Comparative studies using historical controls may find that decreased LOS associated with newer procedures is exaggerated by secular trends in hospital reimbursement.

##### Complication Rates

Most studies report rates of complications, though the amount of detail varies from study to study. Authors who simply report that “there were no major complications” may employ different standards from those who report the introduction of post-op drains as a complication. Unfortunately, there is no standard scale for reporting operating complications. We compared complication rates using a scale adapted from Clavien, Sanabria, and Strasberg (1992), even though only one author actually used that scale. Since most studies were retrospective, complications had to be discovered by chart review. We noted that different authors reporting on the same series of patients sometimes reported slightly different complication rates. (Gagner, Pomp, Heniford, et al., 1997; Weisnagel, Gagner, Breton, et al., 1996; Wells, Merke, Cutler, Jr., et al., 1998).

##### Learning Curve

For each procedure there appears to be a learning curve. As the surgeon becomes more proficient with the procedure, there usually follows a decrease in operating time, blood loss, complication rates, and the number of conversions (midway through the procedure) to a more familiar approach. (Filipponi, Guerrieri, Arnaldi, et al., 1998; Henry, Defechereux, Raffaelli, et al., 2000; Ishikawa, Inaba, Nishiguchi, et al., 2000; Rutherford, Gordon, Stowasser, et al., 1995)

#### Open Series (Tables 22, 23)

Malmaeus, Markaes, Oberg, et al. (1986) did a retrospective review of all the adrenalectomies at his institution between 1976 and 1984, all by the transabdominal approach. In addition, seven comparative studies included 289 patients operated on by the transabdominal route (Aldrighetti, Giacomelli, Calori, et al., 1997; Bruining, Lamberts, Ong, et al., 1984; Brunt, Doherty, Norton, et al., 1996; Inabnet, Pitre, Bernard, et al., 2000; Irvin, Fishman, Sher, et al., 1989; Linos, Stylopoulos, Boukis, et al., 1997; Russell, Hamberger, van Heerden, et al., 1982). Tumors tended to be large, and the proportion of patients with adrenal carcinoma was as high as 48 percent in one study (Nagesser, Kievit, Hermans, et al., 2000). Mean operating time ranged from 95 to 160 minutes, and mean blood loss ranged from 391 to 1,050 ml. Rates of major complications ranged from nine to 47 percent. Mortality ranged from zero to 6.8 percent. The most common complications were accidental injuries to the spleen (necessitating splenectomy), hemorrhage, wound infection, and pneumonia.

From 1992 to 1999 there were eight series, involving 470 patients, examining PA. None was prospective. Most studies had few or no cancers or pheochromcytomas, and mean tumor size ranged from 1.5–3.8 cm. Kolomecki, Pomorski, Kuzdak, et al. (1999), in a study of incidentalomas, included more difficult tumors such as adrenocortical carcinomas and tumors as large as 14 cm. Only four studies reported operating time, with a mean ranging from 84–200 minutes, and an overall range of 45–355 minutes. Only two studies reported mean blood loss—200 ml in Nash, Leibovitch, and Donohue (1995) and 237 ml in Sand, Saaristo, Nordback, et al. (1997). Major complications occurred in 2–24 percent of cases, minor complications in 0–14 percent. Mortality ranged from 0–3 percent, though all deaths occurred in high-risk cases, or were considered unrelated to surgery, according to the authors. The most common complications of PA included pleural tear, wound infection, chronic pain, and bleeding.

##### Comparison of Open Techniques (Table 24)

Four studies compare the transperitoneal or abdominal approach (AA) with PA in 564 patients. In general the quality of the studies was poor. All studies were retrospective and none matched cases for tumor size or type. All but one neglected to report on one or more of the outcome parameters. The three studies that measured LOS (Irvin, Fishman, Sher, et al., 1989; Nagesser, Kievit, Hermans, et al., 2000; Russell, Hamberger, van Heerden, et al., 1982) all found that mean LOS for PA was significantly shorter than for AA. The sole study to find a significant difference in the other parameters (Nagesser, Kievit, Hermans, et al. 2000) found PA quicker and with less blood loss as a result, but tumors in PA patients were less than one-tenth the size of those in AA patients (12 g versus 160 g). Indeed, in multivariate analysis for unilateral adrenalectomy, all advantages for PA disappeared except for blood loss. For this group of studies, mean operating time, blood loss, LOS, complication rates and types of complications were similar to those seen in the cohort series.

#### Laparoscopic Series

##### Transperitoneal Approach (Table 25)

There are 20 cohort series of the transperitoneal approach, including both anterior and flank approaches, incorporating 1,189 patients. Most studies were retrospective with considerable selection bias and/or reporting bias. Half the studies included at least some cancers, and almost all included pheochromocytomas, with two studies (Janetschek, Altarac, Finkenstedt, et al., 1996; Wells, Merke, Cutler, Jr., et al., 1998) reporting that one-third of their operations were performed for pheochromocytoma. Few studies included adrenocortical carcinoma, and these tumors never accounted for more than 4 percent of the operations. Mean tumor size ranged from 2.0 to 5.1 cm and almost all series included tumors over 6 cm. Mean operating time ranged from 92–253 minutes, blood loss from 68–216 ml, and LOS from 2–12 days. There were two post-operative deaths. Major complications occurred in 0–25 percent and minor complications in 0–72 percent of cases. The most common complications were bleeding, conversion to open surgery, hypotension/ hypertension, and wound infection. A number of authors reported learning curves, whereby the operating time, blood loss, LOS and complication rates all decreased over time (Gagner, Pomp, Heniford, et al., 1997; Ishikawa, Inaba, Nishiguchi, et al., 2000; Lezoche, Guerrieri, Paganini, et al., 2000; Rutherford, Gordon, Stowasser, et al., 1995; Shichman, Herndon, Sosa, et al., 1999). In the four studies including at least 100 operations (Guazzoni, Cestari, Montorsi, et al., 2001; Henry, Defechereux, Raffaelli, et al., 2000; Lezoche, Guerrieri, Paganini, et al., 2000; Terachi, Matsuda, Terai, et al., 1997), major complications occurred in 2.5–7 percent and minor complications in 0–8 percent of cases.

##### Retroperitoneal Approach (Table 26)

There are 10 cohort series of the retroperitoneal approach, incorporating 537 patients. Most studies were retrospective, but overall quality was better than in previous series, including one prospective study (Salomon, Soule, Mouly, et al., 2001) which featured consecutive cases and reported outcome measures for both successful and failed laparoscopies. Almost half the studies included at least one case of metastasis, but there was only a single case of adrenocortical carcinoma in the entire series. Mean tumor size ranged from 1.7–3.4 cm and there were no tumors larger than 7.0 cm. Mean operating time ranged from 97–248 min, blood loss from 40–240 ml and LOS from <1–11 days. One patient died. Major complications occurred in 0–10 percent and minor complications in 0–63 percent of cases. The most common complications were retroperitoneal hematoma, subcutaneous emphysema, conversion to open or laparoscopic surgery, and pancreatic or splenic injury.

##### Comparison Between Open and Laparoscopic Approaches (Table 27)

There are 28 studies, incorporating 1,388 patients, which compared open to laparoscopic approaches to adrenalectomy. No studies were entirely prospective, and none were randomized. All studies consisted of case series, collected prospectively or retrospectively, compared with historical controls, and occasionally matched for surgical indication and tumor size. Most studies suffer from considerable selection bias and/or reporting bias. Comparison groups vary among studies. Transperitoneal laparoscopic adrenalectomy (TLA) is compared to the anterior open approach (AA) in eight studies, posterior open approach (PA) in nine studies, or a mixture of the two in nine other studies. Retroperitoneal laparoscopic adrenalectomy (RLA) is compared to PA in two studies. A mixture of laparoscopic approaches is compared with a mixture of open approaches in four studies. Because most studies did not use matched controls, tumor sizes and types are often not comparable between study arms. In general, open approaches had a higher percentage of pheochromocytomas and adrenocortical carcinomas and a larger tumor size than laparoscopic approaches. In only half the studies that compared TLA to PA were there comparable tumor size and type in both arms. TLA and AA had similar operating times, but TLA resulted in less blood loss (four of five studies) and shorter LOS (six of seven studies). Most studies listed all complications but did not apply statistical methods to comparing the complication rates. Six studies did compare rates statistically. Sprung, O'Hara, Jr., Gill, et al., (2000) found a higher rate of hypotension for AA compared to TLA for pheochromocytoma. Jacobs, Goldstein, and Geer (1997) found fewer major complications from TLA when compared with a mixture of open approaches. Bonjer, van der Harst, Steyerberg, et al. (1998) found fewer overall complications from RLA than from PA. On the other hand, Linos, Stylopoulos, Boukis, et al. (1997) and Vargas, Kavoussi, Bartlett, et al. (1997) found no statistical difference in complications among AA, PA and TLA. Finally, Thompson, Grant, van Heerden, et al. (1997) found a comparable rate of early complications between TLA and PA, but an increased rate of late complications with PA, specifically muscle weakness and pain at the incision site. The authors, who sent questionnaires asking about these late complications, hypothesize that they are frequently underreported. PA was significantly quicker than TLA in eight of nine studies and RLA in one of two studies, but TLA resulted in less blood loss (three of six studies) and a shorter LOS (seven of eight studies). The remaining studies did not find any significant differences between specific techniques. Both AA and TLA each resulted in one death, neither of which was considered by the authors to be related to the surgery. There were no deaths from PA or RLA. Studies comparing mixed open approaches or mixed laparoscopic techniques had similar findings; laparoscopy usually took longer, but resulted in less blood loss and a shorter LOS.

##### Comparison of Different Laparoscopic Techniques (Table 28)

There are eight studies comparing different laparoscopic approaches to adrenalectomy, incorporating 716 patients, as well as one study (Henry, Defechereux, Gramatica, et al., 1999) which compared surgery for large and small tumors using TLA in 150 patients. Overall quality of the studies was generally better than in the other series, and there was one prospective, randomized controlled trial (Fernandez-Cruz, Saenz, Benarroch, et al., 1996), albeit a small one. A few studies collected data prospectively, but because the surgeon still dictated the choice of approach, it is possible that considerable bias may have been introduced. One author (Suzuki, Kageyama, Hirano, et al., 2001) conducted a background-matched analysis on a subset of his patients.

In studies of TLA and lateral transperitoneal laparoscopic adrenalectomy (LTLA) vs. RLA, patients were generally well matched concerning tumor size and type. In each series, two studies found no difference in operating time or blood loss, while one study found RLA to be quicker than TLA (Miyake, Yoshimura, Yoshioka, et al., 1998), and another found that LTLA was quicker than either TLA or RLA (Suzuki, Kageyama, Hirano, et al., 2001). None of the studies demonstrated any difference in LOS, and none applied statistical methods to complication rates.

One study compared needlescopic surgery to traditional TLA. Although the tumors removed needlescopically were both larger and contained a higher percentage of pheochromocytomas, the needlescopic group had a shorter operating time, less blood loss and a shorter hospitalization. There were fewer complications in the needlescopic group, but due to the small sample size, the difference did not reach statistical significance.

Finally, Henry, Defechereux, Gramatica, et al. (1999) compared surgery for large (mean 5.2 cm) and small (mean 2.1 cm) tumors and found no difference in operating time, length of stay or complication rate. Moreover, the large tumor group contained 28 percent pheochromocytomas and 6 percent carcinomas that were subsequently converted to open procedures.

##### Summary (Table 29)

We evaluated nine case series of open adrenalectomies, four studies comparing open adrenalectomy techniques, 20 case series of TLA, 10 studies of RLA, 28 studies comparing laparoscopic adrenalectomy to open surgery, and nine studies comparing TLA with RLA.

Nine series of open adrenalectomy included 525 patients. Complications were common. Major complications occurred in 2 to 24 percent of patients and minor complications in 0 to 14 percent. Mortality occurred in 0 to 3 percent of patients. Although all deaths occurred in high-risk patients, they were not considered to be directly related to surgery, according to the authors. The most common complications included pleural tear, wound infection, bleeding and urinary tract infection. Four studies compared open abdominal with open retroperitoneal or posterior approaches in 566 patients. Average LOS was shorter for the posterior approach. In a multivariate analysis, only blood loss was lower for PA.

Twenty series of transperitoneal laparoscopic adrenalectomy included 1,189 patients. Major complications occurred in 0 to 25 percent of patients and minor complications occurred in 0 to 72 percent. Two deaths were reported. The most common complications were bleeding, conversion to open surgery, low or high blood pressure, and wound infection. Of note, in the larger studies both major and minor complications were less common.

Ten series of RLA included 537 patients. Major complications occurred in 0 to 10 percent of patients and minor complications occurred in 0 to 63 percent of patients. One patient died. The most common complications included retroperiotoneal hematoma, subcutaneous emphysema, conversion to a different surgery, pancreatic and splenic injury.

Twenty-eight series compared open and laparoscopic surgery in 1,388 patients. One study found a higher rate of hypotension with the abdominal approach to remove pheochromocytoma. Two studies found fewer complications with laparoscopy than with open approaches. Two studies found no difference in complication rates between different open and laparoscopic approaches. Another found a similar rate of early complications for different approaches, but a higher rate of late complications with posterior approach. The remaining studies did not find any significant differences between specific techniques.

Nine series compared different laparoscopic approaches in 866 patients. None applied statistical methods to complication rates. Two series found no difference in operating time or blood loss.

### Question 4 What are the patient outcomes after surgical excision of adrenocortical carcinoma (morbidity and mortality)? (Table 30, Evidence Table 11)

We found 32 studies with a total of 1,684 patients that met our inclusion criteria and reported data on at least 10 subjects. The number of patients in these studies ranged from 12 to 156. Almost all studies were retrospective. There were wide variations in the quality and amount of reported information about the tumor size, patient characteristics, surgical approaches, and outcomes. Nine studies reported patients who had surgery back in the 1940s and 1950s. One study went back to 1929. The age of the patients ranged from newborn to 85 years.

Table 30. Morbidity and Mortality of Adrenocortical Carcinoma after Surgical Excision

Author, Year | Evaluated, N | Enrollment period | Mean tumor size (range) | Long term survival
Greenberg 1978 | 12 | 1948-75 | ND | 5 y 43%
Sullivan 1978 | 28 | 1950+ | (3.5–20 cm) | 5 y 30%
King 1979 | 49 | 1956-77 | 12.4 cm | 9/49 alive mean 7.2 y post-surgery
Didolkar 1981 | 42 | 1929-77 | (1–30 cm) | 5 y 62%
Nader 1983 | 77 | 1950-81 | ND | 5 y 23%
Henley 1983 | 62 | 1960-80 | 12.4 cm | 5 y 32%
Lefevre 1983 | 42 | 1958-80 | ~350 (20–1400) g | 1 y post-surgery 82%
Watson 1986 | 80 | 1970-79 | 10.5 cm | 2 y 33%
Nakano 1988 | 91 | 1965-82. | ~730 (12–2900) g | Mean survival 18.5 mo
Venkatesh 1989 | 110 | 1944-87 | ND | 5 y disease-free: 42% overall
Borrelli 1989 | 14 | Unclear | (5.4–20 cm) | 2 y 36%
Luton 1990 | 88 | 1963-87 | ~530 (14–3000) g | 5 y 22%
Ribeiro 1990 | 40 | 1966-87 | 256 g | Overall 51%
Grondal 1990 | 54 | 1974-83 | (5–40 cm) | 5 y overall 19%
Padberg 1991 | 16 | ND | 750 (20–3000) g | 7 alive disease-free 4–61 mo; 2 alive with disease 28 & 90 mo
Soreide 1992 | 99 | 1970-85 | ND | 6 y ~60%
Icard 1992 | 156 | 1978-91 | 12±6 (SD) cm | 5 y overall 34%
Pommier 1992 | 73 | 1980-91 | ND | 5 y 47%
Sabbaga 1993 | 55 | 1969-91 | ND | 2 y overall 46%
Zografos 1994 | 53 | 1950-90 | (0.3–35 cm) | 5 y overall 19%
Kasperlik 1995 | 50 | 1965-94 | (3.2–20 cm) | 2 y 29%
Lee 1995 | 23 | 1965-91 | 14.5 (1.7–25) cm | Overall median survival 29 months
Boscaro 1995 | 35 | 1978-93 | 12 (4.5–21) cm | Mean survival 18.5 mo
Evans 1996 | 56 | ND | 15 (5.5–25) cm | 5 y ~40%
Sandrini 1997 | 58 | 1966-92 | ND | Disease-free interval: 60 mo median
Michalkiewicz 1997 | 20 | 1988-94 | 68.5 (11–195) g | Mean survival 29.6 mo
Barzon 1998 | 45 | 1978-95 | 11 (4–21) cm | 5 y overall 29%
Khorram 1998 | 18 | 1975-97 | ~11.9 cm | 5 y overall 58%
Teinturier 1999 | 54 | 1973-93 | 28/54 > 10 cm | 5 y overall 49%
Harrison 1999 | 46 | 1986-96 | 15 (2.5–27) cm | 5 y 36%
Driver 1999 | 14 | 1954-95 | (8–25 cm) | Median survival 52 mo
Tritos 2000 | 24 | 1966-96 | 10 (2–25) cm | 5 y 26%

N, number of subjects; ND, no data; y, years; mo, months; SD, standard deviation

Fifteen of the 32 studies reported perioperative mortality data. Twenty deaths were reported out of a total of 625 patients for an overall perioperative mortality rate of 4.6 percent.

There were diverse methods of reporting the long-term survival. Seventeen studies reported 5-year survival data that ranged from 19 to 62 percent with a median of 34 percent (weighted average of 35 percent). There does not appear to be any important difference in the overall survival rates between the earlier and the more recent series. Most of the studies included patients from a wide range of years thus making it difficult to appreciate if there is any trend over time.

### Question 4.1 Are there data on the influence of age and tumor size on the outcomes? (Table 31)

Eight studies with individual patient follow-up data were identified with a total of 134 cases of adrenocortical carcinoma determined by biopsy or at autopsy. Three studies (Lefevre, Gerard-Marchant, Gubler, et al., 1983; Michalkiewicz, Sandrini, Bugg, et al., 1997; Ribeiro, Sandrini Neto, Schell, et al., 1990) included pediatric cases only, and three studies (Borrelli, Ingenito, Cicchi, et al., 1989; Padberg, Lauritzen, Achilles, et al., 1991; Sullivan, Boileau, and Hodges, 1978) included adults and pediatric cases. The sample from Khorram-Manesh (1998) consisted of adults only, with ages ranging 36 to 76 years. Because of the lack of complete reporting of the data and the variation in the reporting, summary analyses of the influence of age and tumor size on the prognosis after surgery was not possible.

Table 31. Studies with Individual Patient Follow-up Data

Study | Case | Sex | Age | Mass size, cm | Mass weight, g | Stage ^a^ | Procedure | Fwup, months | Survival status
Lefevre 1983 | 2 | F | 3.9 | ND | 750 | ND | resection | 32 | dead
| 5 | M | 13 | | 1400 | | resection | 18 | dead
| 10 | F | 1.0 | | biopsy | | explor lap | 6 | dead
| 13 | M | 4.3 | | 740 | | resection | 21 | dead
| 15 | F | 4.7 | | 820 | | partial | 6 | dead
| 16 | M | 4.4 | | 22 | | resection | 12 | dead
| 17 | M | 4.5 | | biopsy | | explor lap | 48 | dead
| 18 | F | 5.7 | | >1000 | | partial | 132 | alive
| 19 | F | 1.8 | | 50 | | resection | 180 | alive
| 20 | F | 3.6 | | 180 | | partial | 12 | dead
| 22 | F | 1.8 | | 30 | | resection | 80 | alive
| 24 | M | 1.1 | | 300 | | resection | 108 | alive
| 26 | F | 5.4 | | 180 | | resection | 32 | dead
| 27 | F | 4.2 | | biopsy | | explor lap | 9 | dead
| 28 | M | 1.4 | | 295 | | resection | 108 | dead
| 31 | M | 14 | | ND | | partial | 16 | dead
| 32 | F | 11 | | 300 | | resection | 13 | dead
| 33 | M | 0.5 | | 320 | | resection | 9 | dead
| 34 | M | 1.3 | | 150 | | resection | 49 | alive
| 35 | M | 0.5 | | 235 | | resection | 6 | dead
| 37 | F | 2.4 | | 700 | | resection | 10 | dead
| 41 | M | 1.5 | | 500 | | resection | 55 | alive
Michalkiewicz 1997 ^b, c^ | 1 | F | 1 | 4.2 | 42 | low | resection | 74 | ND
| 3 | F | 4 | 3.4 | 30 | high | resection | 58
| 4 | F | 1.9 | 3.7 | 36 | low | resection | 1
| 6 | F | 0.9 | 4.0 | 44 | high | resection | 32
| 9 | F | 1.3 | 4.9 | 60 | low | resection | 44
| 10 | F | 3.5 | ND | 60 | ND | resection | 6
| 11 | F | 4 | 3.4 | 40 | low | resection | 19
| 12 | F | 1.8 | 3.2 | 19 | low | resection | 22
| 13 | F | 3.2 | 2.3 | 8 | high | resection | 33
| 17 | F | 2 | 5.8 | 100 | high | resection | 17
| 18 | F | 0.3 | 4.6 | 100 | low | resection | 14
| 19 | F | 0.8 | 3.2 | 32 | ND | resection | 7
Ribeiro 1990 ^b^ | 1 | ND | ND | 1.7 | ND | ND | resection | ND | ND
| 2 | | | 9.3 | 800 | | resection
| 3 | | | 7.3 | 60 | | resection
| 4 | | | 5.6 | ND | | resection
| 5 | | | 9.7 | 460 | | resection
| 6 | | | 10.6 | 1040 | | resection
| 7 | | | 7.6 | 175 | | resection
| 9 | | | 9.3 | 420 | | resection
| 10 | | | 7.0 | 220 | | resection
| 12 | | | 5.8 | 210 | | resection
| 17 | | | ND | 1320 | | resection
| 18 | | | 8.9 | 390 | | resection
| 19 | | | 3.3 | ND | | resection
| 20 | | | 4.2 | 14 | | resection
| 23 | | | 3.1 | ND | | resection
| 24 | | | 3.8 | 40 | | resection
| 25 | | | 4.1 | 70 | | resection
| 26 | | | 4.2 | 15 | | resection
| 27 | | | 4.5 | 65 | | resection
| 30 | | | 11.3 | 800 | | resection
| 33 | | | 1.9 | 15 | | resection
| 34 | | | 1.8 | 3 | | resection
| 37 | | | 1.8 | ND | | resection
| 39 | | | 3.3 | 17 | | resection
Borrelli 1989 | 1 | F | 18 | 10.7 | ND | high | resection | 9.6 | dead
| 2 | F | 35 | 8.6 | | high | resection | 6 | dead
| 3 | M | 43 | 8.6 | | mod | resection | 1.2 | dead
| 4 | F | 47 | 9.8 | | mod | resection | ND | dead
| 5 | F | 3 | 8.7 | | mod | resection | 30 | dead
| 6 | M | 55 | 20.2 | | mod | resection | ND | dead
| 7 | F | 18 | 5.4 | | high | resection | 2.4 | dead
| 8 | F | 51 | 6.6 | | low | resection | 60 | alive
| 9 | F | 60 | 18.2 | | mod | resection | 48 | alive
| 10 | M | 60 | 11.1 | | high | resection | 2.4 | dead
| 11 | M | 57 | 7.5 | | mod | resection | 36 | alive
| 12 | F | 14 | 8.6 | | mod | resection | 36 | alive
| 13 | F | 27 | 8.6 | | high | resection | 3.6 | dead
| 14 | F | 32 | 9.7 | | low | resection | 12 | alive
Padberg 1991 | 1 | M | 47 | ND | 130 | ND | resection | 7 | dead
| 2 | F | 69 | | 58 | | resection | 2 | dead
| 3 | F | 44 | | 1500 | | resection | 90 | alive
| 4 | M | 2 | | 34 | | resection | 28 | alive
| 5 | M | 62 | | 190 | | resection | 25 | alive
| 6 | F | 51 | | 113 | | resection | 26 | dead
| 7 | F | 57 | | 1300 | | resection | 1 | dead
| 8 | F | 2 | | 20 | | resection | 7 | alive
| 9 | F | 76 | | 250 | | resection | 61 | Alive
| 10 | F | 31 | | 1440 | | resection | 28 | alive
| 11 | F | 40 | | 750 | | resection | 55 | alive
| 12 | F | 40 | | 54 | | resection | 35 | alive
| 13 | F | 44 | | 995 | | resection | 96 | dead
| 14 | F | 61 | | 3000 | | resection | 57 | dead
| 15 | M | 45 | | 280 | | resection | 1 | dead
| 16 | M | 24 | | 1890 | | resection | 31 | alive
Sullivan 1978 | 1 | F | 53 | | ND | 1 | resection | 150 | alive
| 2 | F | 1 | | | 2 | resection | 188 | alive
| 3 | F | 16 | | | 2 | resection | 156 | alive
| 4 | F | 29 | | | 2 | resection | 86 | alive
| 5 | F | 69 | | | 2 | resection | 144 | dead
| 6 | M | 57 | | | 2 | resection | 51 | dead
| 7 | F | 3 | | | 3 | resection | 15 | dead
| 8 | F | 37 | | | 3 | resection | 66 | dead
| 9 | F | 56 | | | 3 | resection | 17 | dead
| 10 | F | 59 | | | 3 | resection | 16 | dead
| 11 | F | 6 | | | 3 | resection | 5 | dead
| 12 | F | 10 | | | 3 | resection | 29 | dead
| 13 | F | 11 | | | 3 | resection | 15 | dead
| 14 | M | 47 | | | 3 | resection | 51 | dead
| 15 | M | 56 | | | 3 | resection | 27 | dead
| 16 | F | 37 | | | 3 | resection | 7 | dead
| 17 | F | 43 | | | 4 | biopsy | 1 | dead
| 18 | M | 46 | | | 4 | biopsy | 9 | dead
| 19 | F | 55 | | | 4 | resection | 12 | dead
| 20 | F | 58 | | | 4 | resection | 4 | dead
| 21 | M | 39 | 11.0 | | 4 | resection | 3 | dead
| 22 | M | 40 | | | 4 | biopsy | 2 | dead
| 23 | F | 42 | | | 4 | biopsy | 0.03 | dead
| 24 | F | 52 | | | 4 | biopsy | 10 | dead
| 25 | M | 59 | | | 4 | resection | 5 | dead
| 26 | M | 60 | | | 4 | biopsy | 0.25 | dead
| 27 | M | 61 | | | 4 | biopsy | 0.25 | dead
| 28 | M | 63 | | | 4 | autopsy | 0.25 | dead
Khorram-Manesh 1998 | 1 | ND | 36–76 | 10.0 | | 2 | resection | 288 | alive
| 2 | | | >5 | | 4 | resection | 1.5 | dead
| 3 | | | >5 | | 3 | resection | 71 | alive
| 4 | | | 20.0 | | 2 | resection | 176 | alive
| 5 | | | 17.0 | | 2 | resection | 159 | alive
| 6 | | | 15.0 | | 4 | resection | 136 | alive
| 7 | | | 15.0 | | 4 | resection | 9 | dead
| 8 | | | 15.0 | | 2 | resection | 72 | dead
| 9 | | | 24.0 | | 2 | resection | 81 | alive
| 10 | | | 10.0 | | 4 | resection | 4 | dead
| 11 | | | 11.0 | | 2 | resection | 42 | dead
| 12 | | | 11.0 | | 2 | resection | 78 | alive
| 13 | | | 13.0 | | 4 | resection | 4 | dead
| 14 | | | 7.0 | | 4 | resection | 14 | Dead
| 15 | | | 9.0 | | 2 | resection | 16 | alive
| 16 | | | 12.0 | | 2 | resection | 14 | alive
| 17 | | | 17.0 | | 4 | resection | 3 | dead
| 18 | | | 6.0 | | 2 | resection | 9 | alive

Fwup, follow-up; F, female; m, Male; ND = no data; explor lap = exploratory laparotomy.

a Staging by MacFarlane.

b Data extrapolated from volume as reported in paper.

c Histology grade.

Medline or unique identifying number assigned by EPC

Individual patient data from three studies (Borrelli, Ingenito, Cicchi, et al., 1989; Khorram-Manesh, Ahlman, Jansson, et al., 1998; Padberg, Lauritzen, Achilles, et al., 1991), showed adults with large and small tumors surviving 2 to 5 years as well as having survival periods of a few months.

Three studies (Borrelli, Ingenito, Cicchi, et al., 1989; Padberg, Lauritzen, Achilles, et al., 1991; Sullivan, Boileau, and Hodges, 1978) offered individual patient data on age and survival with no discernable trends in survival. For each decade of age there were one or two individual patients who had 5 year survival. Short-term survivors of 1 to 6 months were also randomly spread across the age ranges.

Not surprisingly, the prognosis for the patient tended to be better for tumors discovered at earlier stages. In Sullivan (1978), all five of the 28 cases that survived were stage I or II with a follow-up from 86 to 188 months. Khorram-Manesh (1998) reported that eight of the ten stage II cases, as well as the single stage III case were alive at the end of the follow-up period. Of the seven patients with stage IV tumors, only one survived at 136 months, and of the other six cases, only one lived beyond 1 year. Using a histologic degree of malignancy to grade tumors, Borrelli (1989) reported five tumors graded as high had 100 percent mortality. None lived to 1 year. The other five tumors classified as moderate grade and two tumors as low grade were not a predictor of mortality.

Three studies (Borrelli, Ingenito, Cicchi, et al., 1989; Padberg, Lauritzen, Achilles, et al., 1991; Sullivan, Boileau, and Hodges, 1978) reported individual data on sex, functional status of the tumor, and mortality revealed a trend of shorter survival for adult males. Of the 18 adult males in three studies, only three survived beyond 24 months and were still alive at the end of the follow-up period. Two died at 51 months each, but none survived to 5 years. In addition the males also had a higher percentage of nonfunctioning tumors at 78 percent. This compares to 31 to 38 percent for adult females. Because males tended to have nonfunctioning tumors, it may have led them to seek out treatment when the tumor had progressed to a late stage.

Fourteen studies consistently reported nonfunctioning tumors to be predominant in males (Barzon, Fallo, Sonino, et al., 1997; Boscaro, Fallo, Barzon, et al., 1995; Didolkar, Bescher, Elias, et al., 1981; Greenberg and Marks, 1978; Grondal, Cedermark, Eriksson, et al., 1990; Henley, van Heerden, Grant, et al., 1983; Icard, Chapuis, Andreassian, et al., 1992; King and Lack, 1979; Luton, Cerdas, Billaud, et al., 1990; Nader, Hickey, Sellin, et al., 1983; Nakano, 1988; Soreide, Brabrand, and Thoresen, 1992; Tritos, Cushing, Heatley, et al., 2000; Venkatesh, Hickey, Sellin, et al., 1989), though there were conflicting results on sex or functional status as a predictor of survival rates.

None of the three pediatric studies that presented individual data could be generalized because of the lack of consistency in the reported data.

### Questsion 5 What evidence is there to support the use of periodic biochemical and imaging studies to follow untreated adrenal masses? (Evidence Tables 12, 13)

For subjects who presented with incidentally discovered adrenal masses, there are four prospective studies with established follow-up protocols for untreated patients. Two studies (Barzon, Scaroni, Sonino, et al., 1999; Jockenhovel, Kuck, Hauffa, et al., 1992) are clearly prospective, one is ambiguous (Kologlu, Akyar, Baskal, et al., 1988), and one study (Siren, Tervahartiala, Sivula, et al., 2000) identified patients retrospectively from medical records but prospectively follows the patients who gave consent. The studies by Kologlu, Akyar, Baskal, et al. (1988) and Jockenhovel, Kuck, Hauffa, et al. (1992) did not report any exclusion criteria whereas the study by Barzon, Scaroni, Sonino, et al. (1999) excluded patients with hormonally active tumors, cysts, and/or malignant tumors. The exclusion criteria in Siren, Tervahartiala, Sivula, et al. (2000) included the absence of malignancy or hormonally active tumors. The total number of patients in these four studies before follow up is 132. An age range of 19 to 80 is reported by Siren, Tervahartiala, Sivula, et al. (2000) for 27 patients but only 16 were followed. Complete follow-up data for the four studies is available for 109 subjects, the age range is 21–77 years, and the range of tumor size is 0.8–5.6 cm.

Three of the four studies utilized an imaging technology, CT or MRI, in combination with biochemical tests. Jockenhovel, Kuck, Hauffa, et al. (1992) conducted CT scans with biochemical tests with a median follow-up of 32 months (11–101) on 18 subjects. Only one tumor increased in size of 0.5 cm, two previously discovered tumors disappeared, and 15 remained unchanged. Barzon, Scaroni, Sonino, et al. (1999) followed 75 subjects at six-month intervals the first year and yearly thereafter for a median of 4.6 years (2–10). CT or MRI was used in combination with biochemical tests. Fifty-eight subjects had no changes, two had decreased tumor size, and 15 experienced hormonal changes or increase in tumor size. Siren, Tervahartiala, Sivula, et al. (2000) reported follow-up data on 16 subjects one year after initial CT with a mean of 98 months follow up (53–196). All hormonal tests proved normal. MRI imaging showed no changes in seven tumors (in five patients), absence of previously discovered tumors in four patients, increase in size in five tumors (four patients) and decrease in size in three tumors (three patients). One study (Kologlu, Akyar, Baskal, et al., 1988), utilized serial CT but stated that ‘several’ tests were conducted at three or six-month intervals but there were no follow-up data or outcomes.

Overall, 121 patients were followed, and of these, 78 subjects had no changes, 20 had increases in tumor size, and 11 had decreases in tumor size or absence of previously discovered tumor on imaging scans. There were two cancer deaths unrelated to adrenal pathology. Adenoma was confirmed at autopsy.

There are five studies that focused on the management of adrenal tumors but have no structured protocol for follow-up with regards to a predetermined time interval for testing. In addition, because some patients received treatment, a subset of the subjects was followed for each study. Exclusion criteria include adrenalectomy, diagnoses made at different institutions, and the presence of cysts, myelolipoma, and hormonally active tumors. One hundred forty-two of 341 participating patients were not treated and followed for 1 month to 12 years. Follow-up tests included CT in all studies--two studies (Barry, van Heerden, Farley, et al., 1998; Reincke, Winkelmann, Jaursch-Hancke, et al., 1989) utilized CT alone, one study (Mitnick, Bosniak, Megibow, et al., 1983) used serial CT but no information was available as to how many tests were conducted. Glazer, Weyman, Sagel, et al. (1982) used a combination of CT, clinical exam and biochemical tests, while Courtade, Carnaille, Ernst, et al. (1997) used CT, MRI, clinical exam, and telephone contact. Tumor changes were reported only as increases in size in four tumors in the large study of 91 subjects followed by Barry, van Heerden, Farley, et al. (1998).

Three studies had fewer than 20 participants each, showing no change, and the study by Courtade, Carnaille, Ernst, et al. (1997) with 44 patients did not report tumor change. In fact, due to confusing definitions and reporting, the follow up data in that particular paper cannot be reliably derived. Of the aggregate population of 341 in the five studies, the age and tumor size range from 5 to 86 years and 0.6 to 10 cm, respectively.

Overall, 124 patients were followed (rejecting the uncertain data in Courtade, Carnaille, Ernst, et al. (1997)), and of these, 120 had no changes and four had increases in tumor size. There were 81 cancer deaths unrelated to adrenal pathology.