# Methods

Our evidence report on the management of clinically inapparent adrenal mass is based on a systematic review of the literature. Meetings and teleconferences of the EPC staff with technical experts were held to identify specific issues central to this report. A comprehensive search of the medical literature was conducted to identify studies addressing several key questions. We compiled evidence tables of study characteristics and results, appraised the methodological quality of the studies, and summarized their results.

## Key Questions Addressed in this Report

The purpose of an evidence report is to summarize information from relevant studies addressing specific key questions. It is beyond the scope of an evidence report to cover all possible related issues for a topic. Speakers at the State-of-the-Science Conference covered other relevant issues within this topic. The following key questions were addressed in this report:

Question 1. What are the causes and prevalence of clinically inapparent adrenal masses?

- 1.1 What are the causes of clinically inapparent adrenal masses identified by CT, MRI, or US that are confirmed by histology?
- 1.2 What are the prevalence rates for the various causes of inapparent adrenal masses?Are there differences in the rates among the initial diagnostic tests used?
- 1.3 What is the relationship of the age and sex of the patient to the likelihood of having a particular pathology?
- 1.4 What is the relationship of the size of the mass with the likelihood of having a particular pathology?

Question 2. What is the diagnostic accuracy (sensitivity, specificity) of evaluation modalities (FNA/biopsy, CT, MRI, US, biochemical tests) used to differentiate adrenal masses (adrenal carcinoma, pheochromocytoma, adenoma, adrenal hyperplasia, etc.)?

- 2.1 What is the risk of the metastatic spread of adrenal carcinoma by FNA?

Question 3. What are the surgical complication rates for various approaches used to excise adrenal masses; specifically laparoscopic, transabdominal, and retroperitoneal approaches?

Question 4. What are the patient outcomes (morbidity and mortality) after surgical excision of adrenocortical carcinoma?

- 4.1 Are there data on the influence of age and tumor size on the outcomes?

Question 5. What evidence exists to support the use of periodic biochemical and imaging studies to follow untreated adrenal masses?

## Definition of Adrenal Incidentaloma

As we discussed in the introduction of this evidence report, there is wide variation in the definition of adrenal incidentaloma. Applying a strict definition (asymptomatic patient without known cancer and without evidence of adrenal biochemical activity, category H in Figure 1) would likely result in very few studies qualifying for evaluation. Furthermore, because most of the published studies on this topic are retrospective and have methodological problems, it is unclear whether this strict approach would be useful. Therefore, rather than choosing a single definition of incidentaloma that may exclude many potentially relevant studies, we accepted all studies that used their own definitions of incidentaloma.

## Literature Search

Studies were identified primarily through a Medline search of English language literature published between 1966 and October 2000. We also consulted technical experts and examined references of published meta-analyses and selected review articles to identify additional studies.

Using the PubMed search engine, the staff at the National Library of Medicine conducted a search on the databases Medline, PreMedline, BIOSIS, and Embase on September 19–20, 2000. A combination of search terms was used to map to the subject heading, publication title, or publication abstract. Additional filters or limitations were not used. The searches resulted in 2,636 citations, of which 2,323 came from Medline, 21 from PreMedline, 85 from BIOSIS, and 207 from Embase.

The content of the original key questions was later expanded, and the EPC conducted an updated Medline search on March 21, 2001, using the OVID search engine. Additional subject headings were included to address questions on diagnostic accuracy, surgical complication rates as well as morbidity and mortality outcomes for adrenal masses, and monitoring technologies for untreated adrenal masses. The search yielded an additional 2,750 citations. A final Medline update of surgical series was conducted on October 10, 2001, yielding an additional 41 citations.

## Study Selection

The literature searches yielded a total of 5,386 independent citations. The abstracts were screened manually and either categorized to one or more of the key questions or rejected. After screening, we retrieved 602 articles for further examination. Reports published only as letters or abstracts in proceedings were excluded. Specific inclusion criteria and methods of synthesis, developed for each of the key questions, are discussed below. In general, the EPC included all English language studies with at least 10 human subjects. There were no age limitations.

## Summarizing the Literature

About 194 articles met our inclusion criteria for one of the key questions and were included in the evidence report. Forty-five studies provided data about the prevalence of incidentaloma or the distribution of adrenal pathologies. Thirty-one studies evaluated various diagnostic tests to differentiate adrenal masses. Over 80 studies provided outcome information on various adrenal surgical techniques. Thirty-two studies reported prognostic information on patients with adrenal carcinoma after surgical excision, and nine articles reported results of follow-up strategies.

We report the evidence in three forms. The evidence tables offer a detailed description of the studies that we identified addressing each of the key questions. Summary tables report on each study in an abbreviated form using summary measures of the main outcomes. Finally, for several key questions, we provide an overall summary of information presented in various related summary tables.

Evidence tables provide detailed information about the study design, patient characteristics, inclusion and exclusion criteria, intervention or test evaluated, and the outcomes. Where appropriate, we graded the studies according to the methodological quality, applicability, size, and the effect or test performance. The specific methodologies and the results for each key question are presented in the respective sections in the evidence report.

The evidence tables are condensed into summary tables to provide a more succinct impression of the study quality and results. Summary tables include the important variables regarding study size, patient population (location of study, tumor size and type), outcome measures, and methodological quality. Summarizing the data in such a way allows for ease of comparison among studies. The study (sample) size offers a measure of the weight of the evidence. In surgical series, it also indicates the experience of the surgeons with that particular technique. In general, larger studies provide a more precise estimate of the effect in question, though patient population governs more the applicability of any given study

### Specific Selection Criteria of Articles and Methods of Synthesis for Each Key Question

#### Question 1. What are the causes and prevalence of clinically inapparent adrenal masses?

We used autopsy series in order to estimate the rates of adrenal adenoma. Both prospective and retrospective series were searched to gather data about the prevalence of adrenal incidentaloma and the likelihood of various adrenal pathologies among incidentalomas.

#### Question 2. What is the diagnostic accuracy of the various evaluation modalities used to differentiate adrenal masses? What is the risk of metastatic spread of adrenal carcinoma by FNA?

We searched for articles on any diagnostic test of adrenal masses. We specifically included articles on CT, MRI, US, scintigraphy, biochemical tests, and FNA; however, studies of other diagnostic tests were also included. To qualify for inclusion, articles must have reported sufficient data to comment on the performance of a diagnostic test. Our initial screening of abstracts and articles included only studies of subjects with incidentalomas. However, because very few studies met these criteria, and many studies did not clearly define their eligibility criteria, we decided to include all studies of subjects with incidentalomas, adrenal masses found during extra-adrenal cancer evaluation (i.e., staging or search for a primary tumor), or “adrenal masses.” We excluded studies whose subjects primarily or exclusively had subjects with clinically suspected adrenal masses. Because the initial screening of abstracts excluded articles without incidentalomas, the subsequent set of included studies of cancer patients or those with adrenal masses is not comprehensive and can only be considered as representative of all the studies of these populations.

Due to the different prevalence of disease in different populations of patients, we categorized the studies into five groups according to their eligibility criteria. These included 1) incidentally-discovered adrenal masses (incidentalomas); 2) adrenal masses found during extra-adrenal cancer evaluation; 3) adrenal masses (no further description); 4) incidentally-discovered adrenal adenomas only; and 5) clinically-suspected adrenal masses.

Outcomes Considered. The principle measures of test performance were sensitivity and specificity. Whenever possible, we extracted the number of subjects with true positive, true negative, false positive, and false negative tests. We then calculated the sensitivity (percentage of subjects with the outcome of interest who have a (true) positive test) and specificity (percentage of subjects without the outcome of interest who have a (true) negative test). If the data could not be extracted, we relied on reported values of sensitivity, specificity, or, if necessary, other measures of test performance (e.g., accuracy -- total percentage of subjects with either true positive or true negative tests). If authors reported test performance at multiple thresholds (e.g., different density values on CT) or provided raw data, we included the performance at each threshold in the summary tables. Some studies (especially those studies of scintigraphy) did not explicitly calculate test performance. For these studies we calculated test performance to maximize sensitivity.

Of note, tests with multiple thresholds demonstrate a trade-off between sensitivity and specificity. By lowering the threshold for a positive test, high sensitivity can be achieved at the expense of specificity, while raising the threshold has the opposite effect. As a result, studies that include only subjects with disease are of limited value, because only sensitivity, but not the associated specificity can be calculated. If the sensitivity is high, it may be simply that the threshold is set too low and specificity is close to zero. It is the combination of sensitivity and specificity that defines test performance.

Several studies evaluated test performance at multiple thresholds and used receiver operating characteristics (ROC) curve analysis to compare different tests. ROC curves offer a convenient means of graphically displaying the trade-off between sensitivity and specificity. In this method, sensitivity and specificity pairs are plotted for multiple thresholds. The area under the resulting ROC curve (AUC) can then be calculated. By definition, tests that have perfect test performance (100 percent sensitivity and specificity) have an AUC of 1.0; tests that provide no diagnostic information (50 percent sensitivity and specificity) have an AUC of 0.5. Different tests for the same diagnosis can thus be compared by measuring their respective AUCs. Those with a higher AUC can be considered superior to those with a lower AUC. This method is most valid when comparing different tests performed on the same subjects.

Study quality. The internal validity of each study was graded based on study design, conduct, and reporting of the clinical study. For studies of diagnostic test performance, we used a three-category scale to provide some indication of the methodological quality of each study summarized:

Grade A (least bias) - a study that mostly adheres to the traditionally held concepts of high quality diagnostic evaluation, including: prospective design, clear description of the population and setting, the reference standard, the test under investigation, and the diagnostic criteria; blinded interpretation of the reference tests and the test under investigation; verification of the diagnoses in all or most of the patients with negative results; no reporting errors that might hide substantial bias.

Grade B (susceptible to some bias) - a study that does not meet all the criteria of category A. It has some deficiencies, but none likely to cause major bias.

Grade C (likely to have significant bias) - a study with significant design or reporting errors that cannot preclude major bias. This category includes studies in which verification bias could be a large issue and studies that have large amounts of missing information or discrepancies in reporting.

Complications of fine needle aspiration. We searched for articles on FNA or adrenal biopsy. To qualify for inclusion, articles must have reported on short- or long-term procedure complications. Because of the almost complete lack of data specific to metastatic spread of adrenal carcinoma due to FNA, we broadened our eligibility criteria to include all complications. Studies that did not mention complications (either in the positive or the negative) were excluded. Similar to the search for diagnostic tests, our initial screening of abstracts and articles included only studies of subjects with incidentalomas. But since so few studies met these criteria we subsequently included any study of subjects with adrenal masses.

The internal validity of each study was graded based on study design, conduct, and reporting of relevant data. For studies of FNA complications, we used a three-category scale to provide some indication of the methodological quality of each study summarized:

Grade A (least bias) - a study that mostly adheres to the traditionally held concepts of high study quality, including: prospective design, clear description of the population and setting, the biopsy technique under investigation, and a priori definitions of complications; longitudinal follow-up of subjects; proper statistical analysis; complete reporting of complication data and no reporting errors that might hide substantial bias.

Grade B (susceptible to some bias) - study that does not meet all the criteria of category A. It has some deficiencies, but none likely to cause major bias.

Grade C (likely to have significant bias) - a study with significant design or reporting errors that cannot preclude major bias. This category includes studies with inadequate methodology and studies that have large amounts of missing information or discrepancies in reporting.

#### Question 3. Risk and Complication Rates of Different Surgical Techniques

To address this question, we aimed to identify the various complications associated with different surgical approaches to adrenalectomy, in the context of the larger question of adrenal incidentaloma. Therefore, we concentrated on surgery for tumors that ostensibly could have represented incidentalomas, such as adrenal adenomas, but we did not address the issues of Cushing's disease or adrenal hyperplasia.

We included all studies that enrolled at least 10 patients, and excluded articles that did not explicitly state the surgical approach or did not list any surgical outcomes. When one author or institution published multiple articles containing the same patients, we included only the largest series. In October 2001 we conducted a supplementary search for articles published after our initial search. Due to time constraints, we included only those series with at least 50 patients. Overall, there were 81 articles that met our inclusion criteria.

Study population. Adrenal surgeries are performed only when the diagnoses of adrenal pathologies have been established. Thus, there are no surgical series on patients with adrenal incidentalomas. Adrenal pathologies necessitating surgery can occur at any age and in either sex, so we did not exclude any particular population based on age or sex. There were no studies that listed race as a variable, but most studies listed the country where the study was conducted. Tumor size and type perhaps best represent patient population. We excluded studies of adrenalectomy performed exclusively for indications such as Cushing's disease, which would not apply directly to incidentaloma. Studies of patients with hormone secreting tumors, including pheochromocytomas, were included, as these tumors may occasionally present as incidentalomas. We also included studies of aldosteronomas, which rarely present as incidentalomas, because we presumed that the complications from adrenalectomy for aldosteronomas would be similar to the complications from other similarly sized adenomas. When the data were available, the initial indication for surgery, as well as the final pathology, mean tumor size and range, were recorded in the evidence tables. Patient demographics and co-morbidities, location and nature of the study institution were recorded as well.

Outcomes considered. Although we were asked to consider the surgical complications of adrenalectomy, we found no standardized definition of complication. Most study authors collected operative time, blood loss, analgesic use, length of stay, mortality, and numbers of specific complications resulting from each procedure. Operative time also lacks a standardized definition and may represent total operating room time, skin-to-skin, or skin-to-gland-removal. Most authors did not specify their definition, but we noted it when they did. In addition, operative time could include a unilateral or bilateral adrenalectomy. When authors reported stratified results for unilateral and bilateral procedures, we included both times in the evidence table, but only the unilateral data in the summary table.

Blood loss is usually measured during the operation and recorded. Unfortunately, blood loss does not capture post-operative bleeding, which may be severe, nor does it address the more patient-centered outcome of transfusion. We recorded transfusions under the heading of major complications.

Analgesic use varied widely among institutions. There was no standard drug, method of administration, nor even a unit of measurement. Moreover, analgesic use was not always controlled by the patient, but rather by the attending surgeon.

Length of stay offers a potentially useful proxy for surgical complications. Unfortunately, length of stay may be confounded by secular changes in hospital practice over the span of many publication years, by social factors, by concurrent surgical or medical problems not directly related to the surgery, and by cultural expectations of the patients.

Most studies report some figure for mortality. While the definition of intraoperative mortality is clear, the definition of perioperative mortality is vague. The number of deaths in all series was small, and individual deaths were described in detail. There was no intra-operative mortality. We included all deaths within 30 days of surgery and noted when the author felt that the death was unrelated to surgery, which occurred in every case. Because complications were heterogeneous and often unique, we found it difficult to generate an overall rate. For the evidence table, we recorded the number and type of each individual complication in as much detail as possible.

Data extraction. Data extracted included study year, procedural approach, patient demographics, location and nature of the study institutions, inclusion and exclusion criteria, study design and enrollment years, surgical indication and pathology, patient co-morbidities and American Society of Anesthesiologists (ASA) score, tumor size, operative time, blood loss, mortality, post-operative analgesia requirements, length of stay, and complications.

##### Summarizing the Evidence

Applicability (population and indication). Applicability in this series is governed by study location, tumor size and tumor type. Study location includes non-measurable variables such as surgical culture, institutional support, or patient expectations. Surgical culture (the local practices of surgeons) may influence certain outcomes, such as the placement of post-operative drains, or govern the use of intra-operative antibiotics or prophylaxis for deep vein thrombosis, which may affect complication rates, yet are unrelated to the specific procedure. Institutional support may determine how fast patients can be discharged after complicated operations such as pheochromocytoma. Patient expectations may affect different outcome variables such as length of stay or post-operative analgesic use. Furthermore, some subjective complications, such as local pain or paresthesia, may go unrecognized unless patients report them, or investigators ask specifically.

Tumor size and type are particularly useful in judging the applicability of a study to a particular patient known to have a tumor of that size or type. In particular, there is debate in the literature regarding the appropriate procedure to be used for large tumors, pheochromocytomas, adrenal carcinomas and metastatic disease. We captured the mean tumor size and range, as well as the percentage of patients with pheochromocytoma, adrenal carcinoma and metastatic disease. These features are also useful for comparing groups within the same study, when the two study arms are often drawn from different populations. These summary measures allow the reader to judge whether the historical controls chosen by the authors are indeed comparable to the study patients.

Estimating the complication rates. For each study we summarized the operative time, blood loss, length of stay and complication rate. We did not include post-operative analgesic use, because the measures were so diverse, and no comparable metrics could be devised. For operative time, blood loss, and length of stay, we reported the values for unilateral adrenalectomy, if results were stratified by operation. For studies that did not segregate their results, we reported the overall operative time, blood loss, and length of stay, all of which will be proportionately higher depending on the percentage of bilateral cases.

For complication rates, we classified complications as mortality, major or minor complications. We included 30-day post-operative mortality, as well as a comment when and if the author felt that death was not a direct outcome of surgery. Complications were classified according to the classification system developed by Clavien (Clavien, Sanabria, and Strasberg, 1992). We listed as minor all complications that were Clavien grade I. These include all events that, if left untreated, would have spontaneous resolution, or can be treated with a simple bedside procedure involving little or no anesthesia. They require no drugs other than analgesic, antipyretic, antiemetic, antidiarrheal, or drugs for treatment of urinary retention or lower urinary tract infection. They do not result in hospital stay greater than twice the median for the given procedure. All other complications, including Clavien grade II and III, were classified as major. These included potentially life-threatening complications, those requiring additional procedures, prolonged hospital stay, iatrogenic injury, residual disability and organ resection.

##### Grading the Methodological Quality of the Surgical Series

For ease of comparability, we graded the methodological quality (internal validity) of each of the studies using the following scheme:

Grade A (least bias) - a multicenter (or multi-surgeon) prospective series with matched controls, applying the same exclusion criteria to all study arms. Non-comparative case series of consecutive cases with data collected prospectively and no exclusions of difficult cases or bad outcomes (intention-to-treat analysis).

Grade B (susceptible to some bias) - a single surgeon retrospective case series with matched controls and exclusion criteria the same for all study arms. Retrospective non-comparative case series of consecutive cases without exclusions.

Grade C (likely to have significant bias) - a study with no matched controls or unequal treatment of the study arms. Non-consecutive cases due to exclusions.

Grade I (indeterminate) - a study with insufficient information to determine quality.

Summarizing the evidence for each surgical technique. We also constructed a summary table for each surgical technique and its comparisons. Summary tables for techniques include a single line summarizing the number of studies and patients, the range of tumor size and type, the ranges for each outcome, and for comparisons, the number of studies finding each technique to be advantageous. Finally, each table lists the number of studies for each of the methodological grades.

The summary table is intended to supply an overall picture for each surgical technique of the quantity of evidence, the quality of that evidence, and the main outcomes, or at least the ranges of evidence. In the comparison studies, it is also helpful to see the number of studies finding a statistical difference between the various approaches. Due to the wide variability of the study designs and definitions, we did not attempt to combine the data across studies.

#### Question 4. What are the patient outcomes after surgical excision of adrenocortical carcinoma (morbidity and mortality)?

This question is not specifically about adrenal mass incidentally found. A separate literature search was conducted to identify surgical studies of adrenocortical carcinoma that reported outcome data. Both retrospective and prospective studies qualify although mostly retrospective studies were found. We extracted information about the mean age of the study population, sex, study design, enrollment year of the study, procedures performed, mean tumor size, mean study follow-up duration, short term outcomes and long term survival information.

#### Question 5. What evidence is there to support the use of periodic biochemical and imaging studies to follow untreated adrenal masses?

We looked for studies that prospectively applied pre-specified imaging or biochemical testing protocols to a population of patients with untreated incidentally discovered adrenal masses as part of their follow-up strategies. To supplement the few studies that we found with pre-specified protocols, we also accepted studies that reported analyses of patients followed with unspecified protocols. A total of nine studies were included in this report.