# Introduction

## Overview

The Office of Medical Applications of Research (OMAR) at the National Institutes of Health requested that the Agency for Healthcare Research and Quality (AHRQ), through its Evidence-based Practice Center (EPC) program, produce an evidence report for a State-of-the-Science conference on the topic of Management of the Clinically Inapparent Adrenal Mass.

EPCs generally review relevant scientific literature on assigned clinical care topics and produce evidence reports and technology assessments, conduct research on methodologies and the effectiveness of their implementation, and participate in technical assistance activities. The purpose of evidence reports is to search for and summarize evidence on several key questions on a specific topic. It is usually beyond the scope of an evidence report to comprehensively cover all relevant questions on a single topic. EPCs collaborate with science partners to formulate specific key questions. As specified by AHRQ in the EPC program, evidence reports do not make specific clinical recommendations, however, recommendations for future research are typically provided. Public and private sector organizations may use the reports and assessments as the basis for their own clinical guidelines and other quality improvement activities.

This evidence report summarizes the evidence on several key questions on the management of the clinically inapparent adrenal mass. These masses are also commonly known as “incidentaloma” in the medical literature. These two terms will be used interchangeably in this report. The key questions were formulated by the State-of-the-Science Conference planning committee composed of staff from OMAR, National Institute of Child Health and Human Development, National Cancer Institute, national and international experts on this topic, as well as the EPC staff. Anticipating that most of the data available to address the key questions will come from case series and retrospective cohorts, the EPC was also asked to develop a discussion paper on the biases of case series and the potential hazards in making recommendations from case series reports (Appendix C).

## Clinically Inapparent Adrenal Mass

The widespread use of computed tomography (CT), diagnostic ultrasound imaging (US), and magnetic resonance imaging (MRI) has resulted in the incidental discovery of asymptomatic adrenal masses. While there is little debate about the management of large adrenal masses, there are disagreements in the recommendations for the management of small adrenal masses 1 to 6 cm in size.

A major concern for investigating small adrenal masses is the detection and treatment of early adrenal carcinoma. A highly lethal disease, adrenal carcinoma is nevertheless rare, and the search for it must balance the morbidity and mortality resulting from the search against the possible improvement in the outcome of proven carcinoma.

Most reported adrenal carcinomas are large and patients are often symptomatic. The overall prognosis is poor even with surgical removal (Pommier and Brennan, 1992). There is no current effective chemotherapy. Some practitioners have advocated surgical removal of all incidentally discovered adrenal masses, the rationale being that complete and early removal of small potentially cancerous lesions could be life saving (Seddon, Baranetsky, and Van Boxel, 1985). However, removal of all such lesions would result in unnecessary surgery for most patients.

Many approaches have been proposed to manage patients with adrenal incidentalomas. These proposals include repeated CTs at intervals of 2, 4, 6, 12 and 18 months to detect changes in lesion size; needle biopsy, MRI, and radioisotope imaging have been proposed to distinguish adenoma and pheochromocytomas (Abecassis, McLoughlin, Langer, et al., 1985; Belldegrun, Hussain, Seltzer, et al., 1986; Bernardino, 1988; Copeland, 1983; Geelhoed and Druy, 1982; Glazer, Weyman, Sagel, et al., 1982; Guerrero, 1985; Katz and Shirkhoda, 1985; Mitnick, Bosniak, Megibow, et al., 1983; O'Leary and Ooi, 1986; Prinz, Brooks, Churchill, et al., 1982; Seddon, Baranetsky, and Van Boxel, 1985; Thompson and Cheung, 1987; Wood, Delbridge, and Reeve, 1987). Many of these recommendations appear to reflect subspecialty selection bias and the personal experiences of the authors. Several recent studies suggest that removal of small incidentalomas is unnecessary and that repeat CT scanning is of limited benefit (Barry, van Heerden, Farley, et al., 1998; Barzon, Scaroni, Sonino, et al., 1999).

Recent studies have reported that some of these adrenal adenomas may have subtle cortisol production and abnormalities in the hypothalamus-pituitary-adrenal axis. The patients with these tumors have subclinical Cushing's Syndrome and are associated with hypertension and other metabolic derangements (Rossi, Tauchmanova, Luciano, et al., 2000). Estimates of the prevalence of this condition has ranged from 5 to 16 percent. Verification of these findings in future studies will add another layer of complexity to the management of this condition.

### Definition of Adrenal Incidentaloma

Adrenal incidentaloma is generally defined as unexpected adrenal masses seen on diagnostic imaging studies (Reinig, Doppman, Dwyer, et al., 1986) performed for purpose other than imaging the adrenal glands, in patients without signs and symptoms of adrenal pathologies. However, varying definitions in the literature could lead to different meaning and interpretations of the data. For example, Aso and Homma (1992) used the following definition: “Incidental adrenal tumors were defined as adrenal tumors that were detected incidentally primarily as adrenal lesions on occasions unrelated to tumor signs and symptoms. Under the definition, previously unsuspected adrenal masses found at a routine health examination, or during diagnostic or therapeutic procedures for unrelated diseases were considered to be incidental adrenal tumors even if the patient retrospectively proved to have had symptoms or signs attributable to an adrenal tumor.”

Including patients with signs and symptoms attributable to an adrenal tumor will increase the proportion of large masses, which are more likely to be cancerous. Including symptomatic, biochemically active tumors will increase the proportion of pheochromocytomas. Conversely, studies that exclude patients with signs or symptoms will find a greater proportion of small masses and biochemically silent tumors. Some studies categorize adrenal tumors discovered as part of the workup for abdominal pain as incidentalomas. While adrenocortical carcinoma may not have been suspected initially in patients with abdominal pain, clearly this symptom is a potential manifestation of this tumor, especially when it is large.

### Issues with Adrenal Incidentaloma

Adrenal incidentaloma is not a single pathological entity. Adrenal adenoma, adrenocortical carcinoma, pheochromocytoma, cyst, metastasis from primary cancers, and various benign tumors may all present as incidentalomas. The underlying distribution of adrenal pathology in incidentaloma is influenced by a number of factors. These include the history or the presence of known cancer, age, reason for performing the test that led to discovery of incidentaloma, presenting signs and symptoms, and the performance characteristics of the test itself. The likelihood of any particular pathology is further modified by the findings on the imaging study (mass size, appearance) and biochemical activity of the tumor. Appropriate management depends on understanding these factors and how they influence the probability that the incidentaloma is a particular tumor. Unfortunately, published reports are inconsistent in applying inclusion and exclusion criteria for these various factors, making the results difficult to interpret. For example, authors have both included and excluded biochemically active tumors in their published reports. Obviously, those who exclude biochemically active tumors report very few of these tumors as a cause of incidentaloma.

Figure 1 illustrates the effect of applying various commonly considered criteria to define adrenal incidentaloma. By categorizing patients according to recent history of cancers known to have the potential of metastasizing to the adrenals, signs and symptoms of adrenal biochemical activity, and signs and symptoms attributable to adrenal diseases (abdominal enlargement or pain), we form eight different categories of patients with a different distribution of adrenal pathologies. Category H has the strictest inclusion criteria and represents the purest definition of incidentaloma. An example from this category might be an incidentaloma found in a patient who underwent a chest CT for solitary pulmonary nodule that turns out to be a benign granuloma.

Figure 1. Possible presentations of incidentally discovered adrenal masses during imaging studies. The size of the ellipse is not representative of the likelihood of findings

While the probability of the adrenal mass being a metastasis is relatively low in patients without a known cancer, the probability could be quite high in breast cancer patients (Abrams, Spiro, and Goldstein, 1950). This group of patients belongs to category D.

Applying criteria other than the ones shown in Figure 1 would generate other distributions of adrenal pathologies. Published clinical studies often used variations of inclusion and exclusion criteria that result in mixtures of different categories, further confounding the interpretation of prevalence data. The retrospective nature of most of the published studies makes interpretation even more difficult.

### Pathologic Entities of Incidentally Discovered Adrenal Masses

Adenomas comprise the vast majority of incidental asymptomatic adrenal masses. Pheochromocytomas, metastases to the adrenal gland, adrenocortical carcinomas, and lesions such as myelolipomas and adrenal cysts make up the rest. Adenomas are benign, and there is no evidence that they degenerate into malignant lesions. The adrenal glands are frequent sites for metastases from many cancers, including lung and breast cancer. Most of the time either a primary site is obvious, or widespread disease is apparent. Occasionally, an adrenal mass may present as a metastatic cancer of unknown primary. These tumors will not respond to surgical removal and should be treated with systemic therapy based on the origin of the primary. Myelolipomas and cysts are benign lesions that usually require no therapy.

Adrenocortical carcinoma is rare. The incidence ranges from 0.6 to 2 cases per 1 million people (Nader, Hickey, Sellin, et al., 1983). A review published in 1954 of autopsies from 1918 to 1947 at the Los Angeles County Hospital found adrenocortical carcinoma to account for 0.2 percent of all known malignancies (MacFarlane, 1958; Steiner, 1954). Adrenocortical carcinoma can be functional or nonfunctional and the definition varies in the literature. Some authors require a clinically apparent endocrine syndrome, while others will classify a tumor as functional if biochemical activity can be demonstrated in serum or urinary assays. Using the clinical definition, functional tumors accounted for 24 to 46 percent of adrenocortical carcinoma. One series of 34 cases found 53 percent of them to be biochemically functional (Huvos, Hajdu, Brasfield, et al., 1970). When data from six different series are combined, 95 of 237 patients (Ribeiro, Sandrini Neto, Schell, et al., 1990) have functional tumors. Several authors have noted that functional tumors occur more frequently in women (Didolkar, Bescher, Elias, et al., 1981; Hajjar, Hickey, and Samaan, 1975; Hogan, Gilchrist, Westring, et al., 1980; Huvos, Hajdu, Brasfield, et al., 1970; MacFarlane, 1958; Sullivan, Boileau, and Hodges, 1978). One series of twenty-one cases of adrenocortical carcinoma reported that anaplastic adrenocortical carcinomas were nonfunctional, while many of the differentiated tumors were functional. The nonfunctional undifferentiated tumors had a poor prognosis with survival time less than one year in all cases. The only effective treatment is en bloc surgical resection of the cancer before it metastasizes. In addition, nonfunctional tumors did not respond to chemotherapy with op'DDD (Hogan, Gilchrist, Westring, et al., 1980)

While adrenocortical carcinomas are rare, benign adenomas are common, and their prevalence increases with age (Commons and Callaway, 1948). The true incidence of adrenal adenomas is difficult to determine, but several large autopsy series have found adrenal adenomas larger than 2 to 5 mm in 1.5 to 8.7 percent of the population. In the only prospective study, it was found that adenomas with a size greater than 3 mm occur in 8.7 percent of 739 autopsies (Hedeland, Ostberg, and Hokfelt, 1968). Most of these masses are small, and in a large series of 12,000 autopsies only 3 were 6 cm or larger (Copeland, 1983). In a review of 98 patients with suspected adrenal disease, CT scans showed that adenomas ranged in size from 1.4 to 9 cm, with a mean of 3.3 cm (Adams, Johnson, Rickards, et al., 1983).

Pheochromocytomas occur much less frequently than adenomas. This type of tumor secretes vasoactive substances and can lead to significant morbidity and mortality. Between 10 and 13 percent of pheochromocytomas are malignant (ReMine, Chong, van Heerden, et al., 1974; Sutton, Sheps, and Lie, 1981). In a review of 40,078 autopsies at the Mayo Clinic between 1928 and 1977, pheochromocytoma was found in 54 patients (0.13 percent) (Sutton, Sheps, and Lie, 1981). Ninety percent of these tumors are located in the adrenal glands, and the remaining 10 percent are located in the para-aortic sympathetic chain, aortic bifurcation, and wall of the urinary bladder. Diagnosis is made by biochemical testing, which will identify most pheochromocytomas. The false negative rate of urinary vanillylmandelic acid (VMA) is 30 percent, metanephrines 10 percent to 20 percent, and catecholamines 5 percent (ReMine, Chong, van Heerden, et al., 1974).

Adrenal glands are frequent sites for metastases. Carcinoma of the lung, breast, and lymphoma account for a large portion of adrenal metastases. In a review of 1,000 consecutive autopsies of patients with carcinoma, the adrenal glands were involved in 27 percent of the cases (Abrams, Spiro, and Goldstein, 1950). The incidence of adrenal metastases in patients with breast and lung cancer is approximately 39 and 35 percent, respectively (Abrams, Spiro, and Goldstein, 1950; Lumb and Mackenzie, 1959).

### Diagnostic Modalities

CT is an accurate tool for detecting the presence of adrenal masses. Asymptomatic adrenal masses were identified in 14 of 2,200 upper abdominal CT scans (0.6 percent) (Glazer, Weyman, Sagel, et al., 1982). Using a fast scanner and 1 cm scanning intervals, both adrenals can be identified in 97 to 99 percent of patients. Size has been reported to be the most reliable way to distinguish benign adenomas from adrenocortical carcinomas. Adrenal adenomas are often small, well defined, homogeneous lesions that do not enhance on CT, and are believed to remain constant in size on serial CT scans (Hussain, Belldegrun, Seltzer, et al., 1986; Mitnick, Bosniak, Megibow, et al., 1983). Adrenocortical carcinomas are usually large, dense, irregular, heterogeneous, enhancing lesions that invade other structures (Hussain, Belldegrun, Seltzer, et al., 1986). However, small masses, in the range of 1 to 6 cm, may be difficult to discriminate (Fishman, Deutch, Hartman, et al., 1987; Hussain, Belldegrun, Seltzer, et al., 1985; Mitnick, Bosniak, Megibow, et al., 1983)

MRI has been used to differentiate among adenomas, metastases, and pheochromocytomas. Both T1 and T2 relaxation times have been studied. Signal intensity ratios between the adrenal mass and various organs, including spleen, fat, liver, and muscle, have been tested to discriminate adrenal masses. In general, malignant masses are denser than benign masses, though various benign lesions can mimic malignancies (Baker, Spritzer, Blinder, et al., 1987; Chezmar, Robbins, Nelson, et al., 1988; Reinig, Doppman, Dwyer, et al., 1986). There is still debate over the best method to discriminate adrenal masses using MRI.

Transcutaneous needle biopsy, or fine needle aspiration (FNA) of adrenal mass has been advocated by some for the investigation of incidentally discovered adrenal masses (Bernardino, 1988). Needle biopsy is an accepted procedure in evaluating adrenal masses in patients with known carcinoma. The biopsy is generally performed under either CT or US guidance. While accuracy appears to be high, up to 15 percent of biopsies are inconclusive (Karstrup, Torp-Pedersen, Nolsoe, et al., 1991). Complications of adrenal mass needle biopsy include pneumothorax, bleeding, and bacteremia (Bernardino, 1988; Pagani and Bernardino, 1982). Rare instances of metastatic seeding of the cancer along the needle track have been reported (Mody, Kazerooni, and Korobkin, 1995).

Three radioisotopes, ^131^I-iodomethyl-norcholesterol (NP-59), 6-methyl-75-selenomethyl-19-norcholesterol, and ^123^I-meta-iodobenzylguanidine (MIBG) scintigraphy have been used for imaging of adrenal morphology and function. Various methods of analyzing scintigraphy have been used to differentiate adrenal masses, including relative uptake of marker, concordance with CT, and imaging patterns (Dominguez-Gadea, Diez, Bas, et al., 1994; Gross, Shapiro, Francis, et al., 1994; Nakajo, Nakabeppu, Yonekura, et al., 1993). In addition to its potential role in diagnosing malignancy, scintigraphy may also be capable of differentiating autonomously secreting adenomas from non-functioning adenomas, adrenal hyperplasia and other adrenal diseases (Gross, Shapiro, Francis, et al., 1994).

Biochemical tests, including dehydroepiandrosterone sulfate (DHEAS), urine cortisol, plasma catecholamines, and others are used to differentiate metabolically active from inactive adrenal disease (Bardet, Rohmer, Murat, et al., 1996; Bondanelli, Campo, Trasforini, et al., 1997). Biochemical tests to diagnose malignant incidentalomas are rare (Terzolo, Ali, Osella, et al., 2000).

## Survival for Adrenocortical Carcinoma

Surgery with en bloc resection of the tumor is the only chance for a cure. Reported mortality of adrenal carcinoma surgery ranges from 0.8 to 9 percent (Didolkar, Bescher, Elias, et al., 1981; Mitnick, Bosniak, Megibow, et al., 1983; Wood, Delbridge, and Reeve, 1987), and may depend on the stage of disease (Henley, van Heerden, Grant, et al., 1983). In a review of 315 adrenal surgery patients from 1970 to 1979 at the Mayo Clinic, an overall operative morbidity was 14 percent. Morbidity includes wound infections, pneumothorax, pneumonia, hemorrhage, thromboembolic events, gastrointestinal hemorrhage, sepsis, small bowel obstruction, and wound dehiscence.

It has been suggested that tumor size may not correlate with survival, and may actually be inversely related to survival. However, these patients all presented symptomatically. It is not surprising that large low grade malignancies that present as masses can at times be surgically resected, and that smaller high grade symptomatic lesions may be unresectable. Since size, stage, and resectability are often related, extrapolation of this data from symptomatic masses to incidentalomas may not be valid. One study reported that when patients were not candidates for surgery, more than 70 percent of them died within 2 years (Lipsett, Hertz, and Ross, 1963). On the other hand, significant survival benefit is obtained when total excision is achieved. Survival decreases as the stage of the tumor increases (Sullivan, Boileau, and Hodges, 1978). In a review of 28 cases, one stage I patient had no evidence of disease 12.5 years after surgery. Four of five stage II patients were alive at 5 years. Of nine patients at stage III, only one was alive at 5 years. Finally, of the 13 stage IV patients, only one survived for 1 year and none for 2 years (Sullivan, Boileau, and Hodges, 1978).

## Management of Adrenal Incidentaloma

Management of adrenal incidentaloma is a complex decision-making process that involves considering a range of possible diagnoses, choosing additional diagnostic tests and interpreting their results, understanding the natural history of various adrenal pathologies, estimating the benefits and risks of interventions, and customizing therapy based on patient age and the size of the adrenal mass. Ideally one would like to have randomized trials of a sufficiently large number of patients to address this problem, but this might never be feasible given the heterogeneity of incidentaloma.