# Appendix D: Acronyms and Abbreviations

AA | anterior approach open adrenalectomy
ACC | adrenocortical carcinoma
ACTH | adrenocorticotropic hormone
AHRQ | Agency for Healthcare Research and Quality
ASA | American Society of Anesthesiologists
AUC | area under the ROC curve
BL | blood loss
BMI | body mass index
CA | cance
CAD | coronary heart disease
CHF | congestive heart failure
CRH | corticotropin-releasing hormone
CT | computed tomography
ctr | center
CVA | cerebrovascular accident
d | day
Dept | department
DEX | dexamethasone
DHEAS | dehydroepiandrosterone sulfate
DM | diabetes mellitus
DVT | deep vein thrombosis
dx | diagnosis
EPC | Evidence-based Practice Center
FN | false negative
FNA | fine needle aspiration
FNAB | fine needle aspiration biopsy
FP | false positive
FU | follow up
FUO | fever of unknown origin
HTN | hypertension
HU | Hounsfield units
IHD | ischemic heart disease
IV | intravenous
LFT | lost to follow up
LOS | length of (hospital) stay
LTLA | lateral transperitoneal laparoscopic adrenalectomy
MEN | multiple endocrine neoplasia
Mets | metastatic or metastases
MIBG | ^123^I-meta-iodobenzylguanidine
min | minute
mo | month
MRI | magnetic resonance imaging
N or n | number
NA | not available
ND | not documented
NP-59 | ^131^I-6β-iodomethyl-19-norcholesterol
ns | not significant
NSCLC | non-small cell lung cancer
OMAR | Office of Medical Applications of Research
OT | operative time
PA | posterior approach open adrenalectomy
Path | pathology
PE | pulmonary embolis
PET | positron emission tomography
Pheo | pheochromocytoma
PO | post-operative
PRA | plasma renin activity
prev | prevalence
radx | radiation therapy
RLA | retroperitoneal laparoscopic adrenalectomy
ROC | receiver operating characteristics (curve)
SCLC | small cell lung cancer
susp | suspected
SUV | standardized uptake value (in scintigraphy)
TB | tuberculosis
TLA | transperitoneal laparoscopic adrenalectomy
TN | true negative
TP | true positive
UFC | urinary free cortisone
US | ultrasonography
UTI | urinary tract infection
VMA | vanillylmandelic acid
Xr | X-Ray
Y | years