# Appendix B: Acknowledgments

The Evidence-based Practice Center staff acknowledges the collaboration as technical experts by the members of the Planning Committee of the National Institute of Health State-of-the-Science Conference on the Management of the Clinically Inapparent Adrenal Mass (“Incidentaloma”)

## Peer Reviewers

### American College of Surgeons

Dr. Robert C. McIntyre, Jr., MD, FACS

Associate Professor of Surgery

University of Colorado Health Sciences Center

Denver, Colorado

Quan-Yang Duh, MD, FACS

Professor of Surgery

University of San Francisco Medical Center and SF VA Medical Center

San Francisco, California

### American College of Radiology

John Cronan, MD

Department of Diagnostic Imaging

Rhode Island Hospital

Providence, Rhode Island

### American College of Physicians

Nick Fitterman, MD, FACP

North Shore Medical Group

Huntington, NewYork

### American Association of Clinical Endocrinologists

Elise M Brett, MD, FACE

1192 Park Avenue

New York, New York

## New England Medical Center EPC Project Staff

Joseph Lau, MD; EPC/Project Director

Ethan Balk, MD, MPH; Assistant Project Director

Michael Rothberg, MD

John P.A., Ioannidis, MD

Deirdre DeVine, M Litt; Project Manager

Priscilla Chew, MPH; Research Associate

Bruce Kupelnick, BA; Research Associate

Kimberly Miller, BA, Research Assistant