# Appendix A: Literature Search Strategies^*^ * Search strategies #1–3 courtesy of the National Library of Medicine reference librarian, Mary Conway

## Search strategy #1 utilizing PreMedline and Medline databases

#1 Adrenaloma*

#2 Adrenal gland neoplasms OR adrenal glands OR adrenal gland diseases OR Adrenalectomy OR carcinoma, adrenal cortical OR Adrenomegaly [tw]

#3 (Adrenal OR Adrenocortical)

#4 (incidental* OR silent OR subclinical OR pre-clinical OR non-hormonal OR nonhormonal OR nonsecretory OR nonfunction* OR asymptomatic OR serendipitous* OR non-hypersecretory OR nonhypersecretory OR occasionally OR pre-cushing OR precushing OR inapparent OR unapparent OR nonapparent)

#5 (#2 AND #4) OR (#3 AND #4)

#6 #1 OR #5

## Search strategy #2 utilizing BIOSIS database

s1 (adrenal OR adrenocortical) AND (adenoma OR pheochromocytoma OR mass OR Masses OR lesion?? OR tumor?? OR tumour?? OR cyst?? OR nodule?? OR nodular OR enlargement or hyperplasia)

s2 incidental? OR silent OR subclinical OR pre()clinical OR non()hormonal OR nonhormonal OR nonsecretory OR nonfunction? OR asymptomatic OR serendipitous?

s3 non()hypersecretory OR nonhypersecretory OR occasionally OR pre()cushing OR pseudo()cushing OR inapparent OR unapparent OR nonapparent)

s4 s1 AND (S2 OR S3)

s5 s4/CONF OR s4/MEETING

## Search strategy #3 utilizing EMBASE database

s1 (adrenal OR adrenocortical) AND (adenoma OR pheochromocytoma OR mass OR Masses OR lesion?? OR tumor?? OR tumour?? OR cyst?? OR nodule?? OR nodular OR enlargement or hyperplasia)

s2 incidental? OR silent OR subclinical OR pre()clinical OR non()hormonal OR nonhormonal OR nonsecretory OR nonfunction? OR asymptomatic OR serendipitous?

s3 non()hypersecretory OR nonhypersecretory OR occasionally OR pre()cushing OR pseudo()cushing OR inapparent OR unapparent OR nonapparent)

s4 s1 AND (S2 OR S3)

s5 (adrenal or adrenocortical) (5W) (carcinoma? OR neoplasm??)

s6 adrenalectomy

s7 s4 AND (s5 OR s6)

s8 s7/human

## Search strategy #4 utilizing PreMedline and Medline databases

1. adrenaloma$.af.
2. exp adrenal gland neoplasms/ or exp adrenal glands/ or exp adrenal gland diseases/ or exp adrenalectomy/ or exp carcinoma, adrenal cortical/ or adrenomegaly.tw. or (adrenal gland neoplasms or adrenal glands or adrenal gland diseases or adrenalectomy or carcinoma, adrenal cortical).af.
3. (adrenal or adrenocortical).af.
4. (incidental$ or silent or subclinical or preclinical or pre-clinical or non-hormonal or nonhormonal or nonsecretory or nonfunction$ or asymptomatic or serendipitous$ or non-hypersecretory or nonhypersecretory or occasionally or pre-cushing or precushing or inapparent or unapparent or nonapparent or unsuspected).af.
5. (2 and 4) or (3 and 4)
6. 1 or 5
7. exp pheochromocytoma/
8. exp adenoma/
9. pheochromocytoma.tw.
10. (adrenal adj6 adenoma).tw.
11. 7 or 8 or 9 or 10
12. 11 and 4
13. follow-up studies/
14. follow-up.tw.
15. exp Case-Control Studies/
16. case-control.tw.
17. exp Longitudinal Studies/
18. longitudinal.tw.
19. exp Cohort Studies/
20. cohort.tw.
21. (random$ or rct).tw.
22. exp Randomized Controlled Trials/
23. exp random allocation/
24. exp Double-Blind Method/
25. exp Single-Blind Method/
26. randomized controlled trial.pt.
27. clinical trial.pt.
28. (clin$ adj trial$).tw.
29. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
30. exp PLACEBOS/
31. placebo$.tw.
32. exp Research Design/
33. exp Evaluation Studies/
34. exp Prospective Studies/
35. exp Comparative Study/
36. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35
37. exp Adrenal Gland Neoplasms/co, su [Complications, Surgery]
38. exp Adrenal Gland Diseases/co, su [Complications, Surgery]
39. exp Carcinoma, Adrenal Cortical/co, su [Complications, Surgery]
40. exp Pheochromocytoma/co, su [Complications, Surgery]
41. 37 or 38 or 39 or 40
42. 36 and 41
43. exp Postoperative Complications/
44. (post operative or postoperative).tw.
45. ((surg$ or operat$) adj7 (outcome$ or complication$)).tw.
46. (laparoscopic or transabdominal or retroperitoneal).tw.
47. 43 or 44 or 45 or 46
48. 2 or 11
49. 47 and 48 and 36
50. (FNA or needle).tw.
51. 48 and 50
52. 12 or 42 or 49 or 51
53. limit 52 to human
54. limit 53 to english language
55. limit 54 to (addresses or bibliography or biography or comment or dictionary or directory or editorial or festschrift or interview or lectures or legal cases or letter or news or periodical index)
56. case report.sh.
57. 54 not (55 or 56)
58. 57 not 6
59. limit 58 to (guideline or meta analysis or practice guideline or review or review literature or review, academic or review, multicase or review, tutorial)
60. 58 not 59