# Evidence Tables

Evidence Table 1. Natural History of Otitis Media with Effusion

[The six components of study quality are: a prospective cohort study; outcome clearly defined; time point at which outcome measured clearly defined; subjects followed without any intervention; blinded assessment of outcome; and point and variability estimates provided for main outcome measures. 1 indicates presence and 0 indicates absence. OME resolution rates, not otherwise specified, represent the proportion without OME at follow-up compared to those with OME at baseline.]
Record# Author Year | Study Quality OME Definition Group(s) and Sample Size | Time/Place Inclusion/Exclusion Criteria | Influencing Factors | Findings
862 Birch and Elbrønd 1984 | [underlined: Study Type]: prospective single cohort | [underlined: Time]: Jan.–Apr./1982 | [underlined: Type of OME]: Newly diagnosed OME of unknown duration; OME persisting for weeks or months | Data not abstractable. The authors present an equation to estimate OME resolution, most likely cumulative rates, reportedly based on the study data.
| | [underlined: Place]: 10 day-care centers in a municipality of about 20,000 inhabitants; Dept. of Oto-Rhino-Laryngology, University of Aarhus, Denmark
| [underlined: Study Quality Score (0–6)]: 3(111000) | | [underlined: Age]: 0.75–7 years, mean 4.5 years
| | | [underlined: Examiner(s)]: unknown | Y=Y_0_e^–kt^
| [underlined: OME definition]: type B tympanogram signified middle-ear effusion otherwise not defined | | | Y= number of ears with OME
| | | [underlined: OME diagnostic method]: a B tympanogram defined as “compliance below 0.25 ml” signified middle-ear effusion | Y_0_=number of ears with OME a time 0
| | [underlined: Inclusion]:; - attending day-care centers in investigated municipality | | t=time in weeks
| | | | k=0.30
| [underlined: Group]: Children attending a day-care center in a municipality under investigation for incidence of OME
| | | [underlined: Interventions]: The authors did not mention control for interventions such as antibiotics during the course of the study, though the number receiving surgical procedures was noted. | Derived OME resolution rates by ear
| | | | Week | | % remain | % resolved
| | [underlined: Exclusion]:; - tympanometry not practicable (n=15 children); - parental consent not given (n=5 children); - ill or absent at all examinations (n=3 children) | | 0 | | 100 | 0
| | | | 1 | | 74 | 26
| N=373 subjects | | | 2 | | 55 | 45
| | | [underlined: Interval of screening]: every 2 weeks for twelve weeks | 3 | | 41 | 59
| | | | 4 | | 30 | 70
| | | | 5 | | 22 | 78
| | | | 6 | | 17 | 83
| | | | 7 | | 12 | 88
| | | | 8 | | 9 | 91
| | | | 9 | | 7 | 93
| | | | 10 | | 5 | 95
| | | | 11 | | 4 | 96
| | | | 12 | | 3 | 97
| | | | 13 | | 2 | 98
| | | | 14 | | 1 | 99
| | | | 15 | | 1 | 99
| | | | 16 | | 1 | 99
| | | | 14 | | 1 | 99
| | | | 18 | | 0 | 100
1000 Casselbrant, Brostoff, Cantekin, Doyle, Bluestone, and Fria 1985 [This cohort is also in article 2929.] | [underlined: Study Type]: prospective comparative cohort | [underlined: Time]: ~9/1981–8/1983 | [underlined: Type of OME]: newly diagnosed OME of unknown duration | Cumulative OME resolution by [underlined: episode] (Figure 3)
| [underlined: Study Quality Score (0–6)]: 3(111000) | [underlined: Place]: A nursery school in Verona, a suburb of Pittsburgh | [underlined: Age]: 2 year old 23, 3 year old 25, 4 year old 38, 5 year old 17 | Resolution
| [underlined: OME definition]: inflammation of the middle ear accompanied by collection of liquid in the middle ear cleft without the signs and symptoms of acute infection such as otalgia, fever, and a red or white tympanic membrane that is full or bulging | [underlined: Inclusion:]; - 2–5 years old; - nursery school in Verona, a suburb of Pittsburgh | [underlined: Gender]: male 81, female 59 (37 children in years 1 and 2 were counted twice by the authors) | Time | | # resolved/#at risk | (%)
| [underlined: Group]: Children, 2–5 years of age, attending a nursery school and examined from Sep 1981 through Aug 1983 | [underlined: Exclusion]: None | [underlined: Race/ethnicity]: black 4, oriental 1, white 98 | <1 month | | 92/137 | (67.2%)
| N=103 [103 children were entered into the study, 66 in the first year and 37 in the second year. 37 of the 66 children entered in the first year were also observed during the second year. Therefore in data analysis, the 103 children were treated as 140 ‘individuals’ to account for the 37 children who were observed for both years.] | | [underlined: Examiner(s)]: otolaryngologist, nurse trained in tympanometry, and an audiologist; also, validated otoscopists | <2 months | | 109/137 | (79.6%)
| | | [underlined: OME diagnostic method]: an algorithm combining pneumatic otoscopy, tympanometry, and acoustic reflex measurements | <3 months | | 130/137 | (94.9%)
| | | [underlined: Interventions]: The authors informed parents if OME was present 3 consecutive months. 11 children received tympanostomy tubes, and 26 children were treated for 32 episodes of acute otitis media of which 13 were associated with a new episode of OME. | <4 months | | 134/137 | (97.8%)
| | | [underlined: Interval of screening]: monthly in school and every 4 months at the Children's Hospital of Pittsburgh for 2 years after the initial evaluation | <5 months | | 136/137 | (99.3%)
| | | | <6 months | | 137/137 | (100%)
| | | | [This table only includes episodes of known duration without missing exam either prior to onset, during the episode, at resolution, or tympanostomy tubes inserted.]
2929 Casselbrant, Brostoff, Cantekin, Ashoff, and Bluestone 1990 [The 2–5-year-old cohort is also in article 1000.] | [underlined: Study Type]: prospective comparative cohort | [underlined: Time]: Group1~9/1981–8/1983^a^; Group2~9/1984–5/1985 | [underlined: Type of OME]: newly diagnosed OME of unknown duration^a^ | Cumulative OME resolution by episode for both groups combined^b^(page 29)
| [underlined: Study Quality Score (0–6)]: 3(111000) | [underlined: Place]: A nursery school in Verona, a suburb of Pittsburgh, ^a^and Falk Elementary School, Pittsburgh, PA | [underlined: Age]: Group1~2–5 years old^a^ Group2~5–12 years old | Time at
| [underlined: OME definition]: not defined^a^ | [underlined: Inclusion]:; - Group 1: 2–5 years old and in Verona nursery school; - Group 2: 5–12 years old and in Falk Elementary School | [underlined: Examiner(s)]: otolaryngologist and nurse practitioner validated otoscopists, nurse trained in tympanometry, and an audiologist^a^ | resolution | % resolved
| [underlined: Group 1]: Children, 2–5 years of age, attending a nursery school and examined from Sep 1981 through Aug 1983^a^ | [underlined: Exclusion]: None^a^ | [underlined: OME diagnostic method]: an algorithm combining pneumatic otoscopy, tympanometry, and acoustic reflex measurements^a^ | <1 month | ≈60%
| [underlined: Group 2]: School children, 5–12 years of age, attending an elementary school and examined from Sep 1984–May 1985 | | [underlined: Interventions]: Intervention was advised if OME persisted after 3 months. Up to three months, the authors report no intervention though how control was monitored is not mentioned. ^a^ | <2 months | ≈ 80%
| N=214 | | [underlined: Interval of screening]: monthly after the initial evaluation^a^ | ^b^Actual counts are not given, just approximate percentage of OME resolution at 1 and 2 months.
| N1=103^a^
| N2=111
1202 Ernstson and Sundberg 1984 | [underlined: Study Type]: prospective single cohort embedded in a controlled trial (not randomized) | [underlined: Time]: not specified | [underlined: Type of OME]: OME persisting for weeks or months, i.e. at least 3 months, laterality not specified | OME resolution in Group 1 (A) over 2–5 weeks by [underlined: child] (page 768)
| [underlined: Study Quality Score (0–6)]: 2(100100) | [underlined: Place]: The ENT Department, Central Hospital, Karlskrona, Sweden | [underlined: Age]: 1–11 years | Resolution
| [underlined: OME definition]: “nonpurulent effusion behind an intact tympanic membrane at otomicroscopy…supported by a type “B” tympanogram” | [underlined: Inclusion]:; - OME on one or both sides for at least 3 months | [underlined: Laterality]: both unilateral and bilateral, proportions not specified | Time | | #resolved/# at risk | (%)
| [underlined: Group 1]: A~Untreated children with OME at least 3 months scheduled for myringotomy | [underlined: Exclusion]:; - cleft palate; immotile cilia syndrome; - received antibiotics during the period of observation | [underlined: Examiner(s)]: unknown | <5 weeks | | 11/72 | (15.3%)
| [underlined: Group 2]: B~Treated children with OME at least 3 months scheduled for myringotomy (erythromycin orally 20–30 mg/kg body weight twice a day 10 days preceding surgery) | | [underlined: OME diagnostic method]: otomicroscopy tympanometry
| N=98 subjects | | [underlined: Interventions]: The authors did not mention control for interventions such as antibiotics during the pre-operative period prior to the 10 days before myringotomy.
| N1=72 | | [underlined: Interval of screening]: 2–5 weeks, median 3 weeks, between decision to operate and the operation itself.
| N2=26
1235 Fiellau-Nikolajsen 1979 [1976 cohort is also in articles 1237, 1242, and 3051. 1978 cohort is also in article 1245.] | [underlined: Study Type]: two cross-sectional studies | [underlined: Time]: Not specified^a^ | [underlined: Type of OME]: newly diagnosed OME of unknown duration^a^ | Cumulative OME resolution by ear for Group 2 1978 cohort with denominator from Aug. 1978 (Tables V and VII)
| [underlined: Study Quality Score (0–6)]: ^a^ | [underlined: Place]: ENT Clinic, Hjoerring Hospital, Denmark^a^ | [underlined: Age]: 36–48 months old^a^ | <1 month resolution-all subjects
| [underlined: OME definition]: not defined ^a^ | [underlined: Inclusion]: ^a^; - Age: 3 years; - residing in Hjoerring, Denmark; - had tympanometric screening and rescreening | [underlined: Gender]: Group 1 263 males, 260 females; Group 2 234 males, 229 females^a^ | Type | | #resolved/# at risk | (%)
| [underlined: Group 1]: Children aged 36–48 months in January, 1976, living in the municipality of Hjoerring, Denmark | [underlined: Exclusion]: None^a^ | [underlined: Daycare]: Group 1 18.5% in public day-care center, 30.0% in private home day-care, 53.5% in own home; Group 2 31.1% in public day-care center, 23.8% in private home day-care, 46.2% in own home^a^ | B to A | | 7/64 | (10.9%)
| [underlined: Group 2]: Children aged 36–48 months in August, 1978, living in the municipality of Hjoerring, Denmark | | [underlined: Examiner(s)]: unknown^a^ | B to A/C1 | | 14/64 | (21.9%)
| N1=503 children, 1001 ears, tested out of 523 ^a^ | | [underlined: OME diagnostic method]: tympanometry; - A: > –99 mmH_2_0; - B: ≤ 0.1 relative gradient; - C1: –100 to –199 mmH_2_O; - C2: <–200 mmH_2_O | B to A/C1/C2 | | 22/64 | (34.4%)
| N2=435 children, 867 ears, tested out of 465 ^a^ | | [underlined: Interventions]: The authors did not mention control of interventions. ^a^ | B/C2 to A | | 23/107 | (21.5%)
| | | [underlined: Interval of screening]: 1, 3 and 6 months after initial diagnosis. Other articles on the 1976 cohort note that once type A tympanogram was noted; follow-up was discontinued. | B/C2 to A/C1 | | 36/107 | (33.6%)
| | | | B/C2/C1 to A | | 76/203 | (37.4%)
| | | | <1 month resolution-subjects in Daycare
| | | | Type | | #resolved/#at risk | (%)
| | | | B to A | | 3/35 | (8.6%)
| | | | B to A/C1 | | 6/35 | (17.1%)
| | | | B to A/C1/C2 | | 12/35 | (34.3%)
| | | | B/C2 to A | | 11/58 | (19.0%)
| | | | B/C2 to A/C1 | | 16/58 | (27.6%)
| | | | B/C2/C1 to A | | 28/102 | (27.5%)
| | | | <1 month resolution-subjects at home
| | | | Type | | # resolved/# at risk | (%)
| | | | B to A | | 4/29 | (13.8%)
| | | | B to A/C1 | | 8/29 | (27.6%)
| | | | B to A/C1/C2 | | 10/29 | (34.5%)
| | | | B/C2 to A | | 12/49 | (24.5%)
| | | | B/C2 to A/C1 | | 20/49 | (40.8%)
| | | | B/C2/C1 to A | | 48/101 | (47.5%)
| | | | <3 month resolution-all subjects
| | | | Type | | #resolved/#at risk | (%)
| | | | B to A | | 16/62 | (25.8%)
| | | | B to A/C1 | | 25/62 | (40.3%)
| | | | B to A/C1/C2 | | 35/62 | (56.5%)
| | | | B/C2 to A | | 31/104 | (29.8%)
| | | | B/C2 to A/C1 | | 47/104 | (45.2%)
| | | | B/C2/C1 to A | | 83/200 | (41.5%)
| | | | <3 month resolution-subjects in Daycare
| | | | Type | | # resolved/# at risk | (%)
| | | | B to A | | 4/34 | (11.8%)
| | | | B to A/C1 | | 10/34 | (29.4%)
| | | | B to A/C1/C2 | | 15/34 | (44.1%)
| | | | B/C2 to A | | 9/56 | (16.1%)
| | | | B/C2 to A/C1 | | 20/56 | (35.7%)
| | | | B/C2/C1 to A | | 27/100 | (27.0%)
| | | | <3 month resolution-subjects at home
| | | | Type | | #resolved/# at risk | (%)
| | | | B to A | | 12/28 | (42.9%)
| | | | B to A/C1 | | 15/28 | (53.6%)
| | | | B to A/C1/C2 | | 20/28 | (71.4%)
| | | | B/C2 to A | | 22/48 | (45.8%)
| | | | B/C2 to A/C1 | | 27/48 | (56.3%)
| | | | B/C2/C1 to A | | 56/100 | (56.0%)
1237 Fiellau-Nikolajsen and Lous 1979 [This cohort is also in article 1235 1242, and 3051.] | [underlined: Study Type]: prospective single cohort | [underlined: Time]: Jan-July, 1976 | [underlined: Type of OME]: newly diagnosed OME of unknown duration | Cumulative OME resolution by [underlined: ear] (Figure 7)
| [underlined: Study Quality Score (0–6)]: 4(111001) | [underlined: Place]: Municipality of Hjoerring, Denmark (provincial town with about 20,000 inhabitants) | [underlined: Age]: 3 years old (born in 1972) | <1 month resolution-all subjects (Fig 7)
| [underlined: OME definition]: none given but tympanogram B and C2 were regarded as abnormal | [underlined: Inclusion]:; - 3 years old born in 1972 in the municipality of Hjoerring, Denmark | [underlined: Examiner(s)]: unknown | Time | | # resolved/# at risk | (%)
| [underlined: Group]: Children 3 years of age, born in 1972, and living in the municipality of Hjoerring, Denmark | [underlined: Exclusion]: during follow up: Moved out of area; airtight fitting of probe in auditory canal proved impossible; fistula developed in the pars flaccida | [underlined: OME diagnostic method]: tympanometry; - A: > -100 mmH_2_0 and gradient > 0.1; - B: 200 to -400 mmH_2_O or indeterminable and ≤ 0.1 gradient; - C1: -100 to -199 mmH_2_O and >0.1 gradient; - C2: -200 to -400 mmH_2_O and >0.1 gradient | B to A | | 14/94 | (14.9%)
| N=523 children fulfilled criteria; 504 (1005 ears) tested. | | [underlined: Interventions]: The authors state that “surgical procedures were avoided as much as possible.” Six children had adenoidectomy. | B to A/C1 | | 20/94 | (21.3%)
| N for type B at cohort inception=98 ears, 56 males and 14 females. | | [underlined: Interval of screening]: 1, 3, and 6 months after the initial diagnosis. Once a child had a type A tympanogram follow-up was discontinued. | B to A/C1/C2 | | 38/94 | (40.4%)
| N for type B/C2 at cohort inception=220 ears, 112 males and 108 females. | | | B/C2 to A | | 54/212 | (25.5%)
| N for type B/C2/C1 at cohort inception=372 ears, 186 males and 186 females. | | | B/C2 to A/C1 | | 75/212 | (35.4%)
| | | | B/C2/C1 to A | | 83/266 | (31.2%)
| | | | <1 month resolution-males
| | | | Time | | # resolved/# at risk | (%)
| | | | B to A | | 0/52 | ( 0.0%)
| | | | B to A/C1 | | 3/52 | (21.3%)
| | | | B to A/C1/C2 | | 17/52 | (32.7%)
| | | | B/C2 to A | | 18/107 | (16.8%)
| | | | B/C2 to A/C1 | | 30/107 | (28.0%)
| | | | B/C2/C1 to A | | 26/127 | (20.5%)
| | | | <1 month resolution-females
| | | | Time | | # resolved/# at risk | (%)
| | | | B to A | | 14/42 | (33.3%)
| | | | B to A/C1 | | 17/42 | (40.5%)
| | | | B to A/C1/C2 | | 21/42 | (50.0%)
| | | | B/C2 to A | | 36/105 | (34.3%)
| | | | B/C2 to A/C1 | | 45/105 | (42.9%)
| | | | B/C2/C1 to A | | 57/139 | (41.0%)
| | | | <3 month resolution-all subjects (Tab 2)
| | | | Time | | # resolved/# at risk | (%)
| | | | B to A | | 22/91 | (24.2%)
| | | | B to A/C1 | | 30/91 | (33.0%)
| | | | B/C2 to A | | 85/204 | (41.8%)
| | | | B/C2 to A/C1 | | 106/204 | (51.5%)
| | | | <3 month resolution-male subjects
| | | | Time | | # resolved/# at risk | (%)
| | | | B to A | | 5/49 | (10.1%)
| | | | B to A/C1 | | 9/49 | (18.4%)
| | | | B/C2 to A | | 33/103 | (32.0%)
| | | | B/C2 to A/C1 | | 46/103 | (44.7%)
| | | | <3 month resolution-female subjects
| | | | Time | | # resolved/# at risk | (%)
| | | | B to A | | 17/42 | (40.5%)
| | | | B to A/C1 | | 21/42 | (50.0%)
| | | | B/C2 to A | | 52/101 | (51.5%)
| | | | B/C2 to A/C | | 60/101 | (59.4%)
| | | | <6 month resolution-all subjects
| | | | Time | | # resolved/# at risk | (%)
| | | | B to A | | 32/91 | (35.2%)
| | | | B to A/C1 | | 41/91 | (45.1%)
| | | | B/C2 to A | | 120/204 | (58.8%)
| | | | B/C2 to A/C1 | | 136/204 | (66.7%)
| | | | <6 month resolution-male subjects
| | | | Time | | # resolved/# at risk | (%)
| | | | B to A | | 12/49 | (24.5%)
| | | | B to A/C1 | | 16/49 | (32.7%)
| | | | B/C2 to A | | 54/103 | (52.4%)
| | | | B/C2 to A/C1 | | 63/103 | (61.1%)
| | | | <6 month resolution-female subjects
| | | | Time | | # resolved/# at risk | (%)
| | | | B to A | | 20/42 | (47.6%)
| | | | B to A/C1 | | 25/42 | (59.5%)
| | | | B/C2 to A | | 66/101 | (65.3%)
| | | | B/C2 to A/C1 | | 73/101 | (72.3%)
1242 Fiellau-Nikolajsen 1981 [This cohort is also in article 1237, 1235 and 3051.] | [underlined: Study Type]: prospective single cohort within two cross-sectional studies^a^ | [underlined: Time]: 3-year followup (1/1976–1/1979) ^a^ | [underlined: Type of OME]: newly diagnosed OME of unknown duration^a^ | Cumulative OME resolution by [underlined: ear] with denominators from initial Jan. 1976 exam in Figure 1 article 1237 (Table IIa)
| [underlined: Study Quality Score (0–6)]: 4(111001) ^a^ | [underlined: Place]: Testing done in classrooms; the municipality of Hjoerring, Denmark^a^ | [underlined: Age]: 3–6 years (cohort born in 1972~screened at ages 3 & 6) ^a^ | <3 years resolution
| [underlined: OME definition]: not defined, but tympanogram B and C2 were regarded as abnormal^a^ | [underlined: Inclusion:] ^ a^; - Age: 3–6 years (cohort born in 1972-screened at ages 3 & 6); - living in Hjoerring, Denmark | [underlined: Examiner(s)]: unknown^a^ | Type | | #resolved/# at risk | (%)
| [underlined: Group 1]: Children born in 1972 and domiciled in the city of Hjoerring, Denmark in Jan 1976 | [underlined: Exclusion]: ^a^; - showed A tympanograms in both ears at a pminimum of one test | [underlined: OME diagnostic method]: tympanometry; - A: 200 to –99 mmH_2_0 and relative gradient > 0.1; - B: 200 to –400 mmH_2_O or indeterminable and < 0.1 relative gradient; - C1: –100 to –199 mmH_2_O and >0.1 relative gradient; - C2: –200 to –400 mmH_2_O and >0.1 relative gradient | B to A | | 33/65 | (51%)
| [underlined: Group 2]: Children born in 1972 and domiciled in the city of Hjoerring, Denmark in Jan 1979 | | [underlined: Interventions]: The authors did not mention control of medications. Some received surgical treatment during the follow-up period; 46 paracentesis and adenoidectomy and later 14 of those myringostomy with insertion of grommets; 10 paracentesis and adenoidectomy and later 4 of those myringostomy^a^ | B to A/C1 | | 43/65 | (66%)
| N1=523; 503 tested (in article 1237 n=504 were reported tested out of 523)^a^ | | [underlined: Interval of screening]: 1, 3, and 6 months after the initial diagnosis at 3 years of age as reported in article 1237. This articles describes follow-up at 6 years of age. Once a child had a type A tympanogram follow-up was discontinued. ^a^ | B to A/C1/C2 | | 50/65 | (77%)
| N2=505; 498 tested; 352 screened in 1976)^a^ | | | B/C2t to A | | 85/153 | (56%)
| N for type B at cohort inception=98 ears. | | | B/C2 to A/C1 | | 113/153 | (74%)
| N for type B/C2 at cohort inception=220. | | | B/C1/C2 to A | | 142/159 | (89%)
| N for type B/C1/C2 at cohort inception=372. | | | [The authors of article 1242 did not report on the middle-ear status during the three-year interval between the two screenings but comment that there must have been “periodical spontaneous improvements…” (page 98)]
| | | | With respect to subgroups, the authors of article 1242 mention that “When tested at 6 years,…the named subgroups (gender, public institutions versus home, and urban versus rural) showed no difference, either with respect to impedance test or tone audiometry, and the prognostic role of the tympanogram type at 3 years was the same in all subgroups.” Data are not provided on this question. (page 100)
1245 Fiellau-Nikolajsen 1983 [This cohort is also in article 1235.] | [underlined: Study Type]: prospective cohort study | [underlined: Time]: 1978–1979 (four screens: Aug, Sep & Nov, 1978, Feb 1979) | [underlined: Type of OME]: newly diagnosed OME of unknown duration | Cumulative OME resolution by [underlined: child] (page 173)
| [underlined: Study Quality Score (0–6)]: 3(111000) | [underlined: Place]: Subject identified in municipality of Hjoerring (medium-size urban town with a population of approximately 20,000); further testing and surgeries performed at ENT Dept., Hjoerring Hospital, Denmark | [underlined: Age]: 3 years (36–48 months) | Resolution
| [underlined: OME definition]: middle-ear effusion with intact tympanic membrane and absence of symptoms of acute inflammation | [underlined: Inclusion]:; - Age: 3 years (36–48 months); - living in municipality of Hjoerring, Denmark | [underlined: Examiner(s)]: unknown | Time | | # resolved/# at risk | (%)
| [underlined: Group]: Children screened (underwent audiometry testing and pneumatic otoscopy four times during study period) | [underlined: Exclusion]: None | [underlined: OME diagnostic method]: tympanometry; - middle-ear effusion: flat curve, or pressure <100 mmH_2_O with absent middle ear reflexes; - no middle-ear effusion | <1 month | | 28/78 | (35.9%)
| N=404 subjects screened; | | [underlined: Interventions]: The authors did not mention control of medications. None reportedly had adenoidectomy, myringotomy, tubes, or paracentesis during the study period. | <3 months | | 46/78 | (59.0%)
| N had OME at cohort inception=82. | | [underlined: Interval of screening]: 1, 3, and 6 months after initial diagnosis | <6 months | | 53/78 | (68.0%)
1486 Holm-Jensen, Sørenson, and Tos 1981 [This cohort is also in articles 2636, 543, 2639, 2642, 4834, and 4835.] | [underlined: Study Type]: prospective cohort study | [underlined: Time]: February, May, and August, 1979 | [underlined: Type of OME]: newly diagnosed OME of unknown duration | OME resolution by [underlined: ear] the initial Feb. 1979 denominators (Tables I, III, and V)
| [underlined: Study Quality Score (0–6)]: 3(111000) | [underlined: Place]: two counties in Copenhagen, Denmark | [underlined: Age]: 4 years | < 3months resolution
| [underlined: OME definition]: not defined though equated to type B tympanogram | [underlined: Inclusion]:; - born on the 1st-10th of every month in 1975 in two Copenhagen counties; - healthy | [underlined: Examiner(s)]: unknown | [underlined: Type #resolved/# at risk (%)]
| [underlined: Group]: Healthy children, 4 years old and born on the first-tenth day of each month in 1975, who resided in two Copenhagen counties | [underlined: Exclusion]: None | [underlined: OME diagnostic method]: tympanometry; - A: 0 to-99 mmH_2_O; - B: flat curve; - C1:-100 to-199 mmH_2_O; - C2:-200 to -350 mmH_2_O | B to A | | 3/92 | ( 3.3%)
| N=335 children at the first follow-up exam and 333 children at the second follow-up exam | | [underlined: Interventions]: The authors did not mention control of interventions. | B to A/C1 | | 14/92 | (15.2%)
| N for type B at cohort inception=102 ears (101 in article 2631) | | [underlined: Interval of screening]: 3 and 6 months after initial diagnosis | B to A/C1/C2 | | 54/92 | (58.7%)
| N for type B/C2 at cohort inception=318 ears | | | B/C2 to A | | 53/285 | (18.6%)
| N for type B/C2/C1 at cohort inception=477 ears | | | B/C2 to A/C1 | | 113/285 | (39.6%)
| | | | B/C2/C1 to A | | 113/424 | (26.7%)
| | | | <6 months resolution
| | | | [underlined: Type #resolved/# at risk (%)]
| | | | B to A | | 14/93 | (15.1%)
| | | | B to A/C1 | | 25/93 | (26.9%)
| | | | B to A/C1/C2 | | 54/93 | (58.1%)
| | | | B/C2 to A | | 59/282 | (20.9%)
| | | | B/C2 to A/C1 | | 131/282 | (46.5%)
| | | | B/C2/C1 to A | | 106/418 | (25.4%)
1494 Holmquist, Fadala, and Qattan 1987 | [underlined: Study Type]: prospective cohort study | [underlined: Time]: 2/1983–4/1983 | [underlined: Type of OME]: newly diagnosed OME of unknown duration | OME resolution by [underlined: ear] (page 117)
| [underlined: Study Quality Score (0–6)]: 3(111000) | [underlined: Place]: Eight primary schools distributed in the four educational areas of Kuwait with one male and one female school selected randomly from each area | [underlined: Age]: 7–9.5 years | <3 month resolution
| [underlined: OME definition]: middle-ear effusion behind an intact tympanic membrane | [underlined: Inclusion]: • primary schools | [underlined: Examiner(s)]: the authors whose roles are not specifically identified, one is an MD/PhD, one a surgeon, and one an MS | [underlined: Type # resolved/# at risk (%)]
| [underlined: Group]: Children in grade two who were examined at baseline and three months later by tympanometry and otoscopy | [underlined: Exclusion]:; - incomplete data; - refused to be submitted to examination; - occluding ear canal wax; - tympanic membrane perforations | [underlined: OME diagnostic method]: tympanometry; - A: +50 to-99 mmH_2_O; - B: flat curve; - C: +100 to-300 mmH_2_O | B/C to A | | 251/512 | (49.0%)
| N=817 children, 1,634 ears; 788 examined three months later) | | [underlined: Interventions]: The authors did not mention control of interventions.
| | | [underlined: Interval of screening]: follow-up 3 months after initial diagnosis
1714 Lamothe, Boudreault, Blanchette, Tetreault, and Poliquin 1981 | [underlined: Study Type]: prospective single cohort | [underlined: Time]: 10/9/1979–12/15/1979 | [underlined: Type of OME]: newly diagnosed OME of unknown duration | OME resolution rate by target [underlined: ear] (Figure 2)
| [underlined: Study Quality Score (0–6)]: 4(111100) | [underlined: Place]: elementary schools in the Sherbrooke metropolitan area, Canada | [underlined: Age]: First graders | <3 week resolution
| [underlined: OME definition]: not defined | [underlined: Inclusion:]; - First graders attending elementary schools in the Sherbrooke metropolitan area, Canada | [underlined: Gender]: 29 boys, 39 girls | Subjects | | #resolved/#at risk | (%)
| [underlined: Group]: first-grade children | Target ear at first visit was: A) diagnosed with OME if unilateral, B) most affected if bilateral, C) chosen at random if bilateral and evolution was same in both ears | [underlined: Examiner(s)]: otolaryngologist performed otoscopy and pneumatic otoscopy; audiologist performed tympanogram and audiogram | Total | | 24/64 | (37.5%)
| N=958 children of which 68 had OME by otoscopy and pneumatic otoscopy after six week follow-up. | [underlined: Exclusion]: None | - [underlined: OME diagnostic method:]; otoscopy and pneumatic otoscopy establishing; abnormal: air-fluid level, bubbles or complete effusion in the middle ear and hypo- or immobility of the eardrum plus two of the three following signs, eardrum retraction, opaque and thickened eardrum, or slight hyperemia; - tympanometry; abnormal: <= 200 mmH20 or amplitude <= 3; - audiogram; - abnormal: threshold >= 25 dB | Male | | 7/27 | (25.9%)
| N of OME at inception: total=68 target ears, male=29, female=39, left ear=38, and right ear=30. | | [underlined: Interventions]: The authors specifically state the patients were left untreated. | Female | | 17/37 | (45.9%)
| | | [underlined: Interval of screening]: 3 and 6 weeks after initial diagnosis | Left ear | | 7/35 | (20.0%)
| | | | Right year | | 17/29 | (58.6%)
| | | | <6 week resolution
| | | | Subjects | | #resolved/# at risk | (%)
| | | | Total | | 25/53 | (47.2%)
| | | | Male | | 6/23 | (26.1%)
| | | | Female | | 20/33 | (60.6%)
| | | | Left ear | | 10/29 | (34.5%)
| | | | Right ear | | 16/27 | (59.3%)
| | | | Cumulative OME resolution rate by target [underlined: ear] (Figure 2)
| | | | <3 week resolution (Total same as above)
| | | | <6 week resolution
| | | | Subjects | | #resolved/# at risk | (%)
| | | | Total | | 38/53 | (71.7%)
1735 Leiberman and Bartal 1986 | [underlined: Study Type]: retrospective-prospective single cohort | [underlined: Time]: 2 1/2 years (actual dates not specified) | [underlined: Type of OME]: OME persisting for weeks or months, i.e. 3 months or greater, laterality not specified | OME resolution by [underlined: ear] (page 876)
| [underlined: Study Quality Score (0–6)]: 2 (110000) | [underlined: Place]: The Soroka Medical Center in Beer-Sheva, Israel | [underlined: Age]: 2–12 years, mean 6 years | Resolution
| [underlined: OME definition]: not defined | [underlined: Inclusion:]; - children with persistent MEE and scheduled for myringotomy and insertion of ventilating tubes which was delayed 2 1/2 years | [underlined: Gender]: 1:1 ( male: female ratio) | Time | | #resolved/#at risk | (%)
| [underlined: Group]: Children with persistent middle ear effusion who had follow-up after 2–1/2 year delay in insertion of ventilating tubes | [underlined: Exclusion:]; - otomicroscopic findings of fluid and atelectasis, attic retractions, cholesteatoma, perforations, or tympanosclerosis | [underlined: Examiner(s)]: unknown who assessed for OME; certified audiologist performed audiometry | 2.5 years | | 49/158 | (31.0%)
| N=79 children, 158 ears | | [underlined: OME diagnostic method]: not stated | [Authors noted that the middle-ear effusion noted could be either persistent or recurrent. Follow-up for effusion after such a prolonged period may have little meaning.]
| | | [underlined: Interventions]: The authors did not mention control for interventions such as antibiotics during the course of the 2–1/2 year delay in surgical intervention.
| | | [underlined: Interval of screening]: follow-up greater than 2.5 years after decision to operate for persistent middle-ear effusion of greater-than 3 months
1777 Lous and Fiellau-Nikolajsen 1981 | [underlined: Study Type]: prospective single cohort | [underlined: Time]: 8/1978–8/1979 | [underlined: Type of OME]: newly diagnosed OME of unknown duration; OME persisting for weeks or months | OME resolution rate by case/child
| Study Quality Score (0–6): 3(111000) | [underlined: Place]: First graders in two rural municipalities (Hirtshals and Sindal, Denmark) [24 classes at 14 different schools] | [underlined: Age]: 6 1/2–7 1/2 year (first graders) | <3 months resolution – all subjects
| OME definition: type B tympanogram signified middle-ear effusion | [underlined: Inclusion:]; - started first grade in 8/1978 in two rural municipalities (Hirtshals and Sindal, Denmark) | [underlined: Examiner(s)]: specially trained audiometricians performed the tympanogram and audiology testing | Onset Season | | # resolved/# at risk | (%)
| Group: First graders in two municipalities (Hirtshals and Sindal, Denmark) who started school in August, 1978 | [underlined: Exclusion]: None | [underlined: OME diagnostic method:] tympanometry; - A: pressure > –100 mmH_2_O; - B: otoadmittance < 0.20 millimhos, absolute gradient < 0.04 millimhos, and absence of ipsilateral acoustic reflex; - C: ≤ –100 mmH_2_O | Sep-Feb | | 46/69 | (66.7%)
| N=387 children at initial exam with 345 tested at all 10 sessions | | [underlined: Interventions]: The authors did not mention control of medications. One child had adenoidectomy and paracentesis and three had adenoidectomy alone. | Mar-Aug | | 60/70 | (86.0%)
| N=100 with known onset and recovery time. | | [underlined: Interval of screening]: 1, 3, 4, 6, 7, 8, 9, 10, 12 months after initial exam | <3 months resolution – on subjects with known onset or resolution time only, excluding unknowns ^ a ^
| N=31 with unknown onset and recovery time | | | Onset Season | | #resolved/# at risk | (%)
| | | | Sep-Feb | | 46/63 | (73.0%)
| | | | Mar-Feb | | 41/45 | (91.1%)
| | | | ^a^ [Onset and resolution time unknown in 3, onset time unknown in 19, and resolution time unknown in 9.]
9 Marchisio, Principi, Passali, Salpietro, Boschi, Chetri, Caramia, Longhi, Reali, Meloni, DeSantis, Sacher, and Cupido 1998 | [underlined: Study Type]: prospective single cohort embedded in a randomized controlled study | [underlined: Time]: October-January during 1993–4 and 1994–5 | [underlined: Type of OME]: newly diagnosed OME of unknown duration; OME persisting for weeks or months, i.e. at least 12 weeks | OME resolution by child (Page 559)
| [underlined: Study Quality Score (0–6)]: 3(111000) | [underlined: Place]: Eleven primary schools visited by an otoscopist from either one of 9 Pediatric or 2 Otolarynogology departments in different regions of Italy | [underlined: Place]: Eleven primary schools visited by an otoscopist from either one of 9 Pediatric or 2 Otolarynogology departments in different regions of Italy | Resolution Time | | # resolved/# at risk | (%)
| [underlined: OME definition]: asymptomatic middle-ear effusion, demonstrated by an abnormal appearance of the tympanic membrane, diffusely opaque, with impaired mobility or presence of air-fluid levels associated with a flat, type B tympanometric curve | [underlined: Inclusion:]; - Attending year 1 in one of eleven participating primary schools in Italy; - persistent unilateral or bilateral middle-ear effusion | [underlined: Gender]: 248 males, 237 females | <12 weeks | | 331/451 | (73.4%)
| [underlined: Group]: Children attending the first year of primary school in one of eleven primary schools in Italy N=485 children with OME from 3413 screened. N=62 children with OME at 12-week follow-up randomized to placebo. | [underlined: Exclusion:]; - craniofacial abnormality; - any major congenital malformation; - serious underlying disease; - acute upper respiratory infection including AOM; - high risk of sensorineural hearing loss; - chronic suppurative OM; - perforation of tympanic membrane; - previous ear surgery | [underlined: Laterality]: 219 unilateral, 262 bilateral | <16 weeks^a^ | | 7/59 | (11.9%)
| | | | complete | | 7/59 | (11.9%)
| N=485 children with OME from 3413 screened. | | [underlined: Month of exam]: 296 in Oct-Nov, 189 in Dec-Jan | partial^a^ | | 17/59 | (28.8%)
| | | | <20 weeks^a^
| | | | complete | | 11/59 | (18.6%)
| N=62 children with OME at 12-week follow-up randomized to placebo. | | [underlined: Examiner(s)]: validated otoscopist | partial | | 17/59 | (28.8%)
| | | [underlined: OME diagnostic method]: pneumatic otoscopy; - abnormal: abnormal tympanic membrane appearance with impaired mobility or air-fluid levels and; portable tympanometry; - B: flat curve | ^a^ OME resolution (time after initial diagnosis, i.e. 12 weeks plus time after randomization to placebo) of subgroup of children with OME at 12-week follow-up randomized to placebo. (Table III)
| | | [underlined: Interventions]: It appears none of the children received antibiotics in the last month of the follow-up period and did not receive any surgical intervention during the follow-up interval.
| | | [underlined: Interval of screening]: 12 weeks after initial diagnosis; then 16 and 20 weeks after initial diagnosis for children randomized to placebo after 12 weeks
1927 Mills and Vaughan-Jones 1992 | [underlined: Study Type]: prospective single cohort embedded in a prospective comparative cohort | [underlined: Time]: 10/1986–10/1988 | [underlined: Type of OME]: newly diagnosed OME of unknown duration | OME resolution by [underlined: child] (Figure 4)
| [underlined: Study Quality Score (0–6)]: 1(100000) | [underlined: Place]: Clinics, Department of Otolaryngology, Ninewells Hospital and Medical School, Dundee, UK | [underlined: Age]: 1–14 years old, mean 5.5 years | Resolution
| [underlined: OME definition]: not defined | [underlined: Inclusion:]; - <15 years old | [underlined: Examiner(s)]: unknown | Time | | resolved/# at risk | (%)
| [underlined: Group]: New cases of childhood OME (patients < 15 years of age) who presented at principal author's clinic between 10/1986–10/1988 | [underlined: Exclusion:]; - impedance findings suggested effusion was in fact due to thickening of the tympanic membrane | [underlined: OME diagnostic method]: pneumatic otoscopy tympanometry | <2 months | | 57/192 | (29.7%)
| N=192 children | | [underlined: Interventions]: Most of the children had myringotomies at the 2 month follow-up. Two children had “conservative treatment” at some unspecified point in time. | [Authors reported uncertainty in the timing of the follow-up visit.]
| | | [underlined: Interval of screening]: usually 2 months after initial exam
1946 Moller and Tos 1990 | [underlined: Study Type]: prospective single cohort | [underlined: Time]: 11/1/1989–11/30/1989 (21 days of screening) | [underlined: Type of OME]: newly diagnosed OME of unknown duration | OME resolution by [underlined: ear] for OME noted at start of study (page 938 and 939 and Tables IV and V)
| [underlined: Study Quality Score (0–6)]: 3(111000) | [underlined: Place]: A kindergarten in Copenhagen, Denmark; Gentofte Hospital/University of Copenhagen | [underlined: Age]: 37–68 months old | AZ7[Impedance audiometer]
| [underlined: OME definition]: not defined | [underlined: Inclusion:]; - kindergartners | [underlined: Gender]: 21 males, 30 females
| [underlined: Group]: Healthy children attending a kindergarten in Copenhagen, Denmark | [underlined: Exclusion:]; - ears with grommets inserted (two ears excluded); - definite type of tympanogram could not be identified; - child defected from study or refused the examination w/either one or the other instrument | [underlined: Examiner(s)]: unknown | Time Resolved | Type | #resolved/# at risk | (%)
| N=51 children, 100 ears | | [underlined: OME diagnostic method]: tympanometry; - A: +99 to –99 mmH2O; - B:; - AZ 7: flat curve without impedance minimum or with a measurable impedance minimum and relative gradient below 0.1; - ZS 331: flat training or compliance below 0.25 ml and absent ipsilateral stapedial reflex; - C1: –100 to –199 mmH_2_O; - C2: >–200 mmH_2_O | <3 days | B to A | 1/4 | (25.0%)
| | | [underlined: Interventions]: The authors did not mention control of interventions. | | B to A/C1 | 1/4 | (25.0%)
| | | [underlined: Interval of screening]: daily for 30 days | <10 days | B to A | 1/4 | (25.0%)
| | | | | B to A/C1 | 3/4 | (75.0%)
| | | | <15 days | B to A | | not done
| | | | | B to A/C1 | 3/4 | (75.0%)
| | | | <30 days | B to A | 0/2 | ( 0.0%)
| | | | | B to A/C1 | 1/2 | (50.0%)
| | | | ZS331 [Impedance tympanoscope]
| | | | Time Resolved | Type | # resolved/# at risk | (%)
| | | | <3 days | B to A | 2/7 | (28.6%)
| | | | | B to A/C1 | 2/7 | (28.6%)
| | | | <10 days | B to A | 4/7 | (57.1%)
| | | | | B to A/C1 | 6/7 | (85.7%)
| | | | <15 days | B to A | | not done
| | | | | B to A/C1 | 5/6 | (83.3%)
| | | | <30 days | B to A | 0/3 | ( 0.0%)
| | | | | B to A/C1 | 1/3 | (33.3%)
2184 Portoian-Shuhaiber and Cullinan 1984 | [underlined: Study Type]: prospective single cohort | [underlined: Time]: March 1979 and May 1979 | [underlined: Type of OME]: newly diagnosed OME of unknown duration | OME resolution by [underlined: child] (page 1112)
| [underlined: Study Quality Score (0–6)]: 3(111000) | [underlined: Place]: Twelve primary schools in SE London | [underlined: Age]: 5–6 years | <10 weeks resolution
| | [underlined: Inclusion:]
| [underlined: OME definition]: abnormal defined as an abnormal tympanometric curve and/or absent acoustic reflex | - 5–6 years old; - attending one of the twelve selected schools in SE London | [underlined: Ethnicity]: African-American: 57; Indian: 16; White: 234; unknown: 11. | [underlined: Ethnicity] | | # resolved/# at risk | (%)
| [underlined: Group]: Children, 5–6 years old, attending selected primary schools in SE London | | [underlined: Examiner (s)]: unknown | Total | | 65/130 | (50.0%)
| | | [underlined: OME diagnostic method:]
| | | tympanometric and acoustic reflex measurements | African-American | | 5/7 | (71.4%)
| | [underlined: Exclusion:]
| N=130 children with OME from 318 screened | - conditions predisposing to glue ear such as Down's syndrome and cleft palate | - abnormal: abnormal curve and/or absent reflex; - normal: normal tympanogram curve with positive acoustic reflex | Indian | | 5/9 | (55.6%)
| | | [underlined: Interventions]: The authors did not mention control of interventions. | White | | 55/110 | (50.0%)
| | | [underlined: Interval of screening]: 10 weeks after initial diagnosis
2189 Poulsen and Tos 1978[This cohort is also in 2627, 2631, 2634, 2639, 2642, 4834, and 4835.] | [underlined: Study Type]: prospective single cohort | [underlined: Time]: recruitment 1/1997 to 4/1997 with last follow-up 6 months after initial exam | [underlined: Type of OME]: newly diagnosed OME of unknown duration | OME resolution by [underlined: ear] (Figure 1)
| [underlined: Study Quality Score (0–6)]: 3(111000) | [underlined: Place]: Copenhagen, Denmark | [underlined: Age]: Newborns | Resolution from C1 to A
| [underlined: OME definition]: not defined | | [underlined: Gender]: 82 males, 69 females | Time | | # resolved/# at risk | (%)
| | [underlined: Inclusion:]
| [underlined: Group]: Infants born between January-April, 1977, in the Gentofte maternity ward | - healthy newborns born between January and April 1977 in the Gentofte maternity ward | [underlined: Examiner(s)]: unknown | <3 months | | 19/24 | (79.2%)
| N=151 screened initially, 109 children (218 ears) at all examinations. | [underlined: Exclusion]: None | [underlined: OME diagnostic method:tympanometry] | <6 months | | 13/24 | (54.2%)
| N=0 for type B or C2 at cohort inception. | | - A: >–100 mmH_2_O; - B: flat curve with impedance slope ≤0.1; - C: –100 to –300 mmH_2_O with impedance slope >0.1; - C1: –100 to –199 mmH_2_O; - C2: –200 to –350 mmH_2_O | Cumulative OME resolution by ear (Figure 1)
| | | [underlined: Interventions]: The authors did not mention control of interventions. | Resolution from C1 to A
| | | [underlined: Interval of screening]: 3 and 6 months after initial diagnosis at 2–4 days of age | [underlined: Time # resolved/# at risk (%)]
| | | | <3 months | | 19/24 | (79.2%)
| | | | <6 months | | 21/24 | (87.5%)
2190Poulsen and Tos 1980[This cohort is also in articles 2629, 2631, 2634, 2593, 2639, 2642, 4834, and 4835.] | [underlined: Study Type]: prospective single cohort | [underlined: Time]: 11/1977–5/1978 | [underlined: Type of OME]: newly diagnosed OME of unknown duration | OME resolution by [underlined: ear] using the initial Nov. 1977 denominators from Table I in article 2631 (Table III)
| [underlined: Study Quality Score (0–6)]: 3(111000) | [underlined: Place]: Two municipalities in the northern part of Copenhagen county, Denmark | [underlined: Age]: 2 year old at final exam | <6 month resolution
| [underlined: OME definition]: not defined | [underlined: Inclusion]:
| [underlined: Group]: Healthy two-year-old children born between the first and tenth day of every month in 1976 residing in two municipalities in the northern part of Copenhagen county | - Age: 2 years; - born between the 1st and the 10th day in every month of 1976 in 2 Copenhagen county municipalities; - healthy | [underlined: Examiner(s)]:unknown | Type | | # resolved/# at risk | (%)
| N=278 children at initial exam but N=240 children who presented at both follow-up exams | | [underlined: OME diagnostic method]: tympanometry | B to A | | 15/59 | (25.4%)
| N for type B at cohort inception=60. | [underlined: Exclusion]: None | - A: 0 to –99 mmH2O; - B: flat curve; - C1: –100 to –199 mmH2O; - C2: –200 to –350 mmH_2_O | B to A/C1 | | 25/59 | (42.4%)
| N for type B/C2 at cohort inception=172. | | [underlined: Interventions]: The authors did not mention control of medications. Three children received ear tubes, and three had adenoidectomy. | B to A/C1/C2 | | 38/59 | (64.4%)
| N for type B/C2/C1 at cohort inception=290. | | [underlined: Interval of screening]: 3 and 6 months after initial diagnosis | B/C2 to A | | 37/152 | (24.3%)
| | | | B/C2 to A/C1 | | 74/152 | (48.7%)
| | | | B/C2/C1 to A | | 87/248 | (35.1%)
2240 Renvall, Lidén, Jungert, and Nilsson 1978 | [underlined: Study Type]: prospective single cohort | [underlined: Time]: not specified | [underlined: Type of OME]: newly diagnosed OME of unknown duration | OME resolution by ear (Table III and I)
| [underlined: Study Quality (0–6)]: 3 (111000) | [underlined: Place]: Göteborg, Sweden | [underlined: Age]: 10–11 years (initially evaluated at age 7) | <3 years resolution
| [underlined: OME definition]: not defined. | | [underlined: Examiner(s])): otologic examination by experienced otologist, audiologic examiner unknown
| | [underlined: Inclusion]:
| [underlined: Group]: Children aged 10–11 years who were initially examined at age 7 [only ears with a middle ear pressure <=–100 mm H2O or a flat tympanogram at the initial exam were included] | - 10–11 years (initially evaluated at age 7); - only includes ear that at the initial evaluation (age 7) had middle ear pressure of <=–100 mmH_2_O or a flat tympanogram | [underlined: Examiner(s]): otologic examination by experienced otologist, audiologic examiner unknown | [underlined: Diagnostic Method] | | # resolved/# at risk | (%)
| N=210 children, 335 ears | [underlined: Exclusion]: None | [underlined: OME diagnostic method]: | Tympanogram | | 282/335 | (84.2%)
| | | tympanometry and stapedius reflex measurements and otoscopic exam initial screen; - abnormal: ≤–100 mmH2O or flat tympanogram follow-up; - abnormal: ≤–150 mmH2O or flat tympanogram, stapedius reflex threshold > 95 dB H.L., and effusion by otologic exam | Otologic exam | | 250/335 | (74.6%)
| | | [underlined: Interventions]: The authors did not mention control of interventions. | [The authors concluded that “reduced middle ear pressure is more common in ears once having had subnormal middle ear pressure than in a nonselected group. They did not suggest that these necessarily represent persistent OME.]
| | | [underlined: Interval of screening]: 3 years after initial diagnosis
2242Renvall, Anniansson, and Lidén 1982 | [underlined: Study Type]: prospective single cohort | [underlined: Time]: During 1980 | [underlined: Type of OME]: Newly diagnosed OME of unknown duration | Cumulative OME resolution by [underlined: ear] (Figures 2 and 3)
| [underlined: Study Quality (0–6)]: 4(111100) | [underlined: Place]: S1≈Healthy-baby-clinics in Goteborg, Sweden; S2≈children who failed screening were referred to two oto-audiological health centers in Goteborg | [underlined: Age]: 4 years | <6 weeks resolution
| [underlined: OME definition]: not defined | | [underlined: Examiner(s)]: unknown | Type | | #resolved/# at risk | (percnt;)
| [underlined: Group 3]: 4-year-old children with abnormal tympanograms after hearing screen and comprehensive evaluation | | [underlined: OME diagnostic method:] | B to A | | 10/40 | (25.0%)
| | | [underlined: Inclusion]:
| N=5928 initially screened and N=223 ears with abnormal tympanogram. | - Age: 4 years; - S2≈failure criterion >20db | tympanometry, audiology, and otologic exams; - abnormal: middle-ear pressure ≤–150 mmH2O, hearing ≤20 dB HL, and/or retraction pocket on otologic exam; - normal: middle-ear pressure > –150 mmH_2_O, no tympanic membrane retraction, and hearing <= 20 dB HL | B/C to A | | 56/144 | (38.9%)
| N for type B at cohort inception=58 ears. | [underlined: Exclusion]: None | [underlined: Tympanogram classification]: | <12 weeks resolution
| | | - Flat to >150 mmH_2_O [similar to type B to A]; - Flat or –150 to –400 mmH_2_O to >=150 mmH_2_O [similar to type B or C to A] | Type | | #resolved/# at risk | (%)
| | | [underlined: Interventions]: The children did not receive any treatment for four months after initial diagnosis. | B to A | | 16/40 | (40.0%)
| | | [underlined: Interval of screening]: 6 and 12 weeks after initial diagnosis. Those with normal exams at any point did not receive follow-up. | B/C to A 86/144 (59.7%) | | 86/144 | (59.7%)
2243 Reves, Budgett, Miller, Wadsworth, and Haines 1985 | [underlined: Study Type]: prospective single cohort | [underlined: Time]: 11/1983–2/1984 | [underlined: Type of OME]: newly diagnosed OME of unknown duration | OME resolution by [underlined: child] (comment in abstract)
| [underlined: Study Quality (0–6)]: 3(111000) | [underlined: Place]: General practice at a health centre in north west London (situated on a council housing estate and serves a deprived population) | [underlined: Age]: 3 months-6 years on 10/31/1983; <1 year old 59 ears, 1 year old 73 ears, 2 years old 94 ears, 3 years old 86 ears, 4 years old 82 ears, 5 years or older 58 ears
| [underlined: OME definition]: not defined | [underlined: Inclusion:] | [underlined: Laterality]: unilateral 29, bilateral 39 | [underlined: Resoultion Time] | | [underlined: #resolved/# at risk] | (58.8%)
| [underlined: Group]: Children 3 months to 6 years old on 10/31/1983 recruited from age-sex register and successfully tested by tympanometry | - 3 months-6 years on 10/31/1983; - listed in age-sex register | [underlined: Examiner(s)]: unknown | <3 months | | 40/68 | (58.8%)
| N=232 children, 452 ears, of whom n=220 had adequate exams | [underlined: Exclusion]: None | [underlined: OME diagnostic method]:
| | | tympanometry; - A: normal pressure (–100 to +50 mmH20), normal compliance (>0.3), peak at normal pressure; - As: normal pressure, low compliance, small peak at normal pressure; - B: low compliance and middle-ear pressure < –100 mmH20 or indeterminate, usually flat or peak < –100 mmH20 (signified middle-ear effusion); - C: negative pressure, normal compliance, peak at negative pressure
| | | [underlined: Interventions]: The authors did not mention control of interventions.
| | | [underlined: Interval of screening]: every 2–4 weeks after initial diagnosis for 6 months
2262 Roberts, Johnson, Carlin, Turczyk, Karnuta, and Yaffee 1995 | [underlined: Study Type]: prospective single cohort | [underlined: Time]: not specified | [underlined: Type of OME]: newly diagnosed OME of unknown duration | Cumulative OME resolution by otoscopy by [underlined: ears] (page 875)
| [underlined: Study Quality Score (0–6)]: 4(111010) | [underlined: Place]: Normal newborn nursery of MetroHealth Medical Center, a county hospital in Cleveland, Ohio, and a county pediatric clinic | [underlined: Age]: Newborns (max follow-up ~ 2months) | Resolution Time | | # resolved/# at risk | (%)
| [underlined: OME definition]: not defined | [underlined: Inclusion]:; - healthy, full-term newborn | [underlined: Race/ethnicity]: white 47%, African American 43%, Hispanic 10% | <2 weeks | | 22/24 | (91.7%)
| [underlined: Group]: Healthy, full-term infants born in MetroHealth Medical Center, Cleveland, Ohio, were enrolled on day 1 of life | [underlined: Exclusion]: None | [underlined: Examiner(s)]: 2 otoscopists; tympanometry and acoustic reflex measurements by an audiologist on day 1 and 3 and by a research assistant at 2 weeks and 2 months | <2 months | | 24/24 | (100%)
| N=68 subjects | | [underlined: OME diagnostic method]:
| | | pneumatic otoscopy; - middle-ear effusion: tympanic membrane mobility markedly decreased or air-fluid level; - tympanometry; middle-ear effusion: peak susceptance < 0 millisiemens; - no effusion: > 0 millisiemens; - acoustic reflex measurement; middle-ear effusion: threshold at 110dB HL or absent reflex; - no effusion: threshold up to 100dB HL
| | | [underlined: Interventions]: Asymptomatic infants were not treated with antibiotics. No indication of how many infants required intervention.
| | | [underlined: Interval of screening]: 2 weeks and 2 months after birth of infants whose parents chose to receive well-child care from the research team
2270 Robinson, Allen, and Root 1988 | [underlined: Study Type]: prospective single cohort | [underlined: Time]: not specified | [underlined: Type of OME]: | OME resolution by [underlined: ear] (pages 343–344)
| [underlined: Study Quality (0–6)]: 1(110000) | [underlined: Place]: 12 Health Department clinics in two metropolitan Detroit counties (Wayne and Oakland); (8 Oakland County clinics are “well baby” clinics; 4 Wayne County clinics serve Medicaid patients) | [underlined: Age]: 6–13 months, mean 9.7 months (standard deviation 2.3 months) | <6 weeks resolution ^a^
| [underlined: OME definition]: not defined | [underlined: Inclusion]: | [underlined: Gender]: 65 male, 72 female | Type | | # resolved/# at risk | (%)
| [underlined: Group]: Children, primarily lower socioeconomic status infants between 3–6 months of age, who underwent tympanometry as part of the study | - Age: 6–13 months; - income limits are imposed to qualify for Tx at all clinics involved | [underlined: Race/ethnicity]: 63 black, 74 white | B to A | | 10/25 | (40.0%)
| N=137 subjects initially tested of whom n=63 had OME). | [underlined: Exclusion]: None | [underlined: Examiner(s)]: second-year audiology master of arts student | B to A/As | | 11/25 | (44.0%)
| N for B/C/Cs at cohort inception=63. | | [underlined: OME diagnostic method]: | B to A/As/Cs | | 13/25 | (52.0%)
| | | tympanometry | B/C to A | | 22/41 | (53.7%)
| | | - A: -149to +50 mmH_2_O and compliance > 0.2 ml; - failures: all other types As, C, Cs, and B | B/C to A/As | | 23/41 | (56.1%)
| | | [underlined: Interventions]: The authors did not mention control of interventions. | B/C to A/As/Cs | | 24/41 | (58.5%)
| | | [underlined: Interval of screening]: minimum 6 weeks from initial screen if failed | B/C/Cs to A | | 20/34 | (58.8%)
| | | | ^a^ minimum 6-week interval but exact intervals not reported
2457 Sly, Zambie, Fernandes, and Frazer 1980 | [underlined: Study Type]: two prospective single cohorts | [underlined: Time]: February and September, 1977 | [underlined: Type of OME]: newly diagnosed OME of unknown duration | OME resolution by child/ear as unit of measure (only those without any treatment). (Table VII)
| [underlined: Study Quality Score (0–6)]: 3(111000) | [underlined: Place]: Memorial Baptist Kindergarten, New Orleans, LA; from the Dept. of Pediatrics, Louisiana State University Medical Center | [underlined: Age]: Kindergartners (4–5 years) | <2 weeks resolution - February 1997
| [underlined: OME definition]: not defined | [underlined: Inclusion:] | [underlined: Examiner(s)]: unknown | Unit | Type | # resolved# at risk | (%)
| [underlined: Group 1]: February, 1977 screening children in 4–5 year old classes at Memorial Baptist Kindergarten (n=94 children, 188 ears) | - Age: 4–5 years | [underlined: OME diagnostic method]: | Child | B to A | 1/7 | (14.3%)
| [underlined: Group 2]: September, 1977 screening children in 4–5 year old classes at Memorial Baptist Kindergarten | - written parental permission & child willingness | tympanometry | Child | B/C to A | 8/24 | (33.3%)
| N1=94 children, 188 ears | [underlined: Exclusion]: | - abnormal: flat type B without discernible peak in compliance with decrease in pressure to -400 mmH_2_O, compliance < 0.3 cc, or peak compliance occurred at or below pressure -100 mmH_2_O | Ear | B to A | 1/9 | (11.1%)
| N2=94 children, 188 ears | - presence of functional ventilating tube (ear) | [underlined: Interventions]: Group 1 antibiotics with or without antihistamines and decongestants in 2 children and antihistamines and decongestants in 9, Group 2 antibiotics with or without antihistamines and decongestants in 5 children and antihistamine and/or decongestants in 21. | Ear | B/C to A | 8/32 | (25.0%)
| | - not able to obtain adequate seal in the ear canal (ear) | [underlined: Interval of screening]: every two weeks after initial diagnosis for six weeks | <2 weeks resolution - September 1997
| | | | Unit | Type | # resolved# at risk | (%)
| | | | Child | B to A | 0/3 | (0.0%)
| | | | Child | B/C to A | 2/14 | (14.3%)
| | | | Ear | B to A | 0/5 | (0.0%)
| | | | Ear | B/C to A | 4/22 | (18.2%)
| | | | <4 weeks resolution - February 1997
| | | | Unit | Type | # resolved# at risk | (%)
| | | | Child | B to A | 3/7 | (42.9%)
| | | | Child | B/C to A | 12/24 | (50.0%)
| | | | Ear | B to A | 4/9 | (44.4%)
| | | | Ear | B/C to A | 14/32 | (43.8%)
| | | | <4 weeks resolution - September 1997
| | | | Unit | Type | # resolved# at risk | (%)
| | | | Child | B to A | 0/3 | (0.0%)
| | | | Child | B/C to A | 3/14 | (21.4%)
| | | | Ear | B to A | 0/5 | (0.0%)
| | | | Ear | B/C to A | 5/22 | (22.7%)
| | | | <6 weeks resolution - February 1997
| | | | Unit | Type | # resolved# at risk | (%)
| | | | Child | B to A | 5/7 | (71.4%)
| | | | Child | B/C to A | 16/24 | (66.7%)
| | | | Ear | B to A | 6/9 | (66.7%)
| | | | Ear | B/C to A | 18/32 | (56.3%)
| | | | <6 weeks resolution - September 1997
| | | | Unit | Type | # resolved# at risk | (%)
| | | | Child | B to A | 0/3 | (0.0%)
| | | | Child | B/C to A | 7/14 | (50.0%)
| | | | Ear | B to A | 0/5 | (0.0%)
| | | | Ear | B/C to A | 11/22 | (50.0%)
| | | | Note: Denominator at each time is most likely same as total with OME, however defined.
2593 Thomsen and Tos 1981 [This cohort is also in articles 2190, 2629, 2631, 2634, 2639, 2642, 4834, and 4835.] | [underlined: Study Type]: ^a^ | [underlined: Time]: 11/1977 to 2/1980 | [underlined: Type of OME]: ^a^ | OME resolution by ear (Table IV and Figure 1) <2 years resolution
| [underlined: Study Quality (0–6)]: ^a^ | [underlined: Place]: ^a^ | [underlined: Age]: ^a^ | <2 years resolution
| [underlined: OME definition]: ^a^ | [underlined: Inclusion]: ^a^ | [underlined: Gender]: males 92, females 92 | [underlined: Type # resolved/# at risk (%)]
| [underlined: Group]: ^a^ | [underlined: Exclusion]: ^a^ | [underlined: Examiner(s)]: unknown | B to A | | 9/48 | (18.8%)
| N=184 children who presented at all 5 follow-up exams | | [underlined: OME diagnostic method]: ^a^ | B to A/C1 | | 19/48 | (39.6%)
| N for type B at cohort inception=60. | | [underlined: Interventions]: ^a^ | B to A/C1/C2 | | 40/48 | (83.3%)
| N for type B/C2 at cohort inception=172. | | [underlined: Interval of screening]: extended to 5 years old | B/C2 to A | | 26/121 | (21.5%)
| N for type B/C2/C1 at cohort inception=477. | | | B/C2 to A/C1 | | 53/121 | (43.8%)
| | | | B/C2/C1 to A | | 50/199 | (25.1%)
| | | | Resolution based on B to A/C1/C2
| | | | Resolution
| | | | Time # resolved/# at risk (%)
| | | | <3 months | | 25/48 | (52.1%)
| | | | <6 months | | 27/48 | (56.3%)
| | | | <9 months | | 39/48 | (81.3%)
| | | | <12 months | | 35/48 | (72.9%)
| | | | <24 months | | 40/48 | (83.3%)
| | | | Cumulative OME resolution by[underlined: ear]
| | | | Resolution based on B to A/C1/C2
| | | | Resolution
| | | | Time # resolved/# at risk (%)
| | | | <3 months | | 25/48 | (52.1%)
| | | | <6 months | | 30/48 | (62.5%)
| | | | <9 months | | 39/48 | (81.3%)
| | | | <12 months | | 42/48 | (87.5%)
| | | | <24 months | | 47/48 | (97.9%)
2627 Tos 1979 [This cohort is also in articles 2189, 2631, 2634, 2639, 2642, 4834, and 4835] | [underlined: Study Type]: ^a^ | [underlined: Time]: recruitmen1t 1/1997 to 4/1997 with last follow-up 12 months after initial exam | [underlined: Type of OME]: In this evidence table, we are looking at those from the original cohort with tympanogram type B (n=4 in article 2627 and n=3 in article 2189), C1 (n=20 in article 2189), or C2 (n=58 in article 2189) at the 6-month follow-up visit and presented for all 5 follow-up visit. Type B was not seen until the 6-month follow-up visit. Type C1 was seen in 24 patients at 2–4 days of age and 32 at the 3-month follow-up. Type C2 was seen initially in 1 patient at the 3-month follow-up. ^a^ | OME resolution by earusing the 6-month
| [underlined: Study Quality Score (0–6)] | [underlined: Place]: ^a^ | [underlined: Age]: ^a^ | <3 months resolution
| [underlined: OME definition]: ^a^ | [underlined: Inclusion]: ^a^ | [underlined: Gender]: 50 males, 40 females | Type # resolved/# at risk (%)
| [underlined: Group]: ^a^ | [underlined: Exclusion]: ^a^ | [underlined: Examiner(s)]: ^a^ | B to A | | 1/4 | (25.0%)
| N=90 children who presented for all 5 follow-up exams | | [underlined: OME diagnostic method]: ^a^ | B to A/C1 | | 1/4 | (25.0%)
| N for type B at cohort inception=4 in this article but was 3 in articles 3189 and 2631. | | [underlined: Interventions]: ^a^ | B to A/C1/C2 | | 1/4 | (25.0%)
| N for type B/C2 at cohort inception=27. | | [underlined: Interventions]: ^a^ | B/C2 to A | | 5/20 | (25.0%)
| N for type B/.C2/C1 at cohort inception=91. | | | B/C2 to A/C1 | | 11/20 | (55.0%)
| | | | B/C2/C1 to A | | 11/20 | (32.0%)
| | | | <6 months resolution
| | | | Type # resolved/# at risk (%)
| | | | B to A | | 1/4 | (25.0%)
| | | | B to A | | 1/4 | (25.0%)
| | | | B to A/C1 | | 1/4 | (25.0%)
| | | | B to A/C1/C2 | | 1/4 | (25.0%)
| | | | B/C2 to A | | 20/20 | (10.0%)
| | | | B/C2 to A/C1 | | 8/20 | (40.0%)
| | | | B/C2/C1 to A | | 8/20 | (33.3%)
2629 Tos 1979 [This cohort is also in articles 2190, 2631, 2634, 2593, 2639, 2642, 4834, and 4835.] | [underlined: Study Type]:^a^ | [underlined: Time]: 11/1977-81/1978^a^ | [underlined: Type of OME] ^a^ | OME resolution be [underlined: ear] using the initial 11/1977 denominators from Table I in article 2631 (Table III)
| [underlined: Study Quality Score (0–6)]:^a^ | [underlined: Place]:^a^ | [underlined: Age]:^a^ | <9 months resolution
| [underlined: OME definition]:^a^ | [underlined: Inclusion]:^a^ | [underlined: Examiner(s)]:^a^ | Type | | #resolved/# at risk | (%)
| [underlined: Group]:Healthy two-year-old children residing in two Copenhagen county municipalities | [underlined: Exclusion]:^a^ | [underlined: OME diagnostic method] ^a^ | B to A | | 19/51 | (37.3%)
| N=278 children at initial exam; N=222 children who presented at 3 follow-up exams. | | [underlined: Intervensions]:^a^ | B to A/C1 | | 36/51 | (70.6%)
| N for type B at cohort inception=60 | | [underlined: Interval of screening]:3, 6, and 9 months after initial diagnosis^a^ | B to A/C1/C2 | | 43/51 | (84.3%)
| N for type B/C2 at cohort inception=172. | | | B/C2 to A | | 63/138 | (45.7%)
| N for type B/C2/C1 at cohort inception=280 | | | B/C2 to A/C1 | | 100/138 | (72.5%)
| | | | B/C2/C1 to A | | 118/229 | (51.5%)
2634 Tos 1980 [The 1976 cohort is also in articles 2190, 2629, 2631, 2593, 2639, 2642, 4834, and 4835. The 1977 cohort is also in articles 2189, 2627, 2631, 2642, 4834, and 4835.] | [underlined: Study Type]: ^a^ | [underlined: Time]:^a^ | [underlined: Type of OME]:^a^ | OME resolution by[underlined: ear] (Table III)
| [underlined: Study Quality Score (0–6)]: ^a^ | [underlined: Place]:^a^ | [underlined: Age]: ^a^ | <3 months resolution
| [underlined: OME definition]:^a^ | [underlined: Inclusion]:^a^ | [underlined: Examiner(s)]:^a^ | Type | | #resoved/# at risk | (%)
| N=^a^ | | [underlined: Interventions]:^a^ | B toA | | 6/51 | (11.8%)
| | | [underlined: Interval of screening]:^a^ | B to A/C1 | | 13/51 | (25.5%)
| | | | B to A/C1/C2 | | 27/51 | (52.9%
| | | | <6 months resolution
| | | | Type | | #resolution/#at risk | (%)
| | | | B to A | | 15/51 | (29.4%)
| | | | B to A/C1 | | 21/51 | (41.2%
| | | | B to A/C1/C2 | | 30/51 | (58.8%)
| | | | <9 months resolution
| | | | Type | | #resolved/# at risk | (%)
| | | | B to A | | 19/51 | (37.3%)
| | | | B to A/C1 | | 36/51 | (70.6%)
| | | | B to A/C1/C2 | | 43/51 | (84.3%)
| | | | Cumulative OME resolution by [underlined: ear]
| | | | <3 months resolution
| | | | <6 months resolution
| | | | Type | | #resolved/# at risk | (%)
| | | | B to A | | 16/51 | (31.4%)
| | | | B to A/C1 | | 24/51 | (47.1%)
| | | | B to A/C1/C2 | | 34/51 | (66.7%)
| | | | <9 months resolution
| | | | Type | | #resolved/#at risk | (%)
| | | | B to A | | 24/51 | (47.1%)
| | | | B to A/C1 | | 34/51 | (66.7%)
| | | | B to A/C1/C2 | | 44/51 | (86.3%)
543 Tos, Holm-Jensen, Sørenson, and Mogensen 1982 [This cohort is also in articles 1486, 2636, 2639, 2642, 4834, and 4835.] | [underlined: Study Type]: ^a^ | [underlined: Time]: The authors identify this study as their 1976 birth cohort, but it is actually their 1975 birth cohort. ^a^ | [underlined: Type of OME]:^a^ | OME resolution by [underlined: ear]
| [underlined: Study Quality (0–6)]: ^a^ | [underlined: Place]:^a^ | [underlined: Age]:^a^ | <3 months resolution (Figure 1)
| [underlined: OME definition]: ^a^ | [underlined: Inclusion]:^a^ | [underlined: Examiner(s)]:two experienced technicians^a^ | Type | | #resolved#at risk | (%)
| [underlined: Group]:^a^ | [underlined: Exlusion]:^a^ | [underlined: OME diagnostic method]:^a^ | B to A | | 3/87 | (3.4%)
| N=288 children who attended all 4 follow-up exams | | [underlined: Interventions]:^a^ | B to A/C1 | | 12/87 | (13.8%)
| N for type B at cohort inception=101 ears (note difference from article 1486). | | [underlined: Interval of screening]:^a^ | B to A/C1/C2 | | 51/87 | (58.6%)
| N for type B/C2 at cohort inception=317 ears (note difference from article 1486). | | | B/C2 to A | | 49/265 | (18.5%)
| N for type B/C2/C1 at cohort inception=477 ears. | | | B/C2 to A/C1 | | 102/265 | (38.5%)
| | | | B/C2/C1 to A | | 103/393 | (26.2%)
| | | | <6 months resoltuion (Figure 1)
| | | | Type | | #resolved/# at risk | (%)
| | | | B to A | | 14/87 | (16.1%)
| | | | B to A/C1 | | 22/87 | (25.3%)
| | | | B to A/C1/C2 | | 49/87 | (56.3%)
| | | | B/C2 to A | | 51/265 | (19.2%)
| | | | B/C2 to A/C1 | | 118/265 | (44.5%)
| | | | B/C2/C1 to A | | 96/393 | (24.4%)
| | | | < 9 months resolution (Figure 3 and 4)
| | | | Type | | #resolved/# at risk | (%)
| | | | B to A/C1 | | 20/82 | (24.4%)
| | | | B to A/C1/C2 | | 39/82 | (47.6%)
| | | | B/C2 to A/C1 | | 106/247 | (42.9%)
| | | | <12 months resolution (Figures 3 and 4)
| | | | Type | | #resolved/# at risk | (%)
| | | | B to A/C1 | | 15/82 | (18.3%)
| | | | B to A/C1/C2 | | 42/82 | (51.2%)
| | | | B/C2 to A/C1 | | 76/247 | (30.8%)
| | | | Cumulative OME resolution by ear
| | | | <3 months resolution (same as above)
| | | | <6 months resolution (Figure 1)
| | | | Type | | #resolved/# at risk | (%)
| | | | B to A | | 17/87 | (19.5%)
| | | | B to A/C1 | | 31/87 | (35.6%)
| | | | B to A/C1/C2 | | 62/87 | (71.3%)
| | | | B/C2 to A | | 85/265 | (32.1%)
| | | | B/C2 to A/C1 | | 152/265 | (57.4%)
| | | | B/C2/C1 to A | | 152/393 | (38.7%)
| | | | [underlined: <9 months resolution (Figures 3 and 4)]
| | | | Type | | #resolved/# at risk | (%)
| | | | B to A/C1 | | 37/82 | (45.1%)
| | | | B to A/C1/C2 | | 60/82 | (73.2%)
| | | | B/C2 to A/C1 | | 166/247 | (67.2%)
| | | | [underlined: <12 months resolution (Figures 3 and 4)]
| | | | Type | | #resolved/# at risk | (%)
| | | | B to A/C1 | | 41/82 | (50.0%)
| | | | B to A/C1/C2 | | 64/82 | (78.1%)
| | | | B/C2 to A/C1 | | 174/247 | (70.5%)
91 van Balen, de Melker, Touw-Otten 1996 | [underlined: Study Type]: prospective single cohort embedded in a randomized controlled trial | [underlined: Time]: recruited 12/1992 to 8/1994 and then followed for 3 months | [underlined: Type of OME]: newly diagnosed OME of unknown duration | OME resolution by [underlined: child] (Figure)
| [underlined: Study Quality (0–6)]: 3(111000) | [underlined: Place]: 57 general practices in the Netherlands | [underlined: Age]: 6 months to 6 years old | time | | #resolved# | (%)
| [underlined: OME definition]: presence of fluid in the middle-ear cavity behind an intact tympanic membrane without signs or symptoms of acute infection | [underlined: Inclusion]; - 6 months to 6 years old; - bilateral OME | [underlined: Laterality]: all bilateral | <3 months | | 223/433 | (51.5%)
| [underlined: Group]: children with bilateral OME | [underlined: Exclusion]: none | [underlined: Examiner(s)]: general practitioner trained in tympanometry | [Authors did not distinguish between partial and complete resolution.]
| N=433 | | [underlined: OME diagnostic method]: tympanometry; - A: –99 to +200 dPa and max compliance >= 0.2 mmho; - B: <= –400 dPa and max compliance < 0.2 mmho; - C1: –199 to –100 dPa and max compliance >=0.2 mmho; - C2: –399 to –200 dPa and max compliance >= 0.2 mmho; - Middle-ear effusion defined by B or C2 curves.
| | | [underlined: Interventions]: Authors stated children received no treatment for their ear problems and noted that “In the Netherlands it is not common to treat OME with antimicrobial drugs.” It is possible antibiotics were used during the watchful waiting period.
| | | [underlined: Interval of screening]: 3 months after initial exam
2791 Williamson 1994 | [underlined: Study Type]: prospective single cohort | [underlined: Time]: Recruitment 9/1988–3/1989; study period ended summer 1991 | [underlined: Type of OME]: newly diagnosed OME of unknown duration | Ome resolution of a cohort with[underlined: type B tympanogram]in spring of 1990 (We assume the denominator at each time is the total.) (page 932
| [underlined: Study Quality Score (0–6)]: 2(110000) | [underlined: Place]: School medical room in four adjacent Infant and First Schools in the SW Hampshire area | [underlined: Age]: 5–8 years old | Resolution by CHILD
| [underlined: OME definition]: not defined | [underlined: Inclusion]:; - 5–8 years old; - attending four attending four adjacent Infant and First schools in South West Hampshire | [underlined: Examiner(s)]: unknown | Resolution
| [underlined: Group]: Children attending four adjacent Infant and First schools in South West Hampshire participating schools and screened by tympanometry once per term at a four-month interval until they left primary school | [underlined: Exclusion]: None | [underlined: OME diagnostic method]: tympanometry; - A: 200 to –99 pressure; - B: lack of defined compliance maximum; - C1: –100 to –199 pressure; - C2: –200 to –400 pressure | Time | | #resolved# | (%)
| N=856 subject | | [underlined: Interventions]: The authors report that 27 children had grommets in situ during the study period. This includes 6 children in the Spring 1990 cohort with type B tympanograms whose OME resolution is reported. | <4months | | 22/50 | (44.0%)
| | | [underlined: Interval of screening]: once per term at a four-month interval until the child left primary school | <8 months | | 38/50 | (76.0%)
| | | | <1 year | | 45/50 | (90.0%)
| | | | Resulution by EAR
| | | | Resulution
| | | | Time | | #resolved# at risk | (%)
| | | | <4 months | | 35/67 | (52.2%)
| | | | <8 months | | 52/67 | (77.6%)
| | | | <1 year | | 61/67 | (91.0%)
2863 Zielhuis, Rach, and van den Broek 1990 | [underlined: Study Type]: prospective single cohort | [underlined: Time]: Follow-up from age 2–4 years in children born between 9/1/1982-8/31/1983 | [underlined: Type of OME]: newly diagnosed OME of unknown duration | The authors presented an equation to estimate resolution of first OME episode by [underlined: ear] based on the study data. (page 217)
| [underlined: Study Quality Score (0–6)]: 3(111000) | [underlined: Place]: Measurements carried out at the children's home in Nijmegen, The Netherlands | [underlined: Age]: 4 years old | y=2exp(-0.33x)
| [underlined: OME definition]: type B tympanogram signified OME but otherwise not defined | [underlined: Inclusion]: | [underlined: Examiner(s)]: three trained audiologic assistants | y=probability of OME
| [underlined: Group]: Preschool children seen in follow-up for OME every 3 months from 2–4 years of age (n=609 children had all nine total screenings out of 1328 whose parents agreed to participate) | - Age: 4 years; - born in Nijmegen during the period 9/1/1982-8/31/1983 and living in Nijmegen on their 2nd birthday; - screened every 3 months since 2 years of age; - parental consent | [underlined: OME diagnostic method]: tympanometry | x=follow-up in months
| N=1328 subjects | [underlined: Exclusion]: None | - A: compliance ≥0.2 ml and pressure ≥-99 dPa; - B: compliance <0.2 ml and pressure ≤ -400 dPa; - C1: compliance ≥0.2 ml and pressure -100 to -199 dPa; - C2: compliance ≥0.2 ml and pressure -200 to -399 dPa; - B: compliance <0.2 ml and pressure ≤ -400 dPa | r^2^=0.98
| | | [underlined: Interventions]: The authors did not mention control of medications. 56 of the children were treated with ventilating tubes. | Duration of all OME by ear (Figure 4)
| | | [underlined: Interval of screening]: every 3 months after initial screen until 4 years old | Mean: 5.0 months
| | | | Standard error of mean: 0.08 months
| | | | 5^th^ %ile: 3 months
| | | | 25^th^ %ile: 3 months
| | | | median: 3 months
| | | | 75^th^ %ile: 6 months
| | | | 95^th^ %ile: 12 months
| | | | [mixture of OME diagnosed at initial screen and OME arising during the study period]
| | | | Estimated cumulative OME resolution by [underlined: ear] based on the above equation and numbers given in Figure 2Figure 2 (N=1631 ears of 816 children)
| | | | Time | | # resolved/# at risk | (%)
| | | | <3 months | | 816/1631 | (50.0%)
| | | | <6 months | | 1223/1631 | (75.0%)
Record# Author Year | Findings
2863 Zielhuis, Rach, and van den Broek 1990 | Duration of all OME episodes by ear by influencing factors (Table 3)
| | | [underlined: % with duration of]
| [underlined: Factor] | [underlined: Category] | [underlined: 3 months] | [underlined: 6 months] | [underlined: 9 months or more] | [underlined: Mean Duration] | [underlined: p-Value]
| Season at start of OME | Autumn | 59.7% | 19.5% | 20.8% | 4.8 | <0.001
| | Winter | 65.6% | 17.7% | 16.7% | 4.5
| | Spring | 61.3% | 24.2% | 14.5% | 4.6
| | Summer | 69.0% | 20.2% | 10.8% | 4.3
| Age at end of episode | 24–29 | 77.9% | 22.1% | 0.0% | 3.7 | <0.001
| | 30–35 | 60.4% | 19.5% | 20.1% | 4.8
| | 36–41 | 64.4% | 20.7% | 14.9% | 4.5
| | 42–48 | 56.6% | 19.4% | 20.0% | 5.0
| Sex | Male | 64.4% | 20.9% | 14.7% | 4.5 | 0.44
| | Female | 63.7% | 19.7% | 16.6% | 4.6
| Upper respiratory tract infection | Yes | 64.4% | 19.5% | 16.1% | 4.6 | 0.24
| | No | 63.8% | 22.2% | 14.0% | 4.5
| History of acute otitis media | Yes | 62.1% | 23.0% | 14.9% | 4.6 | 0.77
| | No | 57.1% | 24.5% | 18.4% | 4.8

a See 1000 Casselbrant, Brostoff, Cantekin, Doyle, Bluestone, and Fria (1985).

a See 1237 Fiellau-Nikolajsen and lous (1979) and 1245 Fiellau-Nikolajsen (1983).

a See 1237 Fiellau-Nikolajsen and Lous (1979).

[mixture of OME diagnosed at initial screen and OME arising during the study period]

a See 2190 poulsen and Tos (1980).

a See 2189 poulsen and Tos (1978).

a See 2190 Poulsen and Tos (1980).

a See articles 2190 Poulsen and Tos (1980) and 2189 Poulsen and Tos (1978).

a See 2190 Poulsen and Tos (1980).

[The eight components of study quality score are: study cohort clearly defined; subjects assembled at a uniform time point; pathway of subject entry clearly described; complete follow-up achieved; withdrawals/drop-outs described; objective outcomes used; outcome assessment blinded; and extraneous factors adjusted. 1 indicates presence and 0 indicates absence.]

Evidence Table 2. Early Life OM and Long-Term Speech and Language Development

Record# Author Year | Study Quality OME Definition Group(s) and Sample Size | Time/Place Subject Characteristics Inclusion/Exclusion Criteria | | | Risk Groups Predictors Outcome Measures | Findings
877 Black 1993 | Prospective Cohorts Study | [underlined: Time]: 4-year follow-up (actual time of study not specified) | | | [underlined: Age]: OM history: first year of life Outcomes: 4–6 years of age | | OM+ | OM-
| [underlined: Study Quality Score (0–8)]: 3 (00001101) | [underlined: Place]: Inner-city sample in Baltimore, Maryland | | | [underlined: OM History]: At least 2 episodes of OM within the first year documented of otologic exam. A child could receive credit for only one bout of OM within each 29-day period. | Test | Mean (SD) | Mean (SD)
| | [underlined: Characteristics:]
| [underlined: OM Diagnosis:] By otologic examination by unspecified examiner. | - 87% had African-American primary caregivers; - 61% had not completed high school; - 81% single women; - 91% received medical assistance; - all children were enrolled in kindergarten or Head Start I | | | [underlined: Outcome Measures:] Cognitive development: McCarthy Scales of Children's Abilities (verbal, perceptual processing, quantitative, memory, and motor). Each has a mean score of 50 and a standard deviation (SD) of 10. Scores on the first 3 scales are summed to give a GCI with a mean (SD) of 100 (15). | McCarthy Scales
| | [underlined: Inclusion:]
| [underlined: OM Groups:] Group 1: OM+: High Infant Otitis Media (at least two cases of otitis media within the first year of life documented by otologic examination) Group 2: OM-: No Infant Otitis Media (Had not experienced otitis media during first year of life) | - Age: 4 years follow-up of the original cohort of infants; - partipated in authors earlier study; - Born at term with appropriate weight for gestational age; - No medical problems beyond OM | | | Language development: Peabody Picture Vocabulary Test-Revised, an assessment of receptive language. Has mean (SD) of 100 (15). | Verbal | 46.7 (11.5) | 41.0 (10.7)
| N=31 subjects | [underlined: Exclusion]: None | | | | Perceptual | 47.5 (12.8) | 43.2 (11.4)
| N1=21 | | | | | Quantitative | 43.6 ( 8.6) | 39.1 (10.5)
| N2=10 | | | | | Memory | 46.0 (10.6) | 41.5 (12.0)
| | | | | | Motor | 53.0 (12.4) | 36.4 (10.2) | | -------
| | | | | | GCI^a^ | 92.6 (19.5) | 84.9 (19.3)
| | | | | | PPVT-R^b^ | 82.9 (17.3) | 72.4 (17.6)
| | | | | | ^a^ General cognitive index
| | | | | | ^b^ Peabody Picture Vocabulary Test-Revised
1219 Feagans 1987 | Prospective cohort study | [underlined: Time]: 1972-1982 | | | [underlined: Age]: OM History: 0–3 year of life Outcomes: at 5–7 years of age | | | [underlined: Mean (SD)]
| [underlined: Study Quality Score (0–8)]: 5 (11100101) | [underlined: Place]: Children were sampled from a day care center in Pennsylvania | | | [underlined: OM History]: Frequency of OM Duration of OM | Length of utterance
| | [underlined: Characteristics:]
| [underlined: OM Diagnosis]: OM diagnosed by 2 pediatricians and 2 nurse practitioners using pneumatic otoscopy. Beginning 1978 tympanometry was used to corroborate the diagnosis | - Black; - Low socioeconomic status;; - Attended day care center 50 weeks per year from 6 weeks to 5 years of age. | | | [underlined: Outcome Measures]: Mean length of utterance (MLU) at age 5 Mean length of utterance (MLU) at age 6 Paraphrase score at age 5 Paraphrase score at age 6 | | At age 5 | 10.3 (2.9)
| | [underlined: Inclusion:]
| Group: Children who were part of a medical and day care intervention project | - Age: 5–7 years (measures at both time points); - children who were followed from birth to 2nd grade; - biologically normal at birth; - high risk for general developmental delays in language and intelligence due to low SES | | | [underlined: Predictors in the study]: Mother's IQ at birth Mother's education Home environment (HOME) at 18 months Language (WPPSI IQ) at age 5 Frequency of OM in 0–3 years of life Duration of OM in 0–3 years of life | | At age 7 | 12.4 (3.8)
| N=44 subjects | [underlined: Exclusion]: None | | | | Parapharase Score
| | | | | | At age 5 | 10.3 (2.9)
| | | | | | At age 7 | 8.0 (1.0)
| | | | | | [underlined: Multiple regression analysis-Age 5] MLU: R^2^ = 0.07, p>0.10, no variable significant.
| | | | | | [underlined: Paraphrase score]: R^2^ = 0.47, p<0.001, WPPSI IQ most significant followed by frequency of OM.
| | | | | | [underlined: Multiple regression analysis-Age 7] [underlined: MLU]: R^2^ = 0.13, p<0.20; IQ was the only significant predictor (R^2^= 0.12, p<0.02).
| | | | | | [underlined: Paraphrase score]: R^2^ = 0.22, p>0.11; WPPSI and duration of OM were significant predictors (R^2^= 0.18, p<0.02)
1255 Fischler 1985 | Retrospective-prospective study | [underlined: Time]: Start date~7/1974 | | | : OM history: 0–2 years of life Outcome: at 6–8 years | Mean (SD)
| | | | | [underlined: Examiner(s):]
| [underlined: Study Quality Score (0–8)]: 5 (11001110) | [underlined: Place]: Four Indian reservations in Arizona | | | - Unspecified physicians for diagnosis of otitis media;; - School nurse for hearing tests;; - Pediatrician/otolaryngologist for otoscopic examinations;; - Certified speech pathologists for language testing. | | Group 1 | Group 2 | Group 3
| | [underlined: Characteristics:]
| [underlined: OM Diagnosis]: By medical record review of documented physician's clinical diagnosis. | - 50% had family income under $5000 per year; - 37% had housing below average; - 13% primarily Apache speaking at home | | | [underlined: OM history]: Groups defined by number of OM episodes by age 2 | OM risk | High | Moderate | Low
| | [underlined: Inclusion:] | | | [underlined: Outcome measures:]
| [underlined: OM Groups]: Group 1: HR/REC (HR-High risk status,REC-recurrences of OM attacks after age 2) ~ >=2 attacks by age 2 yr and >=3 attacks after age 2 yr Group 2: HR/NREC ~ >=2 attacks by age 2 yr and <3 attacks after age 2 yr Group 3: NHR/NREC ~ <2 attacks by age 2 yr and <3 attacks after age 2 yr | - Age: 6–8 years; - healthy Apache Indian children who had been followed since birth | | | - Four subtests of the Test of Language Development (TOLD).; - Two receptive language subtests (picture vocabulary [PV] and grammatic understanding [GU]); - Two expressive subtests (grammatic completion [GC] and oral vocabulary [OV]); - Articulation: informally scored as normal or suspect; - Nonverbal intelligence by the block-design subtest of the Wechsler Intelligence Scale for Children-Revised (WISC-R) | TOLD subtest
| | [underlined: Exclusion:]
| N=167 | - moved during study period; - absent or not tested because of time constraints; - medical reasons (specific conditions not specified) | | | [For all subtests raw scores were converted into age standardized scores. Standard scores were based on national norms having mean (SD) of 10 (3).] | Receptive language
| N1=33 | | | | | PV | 5.6 (2.3) | 6.8 (2.8) | 6.1 (2.7)
| N2=63 | | | | | GU | 7.2 (2.2) | 8.1 (2.3) | 7.9 (2.1)
| N3=71 | | | | | TOLD subtest
| | | | | | Expressive language
| | | | | | GC | 5.0 (1.7) | 5.7 (1.9) | 5.4 (2.4)
| | | | | | OV | 6.1 (3.0) | 7.7 (2.8) | 7.1 (2.7)
| | | | | | WISC-R block design
| | | | | | Non-verbal intelligence
| | | | | | | 10.6 (2.9) | 10.4 (3.1) | 10.0 (2.7)
1277 Freeark 1992 | Retrospective-Prospective Cohort Study | [underlined: Time]: not specified | | | [underlined: Age]: OM history: 0–3 years of life Outcome: 3–4 years | | [underlined: VSI below mean (# and %)]
| [underlined: Study Quality Score (0–8)]: 4 (10000111) | [underlined: Place]: university-based pediatric clinic, Michigan | | | [underlined: Examiner(s)]: Trained examiners for language testing. | | | High OM | Low OM
| | [underlined: Characteristics:]
| [underlined: OM Diagnosis]: By whom, not specified; How diagnosed, not specified. (OM history obtained from medical records). | - 86% white; - 82% of mothers and 91% of fathers with at least some college education; - 77% of fathers in lower middle to upper middle class occupations or were full-time graduate students; - 75% of mothers employed | | | [underlined: OM Groups]: Group 1: High OM: Above median of OM severity defined by frequency of OM episodes and days with effusion. Group 2: Low OM: Below median of OM severity defined by frequency of OM episodes and days with effusion. N=54 subjects N1=26 N2=28 | | High PVS Group | 2/14 | 10/14
| | [underlined: Inclusion:]
| | - Age: 3–4 years; - in patient roster of a university-based pediatric clinic; - both parents living in home; - parents had at least a high school ed. and not receiving public assistance; - family had no more than four children; - child did not suffer from a chronic illness or disability | | | [underlined: OM History]: OM severity defined by a) number of separate episodes of otitis and b) total number of days of effusion over the first 3 years. | | | 14% | 71%
| | [underlined: Exclusion]: None | | | [underlined: Outcome measures]: Verbal Scale Index (VSI) of the McCarthy Scale of Children's Abilities - a summary measure of the child's verbal abilities derived from 6 subtests assessing verbal fluency and memory, word knowledge, and verbal reasoning. | | Low PVS Group | 8/12 | 4/14
| | | | | [underlined: Stratification Factor]: Parent Verbal Stimulation (PVS) - total frequency of mothers' and fathers' descriptive and reflective statements and questions during the first 10 minutes of the dyadic interaction. | | | 67% | 29%
| | | | | | | Total | 10/26 | 14/28
| | | | | | | | 38% | 50%
| | | | | | Hierarchical multiple regression analysis showed that interactions between parent verbal stimulation and otitis severity were significant in predicting the VSI and the VIP score for the interaction segment with fathers.
1373 Gravel 1992 | Prospective Cohort Study | [underlined: Time]: not specified | | | [underlined: Age]: OM history: 0–1 of life Outcome: at 4 years of age | | | Mean (SD)
Same cohort in 1941, 2295 and 4728. | [underlined: Study Quality Score (0–8)]: 5 (11001110) | [underlined: Place]: Clinical Research Center for Communicative Disorders (which draws subjects from the LIFE Program of the R.F. Kennedy Center, Albert Einstein College of Med. Bronx, NY | | | [underlined: Examiner(s)]: Not specified | | | [underlined: OM+] | [underlined: OM-]
| | [underlined: Characteristics:]
See 1941, 2295, and 4728 for further comments. | [underlined: OM Diagnosis]: Pediatric nurse practitioners completed pneumo-otoscopic examinations. | - low socioeconomic urban neighborhoods based on Hollingshead's (1975) index; - none had sensorineural hearing loss | | | [underlined: OM history]: OM groups were defined by otoscopic histories. | | Cognitive
| | [underlined: Inclusion:]
| [underlined: OM Groups]: Group 1: OM+: Otitis positive children - when bilateral OM was detected at 30% or more of the baby's first year visits. (Also, had poorer auditory sensitivity by click ABR.) | - Age: 4 years (measures taken during first year of life as well); - all children were enrolled at 40 wks postconceptional age for follow-up through the LIFE Program; - either high-risk infant graduates of a NICU or FT graduates of the well-baby nursery of Jacobi Hospital; - English reported as the primary language spoken | | | [underlined: Outcome measures]: Cognitive measures (Stanford-Binet 4^th^ Edition): Composite IQ Score Verbal reasoning Abstract/visual reasoning Quantitative reasoning, Short-term memory | | N | 9 | 13
| | [underlined: Exclusion:]
| Group 2: OM-: Otitis negative children - when middle ear status was rated as normal in both ears during 80% or more of the first year visits. N=23 N1=10 N2=13 | - neurologically compromised | | | Language measure (Sequenced Inventory of Communication Development-Revised (SICD-R) - a standardized measure of communicative functioning combining parental report with direct assessment: Expressive scale Receptive scale | | Global IQ | 87.8 (14.8) | 86.0 (8.6)
| | | | | | | Verbal IQ | 88.3 (15.9) | 84.3 (9.4)
| | | | | | | Expressive language in months
| | | | | | | N | 8 | 12
| | | | | | | Mean (SD) | 36.0 (5.2) | 39.0 (6.2)
| | | | | | | Receptive language in months
| | | | | | | N | 8 | 13
| | | | | | | Mean (SD) | 35.5 (5.4) | 37.8 (5.3)
4728 Gravel 1996 | Prospective Cohort Study | [underlined: Time]: not specified | | | [underlined: Age]: OM history: 0–1 of life Outcome: at 9 years of age | No raw data were reported.
Same study subjects as 1373, 1941, 2295 | [underlined: Study Quality Score (0–8)]: 3 (01000110) | [underlined: Place]: Clinical Research Center for Communicative Disorders (which draws subjects from the LIFE Program of the R.F. Kennedy Center, Albert Einstein College of Med. Bronx, NY | | | [underlined: Examiner(s)]: Not specified | The following were reported between OM+ and OM- groups:; 1. A significant difference between the early OM+ and early OM- groups was found on the story-recall memory task (t=2.42; p=0.032).; 2. No significant differences between the groups were found on the MLD, competitive listening tasks, language screen, the PSI selective auditory attention task, or the story recognition-memory task.
See 1373, 1941, and 2295 for further comments. | [underlined: OM Diagnosis]: Pediatric nurse practitioners completed pneumo-otoscopic examinations. | [underlined: Characteristics:]; - low socioeconomic urban neighborhoods based on Hollingshead's (1975) index; - all had normal hearing and normal middle-ear function on test day | | | [underlined: OM history]: OM groups were defined by otoscopic histories.
| [underlined: OM Groups]: Group 1: Otitis positive children - when bilateral OM was detected at 30% or more of the baby's first year visits. Group 2: Otitis negative children - when middle ear status was rated as normal in both ears during 80% or more of the first year visits. N=17 subjects N1=10 N2=7 | [underlined: Inclusion:]; - Age: 9 years; - born in the same urban hospital; - auditory testing conducted during first year of life and at 9 years of age | | | [underlined: Outcome measures:]; - Binaural masking level difference (MLD); - Speech-in-competition task-adapted from the Pediatric Speech Intelligibility (PSI) test; - Selected auditory attention task - An experimental version of the PSI; - Story memory tasks - a subset of the standardized Wide Range Assessment of Memory and Learning (WRAML); - Clinical Evaluation of Language Fundamentals-Revised (CELF-R)
1435 Harsten 1993 | Prospective Cohort Study | [underlined: Time]: not specified | | | [underlined: Age]: OM history: 0–3 year of life Outcomes: at 4 and 7 year of age | [underlined: Phonology]
| [underlined: Study Quality Score (0–8)]: 6 (11101110) | [underlined: Place]: University Hospital of Lund, Sweden | | | [underlined: Examiner(s)]: Otolaryngologist for otomicroscopy, tympanometry, tone-audiograms Phoniatrician and clinical linguist for hearing and speech | % (#) had traces of deviance/deviant
| [underlined: OM Diagnosis]: AOM was diagnosed by otomicropscopy, performed by an otolaryngologist and defined as an acute episode of earache in a child, with red bulging eardrum(s) or purulent discharge, occasionally febrile and with signs of upper respiratory tract infection. | [underlined: Characteristics]:; - 45% first-borns; - 71% mother educated at college level | | | [underlined: OM history]: Groups defined by number of episodes of AOM during a 12 month period. | | RAOM | Healthy
| [underlined: OM Groups]: Group 1: Children with recurrent AOM (RAOM defined as at least six episodes of AOM during a 12-month period) during the first 3 years of life Group 2: Children without any AOM episode during the first 3 years of life N=42 subjects N1=13 N2=29 | [underlined: Inclusion:]; - Age: Birth cohort; - monolingual, Swedish children, born at University Hospital of Lund | | | [underlined: Outcomes:]; - Phonology - based on material from the phoneme test and producing word pairs of the auditory discrimination task.; - Grammar - from the Ringsted material; - Interaction - Thematic pictures were used for this analysis; - Grammatical and interactional analysis - based on sequential pictures and thematic pictures | Age 4 | 69% (9/13) | 76% (22/29)
| | | | | | Age 7 | 83% (10/12) | 54% (15/28)
| | | | | | [underlined: Grammar]
| | | | | | % (#) abnormal
| | | | | | | RAOM | Healthy
| | | | | | Age 4 | 0% (0/13) | 0% (0/29)
| | | | | | Age 7 | 0% (0/12) | 0% (0/28)
| | | | | | [underlined: Interaction]
| | | | | | % (#) had traces of deviance
| | | | | | | RAOM | Healthy
| | | | | | Age 4 | 31% (4/13) | 21% (6/29)
| | | | | | Age 7 | 17% (2/12) | 39% (11/28)
| | | | | | RAOM=recurrent acute otitis media
1623 Kaplan 1973 | Prospective Cohort Study | [underlined: Time]: Birth cohort (10/1960-12/1962); follow-up conducted between 9/1969-7/1971 | | | [underlined: Age]: OM history: 0–1 year of life Outcome: at 10 years of age | No Hearing Loss Group
| [underlined: Study Quality Score (0–8)]: 6 (11001111) | [underlined: Place]: 28 Eskimo villages located in the Yukon and Kuskokwim River Delta areas of Southwestern Alaska | | | [underlined: Examiner(s)]:; - Experienced audiologist for air and bone conduction measurements; - Two psychologists administered speech and intelligence testing | | Group 1 | Group 2 | Group 3
| [underlined: OM Diagnosis]: A research nurse visited the cohort children 4 times a year during first 2 years and at least 2 times a year for the next 2 years. During each visit, information concerning middle ear abnormality was obtained and medical records of the time between visits were reviewed. Only OM described with otorrhea was used for analysis. | [underlined: Characteristics]: Not described. | | | [underlined: OM history]: Groups based on onset of first episode of otorrhea during 0–1 year; during 2–10 years or no history. | [underlined: 1] ^st^ [underlined: om at] | [underlined: 0–1y] | [underlined: 2–12y] | [underlined: noOM]
| [underlined: OM Groups]: Group 1: age of onset of first otorrhea at 0–1 year of age Group 2: age of onset of first otorrhea at age 2–10 years Group 3: no history of otorrhea N=489 N1=291 N2=83 N3=115 | [underlined: Inclusion:]; - Age: Birth Cohort born between 10/1960-12/1962 and followed up between 9/1969-7/1971; - born in 25 villages w/in Alaska specified under place and/or residing in 3 additional villages at follow-up | | | [underlined: Outcomes:]; - Wechsler Intelligence Scale for Children (WISC) - modified; - Bender-Gestalt test; - Draw-A-Person test | N | 88 | 32 | 53
| | [underlined: Exclusion:]; - Children with pure sensory hearing loss were excluded from analysis | | | [underlined: Stratification Factor]: Concurrent hearing status: No hearing loss or conductive component or hearing loss at 26+dB | Verbal Score
| | | | | | Mean | 80 | 79 | 81
| | | | | | Range | (50–100) | (55–105) | (77-135)
| | | | | | Performance Score
| | | | | | Mean | 100 | 100 | 102
| | | | | | Range | (70–140) | (70–125) | (70-135)
| | | | | | Conductive Component Group
| | | | | | | Group 1 | Group 2 | Group 3
| | | | | | [underlined: 1] ^st^ [underlined: om at] | [underlined: 0–1y] | [underlined: 2–12y] | [underlined: noOM]
| | | | | | N | 42 | 8 | 17
| | | | | | Verbal Score
| | | | | | Mean | 70 | 80 | 76
| | | | | | Range | (45–90) | (60–100) | (55-90)
| | | | | | Performance Score
| | | | | | Mean | 92 | 100 | 95
| | | | | | Range | (55–125) | (85–110) | (75-115)
| | | | | | Hearing Loss 26+dB Group
| | | | | | | Group 1 | Group 2 | Group 3
| | | | | | [underlined: 1] ^st^ [underlined: om at] | [underlined: 0–1y] | [underlined: 2–12y] | [underlined: noOM]
| | | | | | N | 32 | 5 | 6
| | | | | | Verbal Score
| | | | | | Mean | 72 | 71 | 80
| | | | | | Range | (55–100) | (55–85) | (60-100)
| | | | | | Performance Score
| | | | | | Mean | 95 | 94 | 101
| | | | | | Range | (55–125) | (70–120) | (70-115)
4651 Klein 1988 | Prospective Cohort Study | [underlined: Time]: Enrollment of infants began in 1975 & continued for 2 yrs (7-year follow-up) | | | [underlined: Age]: OM history: first 3 years of life (recruited at <3 months of life) | No raw data were given.
| [underlined: Study Quality Score (0–8)]: 4 (10100101) | [underlined: Place]: Private practices in Holliston and Framingham, MA, and an urban health center in East Boston | | | [underlined: Outcome]: at 7 years of age | Multivariate results were reported as follows:
| [underlined: OM Diagnosis]: By pediatricians using pneumatic otoscopy until age 3 and both pneumatic otoscopy and tympanometry in years 4 through 7. | [underlined: Inclusion:]; - Random sample of children still active in the practices at age 7. | | | [underlined: Examiner(s)]: Pediatricians for OM history. Not mentioned for speech and language testing. | Least square (LS) mean and standard error (SE) of full scale WISC-R controlling for socioeconomic status and sex:
| [underlined: OM Groups]: Group 1: Time spent with effusion <32 days during first 2 years of life Group 2: Time spent with effusion 33–108 days during first 2 years of life Group 3: Time spend with effusion >108 days during first 2 years of life. N=196 subjects Number of subjects by groups not given | [underlined: Exclusion]:; - parental refusal; - nonwhite race; - English not the primary language spoken at home; - Seizures; - mental retardation, cerebral palsy; - hearing loss >20db at time of testing (deferred until able to pass hearing test) | | | [underlined: OM History]; - Criteria for effusion - otorrhea, gas-liquid levels visible on otoscopy or marked reduction of mobility. Tympanometric criterion: type B curve.; - Time spent with effusion - assigned a ‘window’ of 23 days to each observation of effusion, whether accompanied by signs of illness or not. It could be shortened or extended by multiple examinations. | Effusion Group
| | | | | [underlined: Outcome measure]:; - Wechsler Intelligence Scale for Children-Revised (WISC-R); - Goldman-Fristoe-Woodcock test; - WUG test; - Peabody Picture Vocabulary Test; - Boston Naming Test; - A recorded language sample; - Metropolitan Achievement Test (reading and mathematics) | | Group 1 | Group 2 | Group 3
| | | | | | | <32 d | 33–108 d | >108 d
| | | | | | LS mean | 113.4 | 107.5 | 105.6
| | | | | | SE | 1.41 | 1.49 | 1.34
| | | | | | Group 1 vs Group 3, p<0.0001
| | | | | | Group 2 vs Group 3, p=NS.
| | | | | | Group 2 vs Group 3, p=NS.
| | | | | | The investigators report that ‘similar results were found in both the performance and verbal scores. Speech and language measures significantly associated with otitis media during the first 3 years of life included aspects of speech production, speech perception, morphologic production, morphologic comprehension, lexical production, and syntactic production.
1941 Mody 1999 | Prospective Cohort Study | [underlined: Time]: Follow-up from birth to 9 years (actual dates not specified) | | | [underlined: Age]: OM history: first year of life Outcome: at 9 years of age | Mean number of items correctly reported
Same study as 4780 Mody 1996 | [underlined: Study Quality Score (0–8)]: 4 (11000101) | [underlined: Place]: Subjects recruited from Longitudinal Infant Follow-up and Evaluation (LIFE) program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, New York, NY | | | [underlined: Examiner(s)]: Trained and validated pediatric nurse practitioner for OM history; | | | OM+ | | OM-
Same cohort as 1373, 2295, and 4728. | [underlined: OM Diagnosis]: By trained and validated pediatric nurse practitioner (PNP) using a pneumatic otoscope under the supervision of a pediatric otolaryngologist. The PNP recorded a description of TM characteristics for each ear, using a 9-item otoscopic checklist and made the determination of “clear,” “suspicious,” or “positive” for OM. | [underlined: Characteristics:]; - 71% high risk births; - 64% male; - 57% African-American; - 36% Hispanic; - 64% low SES; - 36% middle SES | | | Type of examiner(s) not specified for speech and language testing. | Serial Position
See 1373, 2295, and 4728 for further comments. | [underlined: OM Group]: Group 1: OM+: (Children who had 30% or more of the 13 first-year visits with otitis media bilaterally) | [underlined: Inclusion:]; - Age: 9 years (followed from birth); - English is the primary language spoken in the home; - received all medical, audiological, and developmental assessments through the LIFE program at monthly evaluations from birth through first year; - normal hearing and normal middle ear function on test day | | | [underlined: OM history]: Defined by pneumatic otoscopy findings during first year of life. | 1 | | 64 | | 69
| Group 2: OM-: (Children who had 80% or more of the 13 first-year visits with normal middle ear findings bilaterally) | [underlined: Exclusion:]; - neurologically compromised as an infant | | | [underlined: Outcome measures]; - Four nonsense syllables (/sβ /, /zβ /, /kβ /, /gβ /) presented auditorily; - Test on identification and temporal order recall using 4 synthetic speech syllables, /ba/, /da/, /sa/ and /a/. | 2 | | 47 | | 53
| N=14 subjects | | | | | 3 | | 41 | | 57
| N1=7 | | | | | 4 | | 38 | | 53
| N2=7 | | | | | Errors by type and number of phonetic features
| | | | | | | | OM+ | | OM-
| | | | | | Transposition Errors | | 92% | | 95%
| | | | | | Total Errors | | 146 | | 104
| | | | | | 0 shared features | | 30 | | 18
| | | | | | 1 shared features | | 35 | | 21
| | | | | | 2 shared feature | | 81 | | 65
| | | | | | Mean (SD) number of errors on identification and temporal order judgment (TOJ) ^ a ^
| | | | | | | | [underlined: OM+] | | [underlined: OM-]
| | | | | | 1. /ba/-/da/
| | | | | | Identification | | 1.0(1.0) | | 0.4(0.8)
| | | | | | TOJ 400 | | 0.7(1.5) | | 0.0(0.0)
| | | | | | TOJ (100/50/10) | | 4.3(3.7) | | 1.1(0.9)
| | | | | | 2. /sa/-/a/
| | | | | | Identification 2.1(2.3) 1.7(1.4)
| | | | | | TOJ 400 3.1(2.5)0.6(0.8)
| | | | | | TOJ (100/50/10) 6.7(5.7) 3.6(3.2)
| | | | | | ^a^ [underlined: From article 4780.]
4675 Owen 1996 | Prospective Cohort Study | [underlined: Time]: Infants enrolled in program between 1984-1989 (5 yr follow-up) | | | [underlined: Age]: OM history: 0–3 years of life Outcome: at 5 years of age | Raw results were not reported.
| [underlined: Study Quality Score (0–8)]: 4 (11000101) | [underlined: Place]: Texas | | | [underlined: Examiner(s)]: Trained technicians for OM history Trained graduate students for language and cognitive testing. | The following findings were reported:
| [underlined: OM Diagnosis]: By trained technicians using automated screening tympanometers with a 226 Hz probe tone. Acoustic reflectivity was also measured using acoustic otoscope at 30% of visits. OME diagnoses were based on type B tympanogram or >= 5 acoustic reflectivity or visible purulent otorrhea without an otoscope. | [underlined: Characteristics:]; - 49% male; - 56% Euro-American; - 30% African-American; - 14% English-speaking Hispanic; - wide socioeconomic range; - Half breast fed at birth; - 41% had cigarette smoke exposure; - 19% mother smoked; - 63% attended day care | | | [underlined: OM history]: If 2 consecutive visits showed OME, the intervening days were counted as days with OME. If one visit showed OM and the next normal status, or vice versa, half of the intervening days were counted as days with OME. | 1. CELI, a measure of child's productive control of grammar, showed a significant inverse relation to duration of OME [t(266)=-2.62; p=0.01].; 2. Goldman-Fristoe, a measure of articulation errors, OME amount was positively related to articulation errors [t(213)-6.42;p=0.01]; 3. CAVAT yielded significant relations for auditory blending and auditory discrimination in quiet modified by ethnicity and breast feeding.; 4. TACL-R total and word class scores were also related to OME cluster group.; 5. High OME cluster group tended to be most adversely affected, but all relations were moderated, chiefly by ethnicity, breast feeding and home stimulation scores.; 6. Association of duration of OME in first 18 months of life and Stanford Binet composite scores: r=-0.11, p<0.05.; 7. Association of duration of OME and nonverbal reasoning and visualization factor scores: r=0.13, p<0.05); 8. Associations in 5 and 6 were not substantiated when effects of environmental and demographic variables were controlled in multivariate analysis.
| [underlined: OM Groups]: Group 1: High OME (children who had extended OME across first three years of life) | [underlined: Inclusion:]; - Age: 5 years (follow-up from birth); - healthy-term infant from English-speaking family | | | OME duration was defined as the proportion of time a subject spent with OME (total OME days divided by total days) in the period examined.
| Group 2: Early OME (children who had OME which peaked from 0–6 months of age) | [underlined: Exclusion]: None | | | [underlined: Outcome measures:]; - Test for Auditory Comprehension of Language-Revised (TACL-R); - Auditory discrimination subtests of the Carrow Auditory Visual Abilities Test (CAVAT); - Goldman-Fristoe test for articulation (G-F); - Carrow Elicited Language Inventory (CELI); - Stanford-Binet Fourth Edition for cognition
| Group 3: Later OME (children who had OME which peaked from 6–12 months of age) | | | | [underlined: Covariates:]Gender, Ethnicity, Birth rank, Day care attendance, Duration of breast feeding, Cigarette smoke exposure, SES, Educational stimulation at home, Mother's intelligence
| Group 4: Low OME (children who experienced relatively low levels across first 3 yrs of life)
| N=294 subjects Sample size for each group not specified.
2135 Paul 1993 | Retrospective-Prospective Cohort Study | [underlined: Time]: Not specified | | | [underlined: Age]: OM history: first 2 years of life Outcome: at 3 and 4 years of age | MLU - Mean (SD)
| [underlined: Study Quality Score (0–8)]: 3 (00100101) | [underlined: Place]: Portland Oregon. Subjects are subset of those participating in the Portland Language Development Project (PLDP), a longitudinal study of outcomes of early expressive language delay. | | | [underlined: Examiner(s)]: Certified audiologist in sound-treated booth. | | | OM+ | | OM-
| [underlined: OM Diagnosis:]Based on parental reporting. | [underlined: Characteristics:]; - all passed speech reception screenings; - 15–33% of each subgroup had abnormal tympanograms | | | [underlined: OM History]: Based on parental reports. | Normal Talkers | | n=8 | | n=13
| [underlined: OM Group]: Middle ear involvement was defined as either the placement of myringotomy tubes or the presence of six or more ear infections treated by a physician before the second birthday, by parent report. | [underlined: Inclusion:]; - Age: 20–34 at entrance; - subjects recruited from children participating in the Portland Language Development Project (PLDP)7 | | | [underlined: Outcome measures:]; - Goldman-Fristoe Test of Articulation at age 3; - Word Articulation subtest of the Test of Language Development-Primary at age 4.; - Sample of free speech collected during a 15-minute play interaction between mother and child at ages 3 and 4.; - Speech samples were used to compute mean length of utterance (MLU) in morphemes for each sample. | Age 3 | | 4.26(1.56) | | 4.05(0.85)
| Group 1: OM+: defined by middle ear involvement, stratified by normal or late talkers | [underlined: Exclusion]: None | | | [underlined: Stratification groups]: Children were placed in normal versus late talking (LT) groups on the basis of their expressive vocabulary size as reported by parents on the Language Development Survey (LDS) at intake into the PLDP. | Age 4 | | 4.82(0.32) | | 4.55(0.89)
| Group 2: OM-: lack of such middle ear involvement, also stratified by normal or late talkers. | | | | | Late Talkers | | n=12 | | n=11
| N=44 subjects | | | | | Age 3 | | 2.42(0.60) | | 2.61(0.79)
| N1=20 (8 normal and 12 late talkers) | | | | | Age 4 | | 4.08(1.05) | | 3.91(1.09)
| N2=24 (13 normal and 11 late talkers) | | | | | Goldman-Fristoe %tile - Mean (SD)
| | | | | | | | OM+ | | OM-
| | | | | | Normal Talkers^a^ | | n=8 | | n=13
| | | | | | Age 3 | | 58.9(33.0) | | 62.3(32.4)
| | | | | | Age 4 | | 57.1(26.0) | | 54.5(37.8)
| | | | | | Normal Talkers^a^ | | n=12 | | n=11
| | | | | | Age 3 | | 12.3(10.8) | | 18.9(19.8)
| | | | | | Age 4 | | 17.8(19.0) | | 31.6(28.6)
| | | | | | ^a^Children who at 20 to 34 months of age used fewer than 50 words were assigned to the LT group. About one-third of the LT subjects showed some delay in receptive language abilities, but they generally scored within 6 months of age level on the Reynell Receptive Language Scales.
4657 Roberts 1986 | Prospective Cohort Study | [underlined: Time]: 9/1972-12/1984 (follow-up from birth to third year of school) | | | [underlined: Age]: OM history: 2 months-3 years; Outcome: at 3.5–8 years of age | Age 3.5–4 years
4656 Roberts 1989 | [underlined: Study Quality Score (0–8)]: 6 (10101111) | [underlined: Place]: Frank Porter Graham Child Development Center, U of North Carolina at Chapel Hill, NC | | | [underlined: Examiner(s)]: Pediatricians and pediatric nurse practitioners for clinical history | [underlined: Mean (SD)]
Same study subjects as in 4806/ 3118, 3117, and 4319. | [underlined: OM Diagnosis]: By pediatricians and pediatric nurse practitioners based on pneumatic otoscopy. 60% time tympanometry was used to corroborate the OME diagnosis. | [underlined: Characteristics of 61 subjects]; - African American; - 57% boys; - Average of 10.5 years of education of mother; - Mother's mean IQ score was 84.; - Hearing was within normal limits at time of testing | | | Psychologists for measurements of child development. | McCarthy | Group 1 (n=20) | Group 2 (n=20) | Group 3 (n=21)
See 4806/ 3118, 3117, and 4319 for further comments. | [underlined: OM Groups]: Based on total OME duration in days during first 3 years of life. | [underlined: Inclusion:]; - Age: 3.5–6 years of age at followup; - participant in longitudinal on-site research day-care program; - attended the Frank Porter Graham Child Development Center, 5 full days/wk, 50 wks/yr through 5 yrs of age; - identified at birth as biologically normal; - Classified as at risk for poor school performance | | | [underlined: OM History]: Duration of each episode of unilateral and bilateral was calculated by subtracting the date of onset of OME from the resolution date. Days of total | Cognitive | 103 (12) | 104 (10) | 100 (8)
| Group 1: Days with total OME between 0–87 days. | [underlined: Exclusion:]; - incomplete data | | | [underlined: Outcome measures:] | Verbal | 52 ( 7) | 54 ( 7) | 52 ( 5)
| Group 2: Days with total OME between 88–181 days. | | | | Cognitive capacity:; - Stanford-Binet Intelligence Scale; - McCarthy Scale of Children's Abilities (McCarthy); - Wechsler Preschool and Primary Scale of Intelligence (WPPSI); - Wechsler Intelligence Scale for Children-Revised (WISC-R) verbal scale; - Classroom Behavior Inventory (CBI) verbal intelligence | Stanford-Binet Intelligence | (n=20) | (n=20) | (n=19)
| Group 3: Days with total OME over 181 days. | | | | Academic achievement:; - Peabody Individualized Achievement Test (PIAT); - Woodcock-Johnson Psychoeducational Battery (WJPB) | | 101 (11) | 98 ( 8) | 99 (11)
| N=61 subjects up to 6 years | | | | | Age 4.5 years
| N1=20 | | | | | [underlined: Mean (SD)]
| N2=20 | | | | | McCarthy | Group 1 (n=19) | Group 2 (n=20) | Group 3 (n=19)
| N3=21 | | | | | Cognitive | 100 (13) | 103 ( 9) | 97 (10)
| N=44 subjects up to 8 years | | | | | Verbal | 53 ( 9) | 55 ( 6) | 52 ( 8)
| N1=15 | | | | | Age 5 years
| N2=14 | | | | | WPPSI Intelligence | (n=19) | (n=20) | (n=20)
| N3=15 | | | | | Full-scale | 102 (12) | 101 (10) | 98 (11)
| | | | | | Verbal | 104 (11) | 101 ( 9) | 97 (12)
| | | | | | Performance | 100 (13) | 101 (11) | 100 (11)
| | | | | | Age 8 years
| | | | | | [underlined: Groups by OME days]
| | | | | | | <82d (n=15) | 83–157d (n=14) | >157d (n=15)
| | | | | | Intelligence - Verbal IQ
| | | | | | WISC-R | 98 (13) | 96 (14) | 94 (10)
| | | | | | CBI | 14 ( 5) | 12 ( 3) | 12 ( 3)
4806 Roberts 1988 | Prospective Cohort Study | [underlined: Time]: 1975-1986 study period (8 yr follow-up reported); speech and language measured between 1982-1986 | | | [underlined: Age]: OM history: 2 months-3 years; Outcome: at 2.5–8 years of age | Spearman coefficient of correlation (R) between number of phonologic processes and total OME days
3118 Roberts 1988 | [underlined: Study Quality Score (0–8)]: 4 (10100101) | [underlined: Place]: Frank Porter Graham Child Development Center, Un. of North Carolina at Chapel Hill, NC | | | [underlined: Examiner(s)]: Pediatricians and pediatric nurse practitioners for clinical history. | Age(yr) | N | R | P-Value
Same study subjects as in 4657/ 4656, 3117, and 4319. | [underlined: OM Diagnosis]: By pediatricians and pediatric nurse practitioners based on pneumatic otoscopy. 60% time tympanometry was used to corroborate the OME diagnosis. | [underlined: Characteristics:]; - 93% black, 7% white; - 67% boys; - All passed hearing screen and had type A or C tympanogram. | | | Psychologists for measurements of child development. | 3 | 27 | -0.04 | 0.85
See 4657/ 4656, 3117, and 4319 for further comments | [underlined: OM Groups] Based on total OME duration in days during first 3 years of life. Duration of each episode of unilateral and bilateral was calculated by subtracting the date of onset of OME from the resolution date. | [underlined: Inclusion:]; - Age: 8 years (followed from <3 months); - Attended Frank Porter Graham Child Development Center for 5 days/wk, 50 wks/yr until entry into kindergarten; - Socioeconomically disadvantaged; - identified at birth as biologically normal; - Classified as at risk for poor school performance; - Tested for speech and language between 1982-1986 | | | Master's level speech-language pathologists and graduate research assistants collected speech data. | 4 | 25 | 0.29 | 0.16
| Group 1: lower third-OME days (8–143 days) | [underlined: Exclusion]: None | | | [underlined: OM History]: Days of total OME was analyzed both as a continuous and categorical variable. | 5 | 24 | 0.31 | 0.15
| Group 2: middle third-OME days (144–269 days) | | | | [underlined: Outcome measures:] | 6 | 30 | 0.29 | 0.13
| Group 3: upper third-OME days (314–931 days) | | | | Speech; - Goldman-Fristoe Test of Articulation to which 6 additional words were added. | 7 | 29 | 0.18 | 0.34
| N=55 children tested for speech at different ages. | | | | Transcription and Phonology; - CER - total number of consonants in error; - TPP - total number of phonological processes | 8 | 19 | 0.10 | 0.69
| 12 tested once; 7 tested 2 times; 19 tested 3 times; 6 tested 4 times and 11 tested 5 times. | | | | Language - 15-minute elicited conversational speech sample of language play situation.; - Number of words per communication unit (cu); - Dependent clauses per cu; - Ratio of total different words to total cu; - Ratio of total different conjunction words (excluding ‘and’ to total cu; - Number of utterances per turn. | Spearman coefficient of correlation (R) between language measures and total OME days at age 5 (n=34)
| N=34 in the language study | | | | | Measure | | R | P-Value
| | | | | | Words/cu | | -0.04 | 0.83
| | | | | | Dependent Clauses/cu | | 0.17 | 0.33
| | | | | | Different Words/cu | | -0.03 | 0.89
| | | | | | Different Conjunctions/cu | | 0.20 | 0.26
| | | | | | Different Pronouns/cu | | 0.09 | 0.62
| | | | | | Regression analysis revealed that (a) children with more OME tended to have a greater total number of phonological processes and (b) Unilateral OME(0–3) provided independent prediction of median TPP given Bilateral OME(0–3), but that Bilateral OME(0–3) was a nonsignificant predictor given Unilateral OME(0–3).
3117 Roberts 1991 | Prospective Cohort Study | [underlined: Time]: Cohort of 8–12 children entered every 1–2 years between 1978 and 1985 | | | [underlined: Age]: OM history: 2 months-3 years; Outcome: at 4.5–6 years of age | Spearman's correlation coefficient (R) between language outcomes and total OME days during first 3 years of life
Same study subjects as in 4657/ 4656, 4806/3118and 4319. | [underlined: Study Quality Score (0–8)]: 2 (00000101) | [underlined: Place]: Attended the Frank Proter Graham Child Development Center (FPG), a research day-care center, University of North Carolina at Chapel Hill | | | [underlined: Examiner(s)]: Pediatricians and pediatric nurse practitioners for clinical history. | | LSES | | MSES
See 4657/ 4656, 4806/ 3118, and 4319 for further comments. | [underlined: OM Diagnosis]: By pediatricians and pediatric nurse practitioners based on pneumatic otoscopy. 60% time tympanometry was used to corroborate the OME diagnosis. | [underlined: Characteristics:] | | | Psychologists for measurements of child development. | Measure | N | R | N | R
| [underlined: OM Groups]: Based on total OME duration in days during first 3 years of life. Duration of each episode of unilateral and bilateral was calculated by subtracting the date of onset of OME from the resolution date. | | LSES | MSES | Master's level speech-language pathologists and research assistants for speech data. | Standardized Tests
| N=63 subjects Subjects were stratified into two groups SES status: | male | 64% | 50% | [underlined: OM History]: Days of total OME was analyzed both as a continuous and categorical variable. | Bankson | 25 | 0.13 | 22 | 0.02
| Group 1: LSES (Children from families of lower socioeconomic status) | black | 88% | 33% | [underlined: Outcome measures]: Language tests | M-Y | 25 | 0.08 | 22 | 0.08
| Group 2: MSES (Children from families of middle socioeconomic status) | single mom | 82% | 3% | [underlined: Age 4–5 years]; - Miller-Yoder Language Comprehension Test (M-Y); - Bankson Language Screening Test (Bankson); - Clinical Evaluation of Language Functions (CELF); - Peabody Picture Vocabulary Test-Revised (PPVT-R) | PPVT-R | 24 | -0.08 | 20 | 0.03
| N1=33 N2=30 | - all passed hearing screen, had type A or C tympanogram, and did not have OME | | | [underlined: At Age 5], 15-minute elicited sample of language play situation; - Words/communication unit (cu); - Dependent clauses per cu; - Ratio: total different words to total cu; - Ratio: total different conjunction words (excluding ‘and’) to total cu; - Ratio: different pronouns to total cu; - Number of utterances per turn. | CELF receptive | 25 | 0.25 | 21 | 0.24
| | [underlined: Inclusion:]; - Age: 6 years (follow-up from birth); - attended the Frank Porter Graham Child Development Center; - identified at birth as biologically normal; - Classified as at risk for poor school performance | | | | CELF expressive | 24 | 0.23 | 21 | 0.17
| | | | | | Language Sample
| | | | | | Words/cu | 28 | 0.05 | 26 | -0.22
| | | | | | Dependent
| | | | | | Clauses/cu | 28 | 0.04 | 26 | -0.02
| | | | | | Different
| | | | | | Words/cu | 28 | 0.26 | 26 | 0.00
| | | | | | Different
| | | | | | Conjunctions/cu | 28 | 0.02 | 26 | 0.13
| | | | | | Different
| | | | | | Pronouns/cu | 28 | 0.24 | 26 | -0.12
4319 Roberts 1995 | Prospective Cohort Study | [underlined: Time]: Cohort assembled 9/1972-12/1984, follow-up from birth to 12 years of age) | | | [underlined: Age]: OM history: 2 months-3 years; Outcome: at 12 years of age | Correlation coefficient, R, between language outcomes and total OME days during first 3 years of life
This is a continuation of study by Roberts. 4657 4656 | [underlined: Study Quality Score (0–8)]: 3 (00000111) | [underlined: Place]: Frank Porter Graham Child Development Center, U of North Carolina at Chapel Hill, NC | | | [underlined: Examiner(s)]: Pediatricians and pediatric nurse practitioners for clinical history Psychologists for measurements of child development. [underlined: OM History]: Duration of each episode of unilateral and bilateral was calculated by subtracting the date of onset of OME from the resolution date. [underlined: Summary measures:]; - No. OME - total number of OME episodes; - ML/OME - mean length in number of days of the OME episodes; - Duration OME - number of days with either bilateral or unilateral OME. | [underlined: At Age 12]
Same study subjects as in 4657/ 4656, 4806/ 3118 and 3117 | [underlined: OM Diagnosis]: By pediatricians and pediatric nurse practitioners based on pneumatic otoscopy. 60% time tympanometry was used to corroborate the OME diagnosis. [underlined: OM Groups]: Based on total OME duration in days during first 3 years of life. | [underlined: Characteristics of 61 subjects:]; - African American; - 57% boys; - Average of 10.5 years of education of mother; - Mother's mean IQ score was 84.; - Hearing was within normal limits at time of testing | | | [underlined: Outcome measures:]Cognitive capacity:; - Wechsler Intelligence Scale for Children-Revised (WISC-R); - Full-scale IQ verbal IQ; - performance IQ Freedom from Distractibility Factor | Measure | | N | R1 | R2
See 4657/ 4656, 4806/ 3118, and 3117 for further comments. | Group: African American children enrolled as infants in research child-care program (follow-up to 12 years of age) | [underlined: Inclusion:]; - Age: 12 years of age at followup; - participant in longitudinal on-site research day-care program; - attended the Frank Porter Graham Child Development Center, 5 full days/wk, 50 wks/yr through 5 yrs of age; - identified at birth as biologically normal; - Classified as at risk for poor school performance; [underlined: Exclusion:]; - incomplete data | | | Academic performance:; - Woodcock-Johnson Psychoeducational Battery | Intelligence-WISC-R
| | | | | Behavior; - Child Behavior Checklist | Intelligence-WISC-R | | 56 | -0.17 | -0.12
| | | | | | Full scale IQ | | 56 | -0.10 | -0.08
| | | | | | Verbal IQ | | 56 | -0.10 | -0.08
| | | | | | Performance IQ | | 56 | -0.18 | -0.13
| | | | | | Where R1 is the simple correlation coefficient and R2 is the standardized regression coefficient adjusted for gender and home environment.
| | | | | | The multivariate tests of the relationships between the ranks of No. OME(0–3) and ML/OME(0–3) during early childhood and the Full-Scale, Verbal, and Performance IQ were not significant either when the HOME or gender were considered or ignored.
2295Ruben 1997 | Prospective Cohort Study | [underlined: Time]: not specified | | | [underlined: Age]: | Percent OM+ children performed more poorly than the OM− in the following measure:
Same study cohort as 1373, 1941, and 4728 by Gravel | [underlined: Study Quality Score (0–8)]:5 (11001110) | [underlined: Place]: Clinical Research Center for Communicative Disorders (which draws subjects from the LIFE Program of the R.F. Kennedy Center, Albert Einstein College of Med. Bronx, NY | | | OM history: 0–1 of lifeOutcome: 2–9 years of age | [underlined: Measure] | | | | [underlined: %]
See 1373, 1941, and 4728 for further comments. | [underlined: OM Diagnosis] | [underlined: Characteristics]: | | | [underlined: Examiner(s)]: | Expressive language at 1 yr | | | | 0%
| Pediatric nurse practitioners completed pneumo-otoscopic examinations. | - low socioeconomic urban neighborhoods based on Hollingshead's (1975) index | | | Not specified | Expressive language at 2 yr | | | | 8%
| [underlined: OM Groups]: | | | | [underlined: OM history]: | Expressive language at 4 yr | | | | 25%
| Group 1: Otitis positive children - when bilateral OM was detected at 30% or more of the baby's first year visits. | [underlined: Inclusion]: | | | OM groups were defined by otoscopic histories. | Receptive language competition at 4 yr | | | | 38%
| Group 2: Otitis negative children - when middle ear status was rated as normal in both ears during 80% or more of the first year visits. | - Age: 9 years; - born in the same urban hospital; - auditory testing conducted during first year of life and at 9 years of age | | | [underlined: Outcome measures]: | Speech in competition ratio as measured adaptively at 4 yr | | | | 30%
| N=30 subjects | [underlined: Exclusion]: None | | | 18 measures of communicative function was measured. Data were summarized by calculating the mean score for OM− group and then comparing the score of each child in the OM+ group with that of the mean for the OM− group. Each OM+ score that was >= the mean of the OM− group was counted and the percent of children in the OM+ group who had higher scores than the OM− was calculated for each measure. Differences between the groups were considered meaningful when less than 40% of the OM+ children in the group exceeded the score of the OM− group. | Comprehension of grammatical structures at 6 yr | | | | 11%
| N1=18 | | | | | School readiness at 6 yr | | | | 0%
| N2=12 | | | | | Recall of a narrative at 9 yr | | | | 14%
2583 Teele 1990 | Prospective Cohort Study | [underlined: Time]: Enrollment of infants began 6/1975 (follow-up during first 7 yrs of life) | | | [underlined: Age]: OM history: 0–2 years Outcome: at 7 years of age | Cognitive ability (mean IQ by WISC-R) at 7 years of age after adjusting for SES status and gender.
Same cohort as 2579 | [underlined: Study Quality Score (0–8)]: 6 (10101111) | [underlined: Place]: Subjects drawn from larger cohort of children enrolled at an urban health center in East Boston and a private practice in the Holliston/Framingham area of MA | | | [underlined: Examiner(s)]:; - Physicians and nurse practitioners for clinical history.; Experienced psychometricians for intelligence and achievement tests; Certified speech clinicians administered speech and language tests. | | | Time with MEE
| [underlined: OM Diagnosis]: By physicians and nurse practitioners using a standard sealed pneumatic otoscope. | [underlined: Characteristics]:; - 54% male; - 57% high SES; - 69% from private practice | | | [underlined: OM history]: Used the number of days with MEE by age 3 years as a predictor variable. Unless documented to be shorter, each episode of MEE lasted 29 days. | | | lt;30d | 30–129d | >130d
| To resolve ambiguous diagnoses, otoadmittance was used sporadically at 0–3 years of age, but frequently at 4–7 years. | [underlined: Inclusion]:; - Age: 7 years (followed from birth); - Caucasian | | | [underlined: Outcome measures]:Cognitive assessment; - WISC-R | | | (n=58) | (n=77) | (n=59)
| Group: Children followed prospectively from birth until age 7 years and whose cognitive and linguistic abilities were assessed at age 7 | [underlined: Exclusion]:; - seizures; - mental retardation; - cerebral palsy; - two languages spoken in home; - non-white | | | Speech and language; - Subsample of Goldman-Fristoe and Goldman-Fristoe-Woodcock Tests; - WUG test; - Peabody Picture Vocabulary Test; - Boston Naming Test; - Complex sentences and set of pictures for story telling | Full Scale | | 113 | 108 | 105
| N=194 subjects | | | | Academic achievement; - Metropolitan Achievement Test | Verbal | | 112 | 106 | 106
| | | | | | | Performance | | 112 | 108 | 104
| | | | | | | Linguistic abilities (mean score) after adjusting for SES status and gender
| | | | | | | | | Time with MEE
| | | | | | | | | <30d | 30–129d | >130d
| | | | | | | | | (n=58) | (n=77) | (n=59)
| | | | | | | Goldman-Fristoe-Woodcock
| | | | | | | Articulation | | 106 | 66 | 56
| | | | | | | Discrimination | | 34 | 30 | 28
| | | | | | | WUG
| | | | | | | Receptive | | 1.5 | 1.8 | 2.2
| | | | | | | Expressive | | 2.4 | 2.0 | 1.9
| | | | | | | Morphologic markers
| | | | | | | | | 31 | 26 | 20
| | | | | | | Lexical use | | 1.5 | 1.5 | 1.5
| | | | | | | Speech sample score
| | | | | | | | | 83 | 80 | 78

[The eight components of study quality score are: study cohort clearly defined; subjects assembled at a uniform time point; pathway of subject entry clearly described; complete follow-up achieved; withdrawals/drop-outs described; objective outcomes used; outcome assessment blinded; and extraneous factors adjusted. 1 indicates presence and 0 indicates absence.]

Evidence Table 3. Early Life OM and Long-Term Hearing

Record# Author Year | Study Quality OME Definition Group(s) and Sample Size | Time/Place Subject Characteristics Inclusion/Exclusion Criteria | Risk Groups Predictors Outcome Measures | Findings
147 Sorri 1995 | Prospective Cohort Study | [underlined: Time]: Birth cohort 1985-1986 | [underlined: Age]: | Number and percent children exceeding 20 dB (hearing loss)
| | | OM history: 0–2 years of life
| [underlined: Study Quality Score (0–8)]: | [underlined: Place]: Health care centers, hospital and private surgeries in Northern Finland | Outcomes: At age 7 years
| 4 (01001101) | | | NoOM | | RAOM | SOM
| | | [underlined: Examiner(s)]: Not specified | 7/35 | | 28/51 | 5/13
| [underlined: OM Diagnosis]: | | | 20% | | 55% | 38%
| By whom not specified; How not specified; | [underlined: Inclusion]: | [underlined: OM history]:
| | - Age: Born in Northern Finland between 1985-1986 (examined through age 2 and at 7 years); - history of OM meticulously controlled up until the age of 2 yrs | OM history groups defined by number of recurrent otitis media or serous otitis media. | Pure tone (dB), right ear: mean ASD
| [underlined: OM Groups]:
| Group 1: No otitis media until 7 years of age (NoOM) | | [underlined: Outcomes]: | NoOM | | RAOM | SOM
| | | - Pure tone average, type not specified; - Mean air-conduction (AC) thresholds | 3.82±3.50 | | 4.88±4.42 | 6.44±6.27
| Group 2: Recurrent otitis media (>=4 episodes of OM until the age of two) (RAOM) | | | Pure tone (dB), left ear: mean ASD
| | | | NoOM | | RAOM | SOM
| | [underlined: Exclusion]: | | 3.24±2.21 | | 3.63±2.65 | 6.54±6.56
| Group 3: Secretory otitis media until the age of two (SOM) | - middle ear effusion at time of audiometry at age 7 (14 excluded); - 6 children had meningitis, 1 totally deaf child, 1 w/atresia of the ear canal, 5 lacked cooperation, 5 lacked information after age 2 years
| N=99
| N1=35
| N2=51
| N3=13
1255 Fischler 1985 | Retrospective-prospective study | [underlined: Time]: Start date~7/1974 | [underlined: Age]: | Number and percent of children with hearing loss
| | | OM history: 0–2 years of life
| [underlined: Study Quality Score (0–8)]: | [underlined: Place]: Four Indian reservations in Arizona | Outcomes: At 6–8 years
| 5 (11001110) | | | | Group 1 | Group 2 | Group 3
| | | [underlined: Examiner(s)]:
| [underlined: OM diagnosis]: | [underlined: Characteristics]: | - Unspecified physicians for diagnosis of otitis media;; - School nurse for hearing tests;; - Pediatrician/otolaryngologist for otoscopic examinations;; - Certified speech pathologists for language testing. | OM risk | High | Moderate | Low
| By medical record review of documented physician's clinical diagnosis. | - 50% had family income under $5000 per year; - 37% had housing below average; - 13% primarily Apache speaking at home | | | 5/33 | 4/63 | 1/71
| | | | | 15% | 2% | 1%
| [underlined: OM Groups]:
| Group 1: HR/REC (HR-High risk status,REC-recurrences of OM attacks after age 2) ~ >=2 attacks by age 2 yr and >=3 attacks after age 2 yr
| | [underlined: Inclusion]:
| | - Age: 6–8 years; - healthy Apache Indian children who had been followed since birth | [underlined: OM history]:
| | | Groups defined by number of OM episodes by age 2
| Group 2: HR/NREC ~ >=2 attacks by age 2 yr and <3 attacks after age 2 yr
| | | [underlined: Outcomes]:
| | | All children received a hearing screen using a recently calibrated pure tone audiometer (dB hearing level American National Standards Institute [ANSI] 1969). Children whose hearing was better than the following thresholds were considered normal:
| Group 3: NHR/NREC ~ <2 attacks by age 2 yr and <3 attacks after age 2 yr | [underlined: Exclusion]:
| | - moved during study period; - absent or not tested because of time constraints; - medical reasons (specific conditions not specified)
| | | 25 dB at 500 Hz;
| N=167 | | 20 dB at 1,000 Hz;
| N1=33 | | 20 dB at 2,000 Hz;
| N2=63 | | 25 dB at 4,000 Hz;
| N3=71 | | 25 dB at 6,000 Hz;
| | | Otherwise, abnormal or hearing loss.
1373 Gravel 1992 | Prospective Cohort Study | [underlined: Time]: not specified | [underlined: Age]: | PSI S/CM(dB)
| | | OM history: 0–1 of life
| [underlined: Study Quality Score (0–8)]: | [underlined: Place]: Clinical Research Center for Communicative Disorders (which draws subjects from the LIFE Program of the R.F. Kennedy Center, Albert Einstein College of Med. Bronx, NY | Outcome: at 4 years of age | | | OM+ | OM-
| 5 (11001101) | | | Mean±SD | | -6.8±2.8 | -9.7±2.6
| | | [underlined: Examiner(s)]: Not specified
| [underlined: OM Diagnosis]: | | | Pure-tone (dB), right ear
| Pediatric nurse practitioners completed pneumo-otoscopic examinations. | | [underlined: OM history]:
| | | OM groups were defined by otoscopic histories. | | | OM+ | OM
| | [underlined: Characteristics]: | [underlined: Outcomes]: | Mean±SD | | 15.8±4.1 | 14.9±3.2
| [underlined: OM Groups]: | - low socioeconomic urban neighborhoods based on Hollingshead's (1975) index; - none had sensorineural hearing loss | Pediatric Speech Intelligibility (PSI) sentence (S) items/competing messages (CM) ratio
| Group 1: Otitis positive children – when bilateral OM was detected at 30% or more of the baby's first year visits. (Also, had poorer auditory sensitivity by click ABR.) | | | Pure-tone (dB), left ear
| | | Pure-tone averages – based on a conventional clinical staircase procedure (descending-ascending). | | | OM+ | OM
| | | | Mean±SD | | 8±4.1 | 14.6±3.3
| | | Thresholds for each ear of all subjects were obtained at octave frequencies from 500 through 4000 Hz (at a minimum) (ANSI, 1969)
| Group 2: Otitis negative children – when middle ear status was rated as normal in both ears during 80% or more of the first year visits | [underlined: Inclusion]:
| | - Age: 4 years (measures taken during first year of life as well); - all children were enrolled at 40 wks postconceptional age for follow-up through the LIFE Program either high-risk infant graduates of a NICU or FT graduates of the well-baby nursery of Jacobi Hospital; - English reported as the primary language spoken
| N=23
| N1=10
| N2=13
| | [underlined: Exclusion]:
| | - neurologically compromised
1435 Harsten 1993 | Prospective Cohort Study | [underlined: Time]: not specified | [underlined: Age]: | Tone-audiometry at age 4
| | | OM histroy: 0– year of life
| [underlined: Study Quality Score (0–8)]: | [underlined: Place]: University Hospital of Lund, Sweden | Outcomes: at 4 and 7 year of age | | | RAOM | Healthy
| 6 (11101110) | | | Abnormal | | 3/26 | 4/58
| | | [underlined: Examiner(s)]: | hearing | | 12% | 7%
| [underlined: OM Diagnosis]: | [underlined: Characteristics]: | Otolaryngologist for otomicroscopy, tympanometry, tone-audiograms
| AOM was diagnosed by otomicropscopy, performed by an otolaryngologist and defined as an acute episode of earache in a child, with red bulging eardrum(s) or purulent discharge, occasionally febrile and with signs of upper respiratory tract infection. | - 45% first-borns; - 71% mother educated at college level | | Tone-audiometry at age 7
| | | Phoniatrician and clinical linguist for hearing and speech | | | RAOM | Healthy
| | | | Abnormal | | 2/24 | 3/56
| | | | Hearing | | 8% | 5%
| | [underlined: Inclusion]: | [underlined: OM history]:
| | - Age: Birth cohort; - monolingual, Swedish children, born at University Hospital of Lund | Groups defined by number of episodes of AOM during a 12-month period.
| | | [underlined: Outcomes]:
| [underlined: OM Groups]: | | Tone-audiometry: abnormal defined as >=25 dB threshold at any frequency.
| Group 1: Children with recurrent AOM (RAOM defined as at least six episodes of AOM during a 12-month period) during the first 3 years of life
| | [underlined: Exclusion]: None
| | | (Tone-audiograms were recorded at frequencies from 125 to 8000 Hz.)
| Group 2: Children without any AOM episode during the first 3 years of life
| N= 42
| N1=13
| N2=29
1623 Kaplan 1973 | Prospective Cohort Study | [underlined: Time]: Birth cohort (10/1960-12/1962); follow-up conducted between 9/1969-7/1971 | [underlined: Age]: | Hearing Loss at 10 years of age
| | | OM history: 0–1 year of life
| [underlined: Study Quality Score (0–8):] | | Outcome: at 10 years of age | | Group 1 | Group 2 | Group 3
| 5 (11001110) | | | 1^st^ om at | 0–1y | 2–12y | noOM
Same study subjects as 2233 which reported 3–5 year follow-up. This study reported 10-year follow-up. | | [underlined: Place]: 28 Eskimo villages located in the Yukon and Kuskokwim River Delta areas of Southwestern Alaska | [underlined: Examiner(s)]: | Conductive hearing loss (air-bone gap)
| [underlined: OM Diagnosis]: | | Experienced audiologist for air and bone conduction measurements | | 42/162 | 8/45 | 17/76
| A research nurse visited the cohort children 4 times a year during first 2 years and at least 2 times a year for the next 2 years. During each visit, information concerning middle ear abnormality was obtained and medical records of the time between visits were reviewed. Only OM described with otorrhea was used for analysis. | | | | 28% | 18% | 22%
| | | Two psychologists administered speech and intelligence testing | Hearing loss at 26+dB
| | [underlined: Characteristics]: | | | 32/162 | 5/45 | 6/76
| | Not describe. | | | 20% | 11% | 8%
| | | [underlined: OM history]:
| | [underlined: Inclusion]: | Groups based on onset of first episode of otorrhea during 0–1 year; during 2–10 years or no history.
| | - Age: Birth Cohort born between 10/1960-12/1962 and followed up between 9/1969-7/1971; - born in 25 villages w/in Alaska specified under place and/or residing in 3 additional villages at follow-up
| | | [underlined: Outcomes]:
| | | Air and bone conduction measurements were made using a portable audiometer recently calibrated to the ISO 1964 standard. All children were tested at frequencies of 250, 500, 1000, 2000, 4000, and 8000 Hz to evaluate air conduction and at frequencies of 500, 1000, 2000, and 4000 Hz to evaluate bone conduction.
| [underlined: OM Groups]:
| Group 1: age of onset of first otorrhea at 0–1 year of age
| Group 2: age of onset of first otorrhea at age 2–10 years
| | [underlined: Exclusion]: | - Normal hearing: 0 to -25 dB;; - Normal hearing with a conductive component: 0 to -25 dB with a 15 dB air-bone gap;; - Hearing loss: -26 dB or greater.
| Group 3: no history of otorrhea | - Children with pure sensory hearing loss were excluded from analysis
| N=489
| N1=291
| N2=83
| N3=115 | | (Children with pure sensory hearing loss were excluded from analysis.)
2233 Reed 1967 | Prospective Cohort Study | [underlined: Time]: Two birth cohorts (born between 10/1960-12/1962); follow-up conducted between Sept.-Dec.,1965 | [underlined: Age]: | Mild and Severe Hearing Loss at 3–5 years of age
| | | OM history: first 2 years of life
| [underlined: Study Quality Score (0–8):] | | Outcome: at 3–5 years of age
| 4 (11000101) | | | OM history, first 2 years of life
Same study population as 1623. This article reported findings at 3–5 years. Article 1623 reported findings at 10 years of age. | | | [underlined: Examiners]:
| [underlined: OM Diagnosis]: | [underlined: Place]: Testing conducted in schoolhouses or in a community building in 24 of the original 27 Eskimo villages located in the Yukon and Kuskokwim River Delta areas of SW Alaska where the cohort was born | Audiologist | none | | <1/yr | 1+/yr
| A research nurse visited the cohort children 4 times a year during first 2 years and at least 2 times a year for the next 2 years. During each visit, information concerning middle ear abnormality was obtained and medical records of the time between visits were reviewed. Only OM described with otorrhea was used for analysis | | | 21/143 | | 48/139 | 47/96
| | | [underlined: OM history]: | 15% | | 35% | 49%
| | | Groups defined by frequency of otorrhea episodes during first 2 years of life: none, <1 per year of risk, and 1+ per year of risk
| | | [underlined: Outcomes]:
| | [underlined: Characteristics]: | Air and bone conduction measurements were made using the Zenith ZA-100-T Diagnostic Portable Audiometer, calibrated to the ISO 1964 standards.
| | Not described.
| | [underlined: Inclusion]:
| | - Age: Follow-up from birth to 4 years (0–47 months); - Born in one of 27 Eskimo villages between 10/1960-12/1962 and available for testing at follow-up; - audiometric tests completed | Children were classified according to averages of pure tone air hearing thresholds at 500, 1000, and 2000 CPS:
| [underlined: OM Groups]:
| Defined by frequency of otorrhea episodes during first 2 years of life.
| | | - normal: 0 to 25 dB; - mild impairment: 26 to 40 dB; - moderate to severe impairment: 41 to 70+ dB
| Group 1: None
| Group 2: <1 episode per year
| Group 3: 1 or more episode per year
| N=378 | [underlined: Exclusion]:
| N1=198 | - Children with pure sensory hearing loss was excluded from analysis
| N2=180
2309 Ryding 1997 | Prospective Cohort Study | [underlined: Time]: Birth cohort (born between 11/1982–2/1984); 10 yr follow-up | [underlined: Age]: | Median level in dB, right ear
| | | OM history: 0–3 years of life
| [underlined: Study Quality Score (0–8)]: | | Outcome: at 10 years of age | | | RAOM | Healthy
| 5 (01100111) | | | PTA(0.5–2) | | 5 | 5
| | [underlined: Place]: University Hospital, Lund, Sweden | [underlined: Examiner(s)]: | PTA(0.5–4) | | -2 | -2
| [underlined: OM Diagnosis]: | | Audiologist
| AOM was diagnosed by otomicroscopy, performed by an otolaryngologist and defined as an acute episode of earache in a child, with red bulging eardrum(s) or purulent discharge, occasionally febrile and with signs of upper respiratory tract infection. | | | Median level in dB, left ear
| | [underlined: Characteristics]: | [underlined: Instrument]:
| | - 45% first-borns; - 71% mother educated at college level | tone audiometry GSI 16 audiometers | | | RAOM | Healthy
| | | [underlined: OM history]: | PTA(0.5–2) | | 7 | 3
| | | Groups defined by number of recurrent AOM. Recurrent AOM was defined as >= 6 episodes of purulent AOM during a 12-month period. | PTA(0.5–4) | | -2 | 0
| | [underlined: Inclusion:]
| | - 10 years old; - member of this birth cohort
| | | [underlined: Outcomes]:
| [underlined: OM Groups]: | | Children were tested using GSI 16 audiometers with TDH39 earphones calibrated according to ISO 389. Air conduction hearing levels for both ears were individually determined at the frequencies 1000, 1500, 2000, 3000, 4000, 6000, 8000, 500, 250 and 125 Hz, tested in that order. The test was conducted according to the ascending method. Pure tone average (PTA) values for frequencies 500, 1000 and 2000 Hz (PTA: 0.5-2) and 500, 1000, 2000 and 4000 Hz (PTA: 0.5-4) were calculated for each ear.
| Group 1: RAOM Children (>=6 episodes of purulent AOM during a 12-month period)
| | [underlined: Exclusion]:
| | - moved out of Lund
| Group 2: Healthy Children (no AOM and <6 other RTI episodes during the study period)
| N=33
| N1=12
| N2=21
2854 Zargi 1992 | Retrospective prospective cohort study | [underlined: Time]: not specified | [underlined: Age]: Followup examination at 8–10 years of age | Hearing loss | | Group 1 | Group 2
| | [underlined: Place]: University Department of Otorhinolaryngology and Head and Neck Surgery, Ljubljana, Slovenia | [underlined: Examiner(s)]: | | | OM+ | OM-
| [underlined: Study Quality Score (0–6)]: | | Otolaryngologist
| 2 (10000100) | | | Sensorineural | | 10/33 | 4/29
| | | [underlined: OM history]: | | | 30% | 14%
| [underlined: OME definition]: | | During first two years of life. | Conductive or mixed | | 8/33 | 0/29
| Not specified | [underlined: Inclusion]: | | | | 24% | 0%
| | - Age: 8–10 years; - attended similar pre-school, kindergarten, and elementary school programs; - no evidence of mental retardation nor behavioral or emotional disorders | [underlined: Outcomes]:
| Group 1: Experimental - Children treated for recurrent acute unilateral or bilateral suppurative otitis media at 0–2 years of age. | | At age 8–10 years pure-tone audiometry was performed. The criterion for normal hearing was based on the air-conduction threshold results, which had to be at or above the level of 10 dB. Isolated audiometric dips (notches) to 15 dB at not more than one high frequency (6kHz or 8kHz) were not considered to be sensorineural hearing loss. | Both types | | 18/33 | 4/29
| | | | | | 55% | 14%
| Group 2: Control - Children who experienced <=1 episodes of OM in the first 2 years of life)
| | [underlined: Exclusion]: None
| N=62
| N1=33
| N2=29

“The six components of Study Quality Score are: appropriate reference standard; test and reference standard assessed independently of each other; blinded reading of results; patient sample included an appropriate spectrum as in clinical practice; reproducibility and interpretation of test results determined; and description of test method sufficient to permit replication. 1 indicates presence and 0 indicates absence.”

Evidence Table 4. Diagnostic Methods

Record# Author Year | Study Quality Examiner(s) Group(s) and Sample Size | Time/Place/Affiliation Inclusion/Exclusion Criteria Patient Characteristics | [underlined: Comparison(s)] Influencing Factors Diagnostic Methods (Dx), Cutpoints Gold Standards (GS), Cutpoints | Findings
759Avery 1986 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Observation
| [underlined: Study Quality Score (0–6):] 2 (100001) | [underlined: Place]: Not specified | [underlined: Comparisons:]; 1. Acoustic reflectometry; Dx- : ≤ 3 dB; Dx+ : > 3 dB; Validated pneumatic otoscopy; GS- : fluid absent; GS+ : fluid present; 2. Acoustic reflectometry; Dx- : ≤ 4 dB; Dx+ : > 4 dB; Validated pneumatic otoscopy; GS- : fluid absent; GS+ : fluid present; 3. Acoustic reflectometry; Dx- : ≤ 5 dB; Dx+ : > 5 dB; Validated pneumatic otoscopy; GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 77.74% (908/1168); specificity 68.28% (2034/2979); PPV 49.00% (908/1853); NPV 88.67% (2034/2294); accuracy 70.94% (2942/4147); prevalence 28.17% (1168/4147); - [underlined: Comparison 2]:; sensitivity 65.24% (762/1168); specificity 83.08% (2475/2979); PPV 60.19% (762/1266); NPV 85.91% (2475/2881); accuracy 78.06% (3237/4147); prevalence 28.17% (1168/4147); - [underlined: Comparison 3]:; sensitivity 50.43% (589/1168); specificity 92.25% (2748/2979); PPV 71.83% (589/820); NPV 82.60% (2748/3327); accuracy 80.47% (3337/4147); prevalence 28.17% (1168/4147)
| [underlined: Examiner(s)]:; - pneumatic otoscopy: two validated otoscopists; - acoustic reflectometry (Acoustic Otoscope “Endeco Medical”): not specified | [underlined: Affiliation]: Otitis Media Study Center, Santa Rosa Med. Center & The Univ. of Texas Health Sciences Center, San Antonio, TX
| [underlined: Study Cohort]: Children with proven chronic OME treated surgically (2-year follow-up) | [underlined: Inclusion]:; - proven chronic OME and treated surgically as part of an ongoing clinical trial; - ears with intact tympanic membranes
| N=451 subject, 4147 observations | [underlined: Exclusion]: None
| | [underlined: Patient Characteristics]:; - age range 4–8 years old
766Babonis 1991 | Diagnostic study | [underlined: Time]: 12/1988–11/1989 | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 5 (111011) | [underlined: Place]: Not specified | [underlined: Comparisons]:; 1. Portable tympanometer; Dx- : 59–151 daPa; Dx+ : >151 dePa; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Portable tympanometer; Dx- : A, Cl, Ch, As, pA; Dx+ : B; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Acoustic reflectometry; Dx- : ≤ 5 RU; Dx+ : > 5 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 85.59% (101/118); specificity 57.84% (59/102); PPV 70.14% (101/144); NPV 77.63% (59/76); accuracy 72.73% (160/220); prevalence 53.64% (118/220); - [underlined: Comparison 2]:; sensitivity 77.97% (92/118); specificity 82.35% (84/102); PPV 83.64% (92/110); NPV 76.36% (84/110); accuracy 80.00% (176/220); prevalence 53.64% (118/220); - [underlined: Comparison 3]:; sensitivity 57.63% (68/118); specificity 88.24% (90/102); PPV 85.00% (68/80); NPV 64.29% (90/140); accuracy 71.82% (158/220); prevalence 53.64% (118/220)
| Not defined | [underlined: Affiliation]: Department of Pediatrics, Madigan Army Medical Center, Tacoma, WA
| [underlined: Examiner(s)]:; - tympanometry (MicroTymp “Welch Allen”) and acoustic reflectometry (model 501 “ENT Medical Devices”): one of the authors, specialty not specified; - myringotomy: unspecified “surgeon” | [underlined: Inclusion:]; - scheduled for elective myringotomy and PE tube placement
| [underlined: Study Cohort]: Ears in children scheduled for elective myringotomy and PE tube placement | [underlined: Exclusion:]; - poor patient cooperation; - mechanical malfunction precluding hard-copy recordings; - patient PE tubes; - ears microtic, patient undergoing myringotomy and PE tube placement in only 1 ear, and chronic TM perforation
| N=120 potential subjects and 240 potential ears; 220 ears studied. | [underlined: Patient Characteristics:]; - mean age 37.8 months, median 30 months, range 6 months to 10 years 9 months; - male 139 ears
784 Barnett 1998 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure: Ear]
| [underlined: Study Quality Score (0–6)]: 4 (111001) | [underlined: Place]: Children's Hospital, Boston, MA | [underlined: Comparisons]:; 1. Professional tympanometry; Dx- : peak compliance > 0.1; Dx+ : peak compliance ≤ 0.1; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Professional tympanometry; Dx- : peak compliance > 0.2; Dx+ : peak compliance ≤ 0.2; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Acoustic reflectometry; Dx- : > 95 degr. (spec.grad. angle); Dx+ : ≤ 95 degrees; Myringotomy (sedated); GS- : Fluid absent; GS+ : Fluid present; 4. Acoustic reflectometry:; Dx- : ≥ 49 degrees (spec. grad.); Dx+ : < 49 degrees; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 54.29% (95/175); specificity 83.87% (104/124); PPV 82.61% (95/115); NPV 56.52% (104/184); accuracy 66.56% (199/299); prevalence 58.53% (175/299); - [underlined: Comparison 2]:; sensitivity 62.86% (110/175); specificity 75.00% (93/124); PPV 78.01% (110/141); NPV 58.86% (93/158); accuracy 67.89% (203/299); prevalence 58.53% (175/299); - [underlined: Comparison 3]:; sensitivity 95.43% (167/175); specificity 31.45% (39/124); PPV 66.27% (167/252); NPV 82.98% (39/47); accuracy 68.90% (206/299); prevalence 58.53% (175/299); - [underlined: Comparison 4]:; sensitivity 38.29% (67/175); specificity 92.74% (115/124); PPV 88.16% (67/76); NPV 51.57% (115/223); accuracy 60.87% (182/299); prevalence 58.53% (175/299)
| [underlined: Examiner(s)]:; - tympanometry (Race Car Model® “American Electromedics”): research assistant; - acoustic reflectometry (EarCheck PRO® “MDI Instruments”): research assistant; - myringotomy: not specified | [underlined: Affiliation]: as above
| *The two models used to measure acoustic reflectometry gave identical results - only reporting the results for EarCheck PRO | [underlined: Inclusion]:; - Age: 6 months-14 yrs; - scheduling surgery for or receiving placement of tymp. tubes that day
| [underlined: Study Cohort]: Children enrolled in study who had a scheduled surgery for or were receiving placement of tympanostomy tubes that day | [underlined: Exclusion]:; - craniofacial abnormality; - tympanostomy tubes in place or having had them placed w/in past 6 months; - fluid draining from ear
| N=193 subjects enrolled | [underlined: Patient Characteristics]:; - mean age 4.07 years, range 0.51–14.6 years; - male 101; - Caucasian 102, Black 25, Asian 3, other 25
| Visit1~N=150 subjects, 274 ears
| Visit2~N=155 subjects, 299 ears
| *150 children were examined at visit 1; surgery was performed on 155 children and 299 ears were examined at visit 2.
810Beery 1975 | Diagnostic study | [underlined: Time]: not specified | [underlined: Comparisons]:; 1. Professional tympanometry^a^; Dx- : See notes section below; Dx+ : See notes section below; Class II (at B220) if ≥ 0.3mmh; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 95.65% (66/69); specificity 90.00% (54/60); PPV 91.67% (66/72); NPV 94.74% (54/57); accuracy 93.02% (120/129); prevalence 53.49% (69/129)
| [underlined: Study Quality Score (0–6)]: 2 (100001) | [underlined: Place]: Not specified
| [underlined: Examiner(s)]:; - tympanometry (Grason-Stadler 1720): not specified; - myringotomy: not specified | [underlined: Affiliation]: Dept. of Otolaryngology, Tufts Univ., MA
| [underlined: Study Cohort]: Children with history of recurrent AOM, or evidence otoscopically of persistent MEE, or both | [underlined: Inclusion]:; - Age: 2–15 years; - candidate for bilateral myringotomy and insertion of tubes on basis of children's history with concurrent or recent middle ear disease
| N=70 subjects, 129 ears | [underlined: Exclusion]: None
| | [underlined: Patient Characteristics]:; - mean age 6.7 years, range 2–15 years; - male 43, female 27
817 Ben-David 1981 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place0]: Not specified | [underlined: Comparisons]:; 1. Professional tympanometry^a^; Dx- : Type A and Type C; Dx+ : Type B; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Audiometry-air and bone conduction thresholds^b^; Dx- : < 15 db air-bone gap; Dx+ : 15–40 db air-bone gap; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 78.00% (195/250); specificity 63.93% (39/61); PPV 89.86% (195/217); NPV 41.49% (39/94); accuracy 75.24% (234/311); prevalence 80.39% (250/311); - [underlined: Comparison 2]:; sensitivity 73.91% (153/207); specificity 68.18% (45/66); PPV 87.93% (153/174); NPV 45.45% (45/99); accuracy 72.53% (198/273); prevalence 75.82% (207/273)
| [underlined: Examiner(s)]:; - audiometry (Maico MA-24 and Beltone 15 CX): not specified; - tympanometry (Amplaid 702 and American 83): not specified; - myringotomy: operating surgeon | [underlined: Affiliation]: Rothschild Univ. Hospital, Haifa, Israel
| *Air-bone gap was used in this study as the tested diagnostic method. | [underlined: Inclusion]:; - Age: 6 months-14 years; - evidence of SOM, which failed to ease after conservative Tx with decongestants, antibiotics, and systemic steroids; - candidate for myringotomy and tympanostomy-tube insertion
| [underlined: Study Cohort]: Children who underwent tympanometric and audiometric evaluations as well as myringotomy | [underlined: Exclusion]: None
| N=157 subjects, 311 ears | [underlined: Patient Characteristics]:; - age range 6 months-14 years
886 Block 1998 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 6 (111111) | [underlined: Place]: Validation study recruited from four sites: Barstown, KY; Pittsburgh, PA; Scottsdale, AZ; Rochester,NY/ Long. Study ~ Weston Pediatrics, Weston, MA | [underlined: Comparisons]:; 1. Professional tympanometry^a^; Dx- : See notes below. Peak-compensated static acoustic admittance 0.22–1.5 mmhos; Dx+ : See notes below. Peak acoustic admittance <0.22 mmhos; Validated pneumatic otoscopy; GS- : MEE absent; GS+ : MEE present; 2. Acoustic reflectometry; Dx- : ≥70 degrees SG-AR; Dx+ : ≤ 69 degrees SG-AR; Validated pneumatic otoscopy; GS- : MEE absent; GS+ : MEE present | - [underlined: Comparison 1]:; sensitivity 33.92% (58/171); specificity 89.12% (598/671); PPV 44.27% (58/131); NPV 84.11% (598/711); accuracy 77.91% (656/842); prevalence 20.31% (171/842); (Note: PPV and NPV numbers inTable 1 of the article are incorrect.); - [underlined: Comparison 2]:; sensitivity 67.43% (118/175); specificity 87.05% (605/695); PPV 56.73% (118/208); NPV 91.39% (605/662); accuracy 83.10% (723/870); prevalence 20.11% (175/870)
| [underlined: Examiner(s)]:; - tympanometry (American Electromedic RaceCar®): not specified; - acoustic reflectometry (EarCheck PRO®): not specified; - validated pneumatic otoscopy: validated experienced pediatric otoscopists | [underlined: Affiliation]: Kentucky Pediatric Research, Inc.; Children's Hospital of Pittsburgh; Scottsdale Pediatric Center; Elmwood Pediatric Group (NY); Weston Pediatric Physicians; MDI Instruments, Inc. (MA); Capital Management Consulting, Inc. (MA)
| [underlined: Study Cohort]: Children who participated in study to assess diagnostic accuracy of EarCheck PRO and tympanometry | [underlined: Inclusion]:; - Age: 6 months-18 yrs; - Exclusion:; - Myringotomy tubes last 6 months; - Perforated tympanic membrane; - Cerumen that projected into >50% of the radius of the ear canal; - Any serious or psychologic illness; - Immunodeficiencies; - craniofacial deformities and/or middle ear abnormalities
| *(Three additional studies were reported in this article but none reported findings relevant to key question four.) | [underlined: Patient Characteristics]; - Age: 6–11 months (N=27); 5 years (N=261); 6–10 years (N=161); 11–18 years (N=79); - Male 51%, Female 49%
| N=528 subjects, 870 ears
888 Bluestone 1973 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 2 (100001) | [underlined: Place]: Not specified | [underlined: Comparisons]:; 1. Professional tympanometry^a^; Dx- : Patterns 1,2, and 3; Dx+ : Patterns 4 and 5; Myringotomy (sedated); GS- : Effusion absent; GS+ : Effusion present; 2. Audiometry - air conduction threshold; Dx- : Below 25 dB; Dx+ : E 25 dB; Myringotomy (sedated); GS- : Effusion absent; GS+ : Effusion present; 3. Audiometry - air and bone conduction thresholds; Dx- : Not Defined; Dx+ : Not Defined; Myringotomy (sedated); GS- : Effusion absent; GS+ : Effusion present | - [underlined: Comparison 1]:; sensitivity 100.00% (58/58); specificity 55.17% (16/29); PPV 81.69% (58/71); NPV 100.00% (16/16); accuracy 85.06% (74/87); prevalence 66.67% (58/87); - [underlined: Comparison 2]:; sensitivity 51.72% (30/58); specificity 75.76% (25/33); PPV 78.95% (30/38); NPV 47.17% (25/53); accuracy 60.44% (55/91); prevalence 63.74% (58/91); - [underlined: Comparison 3] ^b^:; Not done
| [underlined: Examiner(s)]:; - tympanometry (Madesen ZO-70 Electroacoustic Impedance Bridge): not specified; - audiometry (Maico portable audiometer): not specified | [underlined: Affiliation]: Cleft Palate Center and the Depts. Of Otolaryngology and Pediatrics, Univ. of Pittsburgh, PA; Children's Hospital of Pittsburgh; Dept. of Otolaryngology, Tufts Univ. Boston City Hospital, MA
| [underlined: Study Cohort]: Children who were studied to determine the relative validity of air-conduction audiometry and tympanometry in predicting presence of middle ear effusion | [underlined: Inclusion]:; - Age: 2 months-15 years; - history of recurrent AOM, or evidence otoscopically of persistent MEE, or both (considered candidates for myringotomy and tympanostomy tube insertion)
| N=84 subjects | [underlined: Exclusion]: None
| Comparison 1: 52 subjects, 87 ears | [underlined: Patient Characteristics]:; - mean age 5.3 years; - male 64, female 20
| Comparison 2: 55 subjects, 91 ears
889 Bluestone 1979 | Diagnostic study | [underlined: Time]: S2 ~ 9/1/1977–2/22/1978 | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 4 (110011) | [underlined: Place]: not specified | [underlined: Comparisons]:; 1. Pneumatic otoscopy - examiner; Validation not specified; Dx- : OME absent (- cases); Dx+ : OME present (+ and +/- cases); Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Professional tympanometry^a^; Dx- : Paradise classification variants 1–6, 9,15; Dx+ : Paradise classification variants 7,8,10–14; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Examiner type (Otolaryngologist); Pneumatic otoscopy - unvalidated examiner; Dx- : OME absent (- cases); Dx+ : OME present (+ and +/- cases); Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 4. Examiner type (Pediatrician); Pneumatic otoscopy - unvalidated examiner; Dx- : OME absent (- cases); Dx+ : OME present (+ and +/- cases); Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 5. Examiner type (Pediatrician); Pneumatic otoscopy - unvalidated examiner; Dx- : OME absent (- cases); Dx+ : OME present (+ and +/- cases); Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present) | - [underlined: Comparison 1]:; sensitivity 94.53% (242/256); specificity 77.51% (131/169); PPV 86.43% (242/280); NPV 90.34% (131/145); accuracy 87.76% (373/425); prevalence 60.24% (256/425); - [underlined: Comparison 2]:; sensitivity 93.75% (240/256); specificity 70.41% (119/169); PPV 82.76% (240/290); NPV 88.15% (119/135); accuracy 84.47% (359/425); prevalence 60.24% (256/425); - [underlined: Comparison 3]:; sensitivity 100.00% (29/29); specificity 22.73% (5/22); PPV 63.04% (29/46); NPV 100.00% (5/5); accuracy 66.67% (34/51); prevalence 56.86% (29/51); - [underlined: Comparison 4]:; sensitivity 96.30% (26/27); specificity 25.00% (5/20); PPV 63.41% (26/41); NPV 83.33% (5/6); accuracy 65.96% (31/47); prevalence 57.45% (27/47); - [underlined: Comparison 5]:; sensitivity 76.00% (19/25); specificity 50.00% (7/14); PPV 73.08% (19/26); NPV 53.85% (7/13); accuracy 66.67% (26/39); prevalence 64.10% (25/39)
| [underlined: Examiner(s)]:; - otoscopy: two otolaryngologists, two pediatricians; - tympanometry and middle ear muscle reflex (Model Z073 [Madsen Electronics]): by or under the direction of an audiologist, classified independently by two audiologists; - myringotomy: surgeon | [underlined: Affiliation]: Dept. of Otolaryngology, Children's Hospital of Pittsburgh, PA
| [underlined: Study Cohort]: Validity of diagnosing OME by otoscopy, tympanometry, and middle ear muscle reflex ~ gold standard: Myringotomy (referenced as Study 2 in article) | [underlined: Inclusion]:; - Age: 7 months-15 years; - patients scheduled for bilateral myringotomy and insertion of tympanostomy tubes on basis of a history of recurrent acute and/or persistent OME
| *(an additional study was reported in this article but findings were not relevant to key question four) | [underlined: Exclusion]: None
| N=239 subjects, 425 ears | [underlined: Patient Characteristics]: As above
989 Cantekin 1977 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place]: Not specified | [underlined: Comparisons]:; 1. Professional tympanometry^a^; (Madsen Electro-Acoustic Impedance Bridge, model ZO-70); Dx- : air pressure ≥ -100 mm; H2O; compliance <5.0 OR (See notes.); Dx+ : air press <-100 mm H_2_O; compliance ≥ 5 OR (See notes.); Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Professional tympanometry^b^; (Grason-Stadler Otoadmittance meter, model 1720); Dx- : See notes below.; Dx+ : See notes below.; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 84.13% (53/63); specificity 87.72% (50/57); PPV 88.33% (53/60); NPV 83.33% (50/60); accuracy 85.83% (103/120); prevalence 52.50% (63/120); - [underlined: Comparison 2]:; sensitivity 84.13% (53/63); specificity 87.72% (50/57); PPV 88.33% (53/60); NPV 83.33% (50/60); accuracy 85.83% (103/120); prevalence 52.50% (63/120)
| [underlined: Examiner(s)]; - tympanometry (types described under each comparison): not specified; - myringotomy: not specified | [underlined: Affiliation]: Dept. of Otolaryngology, Children's Hospital of Pittsburgh and the Univ. of Pittsburgh, PA
| [underlined: Study Cohort]: Children scheduled for bilateral myringotomy and insertion of tympanostomy tubes for recurrent acute otitis media history or persistent middle ear effusion by otoscopy | [underlined: Inclusion]:; - Age: 18 months-14 years; - history of recurrent AOM or otoscopic evidence of persistent MEE, or both; - scheduled for bilateral myringotomy and insertion of tympanostomy tubes for recurrent acute otitis media history or persistent middle ear effusion by otoscopy
| N=68 subjects, 120 ears | [underlined: Exclusion]: None
| | [underlined: Patient Characteristics]; - median age 6.5 years; - male 43, female 25
990 Cantekin 1980 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 4 (110011) | [underlined: Place]: Not specified | [underlined: Comparisons:]
| [underlined: Examiner(s):] | [underlined: Affiliation]: Dept. of Otolaryngology, Univ. of Pittsburgh School of Medicine, and Children's Hospital of Pittsburgh, PA | 1. Pneumatic otoscopy^a^ - unvalidated examiner; Dx-: OME absent; Dx+: OME present; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 2. Pneumatic otoscopy^b^ - unvalidated examiner; Dx-: OME absent; Dx+: OME present; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 3. Quantitative tympanometry^c^; Dx-: ME muscle reflex threshold ≤105dB; Dx+: Absence of ME muscle reflex; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 4. Quantitative tympanometry^d^; Dx-: ME muscle reflex threshold ≤105dB; Dx+: Absence of ME muscle reflex; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 5. Quantitative tympanometry^a^; Dx-: ME muscle reflex threshold ≤105dB; Dx+: Absence of ME muscle reflex; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 6. Quantitative tympanometry^b^; Dx-: ME muscle reflex threshold ≤105dB; Dx+: Absence of ME muscle reflex; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 7. 7. Quantitative tympanometry^c^; Dx-: ME muscle reflex threshold ≤105dB; Dx+: Absence of ME muscle reflex; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 8. Quantitative tympanometry^a^; Dx-: ME muscle reflex threshold ≤105dB; Dx+: Absence of ME muscle reflex; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 9. Quantitative tympanometry^b^; Dx-: ME muscle reflex threshold ≤105dB; Dx+: Absence of ME muscle reflex; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 10. Quantitative tympanometry^c^; Dx-: ME muscle reflex threshold ≤105dB; Dx+: Absence of ME muscle reflex; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present | - [underlined: Comparison 1:]; sensitivity 96.96% (223/230); specificity 81.43% (114/140); PPV 89.56% (223/249); NPV 94.21% (114/121); accuracy 91.08% (337/370); prevalence 62.16% (230/370); - [underlined: Comparison 2]:; sensitivity 87.56% (176/201); specificity 80.54% (120/149); PPV 85.85% (176/205); NPV 82.76% (120/145); accuracy 84.57% (296/350); prevalence 57.43% (201/350); - [underlined: Comparison 3]:; sensitivity 96.30%; specificity 34.60%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 4]:; sensitivity 92.90%; specificity 52.00%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 5]:; sensitivity 97.90%; specificity 24.80%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 6]:; sensitivity 95.50%; specificity 37.40%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 7]:; sensitivity 95.50%; specificity 37.40%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 8]:; sensitivity 91.90%; specificity 50.70%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 9]:; sensitivity 97.10%; specificity 29.40%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 10]:; sensitivity 93.30%; specificity 39.40%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown
| - otoscopy: two otolaryngologists; - tympanometry and middle ear muscle reflex (Model ZO73 [Madsen Electronics]): by or under the direction of an audiologist, independently classified by two investigators; - myringotomy: surgeon | [underlined: Inclusion:]
| [underlined: Study Cohort]: Children who underwent myringotomy ~ myringotomy findings were compared to OME diagnosis based on otoscopy, tympanometry and ME muscle reflex | - Age: 7 months-15 years; - patients scheduled for bilateral myringotomy and insertion of tympanostomy tubes; - history of recurrent AOM, or otoscopic evidence of persistent OME, or both
| N=333 subjects, 599 ears | [underlined: Exclusion:] None
| | [underlined: Patient Characteristics:]
| | - median age 6 years; - male 203, female 130
1238 Fiellau-Nikolajsen 1980 | Diagnostic study | [underlined: Time]: Intitial screening in Aug. 1978; operation (if needed) in Feb. 1979 | | [underlined: Unit of measure:] Ear
| [underlined: Study Quality Score (0–6)]: 4 (111001) | [underlined: Place]: Subjects identified from tympanometric screening in a Danish provincial municipality | [underlined: Comparisons:]
| [underlined: Examiner(s)] | [underlined: Affiliation]: ENT Dept. Hjoerring Hospital, Denmark | 1. 1.1 Professional tympanometry; Dx-: Compliance value >.10 ccm; Dx+: Compliance value ≤.10 ccm; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 2. 1.2 Professional tympanometry; Dx-: Compliance value >.20 ccm; Dx+: Compliance value ≤.20 ccm; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 3. 1.3 Professional tympanometry; Dx-: Compliance value >.30 ccm; Dx+: Compliance value ≤.30 ccm; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 4. 2. Professional tympanometry; Dx-: Gradient > .05 ccm; Dx+: Gradient ≤ .05 ccm; Myringotomy (sedated); GS-: Fluid absent; GS+: Fluid present; 5. 3. Professional tympanometry; Dx-: Gradient > .1 ccm; Dx+: Gradient ≤ .1 ccm; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present | - [underlined: Comparison 1.1] ^a^; sensitivity 19.57% (9/46); specificity 100.00% (42/42); PPV 100.00% (9/9); NPV 53.16% (42/79); accuracy 57.95% (51/88); prevalence 52.27% (46/88); - [underlined: Comparison 1.2] ^a^:; sensitivity 45.65% (21/46); specificity 95.24% (40/42); PPV 91.30% (21/23); NPV 61.54% (40/65); Accuracy 69.32% (61/88); prevalence 52.27% (46/88); - [underlined: Comparison 1.3] ^a^:; sensitivity 65.22% (30/46); specificity 76.19% (32/42); PPV 75.00% (30/40); NPV 66.67% (32/48); Accuracy 70.45% (62/88); prevalence 52.27% (46/88); - [underlined: Comparison 2]:; sensitivity 78.26% (36/46); specificity 92.86% (39/42); PPV 92.31% (36/39); NPV 79.59% (39/49); accuracy 85.23% (75/88); - [underlined: Comparison 3] ^a^:; sensitivity 91.30% (42/46); specificity 54.76% (23/42); PPV 68.85% (42/61); NPV 85.19% (23/27); accuracy 73.86% (65/88); prevalence 52.27% (46/88)
| - tympanometry (Madsen Impedance Meter, type ZO-73, testing tone 220Hz): the author; - myringotomy: two otosurgeons | [underlined: Inclusion:]
| *Same study population as record #1241 | - Age: 3 years at initial screening; - one or both ears consistently showed abnormal screening-tympanometry in Aug., Sept., Nov. 1978 and Feb. 1979; - living in municipality of Hjoerring, Denmark
| [underlined: Study Cohort]: Children whose ear(s) persistently showed abnormal screening-tympanometry over 6 months; myringotomic aspiration of any MEE was performed | [underlined: Exclusion:] None
| N=44 subjects (21 children bilateral, 23 unilateral), 88 ears | [underlined: Patient Characteristics:]
| | - mean age 47.2 months, range 42–54 months; - male 23, female 21
1241 Fiellau-Nikolajsen 1980 | Diagnostic study | [underlined: Time]: 8/1978-2/1979 (tested in August, 1978 - retests in September and November, 1978 and February,1979) | | [underlined: Unit of measure:] Ear
| [underlined: Study Quality Score (0–6)]: 4 (111001) | [underlined: Place]: Danish urban municipality (Hjoerring munipality: pop. 37,500) | [underlined: Comparisons:]
| [underlined: Examiner(s):] | [underlined: Affiliation]: Dept's of Otolarygology and Audiology, Hjoerring Hospital, Hjoerring, Denmark | 1. Professional tympanometry; Dx-: Type A and C1 tympanogram; Dx+: Type B and C2 tympanograms; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present | - [underlined: Comparison 1] ^a^; sensitivity 91.30% (42/46); specificity 88.10% (37/42); PPV 89.36% (42/47); NPV 90.24% (37/41); accuracy 89.77% (79/88); prevalence 52.27% (46/88)
| - tympanometry (Madsen Impedance Meter, type ZO-73, testing tone 220Hz): the author; - myringotomies: two otosurgeons | [underlined: Inclusion:]
| *This is the same study as 1238. However, the data are presented slightly differently. | - Age: 3 years at study entry (42–54 months by Feb. 1979); - abnormal tympanometric results persisting through 6 months
| [underlined: Study Cohort]: Children who showed abnormal tympanometry and underwent myringotomy. | [underlined: Exclusion:] None
| N=44 subjects, 88 ears | [underlined: Patient Characteristics:]
| | - mean age 47.2 months, range 42–54 months; - male 23, female 21
1245Fiellau-Nikolajsen 1983 | Diagnostic study | [underlined: Time]: 1978-1979 (four screens: Aug., Sep. & Nov., 1978, Feb. 1979) | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: | | [underlined: Comparisons]:
| 4 (111001) | [underlined: Place]: Subjects identified in municipality of Hjoerring, Denmark, (medium-size urban town with a population of approximately 20,000) | 1. Professional tympanometry; Dx- : Middle ear pressure >-100 mm H2O or non-flat curve; Dx+ : Middle ear pressure ≤-100 mm H2O or flat curve; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Professional tympanometry; Dx- : Middle ear pressure >-200 mm H2O or non-flat curve; Dx+ : Middle ear pressure ≤-200 mm H2O or flat curve; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Professional tympanometry; Dx- : Non-flat curve; Dx+ : Flat curve; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 95.65% (44/46); specificity 64.29% (27/42); PPV 74.58% (44/59); NPV 93.10% (27/29); accuracy 80.68% (71/88); prevalence 52.27% (46/88); [underlined: Comparison 2]:; sensitivity 91.30% (42/46); specificity 88.10% (37/42); PPV 89.36% (42/47); NPV 90.24% (37/41); accuracy 89.77% (79/88); prevalence 52.27% (46/88); [underlined: Comparison 3]:; sensitivity 82.61% (38/46); specificity 100.00% (42/42); PPV 100.00% (38/38); NPV 84.00% (42/50); accuracy 90.91% (80/88); prevalence 52.27% (46/88)
| [underlined: Examiner(s)]:; - tympanometry (Madsen tympanometer, model ZO-73, [Madsen Electronics], 220 Hz testing tone): not specified; - myringotomy: ENT surgeon | [underlined: Affiliation]: ENT Dept., Hjoerring Hospital, Denmark
| *This is the same study as 1238. However, the data are presented slightly different. | [underlined: Inclusion]:; - Age: 3 years (36–48 months); - living in municipality of Hjoerring, Denmark
| [underlined: Study Cohort]: Children who underwent Myringotomy due to persistent abnormal tympanograms across four screens | [underlined: Exclusion]: None
| *(Grp 1 was derived from an overall sample of 404 subjects) | [underlined: Patient Characteristics]:; - age range 36–48 months
| N=44 subjects, 88 ears
1250Finitzo 1992 | Diagnostic study | [underlined: Time]: not specified | | Unit of measure: Ear
| [underlined: Study Quality Score (0–6)]: 4 (111001) | [underlined: Place]: Children's Medical Center in Dallas, Texas | [underlined: Comparisons]:; 1. Pneumatic otoscopy^a^ - unvalidated examiner; Dx- : effusion absent; Dx+ : effusion present; Myringotomy (sedation unknown); GS- : fluid absent; GS+ : fluid present; 2. Professional tympanometry^a^; Dx- : Type A or A' tympanogram; Dx+ : Type B tympanogram; Myringotomy (sedation unknown); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 93.04% (107/115); specificity 58.33% (28/48); PPV 84.25% (107/127); NPV 77.78% (28/36); accuracy 82.82% (135/163); prevalence 70.55% (115/163); [underlined: Comparison 2]:; sensitivity 90.28% (65/72); specificity 86.36% (19/22); PPV 98.59% (65/68); NPV 73.08% (19/26); accuracy 89.36% (84/94); prevalence 76.60% (72/94)
| [underlined: Examiner(s)]:; - tympanometry (Maico Screening Immittance Bridge, model No. 610): certified audiologist; - pneumatic otoscopy: pediatric otolaryngologist; - myringotomy: not specified | [underlined: Affiliation]: Methodist Medical Center, Dallas, TX; Callier Center for Communication Disorders and Dept. of Otolaryngology, Univ. of Texas, Dallas, TX
| *No information regarding when tympanometry occurred relative to myringotomy is provided in the methods section. | [underlined: Inclusion]:; - Age: 6 months-9 years; - undergoing myringotomy for tube placement to treat recurrent OM or persisitent OME
| | [underlined: Exclusion]: None
| [underlined: Study Cohort]: Children who were to undergo myringotomy for the placement of ventilation tubes for recurrent OM or persistent OME | [underlined: Patient Characteristics]:; - mean age 31 months; - male 59, female 27
| N=88 subjects, 163 ears
1280Freyss 1980 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place]: Not specified | [underlined: Comparisons]:; 1. Quantitative tympanometry; Dx- : ≤115 dB (at 1000Hz); Dx+ : > 115 dB (at 1000Hz); Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Quantitative tympanometry; Dx- : < 2 STAR (suprathreshold acoustic reflex) (Madsen units); Dx+ : ≥2 STAR (Madsen units); Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Quantitative tympanometry; Dx- : ≤-100 mmH2O Peak Pressure; Dx+ : >-100 mmH2O; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 4. Quantitative tympanometry; Dx- : ≤ 4 Madsen units Maximum Compliance; Dx+ : > 4 Madsen Units Maximum Compliance; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 5. Quantitative tympanometry; Dx- : <1 Madsen Unit Tympanometric Gradient; Dx+ : ≤1 Madsen Unit Tympanometric Gradient; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 75.00% (57/76); specificity 82.61% (19/23); PPV 93.44% (57/61); NPV 50.00% (19/38); accuracy 76.77% (76/99); prevalence 76.77% (76/99); [underlined: Comparison 2]:; sensitivity 93.42% (71/76); specificity 65.22% (15/23); PPV 89.87% (71/79); NPV 75.00% (15/20); accuracy 86.87% (86/99); prevalence 76.77% (76/99); [underlined: Comparison 3]:; sensitivity 52.63% (40/76); specificity 82.61% (19/23); PPV 90.91% (40/44); NPV 34.55% (19/55); accuracy 59.60% (59/99); prevalence 76.77% (76/99); [underlined: Comparison 4]:; sensitivity 51.32% (39/76); specificity 78.26% (18/23); PPV 88.64% (39/44); NPV 32.73% (18/55); accuracy 57.58% (57/99); prevalence 76.77% (76/99); [underlined: Comparison 5]:; sensitivity 61.84% (47/76); specificity 78.26% (18/23); PPV 90.38% (47/52); NPV 38.30% (18/47); accuracy 65.66% (65/99); prevalence 76.77% (76/99)
| [underlined: Examiner(s)]:; - tympanometry (Madsen ZO 73 impedance bridge): not specified; - myringotomy: same investigator for all children | [underlined: Affiliation]: Univ. of Paris VII, Dept. of Oto-laryngology, Hospital Lariboisiere; Dept. of Oto-laryngology, Children's Hosptial Bretonneau, Paris, France
| | [underlined: Inclusion]:; - Age: 6 months-8 years; - undergoing bilateral myringtomy for recurrent otitis media or respiratory tract infection
| [underlined: Study Cohort]: Children undergoing bilateral myringtomy for recurrent otitis media or respiratory tract infection
| | [underlined: Exclusion]: None
| N=50 subjects, 99 ears | [underlined: Patient Characteristics]:; - age range 6 months-8 years
1282Fria 1980 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 3 (100101) | [underlined: Place]: Normal children were from the ambulatory care center. | [underlined: Comparisons]:^a^; 1. Portable tympanometer; Dx- : Middle Ear Analyzer Regions 1,2, and 3; Dx+ : MEA region 4; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Portable tympanometer; Dx- : acoustic reflex present; Dx+ : acoustic reflex absent; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Portable tympanometer; Dx- : Pressure Peak Present; Dx+ : Pressure Peak Absent; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 96.50% (138/143); specificity 62.28% (71/114); PPV 76.24% (138/181); NPV 93.42% (71/76); accuracy 81.32% (209/257); prevalence 55.64% (143/257); [underlined: Comparison 2]:; sensitivity 98.60% (141/143); specificity 44.74% (51/114); PPV 69.12% (141/204); NPV 96.23% (51/53); accuracy 74.71% (192/257); prevalence 55.64% (143/257); [underlined: Comparison 3]:; sensitivity 86.71% (124/143); specificity 80.70% (92/114); PPV 84.93% (124/146); NPV 82.88% (92/111); accuracy 84.04% (216/257); prevalence 55.64% (143/257)
| [underlined: Examiner(s)]:; - tympanometry (Grason-Stadler, model 1722, 1000Hz at 102 dB SPL): not specified; - myringotomy: not specified | [underlined: Affiliation]: Dept. of Otolaryngology, Univ. of Pittsburgh School of Medicine; Audiology Division, Dept. of Otolaryngology, Children's Hospital of Pittsburgh, Pittsburgh, PA
| [underlined: Study Cohort]: OME - Children with history of recurrent AOM or otoscopic evidence of persistent OME, or both | [underlined: Inclusion]:; - Age: 3–15 years; - history of recurrent AOM or otoscopic evidence of persistent OME, or both
| *(N=40 otoscopically normal children were reported in this article but findings were not relevant to key question four)
| | [underlined: Exclusion]: None
| | [underlined: Patient Characteristics]:; - Grp 1 mean age 8 years, range 3–15 years, Grp 2 mean age 4 years, range 7 months-13 years
| N=172 subjects, 344 ears
4879Fried 1985 | Diagnostic Study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| | | [underlined: Comparisons]:; 1. Acoustic reflectometry; Dx- : ≤ 4 Reflectivity Units; Dx+ : > 4 Reflectivity Units; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:^a^; outcome~(ears - defined by group); sensitivity 70.97% (44/62); specificity 90.00% (36/40); PPV 91.67% (44/48); NPV 66.67% (36/54); accuracy 78.43% (80/102); prevalence 60.78% (62/102)
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place]: Not specified
| | [underlined: Affiliation]: Joint Center for Otolaryngology, Harvard Medical School, Boston, MA
| [underlined: Examiner(s)]:; - pneumatic otoscopy: three surgeons; - acoustic reflectometry (Acoustic Otoscope): not specified
| | [underlined: Inclusion]:; - Age: 1–13 years; - undergoing bilateral myringotomy and ventilation tube insertion
| [underlined: Study Cohort]: Children undergoing bilateral myringotomy and ventilation tube insertion
| | [underlined: Exclusion]: None
| | [underlined: Patient Characteristics]:; - age range 1–13 years
| N=59 subjects, 118 ears
4878 Gersdorff 1986 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place]: Not specified | [underlined: Comparisons]:^a^; 1. Professional tympanometry; Dx- : Type I tympanogram; Dx+ : Type IV tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Professional tympanometry; Dx- : Typanogram types I, II, III, & V; Dx+ : Typanogram type IV; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Professional tympanometry; Dx- : Tympanogram Type I; Dx+ : Tympanogram types II,III,IV,&V; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 89.71% (61/68); specificity 28.57% (8/28); PPV 75.31% (61/81); NPV 53.33% (8/15); accuracy 71.88% (69/96); prevalence 70.83% (68/96); - [underlined: Comparison 2]:; sensitivity 75.31% (61/81); specificity 57.45% (27/47); PPV 75.31% (61/81); NPV 57.45% (27/47); accuracy 68.75% (88/128); prevalence 63.28% (81/128); - [underlined: Comparison 3]:; sensitivity 91.36% (74/81); specificity 17.02% (8/47); PPV 65/49% (74/113); NPV 53.33% (8/15); accuracy 64.06% (82/128); prevalence 63.28% (81/128)
| [underlined: Examiner(s)]:; - tympanometry (Grason-Stadler 1723 oto-admittance meter, 220Hz tone): not specified; myringotomy: ENT surgeon | [underlined: Affiliation]: Dept. of Otorhinolaryngology, Dept. of Anesthesiology, University of Louvain, Belgium
| [underlined: Study Cohort]: Pathological children with serous and secretory otitis media who underwent myringotomy and ventilating tube insertion (50% of these children received denitrogenization before induction of classic inhalation anesthesia) | [underlined: Inclusion]:; - classified as pathological due to presence of serous and secretory OM upon clinical examination
| *(A control group was studied; however, findings were not relevant to key question four.) | [underlined: Exclusion]: None
| N=64 subjects, 128 ears | [underlined: Patient Characteristics]:; - combined mean age 7.5 years
1384 Grimaldi 1976 | Diagnostic study | [underlined: Time]: 9-month period (actual dates not specified) | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 2 (100001) | [underlined: Place]: Patients from ENT Dept. of King's College Hospital and referred by otologists based on data from a routine outpatient clinic | [underlined: Comparisons]:; 1. Non-pneumatic otoscopy^a^; Dx- : Effusion absent (includes n=47 undecided cases); Dx+ : Effusion present; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Non-pneumatic otoscopy^b^; Dx- : Effusion absent; Dx+ : Effusion present (includes n=47 undecided cases); Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Binocular micro-tympanoscopy^c^; Dx- : no effusion visualized, undecided group; Dx+ : effusion visualized; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 4. Binocular micro-tympanoscopy^a^; Dx- : no effusion visualized; Dx+ : effusion visualized; undecided group; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 5. Binocular micro-tympanoscopy^b^; Dx- : No effusion visualized; Dx+ : Effusion visualized; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 85.71% (132/154); specificity 87.27% (48/55); PPV 94.96% (132/139); NPV 68.57% (48/70); accuracy 86.12% (180/209); prevalence 73.68% (154/209); - [underlined: Comparison 2]:; sensitivity 98.05% (151/154); specificity 36.36% (20/55); PPV 81.18% (151/186); NPV 86.96% (20/23); accuracy 81.82% (171/209); prevalence 73.68% (154/209); - [underlined: Comparison 3]:; sensitivity 85.71% (132/154); specificity 87.27% (48/55); PPV 94.96% (132/139); NPV 68.57% (48/70); accuracy 86.12% (180/209); prevalence 73.68% (154/209); - [underlined: Comparison 4]:; sensitivity 98.05% (151/154); specificity 36.36% (20/55); PPV 81.18% (151/186); NPV 86.96% (20/23); accuracy 81.82% (171/209); prevalence 73.68% (154/209); - [underlined: Comparison 5]:; sensitivity 97.78% (132/135); specificity 74.07% (20/27); PPV 94.96% (132/139); NPV 86.96% (20/23); accuracy 93.83% (152/162); prevalence 83.33% (135/162)
| [underlined: Examiner(s)]:; - audiometry (Peters AP 5 audiometer): OME audiologist; - tympanometry (Peters AP 61 impedance meter): one audiologist; - binocular micro-tympanoscopy: not specified; - myringotomy: single surgeon; - visual inspection: effusion probably or possible = OME | [underlined: Affiliation]: Not specified apart from author being from London
| *Although tympanometry and air-conduction audiometry were also assessed in this study, the data cannot be used because they were combined into a diagnostic algorithm rather than being evaluated as individual methods. | [underlined: Inclusion]:; - referred by otologists for presumptive middle ear effusions
| [underlined: Study Cohort]: Children referred by otologists for presumptive middle ear effusions | [underlined: Exclusion]:; - inadequate audiometric data
| N=120 subjects, 209 ears | [underlined: Patient Characteristics]:; - age not specified, other than being children
1397 Haapaniemi 1997 | Diagnostic study | [underlined: Time]: not specified | | Values for the “b” and “d” cells in the 2X2 table are not provided in article
| [underlined: Study Quality Score (0–6)]: 2 (100100) | [underlined: Place]: Elementary schools of Salo, a small town in Finland | | [underlined: Unit of measure]: Varies
| [underlined: Examiner(s)]:; - pure-tone audiometry (Madsen TBN 80 audiometer [Madsen Electronics]): not specified; - tympanometry and stapedius reflexes (GSI 28 tympanometer [Grason-Stadler], 226 Hz tone): not specified; - otomicroscopy: not specified; - paracentesis: not specified | [underlined: Affiliation]: Dept. Otolaryngology, Univ. Central Hospital of Turku, Finland | [underlined: Comparisions]:; 1. Professional tympanometry; Dx- : Tympanometric peak pressure (TPP) ≥-100 daPa; Dx+ : TPP < -100 daPa; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 2. Professional tympanometry; Dx- : Tympanometric peak pressure; (TPP) ≥-100 daPa; Dx+ : TPP < -100 daPa; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 3. Professional tympanometry; Dx- : Tympanometric peak pressure (TPP) ≥-150 daPa; Dx+ : TPP < -150 daPa; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 4. Professional tympanometry; Dx- : Tympanometric peak pressure (TPP) ≥-150 daPa; Dx+ : TPP < -150 daPa; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 5. Professional tympanometry; Dx- : Tympanometric peak pressure (TPP) ≥-200 daPa; Dx+ : TPP < -200 daPa; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 6. Professional tympanometry; Dx- : Tympanometric peak pressure (TPP) ≥-200 daPa; Dx+ : TPP < -200 daPa; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 7. Professional tympanometry; Dx- : non-Type B tympanogram; Dx+ : Type B tympanogram; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 8. Professional tympanometry; Dx- : non-Type B Tympanogram; Dx+ : Type B tympanogram; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 9. Professional tympanometry^a^; Dx- : Cutoff of 0.3 ml is given for admittance (see notes below); Dx+ : Cutoff of 0.3 ml is given for admittance (see notes below); Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 10. Professional tympanometry^a^; Dx- : Cutoff of 0.3 ml is given for admittance (see notes below); Dx+ : Cutoff of 0.3 ml is given for Admittance (see notes below); Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 11. Professional tympanometry^a^; Dx- : Relative gradient > 0.35; Dx+ : Relative gradient ≤ 0.35; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 12. Professional tympanometry^a^; Dx- : Relative gradient > 0.35; Dx+ : Relative gradient ≤ 0.35; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 13. Professional tympanometry; Dx- : Ipsilateral Stapedius Reflex (at 1000Hz) at 105 dB - present; Dx+ : Ipsilateral Stapedius Reflex (at 1000Hz) at 105 dB - absent; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 14. Professional tympanometry; Dx- : Ipsilateral Stapedius Reflex (at 1000Hz) at 105 dB - present; Dx+ : Ipsilateral Stapedius Reflex (at 1000Hz) at 105 dB - absent; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 15. Professional tympanometry; Dx- : Contralateral Stapedius Reflex (at 1000 Hz) 110dB - present; Dx+ : Contralateral Stapedius Reflex (at 1000Hz) at 110 dB - absent; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 16. Professional tympanometry; Dx- : Contralateral Stapedius Reflex (at 1000 Hz) 110dB - present; Dx+ : Contralateral Stapedius Reflex (at 1000Hz) at 110 dB - absent; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 17. Professional tympanometry^a^; Dx- : Tympanogram Types A, C1, and C2; Dx+ : Tympanogram Type B; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 18. Audiometry - air conduction threshold; Dx- : ≤ 15 hearing threshold at .25 to 8 kHz; Dx+ : > 15 dB hearing threshold (at .25 to 8 kHz); Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 19. Audiometry - air conduction threshold; Dx- : ≤ 15 hearing threshold at .25 to8 kHz; Dx+ : > 15 dB hearing threshold (at .25 to 8 kHz); Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 20. Audiometry - air conduction threshold; Dx- : ≤ 20 dB hearing threshold (.25 to 8 kHz); Dx+ : > 20 dB hearing threshold (.25to 8 kHz); Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 21. Audiometry - air conduction threshold; Dx- : ≤ 20 dB hearing threshold (.25 to 8; kHz); Dx+ : > 20 dB hearing threshold (.25 to 8 kHz); Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; [underlined: Unit of measure]: Subjects; sensitivity 93.33% (28/30); specificity 88.00%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 2]:; [underlined: Unit of measure]: Ear; sensitivity 94.74% (36/38); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 3]:; [underlined: Unit of measure:]Subjects; sensitivity 93.33% (28/30); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 4]:; [underlined: Unit of measure]: Ear; sensitivity 94.74% (36/38); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 5]:; [underlined: Unit of measure]: Subjects; sensitivity 86.67% (26/30); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 6]:; [underlined: Unit of measure]: Ear; sensitivity 89.47% (34/38); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 7]:; [underlined: Unit of measure]: Subjects; sensitivity 53.33% (16/30); specificity 100.00%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 8]:; [underlined: Unit of measure]: Ear; sensitivity 55.26% (21/38); specificity 100.00%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 9]:; [underlined: Unit of measure]: Subjects; sensitivity 80.00% (24/30); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 10]:; [underlined: Unit of measure]: Ear; sensitivity 81.58% (31/38); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 11]:; [underlined: Unit of measure]: Subject; sensitivity 76.67% (23/30); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 12]:; [underlined: Unit of measure]: Ear; sensitivity 73.68% (28/38); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 13]:; [underlined: Unit of measure]: Subject; sensitivity 76.67% (23/30); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 14]:; [underlined: Unit of measure]: Ear; sensitivity 78.95% (30/38); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 15]:; [underlined: Unit of measure]: Subject; sensitivity 73.33% (22/30); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 16]:; [underlined: Unit of measure]: Ear; sensitivity 73.68% (28/38); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 17]:; [underlined: Unit of measure]: Ear; sensitivity 55.26% (21/38); specificity 100.00%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 18]:; [underlined: Unit of measure]: Subject; sensitivity 82.76% (24/29); specificity 81.36% (323/397); PPV 24.49% (24/98); NPV 98.48% (323/328); accuracy 81.46% (347/426); prevalence 6.81% (29/426); - [underlined: Comparison 19]:; [underlined: Unit of measure]: Ear; sensitivity 86.49% (32/37); specificity 87.00%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 20]:; [underlined: Unit of measure]: Subject; sensitivity 68.97% (20/29); specificity 87.91% (349/397); PPV 29.41% (20/68); NPV 97.49% (349/358); accuracy 86.62% (369/426); prevalence 8.38% (29/426); - [underlined: Comparison 21]:; [underlined: Unit of measure]: Ear; sensitivity 72.97% (27/37); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown
| [underlined: Study Cohort]: 1^st^and 4th grade children who underwent a routine ENT investigation at school that included: otomicroscopy, pure-tone audiometry, tympanometry and stapedius reflex measurements | [underlined: Inclusion]:; - Age represented by grade level: First, fourth and eighth grade; - attending an elementary school in Salo, Finland
| * (8^th^ grade children were also studied but their age range was above that specified for key question four) | [underlined: Exclusion]: None
| N=426 subjects, 850 ears | [underlined: Patient Characteristics]:; - 1st grade mean age 7.0 years, range 6–9 years; 4th grade mean age 10.2 years, range 10–12 years
1446 Haughton 1977 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 2 (100001) | [underlined: Place]: A typical ear, nose, and throat clinic | [underlined: Comparisons]:; 1. Professional tympanometry; Dx- : Compliance > .21 ml; Dx+ : Compliance ≤ .21 ml; Tympanocentesis (sedation unknown); GS- : Fluid absent; GS+ : Fluid present; 2. Professional tympanometry; Dx- : Compliance > .25 ml; Dx+ : Compliance ≤ .25 ml; Tympanocentesis (sedation unknown); GS- : Fluid absent; GS+ : Fluid present; 3. Professional tympanometry; Dx- : Compliance > .17 ml; Dx+ : Compliance ≤ .17 ml; Tympanocentesis (sedation unknown); GS- : Fluid absent; GS+ : Fluid present; 4. Professional tympanometry; Dx- : Gradient > .04 ml/50 mm H2O; Dx+ : Gradient ≤ .04 ml/ 50 mm H2O; Tympanocentesis (sedation unknown); GS- : Fluid absent; GS+ : Fluid present; 5. Professional tympanometry; Dx- : Gradient > .03 ml/50 mm H2O; Dx+ : Gradient ≤ .03 ml/ 50 mm H2O; Tympanocentesis (sedation unknown); GS- : Fluid absent; GS+ : Fluid present; 6. Professional tympanometry; Dx- : Gradient > .05 ml/50 mm H2O; Dx+ : Gradient ≤ .05 ml/ 50 mm H2O; Tympanocentesis (sedation unknown); GS- : Fluid absent; GS+ : Fluid present; 7. Professional tympanometry; Dx- : Gradient > .1 ml/50 mm H2O; Dx+ : Gradient ≤ .1 ml/ 50 mm H2O; Tympanocentesis (sedation unknown); GS- : Fluid absent; GS+ : Fluid present | - [underlined: Comparison 1]:; sensitivity 75.96% (79/104); specificity 80.74% (109/135); PPV 75.24% (79/105); NPV 81.34% (109/134); accuracy 78.66% (188/239); prevalence 43.51% (104/239); - [underlined: Comparison 2]:; sensitivity 79.81% (83/104); specificity 74.81% (101/135); PPV 70.94% (83/117); NPV 82.79% (101/122); accuracy 76.99% (184/239); prevalence 43.51% (104/239); - [underlined: Comparison 3]:; sensitivity 69.23% (72/104); specificity 85.93% (116/135); PPV 79.12% (72/91); NPV 78.38% (116/148); accuracy 78.66% (188/239); prevalence 43.51% (104/239); - [underlined: Comparison 4]:; sensitivity 76.92% (80/104); specificity 85.19% (115/135); PPV 80.00% (80/100); NPV 82.73% (115/139); accuracy 81.59% (195/239); prevalence 43.51% (104/239); - [underlined: Unit of measure: Ear]; - [underlined: Comparison 5]:; sensitivity 73.08% (76/104); specificity 87.41% (118/135); PPV 39.18% (76/194); NPV 80.82% (118/146); accuracy 81.17% (194/239); prevalence 43.51% (104/239); - [underlined: Comparison 6]:; sensitivity 79.81% (83/104); specificity 81.48% (110/135); PPV 76.85% (83/108); NPV 83.97% (110/131); accuracy 80.75% (193/239); prevalence 43.51% (104/239); - [underlined: Comparison 7]:; sensitivity 87.50% (91/104); specificity 60.00% (81/135); PPV 62.76% (91/145); NPV 86.17% (81/94); accuracy 71.97% (172/239); prevalence 43.51% (104/239)
| [underlined: Examiner(s)]:; - tympanometry (instrument not specified): not specified; - tympanocentesis: one of several surgeons | [underlined: Affiliation]: S1~ Dept. of Otolaryngology and Head and Neck Surgery, Hull Royal Infirmary, Hull, Great Britain
| [underlined: Study Cohort]: S1~ Ears examined in children admitted for aspiration of the middle ear; Haughton study | [underlined: Inclusion]:; - Age: 3 years- >=12 years (max not specified); - admitted for aspiration of the middle ear
| *(Two additional studies were reported in this article but none reported findings relevant to key question four) | [underlined: Exclusion]: None
| N=239 ears, 104 subjects | [underlined: Patient Characteristics]:; - 1% 3 years; 6% 4 years; 14% 5 years; 23% 6 years; 10% 7 years; 13% 8 years; 8% 9 years; 10% 10 years; 5% 11 years; 10% ∃ 12 years
3022 Johnson 1980 | Cross-sectional | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 2 (110000) | [underlined: Place]: Ear, Nose, and Throat Clinic at the University of Utah Medical Center, Salt Lake City, UT | [underlined: Comparisons]:; 1. Professional tympanometry^a^; Dx- : Normal tympanogram; Dx+ : Flat tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 74.32% (55/74); specificity 75.61% (31/41); PPV 84.62% (55/65); NPV 62.00% (31/50); accuracy 74.78% (86/115); prevalence 64.35% (74/115)
| [underlined: Examiner(s)]:; - tympanometry (impedance bridge): audiologist; - myringotomy: not specified | [underlined: Affiliation]: Div. of Otolaryngology, Univ. of Utah
| *The primary aim of this study was to examine the changes in tympanogram types resulting from anesthesia. This is not a study focused on determining the sensitivity and/or specificity of tympanometry on detecting OME. | [underlined: Inclusion]:; - Age: 8 months-10 years; - recurrent AOM or persistent MEE
| [underlined: Study Cohort]: Children undergoing myringotomy with placement of ventillation tubes for recurrent AOM or persistent MEE | [underlined: Exclusion]:; - perforated tympanic membrane (one ear excluded)
| N=61 subjects, 121 ears | [underlined: Patient Characteristics]:; - mean age 3.5 years; - male 40, female 21
1600 Jonathan 1989 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place]: Grp 1 were operative admissions, and Grp 2 were from a general pediatric ward. | [underlined: Comparisons]:; 1. Non-pneumatic otoscopy^a^; Dx- : normal appearance of the tympanic membrane; Dx+ : abnormal appearance of the; tympanic membrane; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Professional tympanometry^a^; Dx- : Tympanogram has any form other than a flat tracing; Dx+ : Tympanogram is flat; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Audiometry - air conduction threshold^a^; Dx- : ≤ 15 dB hearing threshold at all frequencies tested; Dx+ : > 15 dB hearing threshold at all frequencies tested; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 100.00%; specificity 28.00%; PPV unknown; NPV unknown; accuracy 80.36% (90/112); prevalence 100.00% (112/112); - [underlined: Comparison 2]:; sensitivity 86.00%; specificity 86.00%; PPV unknown; NPV unknown; accuracy 85.71% (102/119); prevalence 100.00% (119/119); - [underlined: Comparison 3]:; sensitivity 90.00%; specificity 52.00%; PPV unknown; NPV unknown; accuracy 78.64% (81/103); prevalence 100.00% (103/103)
| [underlined: Examiner(s)]:; - otoscopy (instrument not specified): not specified; - tympanometry (instrument not specified): not specified; - audiometry (instrument not specified): not specified; - myringotomy: not specified | [underlined: Affiliation]: St. George's Hospital, Tooting, London
| *This study focused mainly on sonotubometry. | [underlined: Inclusion]:; - Age: 3–14 years; - admitted for myringotomy
| [underlined: Study Cohort]: Children admitted for routine myringotomies (including in some cases adenoidectomy and/or tonsillectomy) | [underlined: Exclusion]:; - pre-existing perforations
| *(a control group was studied however findings were not relevant to key question four) | [underlined: Patient Characteristics]:; - mean age 6.2 years, range 3–14 years; Grp 2 mean age 7 years, range 3–14 years; - male 35, female 29;
| N=64 subjects, 126 ears
1632 Karma 1989 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear-related visits (1–2 years fo follow-up)
| [underlined: Study Quality Score (0–6)]: 3 (100101) | [underlined: Place]: Outpatient Clinics of Otolaryngology at the Tampere or Pediatrics at the Oulu University Central Hospital, Finland | [underlined: Comparisons]:; 1. Grp 1; Signs/symptoms; Dx- : TM color normal; Dx+ : TM haemorrhagic; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Grp 1; Signs/symptoms; Dx- : TM color normal; Dx+ : TM strongly red; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Grp 1; Signs/symptoms; Dx- : TM color normal; Dx+ : TM moderately red; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 4. Grp 1; Signs/symptoms; Dx- : TM color normal; Dx+ : TM slightly red; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 5. Grp 1^a^; Non-pneumatic otoscopy; Dx- : Tympanic membrane not red; Dx+ : Tympanic membrane red; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 6. Grp 1^a^; Non-pneumatic otoscopy; Dx- : Not red; Dx+ : Distinctly red - hemorrhagic, strongly or moderately red; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 7. Grp 1^a^; Non-pneumatic otoscopy; Dx- : TM not cloudy; Dx+ : TM cloudy; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 8. Grp 1^a^; Non-pneumatic otoscopy; Dx- : TM color normal; Dx+ : TM color abnormal; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 9. Grp 1^a^; Non-pneumatic otoscopy; Dx- : TM not bulging; Dx+ : TM bulging; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 10. Grp 1^a^; Non-pneumatic otoscopy; Dx- : TM not retracted; Dx+ : TM retracted; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 11. Grp 1^a^; Non-pneumatic otoscopy; Dx- : TM position normal; Dx+ : TM position abnormal; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 12. Grp 1; Pneumatic otoscopy - unvalidated examiner; Dx- : TM mobility normal; Dx+ : TM mobility abnormal; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 13. Grp 1^a^; Pneumatic otoscopy - examiner validation not specified; Dx- : TM with normal mobility; Dx+ : TM with impaired mobility; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 14. Grp 1; Pneumatic otoscopy - examiner validation not specified; Dx- : TM with normal mobility; Dx+ : TM mobility distinctly impaired; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 15. Grp 1; Pneumatic otoscopy - examiner validation not specified; Dx- : TM mobility normal; Dx+ : TM mobility slightly impaired; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 16. Grp 2; Signs/symptoms; Dx- : TM color normal; Dx+ : TM haemorrhagic; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 17. Grp 2; Signs/symptoms; Dx- : TM color normal; Dx+ : TM strongly red; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 18. Grp 2; Signs/symptoms; Dx- : TM color normal; Dx+ : TM moderately red; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 19. Grp 2; Signs/symptoms; Dx- : TM color normal; Dx+ : TM slightly red; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 20. Grp 2; Non-pneumatic otoscopy; Dx- : TM color normal; Dx+ : Tympanic membrane red; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 21. Grp 2^a^; Non-pneumatic otoscopy; Dx- : TM color normal; Dx+ : TM distinctly red - hemorrhagic, strongly or moderately red; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 22. Grp 2^a^; Non-pneumatic otoscopy; Dx- : TM color normal; Dx+ : TM cloudy; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 23. Grp 2^a^; Non-pneumatic otoscopy; Dx- : TM color normal; Dx+ : TM color abnormal; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 24. Grp 2 ^a^; Non-pneumatic otoscopy; Dx- : TM not bulging; Dx+ : TM bulging; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 25. Grp 2^a^; Non-pneumatic otoscopy; Dx- : TM not retracted; Dx+ : TM retracted; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 26. Grp 2^a^; Non-pneumatic otoscopy; Dx- : TM position normal; Dx+ : TM position abnormal; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 27. Grp 2; Pneumatic otoscopy - unvalidated examiner; Dx- : TM mobility normal; Dx+ : TM mobility abnormal; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 28. Grp 2^a^; Pneumatic otoscopy - examiner validation not specified; Dx- : TM mobility normal; Dx+ : TM mobility impaired; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 29. Grp 2^a^; Pneumatic otoscopy - examiner validation not specified; Dx- : TM mobility normal; Dx+ : TM mobility distinctly impaired; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 30. Grp 2^a^; Pneumatic otoscopy - examiner validation not specified; Dx- : TM mobility normal; Dx+ : TM mobility slightly impaired; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 0.25% (1/408); specificity 100.00% (185/185); PPV 100.00% (1/1); NPV 31.25% (185/592); accuracy 31.37% (186/593); prevalence 68.80% (408/593); - [underlined: Comparison 2]:; sensitivity 0.74% (3/408); specificity 99.46% (184/185); PPV 75.00% (3/4); NPV 31.24% (184/589); accuracy 31.53% (187/593); prevalence 68.80% (408/593); - [underlined: Comparison 3]:; sensitivity 2.21% (9/408); specificity 97.84% (181/185); PPV 69.23% (9/13); NPV 31.21% (181/580); accuracy 32.04% (190/593); prevalence 47.30% (408/593); - [underlined: Comparison 4]:; sensitivity 1.23% (5/408); specificity 97.84% (181/185); PPV 55.56% (5/9); NPV 30.99% (181/584); accuracy 31.37% (186/593); prevalence 68.80% (408/593); - [underlined: Comparison 5]:; sensitivity 4.66% (19/408); specificity 94.59% (175/185); PPV 65.52% (19/29); NPV 31.03% (175/564); accuracy 32.72% (194/593); prevalence 68.80% (408/593); LR+: 1.10; LR-: 1.00; - [underlined: Comparison 6]:; sensitivity 3.43% (14/408); specificity 97.30% (180/185); PPV 73.68% (14/19); NPV 31.36% (180/574); accuracy 32.72% (194/593); prevalence 68.80% (408/593); LR+: .50; LR-: 1.00; - [underlined: Comparison 7]:; sensitivity 92.89% (379/408); specificity 98.38% (182/185); PPV 99.21% (379/382); NPV 86.26% (182/211); accuracy 94.60% (561/593); prevalence 68.80% (408/593; LR+: 51.60; LR-: .07; - [underlined: Comparison 8]:; sensitivity 97.55% (398/408); specificity 92.97% (172/185); PPV 96.84% (398/411); NPV 94.51% (172/182); accuracy 96.12% (570/593); prevalence 68.80% (408/593); LR+: 13.90; LR-: .03; - [underlined: Comparison 9]:; sensitivity 45.10% (184/408); specificity 98.92% (183/185); PPV 98.92% (184/186); NPV 44.96% (183/407); accuracy 61.89% (367/593); prevalence 68.80% (408/593); LR+: 56.50; LR-: .60; - [underlined: Comparison 10]:; sensitivity 10.05% (41/408); specificity 95.14% (176/185); PPV 82.00% (41/50); NPV 32.41% (176/543); accuracy 36.59% (217/593); prevalence 68.80% (408/593); LR+: 2.00; LR-: .90; - [underlined: Comparison 11]:; sensitivity 55.39% (226/408); specificity 94.05% (174/185); PPV 95.36% (226/237); NPV 48.88% (174/356); accuracy 67.45% (400/593); prevalence 68.80% (408/593); LR+: 9.50; LR-: .50; - [underlined: Comparison 12]:; sensitivity 98.77% (403/408); specificity 90.27% (167/185); PPV 95.72% (403/421); NPV 97.09% (167/172); accuracy 96.12% (570/593); prevalence 68.80% (408/593); - [underlined: Comparison 13]:; sensitivity 98.77% (403/408); specificity 90.27% (167/185); PPV 95.72% (403/421); NPV 97.09% (167/172); accuracy 96.12% (570/593); prevalence 68.80% (408/593); LR+: 10.20; LR-: .01; - [underlined: Comparison 14]:; sensitivity 76.23% (311/408); specificity 97.30% (180/185); PPV 98.42% (311/316); NPV 64.98% (180/277); accuracy 82.80% (491/593); prevalence 68.80% (408/593); LR+: 30.50; LR-: .20; - [underlined: Comparison 15]:; sensitivity 22.30% (91/408); specificity 92.97% (172/185); PPV 87.50% (91/104); NPV 35.17% (172/489); accuracy 44.35% (263/593); prevalence 68.80% (408/593); LR+: 3.20; LR-: .80; - [underlined: Comparison 16]:; sensitivity 5.80% (20/345); specificity 98.05% (151/154); PPV 86.96% (20/23); NPV 31.72% (151/476); accuracy 34.27% (171/499); prevalence 69.14% (345/499); - [underlined: Comparison 17]:; sensitivity 2.90% (10/345); specificity 99.35% (153/154); PPV 90.91% (10/11); NPV 31.35% (153/488); accuracy 32.67% (163/499); prevalence 29.06% (145/499); - [underlined: Comparison 18]:; sensitivity 2.90% (10/345); specificity 98.70% (152/154); PPV 83.33% (10/12); NPV 31.21% (152/487); accuracy 32.46% (162/499); prevalence 69.14% (345/499); - [underlined: Comparison 19]:; sensitivity 8.99% (31/345); specificity 95.45% (147/154); PPV 81.58% (31/38); NPV 31.89% (147/461); accuracy 35.67% (178/499); prevalence 69.14% (345/499); - [underlined: Comparison 20]:; sensitivity 12.17% (42/345); specificity 92.21% (142/154); PPV 77.78% (42/54); NPV 31.91% (142/445); accuracy 36.87% (184/499); prevalence 69.14% (345/499); LR+: .20; LR-: 1.00; - [underlined: Comparison 21]:; sensitivity 11.30% (39/345); specificity 96.75% (149/154); PPV 88.64% (39/44); NPV 32.75% (149/455); accuracy 37.68% (188/499); prevalence 69.14% (345/499); LR+: 3.00; LR-: .90; - [underlined: Comparison 22]:; sensitivity 68.99% (238/345); specificity 87.66% (135/154); PPV 92.61% (238/257); NPV 55.79% (135/242); accuracy 74.75% (373/499); prevalence 69.14% (345/499); LR+: 5.60; LR-: .40; - [underlined: Comparison 23]:; sensitivity 81.16% (280/345); specificity 79.22% (122/154); PPV 89.74% (280/312); NPV 65.24% (122/187); accuracy 80.56% (402/499); prevalence 69.14% (345/499); LR+: 4.00; LR-: .20; - [underlined: Comparison 24]:; sensitivity 18.26% (63/345); specificity 99.35% (153/154); PPV 98.44% (63/64); NPV 35.17% (153/435); accuracy 43.29% (216/499); prevalence 69.14% (345/499); LR+: 23.00; LR-: .80; - [underlined: Comparison 25]:; sensitivity 32.17% (111/345); specificity 90.26% (139/154); PPV 88.10% (111/126); NPV 37.27% (139/373); accuracy 50.10% (250/499); prevalence 69.14% (345/499; LR+: 3.30; LR-: .80; - [underlined: Comparison 26]:; sensitivity 50.43% (174/345); specificity 90.20% (138/153); PPV 91.58% (174/190); NPV 44.66% (138/309); accuracy 62.53% (312/499); prevalence 69.14% (345/499); LR+: 4.90; LR-: .60; - [underlined: Comparison 27]:; sensitivity 93.62% (323/345); specificity 71.43% (110/154); PPV 88.01% (323/367); NPV 83.33% (110/132); accuracy 86.77% (433/499); prevalence 69.14% (345/499); - [underlined: Comparison 28]:; sensitivity 93.62% (323/345); specificity 70.78% (109/154); PPV 87.77% (323/368); NPV 83.21% (109/131); accuracy 86.57% (432/499); prevalence 69.14% (345/499); LR+: 3.30; LR-: .09; - [underlined: Comparison 29]:; sensitivity 84.35% (291/345); specificity 85.71% (132/154); PPV 92.97% (291/313); NPV 70.97% (132/186); accuracy 84.77% (423/499); prevalence 69.14% (345/499); LR+: 5.90; LR-: .20; - [underlined: Comparison 30]:; sensitivity 9.28% (32/345); specificity 85.06% (131/154); PPV 58.18% (32/55); NPV 29.50% (131/444); accuracy 32.67% (163/499); prevalence 69.14% (345/499); LR+: .60; LR-: 1.10
| [underlined: Examiner(s)]; - pneumatic otoscopy: otolaryngologist in Tampere or pediatrician in Oulu; - myringotomy (only peformed when MEE suspected by pneumatic otoscopy): not specified | [underlined: Affiliation]: Dept. of Clinical Sciences, Univ. of Tampere, Finland; National Public Health Institute, Helsinki, Finland
| *OME definition:MEE present without other symptoms/signs of acute infection. | [underlined: Inclusion]:; - Age: 0.5–2.5 years; - had any ear-related problem or suspicion of them and were brought to either the outpatient clinic in Tampere or Oulu
| Grp 1: Children seen by otolaryngologist in Tampere, Finland | [underlined: Exclusion]:; - tympanostomy tubes in one or both ears at a visit; - incomplete data
| Grp 2: Children seen by pediatrician in Oulu, Finland | [underlined: Patient Characteristics]:; - Grp 1 age range 6–11 months 37%, 12–17 m 41%, 18–23 m 18%, 24–29 m 4%, 30–31 m 0.1%; Grp 2 age range 6–11 m 36%, 12–17 m 38%, 18–23 m 20%, 24–29 m 6%, 30–31 m 0.2%
| N=2911 subjects, 11804 visits
| N1=1688 subjects, 5949 visits
| N2=1223 subjects, 5855 visits
1646 Kemaloglu 1999 | Diagnostic study | [underlined: Time]: followed for 3 months (actual dates not specified) | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 3 (111000) | [underlined: Place]: Not specified | [underlined: Comparisons]:; 1. Grps 1 & 2; Professional tympanometry; Dx- : A or C tracing on tympanogram; Dx+ : B tracing on tympanogram Tympanocentesis (sedation unknown); GS- : fluid absent GS+ : fluid present; 2. Grps 1 & 2; Acoustic reflectometry; Dx- : Reflectivity < 5; Dx+ : Reflectivity ≥ 5; Tympanocentesis (sedation unknown); GS- : fluid absent; GS+ : fluid present; 3. Grps 1 & 2; Acoustic reflectometry; Dx- : Curve angle > 75 degrees; Dx+ : Curve angle ≤ 75 degrees; Tympanocentesis (sedation unknown); GS- : fluid absent; GS+ : fluid present; 4. Grps 1 & 2; Acoustic reflectometry; Dx- : Curve angle > 90 degrees; Dx+ : Curve angle ≤ 90 degrees; Tympanocentesis (sedation unknown); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 96.00% (144/150); specificity 92.00% (138/150); PPV 92.31% (144/156); NPV 95.83% (138/144); accuracy 94.00% (282/300); prevalence 50.00% (150/300); - [underlined: Comparison 2]:; sensitivity 65.33% (98/150); specificity 99.33% (149/150); PPV 98.99% (98/99); NPV 74.13% (149/201); accuracy 82.33% (247/300); prevalence 50.00% (150/300); - [underlined: Comparison 3]:; sensitivity 78.00% (117/150); specificity 99.33% (149/150); PPV 99.15% (117/118); NPV 81.87% (149/182); accuracy 88.67% (266/300); prevalence 50.00% (150/300); - [underlined: Comparison 4]:; sensitivity 97.33% (146/150); specificity 85.33% (128/150); PPV 86.90% (146/168); NPV 96.97% (128/132; accuracy 91.33% (274/300); prevalence 50.00% (150/300)
| [underlined: Examiner(s):]; - otoscopy and pneumatic otoscopy: the first author; - tympanometry (AZ7 electroacoustic impedancemeter [Interacoustics]): not specified; - acoustic reflectometry (acoustic otoscope [ENT Medical Devices]); - paracentesis: not specified | [underlined: Affiliation]: Dept. of ENT, Faculty of Medicine, Gazi Univ., Ankara, Turkey
| *Potential problem - only children with OME underwent paracentesis which was how the condition was diagnosed. The children without OME (controls) were diagnosed clinically, i.e., they did not undergo paracentesis. | [underlined: Inclusion:]; - Grp 1-ears presented retracted TM in stage II or III with vascularization & dullness lasting for at least 3 months (effusion detected on paracentesis.); - Grp 2-free of any ENT problem during follow-up of 3 mos.
| Grp 1: Ears with serous otitis media | [underlined: Exclusion:]; - Grp 1-ears with tympanosclerosis or pseudomembrane of the TM and those with adhesive OM; - Grp 1-subjects with recurrent otitis media who presented normal TM between intervals of AOM)
| Grp 2: Normal Ears (age matched children who were free of any ENT problem during 3 month follow-up) | [underlined: Patient Characteristics]:; - Grp 1 mean age 6.17 years; Grp 2 mean age 6.42 years
| N=156 subjects, 300 ears
| N1=81 subjects, 150 ears
| N2=75 subjects, 150 ears
1650 Kennedy 1982 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place]: Not specified | [underlined: Comparisons]:; 1. Professional tympanometry; Dx- : Normal tympanogram; Dx+ : Flat, rollover, or peaked negative pressure tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Professional tympanometry; Dx- : Normal, rollover, or peaked, or negative pressure tympanogram; Dx+: Flat, only; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 100.00% (51/51); specificity 45.83% (11/24); PPV 79.69% (51/64); NPV 100.00% (11/11); accuracy 82.67% (62/75); prevalence 68.00% (51/75); - [underlined: Comparison 2]:; sensitivity 86.27% (44/51); specificity 87.50% (21/24); PPV 93.62% (44/47); NPV 75.00% (21/28); accuracy 86.67% (65/75); prevalence 68.00% (51/75)
| [underlined: Examiner(s):]; - tympanometry (Madsen Z76): audiologist; - myringotomy: not specified | [underlined: Affiliation]: Dept. of Otolaryngology, Geisinger Medical Clinic, Danville, PA
| [underlined: Study Cohort]: Myringotomy or myringtomy with tubes performed on 75 ears suspected of having OME | [underlined: Inclusion:]; - Ages: 9 months – 13 years; - chronic or recurrent OME
| N=75 ears | [underlined: Exclusion]: None
| * number of subjects not specified | [underlined: Patient Characteristics]: Not specified
1685 Koivunen 1997 | Diagnostic study | [underlined: Time]: Grp 1-8/1992–1/1993; Grp 2~two time periods during 1994 and 1995 (months not specified) | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 3 (110001) | [underlined: Place]: Oulu, Finland | [underlined: Comparisons]:; 1. Portable tympanometers^a^; Dx-: Type A and C tympanograms; Dx+:Type B tympanograms; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Portable tympanometer^b^; Dx- : Type A and C tympanograms; Dx+:Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Portable tympanometer^c^; Dx- : Type A and C tympanograms; Dx+:Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 4. Age: <24 months; Portable tympanometer^a^; Dx- : Type A and C tympanograms; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 5. A[underlined: g]e: >=24 months; Portable tympanometer^a^; Dx- : Type A and C tympanograms; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 80.77% (42/52); specificity 92.97% (119/128); PPV 82.35% (42/51); NPV 92.25% (119/129); accuracy 89.44% (161/180); prevalence 28.89% (52/180); - [underlined: Comparison 2]:; sensitivity 71.43% (10/14); specificity 38.30% (18/47); PPV 25.64% (10/39); NPV 81.82% (18/22); accuracy 45.90% (28/61); prevalence 22.95% (14/61); - [underlined: Comparison 3]:; sensitivity 78.79% (52/66); specificity 78.29% (137/175); PPV 57.78% (52/90); NPV 90.73% (137/151); accuracy 78.42% (189/241); prevalence 27.39% (66/241); - [underlined: Comparison 4]:; sensitivity 78.00%; specificity 91.00%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown; - [underlined: Comparison 5]:; sensitivity 79.00%; specificity 94.00%; PPV unknown; NPV unknown; accuracy unknown; prevalence unknown
| [underlined: Examiner(s):]; - tympanometry (MicroTymp [Welch Allyn]): a trained nurse; - myringotomy: operating surgeon | [underlined: Affiliation]: Depts. of Otolaryngology and Pediatrics, University of Oulu, Finland
| *Article does not state when the tympanogram was performed in relation to the myringotomy, thus it is not clear whether this study fits the criterion of the diagnostic test being performed ≤ 24hrs before myringotomy | [underlined: Inclusion:]; - referred for adenoidectomy, tympanostomy tube placement, or both procedures in the Dept. of Otolaryngology, in two time periods during 1994–95
| [underlined: Study Cohort]: Children referred for adenoidectomy, tympanostomy tube placement, or both procedures for recurrent otitis media or glue ear | [underlined: Exclusion:]; - perforation or presence of tympanostomy tubes
| *(another group of children were studied but findings were not relevant to key question four) | [underlined: Patient Characteristics]:; - mean age 4.7 years, range 1 month-16 years; Grp 2 median age 34 months, range 7 months-8 years; - male 130, female 76
| N=162 subjects, 314 ears
1785 Lovette 1976 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 2 (100001) | [underlined: Place]: | [underlined: Comparisons]:; 1. Dx- : Admittance ≥ 0.25 mmhos; Dx+ : Admittance < 0.25 mmhos; Myringotomy (sedation unknown); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 90.00% (27/30); specificity 58.33% (7/12); PPV 84.38% (27/32); NPV 70.00% (7/10); accuracy 80.95% (34/42); prevalence 71.43% (30/42)
| [underlined: Examiner(s):]; - tympanometry (Model 1720 [Grason-Stadler]): nearly half by a third-year medical student; - myringotomy: not specified | [underlined: Affiliation]: Tufts Univ., School of Engineering, Boston, MA; Dept. of Otolaryngology, Children's Hospital of Pittsburgh, PA
| [underlined: Study Cohort]: children involved in study to assess accuracy of detecting MEE by otoscopic tympanometric data alone | [underlined: Inclusion]:; - Age: Not specified; - recurrent AOM or persistent MEE, or both; - candidates for myringotomy and tympanostomy tube insertion
| *(another study was reported but findings were not relevant to key question four) | [underlined: Exclusion]: None
| N=21 subjects, 42 ears | Patient Characteristics: Not Specified
1804 Macknin 1987 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear (comparison specific)
| [underlined: Study Quality Score (0–6)]: 4 (111001) | [underlined: Place]: Not specified | [underlined: Comparisons]:; 1. Acoustic reflectometry^a^; Dx- : Zero reflectivity units (RU); Dx+ : ≥ 1RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Acoustic reflectometry^a^; Dx- : Zero reflectivity units (RU); Dx+ : ≥ 1 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Acoustic reflectometry^a^; Dx- : < 2 reflectivity units (RU); Dx+ : ≥ 2 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 4. Acoustic reflectometry^a^; Dx- : < 2 reflectivity units (RU); Dx+ : ≥ 2 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 5. Acoustic reflectometry^a^; Dx- : < 3 reflectivity units (RU); Dx+ : ≥ 3 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 6. Acoustic reflectometry^a^; Dx- : < 3 reflectivity units (RU); Dx+ : ≥ 3 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 7. Acoustic reflectometry^a^; Dx- : < 4 reflectivity units (RU); Dx+ : ≥ 4 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 8. Acoustic reflectometry^a^; Dx- : < 4 reflectivity units (RU); Dx+ : ≥ 4 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 9. Acoustic reflectometry^a^; Dx- : < 5 reflectivity units (RU); Dx+ : ≥ 5 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 10. Acoustic reflectometry^a^; Dx- : < 5 reflectivity units (RU); Dx+ : ≥ 5 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 11. Acoustic reflectometry^a^; Dx- : < 6 reflectivity units (RU); Dx+ : ≥ 6 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 12. Acoustic reflectometry^a^; Dx- : < 6 reflectivity units (RU); Dx+ : ≥ 6 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 13. Acoustic reflectometry^a^; Dx- : < 7 reflectivity units (RU); Dx+ : ≥ 7 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 14. Acoustic reflectometry^a^; Dx- : < 7 reflectivity units (RU); Dx+ : ≥ 7 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 15. Acoustic reflectometry^a^; Dx- : < 8 reflectivity units (RU); Dx+ : ≥ 8 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 16. Acoustic reflectometry^a^; Dx- : < 8 reflectivity units (RU); Dx+ : ≥ 8 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 17. Acoustic reflectometry^a^; Dx- : < 9 reflectivity units (RU); Dx+ : ≥ 9 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 18. Acoustic reflectometry^a^; Dx- : < 9 reflectivity units (RU); Dx+ : ≥ 9 RU; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; [underlined: Unit of measure]: right ear; sensitivity 98.51% (66/67); specificity 0.00% (0/33); PPV 66.67% (66/99); NPV 0.00% (0/1); accuracy 66.00% (66/100); prevalence 67.00% (67/100); - [underlined: Comparison 2]:; [underlined: Unit of measure]: left ear; sensitivity 98.36% (60/61); specificity 2.70% (1/37); PPV 62.50% (60/96); NPV 50.00% (1/2); accuracy 62.24% (61/98); prevalence 62.24% (61/98); - [underlined: Comparison 3]:; [underlined: Unit of measure]: right ear; sensitivity 97.01% (65/67); specificity 12.12% (4/33); PPV 69.15% (65/94); NPV 66.67% (4/6); accuracy 69.00% (69/100); prevalence 67.00% (67/100); - [underlined: Comparison 4]:; [underlined: Unit of measure]: left ear; sensitivity 90.16% (55/61); specificity 5.41% (2/37); PPV 61.11% (55/90); NPV 25.00% (2/8); accuracy 58.16% (57/98); prevalence 62.24% (61/98); [underlined: Unit of measure]: Ear (comparison specific); - [underlined: Comparison 5]:; [underlined: Unit of measure]: right ear; sensitivity 89.55% (60/67); specificity 18.18% (6/33); PPV 68.97% (60/87); NPV 46.15% (6/13); accuracy 66.00% (66/100); prevalence 67.00% (67/100); - [underlined: Comparison 6]:; [underlined: Unit of measure]: left ear; sensitivity 80.33% (49/61); specificity 21.62% (8/37); PPV 62.82% (49/78); NPV 40.00% (8/20); accuracy 58.16% (57/98); prevalence 62.24% (61/98); - [underlined: Comparison 7]:; [underlined: Unit of measure]: right ear; sensitivity 82.09% (55/67); specificity 36.36% (12/33); PPV 72.37% (55/76); NPV 50.00% (12/24); accuracy 67.00% (67/100); prevalence 67.00% (67/100); - [underlined: Comparison 8]:; [underlined: Unit of measure]: left ear; sensitivity 70.49% (43/61); specificity 48.65% (18/37); PPV 69.35% (43/62); NPV 50.00% (18/36); accuracy 62.24% (61/98); prevalence 62.24% (61/98); [underlined: Unit of measure]: Ear (comparison specific); - [underlined: Comparison 9]: right ear; sensitivity 76.12% (51/67); specificity 60.61% (20/33); PPV 76.69% (51/64); NPV 55.56% (20/36); accuracy 71.00% (71/100); prevalence 67.00% (67/100); - [underlined: Comparison 10]: left ear; sensitivity 54.10% (33/61); specificity 62.16% (23/37); PPV 70.21% (33/47); NPV 45.10% (23/51); accuracy 57.14% (56/98); prevalence 62.24% (61/98); - [underlined: Comparison 11]: right ear; sensitivity 59.70% (40/67); specificity 72.73% (24/33); PPV 81.63% (40/49); NPV 47.06% (24/51); accuracy 64.00% (64/100); prevalence 67.00% (67/100); [underlined: Unit of measure]: Ear (comparison specific); - [underlined: Comparison 12]: left ear; sensitivity 36.07% (22/61); specificity 91.89% (34/37); PPV 88.00% (22/25); NPV 46.58% (34/73); accuracy 57.14% (56/98); prevalence 62.24% (61/98); - [underlined: Comparison 13]: right ear; sensitivity 47.76% (32/67); specificity 90.91% (30/33); PPV 91.43% (32/35); NPV 46.15% (30/65); accuracy 62.00% (62/100); prevalence 67.00% (67/100); - [underlined: Comparison 14]: left ear; sensitivity 26.23% (16/61); specificity 97.30% (36/37); PPV 94.12% (16/17); NPV 44.44% (36/81); accuracy 53.06% (52/98); prevalence 62.24% (61/98); - [underlined: Comparison 15]: right ear; sensitivity 17.91% (12/67); specificity 93.94% (31/33); PPV 85.71% (12/14); NPV 36.05% (31/86); accuracy 43.00% (43/100); prevalence 67.00% (67/100); [underlined: Unit of measure]: Ear (comparison specific); - [underlined: Comparison 16:] left ear; sensitivity 3.28% (2/61); specificity 100.00% (37/37); PPV 100.00% (2/2); NPV 38.54% (37/96); accuracy 39.80% (39/98); prevalence 62.24% (61/98); - [underlined: Comparison 17]: right ear; sensitivity 1.50% (1/67); specificity 100.00% (33/33); PPV 100.00% (1/1); NPV 33.33% (33/99); accuracy 34.00% (34/100); prevalence 67.00% (67/100); - [underlined: Comparison 18]: left ear; sensitivity 0.00% (0/61); specificity 100.00% (37/37); PPV ------ (0/0); NPV 37.76% (37/98); accuracy 37.76% (37/98); prevalence 62.24% (61/98)
| [underlined: Examiner(s):]; - acoustic reflectometry: pediatrician; - myringotomy: one of the staff otologists | [underlined: Affiliation]: Dept. of Pediatric and Adolescent Medicine and Dept. of Otolaryngology and Communicative Disorders, The Cleveland Clinic Foundation, Cleveland, OH
| *This study was done on children with recurrent otitis media; they do not state whether this means recurrent OME or AOM. | [underlined: Inclusion:]; - Age: 1–11 years (one 16 year old female); - underwent myringotomy and tympanostomy tube placement for recurrent OM and had reflectometry performed
| [underlined: Study Cohort]: Children who underwent myringotomy and tympanostomy tube placement for recurrent OM and who had reflectometry performed | [underlined: Exclusion]: None
| N=100 subjects, 198 ears | [underlined: Patient Characteristics:]; - mean age male 3.5 yrs and female 5.6 yrs, range 1–11 yrs except one 16 yr old; - male 70, female 30
1817 Mains 1989 | Diagnostic study | [underlined: Time]: Patients entered study during a consecutive 5 month period (actual dates not specified) | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place]: Belfast City Hospital | [underlined: Comparisons]:; - Examiner type : Oberver^a^; Pneumatic otoscopy - unvalidated examiner; Dx- : TM mobile; Dx+ : TM immobile; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Examiner type: Observer^a^; Pneumatic otoscopy - unvalidated examiner; Dx- : TM mobile; Dx+ : TM immobile; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 87.93% (102/116); specificity 90.32% (84/93); PPV 91.89% (102/111); NPV 85.71% (84/98); accuracy 89.00% (186/209); prevalence 55.50% (116/209); [underlined: Comparison 2]:; sensitivity 84.48% (98/116); specificity 87.10% (81/93); PPV 89.09% (98/110); NPV 81.82% (81/99); accuracy 85.65% (179/209); prevalence 55.50% (116/209)
| [underlined: Examiner(s):]; - pneumatic otoscopy: a senior registrar and a senior house officer; - myringotomy: not specified | [underlined: Affiliation]: Not specified
| [underlined: Study Cohort]: Children admitted to Belfast City Hospital for myringotomy during a consecutive 5 month period | [underlined: Inclusion]:; - admitted for myringotomy to the Belfast City Hospital during a 5-month period
| N=114 subjects, 209 ears | [underlined: Exclusion]: None
| | [underlined: Patient Characteristics:]; - age range 20 months-12 years; - surgery indication primarily persistent middle ear effusion
1837 Marchant 1986 | Diagnostic study | [underlined: Time]: not specified | [underlined: Comparisons]:; 1. Professional tympanometry; Dx- : Peak susceptance > 0 mmho; Dx+ : Peak susceptance ≤ 0; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; 2. Professional tympanometry; Dx- : Ipsilateral acoustic reflex threshold ≤ 100 dB HL; Dx+ : Ipsilateral acoustic reflex threshold absent or > 110 dB HL; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 2 (100001) | [underlined: Place]: Pediatric Outpatient Clinic at Cleveland Metropolitan General Hospital | | - [underlined: Comparison 1] ^a^ :; sensitivity 94.29% (33/35); specificity^a^ 100.00% (3/3); PPV 100.00% (33/33); NPV 60.00% (3/5); accuracy 94.74% (36/38); prevalence 92.11% (35/38); - [underlined: Comparison 2] ^a^ :; sensitivity 97.14% (34/35); specificity 66.67% (2/3); PPV 97.14% (34/35); NPV 66.67% (2/3); accuracy 94.74% (36/38); prevalence 92.11% (35/38)
| [underlined: Examiner(s):]; - pneumatic otoscope: one of two experienced otoscopists; - tympanometry (otoadmittance meter, model 1723 version II [Grason-Stadler]): not specified; - tympanocentesis: not specified | [underlined: Affiliation]: Dept's of Pediatrics and Communication Services, Case Western Reserve University, OH; Division of Communication Disorders, Cleveland Metropolitan General Hospital, OH
| *Tympanocentesis was only performed on 21 out of 73 infants. These are the only infants where a gold standard diagnostic procedure was performed. Select group where MD felt OM+ and child would benefit from knowing bug. | [underlined: Inclusion:]; - Age: <5 months (all infants were 2–18 weeks of age); - attending well-child visit or otitis media was suspected after otoscopic examination by primary physician or nurse practitioner
| [underlined: Study Cohort] : Infants 2–18 weeks old who underwent tympanocentesis | [underlined: Exclusion]: None
| *(Study Cohort was derived from an overall sample of 73 infants) | [underlined: Patient Characteristics:]; - age range 2–18 weeks
| N=21 subjects, 38 ears
1936 Mitchell 1990 | Diagnostic study | [underlined: Time]: Three-month period (actual dates not specified) | [underlined: Comparisons]:; 1. Professional tympanometry; Dx- : Type A or C tympanogram; Dx+ : Type B tympanogram; Myringotomy (sedation unknown); GS- : fluid absent; GS+ : fluid present; 2. Acoustic reflectometry; Dx- : AR value ≤ 2; Dx+ : AR value > 2; Myringotomy (sedation unknown); GS- : fluid absent; GS+ : fluid present; 3. Audiometry - air conduction threshold; Dx- : Hearing threshold < 20dB; Dx+ : Hearing threshold ≥ 20dB; Myringotomy (sedation unknown); GS- : fluid absent; GS+ : fluid present | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place]: Not specified | | - [underlined: Comparison 1]:; sensitivity 87.69% (57/65); specificity 52.63% (10/19); PPV 86.36% (57/66); NPV 55.56% (10/18); accuracy 79.76% (67/84); prevalence 77.38% (65/84); - [underlined: Comparison 2]:; sensitivity 87.32% (62/71); specificity 59.26% (16/27); PPV 84.93% (62/73); NPV 64.00% (16/25); accuracy 79.59% (78/98); prevalence 72.45% (71/98); - [underlined: Comparison 3]:; sensitivity 80.39% (41/51); specificity 68.75% (11/16); PPV 89.13% (41/46); NPV 52.38% (11/21); accuracy 77.61% (52/67); prevalence 76.12% (51/67)
| [underlined: Examiner(s)]: Unknown; - tympanometry (Interacoustics AZ7 tympanometer [PCWerth]):; - acoustic reflectometry (Acoustic otoscope [Endeco Medical]):; - audiometry (Kamplex AC4 audiometer):; - myringotomy: | [underlined: Affiliation]: Dept. of Otolaryngology, St. Thomas' Hospital, London
| [underlined: Study Cohort]: Children with suspected glue ear were studied over a three-month period pure tone audiometry, tympanometry and acoustic reflectometry were attempted on each ear] | [underlined: Inclusion:]; - Age: 6 months-14 yrs; - suspected glue ear
| N=50 subjects, 100 ears | [underlined: Exclusion]: None
| | [underlined: Patient Characteristics]:; - age range 6 months14 years
2012 Nozza 1992 | Diagnostic study | [underlined: Time]: not specified | | Unit of measure: Ear
| [underlined: Study Quality Score (0–6)]: 4 (111001) | [underlined: Place]: Grp 1 Same-Day Surgery Unit of Children's Hospital of Pittsburgh, PA; Grp 2 children coming to outpatient allergy clinic | 1. Grp 1^a^; Professional tympanometry (AR alone); Dx- : acoustic reflex present; Dx+ : acoustic reflex absent; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Grp 1^a^; Professional tympanometry; Dx- : Pressure gradient >0.1; Dx+ : Pressure gradient ≤0.1; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Grp 1^a^; Professional tympanometry; Dx- : Pressure gradient >0.2; Dx+ : Pressure gradient ≤0.2; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 4. Grp 1^a^; Professional tympanometry; Dx- : Peak compensated admittance >0.1; Dx+ : Peak compensated admittance ≤0.1; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 5. Grp 1^a^; Professional tympanometry; Dx- : Peak compensated admittance > 0.2; Dx+ : Peak compensated admittance ≤ 0.2; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 6. Grp 1^a^; Professional tympanometry; Dx- : Peak compensated admittance > 0.3; Dx+ : Peak compensated admittance ≤ 0.3; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 7. Grp 1^a^; Professional tympanometry; Dx- : Peak compensated admittance > 0.4; Dx+ : Peak compensated admittance ≤ 0.4; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 8. Grp 2^a^; Professional tympanometry; Dx- : acoustic reflex present; Dx+ : acoustic reflex absent; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; 9. Grp 2^a^; Professional tympanometry; Dx- : Pressure gradient >0.1; Dx+ : Pressure gradient ≤ 0.1; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; 10. Grp 2^a^; Professional tympanometry; Dx- : Pressure gradient >0.2; Dx+ : Pressure gradient ≤ 0.2; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; 11. Grp 2^a^; Professional tympanometry; Dx- : Peak compensated admittance > 0.1; Dx+ : Peak compensated admittance ≤ 0.1; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; 12. Grp 2^a^; Professional tympanometry; Dx- : Peak compensated admittance > 0.2; Dx+ : Peak compensated admittance ≤ 0.2; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; 13. Grp 2^a^; Professional tympanometry; Dx- : Peak compensated admittance > 0.3; Dx+ : Peak compensated admittance ≤ 0.3; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; 14. Grp 2^a^; Professional tympanometry; Dx- : Peak compensated admittance > 0.4; Dx+ : Peak compensated admittance ≤ 0.4; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present | - [underlined: Comparison 1]:; sensitivity 88.16% (67/76); specificity 85.19% (23/27); PPV 94.37% (67/71); NPV 71.88% (23/32); accuracy 87.38% (90/103); prevalence 73.79% (76/103); - [underlined: Comparison 2]:; sensitivity 77.78% (63/81); specificity 90.00% (27/30); PPV 95.45% (63/66); NPV 60.00% (27/45); accuracy 81.08% (90/111); prevalence 72.97% (81/111); - [underlined: Comparison 3]:; sensitivity 91.36% (74/81); specificity 70.00% (21/30); PPV 89.16% (74/83); NPV 75.00% (21/28); accuracy 85.59% (95/111); prevalence 72.97% (81/111); - [underlined: Comparison 4]:; sensitivity 30.86% (25/81); specificity 96.67% (29/30); PPV 96.15% (25/26); NPV 34.12% (29/85); accuracy 48.65% (54/111); prevalence 72.97% (81/111); - [underlined: Comparison 5]:; sensitivity 55.56% (45/81); specificity 93.33% (28/30); PPV 95.74% (45/47); NPV 43.75% (28/64); accuracy 65.77% (73/111); prevalence 72.97% (81/111); - [underlined: Comparison 6]:; sensitivity 72.84% (59/81); specificity 80.00% (24/30); PPV 90.77% (59/65); NPV 52.17% (24/46); accuracy 74.77% (83/111); prevalence 72.97% (81/111); - [underlined: Comparison 7]:; sensitivity 81.48% (66/81); specificity 63.33% (19/30); PPV 85.71% (66/77); NPV 55.88% (19/34); accuracy 76.58% (85/111); prevalence 72.97% (81/111); - [underlined: Comparison 8]:; sensitivity 87.50% (7/8); specificity 81.98% (91/111); PPV 25.93% (7/27); NPV 98.91% (91/92); accuracy 82.35% (98/119); prevalence 6.72% (8/119); - [underlined: Comparison 9]:; sensitivity 67.67% (6/9); specificity 100.00% (135/135); PPV 100.00% (6/6); NPV 97.83% (135/138); accuracy 97.92% (141/144); prevalence 6.25% (9/144); - [underlined: Comparison 10]:; sensitivity 77.78% (7/9); specificity 99.26% (134/135); PPV 87.50% (7/8); NPV 98.53% (134/136); accuracy 97.92% (141/144); prevalence 6.25% (9/144); - [underlined: Comparison 11]:; sensitivity 67.67% (6/9); specificity 100.00% (135/135); PPV 100.00% (6/6); NPV 97.83% (135/138); accuracy 97.92% (141/144); prevalence 6.25% (9/144); - [underlined: Comparison 12]:; sensitivity 77.78% (7/9); specificity 100.00% (135/135); PPV 100.00% (7/7); NPV 98.54% (135/137); accuracy 98.61% (142/144); prevalence 6.25% (9/144); - [underlined: Comparison 13]:; sensitivity 77.78% (7/9); specificity 97.78% (132/135); PPV 70.00% (7/10); NPV 98.51% (132/134); accuracy 96.53% (139/144); prevalence 6.25% (9/144); - [underlined: Comparison 14]:; sensitivity 77.78% (7/9); specificity 88.89% (120/135); PPV 31.82% (7/22); NPV 98.36% (120/122); accuracy 88.19% (127/144); prevalence 6.25% (9/144)
| [underlined: Examiner(s):]; - tympanometry (GSI-33 Version I Middle Ear Analyzer “Grason-Stadler”, 226 Hz probe tone): Grp 1 audiologist; Grp 2 nurse; - myringotomy: surgeon; - pneumatic otoscopy: nurse otoscopist validated at sensitivity and specificity >85% | [underlined: Affiliation]: Children's Hospital of Pittsburgh, PA; Dept.'s of Otolaryngology and Biostatistics, Univ. of Pittsburgh, PA
| *This article includes 2 different studies: (1) examines tympanometry vs. myringotomy and the second examines validated pneumatic otoscopy vs. tympanometry; (2) represents the “general population.” | [underlined: Inclusion:]; - Age: Grp 1 1–8 years; - Grp 1~undergoing myringotomy and tube surgery for treatment of chronic or recurrent OM; - Grp 2~hospital outpatients who were unscreened with respect to history of middle ear disease (more representative of children in general population)
| Grp 1: Ears in children undergoing myringotomy and tube surgery for treatment of chronic or recurrent OM | [underlined: Exclusion]: None
| Grp 2: Norms~Ears in children who were hospital outpatients and unscreened with respect to history of middle ear disease | [underlined: Patient Characteristics:]; - Grp 1 age range 1–8 years; Grp 2 mean age 9 years, range 3–16 years
| N=138 subjects, 171 ears
| N1=61 subjects, 111 ears
| N2=77 subjects, 144 ears
2013 Nozza 1994 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear (comp. 1–40)
| [underlined: Study Quality Score (0–6)]: 4 (111001) | [underlined: Place]: Grp 1~Same-Day Surgery Unit of Children's Hospital of Pittsburgh, PA | | [underlined: Unit of measure: Subject (comp. 41–43)]
| [underlined: Examiner(s):] | [underlined: Affiliation]: Children's Hospital of Pittsburgh, PA; Dept's of Otolaryngology and Biostatistics, Univ. of Pittsburgh, PA | [underlined: Comparisons:]
| - tympanometry (GSI-33 Version I Middle Ear Analyzer [Grason-Stadler], 226 Hz probe tone): clinically certified and licensed audiologist; - pneumatic otoscopy: Pediatric Nurse Practitioner validated at sensitivity 85% and specificity 71%; - myringotomy: several surgeons | [underlined: Inclusion:] | 1. 1. Grp 1; Diagnostic Method: unknown; Dx-: Tympanometric gradient >0.2; Dx+: Tympanometric gradient ≤0.2; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 2. 2. Grp 1; Diagnostic Method: unknown; Dx-: Tymp. Width ≤250 daPa; Dx+: Tymp. Width >250 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 3. 3. Grp 1^a^; Pneumatic otoscopy - validated examiner; Dx-: MEE absent; Dx+: MEE present; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 4. 4. Grp 1; Professional tympanometry; Dx-: Acoustic reflex present; Dx+: Acoustic reflex absent; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 5. 5. Grp 1; Professional tympanometry; Dx-: tympanometric gradient >0; Dx+: tympanometric gradient ≤ 0; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 6. 6. Grp 1; Professional tympanometry; Dx-: tympanometric gradient >.1; Dx+: tympanometric gradient ≤ 0.1; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 7. 7. Grp 1; Professional tympanometry; Dx-: tympanometric gradient >0.3; Dx+: tympanometric gradient ≤0.3; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 8. 8. Grp 1; Professional tympanometry; Dx-: Peak admittance > 0; Dx+: Peak admittance ≤ 0; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 9. 9. Grp 1; Professional tympanometry; Dx-: Peak admittance >0.1; Dx+: Peak admittance ≤0.1; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 10. 10. Grp 1; Professional tympanometry; Dx-: Peak admittance >0.2; Dx+: Peak admittance ≤0.2; Myr ingotomy (sedated); GS-: fluid absent; GS+: fluid present; 11. 11. Grp 1; Professional tympanometry; Dx-: Peak admittance >0.3; Dx+: Peak admittance ≤0.3; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 12. 12. Grp 1; Professional tympanometry; Dx-: Peak admittance >0.4; Dx+: Peak admittance ≤0.4; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 13. 17. Grp 1; Professional tympanometry; Dx-: tympanometric Width ≤300 daPa; Dx+: tympanometric Width >300daPa; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 14. 18. Grp 1; Professional tympanometry; Dx-: tympanometric Width ≤325 daPa; Dx+: tympanometric Width >325 daPa; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 15. 19. Grp 1; Professional tympanometry; Dx-: tympanometric Width ≤350 daPa; Dx+: tympanometric Width >350 daPa; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 16. 20. Grp 1; Professional tympanometry; Dx-: tympanometric Width ≤400 daPa; Dx+: tympanometric Width >400 daPa; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 17. 21. Grp 1; Professional tympanometry; Dx-: Acoustic reflex present; Dx+: Acoustic reflex absent; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 18. 22. Grp 1; Professional tympanometry; Dx-: Tympanometric gradient >0; Dx+: Tympanometric gradient ≤0; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 19. 23. Grp 1; Professional tympanometry; Dx-: Tympanometric gradient >0.1; Dx+: Tympanometric gradient ≤0.1; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 20. 24. Grp 1; Professional tympanometry; Dx-: Tympanometric gradient >0.2; Dx+: Tympanometric gradient ≤0.2; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 21. 25. Grp 1; Professional tympanometry; Dx-: Tympanometric gradient >0.3; Dx+: Tympanometric gradient ≤0.3; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 22. 26. Grp 1; Professional tympanometry; Dx-: Peak admittance >0; Dx+: Peak admittance ≤0; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 23. 27. Grp 1; Professional tympanometry; Dx-: Peak admittance > 0.1; Dx+: Peak admittance ≤0.1; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 24. 28. Grp 1; Professional tympanometry; Dx-: Peak admittance >0.2; Dx+: Peak admittance ≤0.2; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 25. 29. Grp 1; Professional tympanometry; Dx-: Peak admittance >0.3; Dx+: Peak admittance ≤0.3; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 26. 30. Grp 1; Professional tympanometry; Dx-: Peak admittance >0.4; Dx+: Peak admittance ≤0.4; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 27. 31. Grp 1; Professional tympanometry; Dx-: Tympanometric Width ≤150 daPa; Dx+: Tympanometric Width >150 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 28. 32. Grp 1; Professional tympanometry; Dx-: Tympanometric Width ≤200 daPa; Dx+: Tympanometric Width >200 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 29. 33. Grp 1; Professional tympanometry; Dx-: Tymp. Width ≤225 daPa; Dx+: Tymp. Width >225 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 30. 34. Grp 1; Professional tympanometry; Dx-: Tymp. Width ≤275 daPa; Dx+: Tymp. Width >275 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 31. 35. Grp 1; Professional tympanometry; Dx-: Tymp. Width ≤300 daPa; Dx+: Tymp Width >300 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 32. 36. Grp 1; Professional tympanometry; Dx-: Tymp. Width ≤325 daPa; Dx+: Tymp. Width >325 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 33. 37. Grp 1; Professional tympanometry; Dx-: Tymp. Width ≤350 daPa; Dx+: Tymp. Width >350 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 34. 38. Grp 2; Professional tympanometry; Dx-: Tymp. Width ≤150 daPa; Dx+: Tymp. Width >150 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 35. 39. Grp 2; Professional tympanometry; Dx-: Tymp. Width ≤200 daPa; Dx+: Tymp. Width >200 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 36. 40. Grp 2; Professional tympanometry; Dx-: Tymp. Width ≤250 daPa; Dx+: Tymp. Width >250 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 37. 41. Grp 2; Professional tympanometry; Dx-: Tymp. Width ≤150 daPa; Dx+: Tymp. Width >150 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 38. 42. Grp 2; Professional tympanometry; Dx-: Tymp. Width ≤ 200 daPa; Dx+: Tymp. Width >200 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present; 39. 43. Grp 2; Professional tympanometry; Dx-: Tymp. Width ≤250 daPa; Dx+: Tymp. Width >250 daPa; Validated pneumatic otoscopy; GS-: MEE absent; GS+: MEE present | - [underlined: Comparison 1]:; sensitivity 84.67% (116/137); specificity 61.61% (69/112); PPV 72.96% (116/159); NPV 76.67% (69/90); accuracy 74.30% (185/249); prevalence 55.02% (137/249); - [underlined: Comparison 2]:; sensitivity 84.67% (116/137); specificity 73.21% (82/112); PPV 79.45% (116/146); NPV 79.61% (82/103); accuracy 79.52% (198/249); prevalence 55.02% (137/249); - [underlined: Comparison 3]:; sensitivity 84.67% (116/137); specificity 71.43% (80/112); PPV 78.38% (116/148); NPV 79.21% (80/101); accuracy 78.71% (196/249); prevalence 55.02% (137/249); - [underlined: Comparison 4]:; sensitivity 85.48% (106/124); specificity 64.89% (61/94); PPV 76.26% (106/139); NPV 77.22% (61/79); accuracy 76.61% (167/218); prevalence 56.88% (124/218); - [underlined: Comparison 5]:; sensitivity 23.36% (32/137); specificity 98.21% (110/112); PPV 94.12% (32/34); NPV 95.65% (110/115); accuracy 57.03% (142/249); prevalence 55.02% (137/249); - [underlined: Comparison 6]:; sensitivity 65.69% (90/137); specificity 91.07% (102/112); PPV 90.00% (90/100); NPV 68.46% (102/149); accuracy 77.11% (192/249); prevalence 55.02% (137/249); - [underlined: Comparison 7]:; sensitivity 92.70% (127/137); specificity 38.39% (43/112); PPV 64.80% (127/196); NPV 81.13% (43/53); accuracy 68.27% (170/249); prevalence 55.02% (137/249); - [underlined: Comparison 8]:; sensitivity 10.95% (15/137); specificity 98.21% (110/112); PPV 88.24% (15/17); NPV 47.41% (110/232); accuracy 50.20% (125/249); prevalence 55.02% (137/249); - [underlined: Comparison 9]:; sensitivity 27.01% (37/137); specificity 97.32% (109/112); PPV 92.50% (37/40); NPV 52.15% (109/209); accuracy 58.63% (146/249); prevalence 55.02% (137/249); - [underlined: Comparison 10]:; sensitivity 45.99% (63/137); specificity 91.96% (103/112); PPV 87.50% (63/72); NPV 58.19% (103/177); accuracy 66.67% (166/249); prevalence 55.02% (137/249); - [underlined: Comparison 11]:; sensitivity 70.07% (96/137); specificity 80.36% (90/112); PPV 81.36% (96/118); NPV 68.70% (90/131); accuracy 74.70% (186/249); prevalence 55.02% (137/249); - [underlined: Comparison 12]:; sensitivity 83.21% (114/137); specificity 68.75% (77/112); PPV 76.51% (114/149); NPV 77.00% (77/100); accuracy 76.71% (191/249); prevalence 55.02% (137/249); - [underlined: Comparison 17]:; sensitivity 76.64% (105/137); specificity 84.82% (95/112); PPV 86.07% (105/122); NPV 74.80% (95/127); accuracy 80.32% (200/249); prevalence 55.02% (137/249); - [underlined: Comparison 18]:; sensitivity 70.07% (96/137); specificity 88.39% (99/112); PPV 88.07% (96/109); NPV 70.71% (99/140); accuracy 78.31% (195/249); prevalence 55.02% (137/249); - [underlined: Comparison 19]:; sensitivity 61.31% (84/137); specificity 89.29% (100/112); PPV 87.50% (84/96); NPV 65.36% (100/153); accuracy 73.90% (184/249); prevalence 55.02% (137/249); - [underlined: Comparison 20]:; sensitivity 48.91% (67/137); specificity 96.43% (108/112); PPV 94.37% (67/71); NPV 60.67% (108/178); accuracy 70.28% (175/249); prevalence 55.02% (137/249); - [underlined: Comparison 21]:; sensitivity 76.61% (95/124); specificity 76.60% (72/94); PPV 81.20% (95/117); NPV 71.29% (72/101); accuracy 76.61% (167/218); prevalence 56.88% (124/218); - [underlined: Comparison 22]:; sensitivity 23.36% (32/137); specificity 100.00% (112/112); PPV 100.00% (32/32); NPV 95.73% (112/117); accuracy 57.83% (144/249); prevalence 55.02% (137/249); - [underlined: Comparison 23]:; sensitivity 64.23% (88/137); specificity 93.75% (105/112); PPV 92.63% (88/95); NPV 68.18% (105/154); accuracy 77.51% (193/249); prevalence 55.02% (137/249); - [underlined: Comparison 24]:; sensitivity 84.67% (116/137); specificity 65.18% (73/112); PPV 74.84% (116/155); NPV 77.66% (73/94); accuracy 75.90% (189/249)); prevalence 55.02% (137/249); - [underlined: Comparison 25]:; sensitivity 92.70% (127/137); specificity 32.14% (36/112); PPV 62.56% (127/203); NPV 78.26% (36/46); accuracy 65.46% (163/249); prevalence 55.02% (137/249); - [underlined: Comparison 26]:; sensitivity 10.95% (15/137); specificity 100.00% (112/112); PPV 100.00% (15/15); NPV 47.86% (112/234); accuracy 51.00% (127/249); prevalence 55.02% (137/249); - [underlined: Comparison 27]:; sensitivity 26.28% (36/137); specificity 100.00% (112/112); PPV 100.00% (36/36); NPV 99.12% (112/113); accuracy 59.44% (148/249); prevalence 55.02% (137/249); - [underlined: Comparison 28]:; sensitivity 46.72% (64/137); specificity 97.32% (109/112); PPV 95.52% (64/67); NPV 59.89% (109/182); accuracy 69.48% (173/249); prevalence 55.02% (137/249); - [underlined: Comparison 29]:; sensitivity 70.07% (96/137); specificity 84.82% (95/112); PPV 84.96% (96/113); NPV 69.85% (95/136); accuracy 76.71% (191/249); prevalence 55.02% (137/249); - [underlined: Comparison 30]:; sensitivity 76.74% (105/137); specificity 66.07% (74/112); PPV 73.43% (105/143); NPV 69.81% (74/106); accuracy 71.89% (179/249); prevalence 55.02% (137/249); - [underlined: Comparison 31]:; sensitivity 94.89% (130/137); specificity 28.57% (32/112); PPV 61.90% (130/210); NPV 82.05% (32/39); accuracy 65.06% (162/249); prevalence 55.02% (137/249); - [underlined: Comparison 32]:; sensitivity 89.05% (122/137); specificity 50.89% (57/112); PPV 68.93% (122/177); NPV 79.17% (57/72); accuracy 71.89% (179/249); prevalence 55.02% (137/249); - [underlined: Comparison 33]:; sensitivity 86.13% (118/137); specificity 61.61% (69/112); PPV 73.29% (118/161); NPV 78.41% (69/88); accuracy 75.10% (187/249); prevalence 55.02% (137/249); - [underlined: Comparison 34]:; sensitivity 78.83% (108/137); specificity 85.71% (96/112); PPV 87.10% (108/124); NPV 76.80% (96/125); accuracy 81.93% (204/249); prevalence 55.02% (137/249); - [underlined: Comparison 35]:; sensitivity 78.83% (103/137); specificity 86.61% (97/112); PPV 87.29% (103/118); NPV 74.05% (97/131); accuracy 80.32% (200/249); prevalence 55.02% (137/249); - [underlined: Comparison 36]:; sensitivity 70.07% (96/137); specificity 93.75% (105/112); PPV 93.20% (96/103); NPV 71.92% (105/146); accuracy 80.72% (201/249); prevalence 55.02% (137/249); - [underlined: Comparison 37]:; sensitivity 62.04% (85/137); specificity 94.64% (106/112); PPV 93.41% (85/91); NPV 67.09% (106/158); accuracy 76.71% (191/249); prevalence 55.02% (137/249); - [underlined: Comparison 38]:; sensitivity 88.89% (8/9); specificity 91.97% (126/137); PPV 47.06% (8/17); NPV 99.21% (126/127); accuracy 93.06% (134/144); prevalence 6.25% (9/144); - [underlined: Comparison 39]:; sensitivity 77.78% (7/9); specificity 99.26% (134/135); PPV 87.50% (7/8); NPV 98.53% (134/136); accuracy 97.92% (141/144); prevalence 6.25% (9/144); - [underlined: Comparison 40]:; sensitivity 77.78% (7/9); specificity 100.00% (135/135); PPV 100.00% (7/7); NPV 98.54% (135/137); accuracy 98.61% (142/144); prevalence 6.25% (9/144); - [underlined: Comparison 41]:; sensitivity 88.89% (8/9); specificity 79.41% (54/68); PPV 36.36% (8/22); NPV 98.18% (54/55); accuracy 80.52% (62/77); prevalence 11.69% (9/77); - [underlined: Comparison 42]:; sensitivity 88.89% (8/9); specificity 89.71% (61/68); PPV 53.33% (8/15); NPV 98.39% (61/62); accuracy 89.61% (69/77); prevalence 11.69% (9/77); - [underlined: Comparison 43]:; sensitivity 88.89% (8/9); specificity 92.65% (63/68); PPV 61.54% (8/13); NPV 98.44% (63/64); accuracy 92.21% (71/77); prevalence 11.69% (9/77)
| This study combines results for children with chronic OM and recurrent otitis media; they do not state which of these categories represents OME or if either of them represents AOM. | - Grp 1~Age: 1–12 years; - Grp 1~chronic or recurrent OM; - Grp 1~brought to operating room at Children's Hospital of Pittsburgh for M&T surgery
| Grp 1: Myringotomy and Tympanostomy Group~Ears in children brought to operating room at Children's Hospital of Pittsburgh for M&T surgery | [underlined: Exclusion]: None
| Grp 2: Norms1~Ears studied by Nozza et al. | [underlined: Patient Characteristics:]
| N1=171 subjects, 249 ears | - median age 3.8 years, range 1–12 years
| N2=(subjects?), 130 ears
2048 Orchik 1978 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 4 (111001) | [underlined: Place]: Not specified | [underlined: Comparisons]:; 1. Portable tympanometer^a^; Dx- : Type A and C tympanograms; Dx+ : Type B tympanogram; Myringotomy (sedation unknown); GS- : fluid absent or minimal; GS+ : fluid present in moderate or large amounts; 2. Professional tympanometry^b^; Dx- : Acoustic reflex present; Dx+ : Acoustic reflex absent; Myringotomy (sedation unknown); GS- : fluid absent; GS+ : fluid present; 3. not included; 4. Professional tympanometry; Dx- : Type A & C1&C3 tympanogram; Dx+ : Types B & C2 tympanograms; Myringotomy (sedation unknown); GS- : fluid absent or minimal; GS+ : fluid present in moderate or large amounts; 5. Professional tympanometry^a^; Dx- : acoustic reflex present at 500, 2,000, or 4,000 Hz; Dx+ : acoustic reflex absent at 500, 2000, or 4000 Hz; Myringotomy (sedation unknown); GS- : fluid absent or minimal; GS+ : fluid moderate/large amounts; 6. Professional tympanometry^a^; Dx- : acoustic reflex present at 1000Hz; Dx+ : acoustic reflex absent at 1000 Hz; Myringotomy (sedation unknown); GS- : fluid absent or minimal; GS+ : fluid moderate/large amounts; 7. Quantitative tympanometry; Dx- : Static compliance ≥.28cc; Dx+ : Static compliance <.28; Myringotomy (sedation unknown); GS- : fluid absent or minimal; GS+ : fluid present in moderate or large amounts | - [underlined: Comparison 1]:; sensitivity 53.85% (21/39); specificity 94.59% (35/37); PPV 91.30% (21/23); NPV 66.04% (35/53); accuracy 73.68% (56/76); prevalence 51.32% (39/76); - [underlined: Comparison 2]:; sensitivity 89.74% (35/39); specificity 78.38% (29/37); PPV 81.40% (35/43); NPV 87.88% (29/33); accuracy 84.21% (64/76); prevalence 51.32% (39/76); - [underlined: Comparison 3]:; (not included-same as C1); - [underlined: Comparison 4]:; sensitivity 79.49% (31/39); specificity 86.49% (32/37); PPV 86.11% (31/36); NPV 80.00% (32/40); accuracy 82.89% (63/76); prevalence 51.32% (39/76); - [underlined: Comparison 5]:; sensitivity 87.18% (34/39); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence 51.32% (39/76); - [underlined: Comparison 6]:; sensitivity 89.74% (35/39); specificity unknown; PPV unknown; NPV unknown; accuracy unknown; prevalence 51.32% (39/76); - [underlined: Comparison 7]:; sensitivity 89.74% (35/39); specificity 40.54% (15/37); PPV 61.40% (35/57); NPV 78.95% (15/19); accuracy 65.79% (50/76); prevalence 51.32% (39/76)
| [underlined: Examiner(s)]:; - tympanometry (electroacoustic impedance bridge, Madsen 70–72): performer not specified; - myringotomy: surgeon | [underlined: Affiliation]: Dept. of Audiology and Speech Pathology, Memphis State Univ., TN; East Texas Rehabilitation Center
| [underlined: Study Cohort]: Ears of patients who underwent myringotomy for suspected serous otitis media | [underlined: Inclusion]; - Age: 6 months-14 years; - underwent myringotomy for suspected serous otitis media
| N=76 ears | [underlined: Exclusion]: None
| * number of subjects not specified | [underlined: Patient Characteristics]:; - mean age 4.5 years, range 6 months-14 years
2049 Orchik 1978 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 4 (111001) | [underlined: Place]: not specified | [underlined: Comparison]:; 1. Professional tympanometry^a^; Dx- : Type A and As tympanograms; Dx+ : Type B tympanograms; Myringotomy (sedation unknown); GS- : fluid absent or minimal; GS+ : fluid present in moderate or large amounts; 2. Professional tympanometry^b^; Dx- : Type A, As, C, and Cs tympanograms; Dx+ : Type B tympanograms; Myringotomy (sedation unknown); GS- : fluid absent or minimal; GS+ : fluid present in moderate or large amounts; 3. Professional tympanometry^c^; Dx- : Types A and As; Dx+ : Types B, C, and Cs; Myringotomy (sedation unknown); GS- : fluid absent or minimal; GS+ : fluid moderate/large amounts | - [underlined: Comparison 1]:; sensitivity 75.41% (46/61); specificity 81.25% (26/32); PPV 88.46% (46/52); NPV 63.41% (26/41); accuracy 77.42% (72/93); prevalence 65.59% (61/93); - [underlined: Comparison 2]:; sensitivity 54.76% (46/84); specificity 89.66% (52/58); PPV 88.46% (46/52); NPV 57.78% (52/90); accuracy 69.01% (98/142); prevalence 59.15% (84/142); - [underlined: Comparison 3]:; sensitivity 82.14% (69/84); specificity 44.83% (26/58); PPV 68.32% (69/101); NPV 63.41% (26/41); accuracy 66.90% (95/142); prevalence 59.15% (84/142)
| [underlined: Examiner(s)]:; - tympanometry (electroacoustic impedance bridge): not specified; - myringotomy: surgeon | [underlined: Affiliation]: Div. of Communication Disorder, North Texas State Univ.; J.W. Dunn, MD, and Associates, Denton TX
| [underlined: Study Cohort]: Patients who were undergoing myringotomy for suspected serous otitis media | [underlined: Inclusion]:; - Age: Not specified; - undergoing myringotomy for suspected serous otitis media
| N=75 subjects, 142 ears | [underlined: Exclusion]: None
| | [underlined: Patient Characteristics]: Not Specified
2050 Orchik 1980 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 4 (111001) | [underlined: Place]: not specified | [underlined: Comparisons]:; 1. Professional tympanometry^a^; Dx- : Type A tympanogram; Dx+ : Type B tympanpgram; Myringotomy (sedation unknown); GS- : Fluid absent or minimal; GS+ : Fluid present in moderate or large amounts; 2. Professional tympanometry^b^; Dx- : Type A and C tympanograms; Dx+ : Type B tympanograms; Myringotomy (sedation unknown); GS- : Fluid absent or minimal; GS+ : Fluid present in moderate or large amounts; 3. Professional tympanometry^b^; Dx- : Type A tympanograms; Dx+ : Type B and C tympanograms; Myringotomy (sedation unknown); GS- : Fluid absent or minimal; GS+ : Fluid present in moderate or large amounts; 4. Professional tympanometry; Dx- : Acoustic refl. present @500 Hz; Dx+ : Acoustic refl. absent @500 Hz; Myringotomy (sedation unknown); GS- : Fluid absent or minimal; GS+ : Fluid present in moderate or large amounts; 5. Professional tympanometry; Dx- : Acoustic reflex present at 1000 Hz; Dx+ : Acoustic reflex absent at 1000 Hz; Myringotomy (sedation unknown); GS- : Fluid absent or minimal; GS+ : Fluid present in moderate or large amounts; 6. Professional tympanometry; Dx- : Acoustic reflex present at 2000 Hz; Dx+ : Acoustic reflex absent at 2000 Hz; Myringotomy (sedation unknown); GS- : Fluid absent or minimal; GS+ : Fluid present in moderate or large amounts; 7. Professional tympanometry; Dx- : Acoustic reflex present at 4000 Hz; Dx+ : Acoustic reflex absent at 4000 Hz; Myringotomy (sedation unknown); GS- : Fluid absent or minimal; GS+ : Fluid present in moderate or large amounts; 8. Quantitative tympanometry; Dx- : Static compliance ∃.28 cc; Dx+ : Static compliance < .28 cc; Myringotomy (sedation unknown); GS- : Fluid absent or minimal; GS+ : Fluid present in moderate or large amounts | - [underlined: Comparison 1]:; sensitivity 87.50% (21/24); specificity 92.31% (24/26); PPV 91.30% (21/23); NPV 88.89% (24/27); accuracy 90.00% (45/50); prevalence 48.00% (24/50); - [underlined: Comparison 2]:; sensitivity 53.85% (21/39); specificity 94.59% (35/37); PPV 91.30% (21/23); NPV 66.04% (35/53); accuracy 73.68% (56/76); prevalence 51.32% (39/76); - [underlined: Comparison 3]:; sensitivity 92.31% (36/39); specificity 64.86% (24/37); PPV 73.47% (36/49); NPV 88.89% (24/27); accuracy 78.95% (60/76); prevalence 51.32% (39/76); - [underlined: Comparison 4]:; sensitivity 87.18% (34/39); specificity 70.27% (26/37); PPV 75.56% (34/45); NPV 83.87% (26/31); accuracy 78.95% (60/76); prevalence 51.32% (39/76); - [underlined: Comparison 5]:; sensitivity 89.74% (35/39); specificity 72.97% (27/37); PPV 77.78% (35/45); NPV 87.10% (27/31); accuracy 81.58% (62/76); prevalence 51.32% (39/76); - [underlined: Comparison 6]:; sensitivity 87.18% (34/39); specificity 75.68% (28/37); PPV 79.07% (34/43); NPV 84.85% (28/33); accuracy 81.58% (62/76); prevalence 51.32% (39/76); - [underlined: Comparison 7]:; sensitivity 87.18% (34/39); specificity 75.68% (28/37); PPV 79.07% (34/43); NPV 84.85% (28/33); accuracy 81.58% (62/76); prevalence 51.32% (39/76); - [underlined: Comparison 8]:; sensitivity 89.74% (35/39); specificity 40.54% (15/37); PPV 61.40% (35/57); NPV 78.95% (15/19); accuracy 65.79% (50/76); prevalence 51.32% (39/76)
| [underlined: Examiner(s)]:; - tympanometry (electroacoustic impedance bridge, Madsen ZO-72): not specified; - myringotomy: surgeon | [underlined: Affiliation]: Memphis State Univ, TN; J.W. Dunn, MD, and Associates, TX
| [underlined: Study Cohort]: Ears of patients undergoing myringotomy for suspected serous otitis media | [underlined: Inclusion]:; - Age: 6 months-14 years; - undergoing myringotomy for suspected serous otitis media, usually for recurrent OM or failure of single OM episode to respond to medical treatment
| N=76 ears | [underlined: Exclusion]: None
| * number of subjects not specified | [underlined: Patient Characteristics]:; - mean age 4.5 years, range 6 months-14 years
2055 Ovesen 1993 | N/A | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 4 (111001) | [underlined: Place]: Not specified | [underlined: Comparisons]:; 1. Professional tympanometry^a^; Dx- : Type A tympanogram; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Professional tympanometry^b^; Dx- : Type A/C1/C2 tympanogram; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Professional tympanometry^c^; Dx- : Type A or C1 tympanogram; Dx+ : Type B or C2 tympanogram; Myringotomy (sedated); GS- : Fluid absent; GS+ : Fluid present; 4. Professional tympanometry^d^; Dx- : Type A tympanogram; Dx+ : Types B/C1/C2 tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 99.36% (310/312); specificity 48.15% (13/27); PPV 95.68% (310/324); NPV 86.67% (13/15); accuracy 95.28% (323/339); prevalence 92.04% (312/339); - [underlined: Comparison 2]:; sensitivity 90.64% (310/342); specificity 72.55% (37/51); PPV 95.68% (310/324); NPV 53.62% (37/69); accuracy 88.30% (347/393); prevalence 87.02% (342/393); - [underlined: Comparison 3]:; sensitivity 94.44% (323/342); specificity 52.94% (27/51); PPV 93.08% (323/347); NPV 58.70% (27/46); accuracy 89.06% (350/393); prevalence 87.02% (342/393); - [underlined: Comparison 4]:; sensitivity 99.42% (340/342); specificity 25.49% (13/51); PPV 89.95% (340/378); NPV 86.67% (13/15); accuracy 89.82% (353/393); prevalence 87.02% (342/393)
| [underlined: Examiner(s)]; - tympanometry (Tympan-O-scope model zs 330 [Madsen Electronics]): ENT physician; - otomicroscopy: not specified; - myringotomy: two other ENT specialists | [underlined: Affiliation]: Ear Nose and Throat Dept., Aarhus Univ. Hospital, Aarhus C, Denmark
| [underlined: Study Cohort]: Children with unilateral or bilateral SOM | [underlined: Inclusion]:; - Age: 0.8–14.8 years; - two of the following three criteria: otomicroscopical findings consistent with SOM during 3 months, >20 dB hearing impairment, and/or adenoid symptoms
| N=222 subjects, 440 ears | [underlined: Exclusion]: None
| | [underlined: Patient Characteristics]:; - mean age 4.1 years, 0.8–14.8 years; - male 132, female 88
2058 Oyiborhoro 1987 | Diagnostic study | [underlined: Time]: Referred over a 10-month period (actual dates not specified) | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 3 (100101) | [underlined: Place]: Subjects drawn from the ENT clinic at the Dr. Martin Luther King, Jr. Health Center, Bronx, NY | [underlined: Comparisons]:; 1. Grps 1 & 2 combined; Acoustic reflectometry; Dx- : Acoustic otoscope reflectivity<4; Dx+ : Acoustic otoscope reflect. ≥4; Validated pneumatic otoscopy; GS- : MEE absent; GS+ : MEE present; 2. Grps 1 & combined; Acoustic reflectometry; Dx- : Acoustic otoscope reflectivity<3; Dx+ : Acoustic otoscope reflect. ≥3; Validated pneumatic otoscopy; GS- : MEE absent; GS+ : MEE present; 3. Grp 3^a^; Acoustic reflectometry; Dx- : Acoustic otoscope reflectivity<4; Dx+ : Acoustic otoscope reflect. ≥4; Myringotomy (sedation unknown); GS- : Fluid absent; GS+ : Fluid present | - [underlined: Comparison 1]:; sensitivity 93.14% (163/175); specificity 83.00% (166/200); PPV 82.74% (163/197); NPV 93.26% (166/178); accuracy 87.73% (329/375); prevalence 46.67% (175/375); - [underlined: Comparison 2]:; sensitivity 97.71% (171/175); specificity 65.50% (131/200); PPV 71.25% (171/240); NPV 97.04% (131/135); accuracy 80.53% (302/375); prevalence 46.67% (175/375); - [underlined: Comparison 3]:; sensitivity 95.45% (42/44); specificity - (0/0); PPV 100.00% (42/42); NPV - (0/2); accuracy 95.45% (42/44); prevalence 100.00% (44/44)
| [underlined: Examiner(s)]:; - acoustic reflectometry (acoustic otoscope [Endeco Medical]): not specified; - pneumatic otoscopy: otolaryngologist validated with sensitivity 97.73% and specificity 90.90%; - tympanometry diagnostic impedance audiometer Madsen ZS 77 MB): not specified; - audiometry (Beltone clinical audiotry model 200-C): not specified; - myringotomy | [underlined: Affiliation]: Columbia Univ., NY; VA Medical Center, Cleveland, OH; as above
| Grp 1: Children who did not have MEE | [underlined: Inclusion]:; - Age: 3–12 years; - Grp 1: normal hearing and middle ear function based upon results from otoscopy, tympanometry and pure tone audiometry); - Grp 2: pure tone thresholds ≥20dB HL (250–8000 Hz); air-bone gaps of at least 15 dB HL (250–4000 Hz); type B tympanograms in the ears studied w/no sensorineural components; or demonstrated hearing and immittance abnormalities at least two times in ears studied during the 10-month period of investigation.
| Grp 2: Children who had MEE | [underlined: Exclusion]:; - Grp 1~history suggested the existence of any known middle ear pathology
| Grp 3: Subgroup of children in group2 who underwent myringotomy (44 pathologic ears) | [underlined: Patient Characteristics]:; - mean age 8.7 years, range 3–12 years; - male 90, female 110
| N1=100 subjects, 200 ears
| N2=100 subjects, 175 ears
| N3=23 subjects, 44 ears
2118 Paradise 1976 | Diagnostic study | [underlined: Time]: 5/25/1972-5/9/1974 | [underlined: Comparisons]:; 1. Pneumatic otoscopy^a^ -unvalidated examiner; Dx- : MEE absent; Dx+ : MEE present; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Pneumatic otoscopy^b^ -; unvalidated examiner; Dx- : MEE absent; Dx+ : MEE present; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Pneumatic otoscopy^c^- unvalidated examiner; Dx- : MEE absent; Dx+ : MEE present; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | [underlined: Unit of measure]: Ear
| This ID number includes two separate studies | [underlined: Place]: Grp 1 not specified: Grp 2 various outpatient waiting areas at Children's Hospital of Pittsburgh, PA | | - [underlined: Comparison 1]:; sensitivity 91.37% (127/139); specificity 74.67% (56/75); PPV 86.99% (127/146); NPV 82.35% (56/68); accuracy 85.51% (183/214); prevalence 64.95% (139/214); - [underlined: Comparison 2]:; sensitivity 98.55% (136/138); specificity 74.67% (56/75); PPV 87.74% (136/155); NPV 96.55% (56/58); accuracy 90.14% (192/213); prevalence 64.79% (138/213); - [underlined: Comparison 3]:; sensitivity 98.45% (127/129); specificity 81.16% (56/69); PPV 90.71% (127/140); NPV 96.55% (56/58); accuracy 92.42% (183/198); prevalence 65.15% (129/198)
| [underlined: Study Quality Score] (0–6[underlined: )]: STUDY 1: 4 (111001) STUDY 2: 5 (111101) | [underlined: Affiliation]: Dept. of Pediatrics, Community Med., and Otolaryngology, and Speech and Theatre Arts Cleft Palate Center, Univ. of Pittsburgh; Ambulatory Care Center, Children's Hospital of Pittsburgh
| [underlined: Examiner(s)]; - tympanometry (Madsen Electroacoustic Impedance Meter, Model ZO 70 [Madsen Electronics]): audiologist; - pneumatic otoscopy: pediatrician; - myringotomy: by or under supervision of one of two otolaryngologists | [underlined: Inclusion]:; - Age: 10 days-5 years; - Grp 1:; - scheduled for myringotomy and insertion of tubes due to recurrent AOM or persistent MEE or both; - Grp 2:; - not scheduled for myringotomy; - in various outpatient waiting areas of the Children's Hospital of Pittsburgh; available and parents willing to allow participation in study
| [underlined: Study Cohort]: infants and children who had been scheduled for myringotomy and insertion of tympanostomy tubes because of recurrent AOM or persistent MEE, or both | [underlined: Exclusion]: None
| * (group of infants and children not receiving myringotomy were studied but findings were not relevant to key question four) | [underlined: Patient Characteristics]:; - age range 10 days-5 years 11 months; - Grp 1 male 62, female 45; Grp 2 male 103, female 70; - black 66, white 214
| N=107 subjects, 214 ears
4790 Paradise 1996 | Diagnostic study | [underlined: Time]: not specified | - [underlined: Comparisons]:; - Grp1-1^st^ year of life; [underlined: Examiner type (Audiologist #1)]; Professional tympanometry; Dx- : Normal tympanograms; Dx+ : Questionable or Flat tymp.; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; - Grp 1-1^st^ year of life; [underlined: Examiner type (Audiologist #1)]; Professional tympanometry; Dx- : Normal/questionable tymp.; Dx+ : Flat tympanograms; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; - Grp 1-1^st^ year of life; [underlined: Examiner type (Audiologist #2)]; Professional tympanometry; Dx- : Normal tympanograms; Dx+ : Questionable or Flat tymp.; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; - Grp 1-1^st^ year of life; [underlined: Examiner type (Audiologist #2)]; Professional tympanometry; Dx- : Normal/questionable tymp.; Dx+ : Flat tympanograms; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 5 (111110) | [underlined: Place]: Children's Hospital outpatient department | | - [underlined: Comparison 1]:; sensitivity 85.71% (120/140); specificity 47.95% (269/561); PPV 29.13% (120/412); NPV 93.08% (269/289); accuracy 55.49% (389/701); prevalence 19.97% (140/701); - [underlined: Comparison 2]:; sensitivity 47.86% (67/140); specificity 90.91% (510/561); PPV 56.78% (67/118; NPV 87.48% (510/583); accuracy 82.31% (577/701); prevalence 19.97% (140/701); - [underlined: Comparison 3]:; sensitivity 42.86% (60/140); specificity 90.02% (505/561); PPV 51.72% (60/116); NPV 86.32% (505/585); accuracy 80.60% (565/701); prevalence 19.97% (140/701); - [underlined: Comparison 4]:; - sensitivity 32.14% (45/140); specificity 96.08% (539/561); PPV 67.16% (45/67); NPV 85.02% (539/634); accuracy 83.31% (584/701); prevalence 19.97% (140/701)
| [underlined: Examiner(s)]; - tympanometry (Grason-Stadler GSI 33): two audiologists; - pneumatic otoscopy: tested otoscopists which we interpreted as validated otoscopists | [underlined: Affiliation]: Not specified but authors recognized as being from Children's Hospital of Pittsburgh, PA
| Grp 1: Ears in infants during their first year of | [underlined: Inclusion]; - Age: 2–23 months; - healthy infants
| Grp 2: Ears in infants during their second year of life | [underlined: Exclusion]: None
| (Note: these ears are not necessarily independent.) | [underlined: Patient Characteristics]: Not specified
| N=362 subjects, 1296 ears
| N1=701 ears
| N2=595 ears
| * (did not specify how many children in each group)
| | | - Grp2-2^nd^ year of life; [underlined: Examiner type (Audiologist #1)]; Professional tympanometry; Dx- : Normal tympanograms; Dx+ : Questionable/Flat tymp.; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; - Grp 2-2^nd^ year of life; [underlined: Examiner type (Audiologist #1)]; Professional tympanometry; Dx- : Normal/questionable tymp.; Dx+ : Flat tympanograms; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; - Grp 2-2^nd^ year of life; [underlined: Examiner type (Audiologist #2)]; Professional tympanometry; Dx- : Normal tympanograms; Dx+ : Questionable/Flat tymp.; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; - Grp 2-2^nd^ year of life; [underlined: Examiner type (Audiologist #2)]; Professional tympanometry; Dx- : Normal/questionable tymp.; Dx+ : Flat tympanograms; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 5 (111110) | [underlined: Place]: Children's Hospital outpatient department | | - [underlined: Comparison 5]:; sensitivity 90.36% (75/83); specificity 69.92% (358/512); PPV 32.75% (75/229); NPV 97.81% (358/366); accuracy 72.77% (433/595); prevalence 13.95% (83/595); - [underlined: Comparison 6]:; sensitivity 65.06% (54/83); specificity 94.92% (486/512); PPV 67.50% (54/80); NPV 94.37% (486/515); accuracy 90.76% (540/595); prevalence 13.95% (83/595); - [underlined: Comparison 7]:; sensitivity 68.67% (57/83); specificity 92.00% (471/512); PPV 58.16% (57/98); NPV 94.77% (471/497); accuracy 88.74% (528/595); prevalence 13.95% (83/595); - [underlined: Comparison 8]:; - sensitivity 65.06% (54/83); specificity 94.92% (486/512); PPV 67.50% (54/80); NPV 94.37% (486/515); accuracy 90.76% (540/595); prevalence 13.95% (83/595)
| [underlined: Examiner(s)]; - tympanometry (Grason-Stadler GSI 33): two audiologists; - pneumatic otoscopy: tested otoscopists which we interpreted as validated otoscopists | [underlined: Affiliation]: Not specified but authors recognized as being from Children's Hospital of Pittsburgh, PA
| Grp 1: Ears in infants during their first year of | [underlined: Inclusion]; - Age: 2–23 months; - healthy infants
| Grp 2: Ears in infants during their second year of life | [underlined: Exclusion]: None
| (Note: these ears are not necessarily independent.) | [underlined: Patient Characteristics]: Not specified
| N=362 subjects, 1296 ears N1=701 ears N2=595 ears* (did not specify how many children in each group)
| * (did not specify how many children in each group)
| | | - Grp2-2^nd^ year of life; [underlined: Examiner type (Audiologist #1)]; Professional tympanometry; Dx- : Normal tympanograms; Dx+ : Questionable/Flat tymp.; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; - Grp 2-2^nd^ year of life; [underlined: Examiner type (Audiologist #1)]; Professional tympanometry; Dx- : Normal/questionable tymp.; Dx+ : Flat tympanograms; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; - Grp 2-2^nd^ year of life; [underlined: Examiner type (Audiologist #2)]; Professional tympanometry; Dx- : Normal tympanograms; Dx+ : Questionable/Flat tymp.; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present; - Grp 2-2^nd^ year of life; [underlined: Examiner type (Audiologist #2)]; Professional tympanometry; Dx- : Normal/questionable tymp.; Dx+ : Flat tympanograms; Validated pneumatic otoscopy; GS- : effusion absent; GS+ : effusion present | [underlined: Unit of measure]: Ear
| | | | - [underlined: Comparison 5]:; sensitivity 90.36% (75/83); specificity 69.92% (358/512); PPV 32.75% (75/229); NPV 97.81% (358/366); accuracy 72.77% (433/595); prevalence 13.95% (83/595); - [underlined: Comparison 6]:; sensitivity 65.06% (54/83); specificity 94.92% (486/512); PPV 67.50% (54/80); NPV 94.37% (486/515); accuracy 90.76% (540/595); prevalence 13.95% (83/595); - [underlined: Comparison 7]:; sensitivity 68.67% (57/83); specificity 92.00% (471/512); PPV 58.16% (57/98); NPV 94.77% (471/497); accuracy 88.74% (528/595); prevalence 13.95% (83/595); - [underlined: Comparison 8]:; - sensitivity 65.06% (54/83); specificity 94.92% (486/512); PPV 67.50% (54/80); NPV 94.37% (486/515); accuracy 90.76% (540/595); prevalence 13.95% (83/595)
4793 Park 1988 | Diagnostic study | [underlined: Time]: Grp 1~not specified; Grp 2~1981-1986 | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place]: Korea (specifics not provided) | [underlined: Comparisons]:; 1. [underlined: Male Children]; Professional tympanometry; Dx- : Type A tympanogram; Dx+ : Type B or C tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. [underlined: Male Children]; Professional tympanometry; Dx- : Type A or C tympanograms; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. [underlined: Female Children]; Professional tympanometry; Dx- : Type A tympanogram; Dx+ : Type B or C tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 4. [underlined: Female Children]; Professional tympanometry; Dx- : Type A or C tympanograms; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 5. [underlined: Male Children]; Professional tympanometry; Dx- : Type A tympanogram; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 6. [underlined: Female Children]; Professional tympanometry; Dx- : Type A tympanogram; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 91.94% (228/248); specificity 13.16% (5/38); PPV 87.36% (228/261); NPV 20.00% (5/25); accuracy 81.47% (233/286); prevalence 86.71% (248/286); - [underlined: Comparison 2]:; sensitivity 73.39% (182/248); specificity 39.47% (15/38); PPV 88.78% (182/205); NPV 18.52% (15/81); accuracy 68.88% (197/286); prevalence 86.71% (248/286); - [underlined: Comparison 3]:; sensitivity 94.82% (183/193); specificity 16.13% (5/31); PPV 87.56% (183/209); NPV 33.33% (5/15); accuracy 83.93% (188/224); prevalence 86.16% (193/224); - [underlined: Comparison 4]:; sensitivity 78.76% 152/193); specificity 54.84% 17/31); PPV 91.57% (152/166); NPV 29.31% (17/58); accuracy 75.45% (169/224); prevalence 86.16% (193/224); - [underlined: Comparison 5]:; sensitivity 90.10% (182/202); specificity 17.86% (5/28); PPV 88.78% (182/205); NPV 20.00% (5/25); accuracy 81.30% (187/230); prevalence 87.83% (202/230); - [underlined: Comparison 6]:; sensitivity 93.83% (152/162); specificity 26.32% (5/19); PPV 91.57% (152/166); NPV 33.33% (5/15); accuracy 86.74% (157/181); prevalence 89.50% (162/181)
| [underlined: Examiner(s)]:; - tympanometry (Teledyne Avionics instrument type TA-3D and Grason-Stadler instrument 1723 middle ear analyzer): not specified; - myringotomy: not specified | [underlined: Affiliation]: not specified
| [underlined: Study Cohort]: Children diagnosed as having OME who received myringotomies with and w/out ventilation tubes | [underlined: Inclusion]:; - Grp 1~Age: Not specified; - Grp 2~Age: 2–15 years; - Grp 1~healthy children, who showed <10 db air-bone gap and in whom physical exams were normal; - Grp 2~OME diagnosed by physical exam and impedance audiometry; - Korean pediatric population
| *(a group of 79 healthy children were also studied but findings were not relevant to key question four) | [underlined: Exclusion]: None
| N=290 subjects, 528 ears | [underlined: Patient Characteristics]:; - Grp 2 age range 2–15 years
2236 Rees 1992 | Cross-sectional | [underlined: Time]: 6-month period (actual dates not specified) | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place]: ENT Department of the Radcliffe Infirmary, Oxford, UK | [underlined: Comparisons]:; 1. Portable tympanometer^a^; Dx- : Type A or C tympanogram; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Portable tympanometer^b^; Dx- : Type A or C tympanogram; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 100.00% (260/260); specificity 18.00% (9/50); PPV 86.38% (260/301); NPV 100.00% (9/9); accuracy 86.77% (269/310); prevalence 83.87% (260/310); - [underlined: Comparison 2]:; sensitivity 100.00% (260/260); specificity 100.00% (50/50); PPV 100.00% (260/260); NPV 100.00% (50/50); accuracy 100.00% (310/310); prevalence 83.87% (260/310)
| [underlined: Examiner(s)]:; - tympanometry (Rexton tympanometer): not specified; - myringotomy: not specified | [underlined: Affiliation]: Dept. of Otolaryngology, Radcliffe Infirmary, Oxford, UK
| *This study focuses on changes in tympanometry resulting from general anesthesia, not on the sensitivity/specificity of tympanometry for identifying fluid filled ears. | [underlined: Inclusion]:; - Age: 18 months-11 years; - admitted to the ENT Dept. of the Radcliffe Infirmary over a 6-month period; - seen by an otologist within 3 months of admission; - with clinically persistent middle ear effusion; - able to tolerate examination and tympanometry
| [underlined: Study Cohort]: Children admitted to ENT Dept. for myringtomy and possible grommet insertion | [underlined: Exclusion]: None
| N=155 subjects, 310 ears | [underlined: Patient Characteristics]; - age range 18 months-11 years
4804Renvall 1996 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: | [underlined: Place]: not specified | [underlined: Comparisons]:; 1. Professional tympanometry; Dx- : Peaked tympanogram; Dx+ : Flat tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present\ | [underlined: Comparison 1]:; - sensitivity 86.14% (87/101); specificity 96.15% (25/26); PPV 98.86% (87/88); NPV 64.10% (25/39); accuracy 88.19% (112/127); prevalence 79.53% (101/127)
| [underlined: Examiner(s)]:; - tympanometry (Model 85AR [American Electromedics Corporation]): not specified; - myringotomy: not specified | [underlined: Affiliation]:
| [underlined: Study Cohort]: Children who underwent tympanometry and were candidates for ventilation tube insertion | [underlined: Inclusion]:; - Age: 3–12 years; - suffered from longstanding serous otitis media; - candidate for tympanocentesis and ventilation tube insertion under general anesthesia
| N=73 subjects, 127 ears | [underlined: Exclusion]: None
| | [underlined: Patient Characteristics]:; - age range 3–12 years
2344 Sassen 1994 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 3 (111000) | [underlined: Place]: Study performed in two hospital: Hospital A~ Gemini-Hospital in Den Helder and Hospital B~ St. Elisabeth-Hospital in Leiderdorp, The Netherlands | [underlined: Comparisons]:; 1. Grp 1 and Grp 2; Binocular micro-tympanoscopy; Dx- : Tympanic membrane~normal; Dx+ : Tympanic membrane~abnormal; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 2. Grp 1 and Grp 2; Professional tympanometry-both types; Dx- : Type (A,C1,C2,O); Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 3. Grp 1 and Grp 2; Professional tympanometry-both types; Dx- : Type (A, C1, O) tympanogram; Dx+ : Type B or C2) tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 4. Grp 1 and Grp 2; Age (5 months-2 years); Professional tympanometry-both types; Dx- : Type (A,C1,C2) tympanogram; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 5. Grp 1 and Grp 2; Age (5 months-2 years); Professional tympanometry-both types; Dx- : Type (A, C1) tympanogram; Dx+ : Type (B or C2) tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 6. Grp 1 and Grp 2; Age (2–12 years); Professional tympanometry-both types; Dx- : Type (A,C1,C2) tympanogram; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 7. Grp 1 and Grp 2; Age (2–12 years); Professional tympanometry-both types; Dx- : Type (A, C1) tympanogram; Dx+ : Type (B or C2) tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 8. Grp 1; Professional tympanometry-both types; Dx- : Type (A,C1,C2) tympanogram; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 9. Grp 1; Professional tympanometry-both types; Dx- : Type (A, C1, O) tympanogram; Dx+ : Type (B or C2) tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 10. Grp 2; Professional tympanometry-both types; Dx- : Type (A,C1,C2) tympanogram; Dx+ : Type B tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; 11. Grp 2; Professional tympanometry-both types; Dx- : Type (A, C1) tympanogram; Dx+ : Type (B or C2) tympanogram; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | [underlined: Comparison 1]:; - sensitivity 96.77% (270/279); specificity 13.86% (14/101); PPV 75.63% (270/357); NPV 60.87% (14/23); accuracy 74.74% (284/380); prevalence 73.42% (279/380); [underlined: Comparison 2]:; - sensitivity 80.65% (225/279); specificity 58.42% (59/101); PPV 84.27% (225/267); NPV 52.21% (59/113); accuracy 74.74% (284/380); prevalence 73.42% (279/380); [underlined: Comparison 3]:; - sensitivity 90.68% (253/279); specificity 32.67% (33/101); PPV 78.82% (253/321); NPV 55.93% (33/59); accuracy 75.26% (286/380); prevalence 73.42% (279/380); [underlined: Comparison 4]:; - sensitivity 90.38% (47/52); specificity 66.67% (10/15); PPV 90.38% (47/52); NPV 66.67% (10/15); accuracy 85.07% (57/67); prevalence 77.61% (52/67); [underlined: Comparison 5]:; - sensitivity 92.31% (48/52); specificity 53.33% (8/15); PPV 87.27% (48/55); NPV 66.67% (8/12); accuracy 83.58% (56/67); prevalence 77.61% (52/67); [underlined: Comparison 6]:; - sensitivity 81.38% (236/290); specificity 62.60% (82/131); PPV 82.81% (236/285); NPV 60.29% (82/136); accuracy 75.53% (318/421); prevalence 68.88% (290/421); [underlined: Comparison 7]:; - sensitivity 94.83% (275/290); specificity 35.11% (46/131); PPV 76.39% (275/360); NPV 75.41% (46/61); accuracy 76.01% (320/421); prevalence 68.88% (290/421); [underlined: Comparison 8]:; - sensitivity 75.42% (135/179); specificity 74.65% (53/71); PPV 88.24% (135/153); NPV 54.64% (53/97); accuracy 75.20% (188/250); prevalence 71.60% (179/250); [underlined: Comparison 9]:; - sensitivity 91.62% (164/179); specificity 43.66% (31/71); PPV 80.39% (164/204); NPV 67.39% (31/46); accuracy 78.00% (195/250); prevalence 71.60% (179/250); [underlined: Comparison 10]:; - sensitivity 90.80% (148/163); specificity 52.00% (39/75); PPV 80.43% (148/184); NPV 70.37% (38/54); accuracy 78.57% (187/238); prevalence 68.49% (163/238); [underlined: Comparison 11]:; - sensitivity 97.55% (159/163); specificity 30.67% (23/75); PPV 75.36% (159/211); NPV 85.19% (23/27); accuracy 76.47% (182/238); prevalence 68.49% (163/238)
| [underlined: Examiner(s)]:; - tympanometry (type GSI-27A and type Tymp-85TT, 226 Hz probe tone, used six weeks in each group and then interchanged): not specified; - otomicroscopy: three ENT surgeons; - myringotomy: three ENT surgeons | [underlined: Affiliation]: Dept. of Otorhinolaryngology, Univ. Hospital Leiden, The Netherlands
| *This study combines children undergoing myringotomy because of recurrent AOM or chronic OME but does not stratify the results according to type of OM. | [underlined: Inclusion]:; - Age: 5 months-11 years & 5 months; - candidate for insertion of ventilation tubes, or adenoidectomy and/or tonsillectomy w/myringotomy; - Grp 1~middle ear problems (not URIs) and undergoing insertion of tympanostomy tubes only; - Grp 2~URIs and undergoing (adeno)-tonsillectomy with myringotomy
| Grp 1: Hospital A ~ Ears in children with middle ear problems who were only undergoing insertion of tympanostomy tubes [not (adeno)-tonsillectomy with myringotomy] | [underlined: Exclusion]:; - Grp 1~ URIs; - perforation of the tympanic membrane; - history of >6 myringotomies and/or >3 insertions of middle ear ventilation tubes
| Grp 2: Hospital B ~ Ears in children with URIs who were undergoing (adeno)-tonsillectomy with myringotomy | [underlined: Patient Characteristics]:; - age range 5 months-11 years 5 months; - male 143, female 123
| N=266 subjects, 515 ears
| N1=273 ears
| N2=242 ears
| * (did not specify how many children in each group)
2412 Shaw 1978 | Cross-sectional | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place]: Not specified | [underlined: Comparisons]:; 1. Professional tympanometry^a^; Dx- : Type A tympanogram; Dx+ : Type B and C tympanograms; Myringotomy (sedated); GS- : Fluid absent; GS+ : Fluid present; 2. Professional tympanometry^a^; Dx- : Type A and C tympanogram; Dx+ : Type B tympanograms; Myringotomy (sedated); GS- : Fluid absent; GS+ : Fluid present | - [underlined: Comparison 1]:; sensitivity 100.00% (49/49); specificity 10.00% (1/10); PPV 84.48% (49/58); NPV 100.00% (1/1); accuracy 84.75% (50/59); prevalence 83.05% (49/59); - [underlined: Comparison 2]:; sensitivity 97.96% (48/49); specificity 30.00% (3/10); PPV 87.27% (48/55); NPV 75.00% (3/4); accuracy 86.44% (51/59); prevalence 83.05% (49/59)
| [underlined: Examiner(s)]:; - tympanometry (Grason-Stadler 1720 otoadmittance meter, 220 and 660 Hz probe tones): not specified; - myringotomy; not specified | [underlined: Affiliation]: Univ. of Illinois, Hearing Clinic, Champaign, IL
| *This is a pre-, post-anesthesia study looking at the effects on tympanometry. | [underlined: Inclusion]:; - Age: 2–11 years; - probable middle-ear fluid unilaterally or bilaterally based on otologic and audiologic exam; - underwent myringotomy surgery
| [underlined: Study Cohort]: Ears in children who underwent myringotomy surgery | [underlined: Exclusion]:; - ears that did not undergo myringotomy surgery
| N=59 ears | [underlined: Patient Characteristics]:; - age range 2–11 years
| * Sample size =39 patients and 68 ears with probable middle-ear fluid. Only 59 ears received surgery but the authors did not state whether all patients in the sample received surgery or if some were excluded when number of ears was reduced from 68 to 59.
2545 Szucs 1995 | Diagnostic study | [underlined: Time]: 6 month period between 5/1992-12/1992 | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 1 (100000) | [underlined: Place]: Ear-Nose and Throat Department of Brussels Free University, Brussels, Belgium | [underlined: Comparison]:; 1. Professional tympanometry^a^; Dx- : Type A tympanograms; Dx+ : Type B tympanograms; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; Professional tympanometry^b^; Dx- : Type A and C tympanograms; Dx+ : Type B tympanograms; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; Professional tympanometry^c^; Dx- : Type A tympanogram; Dx+ : Type B and C tympanograms; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; Professional tympanometry^a^; Dx- : Type A and C tympanograms; Dx+ : Type B tympanogram; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present; Professional tympanometry^b^; Dx- : Type A and C tympanograms; Dx+ : Type B tympanogram; Tympanocentesis (non-sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 94.74% (36/38); specificity 57.14% (8/14); PPV 85.71% (36/42); NPV 80.00% (8/10); accuracy 84.62% (44/52); prevalence 73.08% (38/52); - [underlined: Comparison 2]:; sensitivity 73.47% (36/49); specificity 79.31% (23/29); PPV 85.71% (36/42); NPV 63.89% (23/36); accuracy 75.64% (59/78); prevalence 62.82% (49/78); - [underlined: Comparison 3]:; sensitivity 95.92% (47/49); specificity 27.59% (8/29); PPV 69.12% (47/68); NPV 80.00% (8/10); accuracy 70.51% (55/78); prevalence 62.82% (49/78); - [underlined: Comparison 4]:; sensitivity 82.61% (19/23); specificity 90.00% (9/10); PPV 95.00% (19/20); NPV 69.23% (9/13); accuracy 84.85% (28/33); prevalence 69.70% (23/33); - [underlined: Comparison 5]:; sensitivity 57.89% (11/19); specificity 70.59% (12/17); PPV 68.75% (11/16); NPV 60.00% (12/20); accuracy 63.89% (23/36); prevalence 52.78% (19/36)
| [underlined: Examiner(s)]:; - tympanometry (Amplaid 720 type impedance meter): not specified; - myringotomy: ENT surgeon | [underlined: Affiliation]: Dept. of Otorhinolaryngology, Brussels Free Univ., Belgium
| [underlined: Study Cohort]: Children w/ chronic OME and recurrent otitis media | [underlined: Inclusion]:; - Age: 1 year 3 months-11 years 4 months; - chronic OME and/or recurrent OM
| N=40 subjects, 78 ears | [underlined: Exclusion]:; - although not stated specifically to be a criteria none of the children had any accompanying disease
| | [underlined: Patient Characteristics]:; - mean age 5 years 8 months, range 1 year 3 months-11 years 4 months; - male 27, female 13
2601 Tom 1994 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 4 (111001) | [underlined: Place]: Not specified | [underlined: Comparison]:; 1. Professional tympanometry^a^; Dx- : Type A tympanograms; Dx+ : Type B tympanograms; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; Professional tympanometry^b^; Dx- : Type A and C tympanograms; Dx+ : Type B tympanograms; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present; Professional tympanometry^c^; Dx- : Type A tympanogram; Dx+ : Type B and C tympanograms; Myringotomy (sedated); GS- : fluid absent; GS+ : fluid present | - [underlined: Comparison 1]:; sensitivity 92.59% (100/108); specificity 51.85% (14/27); PPV 88.50% (100/113); NPV 63.64% (14/22); accuracy 84.44% (114/135); prevalence 80.00% (108/135); - [underlined: Comparison 2]:; sensitivity 65.36% (100/153); specificity 78.33% (47/60); PPV 88.50% (100/113); NPV 47.00% (47/100); accuracy 69.01% (147/213); prevalence 71.83% (153/213); - [underlined: Comparison 3]:; sensitivity 94.77% (145/153); specificity 23.33% (14/60); PPV 75.92% (145/191); NPV 63.64% (14/22); accuracy 74.65% (159/213); prevalence 71.83% (153/213)
| [underlined: Examiner(s)]:; - tympanometry (Teledyne Screening Meter model no. TA-7A): certified audiologists; - myringotomy: surgeon | [underlined: Affiliation]: Div. of Otolaryngology, Children's Hospital of Philadelphia, PA; Div. of Medical Audiology, Children's Seashore House, PA; Dept. of Otolaryngology, Univ. of Pennsylvania
| *This study combines data for persistent OME and recurrent AOM but does not stratify the results based on this variable. | [underlined: Inclusion]:; - Age: 5 months-11 years; - scheduled to undergo myringotomies w/ pressure equalization tube insertion for either OME refractory to medical management or recurrent OM
| [underlined: Study Cohort]: Children scheduled to undergo myringotomy with pressure equalization tube insertion for either OME refractory to medical management or recurrent OM | [underlined: Exclusion]:; - ears discovered either at tympanometry or surgery to have small perforations (n=5 ears excluded)
| N=109 subjects, 213 ears | [underlined: Patient Characteristics]:; - mean age 3 years 8 months, range 5 months-11 years 5 months; - male 62, female 47
2607 Toner 1990 | Diagnostic study | [underlined: Time]: Consecutive 5-month period (actual dates not specified) | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 2 (100001) | [underlined: Place]: ENT Department of the Belfast City Hospital, Belfast, UK | [underlined: Comparisons]:
| [underlined: Examiner(s):] | [underlined: Affiliation]: as above | 1. Pneumatic otoscopy - unvalidated examiner; Dx-: mobile; Dx+: immobile; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 2. Professional tympanometer^a^; Dx-: Type A, & C tympanograms; Dx+: Type B tympanogram; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 3. Professional tympanometry^b^; Dx-: Type A tympanogram; Dx+: Type B and C tympanograms; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 4. Professional tympanometry^c^; Dx-: Type A tympanograms; Dx+: Type B tympanograms; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present | - [underlined: Comparison 1]:; sensitivity 87.10% (108/124); specificity 88.78% (87/98); PPV 90.76% (108/119); NPV 84.47% (87/103); accuracy 87.84% (195/222); prevalence 55.86% (124/222); - [underlined: Comparison 2]:; sensitivity 86.29% (107/124); specificity 92.86% (91/98); PPV 93.86% (107/114); NPV 84.26% (91/108); accuracy 89.19% (198/222); prevalence 55.86% (124/222); - [underlined: Comparison 3]:; sensitivity 96.77% (120/124); specificity 76.53% (75/98); PPV 83.92% (120/143); NPV 94.94% (75/79); accuracy 87.84% (195/222); prevalence 55.86% (124/222); - [underlined: Comparison 4]:; sensitivity 96.40% (107/111); specificity 91.46% (75/82); PPV 93.86% (107/114); NPV 94.94% (75/79); accuracy 94.30% (182/193); prevalence 57.51% (111/193)
| - pneumatic otoscopy: one of the authors; - tympanometry (REXTON TYMP82): not specified; - myringotomy: not specified | [underlined: Inclusion]:
| [underlined: Study Cohort]: Children undergoing myringotomy due to indication of MEE | - Age: 18 months-12 years; - indication of need for myringotomy (in the majority ~ due to clinically persistent MEE)
| N=121 subjects, 222 ears | [underlined: Exclusion]:
| | - pneumatic otoscopy and tympanometry could not be performed; - lack of cooperation during test procedure or in allowing removal of excessive wax
| | [underlined: Patient Characteristics]:
| | - age range 18 months-12 years
2675 van Balen 1994 | Diagnostic study | [underlined: Time]: 9/1990–8/1991 | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 4 (111010) | [underlined: Place]: Day-care department, University Children's Hospital, Utrecht and the General Hospital, Overvecht, Utrecht, Netherlands | [underlined: Comparisons:]
| [underlined: Examiner(s)]: | [underlined: Affiliation]: Dept. of General Practice, Univ. of Utrecht, Netherlands | 1. Portable tympanometer; Dx-: Type A and C1 tympanogram curves; Dx+: Type B and C2 tympanogram curves; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present | - [underlined: Comparison 1]:; sensitivity 94.23% (147/156); specificity 48.05% (37/77); PPV 78.61% (147/187); NPV 80.43% (37/46); accuracy 78.97% (184/233); prevalence 66.95% (156/233)
| - tympanometry (AR 85 [American Electromedics], 226 Hz probe tone, and microtymp [Welch Allyn], 226 Hz probe tone): general practitioner with special training from ENT department with classification problems discussed with Ear, Nose, and Throat surgeons; - myringotomy: Ear, Nose, and Throat surgeon | [underlined: Inclusion]:
| [underlined: Study Cohort]: Children selected by the Ear, Nose and Throat surgeon for uni- or bilateral myringotomy and/or tympanostomy tube insertion | - Age: 6 months-12 years; - undergoing uni- or bilateral myringtomy and/or tympanostomy tube insertion after referral by General Practitioner
| N=142 subjects, 284 ears | [underlined: Exclusion]:
| | - craniofacial malformations and those w/trisomy 21
| | [underlined: Patient Characteristics]:
| | - age range 6 months-12 years
2713 Vaughan-Jones 1992 | Diagnostic study | [underlined: Time]: not specified | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 2 (100001) | [underlined: Place]: Audiology Department at Ninewells Hospital, Dundee | [underlined: Comparisons]:
| [underlined: Examiner(s)]: | [underlined: Affiliation]: Dept. of Otolaryngology, Ninewells Hospital, Dundee | 1. Pneumatic otoscopy - unvalidated examiner; Dx-: not defined; Dx+: not defined; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 2. Professional tympanometer; Dx-: Type A,C1 & C2 curves; Dx+: Type B curves; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 3. Portable tympanometer; Dx-: Type A and C1 curves; Dx+: Type B and C2 curves; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 4. Professional tympanometry; Dx-: Type A and C1 tympanograms; Dx+: Type B and C2 tympanograms; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 5. Audiometry - air conduction threshold; Dx-: ≤26 dB at 500Hz; Dx+: >26 dB at 500 Hz; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 6. Audiometry - air conduction threshold; Dx-: ≤26 dB at 1000Hz; Dx+: >26 dB at 1000 Hz; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 7. Audiometry - air conduction threshold; Dx-: ≤26 dB at 2000Hz; Dx+: >26 dB at 2000 Hz; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present; 8. Audiometry - air conduction threshold; Dx-: ≤26 dB at 4000Hz; Dx+: > 26 dB at 4000 Hz; Myringotomy (sedated); GS-: fluid absent; GS+: fluid present | - [underlined: Comparison 1]:; sensitivity 89.63% (121/135); specificity 75.38% (49/65); PPV 88.32% (121/137); NPV 77.78% (49/63); accuracy 85.00% (170/200); prevalence 67.50% (135/200); - [underlined: Comparison 2]:; sensitivity 67.41% (91/135); specificity 93.85% (61/65); PPV 95.79% (91/95); NPV 58.10% (61/105); accuracy 76.00% (152/200); prevalence 67.50% (135/200); - [underlined: Comparison 3]:; sensitivity 88.89% (120/135); specificity 63.08% (41/65); PPV 83.33% (120/144); NPV 73.21% (41/56); accuracy 80.50% (161/200); prevalence 67.50% (135/200); - [underlined: Comparison 4]:; sensitivity 88.15% (119/135); specificity 70.77% (46/65); PPV 86.23% (119/138); NPV 74.19% (46/62); accuracy 82.50% (165/200); prevalence 67.50% (135/200); - [underlined: Comparison 5]:; sensitivity 68.15% (92/135); specificity 84.62% (55/65); PPV 90.20% (92/102); NPV 56.12% (55/98); accuracy 73.50% (147/200); prevalence 67.50% (135/200); - [underlined: Comparison 6]:; sensitivity 59.26% (80/135); specificity 93.85% (61/65); PPV 95.24% (80/84); NPV 52.59% (61/116); accuracy 70.50% (141/200); prevalence 67.50% (135/200); - [underlined: Comparison 7]:; sensitivity 32.59% (44/135); specificity 95.38% (62/65); PPV 93.62% (44/47); NPV 40.52% (62/153); accuracy 53.00% (106/200); prevalence 67.50% (135/200); - [underlined: Comparison 8]:; sensitivity 46.67% (63/135); specificity 93.85% (61/65); PPV 94.03% (63/67); NPV 45.86% (61/133); accuracy 62.00% (124/200); prevalence 67.50% (135/200)
| - pneumatic otoscopy: not specified; - audiometry (Audioscope [Welch Allyn] and Madsen OB822 audiometer): not specified; - tympanometry (Microtymp [Welch Allyn], 226 Hz probe tone, and American Electric Model 85, 256 Hz probe tone): not specified; - myringotomy: not specified | [underlined: Inclusion]:
| *For pneumatic otoscopy, the authors do not define a negative or positive test result. | - admitted with a diagnosis of OME and scheduled to undergo myringotomy
| [underlined: Study Cohort]: Children undergoing myringotomy | [underlined: Exclusion]:
| N=100 subjects, 200 ears | - inadequate view of the tympanic membrane or variable audiometric responses
| | [underlined: Patient Characteristics]:
| | - mean age male 6.3 years, female 6.2 years; - male 56, female 44
2758 Watters 1997 | Diagnostic study | [underlined: Time]: 12 month period (11/1/1993–10/1994) | | [underlined: Unit of measure]: Ear
| [underlined: Study Quality Score (0–6)]: 2 (110000) | [underlined: Place:] | [underlined: Comparisons]:
| [underlined: Examiner(s)]: | [underlined: Affiliation]: Dept's of Otolaryngology and Paediatric Audiology, Radcliffe Infirmary, Oxford, UK | 1. Professional tympanometry^a^; Dx-: Type A or C tympanogram; Dx+: Type B tympanogram; Myringotomy (sedation unknown); GS-: fluid absent; GS+: fluid present; 2. Professional tympanometry^b^; Dx-: Type A tympanogram; Dx+: Type B or C tympanograms; Myringotomy (sedation unknown); GS-: fluid absent; GS+: fluid present; 3. Professional tympanometry; Dx-: Type A tympanogram; Dx+: Type B tympanogram; Myringotomy (sedation unknown); GS-: fluid absent; GS+: fluid present | - [underlined: Comparison 1]:; sensitivity 91.14% (679/745); specificity 79.05% (166/210); PPV 93.91% (679/723); NPV 71.55% (166/232); accuracy 88.84% (845/955); prevalence 78.01% (745/955); - [underlined: Comparison 2]:; sensitivity 99.06% (738/745); specificity 33.81% (71/210); PPV 84.15% (738/877); NPV 91.03% (71/78); accuracy 84.71% (809/955); prevalence 78.01% (745/955); - [underlined: Comparison 3]:; sensitivity 98.98% (679/686); specificity 61.74% (74/115); PPV 93.91% (679/723); NPV 91.03% (71/78); accuracy 93.63% (750/801); prevalence 85.64% (686/801)
| - tympanometry (Grayson-Stadler [sic] GS133 Tympanometer): pediatric audiologist; - myringotomy: not specified | [underlined: Inclusion]:
| [underlined: Study Cohort]: Children who underwent surgery (grommet insertion) for possible MEE | - Age: 11 months-15 years; - undergoing surgery (insertion of grommets) for possible MEE
| N=501 subjects, 955 ears | [underlined: Exclusion]:
| | - children with a ‘normal’ tympanogram in one or both ears and had surgery cancelled
| | [underlined: Patient Characteristics]:
| | - age range 11 months-15 years

a DM - pos. cutpoint: For trace at B660 Hz: Class I if suscept. <0.4 mmho, Class III, Class IV; For trace at B220 Hz - Class II if susceptance <0.3 mmho.

DM - negative cutpoint: For trace at B660 Hz - Class I if susc. > or = 0.4 mmh; For trace at B220 Hz - Class II if susceptance ≥0.3 mmho.

a We assumed they considered Type B as positive for effusion and all other types negative although they never state this in the text.

b The authors never officially define negative and positive cutoff points for the diagnostic method; we assumed that the cutoff points we have supplied above are correct based on their comments in the discussion section.

a DM - negative cutoff: equivalent ear canal volume 0.4–2.3 cc; tympanometric peak pressure +200 to -400 daPa; tympanometric Width <180 daPa; DM - positive cutoff: absent tympanometric peak; tympanometric Width >180.

a Pattern 1 = Normal Compliance, Normal Pressure; 2 = Nml comp, negative pressure; 3 = High comp, nml pressure; 4 = low comp, nml pressure; 5 = low comp, pressure high negative, positive, or indeterminate.

b Could not be completed because negative and positive cut-points are not defined for Air-Bone Gap.

a Middle ear muscle reflex testing was also evaluated as a diag. method in this study, but wasn't included in the list of diagnostic test choices.

a Negative cutoff point (continued): air pressure <-100 mm H2O; compliance <5.0 Madsen units; gradient ≥ 0.5 Madsen units. Positive Cut Point (continued): air pressure <-100 mm H2O; compliance ≥5.0 Madsen units; gradient <0.5 Madsen units.

b Negative cutoff: Class I curve with peak susceptance > or = .4mmho at 660 Hz; Class II curve with peak ≥.3 mmhos at 220 Hz. Postive cutoff: Class I curve, peak < .4mmho at 660 Hz; Class II curve, peak <.3mmho at 220 Hz; Class III and IV.

a These are results for otolaryngologist A.

b These results are for otolaryngologist B.

c ME muscle reflex measured using ipsilateral stimulation and ambient pressure; Stimulus frequency = 1000.

d ME muscle reflex measured using ipsilateral stimulation and tympanogram's peak pressure; Stimulus frequency = 1000.

a ME muscle reflex measured using contralateral stimulation and ambient pressure; Stimulus frequency = 1000.

b ME muscle reflex measured using contralateral stimulation and tympanogram's peak pressure; Stimulus frequency = 1000.

c ME muscle reflex measured using ipsilateral stimulation and ambient pressure; Stimulus frequency = 2000.

a ME muscle reflex measured using ipsilateral stimulation and tympanogram's peak pressure; Stimulus frequency = 2000.

b ME muscle reflex measured using contralateral stimulation and ambient pressure; Stimulus frequency = 2000.

c ME muscle reflex measured using contralateral stimulation and tympanogram's peak pressure; Stimulus frequency = 2000.

a Estimated from figure 3.

a These values were calculated from percentages that were provided in the text and thus their accuracy is uncertain.

a Numbers were calculated from percentages and total “n's” presented in Table V.

a Of the 94 ears included the majority underwent myringotomy for recurrent AOM rather than OME; results are not stratified according to rationale for myringotomy. Of 86 children, only 16 had persistent OME; the rest had recurrent OM.

a Combines children undergoing myringotomy for recurrent AOM and persistent OME. Groups are not separated in the analyses.

a The results table includes 102 ears. However, this study was of 118 ears. The authors do not discuss why the other 16 ears were excluded from the results table (Table 1 in the article).

a These data are for tympanograms performed before induction of anesthesia only. Tympanogram classifications: Type I~normal; Type II~endotympanic depression; Type III~endotympanic depression and tympanometric curve rounded by weaker compliance; Type IV~flattened curve; Type V~normal endotympanic pressure and rounded tympanometric curve.

a There were 47 cases where the examiner was undecided; these have been counted as effusion absent (test negative).

b There were 47 cases where the examiner was undecided; these have been counted as effusion present (test positive).

c This result includes the “undecided” group as normal.

a The results table includes the “undecided” group as abnormal.

b There were 47 ears that were not classified as “yes” or “no” pre-operatively; rather they were labeled “undecided.” These 47 are not included in the results table.

a For diagnostic cutoffs, an Admittance value of 0.3 ml was given as the cutpoint; however, not sure whether admittance < or = 0.3 ml would be a negative result for MEE OR values > 0.3.

a For diagnostic cutoffs, a Relative Gradient value of 0.35 was given as the cutpoint; however, not sure whether gradient > 0.35 would be a negative result for MEE (I am assuming it is).

a These results examine sensitivity of type B tympanograms in detecting OME in children with either transient or prolonged effusion. Prolonged = effusion still present 4 weeks after myringotomy. Transient = ear healthy 4 weeks after myringotomy.

Findings excludes 4 ears that were found to have purulent effusion which is consistent with AOM and not OME and 2 where Professional tympanometry result ‘unclassified.’ According to Table 1 in the article those with Class 1 or 5 changes initially had normal (non-flat) tympanograms.

Data neccesary to complete the results table were not provided.

a The raw numbers are calculated using a combination of information from table 2,3, and Table 5 in article.

These results are for the “cooperative” group. These are combined results for children undergoing myringotomy for recurrent AOM and OME; results are not stratified on this variable.

These results are for the “uncooperative” group. These are combined results for children undergoing myringotomy for recurrent AOM and OME; results are not stratified on this variable.

These results are for the “cooperative” and “uncooperative” groups combined. Combined results for children undergoing myringotomy for recurrent AOM & OME; results aren't stratified on this variable.

These are combined results for children undergoing myringotomy for recurrent AOM & OME; results are not stratified on this variable. Raw numbers were not provided for the results stratified by age.

This study combines children undergoing myringotomy for recurrent AOM and OME. The results are not stratified on this variable.

The values in the results table were calculated using the sensitivity and specificity provided in Table 2 in article; total “ns” of right and left ears examined (n=100 and n=98 respectively) and percentage of ears with fluid (67% and 62% respectively).

a Observer described as ‘Senior Registrar.’

a Observer described as ‘Senior House Officer with just several months experience.’

a The authors state that specificity could not be determined from the small number of ears without middle ear effusion on tympanocentesis.:

a Values in the results table were determined by using the values provided in the text of this article which state no MEE group = 30 and MEE group = 81. Combining this information with the provided sensitivity and specificity allowed calculation of the numbers.

a Values in the above results table were determined by using the values provided in the text of this article which state no MEE group = 135 and MEE group = 9. Combining this information with the provided sensitivity and specificity allowed calculation of the numbers.

a Values in the above results table were calculated based on numbers provided under results on pg. 312 in article.

a In this results table the type “c” tympanograms are included as normals.

b Values derived from false positive % and false negative % reported in Table VI for acoustic reflex and total numbers of normal and abnormal ears as reported in Table 2.

a Specificity data might be abstractable from this article for these cutpoints.

a Excluded data presented for type “c” tympanograms. Classified ears with “none” and “minimal” effusion as = no effusion. Classified ears with “moderate” or “impacted” as = +effusion.

b Type “c” and “cs” tympanograms are included as “normals.” Classified ears with “none” and “minimal” effusion as = no effusion. Classified ears with “moderate” or “impacted” as = +effusion.

c Type “c” and “cs” tympanograms are included as “abnormals.” Classified ears with “none” and “minimal” effusion as = no effusion. Classified ears with “moderate” or “impacted” as = +effusion.

a Excluded data presented for type “c” tympanograms. Ears with “none” and “minimal” effusion classified as = no effusion; ears with “moderate” or “impacted” as = +effusion.

b Type “c” tympanograms are included as “normals.” Ears with “none” and “minimal” effusion classified as = no effusion; ears with “moderate” or “impacted” as = +effusion.

a Excludes cases where no operation was performed. It also excludes cases where an operation was performed and the tympanogram was type C1 or C2.

b Excludes cases where no operation was performed. Type C1 and C2 are classified as “normal” in the above results table.

c Excludes cases where no operation was performed. Type A and C1 are classified as “normal”and type B and C2 are classified as “abnormal” in the above results table.

d Excludes cases where no operation was performed. Type A is classified as “normal”and types B, C1, and C2 are classified as “abnormal” in the above results table.

a All children in this group had fluid on myringotomy, thus specificity cannot be determined for this group.

a Ears with fluid “suspected” as having effusion are included as false negatives. Fluid-free ears “suspected” as having effusion included as false positives. “Not examined” ear included as false negatives.

b Ears with fluid “suspected” as having effusion are included as true positives. Effusion-free ears “suspected” as having effusion included as false positives. The one ear “not examined” is not included.

c Ears in the “suspect” category are not included. The one ear that was not examined is not included.

a Results are based on the tympanogram readings 1 hour before myringotomy.

b Results are based on the tympanograms obtained immediately before myringotomy.

a This is a pre-, post-anesthesia study looking at the effects on tympanometry. Pre-operative results were used.

a The above results table excludes type “C” tympanograms.

b The above results table includes type “C” tympanograms as normal.

c The above results table includes type “C” tympanograms.

a Adenoid hypertrophy present in this group.

b Adenoid hypertrophy absent in this group.

a The above results table excludes all ears with type “C” tympanograms.

b The above results table includes type “C” tympanograms as normal.

c The above results table includes type “C” tympanograms as abnormal.

a The above results table includes type “C” tympanograms as normal.

b The above results table includes type “C” tympanograms as abnormal.

c The above results table excludes all ears with type “C“ tympanograms.

a This results table includes type “C” tympanograms as normal.

b This results table includes type “C” tympanograms as abnormal.