# Bibliography

Ababii, II, D'Iakova S A, Antokhii IN, Maniuk MK. [Short-latency auditory evoked potentials in infants with otitis media]. Vestn Otorinolaringol. 1995:28–31.
Abdullah V A, Pringle M B, Shah N S. Use of the trimmed Shah permavent tube in the management of glue ear. J Laryngol Otol. 1994;108:303-306. [pmid: 8182314].
Abolfotouh M A, Ghieth M M, Badawi I A. Hearing loss and other ear problems among schoolboys in Abha, Saudi Arabia. Ann Saudi Med. 1995;15:323-326. [pmid: 17590599].
Abraham S S, Wallace I F, Gravel J S. Early otitis media and phonological development at age 2 years. Laryngoscope. 1996;106:727-732. [pmid: 8656958].
Abramovich S J. Hearing investigation in relation to the duration of acoustic signals. Laryngoscope. 1978;88:334-341. [pmid: 621999].
Abramovich S, O'Grady J, Fuller A, MacKinnon M, Lavelle R. Naproxen in otitis media with effusion. J Laryngol Otol. 1986;100:263-266. [pmid: 3512747].
Abramson M. Topical anesthesia of the tympanic membrane. Arch-Otolaryngol. 1969;90:147-149. [pmid: 4893853].
Adachi M, Hayashi A, Ohkoshi N, et al. Hypertrophic cranial pachymeningitis with spinal epidural granulomatous lesion. Intern Med. 1995;34:806-810. [pmid: 8563127].
Adair-Bischoff C E, Sauve R S, Kimberley B, Brant R. Smoking and middle ear disease [letter; comment]. Otolaryngol Head Neck Surg. 1996;114:837-840. [pmid: 8643317].
Adam D. Five-day therapy with cefpodoxime versus ten-day treatment with cefaclor in infants with acute otitis media. Infection. 1995;23:398-400.
Adam D. Modern cephalosporins as therapeutics for otitis media. Infect Dis Clin Res Pract. 1998;7:S96-S98.
Adams G L, Paparella M M, el-Fiky F M. Primary and metastatic tumors of the temporal bone. Laryngoscope. 1971;81:1273-1285. [pmid: 4328134].
Adams J L. Early recurrent otitis media and mother-child communication. MCN, Am J Matern Child Nurs. 1983;8:261. [pmid: 6412017].
Adams J L, Evans G A, Roberts J E. Diagnosing and treating otitis media with effusion. MCN, Am J Matern Child Nurs. 1984;9:22-28. [pmid: 6422183].
Adelman C, Linder N, Levi H. Auditory nerve and brain stem evoked response thresholds in infants treated with gentamicin as neonates. Ann Otol Rhinol Laryngol. 1989;98:283-286. [pmid: 2705702].
Adelman A. Water precautions in children with tympanostomy tubes. J Fam Pract. 1996;42:567-568. [pmid: 8656164].
Adesman A R, Altshuler L A, Lipkin P H, Walco G A. Otitis media in children with learning disabilities and in children with attention deficit disorder with hyperactivity. Pediatrics. 1990;85:442-446. [pmid: 2304807].
Adler M, McDonald P J, Trostmann U, Keyserling C, Tack K. Cefdinir versus amoxicillin/clavulanic acid in the treatment of suppurative acute otitis media in children. Eur J Clin Microbiol Infect Dis. 1997;16:214-219. [pmid: 9131324].
Adlington P, Davies J R. Virus studies in secretory otitis media. J Laryngol Otol. 1969;83:161-173. [pmid: 5787424].
Agarwal P N, Mishra S D, Pratap V K. Primary liposarcoma of the mastoid. J Laryngol Otol. 1975;89:1079-1082. [pmid: 811743].
Agius A M, Wake M, Pahor A L, Smallman L A. Surface morphology of middle ear epithelium in chronic ear disease. J Laryngol Otol. 1994;108:1024-1030. [pmid: 7861075].
Agius A M, Wake M, Pahor A L, Smallman A. The effects of in vitro cotitine on nasal ciliary beat frequency. Clin Otolaryngol Allied Sci. 1995;20:465-469. [pmid: 8582082].
Agius A M, Wake M, Pahor A L, Smallman L A. Smoking and middle ear ciliary beat frequency in otitis media with effusion. Acta Otolaryngol. 1995;115:44-49. [pmid: 7762384].
Agius A M, Wake M, Pahor A L, Smallman L A. Nasal and middle ear ciliary beat frequency in chronic suppurative otitis media. Clin Otolaryngol. 1995;20:470-474. [pmid: 8582083].
Ahuja G S, Thompson J. What role for antibiotics in otitis media and sinusitis?. Postgrad Med. 1998;104:93-104. [pmid: 9742906].
Aikawa J, Munakata H, Isemura M, et al. Sulfated glycopeptides from middle ear effusions of secretory otitis media. Tohoku J Exp Med. 1985;146:461-467. [pmid: 4071540].
Aithal V, Aithal S, Pulotu L. Otitis media with effusion in children: an audiological case series study. P N G Med J. 1995;38:79-94. [pmid: 9599971].
Akkoyunlu M, Forsgren A. Local and systemic antibody levels against protein D of Haemophilus influenzae following immunization and infection in rats. APMIS. 1996;104:709-717. [pmid: 8980621].
Akpede G O. Localized extracranial infections in children with acute bacterial meningitis. J Trop Pediatr. 1994;40:231-234. [pmid: 7932937].
al Anazy F H, Zakzouk S M. The impact of social and environmental changes on allergic rhinitis among Saudi children. A clinical and allergological study. Int J Pediatr Otorhinolaryngol. 1997;42:1-9. [pmid: 9477347].
al-Serhani A M. Mastoid abscess: underlying disease and management. Am J Otol. 1996;17:694-696. [pmid: 8892562].
Albers F W. [Neuro-otological complications of middle ear infections; the importance of early diagnosis (see comments)]. Ned Tijdschr Geneeskd. 1996;140:1726-1729. [pmid: 8848060].
Alberti P W. Glue ear. Br Med J. 1970;1:431-432. [pmid: 5434669].
Albu S, Babighian G, Trabalzini F. Prognostic factors in tympanoplasty. Am J Otol. 1998;19:136-140. [pmid: 9520047].
Alford B R, McFarlane J R, Neely J G. Homograft replacement of the tympanic membrane. Laryngoscope. 1976;86:199-208. [pmid: 1053359].
Alho O P, Koivu M, Hartikainen-Sorri A L, Sorri M, Kilkku O, Rantakallio P. Is a child's history of acute otitis media and respiratory infection already determined in the antenatal and perinatal period?. Int J Pediatr Otorhinolaryngol. 1990;19:129-137. [pmid: 2373597].
Alho O P, Kilkku O, Oja H, Koivu M, Sorri M. Control of the temporal aspect when considering risk factors for acute otitis media. Arch Otolaryngol Head Neck Surg. 1993;119:444-449. [pmid: 8457307].
Alho O P, Koivu M, Sorri M, Oja H, Kilkku O. Which children are being operated on for recurrent acute otitis media?. Arch Otolaryngol Head Neck Surg. 1994;120:807-811. [pmid: 8049040].
Alho O P, Oja H, Koivu M, Sorri M. Chronic otitis media with effusion in infancy. How frequent is it? How does it develop?. Arch Otolaryngol Head Neck Surg. 1995;121:432-436. [pmid: 7702818].
Alho O P, Oja H, Koivu M, Sorri M. Risk factors for chronic otitis media with effusion in infancy. Each acute otitis media episode induces a high but transient risk. Arch Otolaryngol Head Neck Surg. 1995;121:839-843. [pmid: 7619407].
Alho O P, Laara E, Oja H. What is the natural history of recurrent acute otitis media in infancy?. J Fam Pract. 1996;43:258-264. [pmid: 8797753].
Alho O P, Laara E, Oja H. Public health impact of various risk factors for acute otitis media in northern Finland. Am J Epidemiol. 1996;143:1149-1156. [pmid: 8633605].
Alho O P, Laara, Oja H. How should relative risk estimates for acute otitis media in children aged less than 2 years be perceived?. J Clin Epidemiol. 1996;49:9-14. [pmid: 8598517].
Alho O P. How common is recurrent acute otitis media?. Acta Oto-Laryngologica - Supplement. 1997;529:8-10.
Alho O P, Koivunen P, Luotonen J, Linder T E, Grenier B. Diagnostic criteria for otitis media in children. Oto Rhino Laryngologia Nova. 1998;8:123-128.
Aligne C A. Influenza A vaccine and the incidence of otitis media [letter; comment]. Arch Pediatr Adolesc Med. 1996;150:652-653. [pmid: 8646324].
Aligne C A, Stoddard J J. Tobacco and children. An economic evaluation of the medical effects of parental smoking. Arch Pediatr Adolesc Med. 1997;151:648-653. [pmid: 9232036].
Allen D V, Robinson D O. Middle ear status and language development in preschool children. ASHA. 1984;26:33-37. [pmid: 6743372].
Allen M C, Schubert-Sudia S E. Prevention of prelingual hearing impairment. Seminars in Hearing. 1990;11:134-149.
Allen G C, Tiu C, Koike K, Ritchey A K, Kurs-Lasky M, Wax M K. Transient-evoked otoacoustic emissions in children after cisplatin chemotherapy. Otolaryngol Head Neck Surg. 1998;118:584-588. [pmid: 9591854].
Almadori G, Del Ninno M, Cadoni G, Di Mario A, Ottaviani F. Facial nerve paralysis in acute otomastoiditis as presenting symptom of FAB M2, T8;21 leukemic relapse. Case report and review of the literature. Int J Pediatr Otorhinolaryngol. 1996;36:45-52. [pmid: 8803691].
Almadori G, Trivelli M, Scarano E, Cadoni G. Misleading clinical features in Wegener's granulomatosis. A case report. J Laryngol Otol. 1997;111:746-748. [pmid: 9327013].
Alper C M, Doyle W J, Seroky J T, Bluestone C D. Efficacy of clarithromycin treatment of acute otitis media caused by infection with penicillin-susceptible, -intermediate, and -resistant Streptococcus pneumoniae in the chinchilla. Antimicrob Agents Chemother. 1996;40:1889-1892. [pmcid: 163435]. [pmid: 8843299].
Alper C M, Tabari R, Seroky J T, Doyle W J. Magnetic resonance imaging of the development of otitis media with effusion caused by functional obstruction of the eustachian tube. Ann Otol Rhinol Laryngol. 1997;106:422-431. [pmid: 9153108].
Alsarraf R, Jung C J, Perkins J, Crowley C, Gates G A. Otitis media health status evaluation: a pilot study for the investigation of cost-effective outcomes of recurrent acute otitis media treatment. Ann Otol Rhinol Laryngol. 1998;107:120-128. [pmid: 9486906].
Althaus S R. Surgery on the only hearing ear. Laryngoscope. 1981;91:765-770. [pmid: 7231025].
Altman J S, Haupert M S, Hamaker R A, Belenky W M. Phenylephrine and the prevention of postoperative tympanostomy tube obstruction. Arch Otolaryngol Head Neck Surg. 1998;124:1233-1236. [pmid: 9821925].
Altuntas A, Aslan A, Eren N, Unal A, Nalca Y. Susceptibility of microorganisms isolated from chronic suppurative otitis media to ciprofloxacin. Eur Arch Otorhinolaryngol. 1996;253:364-366. [pmid: 8858262].
Alvarez Acevedo G, Carrillo Esper R, Hernandez Palestina M, Volkow Fernandez P. [ENT nosocomial infections in the intestinal care unit]. An Otorrinolaringol Ibero Am. 1994;21:629-639. [pmid: 7864308].
Alvart R. An open multicentre study to compare the efficacy and safety of sultamicillin with that of cefuroxime axetil in acute ear nose and throat infections in adults. J Int Med Res. 1992:53A–61A.
Alzamil K S, Linthicum F H Jr. Tympanosclerosis. Am J Otol. 1999;20:686-687. [pmid: 10503596].
Amadasun J E. The cost effective medical treatment of suppurative otitis media in a Nigerian environment. West Afr J Med. 1997;16:85-87. [pmid: 9257542].
Amador J M, Esquivias J J, Ciges M. [A CT cytomorphodensitometric study of the proliferating epithelial activity in middle ear cholesteatoma]. Acta Otorrinolaringol Esp. 1994;45:153-159. [pmid: 8068356].
Amedee R G. The effects of chronic otitis media with effusion on the measurement of transiently evoked otoacoustic emissions. Laryngoscope. 1995;105:589-595. [pmid: 7769941].
Aminifarshidmehr N. The management of chronic suppurative otitis media with acid media solution. Am J Otol. 1996;17:24-25. [pmid: 8694129].
Ammann AJ, Ashman RF, Buckley RH, et al. Use of intravenous gamma -globulin in antibody immunodeficiency: Results of a multicenter controlled trial. CLIN-IMMUNOL-IMMUNOPATHOL. 1982:60–67.
Anagnostakis D, Petmezakis J, Papazissis G, Messaritakis J, Matsaniotis N. Hearing loss in low-birth-weight infants. Am J Dis Child. 1982;136:602-604. [pmid: 7201236].
Anari M, Cederberg A, Ernstson S. The effect of cefaclor on the nasopharyngeal flora in children with chronic OME. Acta-Otolaryngol-Suppl-Stockh. 1985:13–16.
Andersen M S, Meistrup-Larsen U, Meistrup-Larsen K I, Peitersen E. The effect of adenoidectomy on secretory otitis media in children. Acta Oto-Laryngologica - Supplement. 1979;360:195-197.
Andersen A B, Ag G, Stenfors L E. Occurrence of otitis media in an arctic region. Acta Oto-Laryngologica - Supplement. 1997;529:11-13.
Anderson H, Filipsson R, Fluur E, Koch B, Lindsten J, Wedenberg E. Hearing impairment in Turner's syndrome. Acta Otolaryngol. 1969;:Suppl:1–26.
Anderson H, Barr B. Conductive high-tone hearing loss. Arch Otolaryngol. 1971;93:599-605. [pmid: 5556022].
Andreasson L, Harris S. Tympanoplasty and eustachian tube function. Clin Otolaryngol Allied Sci. 1978;3:421-430. [pmid: 743789].
Andreasson L, Harris S, Ivarsson A. Pulse volume recordings in outer ear canal in pulse synchronous tinnitus. A comparison between ears with Glomus tumour, serous otitis media, and normal ears. Acta Otolaryngol. 1978;86:241-247. [pmid: 212926].
Andreasson L, Harris S. Middle ear mechanics and Eustachian tube function in tympanoplasty. Acta Oto-Laryngologica - Supplement. 1979;360:141-147.
Andreasson L, Bylander A, Ivarsson A, Tjernstrom O. Treatment with sulfur hexafluoride in children with serous otitis media. An alternative to tubulation. Arch Otolaryngol. 1983;109:358-359. [pmid: 6682653].
Andrews J C, Canalis R F. Otogenic pneumocephalus. Laryngoscope. 1986;96:521-528. [pmid: 3702568].
Angeli S I, Luxford W M, Lo W W. Magnetic resonance imaging in the evaluation of Langerhans' cell histiocytosis of the temporal bone: case report. Otolaryngol Head Neck Surg. 1996;114:120-124. [pmid: 8570233].
Anggard A, Malm L. Orally administered decongestant drugs in disorders of the upper respiratory passages: A survey of clinical results. Clin Otolaryngol Allied Sci. 1984;9:43-49. [pmid: 6202443].
Aniansson G. Screening diagnosis of secretory otitis media. Scand Audiol Suppl. 1986;26:65-69. [pmid: 3472329].
Aniansson G, Alm B, Andersson B, et al. A prospective cohort study on breast-feeding and otitis media in Swedish infants. Pediatr Infect Dis J. 1994;13:183-188. [pmid: 8177624].
Anker J. Proceedings: Preservation of hearing in children with chronic otitis media with cholesteatoma formation. ORL J Otorhinolaryngol Relat Spec. 1975;37:359. [pmid: 1239709].
Anonymous. Phenethicillin and penicillin V in the treatment of acute otitis media in children: a comparative trial from general practice. Lancet. 1962;1:947–949.
Anonymous. Glue ear. Br Med J. 1969;4:578.
Anonymous. Local treatment with a corticosteroid-antibiotic preparation in infections of the ear. Practitioner. 1970;205:691–695.
Anonymous. Outcome of acute otitis media. Lancet. 1970;1:283–284.
Anonymous. Advertisements for hetacillin. Med Lett Drugs Ther. 1972;14:38–39.
Anonymous. Trimethoprim-sulfamethoxazole in the treatment of bacterial infections: report of clinical trials in Japan. J Infect Dis. 1973:Suppl:629–35.
Anonymous. Grand rounds at the Albert Einstein College of Medicine Bronx, New York. Ann Otol Rhinol Laryngol. 1973;82:734–744.
Anonymous. Common hearing disorders. Methods of diagnosis and treatment. Geriatrics. 1974;29:49–55 passim.
Anonymous. Editorial: Tests of hearing in school. Br Med J. 1974;2:3.
Anonymous. Editorial: The glue-ear syndrome. Lancet. 1975;2:397–398.
Anonymous. Summary Reports on National-International Conferences. Use of acoustic impedance measurement in screening for middle ear disease in children. Ann Otol Rhinol Laryngol. 1978;87:288–292.
Anonymous. [Results of treatment with cefaclor, a new oral cephalosporin]. Fortschr-Med. 1979;97:1709–1710.
Anonymous. Otitis media and child development. Ann Otol Rhinol Laryngol Suppl. 1979;88:1–111.
Anonymous. Report of Research on Conference on Recent Advances in Otitis Media with Effusion. Ann Otol Rhinol Laryngol Suppl. 1980;89:1–28.
Anonymous. Doctors' discussion. Am J Otol. 1981;2:291–293.
Anonymous. Recommended procedure for pure-tone bone-conduction audiometry without masking using a manually operated instrument. British Society of Audiology--technical note. Br J Audiol. 1985;19:281–282.
Anonymous. Third International Symposium on Audiological Medicine. Visby, Gotland, Sweden, August 18–21, 1985. Pharmacological treatment of inner ear disorders. Audiological aspects of secretory otitis media. Scand Audiol Suppl. 1986;26:1–96.
Anonymous. Glue ear in children: Medical management. Drug Ther Bull. 1986;24:22–24.
Anonymous. Case records of the Massachusetts General Hospital. Weekly clinicopathological exercises. Case 25-1987. A seven-year-old Japanese-American boy with persistent right-ear drainage despite antibiotic therapy. N Engl J Med. 1987;316:1589–1597.
Anonymous. American Academy of Pediatrics Committee on School Health: Impedance bridge (tympanometer) as a screening device in schools. Pediatrics. 1987;79:472.
Anonymous. Single-dose intramuscular ceftriaxone for acute otitis media in children [news]. Eur J Pediatr. 1993;152:535.
Anonymous. [Infections in childhood; from respiratory infections to tropical medicine]. Fortschr Med Suppl. 1993;144:1–8.
Anonymous. Mechanical blockage of the nose. Annals of Allergy. 1993;70:204–205.
Anonymous. Otitis media with effusion in young children. Guideline overview. Agency for Health Care Policy and Research, Rockville, Maryland [news]. J Natl Med Assoc. 1994;86:731–732, 792–793.
Anonymous. Fumes from the spleen [letter]. Paediatr Perinat Epidemiol. 1994;8:359–362.
Anonymous. Federal guidelines offer choices for treatment of otitis media with effusion [news]. Am J Hosp Pharm. 1994;51:2320.
Anonymous. Managing otitis media with effusion in young children. Otitis Media Guideline Panel [see comments]. Am Fam Physician. 1994;50:1003–1010.
Anonymous. Managing otitis media with effusion in young children. American Academy of Pediatrics The Otitis Media Guideline Panel. Pediatrics. 1994;94:766–773.
Anonymous. Recent Advances in Otitis Media Treatment. Symposium proceedings. Minneapolis, Minnesota, October 1, 1993. Ann Otol Rhinol Laryngol Suppl. 1994;163:1–64.
Anonymous. Recent Advances in Otitis Media. Report of the 5th research conference. Fort Lauderdale, Florida, May 20–24, 1991. Ann Otol Rhinol Laryngol Suppl. 1994;164:1–80.
Anonymous. Managing otitis media with effusion in young children. Agency for Health Care Policy and Research. Clinical Practice Guideline - Quick Reference Guide for Clinicians. 1994:1–13.
Anonymous. Drugs for treatment of acute otitis media in children. Med Lett Drugs Ther. 1994;36:19–21.
Anonymous. Who has hearing, speech, and language problems? ASHA. 1995;37:38–39.
Anonymous. Management of acute otitis media and glue ear. Drug Ther Bull. 1995;33:12–15.
Anonymous. Practice guidelines: chronic otitis media/chronic mastoiditis/cholesteatoma. ORL - Head and Neck Nursing. 1995;13:22–23.
Anonymous. Young children at day care centers at most risk for pneumococcal disease. Pediatr Dent. 1995;17:186.
Anonymous. [Restrictive prescription of antibiotics requires early follow-up]. Lakartidningen. 1996;93:28–29.
Anonymous. Now hear this. Lippincott Health Promotion Letter. 1997;2:3.
Anonymous. Environmental tobacco smoke: a hazard to children. American Academy of Pediatrics Committee on Environmental Health. Pediatrics. 1997;99:639–642.
Anonymous. [Guidelines/algorithms of the German Society of Otorhinolaryngology, Head and Neck Surgery]. HNO. 1997;45:202–204.
Anonymous. [ORL infections. 10th consensus conference on anti-infectious therapeutics. Under the collaboration of the French Societies of Infectious Diseases, of ORL and of Pediatrics]. Arch Pediatr. 1997;4:188–194.
Anonymous. Palivizumab, a humanized respiratory syncytial virus monoclonal antibody, reduces hospitalization from respiratory syncytial virus infection in high-risk infants. The IMpact-RSV Study Group [see comments]. Pediatrics. 1998;102:531–537.
Anonymous. Sensitivity, specificity and predictive value of tympanometry in predicting a hearing impairment in otitis media with effusion. MRC Multi-Centre Otitis Media Study Group. Clin Otolaryngol Allied Sci. 1999;24:294–300.
Anteby I, Hafner H, Pratt H, Uri N. Auditory brainstem evoked potentials in evaluating the central effects of middle ear effusion. Int J Pediatr Otorhinolaryngol. 1986;12:1-11. [pmid: 3818185].
Anteunis L J. Middle ear pressures in patients with nasopharyngeal carcinoma and their clinical significance [letter; comment]. J Laryngol Otol. 1996;110:107. [pmid: 8745799].
Anteunis LJC, Engel JAM, Hendriks JJT, Marres EHMA. Hearing loss in infants with early otitis media with effusion. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:359–361.
Anteunis L J, Engel J A, Hendriks J J, Manni J J. A longitudinal study of the validity of parental reporting in the detection of otitis media and related hearing impairment in infancy. Audiology. 1999;38:75-82. [pmid: 10206516].
Antonelli A, Cimino A, Cimino A, et al. [The treatment of ENT phlogosis: seaprose S vs. nimesulide]. Acta-Otorhinolaryngol-Ital. 1993:1–16.
Antonelli P J, Juhn S K, Goycoolea M V, Giebink G S. Middle ear susceptibility to Pseudomonas infection during acute otitis media. Ann Otol Rhinol Laryngol. 1993;102:531-536. [pmid: 8333675].
Antonelli P J, Daly K A, Juhn S K, Veum E J, Adams G L, Giebink G S. Tobacco smoke and otitis media in the chinchilla model. Otolaryngol Head Neck Surg. 1994;111:513-518. [pmid: 7936688].
Antonelli P J, Juhn S K, Le C T, Giebink G S. Acute otitis media increases middle ear susceptibility to nasal injection of Pseudomonas aeruginosa. Otolaryngol Head Neck Surg. 1994;110:115-121. [pmid: 8290293].
Antonelli P J, Bouchard K R, Kartush J M. Carbon dioxide laser occlusion of the guinea pig posterior semicircular canal. Otolaryngol Head Neck Surg. 1995;113:453-458. [pmid: 7567020].
Anvar B, Mencher G T, Keet S J. Hearing loss and congenital rubella in Atlantic Canada. Ear Hear. 1984;5:340-345. [pmid: 6510579].
Aoki N. Air in acute epidural hematomas. Report of two cases. J Neurosurg. 1986;65:555-556. [pmid: 3760966].
Aoyagi M, Kiren T, Furuse H, et al. Pure-tone threshold prediction by 80-Hz amplitude-modulation following response. Acta Oto-Laryngologica - Supplement. 1994;511:7-14.
Aoyagi M, Yokota M, Nakamura T, et al. Effects of aging on hearing results in tympanoplasty. Acta Oto-Laryngologica - Supplement. 1994;511:81-86.
Aoyagi M, Yamazaki Y, Yokota M, et al. Frequency specificity of 80-Hz amplitude-modulation following response. Acta Oto-Laryngologica - Supplement. 1996;522:6-10.
Aoyagi M, Suzuki Y, Yokota M, Furuse H, Watanabe T, Ito T. Reliability of 80-Hz amplitude-modulation-following response detected by phase coherence. Audiology and Neuro-Otology. 1999;4:28-37. [pmid: 9873150].
Apostolopoulos K, Xenelis J, Tzagaroulakis A, Kandiloros D, Yiotakis J, Papafragou K. The point prevalence of otitis media with effusion among school children in Greece. Int J Pediatr Otorhinolaryngol. 1998;44:207-214. [pmid: 9780065].
Appelman C L, Claessen J Q, Touw-Otten F W, Hordijk G J, de Melker R A. Co-amoxiclav in recurrent acute otitis media: placebo controlled study. Br Med J. 1991;303:1450-1452. [pmid: 1773154]. [pmcid: 1671677].
Appelman CLM, Claessen HQPJ, Touw-Otten FWMM, Hordijk GJ, De Melker RA. Efficacy of amoxicillin-clavulanate in recurrent acute otitis media: a placebo-controlled study. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:242–245.
Appelman C L, Claessen J Q, Touw-Otten F W, Hordijk G J, de Melker R A. Severity of inflammation of tympanic membrane as predictor of clinical course of recurrent acute otitis media. Br Med J. 1993;306:895. [pmid: 8490414]. [pmcid: 1677400].
Arcand P, Gauthier P, Bilodeau G, et al. Post-myringotomy care: a prospective study. J-Otolaryngol. 1984;13:305-308. [pmid: 6085804].
Arcand P, Cerat J, Spenard J R. Acute otomastoiditis in the leukemic child. J Otolaryngol. 1989;18:380-383. [pmid: 2593223].
Arcia E, Roberts J E. Otitis media in early childhood and its association with sustained attention in structured situations. J Dev Behav Pediatr. 1993;14:181-183. [pmid: 8340473].
Arellano B, Gonzalez F M, Pinilla M T, Ramirez-Camacho R A, Vergara J. [Effectiveness of imaging diagnosis in chronic otitis media]. Acta Otorrinolaringol Esp. 1996;47:435-437. [pmid: 9044581].
Arenberg I K, Zoller S A, Van de Water S M. The results of the first 300 consecutive endolymphatic system-mastoid shunts with valve implants for hydrops. Otolaryngol Clin North Am. 1983;16:153-174. [pmid: 6856302].
Arguedas A G, Zaleska M, Stutman H R, Blumer J L, Hains C S. Comparative trial of cefprozil vs. amoxicillin clavulanate potassium in the treatment of children with acute otitis media with effusion. Pediatr Infect Dis J. 1991;10:375-380. [pmid: 1906160].
Arguedas A G, Herrera J F, Faingezicht I, Mohs E. Ceftazidime for therapy of children with chronic suppurative otitis media without cholesteatoma. Pediatr Infect Dis J. 1993;12:246-248. [pmid: 8451104].
Arguedas A, Loaiza C, Herrera J F, Mohs E. Antimicrobial therapy for children with chronic suppurative otitis media without cholesteatoma. Pediatr Infect Dis J. 1994;13:878-882. [pmid: 7854886].
Arguedas A, Loaiza C, Herrera M, Mohs E. Comparative trial of 3-day azithromycin versus 10-day amoxycillin /clavulanate potassium in the treatment of children with acute otitis media with effusion. International Journal of Antimicrobial Agents. 1996;6:233-238. [pmid: 18611713].
Arguedas A, Loaiza C, Rodriguez F, Herrera M L, Mohs E. Comparative trial of 3 days of azithromycin versus 10 days of clarithromycin in the treatment of children with acute otitis media with effusion. J Chemother. 1997;9:44-50. [pmid: 9106017].
Arguedas A, Loaiza C, Perez A, et al. Microbiology of acute otitis media in Costa Rican children. Pediatr Infect Dis J. 1998;17:680-689. [pmid: 9726340].
Armengot M, Escribano A, Carda C, Basterra J. Clinical and ultrastructural correlations in nasal mucociliary function observed in children with recurrent airways infections. Int J Pediatr Otorhinolaryngol. 1995;32:143-151. [pmid: 7657468].
Armengot M, Juan G, Carda C, Basterra J, Cano B. [The prevalence of primary dyskinetic ciliary syndromes in patients with sinusitis and bronchiectasis]. An Otorrinolaringol Ibero Am. 1995;22:85-92. [pmid: 7710015].
Armstrong B W, Armstrong R B. Tympanostomy tubes, their use, abuse, and cost-benefit ratio. Laryngoscope. 1979;89:443-449. [pmid: 107381].
Arnold W, Ganzer U, Kleinmann H. Sensorineural hearing loss in mucous otitis. Arch Otorhinolaryngol. 1977;215:91-93. [pmid: 577143].
Arnold S A, Brown O E, Finitzo T. Hearing loss in children with congenital heart disease: a preliminary report. Int J Pediatr Otorhinolaryngol. 1986;11:287-293. [pmid: 3771108].
Arnold B, Schorn K, Stecker M. Screening of hearing disorders in newborns within the European Community. Laryngo Rhino Otologie. 1995;74:172-178. [pmid: 7755855].
Arola M, Ziegler T, Puhakka H, Lehtonen O P, Ruuskanen O. Rhinovirus in otitis media with effusion. Ann Otol Rhinol Laryngol. 1990;99:451-453. [pmid: 2161634].
Aronoff SC. Antimicrobials in children and the problem of drug resistance [editorial]. Am Fam Physician. 1996;54:44–46, 54, 56.
Aronovitz G H. Treatment of otitis media with cefuroxime axetil. South Med J. 1988;81:978-980. [pmid: 3043692].
Aronovitz G. A multicenter, open label trial of azithromycin vs. amoxicillin/ clavulanate for the management of acute otitis media in children. Pediatr Infect Dis J. 1996;15:S15-S19. [pmid: 8878241].
Arriaga M A, Bluestone C D, Stool S E. The role of tympanocentesis in the management of infants with sepsis. Laryngoscope. 1989;99:1048-1051. [pmid: 2796554].
Arriaga M A, Carrier D. MRI and clinical decisions in cochlear implantation. Am J Otol. 1996;17:547-553. [pmid: 8841699].
Arslan E, Turrini M, Lupi G, Genovese E, Orzan E. Hearing threshold assessment with auditory brainstem response (ABR) and ElectroCochleoGraphy (ECochG) in uncooperative children. Scand Audiol Suppl. 1997;46:32-37. [pmid: 9309836].
Artyushkin A V, Artyushkina E A. Radionuclide investigation using 99mTc-phosphonium in patients with ear diseases. Meditsinskaia Radiologiia. 1987;32:47-51.
Arulkumaran S, Skurr B, Tong H, Kek L P, Yeoh K H, Ratnam S S. No evidence of hearing loss due to fetal acoustic stimulation test. Obstet Gynecol. 1991;78:283-285. [pmid: 2067776].
Ashby J K, Pope G D, Barron S J. A reliability study of the electro-acoustic impedance bridge in private pediatric practice. Am J Otol. 1980;1:168-170. [pmid: 7457581].
Asher E S, Evans J H, Wright R F, Wazen J J. Fabrication and use of a surgical template for placing implants to retain an auricular prosthesis. J Prosthet Dent. 1999;81:228-233. [pmid: 9922439].
Ashikaga R, Araki Y, Ishida O. Bilateral aberrant internal carotid arteries. Neuroradiology. 1995;37:655-657. [pmid: 8748899].
Ashoor A. Hearing levels of school children in Dammam. J Laryngol Otol. 1983;97:37-41. [pmid: 6822769].
Asmar B I, Dajani A S, Del-Beccaro M A, Mendelman P M. Comparison of cefpodoxime proxetil and cefixime in the treatment of acute otitis media in infants and children. Otitis Study Group. Pediatrics. 1994;94:847-852. [pmid: 7971000].
Aspin M M, Hoberman A, McCarty J, et al. Comparative study of the safety and efficacy of clarithromycin and amoxicillin-clavulanate in the treatment of acute otitis media in children [see comments]. J Pediatr. 1994;125:136-141. [pmid: 8021763].
Association AS-L-H. Guidelines for screening for hearing impairment and middle-ear disorders. ASHA. 1990;32:17-24.
Association AS-L-H. Guidelines for the audiologic assessment of children from birth through 36 months of age. ASHA. 1991:37–43.
Association AS-L-H. Guidelines for audiologic screening. ASHA. 1997:1–60.
Astbury J, Orgill A, Bajuk B. Relationship between two-year behaviour and neurodevelopmental outcome at five years of very low-birthweight survivors. Dev Med Child Neurol. 1987;29:370-379. [pmid: 3596073].
Ataoglu H, Goksu N, Kemaloglu Y K, Bengisun S, Ozbilen S. Preliminary report on L-forms: possible role in the infectious origin of secretory otitis media. Ann Otol Rhinol Laryngol. 1994;103:434-438. [pmid: 8203809].
Athanasiou A E, Droschl H, Bosch C. Data and patterns of transverse dentofacial structure of 6- to 15-year-old children: a posteroanterior cephalometric study. Am J Orthod Dentofacial Orthop. 1992;101:465-471. [pmid: 1590296].
Attallah M S, al-Essa A. Hearing results in tympanoplasty in Riyadh. Otolaryngol Pol. 1996;50:145-151. [pmid: 9009673].
Attallah M S, Essa A E. Common complications following ventilation tube insertion. Indian J Otol. 1999;5:17-20.
Augustsson I, Nilsson C, Neander P. Do we treat ‘the right’ children with secretory otitis media at the ENT clinic?. Acta Oto Laryngologica Supplement. 1988;106:39-40.
Augustsson I, Nilson C, Engstrand I. The preventive value of audiometric screening of preschool and young school-children. Int J Pediatr Otorhinolaryngol. 1990;20:51-62. [pmid: 2262293].
Augustsson I, Engstrand I. Secretory otitis media in a cohort of Swedish children as reflected by repeated screening and by medical records. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:40–43.
Austin D F. Types and indications of staging. Arch Otolaryngol. 1969;89:235-242. [pmid: 5763919].
Austin D F. Ossicular reconstruction. Arch Otolaryngol. 1971;94:525-535. [pmid: 5129224].
Austin D F. Transcanal tympanoplasty: a 15-year report. Transactions - American Academy of Ophthalmology and Otolaryngology. 1976;82:ORL30-8.
Austin D F. Avoiding failures in the restoration of hearing with ossiculoplasty and biocompatible implants. Otolaryngol Clin North Am. 1982;15:763-771. [pmid: 7162816].
Austin D F. Adenoidectomy for secretory otitis media [see comments]. Arch Otolaryngol Head Neck Surg. 1989;115:936-939. [pmid: 2751853].
Austin D F. Adenoidectomy for secretory otitis media. Arch Otolaryngol Head and Neck Surgery. 1989;115:936-939.
Austin DF. Adenoidectomy for secretory otitis media (I: Reply). Arch Otolaryngol Head and Neck Surgery. 1990;116.
Austin DF. Adenotonsillectomy in the treatment of secretory otitis media. Ear Nose Throat J. 1994; 73:367–369, 373–374.
Avery C A, Gates G A, Prihoda T J. Efficacy of acoustic reflectometry in detecting middle ear effusion. Ann Otol Rhinol Laryngol. 1986;95:472-476. [pmid: 3532904].
Avery J K. There ain't no justice. J Tenn Med Assoc. 1990;83:405. [pmid: 2402147].
Avery R K, Eavey R D, Della Torre T, Ramos D, Pasternack M S. Bilateral otitis media and mastoiditis caused by a highly resistant strain of Mycobacterium chelonae. Pediatr Infect Dis J. 1996;15:1037-1040. [pmid: 8933554].
Aviel A, Ostfeld E. Acquired irreversible sensorineural hearing loss associated with otitis media with effusion. Am J Otolaryngol. 1982;3:217-222. [pmid: 7201752].
Avraham S, Luntz M, Sade J. The influence of ventilating tubes on the surgical treatment of atelectatic ears. European Archives of Oto Rhino Laryngology. 1991;248:259-261. [pmid: 1888502].
Avramenko L V, Bazarov V G, Butenko L N, et al. Ultrasound tympanometry as an objective method of the middle ear diseases diagnosis and treatment. Vestn Otorinolaringol. 1982;44:56-59. [pmid: 7179650].
Axelsson I. Overtreatment of otitis media [letter]. Pediatr Infect Dis J. 1993;12:889-891. [pmid: 8284133].
Axelsson I. [Research fraud. Manipulated conclusions on therapy of otitis in children]. Lakartidningen. 1993;90:937-940. [pmid: 8459737].
Axon P R, Mawman D J, Upile T, Ramsden R T. Cochlear implantation in the presence of chronic suppurative otitis media. J Laryngol Otol. 1997;111:228-232. [pmid: 9156058].
Baart de la Faille LM. Validity of large scale standardised behavioural screening. Acta Oto-Laryngologica - Supplement. 1991;482:94–101; discussion 102.
Baba S, Ito H, Tsukiyama M, Iwata S, Nishimura T. [Clinical evaluation of long-acting preparation of cephalexin (S-6436) in the treatment of acute tonsillitis and acute otitis media--a double blind study (author's transl)]. Kansenshogaku-Zasshi. 1977;51:286-302. [pmid: 411841].
Baba S, Ito H, Kinoshita H, et al. [Comparative study on cefmetazole and cefazolin in the treatment of suppurative otitis media]. Jpn-J-Antibiot. 1982;35:1523-1552. [pmid: 6752467].
Baba S, Murai K, Kinoshita H, et al. Evaluation of BRL25000 (clavulanic acid-amoxicillin) in acute purulent otitis media and acute exacerbation of chronic purulent otitis media. A comparative double blind study with amoxicillin. CHEMOTHERAPY-(TOKYO). 1983;31:97-112. [pmcid: 314422].
Baba S, Kinoshita H, Mori Y, et al. [A parallel comparative double blind study of cefixime with cefaclor in the treatment of acute suppurative otitis media in children]. Jpn-J-Antibiot. 1987;40:1-24. [pmid: 3295321].
Baba S, Mori Y, Suzuki K, et al. [Evaluation of the efficacy of ceftriaxone in acute suppurative otitis media and acute exacerbation of chronic suppurative otitis media. A comparative study with cefotiam as the control]. Jpn-J-Antibiot. 1989;42:212-247. [pmid: 2523493].
Babighian G. Bioactive ceramics versus proplast implants in ossiculoplasty. Am J Otol. 1985;6:285-290. [pmid: 3839631].
Babighian G. Problems in cochlear implant surgery. Adv Otorhinolaryngol. 1993;48:65-69. [pmid: 8273502].
Babighian G, Dominguez M J. [Introduction to the surgery of the middle ear: general principles]. Acta Otorrinolaringol Esp. 1993;44:327-331. [pmid: 8129965].
Babonis T R, Weir M R, Kelly P C. Impedance tympanometry and acoustic reflectometry at myringotomy [published erratum appears in Pediatrics 1991 Jun;87(6):945]. Pediatrics. 1991;87:475-480. [pmid: 2011423].
Babonis T R, Weir M R, Kelly P C. Impedance tympanometry and acoustic reflectometry at myringotomy. Pediatrics. 1991;87:475-480. [pmid: 2011423].
Babonis T, Weir M R, Kelly P C, Krober M S. Progression of tympanometry and acoustic reflectometry. Findings in children with acute otitis media. Clin Pediatr. 1994;33:593-600.
Bacciu S, Pasanisi E, Perez Raffo G, et al. Scutumplasty: costal cartilage versus bone pate. Auris Nasus Larynx. 1998;25:155-159. [pmid: 9673728].
Backhouse C I, Woods P. Trimethoprim and amoxycillin in acute otitis media. Practitioner. 1985;229:51-54. [pmid: 3887355].
Bader-Meunier B, Pinto G, Tardieu M, Pariente D, Bobin S, Dommergues J P. Mastoiditis, meningitis and venous sinus thrombosis caused by Fusobacterium necrophorum. Eur J Pediatr. 1994;153:339-341. [pmid: 8033922].
Baer S, Hehar S, Maw A R. Tympanic membrane ossification. J Laryngol Otol. 1993;107:550-552. [pmid: 8345305].
Bafaqeeh S A, Zakzouk S M, al Muhaimeid H, Essa A. Relevant demographic factors and hearing impairment in Saudi children: epidemiological study. J Laryngol Otol. 1994;108:294-298. [pmid: 8182312].
Bagger-Sjoback D, Bondesson G. Taste evaluation and compliance of two paediatric formulations of phenoxymethylpenicillin in children. Scand J Prim Health Care. 1989;7:87-92. [pmid: 2511611].
Baggett H C, Prazma J, Rose A S, Lane A P, Pillsbury H C 3rd. The role of glucocorticoids in endotoxin-mediated otitis media with effusion. Arch Otolaryngol Head Neck Surg. 1997;123:41-46. [pmid: 9006502].
Baghai P, Vries J K, Bechtel P C. Retromastoid approach for biopsy of brain stem tumors. Neurosurgery. 1982;10:574-579. [pmid: 7099409].
Bailey Q. The Castelli membrane in the treatment of glue ear. J Laryngol Otol. 1980;94:377-382. [pmid: 7190178].
Bailey CM. Surgical management of otitis media. Pediatr Infect Dis J. 1994;13:S40–43; discussion S50–S54.
Bain D J. Can the clinical course of acute otitis media be modified by systemic decongestant or antihistamine treatment?. Br Med J Clin Res Ed. 1983;287:654-656.
Bain J, Murphy E, Ross F. Acute otitis media: clinical course among children who received a short course of high dose antibiotic. Br Med J Clin Res Ed. 1985;291:1243-1246.
Bakaletz L O, Daniels R L, Lim D J. Modeling adenovirus type 1-induced otitis media in the chinchilla: effect on ciliary activity and fluid transport function of eustachian tube mucosal epithelium [published erratum appears in J Infect Dis 1993 Dec;168(6):1605]. J Infect Dis. 1993;168:865-872. [pmid: 8397268].
Bakaletz L O, Murwin D M, Billy J M. Adenovirus serotype 1 does not act synergistically with Moraxella (Branhamella) catarrhalis to induce otitis media in the chinchilla. Infect Immun. 1995;63:4188-4190. [pmcid: 173592]. [pmid: 7558341].
Bakaletz L O. Viral potentiation of bacterial superinfection of the respiratory tract. Trends Microbiol. 1995;3:110-114. [pmid: 7773588].
Bakaletz L O, Holmes K A. Evidence for transudation of specific antibody into the middle ears of parenterally immunized chinchillas after an upper respiratory tract infection with adenovirus. Clin Diagn Lab Immunol. 1997;4:223-225. [pmcid: 170506]. [pmid: 9067660].
Baker R S, Chole R A. A randomized clinical trial of topical gentamicin after tympanostomy tube placement. Arch Otolaryngol Head Neck Surg. 1988;114:755-757. [pmid: 3289583].
Baker R S, Chole R A. Ventilation tubes and prophylactic antibiotic eardrops [letter; comment]. Otolaryngol Head Neck Surg. 1993;109:559-560. [pmid: 8414583].
Baldwin R L. Effects of otitis media on child development. Am J Otol. 1993;14:601-604. [pmid: 7507647].
Balkany T J, Barkin R M, Suzuki B H, Watson W J. A prospective study of infection following tympanostomy and tube insertion. Am J Otol. 1983;4:288-291. [pmid: 6344649].
Balkany TJ, Arenberg IK, Steenerson RL. Middle ear irrigation during insertion of ventilation tubes. Auris-Nasus-Larynx. 1985:S265–S267.
Balkany T J, Arenberg I K, Steenerson R L. Ventilation tube surgery and middle ear irrigation. Laryngoscope. 1986;96:529-532. [pmid: 3517534].
Balkany T, Gantz B J, Steenerson R L, Cohen N L. Systematic approach to electrode insertion in the ossified cochlea. Otolaryngol Head Neck Surg. 1996;114:4-11. [pmid: 8570249].
Balkany T J, Cohen N L, Gantz B J. Surgical technique for the CLARION cochlear implant. Ann Otol Rhinol Laryngol Suppl. 1999;177:27-30. [pmid: 10214797].
Ball S S, Prazma J, Dais D, Rosbe K W, Pillsbury H C. Nitric oxide: a mediator of endotoxin-induced middle ear effusions. Laryngoscope. 1996;106:1021-1027. [pmid: 8699894].
Ball S S, Prazma J, Dais C G, Triana R J, Pillsbury H C. Role of tumor necrosis factor and interleukin-1 in endotoxin-induced middle ear effusions. Ann Otol Rhinol Laryngol. 1997;106:633-9. [pmid: 9270424].
Ballantyne J. The ear in paediatric practice. Practitioner. 1985;229:809-12. [pmid: 4070153].
Balle V H, Stangerup S E, Sederberg-Olsen J, Thomsen J, Vejlsgaard R. Amoxicillin/clavulanate treatment in secretory otitis media. Bacteriological findings in the nasopharynx. Acta-Otolaryngol-Stockh. 1990;110:274-8. [pmid: 2239218].
Balle V, Sederberg Olsen J, Thomsen J, Hartzen S. Treatment of children with secretory otitis media (SOM) with amoxicillin and clavulanic acid (Spektramox) or penicillin-V (Primcillin). Bacteriological findings in the nasopharynx before and after treatment. Int J Pediatr Otorhinolaryngol. 1998;45:77-82. [pmid: 9804023].
Balli R. Controlled trial on the use of oral acetylcysteine in the treatment of glue-ear following drainage. Eur J Respir Dis. 1980;61.
Balwally A N, Singh B, Sperling N M. Radiological case of the month. Subperiosteal abscess of the mastoid. Arch Pediatr Adolesc Med. 1997;151:201-2. [pmid: 9041879].
Balyan F R, Celikkanat S, Aslan A, Taibah A, Russo A, Sanna M. Mastoidectomy in noncholesteatomatous chronic suppurative otitis media: is it necessary?. Otolaryngol Head Neck Surg. 1997;117:592-5. [pmid: 9419084].
Bamford J. Paediatric audiology in the United Kingdom: moving off in several directions. Br J Audiol. 1986;20:175-9. [pmid: 3742106].
Banerjee D K, Korzec K R, Kim K, Fanelly L. Nasopharyngeal oncocytoma. Otolaryngol Head Neck Surg. 1995;113:136-7. [pmid: 7603708].
Banerjee AR, Ward V, Narula AA. Management of recurrent acute otitis media with grommet insertion. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:199–200.
Bansal R, Raj A. Hearing loss in rural population: The etiology. Indian J Otolaryngol Head Neck Surg. 1998;50:147-155.
Baquero F, Loza E. Antibiotic resistance of microorganisms involved in ear, nose and throat infections. Pediatr Infect Dis J. 1994;13:S9–S14; discussion S20–22.
Barber P S, Rose D E. Bone conduction oscillator placement in testing hearing of selected groups of children. Am J Ment Deficiency. 1969;73:666-672.
Barcz D V, Wood R Pd, Stears J, Jafek B W, Shields M. Subarachnoid space: middle ear pathways and recurrent meningitis. Am J Otol. 1985;6:157-163. [pmid: 4039111].
Barenkamp S J, Bodor F F. Development of serum bactericidal activity following nontypable Haemophilus influenzae acute otitis media. Pediatr Infect Dis J. 1990;9:333-339. [pmid: 2352818].
Barenkamp S J. Immunization with high-molecular-weight adhesion proteins of nontypeable Haemophilus influenzae modifies experimental otitis media in chinchillas. Infect Immun. 1996;64:1246-1251. [pmcid: 173911]. [pmid: 8606086].
Barfoed C, Rosborg J. Secretory otitis media. Long-term observations after treatment with grommets. Arch Otolaryngol. 1980;106:553-556. [pmid: 7190819].
Barfoed C, Sorensen K M, Rosborg J. Secretory otitis media. Long-term observations after treatment with grommets: Double follow-up. Acta Oto Laryngologica Supplement. 1988;106:203-204.
Barkin R M. Acute otitis media: a common presentation in the emergency department. J Emerg Med. 1985;2:163-168. [pmid: 3833916].
Barlan I B, Geha R S, Schneider L C. Therapy for patients with recurrent infections and low serum IgG3 levels. J Allergy Clin Immunol. 1993;92:353-355. [pmid: 8349944].
Barlinski J. [Cefuroxime axetil--efficiency and safety for treatment of upper airways and middle ear infections in children]. Pol Tyg Lek. 1993;48:233-235. [pmid: 8234058].
Barnett E D, Klein J O. The problem of resistant bacteria for the management of acute otitis media. Pediatr Clin North Am. 1995;42:509-517. [pmid: 7761138].
Barnett ED, Klein JO, Teele DW, et al. Short-course therapy for acute otitis media: single dose ceftriaxone. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:216–217.
Barnett E D, Teele D W, Klein J O, Cabral H J, Kharasch S J. Comparison of ceftriaxone and trimethoprim-sulfamethoxazole for acute otitis media. Pediatrics. 1997;99:23-28. [pmid: 8989332].
Barnett E D, Teele D W, Klein J O, Cabral H J, Kharasch S J. Comparison of ceftriaxone and trimethoprim-sulfamethoxazole for acute otitis media. Greater Boston Otitis Media Study Group. Pediatrics. 1997;99:23-28. [pmid: 8989332].
Barnett ED, Klein JO, Hawkins KA, Cabral HJ, Kenna M, Healy G. Comparison of spectral gradient acoustic reflectometry and other diagnostic techniques for detection of middle ear effusion in children with middle ear disease. Pediatr Infect Dis J. 1998;17:556–559; discussion 580.
Barona R, Armengot M, Garin L, Montalt J, Basterra J. [Kniest syndrome. An audiological study]. An Otorrinolaringol Ibero Am. 1993;20:133-141. [pmid: 8484485].
Barone S R, Kaplan M H, Krilov L R. Human herpesvirus-6 infection in children with first febrile seizures. J Pediatr. 1995;127:95-97. [pmid: 7608818].
Barr W H, Affrime M, Chin C C, Batra V. Pharmacokinetics of ceftibuten in children. Pediatr Infect Dis J. 1995;1:44-54.
Barritt P W, Darbyshire P J. Deafness after otitis media in general practice. J R Coll Genl Practitioners. 1984;34:92-94.
Barry B, Muffat-Joly M, Gehanno P, Pocidalo J J. [Physiopathological and therapeutic values of experimental model of acute otitis media. Review of the literature]. Ann Otolaryngol Chir Cervicofac. 1993;110:326-331. [pmid: 8210092].
Barry B, Muffat-Joly M, Gehanno P, Pocidalo J J. Effect of increased dosages of amoxicillin in treatment of experimental middle ear otitis due to penicillin-resistant Streptococcus pneumoniae. Antimicrob Agents Chemother. 1993;37:1599-1603. [pmcid: 188026]. [pmid: 8215269].
Barry B, Gehanno P, Blumen M, Boucot I. Clinical outcome of acute otitis media caused by pneumococci with decreased susceptibility to penicillin. Scand-J Infect Dis. 1994;26:446-452. [pmid: 7984977].
Barry B, Muffat-Joly M, Bauchet J, et al. Efficacy of single-dose ceftriaxone in experimental otitis media induced by penicillin- and cephalosporin-resistant Streptococcus pneumoniae. Antimicrob Agents Chemother. 1996;40:1977-1982. [pmcid: 163458]. [pmid: 8878566].
Bartels L J, Sheehy J L. Total obliteration of the mastoid, middle ear, and external auditory canal. A review of 27 cases. Laryngoscope. 1981;91:1100-1108. [pmid: 7242201].
Bartolozzi G, Sacchetti A, Scarane P, Becherucci P. Natural history of otitis media with effusion in children under six years of age. Adv Otorhinolaryngol. 1992;47:281-283. [pmid: 1456148].
Bartoshuk L M, Duffy V B, Reed D, Williams A. Supertasting, earaches and head injury: genetics and pathology alter our taste worlds. Neurosci Biobehav Rev. 1996;20:79-87. [pmid: 8622833].
Bass J W, Cohen S H, Corless J D, Mamunes P. Ampicillin compared to other antimicrobials in acute otitis media. JAMA. 1967;202:697-702. [pmid: 4964192].
Basset J M, Fleury P, Candau P, et al. Study of changes in bone conduction (BC) in surgery for chronic otitis and its sequelae (review of 800 operations). Ann Oto Laryngol. 1985;102:239-249.
Bassila M K. Middle ear effusion. Journal Medical Libanais - Lebanese Medical Journal. 1994;42:227-229.
Bastos I, Janzon L, Lundgren K, Reimer A. Otitis media and hearing loss in children attending an ENT clinic in Luanda, Angola. Int J Pediatr Otorhinolaryngol. 1990;20:137-148. [pmid: 2286506].
Bastos I, Reimer A, Lundgren K. Chronic otitis media and hearing loss in urban schoolchildren in Angola - A prevalence study. J Audiological Med. 1993;2:129-140.
Bastos I, Mallya J, Ingvarsson L, Reimer A, Andreasson L. Middle ear disease and hearing impairment in northern Tanzania. A prevalence study of schoolchildren in the Moshi and Monduli districts. Int J Pediatr Otorhinolaryngol. 1995;32:1-12. [pmid: 7607816].
Bastos I, Ingvarsson L, Andreasson L, Reimer A. Chronic otitis media and hearing loss among schoolchildren in a refugee camp in Angola: A prevelance study. J Audiological Med. 1995;4:1-11.
Bates G. Glue ear. Practitioner. 1993;237:893-898. [pmid: 8108319].
Bauchner H, Adams W, Barnett E, Klein J. Therapy for acute otitis media. Preference of parents for oral or parenteral antibiotic [see comments]. Arch Pediatr Adolesc Med. 1996;150:396-399. [pmid: 8634735].
Bauchner H, Klein J O. Parental issues in selection of antimicrobial agents for infants and children [see comments]. Clin Pediatr. 1997;36:201-205.
Bauer M. Tympanoplasty after radical mastoid operation. Arch Otolaryngol. 1967;86:387-390. [pmid: 5342617].
Bauer F. Treatment of “glue ear” by intratympanic injection of urea. J Laryngol Otol. 1968;82:717-722. [pmid: 4233584].
Bax M, Hart H, Jenkins S. The behaviour, development, and health of the young child: implications for care. Br Med J Clin Res Ed. 1983;286:1793-1796.
Baxter J D. Chronic otitis media and hearing loss in the Eskimo population of Canada. Laryngoscope. 1977;87:1528-1542. [pmid: 197359].
Baxter J D, Katsarkas A, Ling D, Carson R. The Nakasuk Project- the conservative treatment of chronic otitis media in Inuit elementary school children. J Otolaryngol. 1979;8:201-209. [pmid: 458916].
Baxter J D. My experience with the Canadian Inuit. J Otolaryngol. 1980;9:63-66. [pmid: 7359613].
Baxter J D. Observations on the evolution of chronic otitis media in the Inuit of the Baffin Zone, N.W.T. J Otolaryngol. 1982;11:161-166. [pmid: 7109014].
Baxter J D. Clinical research in the Canadian North: an overview of a decade of participation in the McGill University-Baffin Zone Project. Acta Otolaryngol. 1983;95:615-619. [pmid: 6880674].
Baxter J D, Ilecki H J. Management of hearing impairment in the Canadian Inuit--an update. J Otolaryngol. 1985;14:62-64. [pmid: 4068094].
Baxter J D, Julien G, Tewfik T L, et al. Observations on the prevalence of ear disease in the Inuit and Cree indian school population of Kuujjuaraapik. J Otolaryngol. 1986;15:25-30. [pmid: 3514931].
Baxter J D. What have we learned about otitis media and hearing loss by studying the native peoples of Canada?. J Otolaryngol. 1990;19:386-388. [pmid: 2280452].
Baxter J D. An overview of twenty years of observation concerning etiology, prevalence, and evolution of otitis media and hearing loss among the Inuit in the eastern Canadian Arctic. Arctic Med Res. 1991;Suppl:616-619. [pmid: 1365241].
Bayramoglu I, Ardic F N, Kara C O, Ozuer M Z, Katircioglu O, Topuz B. Importance of mastoid pneumatization on secretory otitis media. Int J Pediatr Otorhinolaryngol. 1997;40:61-66. [pmid: 9184979].
Beagley H A. Progress in objective audiometry. J Laryngol Otol. 1972;86:225-235. [pmid: 5014914].
Beal D D, Stewart K C, Fleshman J K. The surgical program to reduce the morbidity of chronic otitis media in the Alaskan native. Acta Socio-Medica Scandinavica - Supplement. 1972;Suppl:259-265. [pmid: 4536501].
Beales P H. Combined approach tympanoplasty. J Laryngol Otol. 1968;82:769-773. [pmid: 4876439].
Bear V D. The ear: “dos” and “don'ts”. Med J Aust. 1991;154:603-605, 608. [pmid: 2056945].
Beasley J W. Lessons from the International Primary Care Network [editorial; comment]. J Am Board Fam Pract. 1993;6:419-420. [pmid: 8352049].
Beatson J M, Marsh B T, Talbot D J. A clinical comparison of pivmecillinam plus pivampicillin (Miraxid) and a triple tetracycline combination (Deteclo) in respiratory infections treated in general practice. J Int Med Res. 1985;13:197-202. [pmid: 3930309].
Beatson J M, Marsh B T, Talbot D J. A comparison of pivmecillinam plus pivampicillin (Miraxid) and a triple tetracycline combination (Deteclo) in respiratory infections treated in general practice. J Int Med Res. 1985;13:197-202. [pmid: 3930309].
Beaumont G D. Chronic ear disease in aborigines--a research programme. J Otolaryngolog Soc Aust. 1972;3:330-332.
Becker G D, Eckberg T J, Goldware R R. Swimming and tympanostomy tubes: a prospective study. Laryngoscope. 1987;97:740-741. [pmid: 3586818].
Becker S P, Roberts N, Coglianese D. Endoscopic adenoidectomy for relief of serous otitis media. Laryngoscope. 1992;102:1379-1384. [pmid: 1453847].
Beerle B J, Arriaga M. Myringotomy tube placement--another role for EMLA cream? [letter]. Anesth Analg. 1996;83:435. [pmid: 8694340].
Beery Q C, Bluestone C D, Cantekin E I. Otologic history, audiometry and tympanometry as a case finding procedure for school screening. Laryngoscope. 1975;85:1976-1985. [pmid: 1202304].
Beery Q C, Andrus W S, Bluestone C D, Cantekin E I. Tympanometric pattern classification in relation to middle ear effusions. Ann Otol Rhinol Laryngol. 1975;84:56-64. [pmid: 1111435].
Begg C B, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1999;50:1088-1101. [pmid: 7786990].
Begue P, Broussin B, Quinet B, Garabedian N, Sounthavong J P, Riviere F. Acute otitis media in children: A randomized open clinical trial of effectiveness of two major antibiotics. (Erythromycin ethylsuccinate/acetyl-sulfafurazole versus amoxicillin/clavulanic acid). Ann Pediatr. 1990;37:127-130.
Begue P, Broussin B, Quinet B, Garabedian N, Sounthavong J P, Riviere F. [Acute otitis media in children: a randomized and open clinical trial of the efficacy of 2 major antibiotics (erythromycin ethylsuccinate/acetyl sulfafurazole vs amoxicillin/clavulanic acid)]. Ann Pediatr Paris. 1990;37:127-130. [pmid: 2181915].
Begue P, Quinet B, Denoyelle F, Garabedian E N. [Pharmacokinetic study of antibiotics in otitis]. Ann Otolaryngol Chir Cervicofac. 1993;110:393-398. [pmid: 8085720].
Begue P, Boulesteix J, Dubreuil C, et al. Cefixime versus amoxicillin-clavulanate for the treatment of acute otitis media in children. Medecine Et Maladies Infectieuses. 1996;26:125-132.
Behre U, Burow H M, Quinn P, Cree F, Harrison H E. Efficacy of twice-daily dosing of amoxycillin/clavulanate in acute otitis media in children. Infection. 1997;25:163-166. [pmid: 9181384].
Belal A, Stewart T J. Pathologocal changes in the middle ear joints. Ann Otol Rhinol Laryngol. 1974;83:159-167. [pmid: 4817432].
Belal A Jr, Forquer B D. Experimental tympanometry. J Laryngol Otol. 1980;94:595-605. [pmid: 6776207].
Belkengren R, Sapala S. What is your assessment? Otitis media with effusion. Pediatr Nurs. 1995;21:304-305. [pmid: 7792115].
Belkengren R, Sapala S. Pediatric management problems. Febrile seizures. Pediatr Nurs. 1997;23:192-193. [pmid: 9165938].
Bellanti J A, Nsouli S M, Nsouli T M. Serous otitis media and food allergy. Monogr Allergy. 1996;32:188-194. [pmid: 8813198].
Bellioni P, Cantani A, Salvinelli F. Allergy: a leading role in otitis media with effusion. Allergol Immunopathol. 1987;15:205-208.
Bellman S C. Monitoring chemotherapy-induced hearing loss in children. Eur J Cancer. 1996;32A:1185-1188. [pmid: 8758251].
Bellussi L, Ciferri G, De S E, Passali D. Effect of 2-(alpha-thenoylthio)propionylglycine in the treatment of secretory otitis media. CURR THER RES, CLIN EXP. 1984;36:596-605.
Bellussi L, Bernocchi D, Ciferri G, Manini G, Passali D. Sobrerol in the treatment of secretory otitis media in childhood. J Int Med Res. 1989;17:277-286. [pmid: 2767330].
Bellussi L, Passali D. Treatment of upper airways inflammation with nimesulide. Drugs. 1993:107–110.
Bellussi L, Lauriello M. [Experts' opinion on pathogenesis and classification of otitis media with effusion]. Acta Otorhinolaryngol Ital. 1995;15:467-474. [pmid: 8712003].
Bellussi L, Biagini C, Calearo C, et al. Antiphlogistic therapy with ketoprofen lysine salt vs nimesulide in secretive otitis media, rhinitis/rhinosinusitis, pharyngitis/tonsillitis/tracheitis. /TERAPIA ANTIFLOGISTICA CON KETOPROFENE SALE DI LISINA VS NIMESULIDE NELL'OTITE MEDIA SECRETIVA, RINITE/RINOSINUSITE, FARINGITE/TONSILLITE/TRACHEITE. Otorinolaringologia. 1996;46:49-57.
Belshe R B, Mendelman P M, Treanor J, et al. The efficacy of live attenuated, cold-adapted, trivalent, intranasal influenzavirus vaccine in children [see comments]. N Engl J Med. 1998;338:1405-1412. [pmid: 9580647].
Belyakova LV, Grigoryeva NV. [Asymptomatic long-term course of chronic otitis with marked destructive alterations]. Vestn Otorinolaringol. 1997:51–52.
Ben-Ami M, Rosen G, Shlezinger T, Konack S. Otitis media with effusion--complications after treatment. J Laryngol Otol. 1983;97:1091-1094. [pmid: 6685748].
Ben-David J, Podoshin L, Fradis M. Tympanometry and audiometry in diagnosis of middle-ear effusions. Ear Nose Throat J. 1981;60:120-123. [pmid: 7194176].
Ben-David J, Podoshin L, Fradis M, Faraggi D. Is the vestibular system affected by middle ear effusion?. Otolaryngol Head Neck Surg. 1993;109:421-426. [pmid: 8414557].
Benaoudia F, Francois M, Brahimi N, Narcy P, Bingen E. Alcaligenes xylosoxidans-associated infection in an infant with cholesteatoma [letter]. Pediatr Infect Dis J. 1995;14:637-638. [pmid: 7567305].
Benediktsdottir B. Upper airway infections in preschool children--frequency and risk factors. Scand J Prim Health Care. 1993;11:197-201. [pmid: 8272652].
Benfer R A. Morphometric analysis of Cartesian coordinates of the human skull. Am J Phys Anthropol. 1975;42:371-382. [pmid: 1096639].
Benjamin J T. Practice and guidelines [letter; comment]. Pediatrics. 1996;97:604-605. [pmid: 8632960].
Bennett R J. The significance and management of the drumhead retraction pocket. J Laryngol Otol. 1970;84:167-189. [pmid: 5416432].
Bennett F C, Ruuska S H, Sherman R. Middle ear function in learning-disabled children. Pediatrics. 1980;66:254-260. [pmid: 7402810].
Bennett R J. The operation of tympanomastoid re-aeration. Physiological repair of the radical mastoid cavity. J Laryngol Otol. 1981;95:1-10. [pmid: 7462775].
Bennett KE, Haggard MP. Duration of behavior and cognitive outcomes from middle ear disease in the UK. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:389–392.
Bennett K E, Haggard M P. Accumulation of factors influencing children's middle ear disease: risk factor modelling on a large population cohort. J Epidemiol Community Health. 1998;52:786-793. [pmid: 10396519].
Bennett K, Higson J, Haggard M. Do GPs have the techniques for ‘watchful waiting’ in glue ear?. Br J Gen Pract. 1998;48:1079-1080. [pmid: 9624753]. [pmcid: 1410009].
Bennett K E, Haggard M P. Behaviour and cognitive outcomes from middle ear disease. Arch Dis Child. 1999;80:28-35. [pmid: 10325755].
Benninger M S, King F, Nichols R D. Management guidelines for improvement of otolaryngology referrals from primary care physicians. Otolaryngol Head Neck Surg. 1995;113:446-452. [pmid: 7567019].
Benson-Mitchell R, Tolley N, Croft C B, Roberts D. Wegener's granuloma--presenting as a unilateral parotid swelling. J Laryngol Otol. 1994;108:431-432. [pmid: 8035127].
Bento R F, Schuster Grasel S, Konno Ishida L, Miniti A. Clinical study of sensorineural hearing loss in patients with chronic otitis media. Revista Brasileira de Otorrinolaringologia. 1993;59:12-16.
Benz B. [Mucoserotympanon of the adult]. Laryngorhinootologie. 1995;74:62. [pmid: 7888027].
Berera G. Index of suspicion. Case 1. Submucous cleft palate. Pediatr Rev. 1993;14:191-192. [pmid: 8493188].
Berg A O. Middle ear effusion guideline: The co-chair's thoughts [editorial; comment]. Am Fam Physician. 1994;50:897-898. [pmid: 7942408].
Berg A O. Clinical practice guideline panels: personal experience [see comments]. J Am Board Fam Pract. 1996;9:366-370. [pmid: 8884676].
Berger R, Hadziselimovic F, Just M, Reigel P. Effect of feeding human milk on nosocomial rotavirus infections in an infants ward. Dev-Biol-Stand. 1983:219–228.
Berger G, Hawke M, Ekem J K, Johnson A. Mast cells in human middle ear mucosa in health and in disease. J Otolaryngol. 1984;13:370-374. [pmid: 6085806].
Berger G, Hawke M, Proops D W, Ranadive N S. The role of histamine in secretory otitis media. J Otolaryngol. 1984;13:172-174. [pmid: 6544833].
Berger G. Eustachian tube submucosal glands in normal and pathological temporal bones. J Laryngol Otol. 1993;107:1099-1105. [pmid: 8288996].
Berger G, Ophir D. Possible role of adenoid mast cells in the pathogenesis of secretory otitis media. Ann Otol Rhinol Laryngol. 1994;103:632-635. [pmid: 8060058].
Berger G, Sachs Z, Sade J. Histopathologic changes of the tympanic membrane in acute and secretory otitis media. Ann Otol Rhinol Laryngol. 1996;105:458-462. [pmid: 8638897].
Berger G, Ophir D, Berco E, Sade J. Revision myringoplasty. J Laryngol Otol. 1997;111:517-520. [pmid: 9231083].
Bergeron M G, Ahronheim G, Richard J E, et al. Comparative efficacies of erythromycin-sulfisoxazole and cefaclor in acute otitis media: a double blind randomized trial. Pediatr Infect Dis J. 1987;6:654-660. [pmid: 3302918].
Bergholtz L, Hallander H, Rudberg R. Treatment of acute otitis media with azidocillin administered twice daily. Scand-J Infect Dis. 1973;5:203-208. [pmid: 4588302].
Bergmann K. [Fatal complications of otitis 60 years ago]. HNO. 1995;43:478-481. [pmid: 7558904].
Bergstrom L. Continuing management of conductive hearing loss during language development. Int J Pediatr Otorhinolaryngol. 1980;2:3-9. [pmid: 6765127].
Bergstrom B K, Bertilson S O, Movin G. Clinical evaluation of rectally administered ampicillin in acute otitis media. J Int Med Res. 1988;16:376-385. [pmid: 3197915].
Bergus G. Using prediction models to reveal what we need to know [editorial; comment]. Arch Fam Med. 1993;2:817-819. [pmid: 8111508].
Bergus G R, Levy B T, Levy S M, Slager S L, Kiritsy M C. Antibiotic use during the first 200 days of life. Arch Fam Med. 1996;5:523-526. [pmid: 8930223].
Berlinger N T, Schachern P. Myofibroblasts in chronic otitis media. Laryngoscope. 1983;93:1566-1568. [pmid: 6645757].
Berman S, Lauer B A. A controlled trial of cefaclor versus amoxicillin for treatment of acute otitis media in early infancy. Pediatr-Infect-Dis. 1983;2:30-33. [pmid: 6340079].
Berman S, Grose K, Zerbe G O. Medical management of chronic middle-ear effusion. Results of a clinical trial of prednisone combined with sulfamethoxazole and trimethoprim. Am-J-Dis-Child. 1987;141:690-694. [pmid: 3554985].
Berman S, Grose K, Nuss R, et al. Management of chronic middle ear effusion with prednisone combined with trimethoprim-sulfamethoxazole. Pediatr Infect Dis J. 1990;9:533-538. [pmid: 2235167].
Berman S, Nuss R, Roark R, Huber-Navin C, Grose K, Herrera M. Effectiveness of continuous vs. intermittent amoxicillin to prevent episodes of otitis media. Pediatr Infect Dis J. 1992;11:63-67. [pmid: 1741200].
Berman S, Roark R. Factors influencing outcome in children treated with antibiotics for acute otitis media. Pediatr Infect Dis J. 1993;12:20-24. [pmid: 8417420].
Berman S. Medical management of children with otitis media with effusion. In: Quie PG, ed. The Report on Pediatric Infectious Diseases. New York: Churchill Livingstone; 1993:37–38.
Berman S, Roark R, Luckey D. Theoretical cost effectiveness of management options for children with persisting middle ear effusions. Pediatrics. 1994;93:353-363. [pmid: 8115191].
Berman S. Management of acute and chronic otitis media in pediatric practice. Curr Opin Pediatr. 1995;7:513-522. [pmid: 8541950].
Berman S. Otitis media in developing countries. Pediatrics. 1995;96:126-131. [pmid: 7596700].
Berman S. Otitis media in children. N Engl J Med. 1995;332:1560-1565. [pmid: 7739711].
Berman S, Byrns P J, Bondy J, Smith P J, Lezotte D. Otitis media-related antibiotic prescribing patterns, outcomes, and expenditures in a pediatric medicaid population. Pediatrics. 1997;100:585-592. [pmid: 9310510].
Berman S, Wu K, Roark R. Management of otitis media with effusion with prednisone in combination with an antibiotic. International Pediatrics. 1999;14:221-224.
Bernadt I. Otitis media in general practice [letter; comment]. Med J Aust. 1993;159:142. [pmid: 8336597].
Bernard P A, Stenstrom R J, Feldman W, Durieux-Smith A. Randomized, controlled trial comparing long-term sulfonamide therapy to ventilation tubes for otitis media with effusion. Pediatrics. 1991;88:215-222. [pmid: 1861917].
Bernstein J M, Hayes E R, Ishikawa T, Tomasi T B Jr, Herd J K. Secretory otitis media: a histopathologic and immunochemical report. Transactions - American Academy of Ophthalmology and Otolaryngology. 1972;76:1305-1318. [pmid: 4125735].
Bernstein J M, Reisman R. The role of acute hypersensitivity in secretory otitis media. Transactions - American Academy of Ophthalmology and Otolaryngology. 1974;78:ORL120-7. [pmid: 4601138].
Bernstein J M, Okazaki T, Reisman R E. Prostaglandins in middle ear effusions. Arch Otolaryngol. 1976;102:257-258. [pmid: 1267715].
Bernstein J M, Schenkein H A, Genco R J, Bartholomew W R. Complement activity in middle ear effusions. Clin Exp Immunol. 1978;33:340-346. [pmid: 102478]. [pmcid: 1537553].
Bernstein J M, Boerst M, Hayes E R. Mucosubstances in otitis media with effusion. Ann Otol Rhinol Laryngol. 1979;88:334-338. [pmid: 88920].
Bernstein J M, Myers D, Kosinski D, Nisengard R, Wicher K. Antibody coated bacteria in otitis media with effusions. Ann Otol Rhinol Laryngol Suppl. 1980;89:104-9. [pmid: 6778287].
Bernstein J M. Otitis media with effusion: an allergic disease?. Compr Ther. 1980;6:15-21. [pmid: 6771086].
Bernstein J M, Ellis E, Li P. The role of IgE-mediated hypersensitivity in otitis media with effusion. Otolaryngol Head Neck Surg. 1981;89:874-878. [pmid: 6799925].
Bernstein J M, Brentjens J, Vladutiu A. Are immune complexes a factor in the pathogenesis of otitis media with effusion?. Am J Otolaryngol. 1982;3:20-25. [pmid: 7051877].
Bernstein J M, Kano K. Heterophile antibodies in middle ear effusions. Arch Otolaryngol. 1982;108:267-269. [pmid: 7041869].
Bernstein J M, Lee J, Conboy K, Ellis E, Li P. The role of IgE mediated hypersensitivity in recurrent otitis media with effusion. Am J Otol. 1983;5:66-69. [pmid: 6683937].
Bernstein J M, Yamanaka T, Cumella J, Ogra P L. Characteristics of lymphocyte and macrophage reactivity in otitis media with effusion. Acta Oto-Laryngologica - Supplement. 1984;414:131-137.
Bernstein J M. Observations on immune mechanisms in otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1984;8:125-138. [pmid: 6241186].
Bernstein J M, Lee J, Conboy K, Ellis E, Li P. Further observations on the role of IgE-mediated hypersensitivity in recurrent otitis media with effusion. Otolaryngol Head Neck Surg. 1985;93:611-615. [pmid: 3932928].
Bernstein J M, Hard R, Cui Z D, So N, Fisher J, Ogra P L. Human adenoidal organ culture: a model to study nontypable Haemophilus influenzae (NTHI) and other bacterial interactions with nasopharyngeal mucosa--implications in otitis media. Otolaryngol Head Neck Surg. 1990;103:784-791. [pmid: 2126101].
Bernstein JA. Allergic rhinitis. Helping patients lead an unrestricted life. Postgrad Med. 1993;93:124–128, 131–132.
Bernstein J M, Rich G A, Odziemiec C, Ballow M. Are thymus-derived lymphocytes (T cells) defective in the nasopharyngeal and palatine tonsils of children?. Otolaryngol Head Neck Surg. 1993;109:693-700. [pmid: 8233506].
Bernstein J M. The role of IgE-mediated hypersensitivity in the development of otitis media with effusion: a review. Otolaryngol Head Neck Surg. 1993;109:611-620. [pmid: 8414590].
Bernstein J M, Faden H F, Dryja D M, Wactawski-Wende J. Micro-ecology of the nasopharyngeal bacterial flora in otitis-prone and non-otitis-prone children. Acta Otolaryngol. 1993;113:88-92. [pmid: 8442428].
Bernstein J M, Doyle W J. Role of IgE-mediated hypersensitivity in otitis media with effusion: pathophysiologic considerations. Ann Otol Rhinol Laryngol Suppl. 1994;163:15-19. [pmid: 8179263].
Bernstein J M, Sagahtaheri-Altaie S, Dryja D M, Wactawski-Wende J. Bacterial interference in nasopharyngeal bacterial flora of otitis-prone and non-otitis-prone children. Acta Otorhinolaryngol Belg. 1994;48:1-9. [pmid: 8171994].
Bernstein J A. Otitis media in children [letter]. N Engl J Med. 1995;333:1151-1152. [pmid: 7565959].
Bernstein J M. Role of allergy in eustachian tube blockage and otitis media with effusion: a review. Otolaryngol Head Neck Surg. 1996;114:562-568. [pmid: 8643265].
Bernstein J M, Bronson P M, Wilson M E. Immunoglobulin G subclass response to major outer membrane proteins of nontypable Haemophilus influenzae in children with acute otitis media. Otolaryngol Head Neck Surg. 1997;116:363-371. [pmid: 9121792].
Bernstein J M, Ballow M, Xiang S, O'Neil K. Th1/Th2 cytokine profiles in the nasopharyngeal lymphoid tissues of children with recurrent otitis media. Ann Otol Rhinol Laryngol. 1998;107:22-27. [pmid: 9439384].
Bertakis K D. An application of the health belief model to patient education and compliance: acute otitis media. Fam-Med. 1986;18:347-350. [pmid: 3556892].
Berthold H C, Dzendolet E. Sensed movement to sinusoidal angular and electrical stimulation. Percept Mot Skills. 1973;36:23-32. [pmid: 4686716].
Bertin L, Pons G, d'Athis P, et al. A randomized, double-blind, multicentre controlled trial of ibuprofen versus acetaminophen and placebo for symptoms of acute otitis media in children. Fundam-Clin-Pharmacol. 1996;10:387-92. [pmid: 8871138].
Bertrand A M, Chaussain J L, Job B, et al. Three years of GH treatment in Turner's syndrome: Complex effect of GH dosage an growth parameters. Clin Endocrinol. 1996;44:665-671.
Berzon D B. Ear disease in a group general practice. A review of world communities. J Laryngol Otol. 1983;97:817-824. [pmid: 6886542].
Besing J M, Koehnke J. A test of virtual auditory localization. Ear Hear. 1995;16:220-229. [pmid: 7789673].
Bess F H. Impedance screening for children. A need for more research. Ann Otol Rhinol Laryngol Suppl. 1980;89:228-232. [pmid: 6778313].
Bess F H. The minimally hearing-impaired child. Ear Hear. 1985;6:43-47. [pmid: 4038669].
Bess F H, Klee T M. Unilateral sensorineural hearing loss in children. Ear Hear. 1985;7:3-54. [pmid: 3512353].
Beswick A J, Lawley B, Fraise A P, Pahor A L, Brown N L. Detection of Alloiococcus otitis in mixed bacterial populations from middle-ear effusions of patients with otitis media. Lancet. 1999;354:386-389. [pmid: 10437868].
Betow C. Reconstruction of the middle ear and the posterior osseous wall of the auditory canal with homograft (reconstruction of old radical cavities). Transactions - American Academy of Ophthalmology and Otolaryngology. 1975;80:573-576.
Betow C. Use of autograft and homograft TORP and PORP in the reconstruction of the conductive system in the middle ear. Am J Otol. 1985;6:331-333. [pmid: 4025531].
Betz B W, Wiener M D. Air in the temporomandibular joint fossa: CT sign of temporal bone fracture. Radiology. 1991;180:463-466. [pmid: 2068313].
Bhambhani K, Foulds D M, Swamy K N, Eldis F E, Fischel J E. Acute otitis media in children: are decongestants or antihistamines necessary?. Ann-Emerg-Med. 1983;12:13-16. [pmid: 6185020].
Bhatnagar R K. Critical evaluation of Per-Lee tubes in children. J Laryngol Otol. 1990;104:112-113. [pmid: 2324616].
Bhattacharya J, Bennett M J, Tucker S M. Long term follow up of newborns tested with the auditory response cradle. Arch Dis Child. 1984;59:504-511. [pmid: 6540071].
Bhave C G, Gadre K C, Gharpure B S. Myoglobinuria following the use of succinylcholine. J Postgrad Med. 1993;39:157-159. [pmid: 8051650].
Bhaya M H, Schachern P A, Morizono T, Paparella M M. Pathogenesis of tympanosclerosis. Otolaryngol Head Neck Surg. 1993;109:413-420. [pmid: 8414556].
Bhoola D, Hugo R. Prevalence: outer and middle ear disorders in black and Indian preschool children from Durban. South African Journal of Communication Disorders - die Suid-Afrikaanse Tydskrif vir Kommunikasieafwykings. 1995;42:19-27. [pmid: 8928038].
Bicknell M R, Morgan N V. A clinical evaluation of the Zwislocki acoustic bridge. J Laryngol Otol. 1968;82:673-692. [pmid: 5671210].
Bicknell P G. Role of adenotonsillectomy in the management of pediatric ear, nose and throat infections. Pediatr Infect Dis J. 1994;13:S75-S79. [pmid: 8159521].
Biedel C W. Modification of recurrent otitis media by short-term sulfonamide therapy. Am-J-Dis-Child. 1978;132:681-683. [pmid: 665595].
Biedlingmaier J F. Otitis media in children. Medical versus surgical treatment. Postgrad Med. 1993;93:153-155. [pmid: 8460073].
Biedlingmaier JF. Two ear problems you may not need to refer. Otitis externa and bullous myringitis. Postgrad Med. 1994;96:141–145, 148.
Bierman C W, Pierson W E, Donaldson J A. The evaluation of middle ear function in children. Am J Dis Child. 1970;120:233-236. [pmid: 5458557].
Bikhazi P, Ryan A F. Expression of immunoregulatory cytokines during acute and chronic middle ear immune response. Laryngoscope. 1995;105:629-634. [pmid: 7769948].
Bingen E, Bourrillon A. [Resistant pneumococci in pediatrics: therapeutic implications]. Presse Med. 1995;24:137-142. [pmid: 7899346].
Biolcati AH. An open comparative study of the efficacy and safety of sultamicillin versus cefaclor in the treatment of acute otitis media in children. J Int Med Res. 1992:31A-43A.
Birch L, Elbrond O. Prospective epidemiological investigation of secretory otitis media in children attending day-care centers. ORL J Otorhinolaryngol Relat Spec. 1984;46:229-234. [pmid: 6541331].
Birch L, Iversen M, Elbrond O, Lundqvist G R. A prospective epidemiological investigation of secretory otitis media and tubal dysfunction in children attending day-care centers. Serial tympanometry with an interval of two weeks. ORL J Otorhinolaryngol Relat Spec. 1984;46:210-216. [pmid: 6540431].
Birch L, Elbrond O. Daily impedance audiometric screening of children in a day-care institution. Changes through one month. Scand Audiol. 1985;14:5-8. [pmid: 4059845].
Birch L, Elbrond O. Prospective epidemiological study of secretory otitis media in children not attending kindergarten. A prevalence study [published erratum appears in Int J Pediatr Otorhinolaryngol 1986 Nov;12(1):113]. Int J Pediatr Otorhinolaryngol. 1986;11:191-197. [pmid: 3744700].
Birch L, Elbrond O. Prospective epidemiological study of secretory otitis media in children not attending kindergarten. An incidence study. Int J Pediatr Otorhinolaryngol. 1986;11:183-190. [pmid: 3744699].
Birch L, Elbrond O. Prospective epidemiological study of secretory otitis media in children not attending kindergarten. A prevalence study. Int J Pediatr Otorhinolaryngol. 1986;11:191-197. [pmid: 3744700].
Birch L, Elbrond O. A prospective epidemiological study of secretory otitis media in young children related to the indoor environment. ORL J Otorhinolaryngol Relat Spec. 1987;49:253-258. [pmid: 3670806].
Birch L, Elbrond O. Prospective epidemiological study of common colds and secretory otitis media. Clin Otolaryngol Allied Sci. 1987;12:45-48. [pmid: 3493864].
Birck HG, Mravec JJ. Myringostomy for middle ear effusions: Results of a two-year study. The Annals of Otology, Rhinology and Larynogology; 1976:263–267.
Birkin JA, Adams DA, Flanagan RJ, Higson JM. Hearing disability for speech in noise in OME. Br J Audiol. 1998;32.
Birman C S, Fagan P A. Medial canal stenosis--chronic stenosing external otitis. Am J Otol. 1996;17:2-6. [pmid: 8694128].
Birrell J F. Otitis media. Br Med J. 1976;1:443-445. [pmid: 1252785]. [pmcid: 1638938].
Bishop D V, Edmundson A. Is otitis media a major cause of specific developmental language disorders?. British Journal of Disorders of Communication. 1986;21:321-338. [pmid: 3651318].
Bishop D V. The causes of specific developmental language disorder (“development dysphasia”). J Child Psychol Psychiatry. 1987;28:1-8. [pmid: 3558529].
Bisset A F, Russell D. Sex and grommet operations. Clin Otolaryngol. 1993;18:430-432. [pmid: 8877215].
Bisset A F. Glue ear guidelines [letter; comment]. Lancet. 1993;341:57. [pmid: 8093304].
Bisset A F. Persistent glue ear in children [letter; comment]. Br Med J. 1993;306:454-455. [pmid: 8461735].
Bisset F. Glue ear surgery in Scottish children 1990-1994: still plenty of ENT and public health challenges. Clin Otolaryngol. 1997;22:233-238. [pmid: 9222628].
Bisset A. Treatment of glue ear in general practice [letter; comment]. Lancet. 1997;349:134. [pmid: 8996445].
Bitar C N, Steele R W. Use of prophylactic antibiotics in children. Adv Pediatr Infect Dis. 1995;10:227-262. [pmid: 7718208].
Bitar C N, Kluka E A, Steele R W. Mastoiditis in children. Clin Pediatr. 1996;35:391-395.
Bitnun A, Allen U D. Medical therapy of otitis media: Use, abuse, efficacy, and morbidity. J Otolaryngol. 1998;27:26-36. [pmid: 9800637].
Bjuro-Moller M. School audiometry - methods and goals. Scand Audiol Suppl. 1978:13–18.
Black N A. Is glue ear a modern phenomenon? A historical review of the medical literature. Clin Otolaryngol Allied Sci. 1984;9:155-163. [pmid: 6386234].
Black N. Glue ear: the new dyslexia?. Br Med J Clin Res Ed. 1985;290:1963-1965.
Black N, Crowther J, Freeland A. The effectiveness of adenoidectomy in the treatment of glue ear: a randomized controlled trial. Clin-Otolaryngol. 1986;11:149-155. [pmid: 3524910].
Black M M, Gerson L F, Freeland C A, Nair P, Rubin J S, Hutcheson J J. Language screening for infants prone to otitis media. J Pediatr Psychol. 1988;13:423-433. [pmid: 3199297].
Black B. Complications of chronic glue ears. Aust Fam Physician. 1989;18:836–839, 842–843.
Black N A, Sanderson C F, Freeland A P, Vessey M P. A randomised controlled trial of surgery for glue ear [see comments]. Br Med J. 1990;300:1551-1556. [pmid: 2196954]. [pmcid: 1663097].
Black N A, Sanderson C F B, Freeland A P, Vessey M P. A randomised controlled trial of surgery for glue ear. Br Med J. 1990;300:1551-1556. [pmid: 2196954]. [pmcid: 1663097].
Black M M, Sonnenschein S. Early exposure to otitis media: a preliminary investigation of behavioral outcome. J Dev Behav Pediatr. 1993;14:150-155. [pmid: 7688005].
Black N. Surgery for glue ear: the English epidemic wanes. J Epidemiol Community Health. 1995;49:234-237. [pmid: 7629456].
Black B. Mastoidectomy elimination: obliterate, reconstruct, or ablate?. Am J Otol. 1998;19:551-557. [pmid: 9752959].
Blackston M L, Lovchik J C, Gray W C. Presence of Chlamydia trachomatis in tympanocentesis fluid assessed by immunofluorescence microscopy and cell culture. Otolaryngol Head Neck Surg. 1989;100:348-349. [pmid: 2498826].
Blake P, Morrissey G. Canal wall down techniques for managing cholesteatoma. Aust N Z J Surg. 1991;61:914-918. [pmid: 1755772].
Blake P, Busby S. Noise levels in New Zealand junior classrooms: their impact on hearing and teaching. N Z Med J. 1994;107:357-358. [pmid: 8078623].
Blakley B W, Blakley J E. Smoking and middle ear disease: are they related? A review article [see comments]. Otolaryngol Head Neck Surg. 1995;112:441-446. [pmid: 7870447].
Blakley B W, Kim S, VanCamp M. Preoperative hearing predicts postoperative hearing. Otolaryngol Head Neck Surg. 1998;119:559-563. [pmid: 9852525].
Blanshard J D, Maw A R, Bawden R. Conservative treatment of otitis media with effusion by autoinflation of the middle ear. Clin-Otolaryngol. 1993;18:188-192. [pmid: 8365006].
Blatt I M. Fenestration tympanoplasty: an adjunctive technique for hearing restoration. Otolaryngology and Head and Neck Surgery. 1979;87:366-371. [pmid: 492712].
Blayney A W, Colman B H. Dizziness in childhood. Clin Otolaryngol Allied Sci. 1984;9:77-85. [pmid: 6540635].
Blevins NH, Carter BL. Routine preoperative imaging in chronic ear surgery. Am J Otol. 1998;19:527–535; discussion 535–538.
Block S L, Harrison C J, Hedrick J A, et al. Penicillin-resistant Streptococcus pneumoniae in acute otitis media: risk factors, susceptibility patterns and antimicrobial management. Pediatr Infect Dis J. 1995;14:751-759. [pmid: 8559623].
Block J L, Daisy S, Mostaque A K, Waler J A. Index of suspicion. Pediatr Rev. 1996;17:181-184. [pmid: 8935917].
Block S L. Causative pathogens, antibiotic resistance and therapeutic considerations in acute otitis media. Pediatr Infect Dis J. 1997;16:449-456. [pmid: 9109158].
Block SL, Mandel E, McLinn S, et al. Spectral gradient acoustic reflectometry for the detection of middle ear effusion by pediatricians and parents [published erratum appears in Pediatr Infect Dis J 1998 Nov;17(11):1011]. Pediatr Infect Dis J. 1998;17:560–564; discussion 580.
Block S L, Pichichero M E, McLinn S, Aronovitz G, Kimball S. Spectral gradient acoustic reflectometry: detection of middle ear effusion in suppurative acute otitis media. Pediatr Infect Dis J. 1999;18:741-744. [pmid: 10462354].
Blomqvist M, Hedstrom S A. The clinical efficacy and safety of bacampicillin twice daily in comparative studies. J Int Med Res. 1987;15:32-43. [pmid: 3545941].
Bluestone C D, Beery Q C, Paradise J L. Audiometry and tympanometry in relation to middle ear effusions in children. Laryngoscope. 1973;83:594-604. [pmid: 4700869].
Bluestone CD, Beery QC. Adenoidectomy in relation to otitis media. The Annals of Otology, Rhinology and Larynogology; 1976:280–284.
Bluestone CD, Beery QC, Michaels RH, et al. Cefaclor compared with amoxycillin acute otitis media with effusion: a preliminary report. Postgrad-Med-J. 1979:42–49.
Bluestone C D, Cantekin E I. Design factors in the characterization and identification of otitis media and certain related conditions. Ann Otol Rhinol Laryngol Suppl. 1979;88:13-28. [pmid: 115359].
Bluestone C D, Cantekin E I, Douglas G S. Eustachian tube function related to the results of tympanoplasty in children. Laryngoscope. 1979;89:450-458. [pmid: 431249].
Bluestone C D, Cantekin E I. Current clinical methods, indications and interpretation of eustachian tube function tests. Ann Otol Rhinol Laryngol. 1981;90:552-562. [pmid: 7316378].
Bluestone C D. Recent advances in the pathogenesis, diagnosis, and management of otitis media. Pediatr Clin North Am. 1981;28:727-755. [pmid: 7198219].
Bluestone C D. Chronic otitis media with effusion. Pediatr Infect Dis. 1982;1:180-187. [pmid: 6983060].
Bluestone CD. Surgical management of chronic Otitis media with effusion: Myringotomy, tympanostomy tubes, adenoidectomy, and tonsillectomy. Pediatr Infect Dis. 1982;1.
Bluestone CD. Diagnosis of chronic otitis media with effusion: Description, otoscopy, acoustic impedance measurements, and assessment of hearing. Pediatr Infect Dis. 1982;1.
Bluestone C D. Management of chronic otitis media with effusion. Acta Otorhinolaryngol Belg. 1983;37:44-56. [pmid: 6684382].
Bluestone C D. Surgical management of otitis media. Pediatr Infect Dis. 1984;3:392-396. [pmid: 6540871].
Bluestone C D, Carder H M, Coffey J D Jr, et al. Consensus: management of the child with a chronic draining ear. Pediatr Infect Dis. 1985;4:607-612. [pmid: 4080580].
Bluestone C D, Fria T J, Arjona S K, et al. Controversies in screening for middle ear disease and hearing loss in children. Pediatrics. 1986;77:57-70. [pmid: 3940361].
Bluestone C D, Gates G A, Paradise J L, Stool S E. Controversy over tubes and adenoidectomy. Pediatr Infect Dis J. 1988;7:S146-S149. [pmid: 3064039].
Bluestone CD. Otitis media and congenital perilymphatic fistula as a cause of sensorineural hearing loss in children. Pediatr Infect Dis J. 1988;7.
Bluestone CD. Management of otitis media in infants and children: Current role of old and new antimicrobial agents. Pediatr Infect Dis J. 1988;7.
Bluestone CD, Klein JO. Methods of examination: clincial examination. In: Bluestone CD SS, ed. Pediatric Otolaryngogoly 2nd ed. Philadephia: WB Saunders; 1990:chapter 3.
Bluestone CD. Surgery for otitis media: results of randomized clinical trials as related to clinical practice. Adv-Otorhinolaryngol. 1992:319–324.
Bluestone C D. Review of cefixime in the treatment of otitis media in infants and children [see comments]. Pediatr Infect Dis J. 1993;12:75-82. [pmid: 8417430].
Bluestone C D. Surgical management of otitis media: current indications and role related to increasing bacterial resistance. Pediatr Infect Dis J. 1994;13:1058-1063. [pmid: 7845741].
Bluestone C D, Klein J O, Gates G A. Setting the record straight [see comments]. Otolaryngol Head Neck Surg. 1994;120:1051-1053.
Bluestone CD, Klein JO. The appropriateness of tympanostomy tubes for children [letter; comment]. JAMA. 1995;273:697; discussion 700–701.
Bluestone C D, Klein J O. Clinical practice guideline on otitis media with effusion in young children: strengths and weaknesses [editorial]. Otolaryngol Head Neck Surg. 1995;112:507-511. [pmid: 7700654].
Bluestone C D. Pathogenesis of otitis media: role of eustachian tube. Pediatr Infect Dis J. 1996;15:281-291. [pmid: 8866795].
Bluestone CD. Definitions, Terminology, and Classification. In: Rosenfeld RM, Bluestone CD, eds. Evidence-Based Otitis Media . Saint Louis: B.C. Decker, Inc.; 1999:85–103.
Blumer J L, Bertino J S Jr, Husak M p. Comparison of cefaclor and trimethoprim-sulfamethoxazole in the treatment of acute otitis media. Pediatr-Infect- Dis. 1984;3:25-29. [pmid: 6366771].
Blumer J L, Mclinn S E, Deabate C A, Kafetzis D A, Perrotta R J, Salgado O. Multinational multicenter controlled trial comparing ceftibuten with cefaclor for the treatment of acute otitis media. Pediatr Infect Dis. 1995;14:S115-S120.
Blumer J L, Forti W P, Summerhouse T L. Comparison of the efficacy and tolerability of once-daily ceftibuten and twice-daily cefprozil in the treatment of children with acute otitis media. Clin-Ther. 1996;18:811-820. [pmid: 8930425].
Blumer JL. Pharmacokinetics and pharmacodynamics of new and old antimicrobial agents for acute otitis media. Pediatr Infect Dis J. 1998;17:1070–1075; discussion 1099–1100.
Blythe L L. Otitis media and interna and temporohyoid osteoarthropathy. Veterinary Clinics of North America - Equine Practice. 1997;13:21-42.
Bobrov VM. [Ear reoperation and surgical tactics after earlier radical operation]. Vestn Otorinolaringol. 1994:35–36.
Bobrov VM. [A combination of exacerbated chronic suppurative epitympanitis and tick-borne encephalitis]. Vestn Otorinolaringol. 1996:51–52.
Bobrov VM. [Analysis of the pathological process in chronic otitis media: surgical tactics]. Vestn Otorinolaringol. 1997:49–51.
Boccazzi A, Borzani M, Scotti L. [Amocxicillin-clavulanic acid combination in bacterial infections of the upper respiratory tract in childhood. Controlled clinical study]. Pediatr-Med-Chir. 1988;10:395-400. [pmid: 3068633].
Boccazzi A, Careddu P. Acute otitis media in pediatrics: are there rational issues for empiric therapy?. Pediatr Infect Dis J. 1997;16:S65-S69. [pmid: 9076839].
Bockmuhl U, Bruchhage K L, Enzmann H. Primary non-Hodgkin's lymphoma of the temporal bone. Eur Arch Otorhinolaryngol. 1995;252:376-378. [pmid: 8679160].
Bodner E E, Browning G G, Chalmers F T, Chalmers T C. Can meta-analysis help uncertainty in surgery for otitis media in children. J Laryngol Otol. 1991;105:812-819. [pmid: 1753189].
Boedts D, Moerman M, Marquet J. A hairy polyp of the middle ear and mastoid cavity. Acta Otorhinolaryngol Belg. 1992;46:397-400. [pmid: 1462780].
Boedts D. Myringitis granulosa. Acta Otorhinolaryngol Belg. 1995;49:187-189. [pmid: 7610912].
Boedts D. Tympanic membrane perforations. Acta Otorhinolaryngol Belg. 1995;49:149-158. [pmid: 7610907].
Bogomil'skii MR, Sapozhnikov Ia M, Zaslavskii A, Tarutin NP. [The treatment of hypoacusis in children by using a pulsed low-frequency electromagnetic field]. Vestn Otorinolaringol. 1996:23–26.
Bolasco P, Greco A, Monini S. Pharmacological treatment of acute otitis media. Med Riv Encicl Med Ital. 1988;8:419-422.
Boles R. Serous otitis media: thief of hearing and herald of cancer. Medical Times. 1966;94:1333-1338. [pmid: 5922350].
Bollag U, Bollag-Albrecht E. Recommendations derived from practice audit for the treatment of acute otitis media [see comments]. Lancet. 1991;338:96-99. [pmid: 1676479].
Bollag U, Bollag-Albrecht E, Braun-Fahrlander C. The use of acoustic reflectometry in the study of middle ear effusion in children suffering from acute otits media, upper respiratory tract infection and in healthy children [see comments]. Eur J Pediatr. 1996;155:1027-1030. [pmid: 8956938].
Bonacorsi S, Bingen E. Bactericidal activity of erythromycin associated with sulphisoxazole against the infectious agents most frequently responsible for acute infantile otitis media [letter]. J Antimicrob Chemother. 1994;33:885-886. [pmid: 8056713].
Bonadio W A. The evaluation and management of acute otitis media in children. Am J Emerg Med. 1994;12:193-206. [pmid: 8161396].
Bonci M, Bozzi A. Mucoregulating therapy in secreting pathologies of the middle ear. Minerva Med. 1994;85:83-87. [pmid: 8196848].
Bonci M, Bozzi A. [Mucoregulatory therapy in secreting disease of the middle ear]. Minerva-Med. 1994;85:83-87. [pmid: 8196848].
Bonding P, Lorenzen E. Chronic secretory otitis media--long-term results after treatment with grommets. ORL J Otorhinolaryngol Relat Spec. 1974;36:227-235. [pmid: 4215997].
Bonding P, Tos M, Poulsen G. Unilateral insertion of grommets in bilateral secretory otitis media. Tympanometric findings after 1 to 3 years. Acta Oto Laryngologica. 1982;94.
Bonding P, Tos M. Grommets versus paracentesis in secretory otitis media. A prospective, controlled study. Am J Otol. 1985;6:455-460. [pmid: 4073252].
Boon D A. Medical adventure in Nepal. J Otolaryngol. 1980;9:526-533. [pmid: 7206040].
Boon D A. Otology in Nepal. J Otolaryngol. 1990;19:372-373. [pmid: 2280447].
Booth J B. Tympanoplasty. Factors affecting results as determined by audiometry and acoustic impedance measurements. J Laryngol Otol. 1974;88:625-640. [pmid: 4417766].
Borge P. Atopy and secretory otitis media. Immunological studies and responses to topical corticosteroid therapy. J Laryngol Otol. 1983;97:117-129. [pmid: 6681832].
Bosley G S, Whitney A M, Pruckler J M, et al. Characterization of ear fluid isolates of Alloiococcus otitidis from patients with recurrent otitis media. J Clin Microbiol. 1995;33:2876-2880. [pmcid: 228599]. [pmid: 8576338].
Boswell J B, Nienhuys T G. Reflectometric screening for otitis media: inconsistencies in a sample of Australian aboriginal children. Int J Pediatr Otorhinolaryngol. 1993;25:49-60. [pmid: 8436480].
Boswell J, Nienhuys T, Rickards F, Mathews J. Onset of otitis media in Australian Aboriginal infants in a prospective study from birth. Australian Journal of Otolaryngology. 1993;1:232-237.
Boswell J B, Nienhuys T G. Onset of otitis media in the first eight weeks of life in aboriginal and non-aboriginal Australian infants. Ann Otol Rhinol Laryngol. 1995;104:542-549. [pmid: 7598367].
Boswell J. Auditory brainstem response and conductive hearing loss in infants. Australian Journal of Audiology. 1995;17:101-106.
Boswell J B, Nienhuys T G. Patterns of persistent otitis media in the first year of life in aboriginal and non-aboriginal infants. Ann Otol Rhinol Laryngol. 1996;105:893-900. [pmid: 8916866].
Boswell J. Presentation of early otitis media in ‘Top End’ Aboriginal infants. Aust N Z J Public Health. 1997;21:100-102. [pmid: 9141739].
Bottaro G, Rotolo N, Bonforte S, et al. [Evaluation of the clinical efficacy of azithromycin in acute respiratory infections in children]. Clin Ter. 1994;145:35-39. [pmid: 7955949].
Bottrill I D, Poe D S. Endoscope-assisted ear surgery. Am J Otol. 1995;16:158-163. [pmid: 8572114].
Boulesteix J, Begue P, Dubreuil C, et al. Acute otitis media in children: a study of nasopharyngeal carriage of potential pathogens and therapeutic efficacy of cefixime and amoxicillin-clavulanate. Infection. 1995;23 Suppl 2:S79-S82. [pmid: 8537137].
Boulesteix J, Dubreuil C, Moutot M, Rezvani Y, Rosembaum M. Cefpodoxime proxetil five days versus cefixime eight days in the treatment of acute otitis media in children. Medecine Et Maladies Infectieuses. 1995;25:534-539.
Bourgeois F, Lambert-Zechovsky N, Bingen E. [Clinical, diagnostic and therapeutic aspects of Moraxella catarrhalis infections]. Pathol Biol. 1993;41:555-561. [pmid: 8247636].
Bowdler D A, Walsh R M. Comparison of the otoendoscopic and microscopic anatomy of the middle ear cleft in canal wall-up and canal wall-down temporal bone dissections. Clin Otolaryngol Allied Sci. 1995;20:418-422. [pmid: 8582073].
Brackmann D E, Sheehy J L, Luxford W M. TORPs and PORPs in tympanoplasty: a review of 1042 operations. Otolaryngol Head Neck Surg. 1984;92:32-37. [pmid: 6422413].
Brackmann D E. Tympanoplasty with mastoidectomy: canal wall up procedures. Am J Otol. 1993;14:380-382. [pmid: 8238275].
Bradford L J. Understanding and assessing communicative disorders in children. J Dev Behav Pediatr. 1980;1:89-95. [pmid: 7229053].
Bradford B C, Baudin J, Conway M J, Hazell J W, Stewart A L, Reynolds E O. Identification of sensory neural hearing loss in very preterm infants by brainstem auditory evoked potentials. Arch Dis Child. 1985;60:105-109. [pmid: 4038866].
Bradley P J, Manning K P, Shaw M D. Brain abscess secondary to otitis media. J Laryngol Otol. 1984;98:1185-1191. [pmid: 6512390].
Bradley J S, Kaplan S L, Klugman K P, Leggiadro R J. Consensus: management of infections in children caused by Streptococcus pneumoniae with decreased susceptibility to penicillin. Pediatr Infect Dis J. 1995;14:1037-1041. [pmid: 8745014].
Braegger C P, Nadal D. Clarithromycin and pseudomembranous enterocolitis [letter]. Lancet. 1994;343:241-242. [pmid: 7904702].
Bramble D. Two cases of severe head-banging parasomnias in peripubertal males resulting from otitis media in toddlerhood. Child Care Health Dev. 1995;21:247-253. [pmid: 7554105].
Brandes P J, Ehinger D M. The effects of early middle ear pathology on auditory perception and academic achievement. J Speech Hear Disord. 1981;46:301-307. [pmid: 7278176].
Brandow E C Jr. Revision surgery for the mastoid cavity. Otolaryngol Clin North Am. 1974;7:41-56. [pmid: 4591196].
Branger B. [Method of delivery and otitis media (letter; comment)]. Arch Pediatr. 1994;1:106-107. [pmid: 8087210].
Brauer H. Ceftriaxone for otitis media [letter; comment]. Pediatrics. 1993;92:507-508. [pmid: 8361824].
Bredfeldt R C, Ripani A Jr. The effect of an office tympanogram on referrals from a primary care setting. Fam Med. 1987;19:380-382. [pmid: 3678681].
Breitwieser F. [Results of bacteriologic and mycologic investigations of otitis media in dogs]. Tierarztl Prax. 1997;25:257-260. [pmid: 9289887].
Bremond G, Coquin A. Ultrastructure of normal and pathological middle ear mucosa. J Laryngol Otol. 1972;86:457-472. [pmid: 5032990].
Brenman A K, Milner R M, Weller C R. Use of hydrogen peroxide to clear blocked ventilation tubes. Am J Otol. 1986;7:47-50. [pmid: 3946581].
Brennan D F, Falk J L, Rothrock S G, Kerr R B. Infrared tympanic thermometry in the evaluation of pediatric acute otitis media. Acad Emerg Med. 1994;1:354-359. [pmid: 7614281].
Briggs D R, Applebaum E L, Noffsinger D. Eustachian tube function in children. J Otolaryngol. 1976;5:12-18. [pmid: 1053264].
Briggs A, Sculpher M. Commentary: Markov models of medical prognosis [comment]. Br Med J. 1997;314:354-355. [pmid: 9040334].
Brigino E, Bahna S L. Clinical features of food allergy in infants. Clin Rev Allergy Immunol. 1995;13:329-345. [pmid: 8680953].
Brill A H, Martin M M, Fitz-Hugh G S, Constable W C. Postoperative and postradiotherapeutic serous otitis media. Arch Otolaryngol. 1974;99:406-408. [pmid: 4829759].
Britton B H. Radiologic evaluation of sensorineural hearing loss. Otolaryngol Clin North Am. 1978;11:3-6. [pmid: 662352].
Brockbank M J, Jonathan D A, Grant H R, Wright A. Goode T-tubes: do the benefits of their use outweigh their complications?. Clin Otolaryngol Allied Sci. 1988;13:351-356. [pmid: 3243011].
Brockman S J. The enigma of secretory otitis media. Transactions - American Academy of Ophthalmology and Otolaryngology. 1972;76:1296-1304. [pmid: 4666580].
Brockman S J. Method of reconstruction or preservation of external auditory canal. Laryngoscope. 1981;91:883-885. [pmid: 6894626].
Brodie D P, Griggs J V, Cunningham K. Comparative study of cefuroxime axetil suspension and amoxycillin syrup in the treatment of acute otitis media in general practice. J Int Med Res. 1990;18:235-239. [pmid: 2113874].
Brodie H A, Chang P S, Chole R A. Dexamethasone inhibition of the development of dysplastic bony lesions in LP/J mice. Ann Otol Rhinol Laryngol. 1993;102:814-817. [pmid: 8215105].
Brodsky L, Brookhauser P, Chait D, et al. Office-based insertion of pressure equalization tubes: The role of laser-assisted tympanic membrane fenestration. Laryngoscope. 1999;109:2009-2014. [pmid: 10591365].
Broen P A, Moller K T, Carlstrom J, Doyle S S, Devers M, Keenan K M. Comparison of the hearing histories of children with and without cleft palate. Cleft Palate Craniofac J. 1996;33:127-133. [pmid: 8695620].
Bronstein J M, Johnson V A, Fargason C A Jr. Impact of care setting on cost and quality under Medicaid. J Health Care Poor Underserved. 1997;8:202-213. [pmid: 9114628].
Brook I, Gober A E. Microbiologic characteristics of persistent otitis media. Arch Otolaryngol Head and Neck Surgery. 1350;124:1350-1352.
Brook I. Role of Pseudomonas aeruginosa in chronic suppurative otitis media [letter]. Pediatr Infect Dis J. 1993;12:355-356. [pmid: 8483637].
Brook I. Otitis media: microbiology and management. J Otolaryngol. 1994;23:269-275. [pmid: 7996627].
Brook I, Van de Heyning P H. Microbiology and management of otitis media. Scandinavian Journal of Infectious Diseases - Supplementum. 1994;93:20-32. [pmid: 8047854].
Brook I. Management of chronic suppurative otitis media: superiority of therapy effective against anaerobic bacteria. Pediatr Infect Dis J. 1994;13:188-193. [pmid: 8177625].
Brook I, Yocum P. Bacteriology and beta-lactamase activity in ear aspirates of acute otitis media that failed amoxicillin therapy. Pediatr Infect Dis J. 1995;14:805-808. [pmid: 8559633].
Brook I. Anaerobic infections in children with neurological impairments. Am J Ment Retard. 1995;99:579-594. [pmid: 7632426].
Brook I. Role of anaerobic bacteria in chronic otitis media and cholesteatoma. Int J Pediatr Otorhinolaryngol. 1995;31:153-157. [pmid: 7782173].
Brook I, Santosa G. Microbiology of chronic suppurative otitis media in children in Surabaya, Indonesia. Int J Pediatr Otorhinolaryngol. 1995;31:23-28. [pmid: 7729990].
Brook I. Clostridial infection in children. J Med Microbiol. 1995;42:78-82. [pmid: 7869351].
Brook I, Gober A E. Prophylaxis with amoxicillin or sulfisoxazole for otitis media: effect on the recovery of penicillin-resistant bacteria from children. Clin-Infect-Dis. 1996;22:143-145. [pmid: 8824982].
Brook I, Frazier E H. Microbial dynamics of persistent purulent otitis media in children. J Pediatr. 1996;128:237-240. [pmid: 8636819].
Brook I, Gober A E. Bacterial colonization of pacifiers of infants with acute otitis media. J Laryngol Otol. 1997;111:614-615. [pmid: 9282196].
Brook I, Yocum P. Bacterial interference in the adenoids of otitis media-prone children. Pediatr Infect Dis J. 1999;18:835-836. [pmid: 10493351].
Brooker D S, McNeice A. Autoinflation in the treatment of glue ear in children. Clin Otolaryngol Allied Sci. 1992;17:289-290. [pmid: 1526044].
Brookhouser P E, Hixson P K, Matkin N D. Early childhood language delay: the otolaryngologist's perspective. Laryngoscope. 1979;89:1898-1913. [pmid: 513912].
Brookhouser P E, Goldgar D E. Medical profile of the language-delayed child: otitis-prone versus otitis-free. Int J Pediatr Otorhinolaryngol. 1987;12:237-271. [pmid: 3583581].
Brookhouser P E, Worthington D W, Kelly W J. Middle ear disease in young children with sensorineural hearing loss. Laryngoscope. 1993;103:371-378. [pmid: 8459744].
Brookhouser PE. Use of tympanometry in office practice for diagnosis of otitis media. Pediatr Infect Dis J. 1998;17:544–551; discussion 580.
Brooks D N, Dogra T S. Long term results of treatment of middle ear effusion. J Laryngol Otol. 1107;94:1107-1115. [pmid: 7430772].
Brooks D N. A new approach to identification audiometry. Audiology. 1971;10:334-339. [pmid: 5163664].
Brooks D N. Electroacoustic impedance bridge studies on normal ears of children. J Speech Hear Res. 1971;14:247-253. [pmid: 5558077].
Brooks D N. Impedance bridge studies on normal hearing and hearing-impaired children. Acta Otorhinolaryngol Belg. 1974;28:140-145. [pmid: 4837380].
Brooks D N. Middle ear effusion in children. J Otolaryngol. 1976;5:453-458. [pmid: 1011325].
Brooks D N. School screening for middle ear effusions. Ann Otol Rhinol Laryngol. 1976;85:223-228. [pmid: 1267351].
Brooks D N. Auditory screening--time for reappraisal. Public Health. 1977;91:282-288. [pmid: 594291].
Brooks D N. Middle-ear impedance measurements in screening. Audiology. 1977;16:288-293. [pmid: 883909].
Brooks D N. Otitis media and child development. Design factors in the identification and assessment of hearing loss. Ann Otol Rhinol Laryngol. 1979;88:29-47.
Brooks D N. Possible long-term consequences of middle ear effusion. Ann Otol Rhinol Laryngol Suppl. 1980;89:246-248. [pmid: 6778317].
Brooks D N, Dogra T S. Long term results of treatment of middle ear effusion. J Laryngol Otol. 1980;94:1107-1115. [pmid: 7430772].
Brooks D N. Development of school screening audiometry. Br J Audiol. 1981;15:283-290. [pmid: 7296109].
Brooks D N. Four years of British audiology. Br J Audiol. 1984;18:1-5. [pmid: 6539139].
Brooks D N. Acoustic impedance measurement as screening procedure in children: discussion paper. J R Soc Med. 1985;78:119-121. [pmid: 3973870]. [pmcid: 1289581].
Brooks D N. Otitis media with effusion and academic attainment. Int J Pediatr Otorhinolaryngol. 1986;12:39-47. [pmid: 3818189].
Brostoff C, Cantekin EI. Observer invariant diagnosis of middle ear effusion. In: Lim D ea, ed. Recent Advances in Otitis Media: Proceedings of the Fourth International Symposium. Bar Harbor, Main: BC Decker; 1988:47–49.
Brown M. E.N.T. disease among Australian aborigines. The extent of E.N.T. disease in the aboriginal population of the northern territory. J Otolaryngolog Soc Aust. 1972;3:327-329.
Brown M J, Richards S H, Ambegaokar A G. Grommets and glue ear: a five-year follow up of a controlled trial. J-R-Soc-Med. 1978;71:353-356. [pmid: 650647]. [pmcid: 1436597].
Brown H M. Glue ear guidelines [letter; comment]. Lancet. 1993;341:57. [pmid: 8093305].
Brown J A. Management of ventilation tubes: preventing premature extrusion. Journal - South Carolina Medical Association. 1993;89:427-430. [pmid: 8231117].
Brown D P. Speech recognition in recurrent otitis media: results in a set of identical twins. J Am Acad Audiol. 1994;5:1-6. [pmid: 8155888].
Brown J L. Humming test for conductive hearing loss [letter]. Lancet. 1995;346:128. [pmid: 7603203].
Browning G G, Picozzi G L, Calder I T, Sweeney G. Controlled trial of medical treatment of active chronic otitis media. Br Med J Clin Res Ed. 1983;287:1024.
Browning G G, Gatehouse S. Acoustical characteristics of surgically altered human temporal bones. Clin Otolaryngol Allied Sci. 1984;9:87-91. [pmid: 6467648].
Browning G G. Is there still a role for tuning-fork tests?. Br J Audiol. 1987;21:161-163. [pmid: 3620750].
Browning G G, Gatehouse S, Calder I T. Medical management of active chronic otitis media: a controlled study. J Laryngol Otol. 1988;102:491-495. [pmid: 3294318].
Browning G G, Gatehouse S. Hearing in chronic suppurative otitis media. Ann Otol Rhinol Laryngol. 1989;98:245-250. [pmid: 2705698].
Browning G G. The effect of anaesthesia on tympanograms of children undergoing grommet insertion. Clin. Otolaryngol. 17, 200–202 [letter; comment]. Clin Otolaryngol. 1994;19:174. [pmid: 8026098].
Browning G G. Choice, advice and assessment of patients for ear surgery. J R Soc Med. 1996;89:571-576. [pmid: 8976893]. [pmcid: 1295959].
Browning G G. Do patients and surgeons agree?: the Gordon Smyth Memorial Lecture. Clin Otolaryngol Allied Sci. 1997;22:485-496. [pmid: 9466055].
Brownlee R C Jr, DeLoache W R, Cowan C C Jr, Jackson H P. Otitis media in children. Incidence, treatment, and prognosis in pediatric practice. J Pediatr. 1969;75:636-642. [pmid: 5809840].
Broydhouse N. Bromhexine in the Treatment of Otitis Media with Effusion. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:265–269.
Bruyette D S, Lorenz M D. Otitis externa and otitis media: diagnostic and medical aspects. Seminars in Veterinary Medicine and Surgery (Small Animal). 1993;8:3-9. [pmcid: 200744]. [pmid: 8456201].
Bryan D C. An investigation into the accuracy and validity of three points used in the assessment of autorotation in orthognathic surgery. Br J Oral Maxillofac Surg. 1994;32:363-372. [pmid: 7848995].
Bubon M S. Documented instance of restored conductive hearing loss. Functional Orthodontist. 1995;12:26-29. [pmid: 8613110].
Buchman E, Rosenhouse G, Shupak A, Shimoni U. On the transmission of sound generated by an electromagnetic device from the mastoid process to the petrous bone. J Acoust Soc Am. 1991;90:895-903. [pmid: 1939894].
Buchman C A, Doyle W J, Swarts J D. Eustachian tube function in the ferret. Acta Otolaryngol. 1993;113:75-80. [pmid: 8442426].
Buchman C A, Stool S E. Functional-anatomic correlation of eustachian tube obstruction related to the adenoid in a patient with otitis media with effusion: a case report. Ear Nose Throat J. 1994;73:835-838. [pmid: 7828477].
Buchman C A, Doyle W J, Skoner D, Fireman P, Gwaltney J M. Otologic manifestations of experimental rhinovirus infection. Laryngoscope. 1994;104:1295-1299. [pmid: 7934605].
Buchman C A, Doyle W J, Skoner D P, et al. Influenza A virus--induced acute otitis media. J Infect Dis. 1995;172:1348-1351. [pmid: 7594675].
Buchman C A, Swarts J D, Seroky J T, Panagiotou N, Hayden F, Doyle W J. Otologic and systemic manifestations of experimental influenza A virus infection in the ferret. Otolaryngol Head Neck Surg. 1995;112:572-578. [pmid: 7700664].
Buchwach KA, Birck HG. Serous Otitis Media and Type 1 Tympanoplasties in Children: A Retrospective Study. Proceedings of the Second International Symposium: Recent Advances in Otitis Media with Effusion; 1980:324–325.
Buck S H, Mahoney M C, Ginsberg I A, Hoffman S R, White T. Correlates of cochlear implantation, 1986-1992. Otolaryngol Head Neck Surg. 1996;114:22-26. [pmid: 8570245].
Buckingham R A, Valvassori G E. Correlation of surgical and tomographic findings in cholesteatoma of the middle ear and mastoid. Transactions - American Academy of Ophthalmology and Otolaryngology. 1967;71:673-681. [pmid: 6059679].
Buckingham R A, Valvassori G E. Tomographic and surgical pathology of cholesteatoma. Arch Otolaryngol. 1970;91:464-469. [pmid: 5442738].
Buckingham R A, Ferrer J L. Observations of middle ear pressures. Commentary with movie. Ann Otol Rhinol Laryngol Suppl. 1980;89:56-61. [pmid: 6778351].
Buckingham R A. Middle ear gas generation in myringoplasties. Ann Otol Rhinol Laryngol. 1990;99:335-336. [pmid: 2337311].
Buckley G, Hinton A. Otitis media with effusion in children shows a progressive resolution with time. Clin Otolaryngol Allied Sci. 1991;16:354-357. [pmid: 1934548].
Buckley K M, Taylor G A, Estroff J A, Barnewolt C E, Share J C, Paltiel H J. Use of the mastoid fontanelle for improved sonographic visualization of the neonatal midbrain and posterior fossa. AJR. American Journal of Roentgenology. 1997;168:1021-1025. [pmid: 9124108].
Buffin J T. Ear infections. Practitioner. 1979;223:776-780. [pmid: 542446].
Buhrer K, Wall L G, Schuster L. The acoustic reflectometer as a screening device: a comparison. Ear Hear. 1985;6:307-314. [pmid: 4076555].
Bull T R, McKelvie P. Irradiation treatment of secretory otitis media: recent experience. J Laryngol Otol. 1968;82:745-756. [pmid: 5671215].
Bullido Gomez de las Heras E, Domingo Carrasco C, Guerrero Rios J A, et al. [The mastoid surgery in children at the Doce de Octubre Hospital. Review of the years 1988-1991]. Acta Otorrinolaringol Esp. 1994;45:237-242. [pmid: 7917473].
Bulman C H, Brook S J, Berry M G. A prospective randomized trial of adenoidectomy vs grommet insertion in the treatment of glue ear. CLIN-OTOLARYNGOL. 1984;9:67-75. [pmid: 6380828].
Bundo J, Watanabe N, Yoshida K, Mogi G. Study on adhesion factors in lymphocyte migration to the middle ear mucosa. Ann Otol Rhinol Laryngol. 1996;105:795-803. [pmid: 8865775].
Bunse T, Hildmann H, Zan W, Opferkuch W. An immunological study of otitis media with effusion. Antibodies directed against coagulase-negative staphylococci in the effusion fluid. Arch Otorhinolaryngol. 1987;244:123-126. [pmid: 3662924].
Burch J V, Leveille A S, Morse P H. Ichthyosis hystrix (epidermal nevus syndrome) and Coats' disease. Am J Ophthalmol. 1980;89:125-130.
Burggraaff B, Luxford W M, Doyle K J. Neurotologic treatment of acquired cholesteatoma. Am J Otol. 1995;16:480-485. [pmid: 8588649].
Burke P. The diagnosis and management of the discharging ear. Practitioner 1989;233:742, 744, 746.
Burke P, Jones W. Pneumatic otoscopy in the diagnosis of middle ear effusion: the use of video as a teaching aid. J Audiov Media Med. 1989;12:26-28. [pmid: 2809076].
Burke P. Otitis media with effusion: is medical management an option?. J R Coll Genl Practitioners. 1989;39:377-382.
Burke P, Bain J, Robinson D, Dunleavey J. Acute red ear in children: controlled trial of non-antibiotic treatment in general practice. Br Med J. 1991;303:558-562. [pmid: 1912887]. [pmcid: 1670875].
Burton D M, Seid A B, Kearns D B, Pransky S M. Neonatal otitis media. An update. Arch Otolaryngol Head Neck Surg. 1993;119:672-675. [pmid: 8499100].
Burton M J, Shepherd R K, Xu S A, Xu J, Franz B K, Clark G M. Cochlear implantation in young children: histological studies on head growth, leadwire design, and electrode fixation in the monkey model. Laryngoscope. 1994;104:167-175. [pmid: 8302119].
Bush P J, Rabin D L, Spector K K. Evaluation of a drug therapy protocol in an HMO. Med Care. 1979;17:566-577. [pmid: 449432].
Bushong S C, Glaze S A, Foster J K, Copley R L, Miller J T. Panoramic dental radiography for mass screening?. Health Phys. 1973;25:489-494. [pmid: 4786578].
Buslau M, Biermann H, Shah P M. [Gram-positive septic-toxic shock with bullae. Intraepidermal splitting as an indication of toxin effect]. Hautarzt. 1996;47:783-789. [pmid: 9036130].
Byers V W. Conductive SISI test. Ann Otol Rhinol Laryngol. 1974;83:125-127. [pmid: 4811575].
Bylander A. Function and dysfunction of the eustachian tube in children. Acta Otorhinolaryngol Belg. 1984;38:238-245. [pmid: 6516830].
Bylander A. Upper respiratory tract infection and eustachian tube function in children. Acta Otolaryngol. 1984;97:343-349. [pmid: 6539043].
Bylander-Groth A, Stenstrom C. Eustachian tube function and otitis media in children. Ear Nose Throat J. 1998;77.
Byrns P J, Bondy J, Glazner J E, Berman S. Utilization of services for otitis media by children enrolled in Medicaid. Arch Pediatr Adolesc Med. 1997;151:407-413. [pmid: 9111441].
Caffarelli C, Cavagni G, Giordano S, Savini E, Piacentini G. Increased nasal eosinophils in children with otitis media with effusion. Otolaryngol Head Neck Surg. 1996;115:454-457. [pmid: 8903447].
Caffarelli C, Savini E, Giordano S, Gianlupi G, Cavagni G. Atopy in children with otitis media with effusion. Clin Exp Allergy. 1998;28:591-596. [pmid: 9645596].
Caldarelli D D. Incidence and type of otopathology associated with congenital palatopharyngeal incompetence. Laryngoscope. 1978;88:1970-1982. [pmid: 569749].
Calderon E, Gatica R, Echaniz G, et al. Treatment of presumed bacterial pneumonia in ambulatory children. Clin-Ther. 1991;13:699-706. [pmid: 1790545].
Callahan C W Jr, Lazoritz S. Otitis media and language development. Am Fam Physician. 1988;37:186-190. [pmid: 3284303].
Cameron G G, Pomahac A C, Johnston M T. Comparative efficacy of ampicillin and trimethoprim-sulfamethoxazole in otitis media. Can-Med-Assoc-J. 1975;112:87-88. [pmid: 1093657].
Camilleri A E, Swan I R, Sturrock R. Chronic otitis media and ankylosing spondylitis: an HLA association?. Clin Otolaryngol Allied Sci. 1991;16:364-366. [pmid: 1934550].
Campagnari A A, Ducey T F, Rebmann C A. Outer membrane protein B1, an iron-repressible protein conserved in the outer membrane of Moraxella (Branhamella) catarrhalis, binds human transferrin. Infect Immun. 1996;64:3920-3924. [pmcid: 174315]. [pmid: 8751951].
Campbell J P, Pillsbury H Cd. The use of computerized tomographic imaging in revision mastoid surgery for chronic otitis media. Am J Otol. 1990;11:387-394. [pmid: 2285057].
Campbell J B, Nigam A. Hearing aid prescribing: is the specialist opinion necessary?. Clin Otolaryngol Allied Sci. 1991;16:124-127. [pmid: 2070525].
Campbell G, Renner G, Estrem S A. Bilateral aberrant internal carotid arteries. Otolaryngol Head Neck Surg. 1992;107:124-128. [pmid: 1528593].
Campbell D G, Daniel H Jd, Hume W G. Aging and otitis media as sources of variance in the rat auditory brainstem response. Hear Res. 1993;70:127-130. [pmid: 8276729].
Campbell N, Hugo R, Uys I, Hanekom J, Millard S. Early recurrent otitis media, language and central auditory processing in children. South African Journal of Communication Disorders - die Suid-Afrikaanse Tydskrif vir Kommunikasieafwykings. 1995;42:73-84. [pmid: 8928046].
Campos M A, Arias A, Rodriguez C, et al. Etiology and therapy of chronic suppurative otitis. J Chemother. 1995;7:427-431. [pmid: 8596126].
Canafax D M, Russlie H, Lovdahl M J, Erdmann G R, Le C T, Giebink G S. Comparison of two otitis media models for the study of middle ear antimicrobial pharmacokinetics. Pharm Res. 1994;11:855-859. [pmid: 7937525].
Canafax D M, Giebink G S. Antimicrobial treatment of acute otitis media. Ann Otol Rhinol Laryngol Suppl. 1994;163:11-14. [pmid: 8179262].
Cannon C R. Early otorrhea following ear tube insertion. J-Miss-State-Med-Assoc. 1997;38:39-43. [pmid: 9048472].
Cannoni M, Bonfils P, Sednaoui P, Sevenier F, Joubert-Collin M, Nisse D S. Cefotiam hexetil versus amoxicillin/clavulanic acid for the treatment of chronic otitis media in adults. EFFICACITE ET TOLERANCE DU CEFOTIAM HEXETIL VERSUS AMOXICILLINE/ACIDE CLAVULANIQUE DANS LE TRAITEMENT DE L'OTITE MOYENNE CHRONIQUE DE L'ADULTE. Medecine Et Maladies Infectieuses. 1997;27:915-921.
Cantekin E I, Beery Q C, Bluestone C D. Tympanometric patterns found in middle ear effusions. Ann Otol Rhinol Laryngol Suppl. 1977;86:16-20. [pmid: 407828].
Cantekin E I, Bluestone C D, Rockette H E, Beery Q C. Effect of decongestant with or without antihistamine on eustachian tube function. Ann-Otol-Rhinol-Laryngol-Suppl. 1980;89:290-295. [pmid: 6778330].
Cantekin E I, Bluestone C D, Fria T J, Stool S E, Beery Q C, Sabo D L. Identification of otitis media with effusion in children. Ann Otol Rhinol Laryngol Suppl. 1980;89:190-196. [pmid: 6778304].
Cantekin E I, Mandel E M, Bluestone C D, et al. Lack of efficacy of a decongestant-antihistamine combination for otitis media with effusion (“secretory” otitis media) in children. Results of a double-blind, randomized trial. N Engl J Med. 1983;308:297-301. [pmid: 6337322].
Cantekin E I. Algorithm for diagnosis of otitis media with effusion. Ann Otol Rhinol Laryngol. 1983;92:6.
Cantekin E I. Antibiotics for secretory otitis media (I). Arch Otolaryngol Head and Neck Surgery. 1990;116:626-628.
Cantekin E I, McGuire T W, Griffith T L. Antimicrobial therapy for otitis media with effusion (‘secretory’ otitis media) [see comments]. JAMA. 1991;266:3309-3317. [pmid: 1683673].
Cantekin E I, McGuire T W, Griffith T L. Antimicrobial therapy for otitis media with effusion (‘secretory’ otitis media). JAMA. 1991;266:3309-3317. [pmid: 1683673].
Cantekin EI. Antimicrobial therapy for otitis media with effusion: the Pittsburgh response [letter; comment]. JAMA. 1993;270:449; discussion 450.
Cantekin E I. Antibiotics to prevent acute otitis media and to treat otitis media with effusion [letter; comment]. JAMA. 1994;272:203-204. [pmid: 8022038].
Cantekin E I. Otitis media [letter; comment]. Arch Otolaryngol Head Neck Surg. 1995;121:702-704. [pmid: 7632252].
Cantekin EI. The appropriateness of tympanostomy tubes for children [letter; comment]. JAMA. 1995;273:697–698; discussion 700–701.
Cantekin E I. Bacterial DNA fragments in otitis media with effusion [letter; comment]. JAMA. 1996;275:186. [pmid: 8604167].
Cantekin E I. Ceftriaxone for acute otitis media [letter]. Pediatrics. 1997;100:157-158. [pmid: 9229708].
Cantekin E I. Treatment of glue ear in general practice [letter; comment]. Lancet. 1997;349:133-134. [pmid: 8996444].
Cantekin E I, Linder T E. Aggressive and ineffective therapy for otitis media. Oto Rhino Laryngologia Nova. 1998;8:136-147.
Canterbury D R. Public health audiology in rural Alaska: an interagency approach. ASHA. 1978;20:887-890. [pmid: 718734].
Cantor R M. Otitis externa and otitis media. A new look at old problems. Emerg Med Clin North Am. 1995;13:445-455. [pmid: 7737028].
Capo O A. Serous otitis media in children. Importance of prevention and early diagnosis. Ohio State Medical Journal. 1970;66:1112-1114. [pmid: 5474683].
Capper J W, Slack R W, Maw A R. Tuning fork tests in children (an evaluation of their usefulness). J Laryngol Otol. 1987;101:780-783. [pmid: 3655529].
Caprio D, Strunski V, Batteur B, et al. [Audiometric results of 81 ossiculoplasties after tympanoplasty with closed technique in chronic cholesteatomatous otitis]. Ann Otolaryngol Chir Cervicofac. 1995;112:107-117. [pmid: 7486707].
Carbonell Sanchis R, Marco Algarra J. [Influence of secretory otitis media on mastoid pneumatization. Multiple regression analysis]. Acta Otorrinolaringol Esp. 1996;47:209-212. [pmid: 8924285].
Careddu P, Bellosta C, Tonelli P, Boccazzi A. Efficacy and tolerability of brodimoprim in pediatric infections. J Chemother. 1993;5:543-545. [pmid: 8195853].
Carlin W V, Lesser T H, John D G, et al. Systemic antibiotic prophylaxis and reconstructive ear surgery. Clin-Otolaryngol. 1987;12:441-446. [pmid: 3327637].
Carlin S A, Marchant C D, Shurin P A, Johnson C E, Murdell-Panek D, Barenkamp S J. Early recurrences of otitis media: reinfection or relapse? [published erratum appears in J Pediatr 1987 Apr;110(4):668]. J Pediatr. 1987;110:20-25. [pmid: 3540247].
Carlson LH and Stool SE. Diagnosis. In: Rosenfeld RM and Bluestone CD, editors. Evidence-Based Otitis Media. Saint Louis, B.C.: Decker Inc.; 1999. p. 105–116.
Carlsson B, Lundberg C, Ohlsson K. Protease inhibitors in middle ear effusions. Ann Otol Rhinol Laryngol. 1981;90:38-41. [pmid: 6162410].
Carr R. Radiological aspects of recurrent meningitis. Proceedings of the Royal Society of Medicine. 1974;67:1147-1150. [pmid: 4548193]. [pmcid: 1646004].
Carre P, Wodey E, Lucas M M, Colin L, Gruel Y, Malledant Y. [Septic thrombophlebitis of the lateral sinus: a rare but severe complication of mastoiditis in children]. Cah Anesthesiol. 1996;44:231-234. [pmid: 9005013].
Carroll W L, Farrell M K, Singer J I, Jackson M A, Lobel J S, Lewis E D. Treatment of occult bacteremia: a prospective randomized clinical trial. Pediatrics. 1983;72:608-612. [pmid: 6356004].
Carroll K, Reimer L. Microbiology and laboratory diagnosis of upper respiratory tract infections [see comments]. Clin Infect Dis. 1996;23:442-448. [pmid: 8879762].
Carter J A. Correction of deafness. J Med Assoc Ga. 1971;60:330-332. [pmid: 5118314].
Carter L C, Haller A D, Calamel A D, Pfaffenbach A C. Zygomatic air cell defect (ZACD). Prevalence and characteristics in a dental clinic outpatient population. Dento-Maxillo-Facial Radiology. 1999;28:116-122. [pmid: 10522201].
Casellas J M, Rodriguez H A, Fernandez MacLoughlin G J, Lanoel J L, Iribarren A. Efficacy of roxithromycin in the treatment of acute otitis media in infants. Br J Clin Pract. 1988;42:113-114.
Cass R, Kaplan P. Middle ear disease and learning problems: a school system's approach to early detection. J Sch Health. 1979;49:557-560. [pmid: 260791].
Casselbrant M L, Brostoff L M, Cantekin E I, et al. Otitis media with effusion in preschool children. Laryngoscope. 1985;95:428-436. [pmid: 4039020].
Casselbrant M L, Brostoff L M, Cantekin E I, Ashoff V M, Bluestone C D. Incidence, prevalence, and natural history of otitis media in children in Pittsburgh. Ann Otol Rhinol Laryngol. 1990;99:28-29.
Casselbrant M L, Kaleida P H, Rockette H E, et al. Efficacy of antimicrobial prophylaxis and of tympanostomy tube insertion for prevention of recurrent acute otitis media: results of a randomized clinical trial [see comments]. Pediatr Infect Dis J. 1992;11:278-286. [pmid: 1565551].
Casselbrant M L, Kaleida P H, Rockette H E, et al. Efficacy of antimicrobial prophylaxis and of tympanostomy tube insertion for prevention of recurrent acute otitis media: Results of a randomized clinical trial. Pediatr Infect Dis J. 1992;11:278-286. [pmid: 1565551].
Casselbrant M L, Mandel E M, Kurs-Lasky M, Rockette H E, Bluestone C D. Otitis media in a population of black American. And white American infants, 0–2 years of age. Int J Pediatr Otorhinolaryngol. 1995;33:1-16. [pmid: 7558637].
Casselbrant M L, Furman J M, Rubenstein E, Mandel E M. Effect of otitis media on the vestibular system in children. Ann Otol Rhinol Laryngol. 1995;104:620-624. [pmid: 7639471].
Casselbrant MI, Mandel EM, Kurs-Lasky M, Bluestone CD. Efficacy of ceftibuten compared with amoxicillin for otitis media with effusion in infants and children. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:229–231.
Casselbrant M L, Redfern M S, Furman J M, Fall P A, Mandel E M. Visual-induced postural sway in children with and without otitis media. Ann Otol Rhinol Laryngol. 1998;107:401-405. [pmid: 9596218].
Casselman J W, Ars B, Van de Heyning P, Koekelkoren E. Preoperative computed tomography in patients requiring a bone-anchored hearing aid. Eur Arch Otorhinolaryngol. 1995;252:401-404. [pmid: 8562034].
Castiglia P T, Aquilina S S, Kemsley M. Focus: nonsuppurative otitis media. Pediatr Nurs. 1983;9:427-431. [pmid: 6557450].
Castillo M, Albernaz V S, Mukherji S K, Smith M M, Weissman J L. Imaging of Bezold's abscess. AJR. American Journal of Roentgenology. 1998;171:1491-1495. [pmid: 9843276].
Castro R, Robinson N, Klein J, Geimeier W. Malignant external otitis and mastoiditis associated with an IgG4 subclass deficiency in a child. Del Med J. 1990;62:1417-1421. [pmid: 2079118].
Catlin F I. Prevention of hearing impairment from infection and ototoxic drugs. Arch Otolaryngol. 1985;111:377-384. [pmid: 2988488].
Cavaliere F, Masieri S, Liberini L, Proietti R, Magalini S I. Tympanometry for middle-ear effusion in unconscious ICU patients. Eur J Anaesthesiol. 1992;9:71-75. [pmid: 1735401].
Cavaliere F, Masieri S. Chronic middle ear effusion after prolonged intubation [letter]. Anaesthesia. 1994;49:641-642. [pmid: 8042738].
Cavanaugh R M Jr. Pediatricians and the pneumatic otoscope: are we playing it by ear?. Pediatrics. 1989;84:362-364. [pmid: 2748268].
Cavanaugh RMJ Quantitative pneumatic otoscopy in pediatric patients with normal and abnormal tympanic membrane mobility.1992:39–40
Caye-Thomasen P, Hermansson A, Tos M, Prellner K. Changes in goblet cell density in rat middle ear mucosa in acute otitis media. Am J Otol. 1995;16:75-82. [pmid: 8579181].
Caye-Thomasen P, Hermansson A, Tos M, Prellner K. Polyp pathogenesis--a histopathological study in experimental otitis media. Acta Otolaryngol. 1995;115:76-82. [pmid: 7762390].
Caye-Thomasen P, Tos M. Mast cell clusters in pars tensa membranae tympani in acute otitis media: a possible role in perforation healing. Acta Otolaryngol. 1996;116:845-849. [pmid: 8973719].
Caye-Thomasen P, Hermansson A, Tos M, Prellner K. Penicillin reduces secretory capacity in rat middle ear mucosa in acute otitis media. Am J Otol. 1996;17:354-359. [pmid: 8723976].
Caye-Thomasen P, Hermansson A, Tos M, Prellner K. Pathogenesis of middle ear adhesions. Laryngoscope. 1996;106:463-469. [pmid: 8614222].
Caylan R, Titiz A, Falcioni M, et al. Myringoplasty in children: factors influencing surgical outcome. Otolaryngol Head Neck Surg. 1998;118:709-713. [pmid: 9591879].
Celakovsky P, Chrobok V. Causes of a positive pressure in the cavity of the middle ear in tympanometric examinations. Otorinolaryngologie a Foniatrie. 1997;46:107-110.
Celakovsky P, Chrobok V, Vokurka J. Contemporary views on treatment of chronic secretory otitis - Evaluation of questionnaire survey. Otorinolaryngol Foniatr. 1999;48:10-14.
Celen Z, Kanlykama M, Bayazit A Y, Mumbuc B S, Zincirkeser S, Ozbay E. Scintigraphic evaluation of the Eustachian tube functions. Rev Laryngol Otol Rhinol. 1999;120:123-125.
Chalat N I, Lounsbury E. A hearing phenomenon and secretory otitis. Laryngoscope. 1966;76:983-992. [pmid: 5940816].
Chalmers D Stewart A Silva P Mulvena A Otitis media with effusion in children-the Dunedin study In: Publications BS, ed Oxford: Macketh Press Macketh Press; 1989
Chamberlain JM, Grandner J, Rubinoff JL, Klein BL, Waisman Y, Huey M. Comparison of a tympanic thermometer to rectal and oral thermometers in a pediatric emergency department. Clin-Pediatr-Phila. 1991;30:24–29; discussion.
Chamberlain J M, Boenning D A, Waisman Y, Ochsenschlager D W, Klein B L. Single-dose ceftriaxone versus 10 days of cefaclor for otitis media. Clin-Pediatr-Phila. 1994;33:642-646. [pmid: 7859421].
Chambers R D, Rowan L E, Matthies M L, Novak M A. Auditory brain-stem responses in children with previous otitis media. Arch Otolaryngol Head Neck Surg. 1989;115:452-457. [pmid: 2923688].
Chan S C. Reconstructive middle-ear surgery for chronic otitis media. Ann Acad Med Singapore. 1980;9:367-373. [pmid: 7212619].
Chan J, Mak K L, Saw D. Sinus histiocytosis with massive lymphadenopathy, a report of 2 cases in Chinese. Pathology. 1985;17:609-612. [pmid: 3912713].
Chan K H, Cantekin E I, Karnavas W J, Bluestone C D. Autoinflation of eustachian tube in young children. Laryngoscope. 1987;97:668-674. [pmid: 3586805].
Chan K H, Mandel E M, Rockette H E, et al. A comparative study of amoxicillin-clavulanate and amoxicillin. Treatment of otitis media with effusion. Arch Otolaryngol Head Neck Surg. 1988;114:142-146. [pmid: 3276343].
Chan K H, Bluestone C D. Lack of efficacy of middle-ear inflation: treatment of otitis media with effusion in children. Otolaryngol-Head-Neck-Surg. 1989;100:317-323. [pmid: 2498820].
Chan K H, Swarts J D, Doyle W J, Wolf G L. Assessment of middle-ear status during experimental otitis media using magnetic resonance imaging. Arch Otolaryngol Head and Neck Surgery. 1991;117:91-95.
Chan K H, Bluestone C D, Tan L S, Reisinger K S, Blatter M M, Fall P A. Comparative study of sultamicillin and amoxicillin-clavulanate: treatment of acute otitis media. Pediatr Infect Dis J. 1993;12:24-28. [pmid: 8417421].
Chan K H, Swarts J D, Rudoy R, Dever G J, Mesubed Y. Otitis media in the Republic of Palau. A case-series study. Arch Otolaryngol Head Neck Surg. 1993;119:425-428. [pmid: 8457305].
Chan K H, Swarts J D, Tan L. Middle ear mucosal inflammation: an in vivo model. Laryngoscope. 1994;104:970-980. [pmid: 8052083].
Chan LS, Takata GS, Shekelle P, Morton SC, Mason W, Marcy SM. Evidence assessment of management of acute otitis media: II. Research gaps and priorities for future research. Pediatrics. (In Press).
Chandler J R. Intratympanic glomus tumors--diagnostic work-up and new surgical approach. Laryngoscope. 1967;77:562-574. [pmid: 4290329].
Chandler J R, Grobman L, Quencer R, Serafini A. Osteomyelitis of the base of the skull. Laryngoscope. 1986;96:245-251. [pmid: 3485233].
Chang S O, Jang Y J, Rhee C K. Effects of middle ear effusion on transient evoked otoacoustic emissions in children. Auris Nasus Larynx. 1998;25:243-247. [pmid: 9799989].
Chang P, Fagan P A, Atlas M D, Roche J. Imaging destructive lesions of the petrous apex. Laryngoscope. 1998;108:599-604. [pmid: 9546277].
Chao W Y, Wu C C. Hearing impairment in chronic otitis media with cholesteatoma. J Formos Med Assoc. 1994;93:866-869. [pmid: 7749340].
Chao W Y, Leung H W. Effects of irradiation on the rat middle ear mucosa. A scanning electron microscopic study. Eur Arch Otorhinolaryngol. 1995;252:244-248. [pmid: 7546681].
Chao W Y, Shen C L. Ultrastructure of the middle ear mucosa in patients with chronic otitus media with cholesteatoma. Eur Arch Otorhinolaryngol. 1996;253:56-61. [pmid: 8932432].
Chao W Y, Chang S J. Ultrastructure of eustachian tube mucosa in chronic otitis media with cholesteatoma. Am J Otolaryngol. 1996;17:161-166. [pmid: 8827274].
Chao Y H, Yun S H, Shin J O, Yoon J Y, Lee D M. Cochlear fistula in chronic otitis media with cholesteatoma. Am J Otol. 1996;17:15-18. [pmid: 8694120].
Chaput d e S aintonge D M, Levine D F, Savage I T, et al. Trial of three-day and ten-day courses of amoxycillin in otitis media. Br Med J Clin Res Ed. 1982;284:1078-1081.
Chaput d e S aintonge D M, Hattersley L A. Antibiotics for otitis media: can we help doctors agree?. Fam Pract. 1985;2:205-212. [pmid: 4085701].
Charachon R. Cholesteatoma, epidermization: choice between closed and obliteration technique. Clin Otolaryngol Allied Sci. 1978;3:363-367. [pmid: 743781].
Charachon R, Gratacap B. The surgical treatment of cholesteatoma in children. Clin Otolaryngol Allied Sci. 1985;10:177-184. [pmid: 4053417].
Charachon R, Gratacap B, Elbaze D. Anatomical and functional reconstruction of old radical mastoidectomy cavities by obliteration tympanoplasty. Clin Otolaryngol Allied Sci. 1989;14:121-126. [pmid: 2721011].
Charachon R, LeJeune J M, Bouchal H. Reconstruction of radical mastoidectomy by obliteration technique. Ear Nose Throat J. 1991;70:830-838. [pmid: 1819531].
Charles L, Segreti J. Choosing the right macrolide antibiotic. A guide to selection. Drugs. 1997;53:349-357. [pmid: 9074839].
Chayarpham S, Stuart J, Chongsuvivatwong V, Chinpairoj S, Lim A. A study of the prevalence of and risk factors for ear diseases and hearing loss in primary school children in Hat Yai, Thailand. J Med Assoc Thai. 1996;79:468-472. [pmid: 8855627].
Chen J M, Schloss M D, Manoukian J J, Shapiro R S. Congenital cholesteatoma of the middle ear in children. J Otolaryngol. 1989;18:44-48. [pmid: 2921786].
Chen A Y, Ohlms L A, Stewart M G, Kline M W. Otolaryngologic disease progression in children with human immunodeficiency virus infection. Arch Otolaryngol Head Neck Surg. 1996;122:1360-1363. [pmid: 8956750].
Chen B N, Lin H C, Shu M T, Chang K C. Influence of middle ear disease on distortion product otoacoustic emissions in children. J Taiwan Otolaryngol Head Neck Surg. 1999;34:195-199.
Cheney M L, Megerian C A, Brown M T, McKenna M J, Nadol J B. The use of the temporoparietal fascial flap in temporal bone reconstruction. Am J Otol. 1996;17:137-142. [pmid: 8694118].
Cherry J R. Current conservative treatment of childhood chronic secretory otitis media (a survey and discussion). J Laryngol Otol. 1986;100:1019-1026. [pmid: 3760682].
Chesnutt B, Stream R W, Love J T, McLarey D C. Otoadmittance measurements in cases of dual ossicular disorders. Arch Otolaryngol. 1975;101:109-113. [pmid: 1122193].
Chessare J B. Recurrent otitis media and parenting stress in mothers of two-year-old children [letter; comment]. J Dev Behav Pediatr. 1993;14:70. [pmid: 8432880].
Chibante A, Burdeksa A, Kissling M. Efficacy and tolerability of cefetamet pivoxil in toddlers with respiratory tract infections. DRUG INVEST. 1992;4:252-257.
Chibante A, Peixoto E, Lejeune R, Winter K, Kissling M. Clinical efficacy and safety of cefetamet pivoxil in toddlers. INT J ANTIMICROB AGENTS. 1994;4:203-210. [pmid: 18611612].
Chilton L A, Skipper B E. Antihistamines and alpha-adrenergic agents in treatment of otitis media. South-Med-J. 1979;72:953-955. [pmid: 382379].
Chinn K, Brown O E, Manning S C. Effects of inhalant anesthesia on the middle ear as measured by tympanometry. Arch Otolaryngol Head Neck Surg. 1993;119:283-287. [pmid: 8435166].
Chinn K, Brown O E, Manning S C, Crandell C C. Middle ear pressure variation: effect of nitrous oxide. Laryngoscope. 1997;107:357-363. [pmid: 9121313].
Chiossone E. Surgical management of major congenital malformations of the ear. Am J Otol. 1985;6:237-242. [pmid: 4003533].
Chisin R, Gapany-Gapanavicius B, Gafni M, Sohmer H. Auditory nerve and brainstem-evoked responses before and after middle ear corrective surgery. Arch Otorhinolaryngol. 1983;238:27-31. [pmid: 6683961].
Chobaut J C. [Ear discharge. Diagnostic orientation]. Revue du Praticien. 1994;44:677-678. [pmid: 8066408].
Chocas E C, Paap C M, Godley P J. Cefpodoxime proxetil: a new, broad-spectrum, oral cephalosporin. Ann Pharmacother. 1993;27:1369-1377. [pmid: 8286813].
Choi S S, Pafitis I A, Zalzal G H, Herer G R, Patel K M. Clinical applications of transiently evoked otoacoustic emissions in the pediatric population. Ann Otol Rhinol Laryngol. 1999;108:132-138. [pmid: 10030229].
Chole R A. Osteoclasts in chronic otitis media, cholesteatoma, and otosclerosis. Ann Otol Rhinol Laryngol. 1988;97:661-666. [pmid: 3202569].
Chole R A, Hubbell R N. Antimicrobial activity of silastic tympanostomy tubes impregnated with silver oxide. A double-blind randomized multicenter trial. Arch Otolaryngol Head Neck Surg. 1995;121:562-565. [pmid: 7727091].
Chomarat M, Dubreuil C. [Treatment of acute otitis media: comparative study of efficacy of cefatrizine and amoxicillin-clavulanic acid]. Pathol-Biol-Paris. 1991;39:555-557. [pmid: 1881694].
Chonmaitree T, Owen M J, Howie V M. Respiratory viruses interfere with bacteriologic response to antibiotic in children with acute otitis media. J Infect Dis. 1990;162:546-549. [pmid: 2373879].
Chonmaitree T, Owen M J, Patel J A, Hedgpeth D, Horlick D, Howie V M. Effect of viral respiratory tract infection on outcome of acute otitis media. J Pediatr. 1992;120:856-862. [pmid: 1534364].
Chonmaitree T, Patel J A, Lett-Brown M A, et al. Virus and bacteria enhance histamine production in middle ear fluids of children with acute otitis media. J Infect Dis. 1994;169:1265-1270. [pmid: 8195602].
Chonmaitree T, Patel J A, Sim T, et al. Role of leukotriene B4 and interleukin-8 in acute bacterial and viral otitis media. Ann Otol Rhinol Laryngol. 1996;105:968-974. [pmid: 8973284].
Choung PH. The auriculomastoid fasciocutaneous island flap: a new flap for orofacial reconstruction. Journal of Oral and Maxillofacial Surgery. 1996;54:559–567; discussion 568.
Chu Y M, Young Y H. Sudden deafness in children. Journal of the Otolaryngological Society of the Republic of China. 1997;32:641-646.
Chui R. Otitis media. Prim Care. 1982;9:401-412. [pmid: 6922570].
Chumakov FI, Deriugina OV. [A case of tuberculous meningitis erroneously interpreted as otogenous]. Vestn Otorinolaringol. 1996:52–53.
Chung M H, Griffith S R, Park K H, Lim D J, DeMaria T F. Cytological and histological changes in the middle ear after inoculation of influenza A virus. Acta Otolaryngol. 1993;113:81-87. [pmid: 8442427].
Chung M H, Enrique R, Lim D J, De M aria T F. Moraxella (Branhamella) catarrhalis-induced experimental otitis media in the chinchilla. Acta Otolaryngol. 1994;114:415-422. [pmid: 7976314].
Church M W. Chronic in utero alcohol exposure affects auditory function in rats and in humans. Alcohol. 1987;4:231-239. [pmid: 3620090].
Church M W, Gerkin K P. Hearing disorders in children with fetal alcohol syndrome: findings from case reports. Pediatrics. 1988;82:147-154. [pmid: 3399287].
Church M W, Eldis F, Blakley B W, Bawle E V. Hearing, language, speech, vestibular, and dentofacial disorders in fetal alcohol syndrome. Alcoholism: Clinical and Experimental Research. 1997;21:227-237.
Church J A. Immunologic evaluation of the child with recurrent otitis media. Ear Nose Throat J. 1997;76:31-34, 42. [pmid: 9018932].
Churchill I D, Hodson B W, Jones B W, Novak R E. Phonological systems of speech-disordered clients with positive/negative histories of otitis media. Lang Speech Hear Serv School. 1988;19:100-107.
Cisse M F, Sow A I, Adjovi D R, Samb A. [Bacteriological study of purulent otitis media in children in CHU in the tropical zone]. Arch Pediatr. 1995;2:29-33. [pmid: 7735421].
Ciuchi V. Seromucous otitis with loss of perception hearing. Oto Rino Laringologia. 1979;24:265-276. [pmid: 161033].
Civantos F, Ferguson L R, Hemmati M, Gruber B. Temporal meningiomas presenting as chronic otitis media. Am J Otol. 1993;14:403-406. [pmid: 8238280].
Claessen J Q, Appelman C L, Touw-Otten F W, de M elker R A, Hordijk G J. Persistence of middle ear dysfunction after recurrent acute otitis media. Clin-Otolaryngol. 1994;19:35-40. [pmid: 8174299].
Claridge O, Ford R P, Schluter P J, Wild C J, Macleod L. The length of the referral chain after failing preschool tympanometry. N Z Med J. 1995;108:479-481. [pmid: 8538975].
Clark P M, Shiell A, Cox G, Carruth J A. Otitis media with effusion and size at birth. Br J Audiol. 1998;32:13-18. [pmid: 9643303].
Clarke L R, Wiederhold M L, Gates G A. Quantitation of pneumatic otoscopy. Otolaryngol Head Neck Surg. 1987;96:119-124. [pmid: 3120084].
Clarke-Klein S M, Roush J, Roberts J E, Davis K, Medley L. FM amplification for enhancement of conversational discourse skills: case study. J Am Acad Audiol. 1995;6:230-234. [pmid: 7620200].
Clarkson R L, Eimas P D, Marean G C. Speech perception in children with histories of recurrent otitis media. J Acoust Soc Am. 1989;85:926-933. [pmid: 2926008].
Clements D A. Otitis media and hearing loss in a small aboriginal community. Med J Aust. 1968;1:665-667. [pmid: 5653322].
Clements D A, Langdon L, Bland C, Walter E. Influenza A vaccine decreases the incidence of otitis media in 6- to 30- month-old children in day care. Arch Pediatr Adolesc Med. 1995;149:1113-1117. [pmid: 7550814].
Clements D A, Langdon L, Bland C, Walter E. Influenza A vaccine decreases the incidence of otitis media in 6- to 30-month-old children in day care [see comments]. Arch Pediatr Adolesc Med. 1995;149:1113-1117. [pmid: 7550814].
Clemis J D, Shambaugh G E Jr, Derlacki E L. Withdrawal reactions in chronic food addiction as related to chronic secretory otitis media. Ann Otol Rhinol Laryngol. 1966;75:793-797. [pmid: 5917647].
Clemis J D. Identification of allergic factors in middle ear effusions. Ann Otol Rhinol Laryngol. 1976;85:234-237. [pmid: 773245].
Clopton B M, Silverman M S. Changes in latency and duration of neural responding following developmental auditory deprivation. Exp Brain Res. 1978;32:39-47. [pmid: 207547].
Close G R, Rushworth R L, Rob M I, Rubin G L. Variation in selected childhood surgical procedures: the case of tonsillectomy and management of middle ear disease. Journal of Paediatrics and Child Health. 1993;29:429-433. [pmid: 8286158].
Coates H L, McDonald T J. Symposium. ENT for nonspecialists. Serous otitis media. Postgrad Med. 1975;57:87-90. [pmid: 235756].
Coates H, Chai F, Oates J. The use of surface treated and silver oxide impregnated tympanostomy tubes in reducing post-operative otorrhoea. Australian Journal of Otolaryngology. 1998;3:16-19.
Coggins C R, Lovejoy H M, McGuirt W F, Sagartz J W, Hayes A W, Ayres P H. Relevant exposure to environmental tobacco smoke surrogate does not produce or modify secretory otitis media in the rat. Toxicol Pathol. 1997;25:395-397. [pmid: 9280123].
Cohen D, Tamir D. The prevalence of middle ear pathologies in Jerusalem school children. Am J Otol. 1989;10:456-459. [pmid: 2610232].
Cohen R, de la Rocque F, Bouhanna A, et al. [Randomized study of cefatrizine versus cefaclor in conjunctivitis otitis syndrome]. Pathol-Biol-Paris. 1990;38:517-520. [pmid: 2200994].
Cohen D. Secretory otitis media with malignant external otitis. Am J Otol. 1990;11:207-208. [pmid: 2343907].
Cohen R, La R F, Boucherat M, et al. Randomized open study of Pediazole (R) versus cefaclor in children with acute otitis media. ANN. PEDIATR. 1991;38:115-119.
Cohen R, de La Rocque F, Boucherat M, et al. [An open randomized trial, Pediazole versus cefaclor in the treatment of acute otitis media in children]. Ann-Pediatr-Paris. 1991;38:115-119. [pmid: 2029123].
Cohen R, et al. de la Rocque M. [Prevention of acute otitis media. Amoxicillin versus glycoproteins from Klebsiella pneumoniae. Study in children under 5 years of age]. Presse-Med. 1992;21:509-514. [pmid: 1533455].
Cohen S M, Keltner J L. Thrombosis of the lateral transverse sinus with papilledema. Arch Ophthalmol. 1993;111:274-275. [pmid: 8431168].
Cohen R, De LRF, Boucherat M, et al. Cefpodoxime proxetil vx cefixime for painful febrile acute otitis media in children. CEFPODOXIME-PROXETIL VERSUS CEFIXIME DANS LE TRAITEMENT DE L'OTITE MOYENNE AIGUE DOULOUREUSE ET FEBRILE DE L'ENFANT. MED. MAL. INFECT. 1994;24:844-851.
Cohen R, de la Rocque F, Boucherat M, Doit C, Bingen E, Geslin P. Treatment failure in otitis media: an analysis. J Chemother. 1994;6:17–22; discussion 23–24.
Cohen H A, Kauschansky A, Ashkenasi A, Bahir A, Frydman M, Horev Z. Swimming and grommets. J Fam Pract. 1994;38:30-32. [pmid: 8289048].
Cohen R. Clinical experience with cefpodoxime proxetil in acute otitis media. Pediatr Infect Dis J. 1995;14:S12-S18. [pmid: 7792125].
Cohen R, Bingen E, Varon E, et al. Change in nasopharyngeal carriage of Streptococcus pneumoniae resulting from antibiotic therapy for acute otitis media in children. Pediatr Infect Dis J. 1997;16:555-560. [pmid: 9194104].
Cohen R, De lRF, Boucherat M, Levy C, Langue J, Bourrillon A. Randomized trail comparing 5-day cefpodoxime proxetil and 8-day amoxicillin-clavulanate treatment of acute otitis media in children. /ETUDE RANDOMISEE CEFPODOXIME PROXETIL 5 JOURS VERSUS AMOXICILLINE-ACIDE CLAVULANIQUE 8 JOURS DANS LE TRAITEMENT DE L'OTITE MOYENNE AIGUE DE L'ENFANT. Medecine Et Maladies Infectieuses. 1997;27:596-602.
Cohen R. The antibiotic treatment of acute otitis media and sinusitis in children. Diagn Microbiol Infect Dis. 1997;27:35-39. [pmid: 9127104].
Cohen R, Levy C, Boucherat M, Langue J, de La Rocque F. A multicenter, randomized, double-blind trial of 5 versus 10 days of antibiotic therapy for acute otitis media in young children. J Pediatr. 1998;133:634-639. [pmid: 9821420].
Coker N J, Jenkins H A, Fisch U. Obliteration of the middle ear and mastoid cleft in subtotal petrosectomy: indications, technique, and results. Ann Otol Rhinol Laryngol. 1986;95:5-11. [pmid: 3947004].
Cole J M. Reconstructive middle ear surgery for children. Otolaryngol Clin North Am. 1970;3:319-337. [pmid: 5006504].
Cole J M. Conservative tympanomastoidectomy. Laryngoscope. 1974;84:783-792. [pmid: 4827587].
Cole R D, May J S. Aberrant internal carotid artery. South Med J. 1994;87:1277-1280. [pmid: 7973930].
Coles R R. Can present day audiology really help in diagnosis? An otologist's question. J Laryngol Otol. 1972;86:191-224. [pmid: 5014913].
Coles S J, Addlestone M B, Kamdar M K, Macklin J L. A comparative study of clarithromycin and amoxycillin suspensions in the treatment of pediatric patients with acute otitis media. Infection. 1993;21:272-278. [pmid: 8225637].
Colhoun E N, O'Neill G, Francis K R, Hayward C. A comparison between area and volume measurements of the mastoid air spaces in normal temporal bones. Clin Otolaryngol Allied Sci. 1988;13:59-63. [pmid: 3370855].
Collet J P, Burtin P, Gillet J, Bossard N, Ducruet T, Durr F. Risk of infectious diseases in children attending different types of day-care setting. Epicreche Research Group. Respiration. 1994;61:16-19. [pmid: 7800966].
Collet J P, Larson C P, Boivin J F, Suissa S, Pless I B. Parental smoking and risk of otitis media in pre-school children. Can J Public Health. 1995;86:269-273. [pmid: 7497415].
Colletti V. Tympanomety from 200 to 2000 Hz probe tone. Audiology. 1976;15:106-119. [pmid: 1252193].
Colletti V. Multifrequency tympanometry. Audiology. 1977;16:278-287. [pmid: 883908].
Colletti V, Fiorino F G, Sittoni V. Minisculptured ossicle grafts versus implants: long-term results. Am J Otol. 1987;8:553-559. [pmid: 3434620].
Collins M P, Church M K. The effect of an anti-allergic, nasal decongestant combination (‘Dimotapp’) and sodium cromoglycate nose drops on the histamine content of adenoids, middle ear fluid and nasopharyngeal secretions of children with secretory otitis media. Curr-Med-Res-Opin. 1983;8:392-394. [pmid: 6406156].
Colman G, Tanna A, Efstratiou A, Gaworzewska E T. The serotypes of Streptococcus pyogenes present in Britain during 1980-1990 and their association with disease. J Med Microbiol. 1993;39:165-178. [pmid: 8366514].
Colucci R D, Elliott M, Affrime M B, Zampaglione N. Ceftibuten in paediatrics [letter]. Clin Pharmacokinet. 1994;27:166-168. [pmid: 7955778].
Coman W B. Earache and glue ear. Aust Fam Physician. 1978;7:111-119. [pmid: 629722].
Combs J T. Observations on the calibration of acoustic reflectometry. Pediatr Infect Dis J. 1988;7:659-660. [pmid: 3174308].
Combs J T. Precision of acoustic reflectometry with recorder in acute otitis media. Pediatr Infect Dis J. 1988;7:329-330. [pmid: 3380583].
Combs J T. Single vs. double acoustic reflectometry tracings. Pediatr Infect Dis J. 1989;8:616-620. [pmid: 2797957].
Combs J T. Predictive value of the angle of acoustic reflectometry. Pediatr Infect Dis J. 1991;10:214-216. [pmid: 2041669].
Combs J T. Effect of tip size on acoustic reflectometry. Pediatr Infect Dis J. 1992;11:978-979. [pmid: 1454447].
Combs J T. The diagnosis of otitis media: new techniques. Pediatr Infect Dis J. 1994;13:1039-1046. [pmid: 7845737].
Combs J T, Waterman S A, Combs M K. Select picture audiometry in an office setting. Clin Pediatr. 1996;35:161-164.
Combs J T, Combs M K. Acoustic reflectometry: spectral analysis and the conductive hearing loss of otitis media. Pediatr Infect Dis J. 1996;15:683-686. [pmid: 8858672].
Comis S D, Osborne M P, Stephen J, et al. Cytotoxic effects on hair cells of guinea pig cochlea produced by pneumolysin, the thiol activated toxin of Streptococcus pneumoniae. Acta Otolaryngol. 1993;113:152-159. [pmid: 8475728].
Commins D J, Koay B, Milford C A, Renowden S. Otitic hydrocephalus. J Otolaryngol. 1997;26:210-212. [pmid: 9176808].
Conijn E A, Van der Drift J F, Brocaar M P, Van Zanten G A. Conductive hearing loss assessment in children with otitis media with effusion. A comparison of pure tone and BERA results. Clin Otolaryngol Allied Sci. 1989;14:115-120. [pmid: 2721010].
Conley J, Janecka I. Neurilemmoma of the facial nerve. Plast Reconstr Surg. 1973;52:55-60. [pmid: 4351600].
Connolly A A, Picozzi G L, Browning G G. Randomized trial of neomycin/dexamethasone spray vs drop preparation for the treatment of active chronic mucosal otitis media. Clin-Otolaryngol. 1997;22:529-531. [pmid: 9466064].
Cook R A, Teel R W Jr. Negative middle ear pressure and language development. Some observations. Clin Pediatr. 1979;18:296-297.
Cook J A, Krishnan S, Fagan P A. Hearing results following modified radical versus canal-up mastoidectomy. Ann Otol Rhinol Laryngol. 1996;105:379-383. [pmid: 8651632].
Cooke E T, Raghuvaran G. Clindamycin in conjunction with surgery of the chronic suppurative ear. Br-J-Clin-Pract. 1974;28:57-59. [pmid: 4617595].
Cooper J, Inman J S, Dawson A F. A comparison between co-trimoxazole and amoxycillin in the treatment of acute otitis media in general practice. Practitioner. 1976;217:804-809. [pmid: 11457].
Cooper J C Jr. Hearne EMd, Gates GA. Normal tympanometric shape. Ear Hear. 1982;3:241-245. [pmid: 6890487].
Cooter M S, Eisma R J, Burleson J A, Leonard G, Lafreniere D, Kreutzer D L. Transforming growth factor-beta expression in otitis media with effusion. Laryngoscope. 1998;108:1066-1070. [pmid: 9665258].
Coplan J, Gleason J R. Quantifying language development from birth to 3 years using the Early Language Milestone Scale. Pediatrics. 1990;86:963-971. [pmid: 2251032].
Corey J P, Adham R E, Abbass A H, Seligman I. The role of IgE-mediated hypersensitivity in otitis media with effusion. Am J Otolaryngol. 1994;15:138-144. [pmid: 8179105].
Corrigan N, Stewart M, Scott M, Fee F. Predictive value of preschool surveillance in detecting learning difficulties [see comments]. Arch Dis Child. 1996;74:517-521. [pmid: 8758128].
Cortes E, Pigrau C, Barbera J, Almirante B. Cellulitis and spondylitis due to Streptococcus pneumoniae [letter; comment]. Clin Infect Dis. 1995;21:696. [pmid: 8527577].
Corth S B, Harris R W. Incidence of middle ear disease in Indochinese refugee schoolchildren. Audiology. 1984;23:27-37. [pmid: 6704056].
Corwin M J, Weiner L B, Daniels D. Efficacy of oral antibiotics for the treatment of persistent otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1986;11:109-112. [pmid: 3488978].
Costa O A, Swenson R C, Ribeirio N O, Gattaz G. Secretory otitis media and its sequelae in children living in charitable institutions. Scand Audiol Suppl. 1986;26:95-96. [pmid: 3472337].
Costa O A, Balieiro R O. Secretory otitis media in Brazilian children. Scandinavian Audiology Supplementum. 1986;26:93-94. [pmid: 3472336].
Cotter C S, Avidano M A, Stringer S P, Schultz G S. Inhibition of proteases in Pseudomonas otitis media in chinchillas. Otolaryngol Head Neck Surg. 1996;115:342-351. [pmid: 8861889].
Cotton RT. Sequelae of tympanostomy tubes (I). Pediatr Infect Dis J. 1990;9.
Coulehan J L, Eberhard S, Kapner L, Taylor F, Rogers K, Garry P. Vitamin C and acute illness in Navajo school children. N Engl J Med. 1976;295:973-977. [pmid: 787788].
Counsell AM, Maw AR, Golding J, Harvey IM, Peters TJ. The effect of otitis media with effusion on speech, language, learning and behavior. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:334–337.
Couriel J M. Glue ear: prescribe, operate, or wait? [see comments]. Lancet. 1995;345:3-4. [pmid: 7799705].
Courteney-Harris R G, Ford G R, Ganiwalla T M, Mangat K S. Closure of tympanic membrane perforation after the removal of Goode-type tympanostomy tubes: the use of silastic sheeting. J Laryngol Otol. 1992;106:960-962. [pmid: 1479270].
Courtois J. Audiological rehabilitation of Greenlandic patients with hearing loss due to otitis media. Arctic Med Res. 1991;Suppl:639-641. [pmid: 1365248].
Coutte A, Brahe Pedersen C, Bartholdy N, Thommesen P. Histiocytosis X. Recurrent otitis media as a presenting symptom in children with special references to cholesteatoma. Clin Otolaryngol Allied Sci. 1984;9:111-114. [pmid: 6331919].
Cowan D L, Brown M J. Seromucinous otitis media and its sequelae. (A retrospective study of 242 children). J Laryngol Otol. 1974;88:1237-1247. [pmid: 4452807].
Coyas A J. Chronic otitis media and tympanoplasty. Int Surg. 1968;50:516-519. [pmid: 5698649].
Crabtree J A. Tympanoplastic techniques in congenital atresia. Arch Otolaryngol. 1968;88:63-70. [pmid: 5660031].
Craig H B, Stool S E. Otitis media in a school for deaf children: An 8-year study. Ann Otol Rhinol Laryngol. 1990;99:49-51.
Craig W A, Andes D. Pharmacokinetics and pharmacodynamics of antibiotics in otitis media. Pediatr Infect Dis J. 1996;15:255-259. [pmid: 8852915].
Crais ER, Roberts JE. Assessing communication skills. In: McLean M, Bailey Jr DB, and Wolery, editors. Assessing infants and preschoolers with special needs. Chapter 12. Englewood Cliffs, New Jersey: Prentice Hall; 1996.
Crampton P, Nelson K, Bandaranayake D. Evaluation of an otitis media with effusion screening pilot programme. N Z Med J. 1996;109:384-386. [pmid: 8890880].
Cranford J L, Thompson N, Hoyer E, Faires W. Brief tone discrimination by children with histories of early otitis media. J Am Acad Audiol. 1997;8:137-141. [pmid: 9101460].
Crellin R P, Wilson J A, Cowan D L. Mastoid surgery in childhood. Clin Otolaryngol Allied Sci. 1991;16:39-42. [pmid: 2032357].
Cremers W R, Smeets J H. Acquired atresia of the external auditory canal. Surgical treatment and results. Arch Otolaryngol Head Neck Surg. 1993;119:162-164. [pmid: 8427677].
Cremers W R. Myringochorda-vestibulopexy: a new method for total replacement of the ossicular chain. Am J Otol. 1994;15:445-447. [pmid: 8579159].
Cremonesi G, Tarantino V, Stura M, Ciampini M. Comparison of cefatrizine and erythromycin for pediatric ear, nose, and throat infections. Clin-Ther. 1987;9:263-266. [pmid: 3300988].
Croft C B, Shprintzen R J, Ruben R J. Hypernasal speech following adenotonsillectomy. Otolaryngology and Head and Neck Surgery. 1981;89:179-188.
Cron R Q, Webb K H. Necrobacillosis: an unusual cause of purulent otitis media and sepsis. Pediatr Emerg Care. 1995;11:379-380. [pmid: 8751176].
Crovetto dela Torre M A, Fiz Melsio L M, Baralla-Echaburu Arteche J, Lopez J I. [Tuberculous otitis media: a case report]. Acta Otorrinolaringol Esp. 1996;47:63-66. [pmid: 8645492].
Crowley D E, Davis H, Beagley H A. Survey of the clinical use of electrocochleography. Ann Otol Rhinol Laryngol. 1975;84:297-307. [pmid: 1169037].
Crowther J A, Simpson D. Medical treatment of chronic otitis media: steroid or antibiotic with steroid ear-drops?. Clin-Otolaryngol. 1991;16:142-144. [pmid: 2070529].
Cruz O L, Takeuti M, Caldas N e t o S, Miniti A. Clinical and surgical aspects of cholesteatomas in children. Ear Nose Throat J. 1990;69:530, 535-536. [pmid: 2397707].
Crysdale WS. Comparative study of various ventilating tubes. The Annals of Otology, Rhinology and Larynogology; 1976:268–270.
Crysdale W S. Otorhinolaryngologic problems in patients with craniofacial anomalies. Otolaryngol Clin North Am. 1981;14:145-155. [pmid: 7254835].
Culpepper L, Froom J, Bartelds A I, et al. Acute otitis media in adults: a report from the International Primary Care Network [see comments] [published erratum appears in J Am Board Fam Pract 1993 Nov-Dec;6(6):616]. J Am Board Fam Pract. 1993;6:333-339. [pmid: 8352035].
Culpepper L. Family medicine research: need for capacity-building. R I Med. 1993;76:303-308. [pmid: 8329780].
Culpepper L, Froom J. Otitis media with effusion in young children: Treatment in search of a problem?. J Am Board Fam Pract. 1995;8:305-316. [pmid: 7572296].
Cundell D, Masure H R, Tuomanen E I. The molecular basis of pneumococcal infection: a hypothesis. Clin Infect Dis. 1995;21:S204-S211. [pmid: 8749668].
Cunningham M J, Curtin H D, Jaffe R, Stool S E. Otologic manifestations of Langerhans' cell histiocytosis. Arch Otolaryngol Head Neck Surg. 1989;115:807-813. [pmid: 2786723].
Cunningham N. Pediatric management problems. Subacute otitis media with effusion. Pediatr Nurs. 1991;17:594-595. [pmid: 1754288].
Cunningham M J, Harley E H Jr. Preventing perioperative obstruction of tympanostomy tubes: a prospective trial of a simple method. Int J Pediatr Otorhinolaryngol. 1991;21:15-20. [pmid: 2037414].
Cunningham M J, Eavey R D, Krouse J H, Kiskaddon R M. Tympanostomy tubes: experience with removal [see comments]. Laryngoscope. 1993;103:659-662. [pmid: 8502099].
Cunningham M J. Acute otolaryngologic surgical conditions in children. Pediatr Ann. 1994;23:250-256. [pmid: 8065830].
Curi-Spada L, Poerio M, Sciuto S. Acoustic screening of the school population (5–8 years old) of Tivoli's area with a special attention to the diffusion of the secretory otitis media. Rivista Italiana di Otorinolaringologia Audiologia e Foniatria. 1982;2:448-450.
Curley J W A. Grommet insertion: Some basic questions answered. Clin Otolaryngol Allied Sci. 1986;11:1-4. [pmid: 3698323].
Curry M D, Andrews A W, Daniel H J. A community-based nursing approach to the prevention of otitis media. J Community Health Nurs. 1997;14:81-110. [pmid: 9170756].
Curtin J M. Surgery for deafness. Acta Otorhinolaryngol Belg. 1971;25:946-951. [pmid: 5145779].
Cutlip R C, Dennis E D. Retrospective study of diseases in a captive Lemming Colony. J Wildl Dis. 1993;29:620-622. [pmid: 8258869].
Czerwonka R, Zlomaniec J, Semczuk B. [The endoscopic assessment of the pharyngeal opening of the auditory tube in recurrent exudative otitis media in children]. Otolaryngol Pol. 1995;49:426-430. [pmid: 8714566].
D'Agostino A M, Brown M A. A case of pneumonia with extrapulmonary manifestations. Hospital Practice (Office Edition). 1996;31:34-35.
d'Cruz M J. Helping the deaf in Kenya. Scand Audiol Suppl. 1988;28:99-102. [pmid: 3187393].
da Cruz M J, Fagan P, Atlas M, McNeill C. Drill-induced hearing loss in the nonoperated ear. Otolaryngol Head Neck Surg. 1997;117:555-558. [pmid: 9374183].
Dagan R, Yagupsky P, Goldbart A, Wasas A, Klugman K. Increasing prevalence of penicillin-resistant pneumococcal infections in children in southern Israel: implications for future immunization policies. Pediatr Infect Dis J. 1994;13:782-786. [pmid: 7808846].
Dagan R, Shvartzman P, Liss Z. Variation in acceptance of common oral antibiotic suspensions [see comments]. Pediatr Infect Dis J. 1994;13:686-690. [pmid: 7970967].
Dagan R, Abramson O, Leibovitz E, et al. Impaired bacteriologic response to oral cephalosporins in acute otitis media caused by pneumococci with intermediate resistance to penicillin [see comments]. Pediatr Infect Dis J. 1996;15:980-985. [pmid: 8933545].
Dagan R, Abramson O, Leibovitz E, et al. Impaired bacteriologic response to oral cephalosporins in acute otitis media caused by pneumococci with intermediate resistance to penicillin. Pediatr Infect Dis J. 1996;15:980-985. [pmid: 8933545].
Dagan R, Abramson O, Leibovitz E, et al. Bacteriologic response to oral cephalosporins: are established susceptibility breakpoints appropriate in the case of acute otitis media?. J Infect Dis. 1997;176:1253-1259. [pmid: 9359726].
Dagan R, Leibovitz E, Greenberg D, Yagupsky P, Fliss D M, Leiberman A. Early eradication of pathogens from middle ear fluid during antibiotic treatment of acute otitis media is associated with improved clinical outcome. Pediatr Infect Dis J. 1998;17:776-782. [pmid: 9779760].
Dahm M C, Clark G M, Franz B K, Shepherd R K, Burton M J, Robins-Browne R. Cochlear implantation in children: labyrinthitis following pneumococcal otitis media in unimplanted and implanted cat cochleas. Acta Otolaryngol. 1994;114:620-625. [pmid: 7879619].
Dainiak LB. [Organ pathology in Wegener's granulomatosis]. Vestn Otorinolaringol. 1995:32–35.
Dalhuijsen J, Zwaard A M, Grol R P, Mokkink H M. [Performance of family practitioners according to the guideline otitis media acuta of the Dutch College of Family Practitioners]. Ned Tijdschr Geneeskd. 1993;137:2139-2144. [pmid: 8232661].
Dallari S, Zaccarelli S C, Sintini M, Gatti G, Balli R. Acute mastoiditis with complications: a report of two cases. Acta Otorhinolaryngol Belg. 1997;51:113-118. [pmid: 9241378].
Daly K, Giebink G S, Le C T, et al. Determining risk for chronic otitis media with effusion. Pediatr Infect Dis J. 1988;7:471-475. [pmid: 3405649].
Daly K, Giebink GS, Lindgren B, Anderson RS. Controlled Clinical Trial for Prevention of Chronic Otitis Media with Effusion. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:247–250.
Daly K, Giebink G S, Batalden P B, Anderson R S, Le C T, Lindgren B. Resolution of otitis media with effusion with the use of a stepped treatment regimen of trimethoprim-sulfamethoxazole and prednisone. Pediatr Infect Dis J. 1991;10:500-506. [pmid: 1876465].
Daly KA, Giebink GS, Margolis RH, et al. Chronic otitis media with effusion morbidity in a prospective cohort: risk determinants for short-term outcomes in children treated with tympanostomy. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:7–11.
Daly K A, Lindgren B, Giebink G S. Validity of parental report of a child's medical history in otitis media research [see comments]. Am J Epidemiol. 1994;139:1116-1121. [pmid: 8192144].
Daly K. Risk factors for otitis media sequelae and chronicity. Ann Otol Rhinol Laryngol Suppl. 1994;163:39-42. [pmid: 8179268].
Daly K A, Giebink G S, Lindgren B, et al. Randomized trial of the efficacy of trimethoprim-sulfamethoxazole and prednisone in preventing post-tympanostomy tube morbidity. Pediatr Infect Dis J. 1995;14:1068-1074. [pmid: 8745020].
Daly K A, Rich S S, Levine S, et al. The family study of otitis media: design and disease and risk factor profiles. Genet Epidemiol. 1996;13:451-468. [pmid: 8905392].
Daly KA, Meland M, Brown J, Lindgren B, Westover D, Giebink GS. Epidemiology of early otitis media. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:33–35.
Daly K A, Hunter L L, Levine S C, Lindgren B R, Giebink G S. Relationships between otitis media sequelae and age. Laryngoscope. 1998;108:1306-1310. [pmid: 9738746].
Daly KA, Hunter LL, Giebink GS. Chronic otitis media with effusion. Pediatr Rev. 1999;20:85–93; quiz 94.
Dana ST. The appropriateness of tympanostomy tubes for children [letter; comment]. JAMA. 1995;273:698; discussion 700–701.
Dang H S, Nhan T S, Le T, et al. Point prevalence of secretory otitis media in children in southern Vietnam. Ann Otol Rhinol Laryngol. 1998;107:406-410. [pmid: 9596219].
Daniel RR. Comparison of azithromycin and co-amoxiclav in the treatment of otitis media in children. J-Antimicrob-Chemother 1993:65–71.
Daniels D L, Czervionke L F, Yu S, et al. The effect of patient positioning on MR imaging of the internal auditory canal. Neuroradiology. 1988;30:395-398. [pmid: 3211315].
Daniilidis I, Tsalighopoulos M, Themelis C, Vartholomeos A. True giant-cell tumour of the mastoid. A case report. J Laryngol Otol. 1981;95:853-858. [pmid: 7264461].
Dankle SK. The appropriateness of tympanostomy tubes for children [letter; comment]. JAMA. 1995;273:698; discussion 700–701.
Dantsov AA, Kovaleva LM, Grigor'eva IF, Drozdova MV. [Results of collalysine treatment of children with adhesive otitis media]. Vestn Otorinolaringol. 1994:31–34.
Darelid J, Lofgren S, Malmvall B E. Erythromycin treatment is beneficial for longstanding Moraxella catarrhalis associated cough in children. Scand-J Infect Dis. 1993;25:323-329. [pmid: 8362228].
Darrow D H, Keithley E M. Reduction of endotoxin-induced inflammation of the middle ear by polymyxin B. Laryngoscope. 1996;106:1028-1033. [pmid: 8699895].
Das V K. Prevalence of otitis media with effusion in children with bilateral sensorineural hearing loss. Arch Dis Child. 1990;65:757-759. [pmid: 2386380].
Das C, Sanasam J C, Chukhu N, Bimol N. A study of the incidence and causation of deafness among the children in the tribal population of manipur and its prevention. Indian J Otolaryngol Head Neck Surg. 1999;51:11-15.
Dastidar P, Pertti R, Karhuketo T. Axial HRCT, two-dimensional and maximum intensity projection reconstructions in temporal bone lesions. Acta Oto-Laryngologica - Supplement. 1997;529:43-46.
Davernat H, Geslin P, Megraud F, et al. Effects of cefixime or co-amoxiclav treatment on nasopharyngeal carriage of Streptococcus pneumoniae and Haemophilus influenzae in children with acute otitis media. J-Antimicrob-Chemother. 1998;41:253-258. [pmid: 9533468].
Davidson J, Hyde M L, Alberti P W. Epidemiology of hearing impairment in childhood. Scand Audiol Suppl. 1988;30:13-20. [pmid: 3227256].
Davidson B J, Morris M S. The perforated tympanic membrane. Am Fam Physician. 1992;45:1777-1782. [pmid: 1558052].
Davidson M, Parkinson A J, Bulkow L R, Fitzgerald M A, Peters H V, Parks D J. The epidemiology of invasive pneumococcal disease in Alaska, 1986-1990--ethnic differences and opportunities for prevention [see comments]. J Infect Dis. 1994;170:368-376. [pmid: 8035023].
Davidson TM. The appropriateness of tympanostomy tubes for children [letter; comment]. JAMA. 1995;273:698; discussion 700–701.
Davies D G. Deafness. Trans Med Soc Lond. 1972;88:53-60. [pmid: 4665819].
Davies I H, Done S H. Necrotic dermatitis and otitis media associated with Pseudomonas aeruginosa in sheep following dipping. Vet Rec. 1993;132:460-461. [pmid: 8517007].
Davis H. Conservation of hearing. Transactions - American Academy of Ophthalmology and Otolaryngology. 1972;76:41-43. [pmid: 4260164].
Davis L E. Experimental viral infections of the temporal bone. I. Experimental otitis media due to vaccinia virus in hamsters. J Infect Dis. 1979;139:333-337. [pmid: 376758].
Davis J, Elfeinbein J, Schum R, Bentler R. Effects of mild and moderate hearing impairment on language, educational, and psychosocial behavior of children. J Sppech Hear Dis. 1986;51:53-62.
Davis A, Hind S. The impact of hearing impairment: A global health problem. Int J Pediatr Otorhinolaryngol. 1999;49:S51-S54. [pmid: 10577775].
Davison M J, Fields M J. Ventilation tubes, swimming and otorrhoea: a New Zealand perspective. N Z Med J. 1993;106:201-203. [pmid: 7688110].
Davison S P, Facer G W, McGough P F, McCaffrey T V, Reder P A. Use of magnetic resonance imaging and magnetic resonance angiography in diagnosis of sigmoid sinus thrombosis. Ear Nose Throat J. 1997;76:436-441. [pmid: 9248135].
Dawes P J, Bingham B J, Rhys R, Griffiths MV. Aspirating middle ear effusions when inserting ventilation tubes: does it influence post-operative otorrhoea, tube obstruction or the development of tympanosclerosis?. Clin-Otolaryngol. 1991;16:457-461. [pmid: 1742892].
Day JD, Kellogg JX, Tschabitscher M, Fukushima T. Surface and superficial surgical anatomy of the posterolateral cranial base: significance for surgical planning and approach. Neurosurgery. 1996;38:1079–1083; discussion 1083–1084.
de Amesti C, Garcia P, Abello P. [Permanent grommets: easy and quick detection]. Acta Otorrinolaringol Esp. 1994;45:139. [pmid: 8086210].
de Campora E, Camaioni A, Leonardi M, Fardella P, Fiaoni M. Comparative efficacy and safety of roxithromycin and clarithromycin in upper respiratory tract infections. Diagn-Microbiol-Infect-Dis. 1992;15:S119-S122.
De Campora E, Radici M, Camaioni A. Efficacy and tolerability of brodimoprim in otitis. J Chemother. 1993;5:529-531. [pmid: 8195851].
de Castro F J, Jaeger R W, Martin L, Temeck J W, Tournour B. Serous otitis media. A double-blind trial with sulfisoxazole. Mo-Med. 1982;79:629-630. [pmid: 6757712].
de Juan Martin F, Bouthelier Moreno M, Fernandez Liesa R, Lezcano Carrera M A. [Mycobacterium avium otomastoiditis]. An Esp Pediatr. 1996;45:649-650. [pmid: 9133236].
de la Fuente Aguado J, Moreno Sanjuan J A, Fernandez Villar A, Otero Varela I, Conde C. [Meningitis caused by Streptococcus salivarius (letter)]. An Med Interna. 1996;13:355. [pmid: 8962986].
De Lalla F. Cefixime in the treatment of upper respiratory tract infections and otitis media. Chemotherapy. 1998;44:19-23. [pmid: 9797419].
de Lange de Klerk E S, Blommers J, Kuik D J, Bezemer P D, Feenstra L. Effect of homoeopathic medicines on daily burden of symptoms in children with recurrent upper respiratory tract infections [see comments]. Br Med J. 1994;309:1329-1332. [pmid: 7866080].
de Melker R A. Diagnostic value of microtympanometry in primary care. Br Med J. 1992;304:96-98. [pmid: 1737151]. [pmcid: 1881018].
De Melker RA. Diagnostic value of microtympanometry and pneumatic otoscopy in primary care. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:58–60.
de Melker R A. Evaluation of the diagnostic value of pneumatic otoscopy in primary care using the results of tympanometry as a reference standard. Br J Gen Pract. 1993;43:22-24. [pmid: 8457360]. [pmcid: 1372203].
De Melker R A. Treating persistent glue ear in children [editorial] [see comments]. Br Med J. 1993;306:5-6. [pmid: 8435582]. [pmcid: 1676377].
De Schepper S, Schmelzer B. [Local treatment of otitis media and otitis externa: the role of quinolones]. Acta Otorhinolaryngol Belg. 1994;48:67-70. [pmid: 8172004].
De-Campora E, Radici M, Camaioni A. Efficacy and tolerability of brodimoprim in otitis. J Chemother. 1993;5:551-555. [pmid: 8195856].
Dean M, Martin F N. Auditory and tactile bone-conduction thresholds using three different oscillators. J Am Acad Audiol. 1997;8:227-232. [pmid: 9272744].
Debruyne F, Vanderschueren-Lodeweyckx M, Bastijns P. Hearing in congenital hypothyroidism. Audiology. 1983;22:404-409. [pmid: 6615344].
Debruyne F, Degroote M. One-year follow-up after tympanostomy tube insertion for recurrent acute otitis media. ORL J Otorhinolaryngol Relat Spec. 1993;55:226-229. [pmid: 8336923].
Debry C, el Jerrari A, Gentine A, Conraux C. [Thrombophlebitis of the lateral sinus. Apropos of a case]. Rev Laryngol Otol Rhinol. 1993;114:355-358.
Dees S C, Lefkowitz D d. Secretory otitis media in allergic children. Am J Dis Child. 1972;124:364-368. [pmid: 5056874].
Deguchi K, Yokota N, Tanaka S, et al. [A clinical bacteriological efficacy study on a fosfomycin otic solution]. Jpn-J-Antibiot. 1986;39:2344-2354. [pmid: 3099028].
Deguchi K, Yokota N, Koguchi M, et al. [Antibacterial activities of cefmenoxime against recent clinical isolates from patients of otitis media and otitis externa]. Jpn J Antibiot. 1993;46:850-859. [pmid: 8254887].
Deguchi K, Yokota N, Koguchi M, et al. [Antibacterial activities of fosfomycin against recent clinical isolates from patients of otitis media and otitis externa]. Jpn J Antibiot. 1995;48:293-298. [pmid: 7745818].
Deguine C. Longterm results in cholesteatoma surgery. Clin Otolaryngol Allied Sci. 1978;3:301-310. [pmid: 737865].
Deguine C, Pulec J L. Long-term ventilation myringostomy. Ear Nose Throat J. 1993;72:514. [pmid: 8404550].
Deguine C, Pulec J L. Viral otitis media. Ear Nose Throat J. 1993;72:490. [pmid: 8354160].
Deguine C, Pulec J L. Acute suppurative otitis media. Ear Nose Throat J. 1993;72:387. [pmid: 8344177].
Deguine C. Staging in cholesteatoma surgery. Ear Nose Throat J. 1993;72:197-200. [pmid: 8482262].
Deguine C, Pulec J L. Short incus with intact tympanic membrane. Ear Nose Throat J. 1994;73:141. [pmid: 8205971].
Deguine C. [Pathogenesis of cholesteatoma: contribution of otoscopic photography]. Rev Laryngol Otol Rhinol. 1995;116:61-63.
Deguine C, Pulec J L. Classification of chronic suppurative otitis media: type VI. Ear Nose Throat J. 1996;75:764. [pmid: 8991223].
DeGuine C, Pulec J L. Cholesterol granuloma. Ear Nose Throat J. 1996;75:190. [pmid: 8935638].
Deguine C, Pulec J L. Classification of chronic suppurative otitis media: type II. Ear Nose Throat J. 1996;75:454. [pmid: 8828267].
Deguine C, Pulec J L. Classification of chronic suppurative otitis media: type IV. Ear Nose Throat J. 1996;75:642. [pmid: 8942081].
Deguine C, Pulec J L. Attic cholesteatoma and polyp with a blue ear drum. Ear Nose Throat J. 1997;76:488. [pmid: 9282455].
Deguine C, Pulec J L. Attic cholesteatoma and tympanosclerosis. Ear Nose Throat J. 1997;76:364. [pmid: 9210800].
Deguine C, Pulec J L. Dry central perforation with squamous epithelium in the tympanum. Ear Nose Throat J. 1997;76:192. [pmid: 9127516].
Deka R C. Middle ear effusion: its management [editorial]. Indian Pediatr. 1994;31:631-633. [pmid: 7896384].
Deka R C. Acute otitis media. Indian Pediatr. 1996;33:832-836. [pmid: 9057381].
Del Beccaro MA. Cefpodoxime proxetil [published erratum appears in Pediatr Ann 1993 Aug;22(8):following 457][see comments]. Pediatr Ann. 1993;22:187–192, 195–196.
del Castillo F, Barrio Gomez M I, Garcia A. [Bacteriologic study of 80 cases of acute otitis media in children]. Enferm Infecc Microbiol Clin. 1994;12:82-85. [pmid: 8011714].
Del Castillo F, Corretger J M, Medina J, Rosell J, Cruz M. Acute otitis media in childhood: a study of 20,532 cases. Infection. 1995;23:S70-S73. [pmid: 8537135].
del Castillo F, Garcia-Perea A, Baquero-Artigao F. Bacteriology of acute otitis media in Spain: a prospective study based on tympanocentesis. Pediatr Infect Dis J. 1996;15:541-543. [pmid: 8783354].
del Castillo Martin F, Sanchez Purificacion M T, Gonzalez Ipina M, Ortigado Matamala A. [Acute mastoiditis in childhood. A study of 15 cases]. An Esp Pediatr. 1996;44:329-331. [pmid: 8849081].
del Castillo Martin F. [Treatment of acute otitis media in children. Some questions]. Enferm Infecc Microbiol Clin. 1997;15:212-217. [pmid: 9312281].
Del Mar C, Glasziou P, Hayem M. Are antibiotics indicated as initial treatment for children with acute otitis media? A meta-analysis [see comments]. Br Med J. 1997;314:1526-1529. [pmid: 9183201].
Delany M E, Whittle L S. A new artificial ear and mastoid. Journal of Scientific Instruments. 1966;43:519-520. [pmid: 5945258].
Delbrouck C, Mansbach A L, Blondiau P. Otogenic thrombosis of the lateral sinus: report of a case in a child. Acta Otorhinolaryngol Belg. 1996;50:221-226. [pmid: 8888906].
Dellamonica P, Choutet P, Lejeune J M, et al. Efficacy and safety of cefotiam hexetil in the treatment of chronic otitis media. A comparative double blind randomized study versus cefuroxime axetil. Medecine Et Maladies Infectieuses. 1995;25:733-739.
Dellamonica P, Choutet P, Lejeune J M, et al. Efficacy and safety of cefotiam hexetil in the treatment of acute otitis media. A comparative double blind randomized study versus cefuroxime axetil. Medecine Et Maladies Infectieuses. 1995;25:599-604.
DeMarco S, Givens G D. Speech sound discrimination pre- and posttympanostomy: a clinical case report. Ear Hear. 1989;10:64-67. [pmid: 2721831].
DeMaria T F, Prior R B, Briggs B R, Lim D J, Birck H G. Endotoxin in middle-ear effusions from patients with chronic otitis media with effusion. J Clin Microbiol. 1984;20:15-17. [pmcid: 271236]. [pmid: 6611350].
DeMaria T F, McGhee R B Jr, Lim D J. Rheumatoid factor in otitis media with effusion. Arch Otolaryngol. 1984;110:279-280. [pmid: 6538783].
Demaria T F, Billy J M, Danahey D G. Growth factors during endotoxin-induced otitis media. Acta Otolaryngol. 1996;116:854-856. [pmid: 8973721].
DeMaria T F, Murwin D M, Leake E R. Immunization with outer membrane protein P6 from nontypeable Haemophilus influenzae induces bactericidal antibody and affords protection in the chinchilla model of otitis media. Infect Immun. 1996;64:5187-5192. [pmcid: 174506]. [pmid: 8945564].
DeMaria T F, Murwin D M. Tumor necrosis factor during experimental lipopolysaccharide-induced otitis media. Laryngoscope. 1997;107:369-372. [pmid: 9121315].
DeMieri P, Lehner W, Kiser W R. Thermometry for diagnosing acute otitis media [letter; comment] [see comments]. Am J Emerg Med. 1995;13:491-492. [pmid: 7605548].
Dempsey J J, Levitt H. Bone vibrator placement and the cancellation technique. Ear Hear. 1990;11:271-281. [pmid: 2210101].
Dempster J H, Browning G G. Eustachian tube function following adenoidectomy: an evaluation by sniffing. Clin-Otolaryngol. 1989;14:411-414. [pmid: 2582636].
Dempster J H, MacKenzie K. Tympanometry in the detection of hearing impairments associated with otitis media with effusion. Clin Otolaryngol Allied Sci. 1991;16:157-159. [pmid: 2070532].
Dempster J H, Browning G G, Gatehouse S G. A randomized study of the surgical management of children with persistent otitis media with effusion associated with a hearing impairment. J Laryngol Otol. 1993;107:284-289. [pmid: 8320510].
Denoyelle F, Roger G, Ducroz V, Escudier E, Fauroux B, Garabedian E N. Results of tympanoplasty in children with primary ciliary dyskinesia. Arch Otolaryngol Head Neck Surg. 1998;124:177-179. [pmid: 9485109].
Derbeneva ML, Bolotov DA. [The EEG characteristics and EEG toposelective mapping in patients with chronic suppurative otitis media before and after a sanitizing operation on the ear]. Vestn Otorinolaringol. 1996:20–22.
Derbeneva ML. [Characteristics of destructive changes in the middle ear of patients with chronic otitis media, purulent complicated by local pachymeningitis]. Vestn Otorinolaringol. 1997:13–16.
Deriugina OV, Chumakov FI. [Tuberculous meningoencephalitis in a child with bilateral suppurative otitis media]. Vestn Otorinolaringol. 1996:44–45.
Derlacki E L, Clemis J D. Congenital cholesteatoma of the middle ear and mastoid. Transactions - American Otological Society. 1965;53:208-231.
Derlacki E L, Harrison W H, Clemis J D. Congenital cholesteatoma of the middle ear and mastoid: a second report presenting seven additional cases. Laryngoscope. 1968;78:1050-1078. [pmid: 5662764].
Derlacki E L. Congenital cholesteatoma of the middle ear and mastoid. A third report. Arch Otolaryngol. 1973;97:177-182. [pmid: 4686155].
Dermody P, Curotta J, Mackie K. Pass/fail criteria in screening for otitis media in children with learning disorders. Int J Pediatr Otorhinolaryngol. 1983;6:151-162. [pmid: 6662620].
DeRowe A, Bernheim J, Ophir D. Eosinophilic granuloma presenting as chronic otitis media: pitfalls in the diagnosis of aural polyps in children. J Otolaryngol. 1995;24:258-260. [pmid: 8551541].
DerSimonian R, Laird N. Meta-analysis in clinical trial. Control Clin Trials. 1986;7:177-188. [pmid: 3802833].
Desa D J. Mucosal metaplasia and chronic inflammation in the middle ear of infants receiving intensive care in the neonatal period. Arch Dis Child. 1983;58:24-28. [pmid: 6830271].
Desaulty A, Lansiaux V, Machiels S, Gael J F. [Failures after tympanoplasty]. Rev Laryngol Otol Rhinol. 1996;117:357-361.
Desjardins R, Guerguerian A J, Dube J, Deschamps N, Lavertu P. Meningitis and congenital fistula of the internal ear. J Otolaryngol. 1982;11:97-100. [pmid: 7077735].
Desmond J W. Methoxyflurane nephrotoxicity. Canadian Anaesthetists Society Journal. 1974;21:294-307. [pmid: 4838327].
Dettelbach M A, Hirsch B E, Weissman J L. Pseudomonas cepacia of the temporal bone: malignant external otitis in a patient with cystic fibrosis. Otolaryngol Head Neck Surg. 1994;111:528-532. [pmid: 7524007].
Deutsch H J. Serous otitis media. Pa Med. 1967;70:53-55. [pmid: 6077690].
Devars F, Traissac L. [Seromucous otitis. Treatment and long-term development]. Rev Laryngol Otol Rhinol. 1993;114:221-224.
Devgan B K, Leach W. Assessment of adenoidal hyperplasia. South Med J. 1979;72:588-590. [pmid: 571621].
Devriendt K, Fryns J P. The Kabuki make-up (Niikawa-Kuroki) syndrome and isolated transient hyperphosphatasemia [letter]. Clin Genet. 1994;45:330-331. [pmid: 7923866].
Dew L A, Shelton C. Iatrogenic facial nerve injury: prevalence and predisposing factors. Ear Nose Throat J. 1996;75:724-729. [pmid: 8972997].
Dewey K G, Heinig M J, Nommsen-Rivers L A. Differences in morbidity between breast-fed and formula-fed infants. J Pediatr. 1995;126:696-702. [pmid: 7751991].
Dhillon R S. The middle ear in cleft palate children pre and post palatal closure. J-R-Soc-Med. 1988;81:710-713. [pmid: 3065499]. [pmcid: 1291883].
Dhindsa M K, Naidu J, Singh S M, Jain S K. Chronic suppurative otitis media caused by Paecilomyces variotii. J Med Vet Mycol. 1995;33:59-61. [pmid: 7650580].
Dhooge I, Vinck BM, De Vel E, van Cauwenberge P. Click evoked otocoustic emissions: a technique for evaluating ventilation of the middle ear after insertion of tympanostomy tubes. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:156–157.
Di Bartolomeo J R. A “string of pearls”. Ear Nose Throat J. 1995;74:450. [pmid: 7671830].
Dickins J R. Comparative study of otologic surgery in outpatient and hospital settings. Laryngoscope. 1986;96:774-785. [pmid: 3724330].
Diefendorf A O, Ferrell C J, McCallen P. Diagnostic implications of tympanometry in the presence of patent pressure-equalization tubes. Am J Otol. 1986;7:44-46. [pmid: 3946580].
Dieroff H G, Schuhmann G. High frequency hearing following otitis media with effusion in childhood. Scand Audiol Suppl. 1986;26:83-84. [pmid: 3472333].
Dieroff H G. Late-onset auditory inactivity (deprivation) in persons with bilateral essentially symmetric and conductive hearing impairment. J Am Acad Audiol. 1993;4:347-350. [pmid: 8219302].
DiFranza J R, Lew R A. Morbidity and mortality in children associated with the use of tobacco products by other people. Pediatrics. 1996;97:560-568. [pmid: 8632946].
Dimopoulos P A, Muren C, Smedby O, Wadin K. Anatomical variations of the tympanic and mastoid portions of the facial nerve canal. A radioanatomical investigation. Acta Radiologica - Supplementum. 1996;403:49-59. [pmid: 8669312].
Dingle A F, Flood L M, Kumar B U, Hampal S. The mini-grommet and tympanosclerosis: results at two years. J Laryngol Otol. 1993;107:108-110. [pmid: 8496640].
Dingle A F, Flood L M, Kumar B U, Newcombe R C. Tympanosclerosis and mini grommets: the relevance of grommet design. J Laryngol Otol. 1995;109:922-925. [pmid: 7499941].
Dingle A F, Raza S A, Phillipps J J. Otitis media with effusion: a disability or not?. Clin Otolaryngol Allied Sci. 1997;22:463-464. [pmid: 9372260].
Dingman J R, Rayner M G, Mishra S, et al. Correlation between presence of viable bacteria and presence of endotoxin in middle-ear effusions. J Clin Microbiol. 1998;36:3417-3419. [pmcid: 105347]. [pmid: 9774611].
Dirks D D. American National Standard specification for an artificial head-bone. ASHA. 1974;16:71-73. [pmid: 4817517].
Dirks D D, Kamm C, Gilman S. Bone conduction thresholds for normal listeners in force and acceleration units. J Speech Hear Res. 1976;19:181-186. [pmid: 1271796].
Disarno N J, Barringer C. Otitis media and academic achievement in Eskimo high school students. Folia Phoniat. 1987;39:250-255. [pmid: 3679033].
Diven W F, Evans R W, Alper C, Burckart G J, Jaffe R, Doyle W J. Treatment of experimental acute otitis media with ibuprofen and ampicillin. Int J Pediatr Otorhinolaryngol. 1995;33:127-139. [pmid: 7499045].
Diven W F, Evans R W, Swarts J D, Burckart G J, Doyle W J. Effect of ibuprofen treatment during experimental acute otitis media. Auris Nasus Larynx. 1995;22:73-79. [pmid: 7487676].
Djeric D. [Pathological changes of the pyramidal eminence in chronic suppurative otitis media]. Rev Laryngol Otol Rhinol. 1993;114:17-20.
Djeric D R, Schachern P A, Paparella M M, Jaramillo M, Haruna S, Bassioni M. Otitis media (silent): a potential cause of childhood meningitis. Laryngoscope. 1994;104:1453-1460. [pmid: 7990633].
Djeric D R, Ramic Z D, Mostarica M B, Stojkovic M B, Stepanovic S R, Lukic M L. Altered immunoregulation in otitis media with effusion in children: presence of serum immuno-inhibitory factors. Clin Otolaryngol. 1994;19:234-236. [pmid: 7923846].
Djupesland G, Nicklasson B, Helland S, Hemsen E. Hearing threshold level and middle ear pressure in children with phonetic/phonemic disability. Scand Audiol. 1981;Suppl. 17:73–79.
Dobie R A, Berlin C I. Influence of otitis media on hearing and development. Ann Otol Rhinol Laryngol Suppl. 1979;88:48-53. [pmid: 115362].
Dobo M, Czeizel A E. Long-term somatic and mental development of children after periconceptional multivitamin supplementation. Eur J Pediatr. 1998;157:719-723. [pmid: 9776529].
Dobrotin VE. [Computerized tomography assisted determination of the scope of surgical intervention in intracranial involvement in diseases of the middle ear and paranasal sinuses]. Vestn Otorinolaringol. 1996:23–26.
Dodson E E, Hashisaki G T, Hobgood T C, Lambert P R. Intact canal wall mastoidectomy with tympanoplasty for cholesteatoma in children. Laryngoscope. 1998;108:977-983. [pmid: 9665242].
Dohar J E, Kenna M A, Wadowsky R M. In vitro susceptibility of aural isolates of Pseudomonas aeruginosa to commonly used ototopical antibiotics. Am J Otol. 1996;17:207-9. [pmid: 8723948].
Doherty B. An open comparative study of azithromycin versus cefaclor in the treatment of patients with upper respiratory tract infections. J Antimicrob Chemother. 1996;37:71-81.
Dominguez Rovira S, Mainou Cid C, Claros Blanch A, Latorre Otin C, Camarasa Piquer F, Corretger Rauet J M. [Clinical and microbiological study of otitis media in infants]. An Esp Pediatr. 1996;44:341-344. [pmid: 8849084].
Dommerby H, Tos M. Sensorineural hearing loss in chronic adhesive otitis. Arch Otolaryngol Head Neck Surg. 1986;112:628-634. [pmid: 3964449].
Donahue M L. Early phonological and lexical development and otitis media: a diary study. Journal of Child Language. 1993;20:489-501. [pmid: 8300772].
Donaldson J A. Surgical management of otitis media (recurrent and nonsuppurative). J Allergy Clin Immunol. 1020;81:1020-1024. [pmid: 3286727].
Donaldson J D, Martin G F, Maltby C C, Seywerd E B. The efficacy of pulse-dosed antibiotic therapy in the management of persistent otitis media with effusion. J-Otolaryngol. 1990;19:175-178. [pmid: 2192073].
Donaldson I, Snow D G. A five year follow up of incus transposition in relation to the first stage tympanoplasty technique. J Laryngol Otol. 1992;106:607-609. [pmid: 1527457].
Donnelly M J, McShane D P, Burns H. Monostotic fibrous dysplasia of the temporal bone with associated lymphadenopathy. Ear Nose Throat J. 1994;73:328-330. [pmid: 8045238].
Donnelly M J, Quraishi M S, McShane D P. Indications for paediatric tonsillectomy GP versus Consultant perspective. J Laryngol Otol. 1994;108:131-134. [pmid: 8163913].
Donnelly M J, Pyman B C, Clark G M. Chronic middle ear disease and cochlear implantation. Ann Otol Rhinol Laryngol Suppl. 1995;166:406-408. [pmid: 7668725].
Dorfman D H, Vinci R J. An infant with transient intracranial hypertension associated with a febrile illness. Pediatr Emerg Care. 1993;9:92-94. [pmid: 8483789].
Dorittke C, Vandamme P, Hinz K H, Schemken-Birk E M, Wirsing von Konig C H. Isolation of a Bordetella avium-like organism from a human specimen. Eur J Clin Microbiol Infect Dis. 1995;14:451-454. [pmid: 7556237].
Dornhoffer J L. Hearing results with the Dornhoffer ossicular replacement prostheses [see comments]. Laryngoscope. 1998;108:531-536. [pmid: 9546265].
Dornhoffer J L. Surgical modification of the difficult mastoid cavity. Otolaryngol Head Neck Surg. 1999;120:361-367. [pmid: 10064639].
Douek E, Reid J. The diagnostic value of tinnitus pitch. J Laryngol Otol. 1968;82:1039-1042. [pmid: 5686419].
Douek E. ‘Glue-ears’. Dev Med Child Neurol. 1972;14:81-83. [pmid: 4401912].
Douglas RMB, Miles H. Vaccination against streptococcus pneumoniae in childhood: Lack of demonstrable benefit in young Australian children. J Infect Dis. 1984;149.
Douglas R M, Miles H B. Vaccination against streptococcus pneumoniae in childhood: Lack of demonstrable benefit in young Australian children. J INFECT DIS. 1984;149:861-869. [pmid: 6376653].
Douglas R M, Hansman D, Miles H B, Paton J C. Pneumococcal carriage and type-specific antibody. Failure of a 14-valent vaccine to reduce carriage in healthy children. Am-J-Dis-Child. 1986;140:1183-1185. [pmid: 3532763].
Douniadakis D E, Nikolopoulos T P, Tsakanikos M D, Vassiliadis S V, Apostolopoulos N J. Evaluation of acoustic reflectometry in detecting otitis media in children. Br J Audiol. 1993;27:409-414. [pmid: 8054898].
Dowell S F, Schwartz B. Resistant pneumococci: protecting patients through judicious use of antibiotics [see comments]. Am Fam Physician. 1997;55:1647-1654, 16571658. [pmid: 9105195].
Downs M P. The expanding imperatives of early identification. In: Bess FH, ed. Childhood deafness: causation, assessment, and management. New York, Grune and Stratton. 1977;270:95-106.
Downs M P. Implanting electrodes?. ASHA. 1981;23:567-568. [pmid: 6897832].
Downs M P, Jafke B, Wood R P. Comprehensive treatment of children with recurrent serous otitis media. Otolaryngology and Head and Neck Surgery. 1981;89:658-665.
Downs M, Blager F B. The otitis prone child. J Dev Behav Pediatr. 1982;3:106-113. [pmid: 7107900].
Downs M P. Effects of mild hearing loss on auditory processing. Otolaryngol Clin North Am. 1985;18:337-344. [pmid: 4040234].
Downs MP, Walker DD, Northern JL, Gugenheim S. Identification of Children with Language Delays Due to Recurrent Otitis Media. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:382–384.
Doyle P J, Schleuning A J, Echevarria J. Tympanoplasty: should grafts be placed medial or lateral to the tympanic membrane. Laryngoscope. 1972;82:1425-1430. [pmid: 5053982].
Doyle P J, Morwood D. Middle ear disease in native Indian children in British Columbia--incidence of disease and an evaluation of screening methods. J Otolaryngol. 1976;5:103-115. [pmid: 933234].
Doyle K J, Brackmann D E, House J R, 3rd. Pathogenesis of otitic hydrocephalus: clinical evidence in support of Symonds' (1937) theory. Otolaryngol Head Neck Surg. 1994;111:323-327. [pmid: 8084643].
Doyle K J, Luxford W M. Congenital aural cholesteatoma: results of surgery in 60 cases. Laryngoscope. 1995;105:263-267. [pmid: 7877414].
Doyle K J, Burggraaff B, Fujikawa S, Kim J, MacArthur C J. Neonatal hearing screening with otoscopy, auditory brain stem response, and otoacoustic emissions. Otolaryngol Head Neck Surg. 1997;116:597-603. [pmid: 9215369].
Doyle W J, Skoner D P, Alper C M, Allen G, Moody S A, Seroky J T. Effect of rimantadine treatment on clinical manifestations and otologic complications in adults experimentally infected with influenza A (HINI) virus. J Infect Dis. 1998;117:1260-1265.
Drake-Lee A B, Casey W F, Ogg T W. Anaesthesia for myringotomy. The effect of nitrous oxide and intermittent positive pressure ventilation in children with secretory otitis media. Anaesthesia. 1983;38:314-318. [pmid: 6342458].
Drake-Lee A B, Casey W F. Anaesthesia and tympanometry. Int J Pediatr Otorhinolaryngol. 1983;6:171-178. [pmid: 6363321].
Drake-Lee A B, Price J M, Milford C M, Bickerton R C. Nasal mast cells: a preliminary report on their ultrastructure. Journal of Laryngology and Otology - Supplement. 1987;13:1-17.
Drake-Lee A, Price J, Varley R. Mast cell ultrastructure in the adenoids of children with and without secretory otitis media. J Laryngol Otol. 1994;108:1058-1063. [pmid: 7861081].
Drezner D A. Refractory otitis media [letter; comment]. Ear Nose Throat J. 1994;73:340-341. [pmid: 8045242].
Dubin A D. Rational approach to the diagnosis and treatment of secretory otitis media. J Am Osteopath Assoc. 1968;68:391-399. [pmid: 5189413].
Dubois B, Garabedian N, Sounthavong J P, Tournier G. Efficacity of alpha-amylase syrup in glue-ear with mucus spinability test. Therapie. 1987;42:545-547. [pmid: 3502042].
Dubois B, Garabedian N, Sounthavong J P, Tournier G. [Effect of alpha-amylase in serous otitis in children with analysis of mucus spinability in glue-ear]. Therapie. 1987;42:545-547. [pmid: 3502042].
Dubreuil C. [Acute otitis. Etiology, diagnosis, treatment]. Revue du Praticien. 1993;43:2421-2425. [pmid: 8128166].
Duchin J S, Breiman R F, Diamond A, et al. High prevalence of multidrug-resistant Streptococcus pneumoniae among children in a rural Kentucky community. Pediatr Infect Dis J. 1995;14:745-750. [pmid: 8559622].
Duckert L G, Muller J, Makielski K H, Helms J. Composite autograft “shield” reconstruction of remnant tympanic membranes. Am J Otol. 1995;16:21-26. [pmid: 8579173].
Ducroz V, Le Pajolec C, Harboun E, Bobin S. [Acute mastoiditis due to anaerobic bacteria. Review of the literature apropos of a case]. Ann Otolaryngol Chir Cervicofac. 1993;110:55-59. [pmid: 8317866].
Ducroz V, Garabedian E N. Treatment of otitis media with effusion. Medecine et Maladies Infectieuses. 1996;26:53-58.
Duffy L C, Faden H, Wasielewski R, Wolf J, Krystofik D. Exclusive breastfeeding protects against bacterial colonization and day care exposure to otitis media. Pediatrics. 1997;100:E7. [pmid: 9310540].
Dufour R. The search for the etiology of otitis media: results obtained with an application of the system theory. Arctic Med Res. 1991;Suppl:626-629. [pmid: 1365244].
Dugdale A E, Lesina J, Lovell S, Prestwood U, Lewis A N. Influence of nutrition and social conditions on school performance of aboriginal children. Med J Aust. 1975;2:1-6. [pmid: 1177785].
Dumich P S, Harner S G. Cochlear function in chronic otitis media. Laryngoscope. 1983;93:583-586. [pmid: 6843249].
Duncan R B. Malleus handle probe: a middle ear diagnostic procedure. Ann Otol Rhinol Laryngol. 1982;91:281-284. [pmid: 7092049].
Duncan B, Ey J, Holberg C J, Wright A L, Martinez F D, Taussig L M. Exclusive breast-feeding for at least 4 months protects against otitis media [see comments]. Pediatrics. 1993;91:867-872. [pmid: 8474804].
Dupont H, Timsit J F, Souweine B, Gachot B, Wolff M, Regnier B. Torsades de pointe probably related to sparfloxacin [letter]. Eur J Clin Microbiol Infect Dis. 1996;15:350-351. [pmid: 8781892].
Dupuis G, Ebbo D, Evennou A, Pappo M. Efficacy and safety of cefuroxime-axetil for the treatment of upper respiratory tract infections. Results of a randomized trial versus cefadroxil. Rev Laryngol Otol Rhinol. 1989;110:123-126.
Durmowicz A G, Noordeweir E, Nicholas R, Reeves J T. Inflammatory processes may predispose children to high-altitude pulmonary edema. J Pediatr. 1997;130:838-840. [pmid: 9152300].
Duroux S, Devars F, Patuano E, Bondonny J M, Traissac L. [Cleft palate and inflammatory diseases of the middle ear]. Rev Laryngol Otol Rhinol. 1993;114:165-169.
Durr D G, Shapiro R S. Otologic manifestations in congenital velopharyngeal insufficiency. Am J Dis Child. 1989;143:75-77. [pmid: 2910049].
Dusdieker L B, Smith G, Booth B M, Woodhead J C, Milavetz G. The long-term outcome of nonsuppurative otitis media with effusion. Clin-Pediatr-Phila. 1985;24:181-186. [pmid: 3884218].
Dutoit Marco M L, Cherpillod J. Audiometric problems after recurrent serous otitis in children. Ther Umsch. 1023;39:1023-1026. [pmid: 6891840].
Duvall A J d. Fluid ear. Postgrad Med. 1972;52:79-83. [pmid: 4403045].
Duvall A J d, Lowell S H. The “chronic” ear: how to manage mild to severe otitis. Postgrad Med. 1979;66:94-98,101. [pmid: 572048].
Duvillard C, Romanet P. [Acute otitis. Etiology, diagnosis, treatment]. Revue du Praticien. 1997;47:335-340. [pmid: 9122609].
Dworkin P H. The preschool child: developmental themes and clinical issues. Curr Probl Pediatr. 1988;18:73-134. [pmid: 3365985].
Dyson A T, Holmes A E, Duffitt D V. Speech characteristics of children after otitis media. Journal of Pediatric Health Care. 1987;1:261-265. [pmid: 3656042].
Eagles EL, Wishik SM, Doerfler LG. Hearing sensitivity and ear disease in children: a prospective study. Laryngoscope. 1967:274.
Eagles E L. Symposium: conservation of hearing in children. Selected findings from the Pittsburgh study. Transactions - American Academy of Ophthalmology and Otolaryngology. 1972;76:343-348. [pmid: 4667653].
Eagles E L. A longitudinal study of ear disease and hearing sensitivity in children. Audiology. 1973;12:438-445. [pmid: 4744303].
Eason R J, Harding E, Nicholson R, Nicholson D, Pada J, Gathercole J. Chronic suppurative otitis media in the Solomon Islands: a prospective, microbiological, audiometric and therapeutic survey. N-Z-Med-J. 1986;99:812-815. [pmid: 3466089].
East D. The use of Per-Lee ventilation tubes in the management of refractory secretory otitis media. J Laryngol Otol. 1986;100:509-513. [pmid: 3701197].
Eavey R D, Gao Y Z, Schuknecht H F, Gonzalez-Pineda M. Otologic features of bacterial meningitis of childhood. J Pediatr. 1985;106:402-407. [pmid: 3973777].
Eavey R D, Santos J I, Arriaga M A, et al. An education model for otitis media care field-tested in Latin America. Otolaryngol Head Neck Surg. 1993;109:895-898. [pmid: 8247571].
Eavey R D. Abnormalities of the neonatal ear: otoscopic observations, histologic observations, and a model for contamination of the middle ear by cellular contents of amniotic fluid. Laryngoscope. 1993;103:1-31. [pmid: 8419727].
Ebeling O, Ott S, Michel O, Stennert E. [Self-induced illness in ENT medical practice. Artefacts as a contribution to differential diagnosis of unusual illness courses]. HNO. 1996;44:526-531. [pmid: 9005235].
Eby T L, Nadol J B Jr. Postnatal growth of the human temporal bone. Implications for cochlear implants in children. Ann Otol Rhinol Laryngol. 1986;95:356-364. [pmid: 3755577].
Edamatsu H, Yamashita K. [Three-dimensional CT of the ossicles of the middle ear]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1995;98:245-253.
Edelstein D R, Parisier S C, Han J C. Acquired cholesteatoma in the pediatric age group. Otolaryngol Clin North Am. 1989;22:955-966. [pmid: 2616170].
Edstrom S, Lundin K, Jeppsson P H. Secretory otitis media. Aspects on treatment and control. ORL-J-Otorhinolaryngol-Relat-Spec. 1977;39:68-73. [pmid: 333341].
Egeli E, Kiris M. Is aspiration necessary before tympanostomy tube insertion?. Laryngoscope. 1998;108:443-444. [pmid: 9504622].
Egelund E, Bak-Pedersen K. Suppurative labyrinthitis caused by anaerobic bacteria. J Laryngol Otol. 1994;108:413-414. [pmid: 8035121].
Egger M, Smith G D, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. Br Med J. 1997;315:629-634. [pmid: 9310563].
Egusa K, Huang C C, Haddad J Jr. Heat shock proteins in acute otitis media. Laryngoscope. 1995;105:708-713. [pmid: 7603274].
Ehsani B, Collo D. [Three years experience with ionomer cement in reconstructive middle ear surgery]. Laryngorhinootologie. 1994;73:381-384. [pmid: 7916784].
Eichenwald HE. Otitis media in the child. Hospital Practice (Office Edition). 1985;20:51–55, 57, 60–61
Eichenwald H. Developments in diagnosing and treating otitis media. Am Fam Physician. 1985;31:155-164. [pmid: 3872049].
Eilers R, Widen J, Urbano R, Hudson T, Gonzales L. Optimization of automated hearing test algorithms: A comparison of data from simulations and young children. Ear Hear. 1991;12:199-204. [pmid: 1916045].
Eimas P D, Kavanagh J F. Otitis media, hearing loss, and child development: a NICHD conference summary. Public Health Rep. 1986;101:289-293. [pmid: 3086922]. [pmcid: 1477706].
Eiriksson T H, Sigurgeirsson B, Ardal B, Sigfusson A, Valdimarsson H. Cord blood IgE levels are influenced by gestational age but do not predict allergic manifestations in infants. Pediatr Allergy Immunol. 1994;5:5-10. [pmid: 8173640].
Eisenman D J, Parisier S C. Is chronic otitis media with cholesteatoma associated with neurosensory hearing loss?. Am J Otol. 1998;19:20-25. [pmid: 9455942].
el-Guindy A. A correlative manometric and endoscopic study of tubal function in chronic otitis media with effusion. Acta Otolaryngol. 1998;118:692-696. [pmid: 9840506].
el-Sayed Y, Zakzouk S. Point prevalence of type B tympanogram in Riyadh. Int J Pediatr Otorhinolaryngol. 1995;31:53-61. [pmid: 7729995].
el-Sayed Y, al-Sarhani A, al-Essa A R. Otological manifestations of primary ciliary dyskinesia. Clin Otolaryngol Allied Sci. 1997;22:266-270. [pmid: 9222635].
el-Seifi A. Myringoplasty (repair of total or subtotal drum perforations). J Laryngol Otol. 1974;88:731-740. [pmid: 4422397].
el-Shamy H A. Bacteriology of chronic secretory otitis media in children. J Egypt Public Health Assoc. 1993;68:495-505. [pmid: 7775877].
Elahi M M, Elahi F, Elahi A, Elahi S B. Paediatric hearing loss in rural Pakistan. J Otolaryngol. 1998;27:348-353. [pmid: 9857321].
Elam M, Harell M, Luntz M, Fuchs C, Sade J. Middle ear pressure variations during 50% N2O anesthesia as a function of mastoid pneumatization. Am J Otol. 1998;19:709-711. [pmid: 9831141].
Elango S, Purohit G N, Hashim M, Hilmi R. Hearing loss and ear disorders in Malaysian school children. Int J Pediatr Otorhinolaryngol. 1991;22:75-80. [pmid: 1917340].
Elango S, Than T. Mastoiditis in Kelantan. Med J Malaysia. 1995;50:233-236. [pmid: 8926900].
Elango S. Parapharyngeal space lipoma. Ear Nose Throat J. 1995;74:52-53. [pmid: 7867532].
Elbrond O. Defects of the auditory ossicles in ears with intact tympanic membrane. Clinical studies. Acta Oto-Laryngologica - Supplement. 1970;264:1-51.
Elbrond O, Birch L. Daily impedance audiometric screening of children in a day-care institution. Auris Nasus Larynx. 1985;12:S216-S218. [pmid: 3835913].
Elcock H W, Lord I J. Bromhexine hydrochloride in chronic secretory otitis media--a clinical trial. Br-J-Clin-Pract. 1972;26:276-278. [pmid: 4557897].
Eldridge R, Brody J A, Wetmore N. Hearing loss and otitis media on Guam. Arch Otolaryngol. 1970;91:148-153. [pmid: 5410083].
Eliachar I. Audiologic manifestations in otitis media. Otolaryngol Clin North Am. 1978;11:769-776. [pmid: 569803].
Eliachar I, Moscona A R. Reconstruction of the laryngotracheal complex in children using the sternocleidomastoid myocutaneous flap. Head and Neck Surgery. 1981;4:16-21. [pmid: 7287445].
Eliachar I, Joachims HZ. Long-term ventilation of the middle ear. An update. Scand Audiol. 1982;11.
Eliachar I, Joachims H Z, Goldsher M, Golz A. Assessment of long-term middle ear ventilation. Acta Otolaryngol. 1983;96:105-112. [pmid: 6613541].
Elias-Jones A C, Sequeira J, Leitch R N, Heard S R. Tuberculosis presenting as laryngeal stridor in a child. J Infect. 1988;16:61-64. [pmid: 3367057].
Elies W, Pletan Y. An international medico-economic survey of 2007 children with recurrent nasopharyngitis and acute otitis media. Preliminary bindings. Drugs. 1997;54:5-12. [pmid: 9378078].
Ellefsen B, Bonding P. Facial palsy in acute otitis media. Clin Otolaryngol. 1996;21:393-395. [pmid: 8932940].
Elliott M A, Studen-Pavlovich D A, Ranalli D N. Prevalence of selected pediatric conditions in children with Pierre Robin sequence. Pediatr Dent. 1995;17:106-111. [pmid: 7603903].
Elliott C A, Zalzal G H, Gottlieb W R. Acute otitis media and facial paralysis in children. Ann Otol Rhinol Laryngol. 1996;105:58-62. [pmid: 8546426].
Ellis MA, Lee WW, Wallace IF, Gravel JS. Hearing sensitivity and otitis media in one-year old infants: a preliminary report. In: Lim DJ, Bluestone CD, Casselbrant M, Klein JO, Ogra PL, eds. Proceedings of the Sixth International Symposium on Recent Advances in Otitis Media. Hamilton: BC Decker; 1995:396.
Ellis MA, Lee WW, Wallace IF, Gravel JS. Hearing sensitivity and otitis media in one-year old infants: a preliminary report. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:396–398.
Ellison R S, Altemeier W A. Effect of use of a measured dispensing device on oral antibiotic compliance. CLIN. PEDIATR. (PHILADELPHIA). 1982;21:668-671. [pmcid: 358331].
Ellison G W, Donnell R L, Daniel G B. Nasopharyngeal epidermal cyst in a dog. J Am Vet Med Assoc. 1995;207:1590-1592. [pmid: 7493897].
Elverland H H, Mair I W, Haugeto O K, Schroder K E. Influence of adenoid hypertrophy on secretory otitis media. Ann Otol Rhinol Laryngol. 1981;90:7-11. [pmid: 7193427].
Emery M, Weber P C. Hearing loss due to myringotomy and tube placement and the role of preoperative audiograms. Arch Otolaryngol Head and Neck Surgery. 1998;124:421-424.
Endo L H, Antunes A B, Vidolin C, Bilecki M M, Magalhaes K V B. Secretory media otitis: Clinical treatment vs placebo. OTITE MEDIA SECRETORA: TRATAMENTO CLINICO VERSUS PLACEBO. Revista Brasileira De Otorrinolaringologia. 1997;63:116-119.
Endo L H, Antunes A B, Vidolin C, Bilecki M M, Magalhaes K V B. Secretory media otitis: Clinical treatment vs placebo. Revista Brasileira de Otorrinolaringologia. 1997;63:116-119.
Engdahl B, Arnesen A R, Mair I W. Otoacoustic emissions in the first year of life. Scand Audiol. 1994;23:195-200. [pmid: 7997837].
Engel F, Blatz R, Kellner J, Palmer M, Weller U, Bhadki S. Breakdown of the round window membrane permeability barrier evoked by streptolysin O: possible etiologic role in development of sensorineural hearing loss in acute otitis media. Infect Immun. 1995;63:1305-1310. [pmcid: 173151]. [pmid: 7890388].
Engel JM, Anteunis LJC, Hendricks JJT, Marres EHMA. Epidemiologic aspects of otitis media with effusion in infancy. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:47–49.
Engel J, Anteunis L, Volovics A, Hendriks J, Marres E. Risk factors of otitis media with effusion during infancy. Int J Pediatr Otorhinolaryngol. 1999;48:239-249. [pmid: 10402121].
Engel J, Anteunis L, Volovics A, Hendriks J, Marres E. Prevalence rates of otitis media with effusion from 0 to 2 years of age: healthy-born versus high-risk-born infants. Int J Pediatr Otorhinolaryngol. 1999;47:243-251. [pmid: 10321779].
Engel J A M, Anteunis L J C, Volovics A, Hendriks J J T, Manni J J. Chronic otitis media with effusion during infancy, have parent-reported symptoms prognostic value? A prospective longitudinal study from 0 to 2 years of age. Clin Otolaryngol Allied Sci. 1999;24:417-423. [pmid: 10542922].
Engelhard D, Cohen D, Strauss N, Sacks T G, Jorczak-Sarni L, Shapiro M. Randomised study of myringotomy, amoxycillin/clavulanate, or both for acute otitis media in infants. Lancet. 1989;2:141-143. [pmid: 2567903].
Englender M, Somech E, Harell M. Laser myringotomy (L-myringotomy) and ventilating tubes: A preliminary comparative study. Lasers in Medical Science. 1999;14:62-66.
English G M, Hildyard V H, Hemenway W G, Davidson S. Autograft and homograft incus transpositions in chronic otitis media. Laryngoscope. 1971;81:1434-1447. [pmid: 5098106].
Englund J A, Suarez C S, Kelly J, Tate D Y, Balfour H H Jr. Placebo-controlled trial of varicella vaccine given with or after measles-mumps-rubella vaccine. J Pediatr. 1989;114:37-44. [pmid: 2535873].
Enin EP, Morenko VM. [Polysorb as an immobilizing matrix for the drugs used for the local therapy of otitis media]. Vestn Otorinolaringol. 1993:41–42.
Enomoto F, Ichikawa G, Nagaoka I, Yamashita T. [Evaluation of arachidonic acid metabolites in experimental rat otitis media with effusion]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1995;98:959-967.
Enomoto F, Ichikawa G, Nagaoka I, Yamashita T. [Evaluation of the effect of erythromycin on otitis media with effusion in experimental rat models]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1996;99:1126-1135.
Eppes S C, Klein J D, Lewis L L. Ceftriaxone for acute otitis media [letter]. Pediatrics. 1997;100:157-158. [pmid: 9229709].
Epstein M M, Gruskay F. Selective deficiency in pneumococcal antibody response in children with recurrent infections. Ann Allergy Asthma Immunol. 1995;75:125-131. [pmid: 7648376].
Erkan M, Aslan T, Sevuk E, Guney E. Bacteriology of chronic suppurative otitis media. Ann Otol Rhinol Laryngol. 1994;103:771-774. [pmid: 7944167].
Erlach A, Zechner G. Tubotympanic catarrh in childhood. Diagnosis and therapy. Wien Klin Wochenschr. 1983;95:396-399. [pmid: 6613135].
Ernst A, Issing P R. [Ear infections]. Med Monatsschr Pharm. 1994;17:294-298. [pmid: 7990748].
Ernstson S, Sundberg L. Erythromycin in the treatment of otitis media with effusion (OME). J Laryngol Otol. 1984;98:767-769. [pmid: 6540792].
Ernstson S, Anari M. Cefaclor in the treatment of otitis media with effusion. Acta-Otolaryngol-Suppl-Stockh. 1985:17–21.
Ernstson S, Sundberg L. Erythromycin in the treatment of otitis media with effusion: Timing and long-term effects. Current Therapeutic Research, Clinical and Experimental. 1985;38.
Esposito S, D'Errico G, Montanaro C. Topical and oral treatment of chronic otitis media with ciprofloxacin. A preliminary study. Arch Otolaryngol Head Neck Surg. 1990;116:557-559. [pmid: 2328112].
Esposito S, Noviello S, D'Errico G, Montanaro C. Topical ciprofloxacin vs intramuscular gentamicin for chronic otitis media [see comments]. Arch Otolaryngol Head Neck Surg. 1992;118:842-844. [pmid: 1642836].
Etzel R A, Pattishall E N, Haley N J, Fletcher R H, Henderson F W. Passive smoking and middle ear effusion among children in day care. Pediatrics. 1992;90:228-232. [pmid: 1641287].
Everberg G. Conductive lesions in children and young adults in past and present. Prevalence, causes and treatment. Acta Otolaryngol. 1966;Suppl:186+.
Eviatar A, Goodhill V. Myringo-manometry: observations in normal and pathologic ears. A preliminary report. Laryngoscope. 1970;80:1847-1858. [pmid: 5491069].
Ey J L, Holberg C J, Aldous M B, Wright A L, Martinez F D, Taussig L M. Passive smoke exposure and otitis media in the first year of life. Group Health Medical Associates. Pediatrics. 1995;95:670-677. [pmid: 7724301].
Fabian P, Lonnerholm G, Jerrmark-Tera I B, Kleberg A, Melander H. [Effects and adverse effects of decongestants in otosalpingitis]. Lakartidningen. 1986;83:3508-3513. [pmid: 3537593].
Facione N. Quality of life issues in chronic otitis media with effusion: parameters for future study. Int J Pediatr Otorhinolaryngol. 1991;22:167-179. [pmid: 1743877].
Faden H, Brodsky L, Bernstein J, et al. Otitis media in children: local immune response to nontypeable Haemophilus influenzae. Infect Immun. 1989;57:3555-3559. [pmcid: 259867]. [pmid: 2807536].
Faden H, Bernstein J, Brodsky L, Stanievich J, Ogra P L. Effect of prior antibiotic treatment on middle ear disease in children. Ann Otol Rhinol Laryngol. 1992;101:87-91. [pmid: 1728891].
Faden H, Hong J J, Pahade N. Immune response to Moraxella catarrhalis in children with otitis media: opsonophagocytosis with antigen-coated latex beads. Ann Otol Rhinol Laryngol. 1994;103:522-524. [pmid: 8024214].
Faden H, Doern G, Wolf J, Blocker M. Antimicrobial susceptibility of nasopharyngeal isolates of potential pathogens recovered from infants before antibiotic therapy: implications for the management of otitis media. Pediatr Infect Dis J. 1994;13:609-612. [pmid: 7970948].
Faden H, Harabuchi Y, Hong J J. Epidemiology of Moraxella catarrhalis in children during the first 2 years of life: relationship to otitis media. J Infect Dis. 1994;169:1312-1317. [pmid: 8195609].
Faden H. Comparison of the local immune response to nontypable Haemophilus influenzae (nHI) and Moraxella catarrhalis (MC) during otitis media. Adv Exp Med Biol. 1995;371B:733-736. [pmid: 7502887].
Faden H, Duffy L, Hong J J. Adherence of nontypable Haemophilus influenzae to respiratory epithelium of otitis prone and normal children. Acta Oto-Laryngologica - Supplement. 1996;523:142-144.
Faden H, Duffy L, Williams A, Krystofik D A, Wolf J. Epidemiology of nasopharyngeal colonization with nontypeable Haemophilus influenzae in the first two years of life. Acta Oto-Laryngologica - Supplement. 1996;523:128-129.
Faden H, Duffy L, Foels T, Hong J J. Adherence of nontypeable Haemophilus influenzae to respiratory epithelium of otitis-prone and normal children. Ann Otol Rhinol Laryngol. 1996;105:367-370. [pmid: 8651630].
Faden H, Duffy L, Wasielewski R, Wolf J, Krystofik D, Tung Y. Relationship between nasopharyngeal colonization and the development of otitis media in children. Tonawanda/Williamsville Pediatrics. J Infect Dis. 1997;175:1440-1445. [pmid: 9180184].
Fagan J J, Prescott C A. Ascariasis and acute otitis media. Int J Pediatr Otorhinolaryngol. 1993;26:67-69. [pmid: 8444548].
Fagelson M, Martin F N. Sound pressure in the external auditory canal during bone-conduction testing. J Am Acad Audiol. 1994;5:379-383. [pmid: 7858298].
Fair L, Louw B. Early communication intervention with young children with Pierre Robin sequence. South African Journal of Communication Disorders - die Suid-Afrikaanse Tydskrif vir Kommunikasieafwykings. 1998;45:51-60. [pmid: 10472176].
Fajemisin A A. Rhabdomyosarcoma of the middle ear and mastoid. J Laryngol Otol. 1974;88:809-816. [pmid: 4418943].
Falaki N N. Index of suspicion. Case I. Langerhans cell histiocytosis. Pediatr Rev. 1994;15:117-118. [pmid: 8041672].
Falk B. Negative middle ear pressure induced by sniffing. A tympanometric study in persons with healthy ears. J Otolaryngol. 1981;10:299-305. [pmid: 7299886].
Falk B. Sniff-induced negative middle ear pressure: study of a consecutive series of children with otitis media with effusion. Am J Otolaryngol. 1982;3:155-162. [pmid: 7102952].
Falk B. Variability of the tympanogram due to eustachian tube closing failure. Scand Audiol Suppl. 1983;17:11-17. [pmid: 6577550].
Falser N, Mittermayer H, Weuta H. Antibacterial treatment of otitis and sinusitis with ciprofloxacin and penicillin V--a comparison. Infection. 1988:S51–S54.
Farber J M. Therapy for acute otitis media [letter; comment]. Arch Pediatr Adolesc Med. 1996;150:1315. [pmid: 8954010].
Farkas Z, Katona G, Pataki L. Epidemiology of hearing disability in children - A survey in some European countries. J Audiological Med. 1998;7:1-3.
Farrior J B, Endicott J N. Congenital mixed deafness: cerebrospinal fluid otorrhea. Ablation of the aqueduct of the cochlea. Laryngoscope. 1971;81:684-699. [pmid: 5157371].
Farrior J B. XXXII Wherry Memorial Lecture. The ear surgeon of tomorrow. Tympanomastoidectomy techniques and classification. Transactions - American Academy of Ophthalmology and Otolaryngology. 1977;84:15-37.
Farrugia E J, Raza S A, Phillipps J J. Tuberculous otitis media--a case report. J Laryngol Otol. 1997;111:58-59. [pmid: 9292134].
Farwell J R, Blackner G, Sulzbacher S, Adelman L, Voeller M. First febrile seizures. Characteristics of the child, the seizure, and the illness. Clin Pediatr. 1994;33:263-267.
Faye-Lund H. Acute and latent mastoiditis. J Laryngol Otol. 1989;103:1158-1160. [pmid: 2614236].
Feagans L, Sanyal M, Henderson F, Collier A, Appelbaum M. Relationship of middle ear disease in early childhood to later narrative and attention skills. J Pediatr Psychol. 1987;12:581-594. [pmid: 3430288].
Feagans LV, Blood IM. Language and behavioral sequelae of otitis media in infants and young children attending day-care centers. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:521–523.
Feagans L, Kipp E, Blood I. The effects of otitis media on the attention skills of day-care-attending toddlers. Dev Psychol. 1994;30:701-708.
Feder H M Jr. Comparative tolerability of ampicillin, amoxicillin, and trimethoprim-sulfamethoxazole suspensions in children with otitis media. Antimicrob-Agents-Chemother. 1982;21:426-427. [pmcid: 181909]. [pmid: 6980622].
Feder H M Jr. Defining outcomes for otitis media studies [letter; comment]. J Pediatr. 1993;122:669-670. [pmid: 8463924].
Federspil P. [Treatment of “suppurating ear” with intact middle ear tubes]. Laryngorhinootologie. 1993;72:209-210. [pmid: 8494594].
Feenstra L, Sanna M, Zini C, Gamoletti R, Delogu P. Surgical treatment of brain herniation into the middle ear and mastoid. Am J Otol. 1985;6:311-315. [pmid: 4025527].
Feilen S E, Federspil P. [Long-term outcome of tympanoplasty in chronic suppurative middle ear infection in childhood]. HNO. 1996;44:143-147. [pmid: 8641901].
Feiner M V, Pardue K M, Raffin M J M, Matz G J. Infant hearing screening program: High-risk factors for hearing loss. Seminars in Hearing. 1996;17:165-170.
Feinmesser R, Segal K, Granot E. Minimal middle ear effusion: an indication for ventilation tubes in infants with protracted vomiting. J Otolaryngol. 1993;22:108-109. [pmid: 8515506].
Felder H. Chronic otitis media in children. Pediatr Ann. 1976;5:474-477. [pmid: 958737].
Felder H. The use of tympanostomy tubes. Pediatr Ann. 1988;17:616, 618-619. [pmid: 3186300].
Felding J U. “The longitudinal Hjorring-population-study”. Results at 6 years of follow-up. Scand Audiol Suppl. 1983;17:55-59. [pmid: 6577560].
Feldman A S. Tympanometry: application and interpretation. Ann Otol Rhinol Laryngol. 1976;85:202-208. [pmid: 1267349].
Feldman AS. Tympanometry: Application and interpretation. The Annals of Otology, Rhinology and Larynogology; 1976:202–208.
Feldman W, Richardson H, Rennie B, Dawson P. A trial comparing cefaclor with co-trimoxazole in the treatment of acute otitis media. Arch-Dis-Child. 1982;57:594-596. [pmid: 7051985].
Feldman R M, Fria T J, Palfrey C C, Dellecker C M. Effects of rate of air pressure change on tympanometry. Ear Hear. 1984;5:91-95. [pmid: 6539263].
Feldman S, Doolittle M, Lott L, Roberson P, Hughes W T. Similar hematologic changes in children receiving trimethoprim-sulfamethoxazole or amoxicillin for otitis media. J Pediatr. 1985;106:995-1000. [pmid: 3889261].
Feldman W, Momy J, Dulberg C. Trimethoprim-sulfamethoxazole v. amoxicillin in the treatment of acute otitis media. CMAJ. 1988;139:961-964. [pmid: 3052769]. [pmcid: 1268389].
Feldman W, Sutcliffe T, Dulberg C. Twice-daily antibiotics in the treatment of acute otitis media: trimethoprim-sulfamethoxazole versus amoxicillin-clavulanate [see comments]. CMAJ. 1990;142:115-118. [pmid: 2403833]. [pmcid: 1451732].
Feldman HM, Paradise JL, Colborn DK, et al. Word production at age 2 years in relation to otitis media during the first two years of life. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:328.
Feldman H M, Dollaghan C A, Campbell T F, et al. Parent-reported language and communication skills at one and two years of age in relation to otitis media in the first two years of life. Pediatrics. 1999;104:e52. [pmid: 10506277].
Feldmann H. Homolateral and contralateral masking of tinnitus. Journal of Laryngology and Otology - Supplement. 1981:60–70.
Feldmann H. Differential diagnosis of acute hearing impairment. Diagnostik. 1985;18:13-15.
Fenton J E, O'sullivan T J. The otological manifestations of Wegener's granulomatosis. J Laryngol Otol. 1994;108:144-146. [pmid: 8163916].
Ferekidis E, Vlachou S, Douniadakis D, Apostolopoulos N, Adamopoulos G. Multiple-frequency tympanometry in children with acute otitis media. Otolaryngology and Head and Neck Surgery. 1999;121:797-801.
Ferguson P J, Saulsbury F T. Successful treatment of chronic Mycobacterium abscessus otitis media with clarithromycin. Pediatr Infect Dis J. 1996;15:384-385. [pmid: 8866816].
Fernandes D, Gupta S, Sly R M, Frazer M. Tympanometry in children with allergic respiratory disease. Annals of Allergy. 1978;40:181-184. [pmid: 637377].
Fernandez-Blasini N. Use and abuse of ventilation tubes. Am J Otol. 1985;6:142-145. [pmid: 4039110].
Ferrer H P. The use of impedance measurements in the diagnosis of serous otitis media. Int J Pediatr Otorhinolaryngol. 1983;5:243-250. [pmid: 6685114].
Ferrer HP. Impedance Measurements in the Diagnosis of Otitis Media with Effusion. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:246–249.
Ferroni A, Nguyen L, Gehanno P, Boucot I, Berche P. Clonal distribution of penicillin-resistant Streptococcus pneumoniae 23F in France. J Clin Microbiol. 1996;34:2707-2712. [pmcid: 229390]. [pmid: 8897169].
Ficnar B, Huzjak N, Oreskovic K, Matrapazovski M, Klinar I. Azithromycin: 3-day versus 5-day course in the treatment of respiratory tract infections in children. Croatian Azithromycin Study Group. J Chemother. 1997;9:38-43. [pmid: 9106016].
Fielder C P. The effect of adenoidectomy on nasal resistance to airflow. Acta Otolaryngol. 1985;100:444-449. [pmid: 4082983].
Fields J A. Tuberculous mastoiditis. Laryngoscope. 1967;77:489-492. [pmid: 5297919].
Fields M J, Allison R S, Corwin P, White P S, Doherty J. Microtympanometry, microscopy and tympanometry in evaluating middle ear effusion prior to myringotomy. N Z Med J. 1993;106:386-387. [pmid: 8367097].
Fiellau N M, Hojslet P E, Felding J U. Adenoidectomy for Eustachian tube dysfunction: Long-term results from a randomized controlled trial. ACTA-OTO-LARYNGOL. 1982;94:129-131.
Fiellau-Nikolajsen M. Tympanometry in three-year-old children. II. Seasonal influence on tympanometric results in non-selected groups of three-year-old children. Scand Audiol. 1979;8:181-185. [pmid: 515701].
Fiellau-Nikolajsen M. Tympanometry in 3-year-old children. Type of care as an epidemiological factor in secretory otitis media and tubal dysfunction in unselected populations of 3-year-old children. ORL J Otorhinolaryngol Relat Spec. 1979;41:193-205. [pmid: 574241].
Fiellau-Nikolajsen M, Lous J. Tympanometry in three-year-old children. A cohort study on the prognostic value of tympanometry and operative findings in middle ear effusion. ORL J Otorhinolaryngol Relat Spec. 1979;41:11-25. [pmid: 572953].
Fiellau-Nikolajsen M, Lous J. Prospective tympanometry in 3-year-old children. A study of the spontaneous course of tympanometry types in a nonselected population. Arch Otolaryngol. 1979;105:461-466. [pmid: 464883].
Fiellau-Nikolajsen M. Tympanometry in 3-year-old children. Type of case as an epidemiological factor in secretory otitis media and tubal dysfunction in unselected populations of 3-year-old children. Orl. 1979;41:193-205. [pmid: 574241].
Fiellau-Nikolajsen M, Falbe-Hansen J, Knudstrup P. Adenoidectomy for middle ear disorders: a randomized controlled trial. Clin-Otolaryngol. 1980;5:323-327. [pmid: 7002375].
Fiellau-Nikolajsen M. Tympanometry and middle ear effusion: a cohort-study in three-year-old children. Int J Pediatr Otorhinolaryngol. 1980;2:39-49. [pmid: 7188053].
Fiellau-Nikolajsen M, Falbe-Hansen J, Knudstrup P. Tympanometry in three-year-old children. III. Correlation between tympanometry and findings at paracentesis in a prospectively followed population of otherwise healthy children aged 3--4 years. Scand Audiol. 1980;9:49-54. [pmid: 7444320].
Fiellau-Nikolajsen M. Tympanometry in three-year-old children. Prevalence and spontaneous course of MEE. Ann Otol Rhinol Laryngol Suppl. 1980;89:223-227. [pmid: 6778312].
Fiellau-Nikolajsen M. Serial tympanometry and middle ear status in 3-year-old children. ORL J Otorhinolaryngol Relat Spec. 1980;42:220-232. [pmid: 7190666].
Fiellau-Nikolajsen M. Tympanometry in three-year-old children: Prevalence and spontaneous course of MEE. Ann Otol Rhinol Laryngol. 1980;89.
Fiellau-Nikolajsen M. Tympanometry in three-year-old children. The 3-year follow-up of a cohort study. ORL J Otorhinolaryngol Relat Spec. 1981;43:89-103. [pmid: 7194464].
Fiellau-Nikolajsen M. Tympanometry and secretory otitis media. Observations on diagnosis, epidemiology, treatment, and prevention in prospective cohort studies of three-year-old children. Acta Oto-Laryngologica - Supplement. 1983;394:1-73.
Fiellau-Nikolajsen M. Tympanometric prediction of the magnitude of hearing loss in preschool-children with secretory otitis media. Scand Audiol Suppl. 1983;17:68-72. [pmid: 6577563].
Fiellau-Nikolajsen M. Epidemiology of secretory otitis media. A descriptive cohort study. Ann Otol Rhinol Laryngol. 1983;92:172-177. [pmid: 6838108].
Fiellau-Nikolajsen M, Felding JU, Fischer HH. Adenoidectomy for Eustachian Tube Dysfunction: Long-Term Results from a Randomized Controlled Trial. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:302–306.
Fiellau-Nikolajsen M. Tympanometric prediction of hearing loss in secretory otitis media. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:326–329.
Fiellau-Nikolajsen M. Audiological aspects on treatment of SOM. Indications and results. Scand Audiol Suppl. 1986;26:77-81. [pmid: 3472332].
Figueras G, Garcia O, Vall O, Massaguer X, Salvado M. Otogenic Fusobacterium necrophorum meningitis in children. Pediatr Infect Dis J. 1995;14:627-628. [pmid: 7567296].
Fileni A, Colosimo C Jr, Moschini M, Malena S, Gugliantini P. Tomography in the pre-operative evaluation of ear malformations. Report of 47 cases, 58 ears. J Laryngol Otol. 1985;99:433-438. [pmid: 3998628].
Filiaci F, Masieri S, Zambetti G, Orlando M P. Nasal hypersensitivity in purulent middle ear effusion. Allergol Immunopathol. 1997;25:91-94.
Filipo R, Barbara M, Monini S, Mancini P. Clarion cochlear implants: surgical implications. J Laryngol Otol. 1999;113:321-325. [pmid: 10474665].
Fini-Storchi I, Ninu M B. Atypical intranasal foreign body. Ear Nose Throat J. 1996;75:796-799. [pmid: 8991231].
Finitzo T, Roland P, Friel-Patti S, Hieber P, Brown KC, Formby E. Incidence, Prevalence, and Duration of Otitis Media in Infants. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:15–17.
Finitzo T, Friel-Patti S, Chinn K, Brown O. Tympanometry and otoscopy prior to myringotomy: issues in diagnosis of otitis media. Int J Pediatr Otorhinolaryngol. 1992;24:101-110. [pmid: 1428589].
Finkelstein M W, Hammond H L, Jones R B. Hyalinosis cutis et mucosae. Oral Surgery, Oral Medicine, Oral Pathology. 1982;54:49-58.
Finkelstein Y, Talmi Y P, Rubel Y, Bar-Ziv J, Zohar Y. Otitis media with effusion as a presenting symptom of chronic sinusitis. J Laryngol Otol. 1989;103:827-832. [pmid: 2584869].
Finkelstein Y, Ophir D, Talmi Y P, Shabtai A, Strauss M, Zohar Y. Adult-onset otitis media with effusion. Arch Otolaryngol Head Neck Surg. 1994;120:517-527. [pmid: 8172703].
Finney J W, Friman P C, Rapoff M A, Christophersen E R. Improving compliance with antibiotic regimens for otitis media. Randomized clinical trial in a pediatric clinic. Am-J-Dis-Child. 1985;139:89-95. [pmid: 3881932].
Fior R, Veljak C. Late results and complications of tympanostomy tube insertion for prophylaxis of recurrent purulent otitis media in pediatric age. Int J Pediatr Otorhinolaryngol. 1984;8:139-146. [pmid: 6526581].
Fireman P. Eustachian tube obstruction and allergy: a role in otitis media with effusion?. J Allergy Clin Immunol. 1985;76:137-140. [pmid: 4019946].
Fireman P. The role of antihistamines in otitis. J Allergy Clin Immunol. 1990;86:638-641. [pmid: 2229826].
Fireman P. Otitis media and its relation to allergic rhinitis. Allergy Asthma Proc. 1997;18:135-143. [pmid: 9194938].
Fireman P. Treatment strategies designed to minimize medical complications of allergic rhinitis. Am J Rhinol. 1997;11:95-102. [pmid: 9129750].
Fireman P. Otitis media and eustachian tube dysfunction: connection to allergic rhinitis. J Allergy Clin Immunol. 1997;99:S787-S797. [pmid: 9042072].
Fischler R S, Todd N W, Feldman C M. Otitis media and language performance in a cohort of Apache Indian children. Am J Dis Child. 1985;139:355-360. [pmid: 4038844].
Fish B, Banerjee AR, Jennings C, Narula AA. Meeting of the Otorhinolaryngological Research Society (ORS), London , april 1996: The effect of anaesthetic agents on tympanometry and middle ear effusions. Clin Otolaryngol Allied Sci. 1998;23.
Fitz C R, Harwood-Nash D C. Radiology of the ear in children. Radiol Clin North Am. 1974;12:553-570. [pmid: 4548198].
Fitz-Hugh G S, Stone R T. Serous otitis media in children. Virginia Medical Monthly. 1966;93:61-65. [pmid: 5903884].
Fitzhardinge P M, Kazemi M, Ramsay M, Stern L. Long-term sequelae of neonatal meningitis. Dev Med Child Neurol. 1974;16:3-8. [pmid: 4813490].
Fjermedal O, Laukli E. Paediatric auditory brainstem response and pure-tone audiometry: threshold comparisons. A study of 142 difficult-to-test children. Scand Audiol. 1989;18:105-111. [pmid: 2756331].
Fjermedal O, Laukli E. Peadiatric auditory brainstem response and pure-tone audiometry: Threshold comparisons. A study of 142 difficult-to-test children. Scand Audiol. 1989;18:105-111. [pmid: 2756331].
Flanagan P M, Knight L C, Thomas A, Browning S, Aymat A, Clayton M I. Hearing aids and glue ear. Clin Otolaryngol Allied Sci. 1996;21:297-300. [pmid: 8889292].
Fleisher G R, Rosenberg N, Vinci R, et al. Intramuscular versus oral antibiotic therapy for the prevention of meningitis and other bacterial sequelae in young, febrile children at risk for occult bacteremia [see comments]. J Pediatr. 1994;124:504-512. [pmid: 8151462].
Flisberg K, Hallgarde U, Paulsson B. Tympanometry before and during nitrous oxide anesthesia with middle ear effusion. Am J Otolaryngol. 1982;3:344-348. [pmid: 7149146].
Fliss D M, Krauss M, Gorodischer R, Bearman J, Lieberman A. [Cefaclor and trimethoprim-sulfamethoxazole for recurrent otitis media]. Harefuah. 1989;117:361-363. [pmid: 2695415].
Fliss D M, Dagan R, Houri Z, Leiberman A. Medical management of chronic suppurative otitis media without cholesteatoma in children [see comments]. J Pediatr. 1990;116:991-996. [pmid: 2189979].
Fliss DM, Leiberman A, Dagan R. Medical sequelae and complications of acute otitis media. Pediatr Infect Dis J. 1994;13:S34–S40; discussion S50–S54.
Flood J. Glue ear. Nursing Times. 1989;85:38-41. [pmid: 2798170].
Floret D, Dumont C. Neurological complications of otitis media. Medecine et Maladies Infectieuses. 1988;18:486-492.
Flottorp G, Solberg S. Mechanical impedance of human headbones (forehead and mastoid portion of the temporal bone) measured under ISO/IEC conditions. J Acoust Soc Am. 1976;59:899-906. [pmid: 1262591].
Fogelman Y. [Otitis media in childhood and later cognitive and academic difficulties]. Harefuah. 1993;124:570-572. [pmid: 8340012].
Folsom R C, Weber B A, Thompson G. Auditory brainstem responses in children with early recurrent middle ear disease. Ann Otol Rhinol Laryngol. 1983;92:249-253. [pmid: 6859742].
Fombeur J P, Barrault S, Koubbi G, et al. Study of the efficacy and safety of ciprofloxacin in the treatment of chronic otitis. Chemotherapy. 1994;40 S:29-34. [pmid: 7805428].
Fong R. Resident's column. The ear and hearing. Pediatr Ann. 1999;28:396-398. [pmid: 10382200].
Force R W, Hart M C, Plummer S A, Powell D A, Nahata M C. Topical ciprofloxacin for otorrhea after tympanostomy tube placement. Arch Otolaryngol Head Neck Surg. 1995;121:880-884. [pmid: 7619414].
Ford K, Labbok M. Breast-feeding and child health in the United States. J Biosoc Sci. 1993;25:187-194. [pmid: 8478368].
Ford K L 3rd. Aunt Minnie's corner. High-riding jugular bulb. J Comput Assist Tomogr. 1998;22:508. [pmid: 9606398].
Forer M, Murtagh J. Acute otitis media. Aust Fam Physician. 1995;24:2093, 2097. [pmid: 8579546].
Forgays D K, Hasazi J E, Wasserman R C. Recurrent otitis media and parenting stress in mothers of two-year-old children. Dev Behav Pediatr. 1992;13:321-325.
Fornadley J A, Burns J K. The effect of surfactant on eustachian tube function in a gerbil model of otitis media with effusion. Otolaryngol Head Neck Surg. 1994;110:110-114. [pmid: 8290292].
Forquer B D, Linthicum F H Jr. Middle ear effusion: relationship of tympanometry and air-bone gap to viscosity. Ear Hear. 1980;1:87-90. [pmid: 7189493].
Forseni M, Eriksson A, Bagger-Sjoback D, Nilsson J, Hultcrantz M. Development of tympanosclerosis: can predicting factors be identified?. Am J Otol. 1997;18:298-303. [pmid: 9149821].
Forsgren J, Samuelson A, Lindberg A, Rynnel-Dagoo B. Quantitative bacterial culture from adenoid lymphatic tissue with special reference to Haemophilus [corrected] [published erratum appears in Acta Otolaryngol (Stockh) 1994 Jan;114(1):112]. Acta Otolaryngol. 1993;113:668-672. [pmid: 8266797].
Forsgren J, Rynnel-Dagoo B, Christensson B. In situ analysis of the immune microenvironment of the adenoid in children with and without secretory otitis media. Ann Otol Rhinol Laryngol. 1995;104:189-196. [pmid: 7872601].
Forsgren J, Samuelson A, Borrelli S, Christensson B, Jonasson J, Lindberg A A. Persistence of nontypeable Haemophilus influenzae in adenoid macrophages: a putative colonization mechanism. Acta Otolaryngol. 1996;116:766-773. [pmid: 8908258].
Forte V, Turner A, Liu P. Objective tinnitus associated with abnormal mastoid emissary vein. J Otolaryngol. 1989;18:232-235. [pmid: 2769838].
Foshee W S, Qvarnberg Y. Comparative United States and European trials of loracarbef in the treatment of acute otitis media. Pediatr Infect Dis J. 1992;11:S12-S19. [pmid: 1513607].
Foshee W S. Loracarbef (LY163892) versus amoxicillin-clavulanate in the treatment of bacterial acute otitis media with effusion. J Pediatr. 1992;120:980-986. [pmid: 1593361].
Fradis M, Brodsky A, Ben-David J, Srugo I, Larboni J, Podoshin L. Chronic otitis media treated topically with ciprofloxacin or tobramycin. Arch Otolaryngol Head Neck Surg. 1997;123:1057-1060. [pmid: 9339980].
Francois M. [Efficacy and tolerance of a local application of phenazone and chlorhydrate lidocaine (Otipax) in infants and children with congestive otitis]. Annales de Pediatrie. 1993;40:481-484. [pmid: 8239401].
Francois M, Wiener-Vacher S R, Falala M, Narcy P. Audiological assessment of infants and children with preauricular tags. Audiology. 1995;34:1-5. [pmid: 7487642].
Francois M. [Treatment of acute otitis media]. Arch Pediatr. 1995;2:86-88. [pmid: 7735433].
Francois M, Laccourreye L, Huy E T, Narcy P. Hearing impairment in infants after meningitis: detection by transient evoked otoacoustic emissions [see comments]. J Pediatr. 1997;130:712-717. [pmid: 9152278].
Franklin D J, Starke J R, Brady M T, Brown B A, Wallace R J Jr. Chronic otitis media after tympanostomy tube placement caused by Mycobacterium abscessus: a new clinical entity?. Am J Otol. 1994;15:313-320. [pmid: 8579134].
Franklin J H, Marck P A. Outcome analysis of children receiving tympanostomy tubes. J Otolaryngol. 1998;27:293-297. [pmid: 9800629].
Franzetti M, Reali E, Felisati D, et al. Valutazione comparativa dell'amoxicillina e del cefaclor nel trattamento dell'otite media acuta dell'età pediatrica.Cefaclor compared with amoxicillin in the treatment of acute otitis media of infants and children. Rivista-Italiana-di-Pediatria. 1982;8:297-300.
Fraser J G. Deafness and chronic otitis media. Br Med J. 1970;2:95-97. [pmid: 5420243].
Fraser J G. Secretory otitis media in childhood. A survey of current understanding and management. Clin Pediatr. 1971;10:261-264.
Fraser J, Mehta M, Fraser P A. The medical treatment of secretory otitis media. A clinical trial of three commonly used regimes. J Laryngol Otol. 1977;91:757-765. [pmid: 335005].
Fraysse B, Calvet H, Faure P, Schutz D. Value of fenspiride (Pneumorel 80 mg) in the preoperative treatment of chronic open tympanum otitis. Double-blind placebo-controlled study. Rhinol-Suppl. 1988:31–41.
Freeark K, Frank S J, Wagner A E, Lopez M, Olmsted C, Girard R. Otitis media, language development, and parental verbal stimulation. J Pediatr Psychol. 1992;17:173-185. [pmid: 1593393].
Freeman C M, Chandler J R Jr. The radical mastoid operation. South Med J. 1974;67:1061-1066. [pmid: 4855027].
Freeman B A, Parkins C. The prevalence of middle ear disease among learning impaired children. Does a higher prevalence indicate an association?. Clin Pediatr. 1979;18:205-212.
Freeman D, Le CT. Evaluation of Ventilating Tubes and Myringotomy for the Treatment of Otitis Media. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:272–275.
Freeman C R, Krischer J P, Sanford R A, et al. Final results of a study of escalating doses of hyperfractionated radiotherapy in brain stem tumors in children: a Pediatric Oncology Group study. Int-J-Radiat-Oncol-Biol-Phys. 1993;27:197-206. [pmid: 8407392].
Fremaux A, Sissia G, Geslin P. [In vitro antibacterial activity of pristinamycin against penicillin resistant Streptococcus pneumoniae]. Pathol Biol. 1993;41:636-640. [pmid: 8255615].
Frese K A, Hoppe F. [Morphologic studies of autologous and homologous ossicles after long-term implantation]. Laryngorhinootologie. 1996;75:330-334. [pmid: 8766378].
Freyss G E, Narcy P P, Manac'h Y, Toupet M G. Acoustic reflex as a predictor of middle ear effusion. Ann Otol Rhinol Laryngol Suppl. 1980;89:196-199. [pmid: 6778305].
Fria T J, Sabo D L. Auditory brainstem responses in children with otitis media with effusion. Ann Otol Rhinol Laryngol Suppl. 1980;89:200-206. [pmid: 6778307].
Fria T J, Cantekin E I, Probst G. Validation of an automatic otoadmittance middle ear analyzer. Ann Otol Rhinol Laryngol. 1980;89:253-256. [pmid: 7416672].
Fria TJ, Cantekin EI, Eichler JA, Mandel EM, Bluestone CD, Rockette HE. The Effect of Otitis Media with Effusion (“Secretory” Otitis Media) on Hearing Sensitivity in Children. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:320–324.
Fria T J, Cantekin E I, Eichler J A. Hearing acuity of children with otitis media with effusion. Arch Otolaryngol. 1985;111:10-16. [pmid: 4038450].
Fried M, Kelly J, Zubick H, Vernick D, Strome M. Acoustic reflectivity for diagnosis of middle ear effusions: Comparison with results of myringotomy. New dimesnions in otorhinolaryngology - head and neck surgery. 1985;2:931-932.
Fried M P, Vernick D M, Silberstein V, Kelly J H, Strome M. The effects of anesthesia on middle-ear effusions. Laryngoscope. 1988;98:23-25. [pmid: 3336256].
Friedland I R. Cefixime therapy for otitis media [letter]. Pediatr Infect Dis J. 1993;12:544-545. [pmid: 8345993].
Friedland I R, McCracken G H Jr. Management of infections caused by antibiotic-resistant Streptococcus pneumoniae [see comments]. N Engl J Med. 1994;331:377-382. [pmid: 8028618].
Friedman R A, Doyle W J, Casselbrant M L, et al. Immunologic-mediated eustachian tube obstruction: A double-blind crossover study. J Allergy Clin Immunol. 1983;71:442-447. [pmid: 6341435].
Friedman R A, Doyle W J, Casselbrant M L, et al. Immunologic-mediated eustachian tube obstruction: A double-blind crossover study. J Allergy Clin Immunol. 1983;71:442-447. [pmid: 6341435].
Friedman H D, Landaw S A. Recent-onset myelodysplastic syndrome mimicking acute leukemia during infection. Ann Hematol. 1996;72:85-88. [pmid: 8597613].
Friedman R A, Brackmann D E, van Loveren H R, Hitselberger W E. Management of the contracted mastoid in the translabyrinthine removal of acoustic neuroma. Arch Otolaryngol Head Neck Surg. 1997;123:342-344. [pmid: 9076243].
Friedman I, Weir N. Tuberculosis of the ear and a Nepalese experience [letter]. J Laryngol Otol. 1997;111:408. [pmid: 9176632].
Friedmann I. The pathology of acute and chronic infections of the middle ear cleft. Ann Otol Rhinol Laryngol. 1971;80:391-396. [pmid: 4996151].
Friedmann I, Spellacy E, Crow J, Watts R W. Histopathological studies of the temporal bones in Hurler's disease [mucopolysaccharidosis (MPS) IH]. J Laryngol Otol. 1985;99:29-41. [pmid: 3918131].
Friedmann I. On the pathogenesis of glue ear [letter; comment]. J Laryngol Otol. 1994;108:631. [pmid: 7930909].
Friel-Patti S, Finitzo-Hieber T, Conti G, Brown K C. Language delay in infants associated with middle ear disease and mild, fluctuating hearing impairment. Pediatr Infect Dis. 1982;1:104-109. [pmid: 7177899].
Friel-Patti S, Finitzo T, Meyerhoff WL, Hieber JP. Speech-language learning and early middle ear disease: A procedural report Otitis media and child development. In: JF K, ed. Otitis media and child development. Parkton, Maryland: York Press; 1986:129–138.
Friel-Patti S, Finitzo T, Hieber J P. Communication disorders screening in a pediatric practice. Seminars in Hearing. 1987;8:143-148.
Friel-Patti S, Finitzo T. Language learning in a prospective study of otitis media with effusion in the first two years of life. J Speech Hear Res. 1990;33:188-194. [pmid: 2314079].
Friel-Patti S, Finitzo T. Speech-language learning in the first three years in children with tympanostomy tubes for recurrent or persistent otitis media. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:523–527.
Friel-Patti S, Finitzo T, Chinn KM, Lindgren B. Effects of day-care setting on incidence of OME and language development in a cohort of children followed prospectively. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:569–573.
Friese K H, Kruse S, Moeller H. [Acute otitis media in children. Comparison between conventional and homeopathic therapy]. HNO. 1996;44:462-466. [pmid: 8805013].
Friese K H, Kruse S, Ludtke R, Moeller H. The homoeopathic treatment of otitis media in children--comparisons with conventional therapy. Int-J-Clin-Pharmacol-Ther. 1997;35:296-301. [pmid: 9247843].
Fritz W, Schafer J, Klein H J. Hearing loss after microvascular decompression for trigeminal neuralgia. J Neurosurg. 1988;69:367-370. [pmid: 3404234].
Froehle R M. Ear infection: a retrospective study examining improvement from chiropractic care and analyzing for influencing factors. J Manipulative Physiol Ther. 1996;19:169-177. [pmid: 8728460].
Froehlich P, Morgon A. Impact of clinical practice guidelines [letter]. Lancet. 1995;346:1039-1040. [pmid: 7475575].
Froelich P, Morgon A. Antibiotic prophylaxis of otitis media [letter]. Lancet. 1995;346:708. [pmid: 7658852].
Froom J, Culpepper L, Grob P, et al. Diagnosis and antibiotic treatment of acute otitis media: report from International Primary Care Network. Br Med J. 1990;300:582-586. [pmid: 2108756]. [pmcid: 1662354].
Froom J, Culpepper L. Otitis media in day-care children. A report from the International Primary Care Network. J Fam Pract. 1991;32:289-294. [pmid: 2002320].
Froom J, Culpepper L, Bridges-Webb C, et al. Effect of patient characteristics and disease manifestations on the outcome of acute otitis media at 2 months [see comments]. Arch Fam Med. 1993;2:841-846. [pmid: 8111513].
Froom J, Culpepper L, Bridges-Webb C, et al. Effect of patient characteristics and disease manifestations on the outcome of acute otitis media at 2 months [see comments]. Arch Fam Med. 1993;2:841-846. [pmid: 8111513].
Froom J, Culpepper L, Jacobs M, et al. Antimicrobials for acute otitis media? A review from the International Primary Care Network. Br Med J. 1997;315:98-102. [pmid: 9240050].
Fry J, Dillane J B, McNab Jones R F, Kalton G, Andrew E. The outcome of acute otitis media. (A report to the Medical Research Council). British Journal of Preventive and Social Medicine. 1969;23:205-209. [pmid: 5355274].
Fry J. Acute otitis media in general practice. Proceedings of the Royal Society of Medicine. 1970;63:741-742. [pmid: 5434232]. [pmcid: 1811490].
Fry J. Discussion on the aftermath of acute otitis media. Practitioner. 1970;204:582. [pmid: 5443547].
Fuchs M, Arnold W. Indication for the use of ventilating tubes in secretory otitis. Laryngol Rhinol Otol. 1986;65:21-23.
Fucsek M. [Attempt at prevention of chronic otitis media in childhood]. Orv Hetil. 1993;134:513-516. [pmid: 8446402].
Fugas M. Effects of sulphur dioxide and smoke on the incidence of secretory otitis media [letter; comment]. Arh Hig Rada Toksikol. 1994;45:55. [pmid: 8067913].
Fujihara K, Fujihara T, Yamanaka N. Secretory IgA and squamous epithelization in adenoids of children with otitis media with effusion. Acta Oto-Laryngologica - Supplement. 1996;523:155-157.
Fujimori I, Goto R, Hisamatsu K, et al. [Participation in causing O.M.E. with nasopharyngeal alpha-Streptococcus]. Kansenshogaku Zasshi - Journal of the Japanese Association for Infectious Diseases. 1995;69:982-986.
Fujimori I, Kikushima K, Goto R, Hisamatsu K, Murakami Y, Yamada T. Investigation of the nasopharyngeal bacterial flora in children with otitis media with effusion. ORL J Otorhinolaryngol Relat Spec. 1996;58:147-150. [pmid: 8797218].
Fujimori I, Hisamatsu K, Kikushima K, Goto R, Murakami Y, Yamada T. The nasopharyngeal bacterial flora in children with otitis media with effusion [see comments]. Eur Arch Otorhinolaryngol. 1996;253:260-263. [pmid: 8737781].
Fujimori I. The nasopharyngeal bacterial flora in children with otitis media with effusion [Eur Arch Otorhinolaryngol (1996) 253:260–263] [letter; comment]. Eur Arch Otorhinolaryngol. 1997;254:113. [pmid: 9065668].
Fujimoto M, Kira J, Murai H, Yoshimura T, Takizawa K, Goto I. Hypertrophic cranial pachymeningitis associated with mixed connective tissue disease; a comparison with idiopathic and infectious pachymeningitis. Intern Med. 1993;32:510-512. [pmid: 8241599].
Fujioka O. The immunological role of the outer membrane proteins of non-typable Hemophilus influenzae in otitis media with effusion in children. Eur Arch Otorhinolaryngol. 1991;248:483-486. [pmid: 1768412].
Fujita A, Honjo I, Kurata K, Gan I, Takahashi H. Refractory otitis media with effusion from viewpoints of eustachian tube dysfunction and nasal sinusitis. Am J Otolaryngol. 1993;14:187-190. [pmid: 8338201].
Fukuda T, Sugie H, Ito M, Kikawada T. Bilateral facial palsy caused by bilateral masked mastoiditis. Pediatr Neurol. 1998;18:351-353. [pmid: 9588534].
Fulghum R S, Marrow H G. Experimental otitis media with Moraxella (Branhamella) catarrhalis. Ann Otol Rhinol Laryngol. 1996;105:234-241. [pmid: 8615589].
Fuller A P. Otitis media and the surgical physiology of the middle ear. Proceedings of the Royal Society of Medicine. 1970;63:744-746. [pmid: 5434234]. [pmcid: 1811492].
Fuller C G, Schoettler J J, Gilsanz V, Nelson M D Jr, Church J A, Richards W. Sinusitis in status asthmaticus. Clin Pediatr. 1994;33:712-719.
Funk J B, Ruppert E S. Language disorders and behavioral problems in preschool children. J Dev Behav Pediatr. 1984;5:357-360. [pmid: 6511935].
Funke G, Stubbs S, Altwegg M, Carlotti A, Collins M D. Turicella otitidis gen. nov., sp. nov., a coryneform bacterium isolated from patients with otitis media. Int J Syst Bacteriol. 1994;44:270-273. [pmid: 8186090].
Furman S, Berkowicz L, Dippenaar J, et al. Cefetamet pivoxil vs cefaclor in the treatment of acute otitis media in children. Drugs. 1994:21–26.
Furst G, Mann W. [Sigmoid sinus thrombosis, a therapeutic problem]. Laryngorhinootologie. 1993;72:153-157. [pmid: 8471100].
Furukawa M, Kubo N, Yamashita T. Biochemical evidence of platelet-activating factor (PAF) in human middle ear effusions. Laryngoscope. 1995;105:188-191. [pmid: 8544602].
Fuse T, Aoyagi M, Suzuki T, Koike Y. [Clinical application of transiently evoked otoacoustic emissions in screening for auditory dysfunction]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1993;96:1125-1132.
Fuse T, Tada Y, Aoyagi M, Sugai Y. CT detection of facial canal dehiscence and semicircular canal fistula: comparison with surgical findings. J Comput Assist Tomogr. 1996;20:221-224. [pmid: 8606226].
Fyllingen G, Arnesen A R, Ronnevig J. Phenoxymethylpenicillin two or three times daily in bacterial upper respiratory tract infections: a blinded, randomized and controlled clinical study. Scand-J Infect Dis. 1991;23:755-761. [pmid: 1815339].
Gacek R R. The surgical management of labyrinthine fistulae in chronic otitis media with cholesteatoma. Ann Otol Rhinol Laryngol. 1974;83:1-19. [pmid: 4812726].
Gadomski A M, Permutt T, Stanton B. Correcting respiratory rate for the presence of fever. J-Clin-Epidemiol. 1994;47:1043-1049. [pmid: 7730907].
Gadzhimirzaev GA. [Characteristics of the course of temporal lobe abscesses in patients with multiple otogenous intracranial complications]. Vestn Otorinolaringol. 1996:47–49.
Gadzhimirzaev GA, Dzhamaludinov IA. [Otogenic abscess of temporal lobe breaking into the lateral ventricle of brain with good outcome]. Vestn Otorinolaringol. 1997:54.
Gaffney R J, Walsh M. The pencil grip technique for middle ear effusion aspiration. Int J Pediatr Otorhinolaryngol. 1991;21:179-181. [pmid: 1889955].
Gahrn-Hansen B, Hornstrup M K. [Extraintestinal infections caused by Vibrio parahaemolyticus and Vibrio alginolyticus at the county of Funen 1987-1992]. Ugeskr Laeger. 1994;156:5279-5282. [pmid: 7941065].
Gaihede M, Lildholdt T, Lunding J. Sequelae of secretory otitis media: Changes in middle ear biomechanics. Acta Oto Laryngologica. 1997;117:382-389. [pmid: 9199524].
Gaillot O, Berche P. In vitro susceptibility to ciprofloxacin of bacterial strains isolated from chronic otitis media and chronic sinusitis. Drugs. 1995;49:200-202. [pmid: 8549303].
Galetti G, Martini A, Bergamini G, et al. Efficacy and tolerability of brodimoprim in bacterial otitis media in children. Controlled study versus cefaclor. J Chemother. 1993;45:283-286.
Galetti G, Martini A, Bergamini G, et al. Efficacy and tolerability of brodimoprim in bacterial otitis media in children. Controlled study versus cefaclor. J Chemother. 1993;5:551-555. [pmid: 8195856].
Gallo O, Bani D, Rucci L, Fini-Storchi O. Does the epithelium play a central role in the immune function of rhinopharyngeal tonsils? An immunocytochemical and ultrastructural study. Int J Pediatr Otorhinolaryngol. 1991;22:219-229. [pmid: 1752733].
Gamoletti R, Lanzarini P, Sanna M, Zini C. Regenerated middle ear mucosa after tympanoplasty. Part II. Scanning electron microscopy. Otolaryngol Head Neck Surg. 1986;94:430-434. [pmid: 3086802].
Gan V N, Kusmiesz H, Shelton S, Nelson J D. Comparative evaluation of loracarbef and amoxicillin-clavulanate for acute otitis media. Antimicrob-Agents-Chemother. 1991;35:967-971. [pmcid: 245137]. [pmid: 1854178].
Gan V N, McCarty J M, Chu S Y, Carr R. Penetration of clarithromycin into middle ear fluid of children with acute otitis media. Pediatr Infect Dis J. 1997;16:39-43. [pmid: 9002099].
Gananla M C M, Mangabeira Albernaz P L, Ueda H K, Silva M M. Econazol no tratamento das otites medias agudas ou cronicas reacutizadas. / Econazole in the treatment of acute or reacutized chronic otitis media. Acta-AWHO. 1984;3:67-69.
Ganbo T, Hisamatsu K, Shimomura S, Nakajima T, Inoue H, Murakami Y. Inhibition of mucociliary clearance of the eustachian tube by leukotrienes C4 and D4. Ann Otol Rhinol Laryngol. 1995;104:231-236. [pmid: 7872607].
Ganbo T, Hisamatsu K, Kikushima K, Nakajima M, Inoue H, Murakami Y. Effects of platelet activating factor on mucociliary clearance of the eustachian tube. Ann Otol Rhinol Laryngol. 1996;105:140-145. [pmid: 8659935].
Ganbo T, Sando I, Balaban C D, Suzuki C, Sudo M. Immunohistochemistry of lymphocytes and macrophages in human celloidin-embedded temporal bone sections with acute otitis media. Ann Otol Rhinol Laryngol. 1997;106:662-668. [pmid: 9270430].
Gannon M M, Jagger C, Haggard M P. Maternal blood group in otitis media with effusion. Clin Otolaryngol. 1994;19:327-331. [pmid: 7994890].
Garber L Z, Dort J C. Cholesteatoma: diagnosis and staging by CT scan. J Otolaryngol. 1994;23:121-124. [pmid: 8028069].
Garcia R D, Baker A S, Cunningham M J, Weber A L. Lateral sinus thrombosis associated with otitis media and mastoiditis in children. Pediatr Infect Dis J. 1995;14:617-623. [pmid: 7567293].
Garcia-Rodriguez J A, Garcia-Sanchez J E, Garcia-Garcia M I, Garcia-Sanchez E, Munoz-Bellido J L, Ramos-Macias A. Efficacy of topical ciprofloxacin in the treatment of ear infections in adults [letter]. J-Antimicrob-Chemother. 1993;31:452-453. [pmid: 8486586].
Garin P, Remacle M. Laser-assisted myringotomy combined with adenoidectomy in children: preliminary results. Acta Otorhinolaryngol Belg. 1999;53:105-108. [pmid: 10427362].
Garland J. “Glue ear”. N Engl J Med. 1970;282:339-340. [pmid: 5410822].
Garrard K R, Clark B S. Otitis media: the role of speech-language pathologists. ASHA. 1985;27:35-39. [pmid: 4040760].
Garred P, Brygge K, Sorensen C H, Madsen H O, Thiel S, Svejgaard A. Mannan-binding protein--levels in plasma and upper-airways secretions and frequency of genotypes in children with recurrence of otitis media. Clin Exp Immunol. 1993;94:99-104. [pmid: 8403525]. [pmcid: 1534361].
Garrett J A, Stewart J L. Hearing loss and otitis media on Guam: impact of professional services. Asia Pac J Public Health. 1989;3:213-218. [pmid: 2620022].
Garrison M W, Malone C L, Eiland J, Anderson D E. Influence of pH on the antimicrobial activity of clarithromycin and 14-hydroxyclarithromycin against Haemophilus influenzae using an in vitro pharmacodynamic model. Diagn Microbiol Infect Dis. 1997;27:139-145. [pmid: 9154410].
Garzon Calles J A. [Our experience with reconstructive surgery++ of the middle ear in tympanoplasties with mastoidectomy]. Acta Otorrinolaringol Esp. 1994;45:315-327. [pmid: 7811504].
Garzon Calles J A. [The comparative audiometric statistical study of the results obtained with plastipore or with autologous material in tympanoplasty with mastoidectomy]. Acta Otorrinolaringol Esp. 1994;45:243-248. [pmid: 7917474].
Gaskins J D, Holt R J, Kyong C U, Weart C W, Ward J. Chemoprophylaxis of recurrent otitis media using trimethoprim/sulfamethoxazole. Drug-Intell-Clin-Pharm. 1982;16:387-390. [pmid: 7084029].
Gastpar H, Smit R, Schlenter W. Rapid help for children with acute otitis media. TW Padiatrie. 1995;8:531-534.
Gastpar H, Smit R, Schlenter W. Successful treatment of childhood otitis media with the new cephalosporin cefetamet pivoxil. Therapiewoche. 1995;45:1834-1837.
Gates G A, Cooper J C Jr. Effect of anesthetic gases on middle ear pressure in the presence of effusion. Ann-Otol-Rhinol-Laryngol-Suppl. 1980;89:62-64. [pmid: 6778352].
Gates G A, Wachtendorf C A, Holt G R, Hearne E M III. History of Treated Persistent Otitis Media with Effusion. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion. 1984:346-348.
Gates G A, Wachtendorf C, Hearne E M, Holt G R. Treatment of chronic otitis media with effusion: results of tympanostomy tubes. Am J Otolaryngol. 1985;6:249-253. [pmid: 4040338].
Gates G A, Wachtendorf C, Holt G R, Hearne E M. Medical treatment of chronic otitis media with effusion (secretory otitis media). Otolaryngol Head Neck Surg. 1986;94:350-354. [pmid: 2421222].
Gates G A. Differential otomanometry. Am J Otolaryngol. 1986;7:147-150. [pmid: 3963313].
Gates G A. Otologic referral: indications and expectations. Pediatr Infect Dis. 1986;5:1-5. [pmid: 3945557].
Gates G A, Avery C, Cooper J C, Hearne E M, Holt G R. Predictive value of tympanometry in middle ear effusion. Ann Otol Rhinol Laryngol. 1986;95:46-50. [pmid: 3947003].
Gates G A, Avery C A, Prihoda T J, Cooper J C Jr. Effectiveness of adenoidectomy and tympanostomy tubes in the treatment of chronic otitis media with effusion. N Engl J Med. 1987;317:1444-1451. [pmid: 3683478].
Gates G A, Avery C A, Prihoda T J. Effect of adenoidectomy upon children with chronic otitis media with effusion. Laryngoscope. 1988;98:58-63. [pmid: 3336263].
Gates GA, Avery CA, Cooper JC, Jr., Prihoda TJ. Chronic secretory otitis media: effects of surgical management. Ann-Otol-Rhinol-Laryngol-Suppl. 1989:2–32.
Gates G A. Adenoidectomy for otitis media with effusion. Ann Otol Rhinol Laryngol Suppl. 1994;163:54-58. [pmid: 8179272].
Gates GA. The appropriateness of tympanostomy tubes for children [letter]. JAMA. 1995;273:699; discussion 700–701.
Gates G A. Sizing up the adenoid. Arch Otolaryngol Head Neck Surg. 1996;122:239-240. [pmid: 8607949].
Gates GA. Cost-effectiveness considerations in otitis media treatment. In: Lim D, Bluestone CD, Casselbrant M, Klein J, Ogra P, eds. Proceedings of the Sixth International Symposium. Fort Lauderdale, FL: B.C. Decker Inc.; 1996a:1–4.
Gates G A. Cost-effectiveness considerations in otitis media treatment. Otolaryngol Head Neck Surg. 1996b;114:525-530. [pmid: 8643261].
Gatley M S. A foreign body in the ear mimicking secretory otitis media. Practitioner. 1971;207:817-818. [pmid: 5143906].
Gaze M N, Keay D G, Smith I M, Hardcastle P F. Routine nasopharyngeal biopsy in adult secretory otitis media. Clin Otolaryngol Allied Sci. 1992;17:183-184. [pmid: 1587037].
Gebhart D E. Tympanostomy tubes in the otitis media prone child. Laryngoscope. 1981;91:849-866. [pmid: 7017311].
Gehanno P, Taillebe M, Denis P, et al. Short-course cefotaxime compared with five-day co-amoxyclav in acute otitis media in children. J-Antimicrob-Chemother. 1990:29–36.
Gehanno P, Cohen B. Effectiveness and safety of ofloxacin in chronic otitis media and chronic sinusitis in adult outpatients. Eur Arch Otorhinolaryngol. 1993;250:S13-S14. [pmid: 8476579].
Gehanno P, Berche P, Boucot I, et al. Comparative efficacy and safety of cefprozil and amoxycillin/clavulanate in the treatment of acute otitis media in children. J-Antimicrob-Chemother. 1994;33:1209-1218. [pmid: 7928814].
Gehanno P, Barry B, Bobin S, Safran C. Twice daily cefpodoxime proxetil compared with thrice daily amoxicillin/clavulanic acid for treatment of acute otitis media in children. Scand-J Infect Dis. 1994;26:577-584. [pmid: 7855555].
Gehanno P, Lenoir G, Berche P. In vivo correlates for Streptococcus pneumoniae penicillin resistance in acute otitis media. Antimicrob Agents Chemother. 1995;39:271-272. [pmcid: 162525]. [pmid: 7695322].
Gehanno P, Lenoir G, Barry B, Bons J, Boucot I, Berche P. Evaluation of nasopharyngeal cultures for bacteriologic assessment of acute otitis media in children. Pediatr Infect Dis J. 1996;15:329-332. [pmid: 8866802].
Gehanno P. Multicenter study of the efficacy and safety of oral ciprofloxacin in the treatment of chronic suppurative otitis media in adults. The French Study Group. Otolaryngol-Head-Neck-Surg. 1997;117:83-90. [pmid: 9230329].
Gehanno P, Sednaoui P, Nisse-Durgeat S. Acute otitis media in adults: A comparative study of cerotiam hexetil and amoxicillin/clavulanic acid efficacy: OTITE MOYENNE AIGUE DE L'ADULTE: ETUDE COMPARATIVE DU TRAITEMENT PAR CEFOTIAM HEXETIL VERSUS AMOXICILLINE/ACIDE CLAVULANIQUE. Medicine Et Maladies Infectieuses. 1998;28:522-528.
Gentry L R, Jacoby C G, Turski P A, Houston L W, Strother C M, Sackett J F. Cerebellopontine angle-petromastoid mass lesions: comparative study of diagnosis with MR imaging and CT. Radiology. 1987;162:513-520. [pmid: 3492010].
George J C, Caldemeyer K S, Kreipke D L, Chalian A A, Moran C C. Solitary plasmacytoma of the mastoid bone presenting as coalescent mastoiditis. Arch Otolaryngol Head Neck Surg. 1994;120:1393-1394. [pmid: 7980906].
Gersdorff M C. Comparative study between the normally hearing child and the hard of hearing child, by acoustic impedance measurements of the ear. Arch Otorhinolaryngol. 1977;217:13-31. [pmid: 578412].
Gersdorff M, Scholtes JL, Yousif A, Robillard TH. Secretory otitis media, tympanometry and general anesthesia. In: Sade J, ed. Acute and secretory otitis media. Amsterdam: Kugler publications; 1986:39–44.
Gersdorff M C. Diagnostic value of tympanometry in otitis media with effusion. Acta Otorhinolaryngol Belg. 1992;46:361-368. [pmid: 1462775].
Gersdorff M CH, Nouwen J, Decat M, Degols J C, Bosch P. Labyrinthine fistula after cholesteatomatous chronic otitis media. Am J Otol. 2000;21:32-35. [pmid: 10651432].
Geslin P, Fremaux A, Sissia G. [Epidemiology of Streptococcus pneumoniae antibiotic resistance]. Arch Pediatr. 1996;3:93s-95s. [pmid: 8745841].
Ghosh L M. Non-suppurative otitis media. J Indian Med Assoc. 1988;86:253-254. [pmid: 3235847].
Ghufoor K, Diver J, O'Flynn P. Acute on-chronic middle ear disease. International Journal of Clinical Practice. 1998;52:274-275. [pmid: 9744157].
Giamarellou H, Perdikaris G, Galanakis N, Davoulos G, Mandragos K, Sfikakis P. Pefloxacin versus ceftazidime in the treatment of a variety of gram-negative-bacterial infections. Antimicrob-Agents-Chemother. 1989;33:1362-1367. [pmcid: 172655]. [pmid: 2679374].
Giannoni C, Sulek M, Friedman E M, Duncan N O 3rd. Acquired nasopharyngeal stenosis: a warning and review. Arch Otolaryngol Head Neck Surg. 1998;124:163-167. [pmid: 9485107].
Gianoli G J, Worley N K, Guarisco J L. Pediatric tympanoplasty: the role of adenoidectomy. Otolaryngol Head Neck Surg. 1995;113:380-386. [pmid: 7567008].
Gibb A G. President's address. Tympanosclerosis. Proceedings of the Royal Society of Medicine. 1976;69:155-162. [pmid: 1265007]. [pmcid: 1864179].
Gibb A G. Long-term tympanic ventilation by Per-Lee tube. J Laryngol Otol. 1986;100:503-508. [pmid: 3701196].
Gibb A G, Tan K K, Sim R S. The Singapore swing. J Laryngol Otol. 1997;111:527-530. [pmid: 9231085].
Gibson W S Jr, Cochran W. Otalgia in infants and children--a manifestation of gastroesophageal reflux. Int J Pediatr Otorhinolaryngol. 1994;28:213-218. [pmid: 8157421].
Gibson P G, Stuart J E, Wlodarczyk J, Olson L G, Hensley M J. Nasal inflammation and chronic ear disease in Australian Aboriginal children. J-Paediatr-Child-Health. 1996;32:143-147. [pmid: 8860389].
Giebink G S, Juhn S K, Weber M L, Le C T. The bacteriology and cytology of chronic otitis media with effusion. Pediatr Infect Dis. 1982;1:98-103. [pmid: 6983682].
Giebink G S, Le C T, Paparella M M. Epidemiology of otitis media with effusion in children. Arch Otolaryngol. 1982;108:563-566. [pmid: 7202353].
Giebink G S, Batalden P B, Russ J N, Le C T. Cefaclor v amoxicillin in treatment of acute otitis media. AM-J-DIS-CHILD. 1984;138:287-292. [pmid: 6367432].
Giebink GS. Epidemiology and Natural History of Otitis Media. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:5–9.
Giebink GS, Batalden PB, Russ JN, Le CT. Cefaclor versus amoxicillin in the treatment of acute otitis media. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:287–290.
Giebink GS, Batalden PB, Le CT, et al. Randomized Controlled Trial Comparing Trimethoprim-Sulfamethoxazole, Prednisone, Ibuprofen, and No Treatment in Chronic Otitis Media with Effusion. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:240–244.
Giebink G S, Batalden P B, Le C T, Lassman F M, Buran D J, Seltz A E. A controlled trial comparing three treatments for chronic otitis media with effusion. Pediatr Infect Dis J. 1990;9:33-40. [pmid: 2405348].
Giebink G S, Daly K, Buran D J, Satz M, Ayre T. Predictors for postoperative otorrhea following tympanostomy tube insertion. Arch Otolaryngol Head Neck Surg. 1992;118:491-494. [pmid: 1571119].
Giebink G S, Koskela M, Vella P P, Harris M, Le C T. Pneumococcal capsular polysaccharide-meningococcal outer membrane protein complex conjugate vaccines: immunogenicity and efficacy in experimental pneumococcal otitis media. J Infect Dis. 1993;167:347-355. [pmid: 8421168].
Giebink G S. Immunology: promise of new vaccines. Pediatr Infect Dis J. 1994;13:1064-1068. [pmid: 7845742].
Giebink G S. Preventing otitis media. Ann Otol Rhinol Laryngol Suppl. 1994;163:20-23. [pmid: 8179264].
Giebink G S. Treatment of persistent otitis media [letter; comment]. Pediatr Infect Dis J. 1995;14:922-923. [pmid: 8584335].
Giebink G S, Meier J D, Quartey M K, Liebeler C L, Le C T. Immunogenicity and efficacy of Streptococcus pneumoniae polysaccharide-protein conjugate vaccines against homologous and heterologous serotypes in the chinchilla otitis media model. J Infect Dis. 1996;173:119-127. [pmid: 8537648].
Giebink GS, Daly KA, Lindgren B, et al. Seven-year prospective study of tympanic membrane pathology after tympanostomy tube treatment of chronic otitis media with effusion. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:380–383.
Giebink G S. Pneumococcal vaccination of children with recurrent sinusitis. Pediatr Infect Dis J. 1997;16:535-536. [pmid: 9154558].
Gil Tutor E. [Labyrinthine complications of chronic cholesteatoma in middle ear otitis]. An Otorrinolaringol Ibero Am. 1997;24:77-84. [pmid: 9199105].
Gilbert J G. Swimming and grommets: a prospective survey [see comments]. N Z Med J. 1994;107:244-245. [pmid: 7818639].
Giles M, O'Brien P. Otitis media and hearing loss in the children of the Ruatoki valley: a continuing public health problem. N Z Med J. 1989;102:160-161. [pmid: 2704462].
Giles M, O'Brien P. The prevalence of hearing impairment amongst Maori schoolchildren. Clin Otolaryngol Allied Sci. 1991;16:174-178. [pmid: 2070535].
Gill N W. Congenital atresia of the ear. A review of the surgical findings in 83 cases. J Laryngol Otol. 1969;83:551-587. [pmid: 5785652].
Gillette R. Otitis media in adults [letter; comment]. J Am Board Fam Pract. 1994;7:275-276. [pmid: 8059638].
Gimenez F, Marco-Algarra J. The prognostic value of mucociliary clearance in predicting success in tympanoplasty. J Laryngol Otol. 1993;107:895-897. [pmid: 8263384].
Gimsing S, Bergholtz L M. Audiologic screening of seven- and ten-year-old children. Scand Audiol. 1983;12:171-177. [pmid: 6685912].
Gimsing S. Gas absorption in serous otitis. A clinical aspect. Ann Otol Rhinol Laryngol. 1983;92:305-308. [pmid: 6683091].
Ginsburg C M, McCracken G H Jr, Thomas M L, Clahsen J. Comparative pharmacokinetics of amoxicillin and ampicillin in infants and children. Pediatrics. 1979;64:627-631. [pmid: 492836].
Girard A E, Cimochowski C R, Faiella J A. The comparative activity of azithromycin, macrolides and amoxycillin against streptococci in experimental infections. J Antimicrob Chemother. 1993;31:29-37. [pmid: 8396094].
Girard M. Ear disease and schizophrenia: confounding factors [letter; comment]. Acta Psychiatr Scand. 1996;93:219-220. [pmid: 8739671].
Girard A E, Cimochowski C R, Faiella J A. Correlation of increased azithromycin concentrations with phagocyte infiltration into sites of localized infection. J Antimicrob Chemother. 1996;37:9-19. [pmid: 8818842].
Givens G D, Seidemann M F. Acoustic immittance testing of the Eustachian tube. Ear Hear. 1984;5:297-299. [pmid: 6500197].
Gladstone H B, Jackler R K, Varav K. Tympanic membrane wound healing. An overview. Otolaryngol Clin North Am. 1995;28:913-932. [pmid: 8559580].
Glass R. The association of middle ear effusion and auditory learning disabilities in children. Rehabilitation Literature. 1981;42:81-85. [pmid: 7221177].
Glasscock M Ed. Pediatric otology. J Tenn Med Assoc. 1971;64:19-28. [pmid: 5539341].
Glasscock M Ed. “All that palsies is not Bell's”. Medical Times. 1974;102:78-92. [pmid: 4456133].
Glasscock M Ed. Symposium: contraindications to tympanoplasty. II. An exercise in clinical judgment. Laryngoscope. 1976;86:70-76. [pmid: 1256205].
Glasscock M Ed, Kanok M M. Tympanoplasty--a chronological history. Otolaryngol Clin North Am. 1977;10:469-477. [pmid: 337216].
Glasscock M Ed, Miller G W, Drake F D, Kanok M M. Surgery of the skull base. Laryngoscope. 1978;88:905-923. [pmid: 651507].
Glasscock M Ed, Wiet R J, Jackson C G, Dickins J R. Rehabilitation of the face following traumatic injury to the facial nerve. Laryngoscope. 1979;89:1389-1404. [pmid: 481045].
Glasscock M Ed, Dickins J R, Wiet R. Cholesteatoma in children. Laryngoscope. 1981;91:1743-1753. [pmid: 7289705].
Gliklich R E, Cunningham M J, Eavey R D. The cause of aural polyps in children. Arch Otolaryngol Head Neck Surg. 1993;119:669-671. [pmid: 8499099].
Gliklich R E, Eavey R D, Iannuzzi R A, Camacho A E. A contemporary analysis of acute mastoiditis. Arch Otolaryngol Head Neck Surg. 1996;122:135-139. [pmid: 8630206].
Going J A, Ervin D M. Otitis media: when are tubes and/or adenoidectomy needed?. Journal - South Carolina Medical Association. 1994;90:483-484. [pmid: 7990420].
Goksu N, Ataoglu H, Kemaloglu Y K, Ataoglu O, Ozsokmen D, Akyildiz N. Experimental otitis media induced by coagulase negative staphylococcus and its L-forms. Int J Pediatr Otorhinolaryngol. 1996;37:201-216. [pmid: 8905455].
Goksu N, Kemaloglu Y K, Ataoglu O, Ileri F, Hicyilmaz C. Incidental tumours during middle ear surgery. J Otolaryngol. 1996;25:195-199. [pmid: 8783086].
Goksu N, Kemaloglu Y K, Koybasioglu A, Ileri F, Ozbilen S, Akyildiz N. Clinical importance of the Korner's septum. Am J Otol. 1997;18:304-306. [pmid: 9149822].
Gold S, Kamerer D B, Hirsch B E, Cass S P. Hypercoagulability in otologic patients. Am J Otolaryngol. 1993;14:327-331. [pmid: 8238760].
Goldbart A, Yagupsky P, Markus N, Fraser D, Dagan R. Prevalence of antimicrobial resistance among pneumococcal isolates from children with otitis media in southern Israel. Pediatr Infect Dis J. 1997;16:521-523. [pmid: 9154549].
Goldberg B, Goycoolea M V, Schleivert P M, et al. Passage of albumin from the middle ear to the inner ear in otitis media in the chinchilla. Am J Otolaryngol. 1981;2:210-214. [pmid: 7283064].
Goldblatt E L, Dohar J, Nozza R J, et al. Topical ofloxacin versus systemic amoxicillin/clavulanate in purulent otorrhea in children with tympanostomy tubes. Int J Pediatr Otorhinolaryngol. 1998;46:91-101. [pmid: 10190709].
Golden J S, Johnston G D. Problems of distortion in doctor-patient communications. Psychiatry in Medicine. 1970;1:127-149. [pmid: 5524655].
Goldfarb J, Medendorp S. New therapies for otitis media [editorial]. Clin Pediatr. 1994;33:647-648.
Goldie P, Jung T T, Hellstrom S. Arachidonic acid metabolites in experimental otitis media and effects of anti-inflammatory drugs. Ann Otol Rhinol Laryngol. 1993;102:954-960. [pmid: 8285517].
Goldstein N A, Sculerati N. Compliance with prophylactic antibiotics for otitis media in a New York City clinic. Int J Pediatr Otorhinolaryngol. 1994;28:129-140. [pmid: 8157411].
Goldstein N A, Roland J T Jr, Sculerati N. Complications of tympanostomy tubes in an inner city clinic population. Int J Pediatr Otorhinolaryngol. 1996;34:87-99. [pmid: 8770676].
Goldstein N A, Casselbrant M L, Bluestone C D, Kurs-Lasky M. Intratemporal complications of acute otitis media in infants and children. Otolaryngol Head Neck Surg. 1998;119:444-454. [pmid: 9807067].
Golz A, Angel Yeger B, Parush S. Evaluation of balance disturbances in children with middle ear effusion. Int J Pediatr Otorhinolaryngol. 1998;43:21-26. [pmid: 9596366].
Golz A, Angel-Yeger B, Parush S. Evaluation of balance disturbances in children with middle ear effusion. Int J Pediatr Otorhinolaryngol. 1998;43:21-26. [pmid: 9596366].
Gomez J R, Gomez G. Comparative trial of erythromycin and tetracycline in common infections found in general practice. Br-J-Clin-Pract. 1968;22:475-477. [pmid: 4880249].
Gomez Rueda J C, Garcia Sanchez A, Povedano Rodriguez V, Madrid Sanchez C, Lopez Guerrero M. [A descriptive study of hearing in children]. Acta Otorrinolaringol Esp. 1994;45:173-176. [pmid: 8068359].
Gonzalez C, Arnold J E, Woody E A, et al. Prevention of recurrent acute otitis media: chemoprophylaxis versus tympanostomy tubes. Laryngoscope. 1986;96:1330-1334. [pmid: 3537596].
Gonzalez Sanchez M, Sanchez Munoz C, Orueta Sanchez R. [What is the treatment of choice in acute otitis media? (letter; comment)]. Aten Primaria. 1995;15:58-59. [pmid: 7646649].
Goo Y A, Hori M K, Voorhies J H Jr, Kuo C C, Wang S P, Campbell L A. Failure to detect Chlamydia pneumoniae in ear fluids from children with otitis media. Pediatr Infect Dis J. 1995;14:1000-1001. [pmid: 8584337].
Gooch W M 3d, Gan V N, Corder W T, Khurana C M, Andrews W P Jr. Clarithromycin and cefaclor suspensions in the treatment of acute otitis media in children. Pediatr Infect Dis J. 1993;12:S128-S133. [pmid: 8295814].
Gooch W M 3rd, Blair E, Puopolo A, et al. Clinical comparison of cefuroxime axetil suspension and amoxicillin/clavulanate suspension in the treatment of pediatric patients with acute otitis media with effusion. Clin-Ther. 1995;17:838-851. [pmid: 8595636].
Gooch W M 3rd, Blair E, Puopolo A, et al. Effectiveness of five days of therapy with cefuroxime axetil suspension for treatment of acute otitis media. Pediatr Infect Dis J. 1996;15:157-164. [pmid: 8822290].
Gooch W M 3rd, Philips A, Rhoades R, Rosenberg R, Schaten R, Starobin S. Comparison of the efficacy, safety and acceptability of cefixime and amoxicillin/clavulanate in acute otitis media. Pediatr Infect Dis J. 1997;16:S21-S24. [pmid: 9041624].
Gooch W M 3rd, Adelglass J, Kelsey D K, Masica D, Johns D Jr, Weinberg B C. Loracarbef versus clarithromycin in children with acute otitis media with effusion. Clin Ther. 1999;]21:711-722. [pmid: 10363736].
Goode R L, Friedrichs R, Falk S. Effect on hearing thresholds of surgical modification of the external ear. Ann Otol Rhinol Laryngol. 1977;86:441-450. [pmid: 889221].
Goodey R J, Bowers M. Antibiotic treatment of secretory otitis media assessed by impedence audiometry. N Z Med J. 1975;82:187-188. [pmid: 812030].
Goodhill V. Some crucial problems in case selection and surgical technique in tympanoplasty. Ann Otol Rhinol Laryngol. 1967;76:587-598. [pmid: 6046005].
Goodhill V. Pediatric deafness. 2. A stroll through the broad fields of otological problems in childhool. J Otolaryngolog Soc Aust. 1970;3:89-93.
Goodhill V, Dirks D, Malmquist C. Bone-conduction thresholds. Relationships of frontal and mastoid measurements in conductive hypacusis. Arch Otolaryngol. 1970;91:250-256. [pmid: 5414077].
Goodhill V, Ben H. Senturia lecture. Leaking labyrinth lesions, deafness, tinnitus and dizziness. Ann Otol Rhinol Laryngol. 1981;90:99-106. [pmid: 7224522].
Goodwin M H Jr, Shaw J R, Feldman C M. Distribution of otitis media among four Indian populations in Arizona. Public Health Rep. 1980;95:589-594. [pmid: 7433614]. [pmcid: 1422794].
Goorin A M, Hershey B J, Levin M J, et al. Use of trimethoprim-sulfamethoxazole to prevent bacterial infections in children with acute lymphoblastic leukemia. Pediatr-Infect-Dis. 1985;4:265-269. [pmid: 3889875].
Gordon N. Intermittent deafness and learning. Dev Med Child Neurol. 1986;28:364-369. [pmid: 3721080].
Gordon A G. Some comments on Bishop's annotation “Developmental dysphasia and otitis media”. J Child Psychol Psychiatry. 1988;29:361-368. [pmid: 2458371].
Gordon AG. Debate and argument: interpretation of auditory impairment and markers for brain damage in autism [comment]. J Child Psychol Psychiatry. 1993;34:587–592; discussion 593–596.
Gordon A G. Ear disease and schizophrenia--brain not needed? [letter; comment]. Acta Psychiatr Scand. 1996;93:409-411. [pmid: 8792914].
Gordts F, Clement P A, Derde M P. [Lens drain versus Donaldson drain: intermediate results of a prospective comparative study of a new versus a classical ventilation tube]. Acta-Otorhinolaryngol-Belg. 1989;43:59-65. [pmid: 2801097].
Gordts F, Clement P A, Derde M P. Lens tube vs Donaldson tube: results of a prospective study comparing a new with a conventional ventilation tube. Clin Otolaryngol. 1993;18:410-414. [pmid: 8877210].
Gosain A K, Conley S F, Marks S, Larson D L. Submucous cleft palate: diagnostic methods and outcomes of surgical treatment. Plast Reconstr Surg. 1996;97:1497-1509. [pmid: 8643740].
Gotay-Rodriguez V M, Schuknecht H F. Experiences with type IV tympanomastoidectomy. Laryngoscope. 1977;87:522-528. [pmid: 839940].
Gothamy B, Fujita S, Hayden R C Jr. Rhabdomyosarcoma--a temporal bone report. Arch Otolaryngol. 1973;98:106-111. [pmid: 4541877].
Gottlieb M I, Zinkus P W, Thompson A. Chronic middle ear disease and auditory perceptual deficits: is there a link?. Clin Pediatr. 1979;18:725-732.
Gottschalk G H. Nonsurgical management of otitis media with effusion. Ann Otol Rhinol Laryngol Suppl. 1980;89:301-302. [pmid: 6778332].
Gould H J, Caldarelli D D. Hearing and otopathology in Apert syndrome. Arch Otolaryngol. 1982;108:347-349. [pmid: 7201310].
Govender D, Naidoo K, Chetty R. Granuloma inguinale (donovanosis): an unusual cause of otitis media and mastoiditis in children. Am J Clin Pathol. 1997;108:510-514. [pmid: 9353089].
Goycoolea M V, Paparella M M, Muchow D. Mastoidotomy tympanotomy approach for cochlear implantation. Laryngoscope. 1987;97:766-771. [pmid: 3586826].
Goycoolea M V, Muchow D C. Sustained release of antimicrobials in the middle ear using a biodegradable support. Ann Otol Rhinol Laryngol Suppl. 1994;163:46-48. [pmid: 8179270].
Goycoolea M V. Oval and round window membrane changes in otitis media in the human. An ultrastructural study. Acta Otolaryngol. 1995;115:282-285. [pmid: 7610823].
Grace A R, Pfleiderer A G. Dysequilibrium and otitis media with effusion: what is the association?. J Laryngol Otol. 1990;104:682-684. [pmid: 2230572].
Grafstein E, Fernandes C M, Samoyloff S. Lateral sinus thrombosis complicating mastoiditis. Ann Emerg Med. 1995;25:420-423. [pmid: 7864487].
Graham M D. Surgical exposure of the facial nerve indications and techniques. J Laryngol Otol. 1975;89:557-575. [pmid: 1141751].
Graham M D, Kemink J L. Surgical management of Meniere's disease with endolymphatic sac decompression by wide bony decompression of the posterior fossa dura: technique and results. Laryngoscope. 1984;94:680-683. [pmid: 6717227].
Graham J M, East C A, Fraser J G. UCH/RNID single channel cochlear implant: surgical technique. Journal of Laryngology and Otology - Supplement. 1989;18:14-19.
Grant H R, Quiney R E, Mercer D M, Lodge S. Cleft palate and glue ear. Arch-Dis-Child. 1988;63:176-179. [pmid: 3348665].
Grasl M, Welleschik B. Functional results of middle-ear ventilation tubes in cases of chronic seromuco-tympanum (SMT). Observations covering a period of up to two years after the operation. Laryngol Rhinol Otol. 1983;62:394-401.
Gravel J S, McCarton C M, Ruben R J. Otitis media in neonatal intensive care unit graduates: a 1-year prospective study. Pediatrics. 1988;82:44-49. [pmid: 3380599].
Gravel J S, Wallace I F. Listening and language at 4 years of age: effects of early otitis media. J Speech Hear Res. 1992;35:588-595. [pmid: 1608250].
Gravel JS, Wallace IF, Ruben RJ. Auditory capabilities of preschoolers with and without a history of otitis media. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:543–545.
Gravel J S, Wallace I F, Ruben R J. Early otitis media and later educational risk. Acta Otolaryngol. 1995;115:279-281. [pmid: 7610822].
Gravel J S, Ellis M A. Examining the auditory consequences of otitis media with effusion: the audiogram and beyond. Semin Hear. 1995;16:44-59.
Gravel JS. Hearing and auditory sequelae. In: Lim DJ, Bluestone CD, Casselbrant M, Klein JO, Ogra PL, eds. Proceedings of the Sixth International Symposium on Recent Advances in Otitis Media. Hamilton: BC Decker; 1995:30–32.
Gravel JS, Wallace IF, Ellis MA, Lee WW, Mody M, Ruben RJ. Higher-order auditory abilities at nine years of age and early otitis media. In: Lim DJ, Bluestone CD, Casselbrant M, Klein JO, Ogran PL, eds. Proceedings of the Sixth International Symposium on Recent Advances in Otitis Media. Hamilton: BC Decker; 1995.
Gravel J S, Wallace I F, Ruben R J. Auditory consequences of early mild hearing loss associated with otitis media. Acta Otolaryngol. 1996;116:219-221. [pmid: 8725518].
Gravel JS, Wallace IF, Ellis MA, Lee WW, Mody M, Ruben RJ. Higher-order auditory abilities at nine years of age and early otitis media. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:356–358.
Gravel JS, Nozza RJ. Hearing loss among children with otitis media with effusion. In: Roberts JE, Wallace IF, Henderson FW, eds. Otitis media in young children. Baltimore (MD): Paul H. Brookes Publishing Co; 1997:63–92.
Gravel J S, Wallace I F. Language, speech, and educational outcomes of otitis media. J Otolaryngol. 1998;27:17-25. [pmid: 9800636].
Gravel J S, Wallace I F. Effects of otitis media with effusion on hearing in the first 3 years of life. J Sp Lang Hear Res. 2000;43:631-644.
Gray B M. Immune globulin administration as an approach to prevention of acute otitis media [editorial; comment]. J Pediatr. 1993;123:739-741. [pmid: 8229482].
Gray R F, Irving R M. Cochlear implants in chronic suppurative otitis media. Am J Otol. 1995;16:682-686. [pmid: 8588677].
Green S M, Rothrock S G. Single-dose intramuscular ceftriaxone for acute otitis media in children [see comments]. Pediatrics. 1993;91:23-30. [pmid: 8416502].
Green B A, Vazquez M E, Zlotnick G W, et al. Evaluation of mixtures of purified Haemophilus influenzae outer membrane proteins in protection against challenge with nontypeable H. influenzae in the chinchilla otitis media model. Infect Immun. 1993;61:1950-1957. [pmcid: 280788]. [pmid: 8478084].
Green S M, Rothrock S G, Nesper T P, Hummel C B. Outcome of acute otitis media with abnormal tympanometric patterns in children. Acad Emerg Med. 1994;1:346-353. [pmid: 7614280].
Green B A, Doyle W J, Cowell J L. Chinchilla model of experimental otitis media for study of nontypable Haemophilus influenzae vaccine efficacy. Methods Enzymol. 1994;235:59-68. [pmid: 8057928].
Green K M, de Carpentier J P, Curley J W. An unusual complication of T-tubes. J Laryngol Otol. 1997;111:282-283. [pmid: 9156070].
Greenfield B J, Selesnick S H, Fisher L, Ward R F, Kimmelman C P, Harrison W G. Aural tuberculosis. Am J Otol. 1995;16:175-182. [pmid: 8572117].
Greenstone M, Rutman A, Dewar A, Mackay I, Cole P J. Primary ciliary dyskinesia: cytological and clinical features. Quarterly Journal of Medicine. 1988;67:405-423. [pmid: 2975807].
Gregg J B, Roberts K M, Colleran M J. Ear disease and hearing loss, Pierre, South Dakota, 1962–1982. S D J Med. 1983;36:9-17. [pmid: 6580741].
Greval R S, Ram S. Bacteriological patterns of chronic suppurative otitis media in Ludhiana. Indian J Med Sci. 1996;50:192-195. [pmid: 8979528].
Greville K A, Keith W J, Laven J W. Performance of children with previous OME on central auditory measures. Australian Journal of Audiology. 1985;7:69-78.
Greville A. Preschool ear screening [letter]. N Z Med J. 1995;108:44. [pmid: 7891940].
Grewal D S, Baser B, Shahani R N, Khanna S. Tuberculous otitis media presenting as complications: report of 18 cases. Auris Nasus Larynx. 1991;18:199-208. [pmid: 1799326].
Grewal D S, Bhargava P, Mistry B, Gaikwad N. Tuberculoma of the mastoid. J Laryngol Otol. 1995;109:232-235. [pmid: 7745342].
Grievink E H, Peters S A, van Bon W H, Schilder A G. The effects of early bilateral otitis media with effusion on language ability: a prospective cohort study. J Speech Hear Res. 1993;36:1004-1012. [pmid: 8246466].
Griffith T E. Epidemiology of otitis media--an interracial study. Laryngoscope. 1979;89:22-30. [pmid: 423650].
Grimaldi P M. The value of impedance testing in diagnosis of middle ear effusion. J Laryngol Otol. 1976;90:141-152. [pmid: 1249493].
Groenen P, Crul T, Maassen B, van Bon W. Perception of voicing cues by children with early otitis media with and without language impairment. J Speech Hear Res. 1996;39:43-54. [pmid: 8820698].
Groeneveld P H, Visser H J, de Groot R, Bosboom R. [Post-pharyngitis sepsis caused by Fusobacterium necrophorum: Lemierre's syndrome (letter; comment)]. Ned Tijdschr Geneeskd. 1993;137:1526. [pmid: 8366943].
Grol R, Thomas S, Roberts R. Development and implementation of guidelines for family practice: lessons from The Netherlands [editorial]. J Fam Pract. 1995;40:435-439. [pmid: 7730766].
Groothuis J R, Sell S H, Wright P F, Thompson J M, Altemeier W Ad. Otitis media in infancy: tympanometric findings. Pediatrics. 1979;63:435-442. [pmid: 571598].
Grossan M. Children who have had a complete and adequate adenoidectomy [letter; comment]. Ear Nose Throat J. 1995;74:128.
Grossman D. The appropriateness of tympanostomy tubes for children [letter; comment]. JAMA. 1995;273:699; discussion 700–1.
Grosso P, Rupp R R. Pure-tone and tympanometric screening: an ideal pair in identification audiometry. Journal of the American Audiology Society. 1978;4:11-15. [pmid: 721666].
Grote J J, Kuijpers W. Middle ear effusion and sinusitis. J Laryngol Otol. 1980;94:177-183. [pmid: 7373122].
Grote J J. Reconstruction of the middle ear with hydroxylapatite implants: long-term results. Ann Otol Rhinol Laryngol Suppl. 1990;144:12-16. [pmid: 2154156].
Grote J J, Hesseling S C, Tjebbes G J, van Blitterswijk C A. Effect of HA-1A monoclonal IgM antibody on endotoxin-induced proliferation of cultured rat middle ear epithelium. Ann Otol Rhinol Laryngol. 1995;104:226-230. [pmid: 7872606].
Grote J J. [Antibiotics in otitis media with effusion (see comments)]. Ned Tijdschr Geneeskd. 1997;141:76-77. [pmid: 9036349].
Gruber W C, Belshe R B, King J C, et al. Evaluation of live attenuated influenza vaccines in children 6–18 months of age: Safety, immunogenicity, and efficacy. J Infect Dis. 1996;173:1313-1319. [pmid: 8648202].
Grundfast K M. Management of otitis media: a controversial issue [comment]. Pediatr Infect Dis J. 1991;10:269-274. [pmid: 2062622].
Grundfast K M. Management of otitis media and the New Agency for Health Care Policy and Research Guideline. Arch Otolaryngol Head Neck Surg. 1994;120:797-798. [pmid: 8049038].
Grundfast KM. The appropriateness of tympanostomy tubes for children [letter; comment]. JAMA. 1995;273:699–700; discussion 700–701.
Gryczynska D, Powajbo K. Clinical results of cefuroxime axetil therapy for acute otitis media in children. Pediatr Pol. 1999;74:569-571.
Guay D R, Craft J C. Overview of the pharmacology of clarithromycin suspension in children and a comparison with that in adults. Pediatr Infect Dis J. 1993;12:S106-S111. [pmid: 8295810].
Gubas J, Sente M, Zomborcevic S, Takacs K, Ivkic M, Berkes B. [Personal experience with the occurrence of pediatric otitis of allergic etiology in the North Backa Region]. Med Pregl. 1993;46:133-136. [pmid: 7862048].
Guerrier T H. Open cavity mastoidectomy in children. Hearing results at 5 years. Adv Otorhinolaryngol. 1988;40:138-141. [pmid: 3389226].
Gulya A J. Environmental tobacco smoke and otitis media. Otolaryngol Head Neck Surg. 1994;111:6-8. [pmid: 8028944].
Gundersen T, Gluck E. The middle ear mucosa in serous otitis media. Arch Otolaryngol. 1972;96:40-44. [pmid: 4113348].
Gundersen T, Tonning F M. Ventilating tubes in the middle ear. Arch Otolaryngol. 1976;102:198-199. [pmid: 1267702].
Gundersen T, Tonning F M, Kveberg K H. Ventilating tubes in the middle ear. Long-term observations. Arch Otolaryngol. 1984;110:783-784. [pmid: 6542349].
Gunnarson A D, Finitzo T. Conductive hearing loss in infancy: effects on later auditory brainstem electrophysiology. J Speech Hear Res. 1991;34:1207-1215. [pmid: 1749250].
Guo Y, Wu Y, Chen W, Lin J. Endotoxic damage to the stria vascularis: the pathogenesis of sensorineural hearing loss secondary to otitis media?. J Laryngol Otol. 1994;108:310-313. [pmid: 8182316].
Gupta A K, Nagarkar N M, Mann S B, Gupta S K. Bilateral otogenic temporal lobe and post-aural abscesses. J Laryngol Otol. 1997;111:284-285. [pmid: 9156071].
Gutierrez E, Cuervo E. Efficiency and safety of sultamicillin compared with cefaclor in the treatment of acute otitis media in children. International Pediatrics. 1996;11:38-40.
Gutman LT, Wilfert CM, Idriss ZH, Schmidt E, Andrews S, Katz SL. Single-dose trials of monovalent A/New Jersey/76 (Hsw1N1) influenza virus vaccine in children in Durham, North Carolina. J Infect Dis. 1977:S575–S578.
Guttenplan M D, Tom L W, DeVito M A, Handler S D, Wetmore R F, Potsic W P. Radial versus circumferential incision in myringotomy and tube placement. Int J Pediatr Otorhinolaryngol. 1991;21:211-215. [pmid: 1869374].
Gyde M C. When the weeping stopped: an otologist views otorrhea and gentamicin. Arch Otolaryngol. 1976;102:542-546. [pmid: 962698].
Gyde M C, Randall R F. [Double-blind comparative study of trimethroprim-sulphacetamide-polymyxin b and gentamicin in the treatment of otorrhoea (author's transl)]. Ann-Otolaryngol-Chir-Cervicofac. 1978;95:43-55. [pmid: 207210].
Gyde M C. A double-blind comparative study of trimethoprim-polymyxin B versus trimethoprim-sulfacetamide-polymyxin B otic solutions in the treatment of otorrhea. J Laryngol Otol. 1981;95:251-259. [pmid: 6257815].
Gyde M C. A double-blind comparative study of trimethoprim-polymyxin B versus trimethoprin-sulfacetamide-polymixin B otic solutions in the treatment of otorrhea. J LARYNGOL OTOL. 1981;95:251-259. [pmid: 6257815].
Gyde M C. [Double-blind comparative trial of trimethoprim-polymyxin B and trimethoprim-sulphacetamide-polymyxin B ear drops in the treatment of otorrhoea (author's transl)]. Ann-Otolaryngol-Chir-Cervicofac. 1981;98:37-40. [pmid: 6269476].
Gyde M C, Norris D, Kavalec E C. The weeping ear: clinical re-evaluation of treatment. J Int Med Res. 1982;10:333-340. [pmid: 6754505].
Gyo K, Goode R L, Miller C. Effect of middle ear modification on umbo vibration. Human temporal bone experiments with a new vibration measuring system. Arch Otolaryngol Head Neck Surg. 1986;112:1262-1268. [pmid: 3768150].
Gyo K, Jyokou H, Komori M, Zenke K. A case of acquired petrous cholesteatoma associated with insidious middle ear infection treated by staging the surgical procedures. Auris Nasus Larynx. 1995;22:192-196. [pmid: 8561701].
Gyo K, Sasaki Y, Yumoto E, Yanagihara N. Residual bacterial infection in the tympanic cavity following surgery for ears with chronic discharge. Auris Nasus Larynx. 1996;23:13-19. [pmid: 8809318].
H.C. P, Drake AF, Hall JW, Grose JH. The masking-level difference in children having a history of otitis media with effusion. Arch Otolaryngol. 1991;117:718–723.
Haapaniemi J J. Pure-tone audiometric and impedance measurements in school-aged children in Finland. Eur Arch Otorhinolaryngol. 1997;254:269-273. [pmid: 9248733].
Haberkamp T J, Tanyeri H. Surgical techniques to facilitate endoscopic second-look mastoidectomy. Laryngoscope. 1999;109:1023-1027. [pmid: 10401834].
Habib M A. Non-suppurative otitis media in children. (A retrospective study of 100 cases). J Laryngol Otol. 1979;93:129-133. [pmid: 429896].
Haddad J Jr. Treatment of acute otitis media and its complications. Otolaryngol Clin North Am. 1994;27:431-441. [pmid: 8065751].
Haddad J Jr, Gonzalez C, Kurland G, Orenstein D M, Casselbrant M L. Ear disease in children with cystic fibrosis. Arch Otolaryngol Head Neck Surg. 1994;120:491-493. [pmid: 8172699].
Hadfield P J, Shah B K, Glover G W. Facial palsy due to tuberculosis: the value of CT. J Laryngol Otol. 1995;109:1010-1012. [pmid: 7499936].
Hadfield P J, Rowe-Jones J M, Bush A, Mackay I S. Treatment of otitis media with effusion in children with primary ciliary dyskinesia. Clin Otolaryngol Allied Sci. 1997;22:302-306. [pmid: 9298603].
Hafner H, Anteby I, Pratt H, Goldsher M, Shenhav R, Joachims H Z. Auditory brainstem evoked potentials in evaluating the efficacy of surgical ventilation of the middle ear. Int J Pediatr Otorhinolaryngol. 1986;12:13-22. [pmid: 3818186].
Hagan W E, Tabb H G, Cox R H, Travis L W. Gunshot injury to the temporal bone: an analysis of thirty-five cases. Laryngoscope. 1979;89:1258-1272. [pmid: 459659].
Hagerman R J, Altshul-Stark D, McBogg P. Recurrent otitis media in the fragile X syndrome. Am J Dis Child. 1987;141:184-187. [pmid: 3812386].
Haggard M P. Hearing as a community health problem. Br Med Bull. 1027;43:1027-1037. [pmid: 3329924].
Haggard M P. Population studies into hearing disorders. Implications for general practice. Practitioner. 1983;227:1043-1049. [pmid: 6889260].
Haggard M P, McCormick B, Gannon M M, Spencer H. The paediatric otological caseload resulting from improved screening in the first year of life. Clin Otolaryngol Allied Sci. 1992;17:34-43. [pmid: 1555316].
Haggard MP, Lim MJ, Smith D, Fantini DA. Long-term OME sequelae in binaural hearing. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:546–549.
Haggard MP, Birkin JA, Browning GG, Gatehouse S, Lewis S. Behavior problems in otitis media. Pediatr Infect Dis J. 1994;13:S43–S50; discussion S50–54.
Haggard M P. Commentary: reduced confusion over ear effusion? [comment]. Br Med J. 1997;314:354. [pmid: 9040333].
Haines S T, Kraynak M A. Twice-daily cefaclor therapy. Ann Pharmacother. 1994;28:1353-1355. [pmid: 7696725].
Hakansson B, Liden G, Tjellstrom A, et al. Ten years of experience with the Swedish bone-anchored hearing system. Ann Otol Rhinol Laryngol Suppl. 1990;151:1-16. [pmid: 2121086].
Hakansson B, Tjellstrom A, Carlsson P. Percutaneous vs. transcutaneous transducers for hearing by direct bone conduction. Otolaryngol Head Neck Surg. 1990;102:339-344. [pmcid: 158786].
Halama A R, Voogt G R, Musgrave G M. Prevalence of otitis media in children in a black rural community in Venda (South Africa). Int J Pediatr Otorhinolaryngol. 1986;11:73-77. [pmid: 3710702].
Hall L J, Asuncion J, Lukat M. Allergy skin testing under general anesthesia with treatment response in ninety-two patients with chronic serous otitis media. Am J Otol. 1980;2:150-157. [pmid: 7193979].
Hall L J. Chronic serous otitis media. J Ky Med Assoc. 1981;79:73-77. [pmid: 6974210].
Hall D M, Hill P. When does secretory otitis media affect language development?. Arch Dis Child. 1986;61:42-47. [pmid: 3954418].
Hall J W, Derlacki E D. Binaural hearing after middle-ear surgery. J Otol Rhinol Laryngol. 1986;95:118-124.
Hall J W, Grose J H, Pillsbury H C. Predicting binaural hearing after stapedectomy from pre-surgery results. Arch Otolaryngol. 1990;116:946-950.
Hall J W, Grose J H. The effect of otitis media with effusion on the masking-level difference and the auditory brainstem response. J Speech Hear Res. 1993;36:210-217. [pmid: 8450661].
Hall P J, Farrior J B. Aspergillus mastoiditis. Otolaryngol Head Neck Surg. 1993;108:167-170. [pmid: 8441542].
Hall J W, Grose J H. Effect of otitis media with effusion on comodulation masking release in children. J Speech Hear Res. 1994;37:1441-1449. [pmid: 7877299].
Hall J W 3rd, Grose J H, Pillsbury H C. Long-term effects of chronic otitis media on binaural hearing in children. Arch Otolaryngol Head Neck Surg. 1995;121:847-852. [pmid: 7619408].
Hall D. ‘Otitis media with effusion’ [letter; comment]. Dev Med Child Neurol. 1997;39:280. [pmid: 9183271].
Hall MJ, Lawrence L. Ambulatory surgery in the Unites States, 1995. Advance data from vital and health statistics; no 296 Hyattsville (MD): National Center for Health Statistics; 1997.
Hall J W 3rd, Grose J H, Dev M B, Ghiassi S. The effect of masker interaural time delay on the masking level difference in children with history of normal hearing or history of otitis media with effusion. Ear Hear. 1998;19:429-433. [pmid: 9867291].
Hall J W 3rd, Grose J H, Dev M B, Drake A F, Pillsbury H C. The effect of otitis media with effusion on complex masking tasks in children. Arch Otolaryngol Head Neck Surg. 1998;124:892-896. [pmid: 9708715].
Hallmo P, Mair I W. Drilling in ear surgery. A comparison of pre- and postoperative bone-conduction thresholds in both the conventional and extended high-frequency ranges. Scand Audiol. 1996;25:35-38. [pmid: 8658024].
Halsted C, Lepow M L, Balassanian N, Emmerich J, Wolinsky E. Otitis media: microbiology and evaluation of therapy. Ann-N-Y-Acad-Sci. 1967;145:372-378. [pmid: 4397881].
Halsted C, Lepow M L, Balassanian N, Emmerich J, Wolinsky E. Otitis media. Clinical observations, microbiology, and evaluation of therapy. Am-J-Dis-Child. 1968;115:542-551. [pmid: 4384577].
Hamada E, Iwano T, Ushiro K, Tada N, Kinoshita T, Kumazawa T. Animal model of otitis media with effusion. Acta Oto-Laryngologica - Supplement. 1993;500:70-74.
Hamaguchi F, Hamaguchi Y, Juhn S K, Sakakura Y. The relationship between antigen levels and middle ear inflammation in antigen-induced otitis media in the chinchilla. Arch Otorhinolaryngol. 1988;245:42-46. [pmid: 3390068].
Hamaguchi Y, Sakakura Y. Neutrophil elastase and its complex with alpha 1-antitrypsin in the pathogenesis of chronic suppurative otitis media. Ann Otol Rhinol Laryngol Suppl. 1992;157:26-31. [pmid: 1416649].
Hamilton M A, McKenzie-Pollock M, Heath M E. Aural health in 227 Northland school and preschool children. N Z Med J. 1980;91:59-62. [pmid: 6929441].
Hampal S, Flood L M, Kumar B U. The mini-grommet and tympanosclerosis. J Laryngol Otol. 1991;105:161-164. [pmid: 2019798].
Hampton S M, Adams D A. Perforation rates after ventilation tube insertion: does the positioning of the tube matter?. Clin-Otolaryngol. 1996;21:548-549. [pmid: 9118580].
Hamrick H J, Garfunkel J M. Therapy for acute otitis media: applicability of metaanalysis to the individual patient [editorial; comment]. J Pediatr. 1994;124:431. [pmid: 8120714].
Hanafee W N, Wilson G H. Pontocerebellar angle tumors. Newer diagnostic methods. Arch Otolaryngol. 1970;92:236-243. [pmid: 5313297].
Hanafee W N, Gussen R, Rand R W. Laminography of the mastoid in the basal projection. American Journal of Roentgenology, Radium Therapy and Nuclear Medicine. 1970;110:111-118.
Handa J, Yamamoto I, Morita R, Kousaka T, Fujita T, Handa H. 99mTc-polyphosphate and 99mTc-diphosphonate bone scintigraphy in neurosurgical practice. Surg Neurol. 1974;2:307-310. [pmid: 4528122].
Handler S D, Potsic W P, Marsh R R. A trial of Biolite ventilation tubes in children: Is further use warranted?. Otolaryngology and Head and Neck Surgery. 1983;91:437-440.
Handler SD. Adenoidectomy for secretory otitis media (I). Arch Otolaryngol Head and Neck Surgery. 1990;116.
Handler S D. Current indications for tympanostomy tubes. Am J Otolaryngol. 1994;15:103-108. [pmid: 8179100].
Handzic J, Bagatin M, Subotic R, Cuk V. Hearing levels in Pierre Robin syndrome. Cleft Palate Craniofac J. 1995;32:30-36. [pmid: 7727485].
Hanson M S, Lapcevich C V, Haun S L. Progress on development of the live BCG recombinant vaccine vehicle for combined vaccine delivery. Ann N Y Acad Sci. 1995;754:214-221. [pmid: 7625654].
Hanson M J. Acute otitis media in children. Nurse Pract. 1996;21:72-74, 80. [pmid: 8734627].
Hanson M J. Otitis media with effusion. Lippincotts Primary Care Practice. 1997;1:168-171.
Harabuchi Y, Faden H, Yamanaka N, Duffy L, Wolf J, Krystofik D. Nasopharyngeal colonization with nontypeable Haemophilus influenzae and recurrent otitis media. Tonawanda/Williamsville Pediatrics. J Infect Dis. 1994;170:862-866. [pmid: 7930728].
Harabuchi Y, Faden H, Yamanaka N, Duffy L, Wolf J, Krystofik D. Human milk secretory IgA antibody to nontypeable Haemophilus influenzae: possible protective effects against nasopharyngeal colonization. J Pediatr. 1994;124:193-198. [pmid: 8301421].
Harabuchi Y, Hamamoto M, Kodama H, Kataura A. Spontaneous immunoglobulin production by adenoidal and tonsillar lymphocytes in relation to age and otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1996;35:117-125. [pmid: 8735408].
Harabuchi Y, Murakata H, Goh M, et al. Serum antibodies specific to CD outer membrane protein of Moraxella catarrhalis, P6 outer membrane protein of non-typeable Haemophilus influenzae and capsular polysaccharides of Streptococcus pneumoniae in children with otitis media with effusion. Acta Otolaryngol. 1998;118:826-832. [pmid: 9870628].
Harada T, Yamasoba T, Yagi M. Sensorineural hearing loss associated with otitis media with effusion. ORL J Otorhinolaryngol Relat Spec. 1992;54:61-65. [pmid: 1614686].
Harakeh H, Bosley G S, Keihlbauch J A, Fields B S. Heterogeneity of rRNA gene restriction patterns of multiresistant serotype 6B Streptococcus pneumoniae strains. J Clin Microbiol. 1994;32:3046-3048. [pmcid: 264224]. [pmid: 7533781].
Harbert F, Young I M. The low frequency air-bone gap in sensorineural deafness. Ann Otol Rhinol Laryngol. 1969;78:107-111. [pmid: 5763179].
Harbert F, Young I M, Menduke H. Audiologic findings in serous otitis media. Eye, Ear, Nose and Throat Monthly. 1970;49:409-411.
Harder H, Arlinger S. Ear-canal compared to mastoid electrode placement in BRA. Scand Audiol Suppl. 1981;13:55-57. [pmid: 6944778].
Hardjasudarma M, Edwards R L, Ganley J P, Aarstad R F. Magnetic resonance imaging features of Gradenigo's syndrome. Am J Otolaryngol. 1995;16:247-250. [pmid: 7573745].
Hardy A M, Fowler M G. Child care arrangements and repeated ear infections in young children [see comments]. Am J Public Health. 1993;83:1321-1325. [pmid: 8363010]. [pmcid: 1694997].
Harell M, Shea J J. Hazards of ventilation tubes. Adv Otorhinolaryngol. 1978;23:22-28. [pmid: 622914].
Hariri M A. Sensorineural hearing loss in bullous myringitis. A prospective study of eighteen patients. Clin Otolaryngol Allied Sci. 1990;15:351-353. [pmid: 2225506].
Harker L A, Van Wagoner R. Application of impedance audiometry as a screening instrument. Acta Otolaryngol. 1974;77:198-201. [pmid: 4819032].
Harkness P, Brown P, Fowler S, Grant H, Ryan R, Topham J. Mastoidectomy audit: results of the Royal College of surgeons of England comparative audit of ENT surgery. Clin Otolaryngol Allied Sci. 1995;20:89-94. [pmid: 7788943].
Harley EH. 7th Annual meeting of the American Society of Pediatric Otolaryngology, April 14 and 15, 1992, Palm Desert, Calif. Arch Otolaryngol Head and Neck Surgery. 1992;118.
Harley E H, Sdralis T, Berkowitz R G. Acute mastoiditis in children: a 12-year retrospective study. Otolaryngol Head Neck Surg. 1997;116:26-30. [pmid: 9018253].
Harris I, Barton S, Gussen R, Goodhill V. Gelfilm-induced neotympanic membrane in tympanoplasty. Laryngoscope. 1971;81:1826-1837. [pmid: 5000737].
Harris J P, Keithley E M. Inner ear inflammation and round window otosclerosis. Am J Otol. 1993;14:109-112. [pmid: 8503480].
Harrison C J, Hedrick J A, Block S L, Gilchrist M J. Relation of the outcome of conjunctivitis and the conjunctivitis-otitis syndrome to identifiable risk factors and oral antimicrobial therapy. Pediatr Infect Dis J. 1987;6:536-540. [pmid: 3497379].
Harrison C J, Chartrand S A, Pichichero M E. Microbiologic and clinical aspects of a trial of once daily cefixime compared with twice daily cefaclor for treatment of acute otitis media in infants and children. Pediatr Infect Dis J. 1993;12:62-69. [pmid: 8417428].
Harrison H C, Jacobson I, Havas T E. Otitis media in general practice [letter; comment]. Med J Aust. 1994;160:584. [pmid: 8018164].
Harrison C J. Rational selection of antimicrobials for pediatric upper respiratory infections. Pediatr Infect Dis J. 1995;14:S121-S129. [pmid: 7567312].
Harrison C J. The other effect of intravenously administered respiratory syncytial virus-enriched immune globulin for prophylaxis: less acute otitis media [editorial; comment]. J Pediatr. 1996;129:193-196. [pmid: 8765615].
Harrison C J, Chartrand S A, Rodriguez W, et al. Middle ear effusion concentrations of cefixime during acute otitis media with effusion and otitis media with effusion. Pediatr Infect Dis J. 1997;16:816-817. [pmid: 9271047].
Harrison C J. Using antibiotic concentrations in middle ear fluid to predict potential clinical efficacy. Pediatr Infect Dis J. 1997;16:S12-S16. [pmid: 9041622].
Harrison H, Fixsen A, Vickers A. A randomized comparison of homoeopathic and standard care for the treatment of glue ear in children. Complementary Therapies in Medicine. 1999;7:132-135. [pmid: 10581822].
Harsten G, Nettelbladt U, Schalen L, Kalm O, Prellner K. Language development in children with recurrent acute otitis media during the first three years of life. Follow-up study from birth to seven years of age. J Laryngol Otol. 1993;107:407-412. [pmid: 8326219].
Hartley C, Saeed S R, Lyons T J. Non-cholesteatomatous suppurative otitis media: facial nerve palsy in an immunocompromised patient. J Laryngol Otol. 1995;109:755-758. [pmid: 7561501].
Hartwein J, Leuwer R M, Kehrl W. The total reconstruction of the tympanic membrane by the “crowncork” technique. Am J Otolaryngol. 1992;13:172-175. [pmid: 1626618].
Harvey R M. Deafness in children. 3. Treatment. Nursing Times. 1968;64:1694-1695. [pmid: 5705603].
Harvey S A, Paparella M M, Sperling N M, Alleva M. The flexible (conservative surgical) approach for chronic otitis media in young children. Laryngoscope. 1992;102:1399-1403. [pmid: 1453851].
Harvey S A, Fox M C. Relevant issues in revision canal-wall-down mastoidectomy. Otolaryngol Head Neck Surg. 1999;121:18-22. [pmid: 10388870].
Harvey S A, Lin S Y. Double cartilage block ossiculoplasty in chronic ear surgery. Laryngoscope. 1999;109:911-914. [pmid: 10369281].
Harwood-Nash D C. The radiology of rhabdomyosarcomas of the middle ear with intracranial extension in children. Clin Radiol. 1971;22:321-329. [pmid: 5314770].
Hasenstab MS. Auditory processing and cognitive performance of five- and six-year-old children with recurrent otitis media with effusion. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:549–551.
Hashash M, Attallah M, Joharjy I. The “temporocele”. J Otolaryngol. 1995;24:370-374. [pmid: 8699606].
Hashiguchi K, Ogawa H, Koga K, Tateno H, Yamazaki Y. Otitis media with effusion associated with Chlamydia trachomatis infection in children. Auris Nasus Larynx. 1990;17:149-155. [pmid: 2278524].
Hassel D M, Schott H C, 2nd, Tucker R L, Hines M T. Endoscopy of the auditory tube diverticula in four horses with otitis media/interna. J Am Vet Med Assoc. 1995;207:1081-1084. [pmid: 7559051].
Hatanaka E. Results of treatment with large ventilating tubes and grommet tubes in children with middle ear effusion. Otolaryngology. 1983;55:915-919.
Hatcher J, Smith A, Mackenzie I, et al. A prevalence study of ear problems in school children in Kiambu district, Kenya, May 1992. Int J Pediatr Otorhinolaryngol. 1995;33:197-205. [pmid: 8557476].
Hathaway T J, Katz H P, Dershewitz R A, Marx T J. Acute otitis media: who needs posttreatment follow-up?. Pediatrics. 1994;94:143-147. [pmid: 8036064].
Hatrick A G, Howlett D C, Cox T C S. Funny turns. Br J Radiol. 1998;71:895-896. [pmid: 9828808].
Hattori T. [3D-CT of the temporal bone area with high-speed processing]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1994;97:2233-2238.
Hattori Y. [Otitis media with effusion in children]. Nippon Ika Daigaku Zasshi - Journal of the Nippon Medical School. 1994;61:160-163.
Haugeto OK, Elverland HH, Schroder KE, Mair IWS. Chronic secretory otitis media. Tidsskr Nor Laegeforen. 1713;100.
Haugeto O K, Elverland H H, Schroder K E, Mair I W. Chronic secretory otitis media. Acta Oto-Laryngologica - Supplement. 1979;360:192-194.
Haugeto O K, Schroder K E, Mair I W S. Secretory otitis media, oral decongestant and antihistamine. J Otolaryngol. 1981;10:359-362. [pmid: 7199092].
Haughton P M. Validity of tympanometry for middle ear effusions. Arch Otolaryngol. 1977;103:505-513. [pmid: 901276].
Haughton P M, Pardoe K. Normal pure tone thresholds for hearing by bone conduction. Br J Audiol. 1981;15:113-121. [pmid: 7225647].
Haughton P M, Pardoe K. A comparison of otoscopy and tympanometry in the diagnosis of middle ear effusion. Clinical Physics and Physiological Measurement. 1982;3:213-220. [pmid: 7140159].
Haughton P M. A system for generating a variable mechanical impedance and its use in an investigation of the electromechanical properties of the B71 audiometric bone vibrator. Br J Audiol. 1982;16:1-7. [pmid: 7055651].
Hauswald M, Anison C. Prescribing analgesics: the effect of patient age and physician specialty. Pediatr-Emerg-Care. 1997;13:262-263. [pmid: 9291514].
Havas T, Koutsis A, Jacobson I. Nasal balloon auto-inflation (Otovent) as a treatment of otitis media with effusion in children. Australian Journal of Otolaryngology. 1995;2:37-41.
Havas T, Koutsis A. Preliminary experience with intraoperative, transiently evoked otoacoustic emissions in otitis media with effusion. Australian Journal of Otolaryngology. 1996;2:234-236.
Havas T, Koutsis A. The measurement of transiently evoked otoacoustic emissions in the auditory assessment of children with tympanostomy tubes in situ. Australian Journal of Otolaryngology. 1997;2:472-474.
Hawkins D B, Dru D, House J W, Clark R W. Acute mastoiditis in children: a review of 54 cases. Laryngoscope. 1983;93:568-572. [pmid: 6843246].
Hayden G F, Randall J E, Randall J C, Hendley J O. Topical phenylephrine for the treatment of middle ear effusion. ARCH-OTOLARYNGOL. 1984;110:512-514. [pmid: 6378158].
Hayes D, Jerger J. Impedance audiometry in otologic diagnosis. Otolaryngol Clin North Am. 1978;11:759-767. [pmid: 733258].
Hayes E, Babin R, Platz C. The otologic manifestations of mucopolysaccharidoses. Am J Otol. 1980;2:65-69. [pmid: 6782888].
Hazan A. [Serous otitis]. Soins - Chirurgie. 1993:7–10.
Head M. Does nose blowing help hearing in glue ear?. Nurs-Times. 1992;88:53. [pmid: 1738677].
Heaf M, Hutchings S, Bunch K. Does nose blowing improve hearing in serous otitis? A community study [see comments]. Br-J-Gen-Pract. 1991;41:377-379. [pmid: 1793648]. [pmcid: 1371720].
Heald M M, Matkin N D, Meredith K E. Pressure-equalization (PE) tubes in treatment of otitis media: national survey of otolaryngologists. Otolaryngol Head Neck Surg. 1990;102:334-338. [pmid: 2113259].
Health AAoPCoS. Impedance bridge (tympanometer) as a screening device in schools. Pediatrics. 1987;79:472. [pmid: 3822657].
Healy G B, Teele D W. The microbiology of chronic middle ear effusions in children. Laryngoscope. 1977;87:1472-1478. [pmid: 19659].
Healy G B, Smith H G. Current concepts in the management of otitis media with effusion. Am J Otolaryngol. 1981;2:138-144. [pmid: 7196702].
Healy G B. Antimicrobial therapy of chronic otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1984;8:13-17. [pmid: 6389394].
Healy GB. Antimicrobial Therapy for Chronic Otitis Media with Effusion. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:285–287.
Healy G B. Otitis media. Pediatr Rev. 1992;13:23-24. [pmid: 1734435].
Healy GB, McGill TJ, Sullivan KF, et al. Outcome factors in ventilation tube insertion: a prospective monitoring program. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:301–304.
Healy G B. Quick reference guide for clinicians. Managing otitis media with effusion in young children: a commentary [see comments]. Arch Otolaryngol Head Neck Surg. 1994;120:1049-1050. [pmid: 7917186].
Healy GB. The appropriateness of tympanostomy tubes for children [letter; comment]. JAMA. 1995;273:700; discussion 700–701.
Heaton J M, Bingham B J, Osborne J. A comparison of performance of Shepard and Sheehy collar button ventilation tubes. J Laryngol Otol. 1991;105:896-898. [pmid: 1761941].
Heaton J M, Mills R P. Otorrhoea via ventilation tubes in adults and children. Clin Otolaryngol. 1993;18:496-499. [pmid: 8877228].
Heaton J M, Mills R P. Factors associated with positive bacteriological cultures of chronic middle ear effusions. Clin Otolaryngol. 1995;20:262-265. [pmid: 7554342].
Hebblethwaite E M, Brown G W, Cox D M. A comparison of the efficacy and safety of cefuroxime axetil and augmentin in the treatment of upper respiratory tract infections. Drugs-Exp-Clin-Res. 1987;13:91-94. [pmid: 3582135].
Hedges LV, Olkin I. Statistical Methods for meta-analysis. San Diego: Academic Press; 1985.
Heermann J. Autograft tragal and conchal palisade cartilage and perichondrium in tympanomastoid reconstruction. Ear Nose Throat J. 1992;71:344-349. [pmid: 1396182].
Heery L B. Exclusive breast-feeding for at least 4 months protects against otitis media [letter; comment]. Pediatrics. 1994;93:537-538. [pmid: 8115228].
Hefelfinger D C. Cefixime therapy for otitis media [letter; comment]. Pediatr Infect Dis J. 1993;12:703-705. [pmid: 8414791].
Hegewald M, Heitman R, Wiederhold M L, Cooper J C, Gates G A. High-frequency electrostimulation hearing after mastoidectomy. Otolaryngol Head Neck Surg. 1989;100:49-56. [pmid: 2493616].
Heggie A A. Concepts in the management of temporomandibular ankylosis. Annals of the Royal Australasian College of Dental Surgeons. 1996;13:132-135. [pmid: 9178984].
Heikkinen T. Temporal development of acute otitis media during upper respiratory tract infection. Pediatr Infect Dis J. 1994;13:659-661. [pmid: 7970958].
Heikkinen T, Ruuskanen O, Ziegler T, Waris M, Puhakka H. Clinical and laboratory observations. Short-term use of amoxicillin- clavulanate during upper respiratory tract infection for prevention of acute otitis media. J Pediatr. 1995;126:313-316. [pmid: 7844685].
Heikkinen T, Ruuskanen O, Ziegler T, Waris M, Puhakka H. Short-term use of amoxicillin-clavulanate during upper respiratory tract infection for prevention of acute otitis media. J Pediatr. 1995;126:313-316. [pmid: 7844685].
Heikkinen T, Waris M, Ruuskanen O, Putto-Laurila A, Mertsola J. Incidence of acute otitis media associated with group A and B respiratory syncytial virus infections. Acta Paediatr. 1995;84:419-423. [pmid: 7795353].
Heikkinen T, Ruuskanen O. Signs and symptoms predicting acute otitis media [see comments]. Arch Pediatr Adolesc Med. 1995;149:26-29. [pmid: 7827655].
Heikkinen T, Ruuskanen O. New prospects in the prevention of otitis media. Ann Med. 1996;28:23-30. [pmid: 8932502].
Heiskanen-Kosma T, Korppi M, Jokinen C, Heinonen K. Risk factors for community-acquired pneumonia in children: a population-based case-control study. Scand J Infect Dis. 1997;29:281-285. [pmid: 9255890].
Hellier W P, Corbridge R J, Watters G, Freeland A P. Grommets and patient satisfaction: an audit. Ann R Coll Surg Engl. 1997;79:428-431. [pmid: 9422869].
Hellin Meseguer D, Merino Galvez E, Armengot Carceller M. [Adenoidectomy and nasal mucociliary transport]. An Otorrinolaringol Ibero Am. 1994;21:455-462. [pmid: 7810828].
Hemlin C, Brauner A, Carenfelt C, Wretlind B. Test-retest reliability of the nasopharyngeal culture in children. APMIS. 1989;97:887-890. [pmid: 2679807].
Hemlin C, Hallden G, Hed J. Flow cytometric quantification of lymphocyte subpopulations and immunoglobulin-containing cells in adenoid tissue in relation to secretory otitis media and age. Acta Otolaryngol. 1995;115:443-448. [pmid: 7653269].
Hemlin C, Carenfelt C, Papatziamos G. Single dose of betamethasone in combined medical treatment of secretory otitis media. Ann-Otol-Rhinol-Laryngol. 1997;106:359-363. [pmid: 9153098].
Hemmer V H, Ratner N B. Communicative development in twins with discordant histories of recurrent otitis media. J Commun Disord. 1994;27:91-106. [pmid: 7929882].
Henderson J P, McCullough W P. Otitis media in suckler calves [letter]. Vet Rec. 1993;132:24. [pmid: 8438544].
Henderson FW, Zeisel SA, Burchinal MR, et al. Natural history of middle ear effusion among African American infants and toddlers followed prospectively in group child care. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:44–47.
Hendolin P H, Karkkainen U, Himi T, Markkanen A, Ylikoski J. High incidence of Alloiococcus otitis in otitis media with effusion. Pediatr Infect Dis J. 1999;18:860-865. [pmid: 10530580].
Hendrickse W A, Kusmiesz H, Shelton S, Nelson J D. Five vs. ten days of therapy for acute otitis media. Pediatr Infect Dis J. 1988;7:14-23. [pmid: 3277153].
Henriksen AO, Stenfors LE. The Lappish way of treating otitis media over the centuries. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:262–264.
Hentzer E. Ultrastructure of the normal mucosa in the human middle ear, mastoid cavities, and eustachian tube. Ann Otol Rhinol Laryngol. 1970;79:1143-1157. [pmid: 5490199].
Hentzer E, Jorgensen M B. The submucous layer of the middle ear in chronic otitis media. I. Secretory otitis media. A histological and ultrastructural study. Archiv fur Klinische und Experimentelle Ohren-, Nasen- und Kehlkopfheilkunde. 1972;201:108-118. [pmid: 5051279].
Hentzer E. Ultrastructure of the middle-ear mucosa in secretory otitis media. II. Mucous effusion. Acta Otolaryngol. 1972;73:467-475. [pmid: 4261675].
Hentzer E. Ultrastructure of the middle-ear mucosa in secretory otitis media. I. Serous effusion. Acta Otolaryngol. 1972;73:394-401. [pmid: 4113345].
Heppt W, Lutz H. Clinical experiences with ofloxacin sequential therapy in chronic ear infections. Eur Arch Otorhinolaryngol. 1993;250:S19-S21. [pmid: 8476581].
Herberts G, Jeppsson P H, Nylen O, Branefors-Helander P. Acute otitis media. Etiological and therapeutical aspects on acute otitis media. Practica Oto-Rhino-Laryngologica. 1971;33:191-202. [pmid: 4108523].
Herer G R. Editorial: Otitis media and educational achievement. Eye, Ear, Nose and Throat Monthly. 1974;53:447-448.
Hergils L, Magnuson B, B. F. Tympanometry compared with simultaneous direct pressure measurement in normal human middle ears. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:45–46.
Hergils L, Magnuson B. Middle ear gas composition in pathologic conditions: Mass spectrometry in otitis media with effusion and atelectasis. Ann Otol Rhinol Laryngol. 1997;106:743-745. [pmid: 9302904].
Herman P, Yen P T, Tu T Y, et al. Pathophysiology of middle ear epithelium: a new role for prostaglandin E2. Am J Otolaryngol. 1994;15:258-266. [pmid: 7978024].
Hermans R, Baert A L, Debruyne F, Feenstra L. [The contribution of proton spin resonance tomography in the diagnosis of petrous bone anomalies]. Ned Tijdschr Geneeskd. 1994;138:1401-1405. [pmid: 8047178].
Hern J D, Hasnie A, Shah N S. A long-term review of the Shah Permavent tube. J Laryngol Otol. 1995;109:277-280. [pmid: 7782679].
Heron T G. Glue ear [letter; comment] [see comments]. J R Soc Med. 1994;87:182. [pmid: 7802760].
Herranz Jordan B, Sanchez Casado M L, Carrasco Claver F. [Otitis media in pediatric primary care]. Aten Primaria. 1993;12:102-103, 105108. [pmid: 8329539].
Heshiki Z, Tagliarini J V, Javaroni A C. Effect of chronic otitis media without complication of the sensorineural hearing loss. Revista Brasileira de Otorrinolaringologia. 1994;60:174-176.
Hesseling S C, van Blitterswijk C A, Lim D J, DeMaria T F, Bakaletz L O, Grote J J. Effect of endotoxin on cultured rat middle ear epithelium, rat meatal epidermis, and human keratinocytes. Am J Otol. 1994;15:762-768. [pmid: 8572089].
Hester T O, Jones R O, Archer S M, Haydon R C. Prophylactic antibiotic drops after tympanostomy tube placement. Arch Otolaryngol Head Neck Surg. 1995;121:445-448. [pmid: 7702820].
Hester T O, Jones R O. Prophylactic antibiotics in surgery for chronic ear disease. Laryngoscope. 1998;108:1334-1337. [pmid: 9738752].
Hick J F. Signs and symptoms predicting acute otitis media [letter; comment]. Arch Pediatr Adolesc Med. 1995;149:1285. [pmid: 7581769].
Hicks G W, Wright J W Jr, Wright J Wd. Cerebrospinal fluid otorrhea. Laryngoscope. 1980;90:1-25. [pmid: 6968860].
Hicks G W, Wright J W Jr, Wright J Wd. Otologic disorders in children. Journal of the Indiana State Medical Association. 1982;75:798-801. [pmid: 6890966].
Hicks J N. Secondary tobacco smoke and preventive and protective measures. Laryngoscope. 1995;105:1287-1289. [pmid: 8523978].
Hignett W. Effect of otitis media on speech, language, and behavior. Ann Otol Rhinol Laryngol. 1983;96.
Hilding D A, Ammerman S. Tympanostomy tube complications and efficacy in children of a rural community. West J Med. 1986;144:318-320. [pmid: 3962295]. [pmcid: 1306606].
Hildmann H, Hildmann A. [Tympanic effusion]. HNO. 1993;41:455-464. [pmid: 8226134].
Hildmann H, Sudhoff H. Cholesteatoma in children. Int J Pediatr Otorhinolaryngol. 1999;49:S81-S86. [pmid: 10577781].
Hill J, Hutton D A, Green G G, Birchall J P, Pearson J P. Culture of human middle ear mucosal explants; mucin production. Clin Otolaryngol Allied Sci. 1992;17:491-496. [pmid: 1493622].
Hillyard S A, Galambos R. Effects of stimulus and response contingencies on a surface negative slow potential shift in man. Electroencephalogr Clin Neurophysiol. 1967;22:297-304. [pmid: 4164739].
Himi T, Kamimura M, Kataura A, Imai K. Quantitative analysis of soluble cell adhesion molecules in otitis media with effusion. Acta Otolaryngol. 1994;114:285-288. [pmid: 7521106].
Himi T, Harabuchi Y, Shintani T, Yamaguchi T, Kataura A. Surgical strategy of cochlear implant in patients with otitis media. Adv Otorhinolaryngol. 1997;52:158-160. [pmid: 9042476].
Hinchcliffe R, Prasansuk S. Epidemiology and SOM. A review. Scandinavian Audiology Supplementum. 1986;26:53-58. [pmid: 3554486].
Hind SE, Wade AR, Haggard MP. Optimization of a cognitive test battery for assessing OME sequelae. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:346–350.
Hinton A E, Buckley G. Parental smoking and middle ear effusions in children. J Laryngol Otol. 1988;102:992-996. [pmid: 3209951].
Hinton A, Herdman R C, Hartley C, O'Keefe L. The incidence of bacteria in middle ear effusions. Clin Otolaryngol. 1996;21:158-161. [pmid: 8735403].
Hiranandani L H, Deshpande C K. Histopathological study of the middle-ear cleft. J Laryngol Otol. 1969;83:529-550. [pmid: 5785651].
Hiroyuki T. [Bacterial quantification and anti-bacterial antibodies in otitis media with effusion in children]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1993;96:959-968.
Hiroyuki T, Tetsuo H. [Antibody titers to bacterial antigens in middle ear effusion of otitis media with effusion]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1993;96:952-958.
Hirsch A. Behavioural tests: applications and limitations in comparison with brainstem response audiometry. Acta Oto-Laryngologica - Supplement. 1991;482:118–124; discussion 125.
Hirsch B E, Kamerer D B, Doshi S. Single-stage management of cholesteatoma. Otolaryngol Head Neck Surg. 1992;106:351-354. [pmid: 1565484].
Hisamatsu K, Ganbo T, Nakazawa T, et al. Clinical efficacy of Tranilast on otitis media with effusion in children. Auris-Nasus-Larynx. 1994;21:150-157. [pmid: 7532938].
Hlobil H. Temporary threshold shift in patients with serous otitis media. Arch Oto Rhino Laryngol. 1979;225:211-219.
Hoang K D, Pollack C V Jr. Antibiotic use in the emergency department. IV: Single-dose therapy and parenteral-loading dose therapy. J Emerg Med. 1996;14:619-628. [pmid: 8933325].
Hoberman A, Paradise JL, Kaleida PH. Ceftriaxone for otitis media [letter; comment]. Pediatrics. 1993;92:507; discussion 508.
Hoberman A, Paradise J L, Block S, Burch D J, Jacobs M R, Balanescu M I. Efficacy of amoxicillin/clavulanate for acute otitis media: relation to Streptococcus pneumoniae susceptibility. Pediatr Infect Dis J. 1996;15:955-962. [pmid: 8895940].
Hoberman A, Paradise J L, Reynolds E A, Urkin J. Efficacy of Auralgan for treating ear pain in children with acute otitis media. Arch Pediatr Adolesc Med. 1997;151:675-678. [pmid: 9232040].
Hoberman A, Paradise J L, Burch D J, et al. Equivalent efficacy and reduced occurrence of diarrhea from a new formulation of amoxicillin/clavulanate potassium (Augmentin (R)) for treatment of acute otitis media in children. Pediatr Infect Dis J. 1997;16:463-470. [pmid: 9154538].
Hoberman A, Paradise J L, Burch D J, et al. Equivalent efficacy and reduced occurrence of diarrhea from a new formulation of amoxicillin/clavulanate potassium (Augmentin) for treatment of acute otitis media in children. Pediatr Infect Dis J. 1997;16:463-470. [pmid: 9154538].
Hoberman A, Paradise J L, Wald E R. Tympanocentesis technique revisited. Pediatr Infect Dis J. 1997;16:S25-S26. [pmid: 9041625].
Hobson R, Gould I, Govan J. Burkholderia (Pseudomonas) cepacia as a cause of brain abscesses secondary to chronic suppurative otitis media. Eur J Clin Microbiol Infect Dis. 1995;14:908-911. [pmid: 8605906].
Hodson A H. Glue ear [letter; comment] [see comments]. J R Soc Med. 1993;86:247. [pmid: 8060392].
Hodson A H. Glue ear [letter; comment]. J R Soc Med. 1994;87:571. [pmid: 7932475].
Hoffman R A. Serous otitis media: A rationale for therapy. Bull Ny Acad Med. 1980;56:728-733.
Hoffman-Lawless K, Keith R W, Cotton R T. Auditory processing abilities in children with previous middle ear effusion. Ann Otol Rhinol Laryngol. 1981;90:543-545. [pmid: 7316376].
Hogan S C, Meyer S E, Moore D R. Binaural unmasking returns to normal in teenagers who had otitis media in infancy. Audiol Neurootol. 1996;1:104-111. [pmid: 9390794].
Hogan S C, Moore D R. Long-term follow-up of binaural masking level differences in children with a history of otitis media. Br J Audiol. 1996;30:131-132.
Hogan S C, Stratford K J, Moore D R. Duration and recurrence of otitis media with effusion in children from birth to 3 years: prospective study using monthly otoscopy and tympanometry [see comments]. Br Med J. 1997;314:350-353. [pmid: 9040332].
Hohmann A. Experimental mastoidectomy with replacement of posterior bony canal wall in primates. Adv Otorhinolaryngol. 1983;31:39-49. [pmid: 6624600].
Holborow C. Prevention of deafness in rural tropical areas. Trop Doct. 1985;15:39-41. [pmid: 3976006].
Holliday R A, Reede D L. MRI of mastoid and middle ear disease. Radiol Clin North Am. 1989;27:283-299. [pmid: 2537500].
Holm V A, Kunze L H. Effect of chronic otitis media on language and speech development. Pediatrics. 1969;43:833-839. [pmid: 5769509].
Holm E, Seibaek M, Iversen P B. Two cases of otolaryngeal tuberculosis in a Danish married couple. J Laryngol Otol. 1995;109:1080-1081. [pmid: 8551125].
Holm-Jensen S, Sorensen C H, Tos M. Repetitive tympanometric screenings in 4-year-old children. Seasonal influence on secretory otitis and tubal dysfunction. ORL J Otorhinolaryngol Relat Spec. 1981;43:164-174. [pmid: 7194998].
Holmberg K, Axelsson A, Hansson P, Renvall U. The correlation between otoscopy and otomicroscopy in acute otitis media during healing. Scand Audiol. 1985;14:191-199. [pmid: 4095486].
Holmberg K, Axelsson A, Hansson P, Renvall U. Comparison of tympanometry and otomicroscopy during healing of otitis media. Scand Audiol. 1986;15:3-8. [pmid: 3704539].
Holmes N, Conway M J, Flood L, Fraser J G, Stewart A. Language development in a group of very low-birth-weight children whose postauricular myogenic response was tested in infancy. Pediatrics. 1983;71:257-261. [pmid: 6823431].
Holmquist J. The role of the eustachian tube in myringoplasty. Acta Otolaryngol. 1968;66:289-295. [pmid: 5734497].
Holmquist J, Hallen O. Eustachian tube function and the mastoid air cell system in tympanoplasty. Otolaryngol Clin North Am. 1970;3:95-102. [pmid: 5522277].
Holmquist J, Renwall U. Eustachian tube function in secretory otitis media. Arch Otolaryngol. 1974;99:59-61. [pmid: 4809087].
Holmquist J, Oleander R, Hallen O. Peroperative drill-generated noise levels in ear surgery. Acta Otolaryngol. 1979;87:458-460. [pmid: 463518].
Holmquist J, Jarlstedt J, Tjellstrom A. Surgery of the Mastoid in Ears with Middle Ear Effusion. Proceedings of the Second International Symposium: Recent Advances in Otitis Media with Effusion; 1980:322–333.
Holmquist J, Al F a d a l a S, Qattan Y. Prevalence of secretory otitis media among school children in Kuwait. J Laryngol Otol. 1987;101:116-119. [pmid: 3572214].
Holt G R, Young W C. Acute coalescent mastoiditis. Otolaryngol Head Neck Surg. 1981;89:317-321. [pmid: 6787534].
Holt G R, Watson M J. The otolaryngologist's role in the craniofacial anomalies team. Otolaryngol Head Neck Surg. 1984;92:406-409. [pmid: 6435059].
Holt E, Guyer B, Hughart N, et al. The contribution of missed opportunities to childhood underimmunization in Baltimore. Pediatrics. 1996;97:474-480. [pmid: 8632931].
Holt D E, Walker L. Radiographic appearance of the middle ear after ventral bulla osteotomy in five dogs with otitis media. Veterinary Radiology and Ultrasound. 1997;38:182-184. [pmid: 9238788].
Holtby I, Elliott K, Kumar U. Is there a relationship between proximity to industry and the occurrence of otitis media with effusion in school entrant children?. Public Health. 1997;111:89-91. [pmid: 9090283].
Holte L, Margolis R H. Screening tympanometry. Seminars in Hearing. 1987;8:329-337.
Holzmann D, Huisman T A, Linder T E. Lateral dural sinus thrombosis in childhood. Laryngoscope. 1999;109:645-651. [pmid: 10201757].
Homer J J, Johnson I J, Jones N S. Middle ear infection and sixth nerve palsy. J Laryngol Otol. 1996;110:872-874. [pmid: 8949301].
Homoe P, Lynnerup N, Videbaek H. CT-scanning of ancient Greenlandic Inuit temporal bones. Acta Otolaryngol. 1992;112:674-679. [pmid: 1442014].
Homoe P, Lynnerup N, Rasmussen N, Skovgaard L T. Statistical model estimating the occurrence of otitis media from temporal bone pneumatization. Ann Otol Rhinol Laryngol. 1994;103:469-473. [pmid: 8203813].
Homoe P, Christensen R B, Breatlau P. Hearing in elementary school children in Nuuk and Sisimiut, Greenland. Arctic Med Res. 1995;54:145-150. [pmid: 7669128].
Homoe P, Lynnerup N, Skovgaard L T. Pneumatization and otitis media in Greenlandic Inuit before European colonization. J Otolaryngol. 1995;24:330-335. [pmid: 8699597].
Homoe P, Prag J, Farholt S, et al. High rate of nasopharyngeal carriage of potential pathogens among children in Greenland: results of a clinical survey of middle-ear disease. Clin Infect Dis. 1996;23:1081-1090. [pmid: 8922807].
Homoe P, Lynnerup N, Skovgaard L T, Rasmussen N. Estimation of otitis media in ancient populations. A study of past and present Greenlandic Inuit. J Laryngol Otol. 1996;110:1114-1119. [pmid: 9015422].
Homoe P, Christensen R B, Bretlau P. Prevalence of otitis media in a survey of 591 unselected Greenlandic children. Int J Pediatr Otorhinolaryngol. 1996;36:215-230. [pmid: 8864805].
Homoe P. Present aspects of otitis media among children in Greenland. Int J Pediatr Otorhinolaryngol. 1999;49:169-172.
Honda K, Tanke M, Kumazawa T. Otitis media with effusion and tubal tonsil (video). Acta Oto-Laryngologica - Supplement. 1988;454:218-221.
Honjo I, Hamasaki H, Okazaki N, Kumazawa T. Acoustic analysis of the inflation sound in Eustachian catheterization. Arch Otorhinolaryngol. 1980;229:183-190. [pmid: 7193449].
Honjo I, Tashima K, Mitoma T, Hamada E. Effect of adenoidectomy on eustachian tube function. Auris Nasus Larynx. 1985;12:S231-S233. [pmid: 3835917].
Honjo I. [Imaging diagnosis and function tests--exudative otitis media (CT, MRI, ear canal function tests, and tympanography)]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1996;99:954-957.
Hoover K M, Chermak G D, Doyle C S. A comparative study of immittance screening procedures with preschool-aged children. Am J Otol. 1982;4:142-147. [pmid: 7149006].
Hopkin R J, Bergeson P S, Pinckard K C, Lewis K, Pinckard R C. Otitis externa posing as mastoiditis [published erratum appears in Arch Pediatr Adolesc Med 1995 Sep;149(9):1028]. Arch Pediatr Adolesc Med. 1994;148:1346-1349. [pmid: 7951821].
Hopkins S. Clinical safety and tolerance of azithromycin in children. J-Antimicrob-Chemother. 1993:111–117.
Hopkinson N T, Schramm V L, Bosse B F, Leggett S H. A comparison of results--acoustic susceptance and otolaryngology. Journal of the American Audiology Society. 1978;3:191-199. [pmid: 659291].
Hoppe J E, Koster S, Bootz F, Niethammer D. Acute mastoiditis--relevant once again. Infection. 1994;22:178-182. [pmid: 7927813].
Hori F, Kawauchi H, Mogi G. Effect of S-carboxymethylcysteine on the clearance of middle ear effusion: An experimental study. Ann Otol Rhinol Laryngol. 1994;103:567-575. [pmid: 8024221].
Horn K L, Erasmus M D, Akiya F I. Suppurative petrous apicitis: osteitis or osteomyelitis? an imaging case report. Am J Otolaryngol. 1996;17:54-57. [pmid: 8801817].
Horowitz F D. Design factors in the assessment of intelligence. Ann Otol Rhinol Laryngol Suppl. 1979;88:64-77. [pmid: 115364].
Horowitz F D, Leake H d. Effects of otitis media on cognitive development. Ann Otol Rhinol Laryngol Suppl. 1980;89:264-268. [pmid: 6778322].
Hoshino T, Miyashita H, Asai Y. Computed tomography of the temporal bone in tuberculous otitis media. J Laryngol Otol. 1994;108:702-705. [pmid: 7930928].
Host A. Mechanisms in adverse reactions to food. The ear. Allergy. 1995;50:64-67. [pmid: 7741208].
Host A. Otitis serosa: a food allergy?. Monogr Allergy. 1996;32:195-197. [pmid: 8813199].
Hotomi M, Tabata T, Kakiuchi H, Kunimoto M. Detection of Haemophilus influenzae in middle ear of otitis media with effusion by polymerase chain reaction. Int J Pediatr Otorhinolaryngol. 1993;27:119-126. [pmid: 8258479].
Hotomi M, Samukawa T, Yamanaka N. Interleukin-8 in otitis media with effusion. Acta Otolaryngol. 1994;114:406-409. [pmid: 7976312].
Hough J V, Stuart W D. Middle ear injuries in skull trauma. Laryngoscope. 1968;78:899-937. [pmid: 5662767].
Hough J V. Tympanoplasty with the interior fascial graft technique and ossicular reconstruction. Laryngoscope. 1970;80:1385-1413. [pmid: 5470224].
Houghton D J, White P S, Browning G G. Predictors of outcome in children with otitis media with effusion. Clin Otolaryngol Allied Sci. 1998;23:48-50. [pmid: 9563665].
House H P. ‘Everywhere the old order changes and happy are those who can change with it’. J Laryngol Otol. 1976;90:41-48. [pmid: 1255003].
House J W, Sheehy J L. Cholesteatoma with intact tympanic membrane: a report of 41 cases. Laryngoscope. 1980;90:70-76. [pmid: 7188710].
House W F. Surgical considerations in cochlear implantation. Ann Otol Rhinol Laryngol Suppl. 1982;91:15-20. [pmid: 6805392].
House W F, Luxford W M, Courtney B. Otitis media in children following the cochlear implant. Ear Hear. 1985;6:24S-26S. [pmid: 3839472].
House W F. Cochlear implants in children--point, counterpoint. Am J Otol. 1988;9:161-162. [pmid: 3407752].
Howard J E, Nelson J D, Clahsen J, Jackson L H. Otitis media of infancy and early childhood. A double-blind study of four treatment regimens. Am-J-Dis-Child. 1976;130:965. [pmid: 8980].
Howard J E, Nelson J D, Clahsen J, Jackson L H. Otitis media of infancy and early childhood. A double-blind study of four treatment regimens. CURR THER. 1977;18:92.
Howard J D, Elster A D, May J S. Temporal bone: three-dimensional CT. Part I. Normal anatomy, techniques, and limitations. Radiology. 1990;177:421-425. [pmid: 2217779].
Howie V M, Ploussard J H. Bacterial etiology and antimicrobial treatment of exudative otitis media: relation of antibiotic therapy to relapses. South-Med-J. 1971;64:233-239. [pmid: 5313487].
Howie V M, Ploussard J H. Efficacy of fixed combination antibiotics versus separate components in otitis media. Effectiveness of erythromycin estrolate, triple sulfonamide, ampicillin, erythromycin estolate- triple sulfonamide, and placebo in 280 patients with acute otitis media under two and one-half years of age. Clin-Pediatr-Phila. 1972;11:205-214. [pmid: 4537206].
Howie V M, Ploussard J H, Sloyer J. Comparison of ampicillin and amoxicillin in the treatment of otitis media in children. J Infect Dis. 1974;129(suppl):S181-S184. [pmid: 4152132].
Howie V M, Ploussard J H. Treatment of serous otitis media with ventilatory tubes. Clin Pediatr. 1974;13:919-921.
Howie VM, Ploussard JH, Sloyer JL. Natural history of otitis media. The Annals of Otology, Rhinology and Larynogology;1976;18–19.
Howie VM. Acute and recurrent otitis media. In: B J, ed. Hearing Loss in Children. Baltimore: University Park Press; 1977:421–430.
Howie V M, Jensen N J, Fleming J W, Peeler M B, Meigs S. The effect of early onset of otitis media on educational achievement. Int J Pediatr Otorhinolaryngol. 1979;1:151-155. [pmid: 553893].
Howie V M. Developmental sequelae of chronic otitis media: a review. J Dev Behav Pediatr. 1980;1:34-38. [pmid: 7251873].
Howie V M, Schwartz R H. Acute otitis media. One year in general pediatric practice. Am J Dis Child. 1983;137:155-158. [pmid: 6681578].
Howie V M, Dillard R, Lawrence B. In vivo sensitivity test in otitis media: efficacy of antibiotics. Pediatrics. 1985;75:8-13. [pmid: 3871251].
Howie V M. Otitis media. Pediatr Rev. 1993;14:320-323. [pmid: 8255828].
Hozawa K, Suzuki M, Jingu K, Takahashi Y, Takasaka T. Low-dose, long-term erythromycin treatment for secretory otitis media in childhood. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:217–219.
Hsu M M, Young Y H, Lin K L. Eustachian tube function of patients with nasopharyngeal carcinoma. Ann Otol Rhinol Laryngol. 1995;104:453-455. [pmid: 7771718].
Hsu G S, Levine S C, Giebink G S. Management of otitis media using agency for health care policy and research guidelines. Otolaryngology and Head and Neck Surgery. 1998;118:437-443.
Huang T S, Lee F P. Congenital cholesteatoma: review of twelve cases. Am J Otol. 1994;15:276-281. [pmid: 8172318].
Huang J L, Lin C Y. A hereditary C3 deficiency due to aberrant splicing of exon 10. Clin Immunol Immunopathol. 1994;73:267-273. [pmid: 7923934].
Huang M H, Lee S T, Rajendran K. A fresh cadaveric study of the paratubal muscles: implications for eustachian tube function in cleft palate. Plast Reconstr Surg. 1997;100:833-842. [pmid: 9290650].
Hubbard T W, Paradise J L, McWilliams B J, Elster B A, Taylor F H. Consequences of unremitting middle-ear disease in early life. Otologic audiologic and developmental findings in children with cleft palate. N Engl J Med. 1985;312:1529-1534. [pmid: 4039792].
Huber C J, Stangler S R, Routh D K. The BOEL test as a screening device for otitis media in infants. Nurs Res. 1978;27:178-180. [pmid: 248189].
Hug J E. A planimetric study of temporal bone pneumatization. Arch Otorhinolaryngol. 1986;243:304-308. [pmid: 3813966].
Hughes W T, Kuhn S, Chaudhary S, et al. Successful chemoprophylaxis for Pneumocystis carinii pneumonitis. N Engl J Med. 1977;297:1419-1426. [pmid: 412099].
Hughes K B. Management of middle-ear effusions in children. J Laryngol Otol. 1984;98:677-684. [pmid: 6379082].
Hughes L A, Wight D. Tympanostomy tubes: long-term effects. Am Fam Physician. 1988;38:186-190. [pmid: 3189124].
Hughes C E, Spear R K, Shinabarger C E, Tuna I C. Septic pulmonary emboli complicating mastoiditis: Lemierre's syndrome revisited. Clin Infect Dis. 1994;18:633-635. [pmid: 8038323].
Hui Y, Park A, Crysdale W S, Forte V. Ototoxicity from ototopical aminoglycosides. J Otolaryngol. 1997;26:53-56. [pmid: 9055175].
Hultcrantz M, Sylven L. Turner's syndrome and hearing disorders in women aged 16–34. Hear Res. 1997;103:69-74. [pmid: 9007575].
Hung W. Impedance audiometry in secretory otitis. Acta Otorhinolaryngol Belg. 1974;28:499-509. [pmid: 4440478].
Hunter D. Serous otitis media. Journal of the Medical Association of the State of Alabama. 1980;49:19-23. [pmid: 7365337].
Hunter LL, Margolis RH, Rykken JR, Giebink GS. Multifrequency tympanometry in normal children and children recovering from otitis media-a preliminary report. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:46–49.
Hunter L L, Margolis R H, Giebink G S. Identification of hearing loss in children with otitis media. Ann Otol Rhinol Laryngol Suppl. 1994;163:59-61. [pmid: 8179273].
Hunter LL, Margolis RH, Giebink GS, Schmidth JL, Le CT, Daly KA. Long-term prospective study of hearing loss in children after tympanostomy tube treatment of chronic otitis media with effusion. In: Lim DJ, Bluestone CD, Casselbrant M, Klein JO, Ogra PL, eds. Proceedings of the Sixth International Symosium on Recent Advances in Otitis Media. Hamilton: BC Decker; 1995:383.
Hunter L L, Margolis R H, Rykken J R, Le C T, Daly K A, Giebink G S. High frequency hearing loss associated with otitis media. Ear Hear. 1996;17:1-11. [pmid: 8741962].
Hunter LL, Margolis RH, Giebink GS, Schmitz JL, Le CT, Daly KA. Long-term prospective study of hearing loss in children after tympanostomy tube treatment of chronic otitis media with effusion. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:383–386.
Hunter L L, Margolis R H. Effects of tympanic membrane abnormalities on auditory function. J Am Acad Audiol. 1997;8:431-446. [pmid: 9433689].
Hurley MM, Guzell JR, Vernon-Feagans L. Examination of otitis media, quality of child care, and language skills. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:416–418.
Hurst P L. Involvement of a prepaid health plan in prospective studies on tonsillectomy and adenoidectomy. Ann Otol Rhinol Laryngol. 1975;84:22-24. [pmid: 1130769].
Hurst D S. Allergy management of refractory serous otitis media. Otolaryngol Head Neck Surg. 1990;102:664-669. [pmid: 2115652].
Hurst D S, Venge P. The presence of eosinophil cationic protein in middle ear effusion. Otolaryngol Head Neck Surg. 1993;108:711-722. [pmid: 8516010].
Hurst D S. Association of otitis media with effusion and allergy as demonstrated by intradermal skin testing and eosinophil cationic protein levels in both middle ear effusions and mucosal biopsies. Laryngoscope. 1996;106:1128-1137. [pmid: 8822719].
Hurst D S, Venge P. Levels of eosinophil cationic protein and myeloperoxidase from chronic middle ear effusion in patients with allergy and/or acute infection. Otolaryngol Head Neck Surg. 1996;114:531-544. [pmid: 8643262].
Hurst D S, Fredens K. Eosinophil cationic protein in mucosal biopsies from patients with allergy and otitis media with effusion. Otolaryngol Head Neck Surg. 1997;117:42-48. [pmid: 9230321].
Hurst D S, Weekley M, Ramanarayanan M P. Evidence of possible localized specific immunoglobulin E production in middle ear fluid as demonstrated by ELISA testing. Otolaryngol Head Neck Surg. 1999;121:224-230. [pmid: 10471862].
Hurst D S, Amin K, Seveus L, Venge P. Evidence of mast cell activity in the middle ears of children with otitis media with effusion. Laryngoscope. 1999;109:471-477. [pmid: 10089978].
Hussain M A, Ali E M, Ahmed H S. Otitis media in Sudanese children: presentation and bacteriology. East Afr Med J. 1991;68:679-685. [pmid: 1797530].
Hussain S S. Extrusion rate of Shah and Shepard ventilation tubes in children. Ear Nose Throat J. 1992;71:273-275. [pmid: 1451676].
Hussl B, Welzl-Mueller K. Secretory otitis media and mastoid pneumatization. Ann Otol Rhinol Laryngol Suppl. 1980;89:79-82. [pmid: 6778358].
Hutchings S A. Audiometric screening in schools--2. A child with bilateral sensorineural loss and secretory otitis media. Nursing Times. 1978;74:1991-1994. [pmid: 251980].
Hutchings M E, Meyer S E, Moore D R. Binaural masking level differences in infants with and without otitis media with effusion. Hear Res. 1992;63:71-78. [pmid: 1464577].
Hutchinson J C Jr, Caldarelli D D, Valvassori G E, Pruzansky S, Parris P J. The otologic manifestations of mandibulofacial dysostosis. Transactions - American Academy of Ophthalmology and Otolaryngology. 1977;84:ORL520-8.
Huttenbrink K B. [Surgical treatment of chronic otitis media. III: Middle ear reconstruction]. HNO. 1994;42:701-718. [pmid: 7844003].
Huttenbrink K B. [Surgical treatment of chronic otitis media. II: Cholesteatoma removal, open and closed techniques]. HNO. 1994;42:648-657. [pmid: 8002373].
Huttenbrink K B. [Surgical treatment of chronic otitis media. I: Indications, preoperative care and surgical principles]. HNO. 1994;42:582-593. [pmid: 7989230].
Huttenbrink K B. [Acoustically optimized middle ear prostheses. New techniques for future research and development of improved implants (comment)]. HNO. 1997;45:509-511. [pmid: 9340331].
Hutton J B. Effect of middle ear pathology on selected psychoeducational measures following surgical treatment. Percept Mot Skills. 1983;57:1095-1100. [pmid: 6686671].
Hutton D A, Fogg F J, Murty G, Birchall J P, Pearson J P. Preliminary characterization of mucin from effusions of cleft palate patients. Otolaryngol Head Neck Surg. 1993;109:1000-1006. [pmid: 8265181].
Iarlykov S A, Poliakova S D, Zemskov A M. [Correction of immunologic disorders in patients with chronic suppurative otitis media]. Vestn-Otorinolaringol. 1995;1995:9-11. [pmid: 7725591].
Ibekwe A O, Okoye B C. Subperiosteal mastoid abscesses in chronic suppurative otitis media. Ann Otol Rhinol Laryngol. 1988;97:373-375. [pmid: 3408111].
Ibekwe A O, al Shareef Z, Benayam A. Anaerobes and fungi in chronic suppurative otitis media. Ann Otol Rhinol Laryngol. 1997;106:649-652. [pmid: 9270427].
Ichijo H, Hosokawa M, Shinkawa H. Differences in size and shape between the right and left sigmoid sinuses. Eur Arch Otorhinolaryngol. 1993;250:297-299. [pmid: 8217134].
Ichijo H, Hosokawa M, Shinkawa H. The relationship between mastoid pneumatization and the position of the sigmoid sinus. Eur Arch Otorhinolaryngol. 1996;253:421-424. [pmid: 8891487].
Ichimiya I, Kurono Y, Mogi G. Immunology of the tympanic membrane. Acta Otorhinolaryngol Belg. 1995;49:121-125. [pmid: 7610905].
Ichimiya I, Kurono Y, Mogi G. Immunological potential of the tympanic membrane. Observation under normal and inflammatory conditions. Am J Otolaryngol. 1997;18:165-172. [pmid: 9164618].
Iemma M, Maurer J. Distorsion product otoacoustic emissions in children before and after adenotomy, tonsillectomy and myringotomy. Oto Rhino Laryngologia Nova. 1997;7:14-20.
Iino Y, Kaneko Y, Takasaka T. Endotoxin in middle ear effusions tested with Limulus assay. Acta Otolaryngol. 1985;100:42-50. [pmid: 4040697].
Iino Y, Yuasa R, Kaneko Y, Takasaka T, Kawamoto K. Prognosis and endotoxin contents in middle ear effusions in cases after acute otitis media. Acta Oto-Laryngologica - Supplement. 1987;435:85-89.
Iino Y, Ishitoya J, Ikeda M, et al. [Factors on delayed recovery of otitis media with effusion in children--clinical and bacteriological study]. Nippon-Jibiinkoka-Gakkai-Kaiho. 1989;92:1183-1191. [pmid: 2685215].
Iino Y, Nakamura Y, Koizumi T, Toriyama M. Prognostic factors for persistent middle ear effusion after acute otitis media in children. Acta Otolaryngol. 1993;113:761-765. [pmid: 8291435].
Iino Y, Nakamura Y, Koizumi T, Toriyama M. Prognostic factor for persistent middle ear effusion after acute otitis media in children. Acta Oto Laryngologica. 1993;113:761-765. [pmid: 8291435].
Iino Y, Sugita K, Toriyama M, Kudo K. Erythromycin therapy for otitis media with effusion in sinobronchial syndrome. Arch Otolaryngol Head Neck Surg. 1993;119:648-651. [pmid: 8499096].
Iino Y, Imamura Y, Hiraishi M, Yabe T, Suzuki J. Mastoid pneumatization in children with congenital cholesteatoma: an aspect of the formation of open-type and closed-type cholesteatoma. Laryngoscope. 1998;108:1071-1076. [pmid: 9665259].
Ijaduola T G. Acute otalgia in Nigerian children. Trop Geogr Med. 1985;37:343-344. [pmid: 4095773].
Ikarashi F, Nakano Y, Okura T. The relationship between the degree of chronic middle ear inflammation and tympanic bulla pneumatization in the pig as animal model. Eur Arch Otorhinolaryngol. 1994;251:100-104. [pmid: 8024755].
Ikarashi F, Nakano Y, Okura T. Pneumatization of the tympanic bulla after blockage of the ventilation route through the eustachian tube in the pig. Ann Otol Rhinol Laryngol. 1996;105:784-790. [pmid: 8865773].
Ikeda K, Takasaka T. In vitro activity of ototopical drops against middle ear pathogens. Am J Otol. 1993;14:170-171. [pmid: 8389100].
Ikeda S, Tsuchihashi N, Kawashiro N, Kanzaki J. Management of acute otitis media. Assessment of therapeutic strategy in Japan today. Int J Technol Assess Health Care. 1994;10:426-435. [pmid: 8071004].
Ilecki H J, Baxter J D. Arctic audiology: trials, tribulations, and occasional successes. J Otolaryngol. 1981;10:294-298. [pmid: 6170765].
Illig P A. Successful approaches to reducing ear disease among native Alaskan children. Alaska Med. 1980;22:4-8. [pmid: 7406186].
Imamura N, Kato T, Suoya Y, Soda T, Shiraishi K, Morizono T. Changes in bone conduction audiograms in patients with otitis media. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:398–400.
Inagaki M, Sakakura Y, Shimizu T, Majima Y, Ukai K. Ultrastructure of mucous blanket in otitis media with effusion. Ann Otol Rhinol Laryngol. 1988;97:313-317. [pmid: 3377400].
Indudharan R, Dharap A S, Htun Y N. An unusual differential diagnosis of myringitis bullosa haemorrhagica. Trop Geogr Med. 1995;47:227-228. [pmid: 8553451].
Indudharan R, Haq J A. Use of pre-reduced swabs in bacteriology of chronic suppurative otitis media. J Laryngol Otol. 1996;110:950-951. [pmid: 8977860].
Infante-Rivard C, Fernandez A. Otitis media in children: frequency, risk factors, and research avenues. Epidemiol Rev. 1993;15:444-465. [pmid: 8174666].
Ingelstedt S, Jonson B, Rundcrantz H. Gas tension and pH in middle ear effusion. Ann Otol Rhinol Laryngol. 1975;84:198-202. [pmid: 235875].
Ingram T T. Intermittent hearing loss in young children. Dev Med Child Neurol. 1976;18:239-241. [pmid: 1278631].
Ingram J M. Nothing to sneeze about: allergies and allergic rhinitis. J Ark Med Soc. 1996;93:81-86. [pmid: 8800004].
Ingvarrson L, Lundegren K, Olofsson G. Epidemiology of acute otitis media in children-a chohort study in an urban population. In: Lim DJ, Bluestone CD, Klein JO, Nelson D, eds. Recent advances in otitis media with effusion. Philadephia (PA): BD Decker; 1984:19–22.
Ingvarsson L. Acute otalgia in children - findings and diagnosis. Acta Paediatrica Scandinavica. 1982;71:705-710. [pmid: 6891167].
Ingvarsson L, Lundgren K, Olofsson B. Incidence and Risk Factors of Acute Otitis Media in Children: Longitudinal Cohort Studies in an Urban Population. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:6–8.
Ingvarsson L, Bastos I, Westin L, Larsson A. Long-term follow-up of otitis-prone children: a prospective computerized study. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:54–55.
Inoue M, Arai S, Kawamura Y, et al. The prophylactic effect of trimethoprim-sulfamethoxazole on infections in children with acute leukaemia. DRUGS-EXP-CLIN-RES. 1983;9:35-43.
Irander K, Borres M P, Bjorksten B. Middle ear diseases in relation to atopy and nasal metachromatic cells in infancy. Int J Pediatr Otorhinolaryngol. 1993;26:1-9. [pmid: 7680334].
Isaac M L, Oliveira J A A, Holanda F. Importance of Otomicroscopy and Acoustic Imittance measurements for the early detection of effusion in the middle ear of asymptomatic children in a pediatric outpatient clinic. Revista Brasileira de Otorrinolaringologia. 1999;65:122-127.
Isaacman D J, Purvis K, Gyuro J, Anderson Y, Smith D. Standardized instructions: do they improve communication of discharge information from the emergency department?. Pediatrics. 1992;89:1204-1208. [pmid: 1594378].
Isaacs D. The management of otitis media with effusion: goodbye to grommets? Commentary. Curr Opin Pediatr. 1994;6:3-6. [pmid: 8205171].
Isaacson G, Rosenfeld R M. Care of the child with tympanostomy tubes: a visual guide for the pediatrician. Pediatrics. 1994;93:924-929. [pmid: 8190578].
Isaacson G. The natural history of a treated episode of acute otitis media. Pediatrics. 1996;98:968-971. [pmid: 8909497].
Isaacson G, Rosenfeld R M. Care of the child with tympanostomy tubes. Pediatr Clin North Am. 1996;43:1183-1193. [pmid: 8973507].
Ishida M. Otitis media with effusion (OME) in children. Otolaryngology Head and Neck Surgery. 1991;63:23-28.
Ishigami H, Nomura T, Yamada K. Sensory-neural hearing loss in acute otitis media. Pract Otol. 1985;78.
Ishigooka J, Wakatabe H, Shimada E, Suzuki M, Fukuyama Y, Murasaki M, Miura S. Rinsho Hyoka (Clinical Evaluation). 1993;21(3):441–490
Ishii N, Chiba M, Iizuka M, Masamune O, Kodama M, Ohta M. Sclerosing peritonitis associated with keratoconjunctivitis sicca, pleurisy, and secretory otitis media. Intern Med. 1993;32:311-315. [pmid: 8358122].
Ishikawa T, Bernstein J, Reisman R E, Arbesman C E. Secretory otitis media: immunologic studies of middle ear secretions. J Allergy Clin Immunol. 1972;50:319-325. [pmid: 4628904].
Ishizaka A, Sakiyama Y, Otsu M, Ozutsumi K, Matsumoto S. Successful intravenous immunoglobulin therapy for recurrent pneumococcal otitis media in young children. Eur J Pediatr. 1994;153:174-178. [pmid: 8181500].
Isoda K, Kitahara M, Kitano H. Treatment of endolymphatic hydrops caused by otitis media. Equilibrium Research. 1988;47:109-110.
Issing P R, Schonermark M, Kempf H G, Lenarz T. [Indications for middle ear obliteration within the scope of cochlear implant management]. Laryngorhinootologie. 1996;75:727-731. [pmid: 9081277].
Ito K, Wada K, Nomura Y, Fukazawa O, Hirabayashi C, Taguchi K. On fluctuation of hearing in otitis media with effusion after myringotomy. Auris Nasus Larynx. 1985;12:S255-S257. [pmid: 3835925].
Ito M, Tajima A, Nitta T, Sato K, Ishii S, Ragsdale B. Massive cranial ossifying myxoma in a child. Clin Neurol Neurosurg. 1990;92:271-275. [pmid: 2171838].
Ito Y, Shinogi J, Yuta A, Okada E, Taki M, Matsukage H. Clinical records: a case report of Wegener's granulomatosis limited to the ear. Auris Nasus Larynx. 1991;18:281-289. [pmid: 1799332].
Ito K, Ito Y, Mizuta K, et al. Bacteriology of chronic otitis media, chronic sinusitis, and paranasal mucopyocele in Japan. Clin Infect Dis. 1995;20:S214-S219. [pmid: 7548557].
Ivarsson A. A New Impedance Method for Measuring Middle Ear Mechanics and Eustachian Tube Function. Proceedings of the Second International Symposium: Recent Advances in Otitis Media with Effusion; 1980:207–210.
Iversen M, Birch L, Lundqvist G R, Elbrond O. Middle ear effusion in children and the indoor environment: an epidemiological study. Arch Environ Health. 1985;40:74-79. [pmid: 3923950].
Iwai N, Miyazu M, Nakamura H, Katayama M, Kasai K. Studies on rokitamycin in pediatrics. 41. 1988;7.
Iwaki E, Saito T, Tsuda G, et al. Timing for removal of tympanic ventilation tube in children. Auris Nasus Larynx. 1998;25:361-368. [pmid: 9853658].
Iwano T, Kinoshita T, Hamada E, Doi T, Ushiro K, Kumazawa T. Otitis media with effusion and eustachian tube dysfunction in adults and children. Acta Oto-Laryngologica - Supplement. 1993;500:66-69.
Iwano T, Ushiro K, Yukawa N, et al. Active opening function of the human eustachian tube: comparison between sonotubometry and pressure equilibration test. Acta Oto-Laryngologica - Supplement. 1993;500:62-65.
Jaber L, Gabriel R, Merlob P. Meconium aspiration and otitis media in children. Eur J Pediatr. 1993;152:164-165. [pmid: 8444228].
Jackler R K, Dillon W P, Schindler R A. Computed tomography in suppurative ear disease: a correlation of surgical and radiographic findings. Laryngoscope. 1984;94:746-752. [pmid: 6727511].
Jackler R K, Schindler R A. Role of the mastoid in tympanic membrane reconstruction. Laryngoscope. 1984;94:495-500. [pmid: 6708693].
Jackler R K. CT and MRI of the ear and temporal bone: Current state of the art and future prospects. Am J Otol. 1988;9:232-239. [pmid: 3052096].
Jackson C G, Levine S C, McKennan K X. Hemangioma of the middle ear. Am J Otol. 1987;8:131-132. [pmid: 3591920].
Jackson M A, Burry V F, Olson L C, Duthie S E, Kearns G L. Breakthrough sepsis in macrolide-resistant pneumococcal infection. Pediatr Infect Dis J. 1996;15:1049-1051. [pmid: 8933560].
Jackson CG, Pappas DG, Jr., Manolidis S, et al. Brain herniation into the middle ear and mastoid: concepts in diagnosis and surgical management. Am J Otol. 1997;18:198–205; discussion 205–206.
Jacob A, Rupa V, Job A, Joseph A. Hearing impairment and otitis media in a rural primary school in south India. Int J Pediatr Otorhinolaryngol. 1997;39:133-138. [pmid: 9104621].
Jacobs M R. Increasing importance of antibiotic-resistant Streptococcus pneumoniae in acute otitis media. Pediatr Infect Dis J. 1996;15:940-943. [pmid: 8895938].
Jacobson JA, Metcalf TJ, Parkin JL, Wenerstrom LG, Matsen JM. Evaluation of cefaclor and amoxycillin in the treatment of acute otitis media. Postgrad-Med-J. 1979:39–41.
Jacobsson S, Fogh A, Larsson P, Lomborg S. Evaluation of amoxicillin clavulanate twice daily versus thrice daily in the treatment of otitis media in children. Danish-Swedish Study Group. Eur J Clin Microbiol Infect Dis. 1993;12:319-324. [pmid: 8354296].
Jaeschke R, Guyatt G, Sackett D L. Users' guides to the medical literature: III. How to use an article about diagnostic test: A. Are the results of study valid?. J Am Med Assoc. 1994;271:389-391.
Jaffe B F. The incidence of ear diseases in the Navajo Indians. Laryngoscope. 1969;79:2126-2134. [pmid: 5362681].
Jahn A F, Tonndorf J. Lateralization of bone-conducted sounds. Am J Otolaryngol. 1982;3:133-140. [pmid: 7091540].
Jaisinghani V J, et al. Tympanic membrane/middle ear pathologic correlates in chronic otitis media. Laryngoscope. 1999;109:712-716. [pmid: 10334219].
Jaklis A, Tohme S. Coalescent mastoiditis in a child with severe congenital neutropenia. Report of a case. Journal Medical Libanais - Lebanese Medical Journal. 1996;44:96-99.
Jakob T, Wright C G, Robinson K, Meyerhoff W L. Ototoxicity of topical ticarcillin and clavulanic acid in the chinchilla. Arch Otolaryngol Head Neck Surg. 1995;121:39-43. [pmid: 7803021].
Jakubikova J, Zavodna M. Examinations of hearing by otoacoustic emissions in children after insertion of ventilation tubes. Otorinolaryngol Foniatr. 1999;48:6-10.
Jamal M N. Imaging and management of angiofibroma. Eur Arch Otorhinolaryngol. 1994;251:241-245. [pmid: 7917259].
Jamal T S. Avoidance of postoperative blockage of ventilation tubes. Laryngoscope. 1995;105:833-834. [pmid: 7543180].
James J M. Role of food allergy in serous otitis media [letter; comment]. Ann Allergy Asthma Immunol. 1995;74:277-278. [pmid: 7889388].
Jan M M. Facial paralysis: a presenting feature of rhabdomyosarcoma. Int J Pediatr Otorhinolaryngol. 1998;46:221-224. [pmid: 10190593].
Janeke J B. Recurrent otitis media in the young child [letter]. S Afr Med J. 1993;83:867. [pmid: 7839235].
Janeke J B. Foreign bodies in the ear canal--take them out, but look behind: [letter]. S Afr Med J. 1993;83:698. [pmid: 8310376].
Jang C H, Merchant S N. Histopathology of labyrinthine fistulae in chronic otitis media with clinical implications. Am J Otol. 1997;18:15-25. [pmid: 8989947].
Jansen C. Heterologous tympanoplasty. Transactions - American Academy of Ophthalmology and Otolaryngology. 1973;77:ORL111-6. [pmid: 4731493].
Jansen C. Cholesteatoma in children. Clin Otolaryngol Allied Sci. 1978;3:349-352. [pmid: 743779].
Janson H, Melhus A, Hermansson A, Forsgren A. Protein D, the glycerophosphodiester phosphodiesterase from Haemophilus influenzae with affinity for human immunoglobulin D, influences virulence in a rat otitis model. Infect Immun. 1994;62:4848-4854. [pmcid: 303197]. [pmid: 7927765].
Jantunen E, Koivula I. [Persistent ear infection, impaired hearing and fever]. Duodecim. 1994;110:1797-1799. [pmid: 7555776].
Janzen V D. Mastoid obliteration with primary ossicular reconstruction. J Otolaryngol. 1981;10:321-324. [pmid: 7299890].
Janzen V D. Ossiculoplasty using a hemi-incus interposition. J Otolaryngol. 1984;13:211-212. [pmid: 6471155].
Janzen V D, Schaefer D. Etiology of deafness in Robarts School for the Deaf. J Otolaryngol. 1984;13:47-48. [pmid: 6716551].
Jardine A. Diagnosing glue ear. Practitioner. 1989;233:985-986. [pmid: 2594679].
Jardine A, Rossdale M, Birchall MA. Are hearing tests performed in General Practice at the 3 [quarter] -year developmental assessment a reliable indicator of the presence of otitis media with effusion? Clin Otolaryngol Allied Sci. 1998;23.
Jardine A H, Maw A R, Coulton S. Dry tap at myringotomy: a three-year study of 1688 children undergoing myringotomy. Clin Otolaryngol Allied Sci. 1999;24:266-269. [pmid: 10472457].
Jardine A H, Griffiths M V, Midgley E. The acceptance of hearing aids for children with otitis media with effusion. J Laryngol Otol. 1999;113:314-317. [pmid: 10474663].
Jauris-Heipke S, Leake E R, Billy J M, DeMaria T F. The effect of antibiotic treatment on the release of endotoxin during nontypable Haemophilus influenzae-induced otitis media in the chinchilla. Acta Otolaryngol. 1997;117:109-112. [pmid: 9039490].
Jawahar S, Moody C, Chan M, Finberg R, Geha R, Chatila T. Natural Killer (NK) cell deficiency associated with an epitope-deficient Fc receptor type IIIA (CD16-II). Clin Exp Immunol. 1996;103:408-413. [pmid: 8608639].
Jecker P, Pabst R, Westermann J. The mucosa of the middle ear and Eustachian tube in the young rat: number of granulocytes, macrophages, dendritic cells, NK cells and T and B lymphocytes in healthy animals and during otitis media. Acta Otolaryngol. 1996;116:443-450. [pmid: 8790746].
Jehle D, Cottington E. Acoustic otoscopy in the diagnosis of otitis media. Ann-Emerg-Med. 1989;18:396-400. [pmid: 2650590].
Jensen J H, Leth N, Bonding P. Topical application of decongestant in dysfunction of the Eustachian tube: a randomized, double-blind, placebo-controlled trial. Clin-Otolaryngol. 1990;15:197-201. [pmid: 1697515].
Jensen PM, Lous J. Treatment of acute otitis medica in Danish general practice. Proceedings of the Sixth Internantional Symposium: Recent Advances in Otitis Media with Effusion; 1996:226–228.
Jensen W. Drug treatment of otitis media. S D J Med. 1997;50:137-138. [pmid: 9136263].
Jensen P M, Lous J. Criteria, performance and diagnostic problems in diagnosing acute otitis media. Fam Pract. 1999;16:262-268. [pmid: 10439980].
Jeppsson P, Nylen O, Liden G. Audiological aspects of acute otitis media. Acta Otolaryngol. 1973;75:439-442. [pmid: 4125920].
Jerger J. Clinical experience with impedance audiometry. Arch Otolaryngol. 1970;92:311-324. [pmid: 5455571].
Jerger J, Anthony L, Jerger S, Mauldin L. Studies in impedance audiometry. 3. Middle ear disorders. Arch Otolaryngol. 1974;99:165-171. [pmid: 4854446].
Jerger S, Jerger J, Mauldin L, Segal P. Studies in impedance audiometry. II. Children less than 6 years old. Arch Otolaryngol. 1974;99:1-9. [pmid: 4809082].
Jerger J F, Hayes D. The cross-check principle in pediatric audiometry. Arch Otolaryngol. 1976;102:614-620. [pmid: 971134].
Jerger S, Jerger J, Alford B R, Abrams S. Development of speech intelligibility in children with recurrent otitis media. Ear Hear. 1983;4:138-145. [pmid: 6862115].
Jero J, Virolainen A, Salo P, Leinonen M, Eskola J, Karma P. PCR assay for detecting Streptococcus pneumoniae in the middle ear of children with otitis media with effusion. Acta Otolaryngol. 1996;116:288-292. [pmid: 8725534].
Jero J, Virolainen A, Virtanen M, Eskola J, Karma P. Prognosis of acute otitis media: Factors associated with poor outcome. Acta Oto Laryngologica. 1997;117:278-283. [pmid: 9105466].
Jero J, Karma P. Prognosis of acute otitis media. Factors associated with the development of recurrent acute otitis media. Acta Oto-Laryngologica - Supplement. 1997;529:30-33.
Jero J, Karma P. Bacteriological findings and persistence of middle ear effusion in otitis media with effusion. Acta Oto-Laryngologica - Supplement. 1997;529:22-26.
Jesic S, Radulovic R, Arsovic N. Altered immunoregulations in otosclerosis: presence of autoantibodies in otosclerotic sera samples. Eur Arch Otorhinolaryngol Suppl. 1997;1:S50-S52.
Jimenez Antolin J A, Lasso Luis O, Munoz Platon E, Rodriguez Francos M, Galdeano Granda E. [Myringotomy and transtympanic ventilation tubes in secretory otitis media. A study of 108 children]. Acta Otorrinolaringol Esp. 1994;46:415-419. [pmid: 7873230].
Jin C S, Hamaguchi Y, Sakakura Y. ELISA to determine immunoreactive Pseudomonas aeruginosa elastase in chronic suppurative otitis media. International Archives of Allergy and Applied Immunology. 1991;96:193-198. [pmid: 1804790].
Jin Y T, Tsai S T, Li C, et al. Prevalence of human papillomavirus in middle ear carcinoma associated with chronic otitis media. Am J Pathol. 1997;150:1327-1333. [pmid: 9094989]. [pmcid: 1858153].
Job A, Kurien M, Jacob A, Mathew J. Bilateral simultaneous hearing preservation mastoidectomy in otogenic meningitis. Ann Otol Rhinol Laryngol. 1998;107:872-875. [pmid: 9794618].
Johansson U, Hellstrom S, Anniko M. Round window membrane in serous and purulent otitis media. Structural study in the rat. Ann Otol Rhinol Laryngol. 1993;102:227-235. [pmid: 8457125].
John W R, Valle-Jones J C. Treatment of otitis media in children. A comparison between cefaclor and amoxycillin. Practitioner. 1983;227:1805-1809. [pmid: 6361721].
Johnson R L. Chronic otitis media in school age Navajo Indians. Laryngoscope. 1967;77:1990-1995. [pmid: 6065524].
Johnson S E, Foord R D. Cephalexin dosage in general practice assessed by double-blind trial. Curr-Med-Res-Opin. 1972;1:37-48. [pmid: 4589401].
Johnson E W. Clinical application of special hearing tests. Arch Otolaryngol. 1973;97:92-95. [pmid: 4684914].
Johnson L P, Parkin J L, Stevens M H, et al. Action of general anesthesia on middle ear effusions. Arch Otolaryngol. 1980;106:100-102. [pmid: 7352900].
Johnson A P, Murray J A, Maran A G. Errors in the assessment of nasopharyngeal airway by radiography. J Laryngol Otol. 1983;97:1017-1026. [pmid: 6685747].
Johnson D W, Voorhees R L, Lufkin R B, Hanafee W, Canalis R. Cholesteatomas of the temporal bone: role of computed tomography. Radiology. 1983;148:733-737. [pmid: 6878694].
Johnson C E, Carlin S A, Super D M, et al. Cefixime compared with amoxicillin for treatment of acute otitis media. J Pediatr. 1991;119:117-122. [pmid: 1906097].
Johnson D L, Swank P, Howie V M, Baldwin C D, Owen M, Luttman D. Does HOME add to the prediction of child intelligence over and above SES?. J Genet Psychol. 1993;154:33-40. [pmid: 8331328].
Johnson M D, Contrino A, Contrino J, Maxwell K, Leonard G, Kreutzer D. Murine model of otitis media with effusion: immunohistochemical demonstration of IL-1 alpha antigen expression. Laryngoscope. 1994;104:1143-1149. [pmid: 8072363].
Johnson M D, Fitzgerald J E, Leonard G, Burleson J A, Kreutzer D L. Cytokines in experimental otitis media with effusion. Laryngoscope. 1994;104:191-196. [pmid: 8302123].
Johnson I J, Brooks T, Hutton D A, Birchall J P, Pearson J P. Compositional differences between bilateral middle ear effusions in otitis media with effusion: evidence for a different etiology?. Laryngoscope. 1997;107:684-689. [pmid: 9149175].
Johnson M, Leonard G, Kreutzer D L. Murine model of interleukin-8-induced otitis media. Laryngoscope. 1997;107:1405-1408. [pmid: 9331321].
Johnston O. III health and developmental delays in Adelaide four-year-old children. Australian Paediatric Journal. 1980;16:248-254. [pmid: 6165347].
Johnstone D E. Decongestant-antihistamine combination for otitis media with effusion in children. N Engl J Med. 1598;308:1598-1599.
Johonnott S C. Differences in chronic otitis media between rural and urban Eskimo children: a comparative study. Clin Pediatr. 1973;12:415-419.
Jolin S W, Howell J M. Infrared emission detection tympanic thermometry [letter; comment]. Am J Emerg Med. 1995;13:605. [pmid: 7662066].
Jolin S W, Howell J M, Milzman D P, Stair T O, Butzin C A. Infrared emission detection tympanic thermometry may be useful in diagnosing acute otitis media [see comments]. Am J Emerg Med. 1995;13:6-8. [pmid: 7832959].
Jonathan D A. Sonotubometry: its role in childhood glue ear. Clin Otolaryngol Allied Sci. 1989;14:151-154. [pmid: 2721016].
Jones R F. Long-term investigation of hearing in otitis media. Proceedings of the Royal Society of Medicine. 1970;63:742-744. [pmid: 5434233]. [pmcid: 1811495].
Jones H M. Cranial pneumatocele. Proceedings of the Royal Society of Medicine. 1970;63:257-262. [pmid: 5445566]. [pmcid: 1811324].
Jones R F. The aftermath of acute otitis media. Adverse factors. Practitioner. 1970;204:583. [pmid: 5443549].
Jones H M. The problem of recurrent meningitis. Proceedings of the Royal Society of Medicine. 1974;67:1141-1147. [pmid: 4438297]. [pmcid: 1646039].
Jones E A Jr, Thomas L R, Davis N C. The significance of secretory IgA in middle ear fluid. Annals of Allergy. 1979;42:236-240. [pmid: 571255].
Jones R O, Pillsbury H C. Histiocytosis X of the head and neck. Laryngoscope. 1984;94:1031-1035. [pmid: 6611470].
Jones R, Bain J. Three-day and seven-day treatment in acute otitis media: a double-blind antibiotic trial. J-R-Coll-Gen-Pract. 1986;36:356-358. [pmid: 3735223].
Jones N S. Cerebrospinal fluid otorrhea at myringotomy. A meningocele through a defect in the tegmen. Int J Pediatr Otorhinolaryngol. 1991;21:79-83. [pmid: 2037421].
Jones R N. Can antimicrobial activity be sustained? An appraisal of orally administered drugs used for respiratory tract infections. Diagn Microbiol Infect Dis. 1997;27:21-28. [pmid: 9127102].
Jorgensen F, Holmquist J. Toynbee phenomenon and middle ear disease. Am J Otol. 1984;5:291-294. [pmid: 6539080].
Jorgensen F, Andersson B, Larsson SH, Nylen O, Eden CS. Children with Frequent Attacks of Acute Otitis Media: A Re-Examination after Eight Year. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:141–145.
Jorgensen F, Andersson B, Hanson L A, Nylen O, Eden C S. Gamma-globulin treatment of recurrent acute otitis media in children. Pediatr Infect Dis J. 1990;9:389-394. [pmid: 2367159].
Jorgensen F, Hansson H A, Petruson B, Andersson B. Nasal mucosal changes in children treated with gammaglobulin. Aspects on middle ear pathology and nasopharyngeal bacteriology. Acta Otolaryngol. 1991;111:785-796. [pmid: 1950543].
Josebe Unzaga M, Rojo P, Pardo C, Melero P, Cisterna R. [Alloiococcus otitidis: a more common microorganism than we thought? (letter)]. Enferm Infecc Microbiol Clin. 1997;15:174-175. [pmid: 9235069].
Joseph P R. Otitis media in practice [letter; comment]. Clin Pediatr. 1993;32:512.
Jossart G H, Canafax D M, Erdmann G R, et al. Effect of Streptococcus pneumoniae and influenza A virus on middle ear antimicrobial pharmacokinetics in experimental otitis media. Pharm Res. 1994;11:860-864. [pmid: 7937526].
Jubb T F, Vassallo R I, Wroth R H. Suppurative otitis in cattle associated with ear mites (Raillietia auris). Aust Vet J. 1993;70:354-355. [pmid: 8240177].
Juers A L. Traumatic tympanic perforation. Transactions - American Academy of Ophthalmology and Otolaryngology. 1974;78:ORL261-3. [pmid: 4855250].
Juhn S K, Tolan C T, Garvis W J, Cross D S, Giebink G S. The levels of IL-1 beta in human middle ear effusions. Acta Oto-Laryngologica - Supplement. 1992;493:37-42.
Juhn S K, Garvis W J, Lees C J, Le C T, Kim C S. Determining otitis media severity from middle ear fluid analysis. Ann Otol Rhinol Laryngol Suppl. 1994;163:43-45. [pmid: 8179269].
Julien G, Baxter J D, Crago M, Ilecki H J, Therien F. Chronic otitis media and hearing deficit among native children of Kuujjuaraapik (Northern Quebec): a pilot project. Can J Public Health. 1987;78:57-61. [pmid: 3828942].
Julien N, Perie S, Lassen C, Sevali Garcia J, Sterkers O. [Bacterial epidemiology of chronic otitis. Prophylactic and therapeutic deductions]. Ann Otolaryngol Chir Cervicofac. 1993;110:81-86. [pmid: 8363301].
Jung T T K. Classification of otitis media and surgical principles. Otolaryngol Clin North Am. 1999 Jun;32:369-383. [pmid: 10393773].
Juni P, Witschi A, Bloch R, Egger M. The hazards of scoring the quality of clinical trials for meta-analysis. J Am Med Assoc. 1999;282:1054-1060.
Jury S C. Prevention of severe mucosecretory ear disease and its complications in patients with cleft lip and palate malformations. Folia Phoniatr Logop. 1997;49:177-180. [pmid: 9256539].
Kaada B, Hognestad S, Havstad J. Transcutaneous nerve stimulation (TNS) in tinnitus. Scand Audiol. 1989;18:211-217. [pmid: 2609098].
Kafetzis D A. Multi-investigator evaluation of the efficacy and safety of cefprozil, amoxicillin-clavulanate, cefixime and cefaclor in the treatment of acute otitis media. Eur J Clin Microbiol Infect Dis. 1994;13:857-865. [pmid: 7889960].
Kafetzis D A, Malaka-Zafiriou C, Bairamis T, Roilides E, Valeri R, Stamler D A. Comparison of the efficacy and tolerability of clarithromycin suspension and cefuroxime axetil suspension in the treatment of acute otitis media in paediatric patients. Clinical Drug Investigation. 1997;14:192-199.
Kafetzis D A, Astra H, Mitropoulos L. Five-day versus ten-day treatment of acute otitis media with cefprozil. Eur J Clin Microbiol Infect Dis. 1997;16:283-286. [pmid: 9177961].
Kaga K, Ichimura K. A preliminary report: clinical effects of otic solution of ofloxacin in infantile myringitis and chronic otitis media. Int J Pediatr Otorhinolaryngol. 1998;42:199-205. [pmid: 9466223].
Kahonen K, Palva T, Bergroth V, Konttinen Y T, Reitamo S. Immunohistochemical identification of inflammatory cells in secretory and chronic otitis media and cholesteatoma using monoclonal antibodies. Acta Otolaryngol. 1984;97:431-436. [pmid: 6380206].
Kaleida P H, Bluestone C D, Rockette H E, et al. Amoxicillin-clavulanate potassium compared with cefaclor for acute otitis media in infants and children [published erratum appears in Pediatr Infect Dis J 1987 Aug;6(8):734]. Pediatr Infect Dis J. 1987;6:265-271. [pmid: 3554125].
Kaleida P H, Casselbrant M L, Rockette H E, et al. Amoxicillin or myringotomy or both for acute otitis media: results of a randomized clinical trial. Pediatrics. 1991;87:466-474. [pmid: 2011422].
Kaleida P H, Stool S E. Assessment of otoscopists' accuracy regarding middle-ear effusion. Otoscopic validation. Am J Dis Child. 1992;146:433-435. [pmid: 1558077].
Kaleida PH, Stool SE, Karabin JC. Assessment of otoscopic accuracy in diagnosis of middle-ear effusion in children (“otoscopic validation”). Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:41.
Kaleida PH, Hoberman A, Smith CG. Assessment and enhancement of otoscopic diagnostic accuracy using videotaped otoendoscopic examinations. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:160.
Kallail K J, Rainbolt H R, Bruntzel M D. Passive smoking and middle ear problems in Kansas public school children. J Commun Disord. 1987;20:187-196. [pmid: 3597819].
Kalm O, Prellner K, Christensen P. The effect of intravenous immunoglobulin treatment in recurrent acute otitis media. Int J Pediatr Otorhinolaryngol. 1986;11:237-246. [pmid: 3533818].
Kalm O, Johnson U, Prellner K. HLA frequency in patients with chronic secretory otitis media. Int J Pediatr Otorhinolaryngol. 1994;30:151-157. [pmid: 8063501].
Kalpana R, Chamyal P C. Study of prevalence and aetiology of the hearing loss amongst school going children. Indian Journal of Otolaryngology and Head and Neck Surgery. 1997;49:142-144.
Kameswaran S, Kumar P V, Jeyapaul J I, Manoharan S. Audiological and haematological studies on the Todas of Nilgiris. J Laryngol Otol. 1976;90:325-333. [pmid: 1270907].
Kamimura M, Himi T, Kataura A. Cell adhesion molecules of experimental otitis media in the rat. Acta Otolaryngol. 1996;116:857-862. [pmid: 8973722].
Kamimura M, Himi T, Kataura A. In vitro regulation of neutrophil migration by beta 2 integrins (LFA-1 and Mac-1) in patients with otitis media. Eur Arch Otorhinolaryngol. 1997;254:150-152. [pmid: 9112036].
Kaneko A, Doi T, Hosoda Y, Iwano T, Yamashita T. Direct measurement of eustachian tube compliance. Acta Otolaryngol. 1996;116:594-598. [pmid: 8831848].
Kaneko Y, Takasaka T, Sakuma M, Kambayashi J, Okitsu T. Middle ear inflation as a treatment for secretory otitis media in children. Acta Otolaryngol. 1997;117:564-568. [pmid: 9288213].
Kangsanarak J, Fooanant S, Ruckphaopunt K, Navacharoen N, Teotrakul S. Extracranial and intracranial complications of suppurative otitis media. Report of 102 cases. J Laryngol Otol. 1993;107:999-1004. [pmid: 8288994].
Kangsanarak J, Navacharoen N, Fooanant S, Ruckphaopunt K. Intracranial complications of suppurative otitis media: 13 years' experience. Am J Otol. 1995;16:104-109. [pmid: 8579165].
Kanzaki J, Taiji H, Kanke H, Shiga H. Evaluation of the eustachian tube in normal subjects and in patients with otitis media with effusion by high resolution computerized tomography. Auris Nasus Larynx. 1985;12:S52-S54. [pmid: 3835936].
Kapidzic A, Basic F, Volic A. [Anaerobic bacteria in chronic otitis media]. Med Arh. 1995;49:27-29. [pmid: 9324554].
Kaplan G J, Fleshman J K, Bender T R, Baum C, Clark P S. Long-term effects of otitis media: a ten-year cohort study of Alaskan Eskimo children. Pediatrics. 1973;52:577-585. [pmid: 4742253].
Kaplan S L, Mason E O Jr. Antimicrobial agents: resistance patterns of common pathogens. Pediatr Infect Dis J. 1994;13:1050-1053. [pmid: 7845739].
Kaplan D M, Leiberman A, Noghreyan A, Fliss D M. Acute Salmonella mastoiditis in an infant. Int J Pediatr Otorhinolaryngol. 1995;32:87-91. [pmid: 7607825].
Kaplan D M, Fliss D M, Kraus M, Dagan R, Leiberman A. Audiometric findings in children with chronic suppurative otitis media without cholesteatoma. Int J Pediatr Otorhinolaryngol. 1996;35:89-96. [pmid: 8735405].
Kaplan S L. Streptococcus pneumoniae: impact of antibiotic resistance in pediatrics. Curr Probl Pediatr. 1997;27:187-195. [pmid: 9167096].
Kaplan B, Wandstrat T L, Cunningham J R. Overall cost in the treatment of otitis media. Pediatr Infect Dis J. 1997;16:S9-S11. [pmid: 9041621].
Kaplan D M, Kraus M, Puterman M, Niv A, Leiberman A, Fliss D M. Otogenic lateral sinus thrombosis in children. Int J Pediatr Otorhinolaryngol. 1999;49:177-183. [pmid: 10519696].
Kapur Y P, Oyer H J. Ear disease in developing countries: a proposal. Folia Phoniatr Logop. 1996;48:150-155. [pmid: 8768368].
Kara C O, Ozuer M Z, Kilic I, Yalcin A N, Ergin H. Comparison of amoxicillin with second and third generation cephalosporins in the treatment of acute otitis media. Infezioni in Medicina. 1998;6:93-95. [pmid: 12750572].
Karabaev KE, Antoniv VF, Bekmuradov RU. [Pathogenetic validation of optimal antioxidant therapy in suppurative inflammatory otic diseases in children]. Vestn Otorinolaringol. 1997:5–7.
Karjalainen H. Cellular events in relation to bacteria-specific antibodies in middle ear effusion during acute otitis media. Acta Otolaryngol. 1991;111:750-755. [pmid: 1950538].
Karjalainen H, Koskela M, Luotonen J, Sipila P. Secretory antibodies specific to Streptococcus pneumoniae, Haemophilus influenzae and Branhamella catarrhalis in middle ear effusion during acute otitis media. Acta Otolaryngol. 1991;111:524-529. [pmid: 1909486].
Karjalainen H, Koskela M, Luotonen J, Herva E, Sipila P. Occurrences of antibodies against Streptococcus pneumoniae, Haemophilus influenzae and Branhamella catarrhalis in middle ear effusion and serum during the course of acute otitis media. Acta Otolaryngol. 1991;111:112-119. [pmid: 1901685].
Karkanevatos A, Lesser T H. Grommet insertion in children: a survey of parental perceptions. J Laryngol Otol. 1998;112:732-741. [pmid: 9850314].
Karlsson Y. [Antibiotics in acute otitis a touchstone in the debate on resistance]. Lakartidningen. 1997;94:3021. [pmid: 9312622].
Karma P, Pukander J, Sipila M, et al. Prevention of otitis media in children by pneumococcal vaccination. Am J Otolaryngol. 1985;6:173-184. [pmid: 3893185].
Karma PH, Penttila MA, Sipila MM, Timonen MS. Diagnostic Value of Otoscopic Signs in Acute Otitis Media. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:44–47.
Karma P, Sipila M, Rahko T. Hearing and hearing loss in 5-year-old children. Pure-tone thresholds and the effect of acute otitis media. Scand Audiol. 1989;18:199-203. [pmid: 2609096].
Karma P H, Penttila M A, Sipila M M, Kataja M J. Otoscopic diagnosis of middle ear effusion in acute and non-acute otitis media. I. The value of different otoscopic findings. Int J Pediatr Otorhinolaryngol. 1989;17:37-49. [pmid: 2707977].
Karma PH, Sipila MM, Kataja MJ, Penttila MA. Pneumatic otoscopy and otitis media. I. Value of different tympanic membrane findings and their combinations. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:41–45.
Karma PH, Sipila MM, Rahko KT. Hearing and history of acute otitis media in childhood. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:552–554.
Karma P H, Bakaletz L O, Giebink G S, Mogi G, Rynnel-Dagoo B. Immunological aspects of otitis media: present views on possibilities of immunoprophylaxis of acute otitis media in infants and children. Int J Pediatr Otorhinolaryngol. 1995;32:S127-S134. [pmid: 7665281].
Karma PH, Laitila P, M.E., Sipila M, Manninen MP, Rahko T. Sensorineural hearing and childhood acute otitis media in adolescents. In: Lim DJ, Bluestone CD, Casselbrant M, Klein JO, Ogra PL, eds. Proceedings of the Sixth International Symposium on Recent Advances in Otitis Media. Hamilton: BC Decker; 1995:387.
Karma PH, Laitila PME, Sipila M, Manninen MP, Rahko KT. Sensorineural hearing and childhood acute otitis media in adolescents. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:367–369.
Karov I. Preoperative treatment of children with chronic suppurative otitis media. Folia Med. 1996;38:63-69.
Kasemsuwan L, Schachern P, Paparella M M, Le C T. Residual mesenchyme in temporal bones of children. Laryngoscope. 1996;106:1040-1043. [pmid: 8699897].
Kasemsuwan L, Clongsuesuek P. A double blind, prospective trial of topical ciprofloxacin versus normal saline solution in the treatment of otorrhoea. Clin-Otolaryngol. 1997;22:44-46. [pmid: 9088679].
Kass J R, Beebe M E. Serous otitis media. Nurse Pract. 1979;4:25-28. [pmid: 264234].
Katz S, Schmelzer B, Van Rompaey D. Surgical management of chronic otitis media with effusion. Acta Otorhinolaryngol Belg. 1995;49:69-73. [pmid: 7725924].
Kavanagh K T, Clark S T. Comparison of the mastoid to vertex and mastoid to high forehead electrode arrays in recording auditory evoked potentials. Ear Hear. 1989;10:259-261. [pmid: 2776987].
Kawabata I, Nomura Y, Kikuchi K. Azeptin(TM)'s efficacy in patients with otitis media with effusio. Practica Otologica. 1993;86:895-909.
Kawakami M, Hattori Y, Nakamura S. Reflection of structural abnormality in the axoneme of respiratory cilia in the clinical features of immotile cilia syndrome. Intern Med. 1996;35:617-623. [pmid: 8894735].
Kawamoto K. Clinical and experimental studies on the pathogenesis of otitis media with effusion. Auris Nasus Larynx. 1985;12:S11-S14. [pmid: 3835880].
Kawamura S, Sugita R, Fujimaki T, et al. A randomized, controlled trial of bacampicillin vs. cephalexin in the treatment of acute purulent otitis media. PRACT-OTOL-(KYOTO). 1985;78:1147-1165.
Kawana M, Kawana C, Amesara R, Juhn S K, Giebink G S. Neutrophil oxygen metabolite inhibition of cultured chinchilla middle ear epithelial cell growth. Ann Otol Rhinol Laryngol. 1994;103:812-816. [pmid: 7944174].
Kawana M. Early inflammatory changes of the Haemophilus influenzae-induced experimental otitis media. Auris Nasus Larynx. 1995;22:80-85. [pmid: 7487677].
Kawanami M, Sato N, Kashiwamura M, et al. [Evoked oto-acoustic emissions in patients with secretory otitis media]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1993;96:1423-1429.
Kawasaki Y, Sakamoto Y, Honmura Y, et al. Long-term results of ventilation tube for otitis media with effusion in children. Auris Nasus Larynx. 1985;12:S225-S227. [pmid: 3835916].
Kawata R, Mizukoshi O, Kuriyama K, Urade Y. Prostaglandin content in human middle ear effusions. Arch Otorhinolaryngol. 1989;246:133-136. [pmid: 2757560].
Kayhty H, Eskola J. New vaccines for the prevention of pneumococcal infections. Emerg Infect Dis. 1996;2:289-298. [pmid: 8969245].
Kazama S, Yagihashi T, Morita T, Awakura T, Shimada A, Umemura T. Isolation of Mycoplasma hyorhinis and Mycoplasma arginini from the ears of pigs with otitis media. Res Vet Sci. 1994;56:108-110. [pmid: 8146440].
Kazanas S G, Maw A R. Tympanometry, stapedius reflex and hearing impairment in children with otitis media with effusion. Acta-Otolaryngol-Stockh. 1994;114:410-414. [pmid: 7976313].
Kean H. Current concepts of otitis media. IMS - Industrial Medicine and Surgery. 1971;40:19-21.
Kearns G L, Reed M D, Jacobs R F, Ardite M, Yogev R D, Blumer J L. Single-dose pharmacokinetics of ceftibuten (SCH 39720) in infants and children. Antimicrob-Agents-Chemother. 1991;35:2078-2084. [pmcid: 245329]. [pmid: 1759830].
Kearns G L, Young R A. Ceftibuten pharmacokinetics and pharmacodynamics. Focus on paediatric use. Clin Pharmacokinet. 1994;26:169-189. [pmid: 8194281].
Keating L W, Fria T J. Report on the status of calibration of bone vibrators in selected clinics. Audiology. 1974;13:205-211. [pmid: 4415568].
Kedjanyi W K, Bath A P, Ball R Y, Hosni A A, Wickstead M. Metastatic adenocarcinoma of the temporal bone. J Laryngol Otol. 1994;108:710-712. [pmid: 7930930].
Keim R J. Common ear diseases: recognition and management. Postgrad Med. 1977;61:72-80. [pmid: 857250].
Keim R J, Erdreich J, Love T J. Thermal hazards in mastoid surgery: an evaluation of instruments and irrigation techniques. Otolaryngology and Head and Neck Surgery. 1979;87:472-478. [pmid: 503508].
Keith R W, Murphy K P, Martin F. Acoustic impedance measurement in the otological assessment of multiply handicapped children. Clin Otolaryngol Allied Sci. 1976;1:221-224. [pmid: 144574].
Kelly B, Alexander D. Effect of otitis media on infrared tympanic thermometry. Clin Pediatr. 1991;30:46–48; discussion 49.
Kelly H A, Weeks S A. Ear disease in three aboriginal communities in Western Australia [see comments]. Med J Aust. 1991;154:240-245. [pmid: 1994196].
Kelly K M. Recurrent otitis media: genetic immunoglobulin markers in children and their parents [letter]. Int J Pediatr Otorhinolaryngol. 1993;25:279-280. [pmid: 8436478].
Kemaloglu Y K, Goksu N, Ozbilen S, Akyildiz N. Otitis media with effusion and craniofacial analysis-II: “Mastoid-middle ear-eustachian tube system” in children with secretory otitis media. Int J Pediatr Otorhinolaryngol. 1995;32:69-76. [pmid: 7607822].
Kemaloglu Y K. Developmental anatomy of the supratubal recess in temporal bones from fetuses and children [letter; comment]. Am J Otol. 1997;18:125-126. [pmid: 8989962].
Kemaloglu Y K, Sener T, Beder L, Bayazit Y, Goksu N. Predictive value of acoustic reflectometry (angle and reflectivity) and tympanometry. Int J Pediatr Otorhinolaryngol. 1999;48:137-142. [pmid: 10375039].
Kempf H G, Johann K, Weber B P, Lenarz T. Complications of cochlear implant surgery in children. Am J Otol. 1997;18:S62-S63. [pmid: 9391600].
Kempthorne J, Giebink G S. Pediatric approach to the diagnosis and management of otitis media. Otolaryngol Clin North Am. 1991;24:905-929. [pmid: 1870882].
Kendall G, Inglis M. The experience of parenting a child with glue ear. Nursing Praxis in New Zealand. 1993;8:27-33.
Kenna M A, Bluestone C D, Reilly J S, Lusk R P. Medical management of chronic suppurative otitis media without cholesteatoma in children. Laryngoscope. 1986;96:146-151. [pmid: 3945144].
Kenna MA, Bluestone CD. Medical Management of Chronic Suppurative Otitis Media Without Cholesteatoma. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:222–226.
Kenna MA, Bluestone CD, Fall P, et al. Cefixime versus cefaclor in treatment of acute otitis media with effusion. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:217–218.
Kenna M A, Rosane B A, Bluestone C D. Medical management of chronic suppurative otitis media without cholesteatoma in children--update 1992. Am J Otol. 1993;14:469-473. [pmid: 8122710].
Kenna M A. Treatment of chronic suppurative otitis media. Otolaryngol Clin North Am. 1994;27:457-472. [pmid: 8065753].
Kenna MA BC, Fall P, Stephenson J, Kurs-Lasky M, Wucher FP, Blatter MM, Reisinger KS. Cefuroxime axetil versus cefaclor in treatment of acute otitis media. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:214–216.
Kennedy T L, Gore L B. Middle ear effusions and the nitrous oxide myth. Laryngoscope. 1982;92:169-172. [pmid: 7162312].
Kenney R D, Fortenberry J D, Surratt S S, Ribbeck B M, Thomas W J. Evaluation of an infrared tympanic membrane thermometer in pediatric patients [see comments]. Pediatrics. 1990;85:854-858. [pmid: 2330251].
Keohane J. Hearing aids in glue ear. Br Med J. 1970;1:367. [pmid: 5429471].
Keohane J D, Ruby R R, Janzen V D, MacRae D L, Parnes L S. Medial meatal fibrosis: the University of Western Ontario experience. Am J Otol. 1993;14:172-175. [pmid: 8503492].
Kerr A G, Byrne J E. Concussive effects of bomb blast on the ear. J Laryngol Otol. 1975;89:131-143. [pmid: 1123564].
Kerr A G, Toner J G, McKee G J, Smyth G D. Role and results of cortical mastoidectomy and endolymphatic sac surgery in Meniere's disease. J Laryngol Otol. 1989;103:1161-1166. [pmid: 2614237].
Kessler M E, Randolph K. The effects of early middle ear disease on the auditory abilities of third grade children. J Acad Rehabil Audiol. 1984;12:6-20.
Kessner D M, Kalk C E, Singer J. Assessing health quality--the case for tracers. N Engl J Med. 1973;288:189-194. [pmid: 4682231].
Kessner D M. Screening high-risk populations: a challenge to primary medical care. J Community Health. 1976;1:216-225. [pmid: 1002864].
Khakimov AM, Arifov SS, Faizulaeva FN. [Atypical thrombosis of venous collectors of posterior cranial fossa as a complication of chronic otitis media, purulent]. Vestn Otorinolaringol. 1997:55.
Khan N A. The L-shaped homograft incus as substitute for the ossicular chain and bridge plasty in radical cavities. Acta Otorhinolaryngol Belg. 1974;28:627-634. [pmid: 4440492].
Khan J A, Marcus P, Cummings S W. S-carboxymethylcysteine in otitis media with effusion. (A double-blind study). J Laryngol Otol. 1981;95:995-1001. [pmid: 7028897].
Khan JA. A comparative study of mucodyne and a decongestant combination in otitis media with effusion. FORUM SER R SOC MED, No. 1982.
Khan N A. Technique and clinical importance of eustachian tube radiography. Am J Otol. 1985;6:222-224. [pmid: 4003529].
Khasanov SA, Omonov Sh E, Setvaldieva IA. [Chronic suppurative otitis media complicated by septicemia and disseminated intravascular coagulation syndrome in a 2-year-old child]. Vestn Otorinolaringol. 1995:49.
Khasanov SA, Omonov SE. [Outcomes of heterobrephomastoidoplasty in surgical treatment of chronic otitis media purulent in children]. Vestn Otorinolaringol. 1997:17–18.
Khurana C M. A multicenter, randomized, open label comparison of azithromycin and amoxicillin/clavulanate in acute otitis media among children attending day care or school. Pediatr Infect Dis J. 1996;15:S24-S29. [pmid: 8878243].
Kieserman S P, Stern J. Malignant transformation of nasopharyngeal lymphoid hyperplasia. Otolaryngol Head Neck Surg. 1995;113:474-476. [pmid: 7567024].
Kikuchi S, Yamasoba T, Iinuma T. An analysis of bone destruction in cholesteatomas by high resolution computed tomography. Auris Nasus Larynx. 1993;20:11-17. [pmid: 8323487].
Kikuchi A, Funakubo T, Kohsyu H. A study of fungal infections in otorhinolaryngology. Acta Oto-Laryngologica - Supplement. 1994;511:224-227.
Kikuno K, Goto S, Iwasaki H, et al. [Two patients with acute promyelocytic leukemia whose relapse was noted by cytodiagnosis of middle ear discharge]. Rinsho Ketsueki - Japanese Journal of Clinical Hematology. 1996;37:323-328.
Kilby D, Richards S H, Hart G. Grommets and glue ears: two-year results. J Laryngol Otol. 1972;86:881-888. [pmid: 5070299].
Kim H K, Bluestone C D, Blatter M M, et al. Comparison of bacampicillin and amoxicillin in acute otitis media with effusion. Bull-N-Y-Acad-Med. 1983;59:515-523. [pmid: 6349733].
Kim J Y, Lee C H. Clinical study on the efficacy of tonsilloadenoidectomy. Acta Oto Laryngologica Supplement. 1988;106:265-272.
Kim D G, Hong S C, Kim H J, et al. Cerebral aspergillosis in immunologically competent patients. Surg Neurol. 1993;40:326-331. [pmid: 8211644].
Kim C S, Jung H W, Yoo K Y. Prevalence of otitis media and allied diseases in Korea--results of a nation-wide survey, 1991. J Korean Med Sci. 1993;8:34-40. [pmid: 8343220].
Kim C S, Jung H W, Yoo K Y. Prevalence and risk factors of chronic otitis media in Korea: results of a nation-wide survey. Acta Otolaryngol. 1993;113:369-375. [pmid: 8517141].
Kim C S, Kim H J. Auditory brain stem response changes after application of endotoxin to the round window membrane in experimental otitis media. Otolaryngol Head Neck Surg. 1995;112:557-565. [pmid: 7700662].
Kimball S. Acoustic reflectometry: spectral gradient analysis for improved detection of middle ear effusion in children. Pediatr Infect Dis J. 1998;17:552–555; discussion 580.
King J T. Modified exploratory anterior tympanotomy in chronic secretory otitis media in children. Transactions - American Academy of Ophthalmology and Otolaryngology. 1972;76:1292-1295. [pmid: 4666579].
King G E, Markowitz L E, Heath J, et al. Antibody response to measles-mumps-rubella vaccine of children with mild illness at the time of vaccination. JAMA. 1996;275:704-707. [pmid: 8594268].
Kinney S E, Wood B G. Surgical treatment of skull-base malignancy. Otolaryngol Head Neck Surg. 1984;92:94-99. [pmid: 6422425].
Kinney S E. Intact canal wall tympanoplasty with mastoidectomy for cholesteatoma: long-term follow-up. Laryngoscope. 1988;98:1190-1194. [pmid: 3185073].
Kinnman J, Lke C W. Cerebrospinal fluid otorrhoea. J Laryngol Otol. 1966;80:66-72. [pmid: 5902155].
Kinoshita K. [The roles of interleukin-1 alpha, tumor necrosis factor-alpha and parathyroid hormone-related protein in bone resorption of cholesteatoma otitis]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1994;97:1472-1480.
Kinsella J B, Fenton J, Donnelly M J, McShane D P. Tympanostomy tubes and early post-operative otorrhea. Int J Pediatr Otorhinolaryngol. 1994;30:111-114. [pmid: 8063496].
Kinsella J B, O'sullivan P, McShane D P. The role of the middle ear and tonsil in the etiology of febrile convulsions. Int J Pediatr Otorhinolaryngol. 1995;32:153-157. [pmid: 7657469].
Kirkwood C R, Kirkwood M E. Otitis media and learning disabilities: The case for a causal relationship. J Fam Pract. 1983;17:219-227. [pmid: 6348203].
Kiroglu M M, Aydogan B. Plain roentgenographic changes of the paranasal sinuses in cases with and without otitis media with effusion. Annals of Medical Sciences. 1996;5:84-86.
Kiroglu M, Tap O, Mete U O, et al. Ultrastructure of the nasopharyngeal orifice epithelium of the eustachian tube in otitis media with effusion. J Submicrosc Cytol Pathol. 1997;29:79-84. [pmid: 9066145].
Kiroglu M M, Ozbilgin K, Aydogan B, et al. Adenoids and otitis media with effusion: a morphological study. Am J Otolaryngol. 1998;19:244-250. [pmid: 9692633].
Kirsch C M, Wehner J H, Jensen W A, Kagawa F T, Campagna A C. Tuberculous otitis media. South Med J. 1995;88:363-366. [pmid: 7886539].
Kirtane M V, Merchant S N, Raje A R, Zantye S P, Shah K L. Sensorineural hearing loss in chronic otitis media--a statistical evaluation. J Postgrad Med. 1985;31:183-186. [pmid: 3834081].
Kitanoski B, Haralampiev K. Differentially diagnostic problems concerning conductive hearing loss. Symp Otorhinolaryngol Iugosl. 1984;19:253-258.
Kitchens G G. Relationship of environmental tobacco smoke to otitis media in young children. Laryngoscope. 1995;105:1-13. [pmid: 7760681].
Kiuchi S. Diagnostic value of axial CT scan. Otolaryngology. 1983;55:167-178.
Kivimae P. Long tympanostomy tubes increase the possibility to live a normal life. Lakartidningen. 1983;80.
Kjellman N I, Synnerstad B, Hansson L O. Atopic allergy and immunoglobulins in children with adenoids and recurrent otitis media. Acta Paediatrica Scandinavica. 1976;65:593-600. [pmid: 961411].
Kjellman N I, Harder H, Lindwall L, Synnerstad B. Longterm treatment with brompheniramine and phenylpropanolamine in recurrent otitis media--a double-blind study. J-Otolaryngol. 1978;7:257-61. [pmid: 357754].
Klein J O. Design factors in the assessment of intelligence. Ann Otol Rhinol Laryngol. 1979;88:99-106.
Klein S W, Olson A L, Perrin J, et al. Prevention and treatment of serous otitis media with an oral antihistamine. A double-blind study in pediatric practice. Clin-Pediatr-Phila. 1980;19:342-347. [pmid: 6767576].
Klein JO. Persistent middle ear effusions: Natural history and morbidity. Pediatr Infect Dis. 1982;1.
Klein J O. Otitis media and the development of speech and language. Pediatr Infect Dis. 1984;3:389-391. [pmid: 6206480].
Klein J O. Antimicrobial prophylaxis for recurrent acute otitis media. Pediatr Ann. 1984;13:398-403. [pmid: 6539903].
Klein JO, D.W. T, R. M, P. M, B.A. R. Otitis Media with Effusion During the First Three Years of Life and Development of Speech and Language. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:332–334.
Klein J O. Emerging perspectives in management and prevention of infections of the respiratory tract in infants and children. Am J Med. 1985;78:38-44. [pmid: 4014286].
Klein J O. Otitis media: diagnosis and epidemiology. Clin Ther. 1988;10:2-7. [pmid: 2466567].
Klein JO, Chase C, Teele DW, Menyuk P, Rosner BA, Group tGBOMS. Otitis media and the developoment of speech, language and cognititve abilities at seven years of age. In: Lim DJ BC, Klein JO, Nelson JD, ed. Recent advances in otitis media with effusion.Philadelphia: Decker; 1988:396–397.
Klein JO, Teele DW, Rosner BA, et al. Epidemiology of acute otitis media in Boston children from birth to seven years of age. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:14–15.
Klein J O, Tos M, Hussl B, Naunton R F, Ohyama M, van Cauwenberge P B. Recent advances in otitis media. Definition and classification. Ann Otol Rhinol Laryngol Suppl. 1989;139:10. [pmid: 2494923].
Klein A J, Armstrong B L, Greer M K, Brown F Rd. Hyperacusis and otitis media in individuals with Williams syndrome. J Speech Hear Disord. 1990;55:339-344. [pmid: 2329796].
Klein J O, Teele D W, Pelton S I. New concepts in otitis media: results of investigations of the Greater Boston Otitis Media Study Group. Adv Pediatr. 1992;39:127-156. [pmid: 1442312].
Klein J O. Microbiologic efficacy of antibacterial drugs for acute otitis media [published erratum appears in Pediatr Infect Dis J 1994 Dec;13(12):1125]. Pediatr Infect Dis J. 1993;12:973-975. [pmid: 8108222].
Klein J O, Wise R. At the sixth international congress for infectious diseases, Prague, Czech Republic, April 1994: Introduction. Eur J Clin Microbiol Infect Dis. 1994;13:837-838.
Klein J O. Otitis media [see comments]. Clin Infect Dis. 1994;19:823-833. [pmid: 7893865].
Klein J O. Lessons from recent studies on the epidemiology of otitis media. Pediatr Infect Dis J. 1994;13:1031-1034. [pmid: 7845735].
Klein JO. Current issues in upper respiratory tract infections in infants and children: rationale for antibacterial therapy. Pediatr Infect Dis J. 1994;13:S5–S9; discussion S20–S22.
Klein J O. Antimicrobial therapy issues facing pediatricians. Pediatr Infect Dis J. 1995;14:415-419. [pmid: 7638030].
Klein J O. [Microbiological evaluation of effectiveness of antibacterial drugs for the acute inflammation of the middle ear]. Pediatr Pol. 1995;70:91-94. [pmid: 7624178].
Klein J O, Bluestone C D. Management of otitis media in the era of managed care. Adv Pediatr Infect Dis. 1996;12:351-386. [pmid: 9033984].
Klein J O. Role of nontypeable Haemophilus influenzae in pediatric respiratory tract infections. Pediatr Infect Dis J. 1997;16:S5-S8. [pmid: 9041620].
Klein J O. Haemophilus influenzae: it's role in pediatric infections. Introduction. Pediatr Infect Dis J. 1997;16:S3-S4. [pmid: 9041619].
Kleinman L C, Kosecoff J, Dubois R W, Brook R H. The medical appropriateness of tympanostomy tubes proposed for children younger than 16 years in the United States [see comments]. JAMA. 1994;271:1250-1255. [pmid: 7710469].
Kletzker G R, Smith P G, McIntire L D, Leonetti J P. Presentation and management of uncommon lesions of the middle ear. Am J Otol. 1995;16:634-642. [pmid: 8588669].
Klugman K P, Coffey T J, Smith A, Wasas A, Meyers M, Spratt B G. Cluster of an erythromycin-resistant variant of the Spanish multiply resistant 23F clone of Streptococcus pneumoniae in South Africa. Eur J Clin Microbiol Infect Dis. 1994;13:171-174. [pmid: 8013492].
Klugman K P. Epidemiology, control and treatment of multiresistant pneumococci. Drugs. 1996;52:42-46. [pmid: 8869835].
Knappe M V, Gregor R T. Luc's abscess--a rare complication of middle-ear infection. J Laryngol Otol. 1997;111:461-464. [pmid: 9205610].
Knight L C, Hilger A. The effects of grommet insertion on Eustachian tube function. Clin Otolaryngol. 1993;18:459-461. [pmid: 8877219].
Knishkowy B, Palti H, Adler B, Tepper D. Effect of otitis media on development: a community-based study. Early Hum Dev. 1991;26:101-111. [pmid: 1743115].
Koba R, Yagi M, Tabe H, Kawabata I. Kinetic analysis of cell proliferation using bromodeoxyuridine labeling and in situ detection of dying cells in the tympanic membrane and middle ear cholesteatoma. Arch Histol Cytol. 1996;59:339-346. [pmid: 8937634].
Kobayashi H, Zusho H. When to remove the ventilation tube--judgement using T-tube on the time to remove the tube. Auris Nasus Larynx. 1985;12:S247-S248. [pmid: 3835922].
Kobayashi K, Kodama H, Takezawa H, Suzuki T, Kataura A. Elevation of bone conduction threshold in children with middle ear effusion. Int J Pediatr Otorhinolaryngol. 1988;16:95-100. [pmid: 3209365].
Kobayashi K, Yamanaka N, Kataura A, Ohtani S, Saito T, Akino T. Presence of an 80 kilodalton protein, cross-reacted with monoclonal antibodies to pulmonary surfactant protein A, in the human middle ear. Ann Otol Rhinol Laryngol. 1992;101:491-495. [pmid: 1610065].
Kobayashi T, Yaginuma Y, Toshima M, et al. Use of surfactant in the treatment of secretory otitis media: a preliminary report.Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:286–289.
Kodama H, Asakura K. [Role of surface tension lowering substances in the function of normal and diseased eustachian tubes of guinea pigs]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1993;96:674-684.
Kodama A, Kitahara M, Ozawa H, Izukura H. A ventilation capacity test for the Eustachian tube using a soundproof pressure chamber. Acta Oto-Laryngologica - Supplement. 1994;510:99-103.
Kodama H, Faden H, Harabuchi Y, Kataura A, Bernstein J M, Brodsky L. Adenoid lymphocyte responses to outer membrane protein P6 of nontypable Haemophilus influenzae in children with and without otitis media. Acta Oto-Laryngologica - Supplement. 1996;523:153-154.
Koebsell K A, Margolis R H. Tympanometric gradient measured from normal preschool children [published erratum appears in Audiology 1989;28(2):following 116]. Audiology. 1986;25:149-157. [pmid: 3753303].
Koenigsberger M R, Chandrasekhar S S. [An infant with dizziness]. Rev Neurol. 1995;23:S410-S417. [pmid: 7497324].
Kohli V, Singhi S, Sharma P, Ganguly N K. Value of serum C-reactive protein concentrations in febrile children without apparent focus. Ann Trop Paediatr. 1993;13:373-378. [pmid: 7506886].
Kohsyu H, Aoyagi M, Tojima H, et al. Facial nerve enhancement in Gd-MRI in patients with Bell's palsy. Acta Oto-Laryngologica - Supplement. 1994;511:165-169.
Koike Y. Facial palsies due to skull trauma. Arch Otolaryngol. 1972;95:434-436. [pmid: 5026278].
Koivunen P, Alho O P, Uhari M, Partanen A, Luotonen J. General anesthesia with and without nitrous oxide (N2O) and the weight of middle ear effusion in children undergoing adenoidectomy and tympanostomy. Laryngoscope. 1996;106:724-726. [pmid: 8656957].
Koivunen P, Alho O P, Uhari M, Niemela M, Luotonen J. Minitympanometry in detecting middle ear fluid. J Pediatr. 1997;131:419-422. [pmid: 9329419].
Kokko E. Chronic secretory otitis media in children. A clinical study. Acta Oto-Laryngologica - Supplement. 1974;327:1-44.
Kokko E, Palva T. Clinical results and complications of tympanostomy. The Annals of Otology, Rhinology and Larynogology; 1976:277–279.
Kollar A, Lamonthe M G. Changes of the threshold of bone conduction in acute otitis media. Ceskoslovenska Otolaryngologie. 1982;31:340-346. [pmid: 7159974].
Komoroski E M, Graham C J, Kirby R S. A comparison of interventions to improve clinic follow-up compliance after a pediatric emergency department visit. Pediatr-Emerg-Care. 1996;12:87-90. [pmid: 8859914].
Komune S, Hisashi K, Wakizono S, Inoue H, Uemura T. Importance of atticotomy in chronic otitis media with fixation of ossicles. Auris Nasus Larynx. 1992;19:23-28. [pmid: 1514943].
Konstantareas M M, Homatidis S. Ear infections in autistic and normal children. J Autism Dev Disord. 1987;17:585-594. [pmid: 3680158].
Kontiokari T, Niemela M, Uhari M. Middle ear effusion among children diagnosed and treated actively for acute otitis media. Eur J Pediatr. 1998;157:731-734. [pmid: 9776531].
Kontrogianni A, Ferekidis E, Ntouniadakis E, Psarommatis I, Apostolopoulos N, Adamopoulos G. Multiple-frequency tympanometry in children with otitis media with effusion. ORL J Otorhinolaryngol Relat Spec. 1996;58:78-81. [pmid: 8736051].
Koos W T, Day J D, Matula C, Levy D I. Neurotopographic considerations in the microsurgical treatment of small acoustic neurinomas. J Neurosurg. 1998;88:506-512. [pmid: 9488305].
Koriwchak M. Temporal bone cancer. Am J Otol. 1993;14:623-626. [pmid: 8296870].
Korppi M, Leinonen M, Saikku P. Chlamydial infection and reactive airway disease [letter; comment]. Arch Pediatr Adolesc Med. 1995;149:341-342. [pmid: 7858699].
Koskela M. Antibody response of young children to parenteral vaccination with pneumococcal capsular polysaccharides: a comparison between antibody levels in serum and middle ear effusion. Pediatr Infect Dis. 1986;5:431-434. [pmid: 3755238].
Kosling S, Keiner S. [Meningitis. Meningitis, induced by aggressive labyrinthitis]. HNO. 1997;45:570-571. [pmid: 9340342].
Kosowicz J, Rzymski K. Radiological features of the skull in Klinefelter's syndrome and male hypogonadism. Clin Radiol. 1975;26:371-378. [pmid: 1201634].
Kossowska E, Chmielik M, Komorowska A, Zaleski W. [Sultamicillin in treatment of acute middle ear infection in children]. Pol Tyg Lek. 1993;48:9-10. [pmid: 8008666].
Koutnouyan H A, Baird A, Ryan A F. Acidic and basic FGF mRNA expression in the middle ear mucosa during experimental acute and chronic otitis media. Laryngoscope. 1994;104:350-358. [pmid: 7510359].
Koyuncu M, Mason S M, Saunders M W. Electrocochleography in endolymphatic hydrops using tone-pip and click stimuli. Clin Otolaryngol Allied Sci. 1994;19:73-78. [pmid: 8174307].
Koyuncu M, Saka M M, Tanyeri Y, et al. Effects of otitis media with effusion on the vestibular system in children. Otolaryngol Head Neck Surg. 1999;120:117-121. [pmid: 9914561].
Kozak LJ, Hall MJ, Pokras R, Lawrence L. Ambulatory Surgery in the Unites States, 1994. Advance Data from vital and health statistics Hyattsville (MD): National Center for Health Statistics; 1997 Mar.
Kramer B M, Kaseff L G. The surgical correlation of x-ray findings by polytomography. With special reference to chronic otitis. Laryngoscope. 1967;77:1099-1108. [pmid: 6028524].
Kramer A H, McCullough D W. The prevalence of otitis media with effusion among Inuit children. International Journal of Circumpolar Health. 1998;57:265-267. [pmid: 10093287].
Kraus E M. Hearing results with clothespin ossiculoplasty: preliminary report on the Kraus Modified Schuring Ossicle-Cup Prosthesis (Clothespin Prosthesis). Otolaryngol Head Neck Surg. 1993;109:26-34. [pmid: 8336964].
Kremer M, Podoshin L, Fradis M. Treatment of serous otitis media with tympanic ventilation tubes. Ear Nose Throat J. 1979;58:203-209. [pmid: 456299].
Kries R, Huisman J J, Bode C, et al. Pediatric screening for hearing loss in six-month-old infants: Improved efficacy with the use of a parent questionnaire. Laryngo Rhino Otologie. 1995;74:543-548. [pmid: 7495435].
Krueger W W, Wagner A P. Needle placement with transtympanic electrocochleography. Laryngoscope. 1997;107:1671-1673. [pmid: 9396685].
Kruk-Zagajewska A, Jedras M. [Congenital auricular fistula imitating otogenic complication]. Otolaryngol Pol. 1996;50:622-627. [pmid: 9173393].
Kubo T. [Diagnostic imaging and physiological function tests--cholesteatomatous otitis media]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1996;99:612-615.
Kudrjavcev T, Schoenberg B S. Otitis media and developmental disability. Epidemiologic considerations. Ann Otol Rhinol Laryngol Suppl. 1979;88:88-98. [pmid: 115366].
Kuijpers W. Persisting changes in the structure of the tympanic membrane. Acta Otorhinolaryngol Belg. 1995;49:181-185. [pmid: 7610911].
Kuijpers W, Vennix P P, Peters T A, Ramaekers F C. Squamous metaplasia of the middle ear epithelium. Acta Otolaryngol. 1996;116:293-298. [pmid: 8725535].
Kulik J A, Carlino P. The effect of verbal commitment and treatment choice on medication compliance in a pediatric setting. J Behav Med. 1987;10:367-376. [pmid: 3669071].
Kumar V, Patial R K, Mahindroo N K. Meningeal tuberculosis secondary to an unusual primary site. J Assoc Physicians India. 1996;44:749. [pmid: 9251360].
Kumazawa T, Ushiro K. Clinical evaluation of S-CMC syrup applied in the treatment of otitis media with effusion. Double blind comparative test with placebo. ACTA OTO-LARYNGOL SUPPL. 1989;107:56-62.
Kumazawa T, Iwano T, Ushiro K, Tsuruhara K, Hosodo Y, Doi T. Tubotympanoplasty. Acta Oto-Laryngologica - Supplement. 1993;500:14-17.
Kumazawa T, Iwano T, Ushiro K, Kinoshita T, Hamada E, Kaneko A. Eustachian tube function tests and their diagnostic potential in normal and diseased ears. Acta Oto-Laryngologica - Supplement. 1993;500:10-13.
Kummer A. An open comparative random study with Brodimoprim(Reg.trademark) and doxycyclin in 46 patients affected with upper airway infections. CHEMIOTERAPIA. 1982;1:153.
Kupperman D, Tange R A. Long-term results of glass ionomer cement, Ionocem, in the middle ear of the rat. Acta Otorhinolaryngol Belg. 1997;51:27-30. [pmid: 9105479].
Kurata K, Fujita A, Sakakihara J, Honjo I. Validity of adenoidectomy for treatment of otitis media with effusion. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:312–314.
Kurata K, Takahashi H, Fujita A, Honjo I. Clinical efficacy of clarithromycin treatment of refractory otitis media with effusion. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:236–238.
Kurien M, Job A, Mathew J, Chandy M. Otogenic intracranial abscess: concurrent craniotomy and mastoidectomy--changing trends in a developing country. Arch Otolaryngol Head Neck Surg. 1998;124:1353-1356. [pmid: 9865758].
Kuroki A, Moller A R. Microsurgical anatomy around the foramen of Luschka in relation to intraoperative recording of auditory evoked potentials from the cochlear nuclei. J Neurosurg. 1995;82:933-939. [pmid: 7760194].
Kurono Y, Shigemi H, Kodama S, Mogi G. The role of adenoids in nasopharyngeal colonization with nontypeable Haemophilus influenzae. Acta Oto-Laryngologica - Supplement. 1996;523:147-149.
Kuschke E R. Chronic middle ear effusions (secretory otitis media). S Afr Med J. 1979;56:443-445. [pmid: 550367].
Kuttner K, Buntzel J, Andra K. [Follow-up of mastoiditis and mastoidectomy]. Laryngorhinootologie. 1996;75:65-69. [pmid: 8867741].
Kuyvenhoven M, de Melker R, van der Velden K. Prescription of antibiotics and prescribers' characteristics. A study into prescription of antibiotics in upper respiratory tract infections in general practice. Fam Pract. 1993;10:366-370. [pmid: 8168670].
Kvaerner K J, Arnesen A R. Hearing impairment in Oslo born children 1989-91. Incidence, etiology and diagnostic delay. Scand Audiol. 1994;23:233-239. [pmid: 7878374].
Kvaerner K J, Tambs K, Harris J R, Magnus P. The relationship between otitis media and intrauterine growth: a co-twin control study. Int J Pediatr Otorhinolaryngol. 1996;37:217-225. [pmid: 8905456].
Kvaerner K J, Nafstad P, Hagen J A, Mair I W, Jaakkola J J. Early acute otitis media and siblings' attendance at nursery. Arch Dis Child. 1996;75:338-341. [pmid: 8984924].
Kvaerner K J, Tambs K, Harris J R, Mair I W, Magnus P. Otitis media: relationship to tonsillitis, sinusitis and atopic diseases. Int J Pediatr Otorhinolaryngol. 1996;35:127-141. [pmid: 8735409].
Kvaerner K J, Nafstad P, Hagen J, Mair I W, Jaakkola J J. Early acute otitis media: determined by exposure to respiratory pathogens. Acta Oto-Laryngologica - Supplement. 1997;529:14-18.
Kvaerner K J, Tambs K, Harris J R, Magnus P. Distribution and heritability of recurrent ear infections. Ann Otol Rhinol Laryngol. 1997;106:624-632. [pmid: 9270423].
Kveton J F, Pillsbury H Cd, Sasaki C T. Nasal obstruction. Adenoiditis vs adenoid hypertrophy. Arch Otolaryngol. 1982;108:315-318. [pmid: 7200351].
Kveton J F. Hearing loss in the absence of otitis media. Pediatr Rev. 1994;15:115-116. [pmid: 8041671].
Kwong D L, Wei W I, Sham J S, et al. Sensorineural hearing loss in patients treated for nasopharyngeal carcinoma: a prospective study of the effect of radiation and cisplatin treatment [see comments]. Int J Radiat Oncol Biol Phys. 1996;36:281-289. [pmid: 8892450].
Kylen P, Arlinger S D, Bergholtz L M. Peroperative temporary threshold shift in ear surgery. An electrocochleographic study. Acta Otolaryngol. 1977;84:393-401. [pmid: 920141].
Kylen P, Harder H, Jerlvall L, Arlinger S. Reliability of bone-conducted electrocochleography. A clinical study. Scand Audiol. 1982;11:223-226. [pmid: 7163764].
Lacher G. [Clinical trial of Otipax: auricular pulverizations]. Rev-Laryngol-Otol-Rhinol-Bord. 1969;90:719-722. [pmid: 5405045].
Lacosta J L, Infante J C, Undabeitia E, Gastanares M J. [The microbiology of secretory otitis]. An Otorrinolaringol Ibero Am. 1995;22:439-448. [pmid: 7485853].
Lacosta J L, Manrique M, Infante J C. [Study of the nasopharyngeal microflora obtained by a cotton swab]. Acta Otorrinolaringol Esp. 1995;46:191-194. [pmid: 7619553].
Lacosta J L, Zabaleta M, Erdozain I. [The evolution of otitis media with effusion treated by transtympanic drainage]. Acta Otorrinolaringol Esp. 1996;47:349-353. [pmid: 8991399].
Lacosta J L, Infante J C, Pison F. [Considerations regarding functional cholesteatoma surgery. II. Open techniques]. Acta Otorrinolaringol Esp. 1996;47:277-280. [pmid: 8962728].
Lacosta J L, Infante J C, Pison F. [Functional surgery of cholesteatoma. I. Closed techniques]. Acta Otorrinolaringol Esp. 1997;48:115-120. [pmid: 9198461].
Lagace E. Antibiotic treatment for AOM. J Fam Pract. 1997;45:202-203. [pmid: 9312561].
Lagging E, Papatziamos G, Hallden G, Hemlin C, Harfast B, Van Hage-Hamsten M. T-cell subsets in adenoids and peripheral blood related to age, otitis media with effusion and allergy. APMIS. 1998;106:354-360. [pmid: 9548423].
Lahikainen E A, Vuori M, Virtanen S. Azidocillin and ampicillin concentrations in middle ear effusion. Acta Otolaryngol. 1977;84:227-232. [pmid: 578645].
Laird N M, Mosteller F. Some statistical methods for combining experimental results. Int J Technol Assess Health Care. 1990;6:5-30. [pmid: 2361819].
Laitila P, Karma P, Sipila M, Manninen M, Rakho T. Extended high frequency hearing and history of acute otitis media in 14-year-old children in Finland. Acta Oto-Laryngologica - Supplement. 1997;529:27-29.
Lakshmi V, Rao R R, Dinakar I. Bacteriology of brain abscess--observations on 50 cases. J Med Microbiol. 1993;38:187-190. [pmid: 7681113].
Lambert P R. Oral steroid therapy for chronic middle ear perfusion: a double-blind crossover study. Otolaryngol-Head-Neck-Surg. 1986;95:193-199. [pmid: 3108758].
Lamore P J. Vibrotactile threshold for hairy skin and its transformation into equivalent bone-conduction loss for the mastoid. Audiology. 1984;23:537-551. [pmid: 6517747].
Lamothe A, Boudreault V, Blanchette M, Tetreault L, Poliquin J. Serous otitis media: a six week prospective study. J Otolaryngol. 1981;10:371-379. [pmid: 7199093].
Lampe R M, Weir M R, McLeod H L, Artalejo Lr. A clinical trial of antihistamine, decongestant, or placebo in antibiotic-treated acute otitis media followed with pneumatic otoscopy and impedance tympanometry. Mil-Med. 1981;146:259-261. [pmid: 6784022].
Lampe R M, Weir M R, McLeod H, Aspinall K, Artalejo L. Tympanometry in acute otitis media: prognostic implications. Am-J-Dis-Child. 1981;135:233-235. [pmid: 6111216].
Lampe R M, Weir M R, McLeod H L, Artalejo L d. A clinical trial of antihistamine, decongestant, or placebo in antibiotic-treated acute otitis media followed with pneumatic otoscopy and impedance tympanometry. Mil Med. 1981;146:259-261. [pmid: 6784022].
Lampe R M, Weir M R, Spier J, Rhodes M F. Acoustic reflectometry in the detection of middle ear effusion. Pediatrics. 1985;76:75-78. [pmid: 4040237].
Lampe R M, Schwartz R H. Diagnostic value of acoustic reflectometry in children with acute otitis media. Pediatr Infect Dis J. 1989;8:59-61. [pmid: 2922242].
Landholt TF, Kotschwar TR. A pharmacoeconomic comparison of amoxicillin/clavulanate and cefpodoxime proxetil in the treatment of acute otitis media. Clin Ther. 1994;16:327–333; discussion 271–272.
Landis L. Comment on ‘otitis media in early childhood and its relationship to later phonological development’. J Speech Hear Disord. 1990;55.
Landsberg R, Lang R, Wollach B, Dubin Z, Ophir D. [Lateral sinus thrombophlebitis]. Harefuah. 1994;126:386-389, 427. [pmid: 8200585].
Lang A H, Happonen J M, Salmivalli A. An improved technique for the non-invasive recording of auditory brain-stem responses with a specially constructed meatal electrode. Scand Audiol Suppl. 1981;13:59-62. [pmid: 6944779].
Lannigan F J, O'Higgins P, McPhie P. The cellular mechanism of ossicular erosion in chronic suppurative otitis media. J Laryngol Otol. 1993;107:12-16. [pmid: 8445302].
Lapidot A, Mazzarella L A, Ratanaprasatporn S. Vestibule exposure during surgery. Clinical observations in three cases of cholesteatoma. Arch Otolaryngol. 1970;92:24-27. [pmid: 5422335].
LaRossa M M, Mitchell S, Cardinal J W. Tympanometry as a screening tool in the NICU: is it effective?. Neonatal Network. 1993;12:33-35. [pmid: 8121353].
Lashin N, Zaher S, Ragab A, ElGabri T H. Hearing loss in bullous myringitis. Ear Nose Throat J. 1988;67:206, 208, 210. [pmid: 3383758].
Laskiewicz B, Chalstrey S, Gatland D J, Jones N, Michaels L. Congenital cholesteatoma. J Laryngol Otol. 1991;105:995-998. [pmid: 1787381].
Latorre F, Cassano P, De Candia N. [Muco-ciliary transport in chronic inflammatory pathology of the middle ear]. Bollettino - Societa Italiana Biologia Sperimentale. 1993;69:403-407.
Latorre M, Alvarez M, Fernandez J M, Berdonces P, Llanos A, Cisterna R. A case of meningitis due to “Streptococcus zooepidemicus” [letter]. Clin Infect Dis. 1993;17:932-933. [pmid: 8286648].
Latorre C, Munoz C, Trujillo G, Juncosa T, Claros P. Susceptibility of pneumococci isolated from middle ear effusions to antimicrobial agents commonly used in otitis media [letter] [published erratum appears in J Antimicrob Chemother 1994 May;33(5):1077–8]. J Antimicrob Chemother. 1994;33:186-187. [pmid: 8157564].
Lau T, Tos M. Long-term results of surgery for chronic granulating otitis. Am J Otolaryngol. 1986;7:341-345. [pmid: 3777357].
Lau T, Tos M. Cholesteatoma in children: recurrence related to observation period. Am J Otolaryngol. 1987;8:364-375. [pmid: 3434674].
Lau T, Tos M. When to do tympanoplasty in children?. Adv Otorhinolaryngol. 1988;40:156-161. [pmid: 3389229].
Lau T, Tos M. Tensa retraction cholesteatoma: treatment and long-term results. J Laryngol Otol. 1989;103:149-157. [pmid: 2926259].
Laurent C, Soderberg O, Anniko M, Hartwig S. Repair of chronic tympanic membrane perforations using applications of hyaluronan or rice paper prostheses. ORL-J-Otorhinolaryngol-Relat-Spec. 1991;53:37-40. [pmid: 2008293].
Lauret M H. Is treatment of AOM with once-a-day amoxicillin feasible? [letter; comment]. Clin Pediatr. 1995;34:175.
Laxdal O E, Merida J, Jones R H. Treatment of acute otitis media: a controlled study of 142 children. Can-Med-Assoc-J. 1970;102:263-268. [pmid: 4190002].
Lazarev VN, Suzdaltsev AE. [Peripheral nervous system in children with chronic inflammatory otorhinolaryngologic diseases]. Vestn Otorinolaringol. 1994:27–30.
Le C T, Freeman D W, Fireman B H. Evaluation of ventilating tubes and myringotomy in the treatment of recurrent or persistent otitis media. Pediatr Infect Dis J. 1991;10:2-11. [pmid: 2003051].
Le C T, Freeman D W, Fireman B H. Evaluation of ventilating tubes and myringotomy in the treatment of recurrent or persistent otitis media [see comments]. Pediatr Infect Dis J. 1991;10:2-11. [pmid: 2003051].
Le C T, Daly K A, Margolis R H, Lindgren B R, Giebink G S. A clinical profile of otitis media [see comments]. Arch Otolaryngol Head Neck Surg. 1992;118:1225-1228. [pmid: 1418901].
Le C T, Daly K A, Margolis R H, Lindgren B R, Giebink G S. A clinical profile of otitis media. Arch Otolaryngol Head and Neck Surgery. 1992;118:1225-1228.
Le C T, Lindgren B R, Daly K A, Giebink G S. Treatment evaluation in otitis media research [see comments]. Arch Otolaryngol Head Neck Surg. 1994;120:507-509. [pmid: 8172701].
Le C T, Hunter L L, Margolis R H, Daly K A, Lindgren B R, Giebink G S. A clinical profile of otitis media without an intact tympanic membrane [see comments]. Arch Otolaryngol Head Neck Surg. 1994;120:513-516. [pmid: 8172702].
Le C T, Lindgren B R. Duration of ventilating tubes: a test for comparing two clustered samples of censored data. Biometrics. 1996;52:328-334. [pmid: 8934600].
Le CT, Lindgren BR. Interactions between otoscopic findings and tympanometric measurements in the diagnosis of otitis media with effusion. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:151–153.
Le Bideau M, Mouzard A, Chamoux C, Richet H, Bordure P, Maugard T. [Bacteriological study in acute otitis media]. Arch Pediatr. 1997;4:213-218. [pmid: 9181013].
Leach A J, Boswell J B, Asche V, Nienhuys T G, Mathews J D. Bacterial colonization of the nasopharynx predicts very early onset and persistence of otitis media in Australian Aboriginal infants. Pediatr Infect Dis J. 1994;13:983-989. [pmid: 7845752].
Leake E R, Holmes K, Lim D J, DeMaria T F. Peptidoglycan isolated from nontypeable Haemophilus influenzae induces experimental otitis media in the chinchilla. J Infect Dis. 1994;170:1532-1538. [pmid: 7995993].
Lebedev Iu A. [Clinico-audiological characteristics of secretory otitis media in children]. Vestn Otorinolaringol. 1996:38–42.
Lebedev Iu A, Shakhov V. [Criteria of the evaluation of tubal function in patients with secretory otitis media]. Vestn Otorinolaringol. 1997:30–34.
Lebovics R S, Murthy V V, Karmen A. Leukocyte esterase activity in effusion fluid of patients with otitis media. Otolaryngol Head Neck Surg. 1993;108:248-250. [pmid: 8464637].
Lecks H I, Kravis L P, Wood D W. Serous otitis media: Reflections on pathogenesis and treatment: With a comment on the use of intranasal dexamethasone (turbinaire). Clin Pediatr. 1991;30:174-177.
Leclercq P, Bigdeli M. [Health economics and antibiotic therapy]. Rev Med Brux. 1995;16:320-324. [pmid: 7481251].
Lee K, Schuknecht H F. Results of tympanoplasty and mastoidectomy at the Massachusetts Eye and Ear Infirmary. Laryngoscope. 1971;81:529-543. [pmid: 4928558].
Lee T B, Stingle W H, Ombres P, Lewis J S, Cooper L Z. Neonatal meningitis and mastoiditis caused by Hemophilus influenzae. JAMA. 1976;235:407-409. [pmid: 1082037].
Lee S T. Cholesteatoma in an Asian population. Acta Otolaryngol. 1991;111:536-541. [pmid: 1887780].
Lee P Y, Drysdale A J. Tuberculous otitis media: a difficult diagnosis. J Laryngol Otol. 1993;107:339-341. [pmid: 8320523].
Lee R J, Sidey C, Narula A A, James R F. The nature of the epithelium in acquired cholesteatoma: Part 3--Cytokeratin patterns in aural epithelial and cholesteatoma cells grown in cell culture. Clin Otolaryngol. 1994;19:516-520. [pmid: 7534665].
Lee W C, Weiner G M, Campbell J B. Should nasopharyngeal biopsy be mandatory in adult unilateral glue ear? [see comments]. J Laryngol Otol. 1996;110:62-64. [pmid: 8745785].
Lee D, Rosenfeld R M. Adenoid bacteriology and sinonasal symptoms in children. Otolaryngol Head Neck Surg. 1997;116:301-307. [pmid: 9121781].
Lee H K, Lee E H, Choi J Y, Choi H S, Kim H N. Noise level of drilling instruments during mastoidectomy. Yonsei Med J. 1999;40:339-342. [pmid: 10487136].
Legent F, Bordure P, Beauvillain C, Berche P. Controlled prospective study of oral ciprofloxacin versus amoxycillin/clavulanic acid in chronic suppurative otitis media in adults. Chemotherapy. 1994:16–23.
Lehmann M D, Charron K, Kummer A, Keith R W. The effects of chronic middle ear effusion on speech and language development -- a descriptive study. Int J Pediatr Otorhinolaryngol. 1979;1:137-144. [pmid: 553891].
Lehnert T. Acute otitis media in children. Role of antibiotic therapy. Can Fam Physician. 1993;39:2157-2162. [pmid: 8219863].
Leibecke R R, Schwartz W. [Initial otologic manifestation of Wegener's granulomatosis]. HNO. 1994;42:119-122. [pmid: 8163396].
Leiberman A, Bartal N. Untreated persistent middle ear effusion. J Laryngol Otol. 1986;100:875-878. [pmid: 3746102].
Leiberman A, Lupu L, Landsberg R, Fliss D M. Unusual complications of otitis media. Am J Otolaryngol. 1994;15:444-448. [pmid: 7872481].
Leibovitz E, Dagan R. Oral cephalosporins in upper respiratory infections. Antibiot Chemother. 1995;47:110-122. [pmid: 8554303].
Leidinger J, Jahnke K. [Fatal outcome after retrograde insufflation of the eustachian tube]. HNO. 1995;43:108-110. [pmid: 7713762].
Leigh A P, Robinson D, Millar E D. A general practice comparative study of a new third-generation oral cephalosporin, cefixime, with amoxycillin in the treatment of acute paediatric otitis media. Br-J-Clin-Pract. 1989;43:140-143. [pmid: 2686744].
Leighton S E, Robson A K, Anslow P, Milford C A. The role of CT imaging in the management of chronic suppurative otitis media. Clin Otolaryngol. 1993;18:23-29. [pmid: 8448886].
Lejeune H B, Cote D N. Passive smoking. J La State Med Soc. 1995;147:444-447. [pmid: 8558049].
Lejman T, Strong M, Michno P. [Septic arthritis in newborns and infants--clinical epidemiology]. Chir Narzadow Ruchu Ortop Pol. 1995;60:409-413. [pmid: 8565685].
Lenhardt M L, Shaia F T, Abedi E. Brain-stem evoked response waveform variation associated with recurrent otitis media. Arch Otolaryngol. 1985;111:315-316. [pmid: 3985852].
Lesinski S G, Fox J M, Seid A B, Bratcher G O, Cotton R. Does the Silastic Eustachian Tube prosthesis improve eustachian tube function?. Laryngoscope. 1980;90:1413-1428. [pmid: 7190631].
Lesinski S G. Complications of homograft tympanoplasty. Otolaryngol Clin North Am. 1982;15:795-811. [pmid: 7162819].
Lesinski S G. Reconstruction of hearing when malleus is absent: TORP vs. homograft TMMI. Laryngoscope. 1984;94:1443-1446. [pmid: 6548539].
Lesinski S G. Homograft (allograft) tympanoplasty update. Laryngoscope. 1986;96:1211-1220. [pmid: 3773619].
Lesperance M M, Grundfast K M, Rosenbaum K N. Otologic manifestations of Wolf-Hirschhorn syndrome. Arch Otolaryngol Head Neck Surg. 1998;124:193-196. [pmid: 9485112].
Lesser T H, Clayton M I, Skinner D. Efficacy of medical treatment as an adjunct to surgery in the treatment of secretory otitis media. J Laryngol Otol. 1986;100:1347-1350. [pmid: 3543180].
Lesserson J A, Kieserman S P, Finn D G. The radiographic incidence of chronic sinus disease in the pediatric population. Laryngoscope. 1994;104:159-166. [pmid: 8302118].
Leston jr JA, Battin R, Tallman J, et al. An equation to help evaluate the potential adverse effects of middle ear disease upon language development. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:350–351.
Leunig A, Mees K. Autoinflation of the middle ear with otovent(TM. Laryngo Rhino Otologie. 1995;74:352-354. [pmid: 7662078].
Levine L R. Quantitative comparison of adverse reactions to cefaclor vs. amoxicillin in a surveillance study. Pediatr-Infect-Dis. 1985;4:358-361. [pmid: 3161007].
Levine B A, Shelton C, Berliner K I, Sheehy J L. Sensorineural loss in chronic otitis media. Is it clinically significant?. Arch Otolaryngol Head and Neck Surgery. 1989;115:814-816.
Levine S, Daly K, Giebink G S. Tympanic membrane perforations and tympanostomy tubes. Ann Otol Rhinol Laryngol Suppl. 1994;163:27-30. [pmid: 8179266].
Levinson S R, Gill A J, Teich L. Semipermeable membrane tubes: a prospective study. Otolaryngol Head Neck Surg. 1982;90:622-628. [pmid: 6819525].
Leviton A. Otitis media and learning disorders. J Dev Behav Pediatr. 1980;1:58-63. [pmid: 7194887].
Levy D, Herman M, Luntz M, Sade J. Direct demonstration of gas diffusion into the middle ear. Acta Otolaryngol. 1995;115:276-278. [pmid: 7610821].
Lewis N. Otitis media and linguistic incompetence. Arch Otolaryngol. 1976;102:387-390. [pmid: 938317].
Lewis D M, Schram J L, Lim D J, Birck H G, Gleich G. Immunoglobulin E in chronic middle ear effusions: conmparison of RIST, PRIST, and RIA techniques. Ann Otol Rhinol Laryngol. 1978;87:197-201. [pmid: 646287].
Lewis D M, Schram J L, Birck H G, Lim D J. Antibody activity in otitis media with effusion. Ann Otol Rhinol Laryngol. 1979;88:392-396. [pmid: 380443].
Lewis D R, Thompson D H, Fetter T W, Mocnik J, Shelby J H. Computerized axial tomography versus complex motion as a predictor of surgical findings in middle ear and mastoid cholesteatoma. Laryngoscope. 1985;95:689-691. [pmid: 3999904].
Lewis D M. Histopathology associated with cochlear implants. Ear Nose Throat J. 1987;66:86-94. [pmid: 3104007].
Lexchin J. The management of acute otitis media [letter; comment] [see comments]. N Z Med J. 1994;107:160. [pmid: 8164908].
Li Z. [Facial nerve and petrous bone cholesteatoma]. Chung Hua Erh Pi Yen Hou Ko Tsa Chih - Chinese Journal of Otorhinolaryngology. 1993;28:325-327, 380.
Li W, Schachern P A, Morizono T, Paparella M M. The temporal bone in multiple myeloma. Laryngoscope. 1994;104:675-680. [pmid: 8196442].
Li Z X, Zhao B, Feng Z. Brain abscess due to Pasteurella multocida. Kansenshogaku Zasshi - Journal of the Japanese Association for Infectious Diseases. 1994;68:403-406.
Li J C. Mastoid oscillation: a critical factor for success in canalith repositioning procedure. Otolaryngol Head Neck Surg. 1995;112:670-675. [pmid: 7777350].
Li Y, Hunter L L, Margolis R H, et al. Prospective study of tympanic membrane retraction, hearing loss, and multifrequency tympanometry. Otolaryngol Head Neck Surg. 1999;121:514-522. [pmid: 10547462].
Liden G. Impedance audiometry. Ann Otol Rhinol Laryngol Suppl. 1980;89:53-58. [pmid: 6786192].
Liden G, Renvall U. Impedance and tone screening of school children. Scand Audiol. 1980;9:121-126. [pmid: 7444325].
Liden M, Flodstrom A, Thore M. Treatment of early recurrences of acute purulent otitis media; value of myringotomy. Acta-Otolaryngol-Stockh. 1988;106:441-447. [pmid: 3207009].
Lieberum B, Jahnke K. [Golden tube wire for temporary or permanent implantation]. HNO. 1996;44:140-142. [pmid: 8641900].
Liening D A, McGath J H, McKinney L. Comparison of polydioxanone and silicone plastic in the prevention of adhesive otitis media in the Mongolian gerbil. Otolaryngol Head Neck Surg. 1995;112:303-307. [pmid: 7838554].
Lijmer J G, Mol B W, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. J Am Med Assoc. 1999;282:1061-1066.
Lildholdt T, Courtois J, Kortholm B, Schou J W, Warrer H. The correlation between negative middle ear pressure and the corresponding conductive hearing loss in children. A 12-month study of 352 unselected 7-year-old children. Scand Audiol. 1979;8:117-120. [pmid: 515688].
Lildholdt T. Unilateral grommet insertion and adenoidectomy in bilateral secretory otitis media: preliminary report of the results in 91 children. Clin Otolaryngol Allied Sci. 1979;4:87-93. [pmid: 455774].
Lildholdt T, Courtois J, Kortholm B, Schou J W, Warrer H. The diagnosis of negative middle ear pressure in children. The accuracy of symptoms and signs assessed by tympanometry. Acta Otolaryngol. 1980;89:459-464. [pmid: 7192475].
Lildholdt T, Cantekin E I, Marshak G, Bluestone C D, Rohn D D, Schuit K E. Pharmacokinetics of cefaclor in chronic middle ear effusions. Ann Otol Rhinol Laryngol Suppl. 1981;90:44-47. [pmid: 6791562].
Lildholdt T, Kortholm B. Beclomethasone nasal spray in the treatment of middle-ear effusion - a double-blind study. Int J Pediatr Otorhinolaryngol. 1982;4:133-137. [pmid: 6752070].
Lildholdt T, Cantekin E I, Bluestone C D, Rockette H E. Effect of a topical nasal decongestant on Eustachian tube function in children with tympanostomy tubes. Acta-Otolaryngol-Stockh. 1982;94:93-97. [pmid: 6889803].
Lildholdt T. Ventilation tubes in secretory otitis media. A randomized, controlled study of the course, the complications, and the sequelae of ventilation tubes. Acta-Otolaryngol-Suppl-Stockh. 1983:1–28.
Lildholdt T, Felding J U, Juul A, Kristensen S, Schouenborg P. Efficacy of perioperative ceftazidime in the surgical treatment of chronic otitis media due to Pseudomonas aeruginosa. Preliminary report of a prospective, controlled study. Arch-Otorhinolaryngol. 1986;243:167-169. [pmid: 3530224].
Lildholdt T, Felding J U, Eriksen E W, Pedersen L V. [Diagnosis and treatment of ear diseases in general practice. A controlled trial of the effect of the introduction of middle ear measurement (tympanometry)]. Ugeskr-Laeger. 1991;153:3004-3007. [pmid: 1801385].
Lildholdt T. Tympanometry in general practice. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:50–53.
Lim D J, Birck H. Ultrastructural pathology of the middle ear mucosa in serous otitis media. Ann Otol Rhinol Laryngol. 1971;80:838-853. [pmid: 5127754].
Lin C, Kumari P, Perrotta R J, Reidenberg B E. Penetration of ceftibuten into middle ear fluid. Antimicrob Agents Chemother. 1996;40:1394-1396. [pmcid: 163337]. [pmid: 8726007].
Lin J, Kim Y, Lees C, Juhn S K. Effects of platelet-activating factor (PAF) receptor blockage on mucous glycoprotein secretion in cultured chinchilla middle ear epithelium. Acta Otolaryngol. 1996;116:69-73. [pmid: 8820353].
Lindberg K, Freijd A, Rynnel-Dagoo B, Hammarstrom L. Anti pneumococcal antibody activity in nasopharyngeal secretions in healthy adults and children. Acta Otolaryngol. 1993;113:673-678. [pmid: 8266798].
Lindberg K, Rynnel-Dagoo B, Sundqvist K G. Cytokines in nasopharyngeal secretions; evidence for defective IL-1 beta production in children with recurrent episodes of acute otitis media. Clin Exp Immunol. 1994;97:396-402. [pmid: 8082294]. [pmcid: 1534847].
Lindeman P, Holmquist J, Shea J. The size of the mastoid air cell system among black and white children with middle ear effusion. Int J Pediatr Otorhinolaryngol. 1981;3:251-256. [pmid: 7319703].
Lindeman P, Holmquist J. Middle ear effusion among children after acute otitis media. A diagnostic problem. Int J Pediatr Otorhinolaryngol. 1981;3:145-150. [pmid: 7287317].
Lindeman P, Haglund M. Size of the mastoid air cell system obtained with two types of X-ray equipment. Acta Otolaryngol. 1983;95:101-104. [pmid: 6829290].
Linder T E, Daniels R L, Lim D J, DeMaria T F. Effect of intranasal inoculation of Streptococcus pneumoniae on the structure of the surface carbohydrates of the chinchilla eustachian tube and middle ear mucosa. Microb Pathog. 1994;16:435-441. [pmid: 7830530].
Linder T E, Zwicky S, Brandle P. Ototoxicity of ear drops: a clinical perspective. Am J Otol. 1995;16:653-657. [pmid: 8588672].
Linder T, Funke G, Schmid S, Nadal D. [Acute otitis media with effusion: an overview of the pathogenesis and recommendations for therapy]. Schweiz Med Wochenschr. 1996;126:2223-33. [pmid: 9011932].
Linder T. [The effectiveness of antibiotics in chronic middle ear effusion and chronic suppurative otitis media. Comment on 2 contributions from Lancet]. HNO. 1997;45:107-109. [pmid: 9417428].
Linder T E, Marder H P, Munzinger J. Role of adenoids in the pathogenesis of otitis media: a bacteriologic and immunohistochemical analysis. Ann Otol Rhinol Laryngol. 1997;106:619-623. [pmid: 9270422].
Lindroos R. Surgery for chronic ear disease in a non-university hospital: open cavity, obliteration and intact canal wall techniques. Clin Otolaryngol Allied Sci. 1991;16:252-256. [pmid: 1879067].
Lindsay J R. Progress in otorhinolaryngology. IMJ - Illinois Medical Journal. 1969;135:565-571. [pmid: 4389093].
Lindsay J R. Histopathology of deafness due to postnatal viral disease. Arch Otolaryngol. 1973;98:258-264. [pmid: 4778641].
Lindsay R L, Tomazic T, Whitman B Y, Accardo P J. Early ear problems and developmental problems at school age. Clin Pediatr. 1999;38:123-132.
Ling D, McCoy R H, Levinson E D. The incidence of middle ear disease and its educational implications among Baffin Island Eskimo children. Can J Public Health. 1969;60:385-390. [pmid: 5345619].
Ling D, Katsarkas A, Baxter J D. Ear disease and hearing loss among Eskimo elementary school children. Can J Public Health. 1974;65:37-40. [pmid: 4815347].
Ling D. Audiological problems of the Eskimo population in the Baffin zone. pp. 409–12. In: Shephard RJ, Itoh S, ed. Circumpolar health. Toronto, Univ of Toronto Press. 1976.
Linstrom C J, Pincus R L, Leavitt E B, Urbina M C. Otologic neurotologic manifestations of HIV-related disease. Otolaryngol Head Neck Surg. 1993;108:680-687. [pmid: 8516005].
Linthicum F H Jr, Tian Q, Slattery W 3rd. Marrow-mesenchyme connections in the fetal and newborn tympanum. A new entity. Ann Otol Rhinol Laryngol. 1997;106:466-470. [pmid: 9199604].
Lippy W H, Rotolo A L, Berger K W. Bone conduction measurement: mastoid versus upper central incisor. Transactions - American Academy of Ophthalmology and Otolaryngology. 1966;70:1084-1088. [pmid: 5339454].
Lisby-Sutch S M, Nemec-Dwyer M A, Deeter R G, Gaur S M. Therapy of otitis media. Clinical Pharmacy. 1990;9:15-34. [pmid: 2406100].
Liston T E, Foshee W S, Pierson W D. Sulfisoxazole chemoprophylaxis for frequent otitis media. Pediatrics. 1983;71:524-530. [pmid: 6601256].
Liston S L. Ambroise Pare and the king's mastoiditis. Am J Surg. 1994;167:440-442. [pmid: 8179092].
Liston T E. Management of otitis media. A review. Clin Pediatr. 1995;34:542-548.
Little P, Bridges A, Guragain R, Friedman D, Prasad R, Weir N. Hearing impairment and ear pathology in Nepal. J Laryngol Otol. 1993;107:395-400. [pmid: 8326217].
Little P, Gould C, Williamson I, Warner G, Gantley M, Kinmonth A L. Reattendance and complications in a randomised trial of prescribing strategies for sore throat: the medicalising effect of prescribing antibiotics [see comments]. Br Med J. 1997;315:350-352. [pmid: 9270458].
Liu Y S, Lim D J, Lang R W, Brick H G. Chronic middle ear effusions. Immunochemical and bacteriological investigations. Arch Otolaryngol. 1975;101:278-286. [pmid: 805583].
Liu S J, Hsu C J, Hsieh T. Chronic mastoiditis mimicking recurrence of nasopharyngeal carcinoma: report of a case. J Formos Med Assoc. 1993;92:1007-1009. [pmid: 7910058].
Liu L, Li Z, Hu M. [Langerhans cells and human aural cholesteatoma]. Chung Hua Erh Pi Yen Hou Ko Tsa Chih - Chinese Journal of Otorhinolaryngology. 1995;30:33-36.
Loeb W J. Radiation therapy of the nasopharynx: a 30 year view. Laryngoscope. 1979;89:16-21. [pmid: 570625].
Loesel L S. Detection of allergic disease in adenoid tissue. Am J Clin Pathol. 1984;81:170-175. [pmid: 6364780].
Lof G L. Factors associated with speech-sound stimulability. J Commun Disord. 1996;29:255-278. [pmid: 8863118].
Lofgren R H. The complaining earache-key to serous otitis media. Pa Med. 1968;71:40-42.
Lonigan CJ, Fischel JE, Whitehurst GJ, Arnoid DS, Valdez-Menchaca MC. The role of otitis media in the development of expressive language disorder. Otitis Media and Language Delay. 1992:430–440.
Lopatin BS, Lisiutin LS. [A rare foreign body of the tympanic cavity (acryl) necessitating surgical intervention in the middle ear]. Vestn Otorinolaringol. 1997:54.
Lopes F O. Amoxicillin versus amoxicillin + nimesulide in otolaryngologic infections - A randomized study. FOHLA MED. 1991;102:81-85.
Lopes F O, Da S L, De M J C. Controlled randomized study of cefixime versus amoxicillin /clavulanate in the treatment of acute otitis media. Folha Medica. 1996;112:245-250.
Lopes Cardoso F L, Machado E S, Souza M J, Cunha R. Rhodococcus equi mastoiditis in a patient with AIDS. Clin Infect Dis. 1996;22:713. [pmid: 8729214].
Lopes Filho Ol, Mimica I, Betti E, Burlamaqui J C, Takara C, Mimica L J. Efic cia cl¡nica e bacteriol¢gica da associa‡,o clavulanato de pot ssio + amoxicilina e do cefaclor em otite m,dia aguda em crian‡as / Clinical and bacteriological efficacy of the association amoxillin-clavulanate potassium compared with cefaclor for acute otitis media in children. Folha-m,d. 1992;104:39-42.
Lopez J, Eres N, Fernandez X, Buti M. [Cellulitis caused by Streptococcus pneumoniae associated with spondylodiscitis after suppurative otitis media (letter)]. Enferm Infecc Microbiol Clin. 1997;15:171-172. [pmid: 9235066].
Lopez Amado M, Arrojo Alonso F, Garcia Sarandeses A, Herranz Gonzalez J, Martinez Vidal J. [ENT diagnosis of Wegener's syndrome]. An Otorrinolaringol Ibero Am. 1994;21:343-355. [pmid: 8092442].
Lopez Amado M, Martinez Vidal J, Garcia Sarandeses A. [Antibiotic prophylaxis in surgery of uncomplicated cholesteatoma: review of 150 patients]. Acta Otorrinolaringol Esp. 1995;46:421-426. [pmid: 8554821].
Lopez-Gomez M, Mediavilla Garcia J D, Duro Ruiz G, Bianchi Llave J L. [Convulsions induced by imipenem in an HIV-positive patient (letter]. Enferm Infecc Microbiol Clin. 1995;13:571. [pmid: 8519843].
Lopponen H, Sorri M, Pekkala R, Penna J. Secretory otitis media and high-frequency hearing loss. Acta Oto-Laryngologica - Supplement. 1992;493:99-107.
Lorente D J, Sabater F, Maristany M, et al. Multi-centre study comparing the efficacy and tolerance of topical ciprofloxacin (0,3%) versus topical gentamicin (0,3%) in the treatment of simple, non-cholesteatomatous chronic otitis media in the suppurative phase. Anales Otorrinolaringologicos Ibero Americanos. 1995;22:521-533. [pmid: 7485860].
Lorente J, Sabater F, Maristany M, et al. [Multicenter study comparing the efficacy and tolerance of topical ciprofloxacin (0.3%) versus topical gentamicin (0.3%) in the treatment of simple, non-cholesteatomaous chronic otitis media in the suppurative phase]. An-Otorrinolaringol-Ibero-Am. 1995;22:521-533. [pmid: 7485860].
Losada J S. Classification and treatment of loss of conductive hearing. Medical Journal of Zambia. 1975;9:107-111. [pmid: 1224772].
Louhiala P J, Jaakkola N, Ruotsalainen R, Jaakkola J J. Form of day care and respiratory infections among Finnish children. Am J Public Health. 1995;85:1109-1112. [pmid: 7625505]. [pmcid: 1615809].
Lous J, Fiellau-Nikolajsen M. Epidemiology and middle ear effusion and tubal dysfunction. A one-year prospective study comprising monthly tympanometry in 387 non-selected 7-year-old children. Int J Pediatr Otorhinolaryngol. 1981;3:303-317. [pmid: 6976949].
Lous J. Three impedance screening programs on a cohort of seven-year-old children. Can serial impedance screening reveal chronic middle ear disease? Scand Audiol. 1982;11.
Lous J. Three impedance screening programs on a cohort of seven-year-old children. Can serial impedance screening reveal chronic middle ear disease?. Scand Audiol Suppl. 1983;17:60-64. [pmid: 6577561].
Lous J, Fiellau-Nikolajsen M. A 5-year prospective case-control study of the influence of early otitis media with effusion on reading achievement. Int J Pediatr Otorhinolaryngol. 1984;8:19-30. [pmid: 6542073].
Lous J. Linguistic and cognitive sequelae to secretory otitis media in children. Scand Audiol Suppl. 1986;26:71-75. [pmid: 3472331].
Lous J. Screening for secretory otitis media: evaluation of some impedance screening programs for long-lasting secretory otitis media in 7-year-old children. Int J Pediatr Otorhinolaryngol. 1987;13:85-97. [pmid: 3623813].
Lous J, Fiellau-Nikolajsen M, Jeppesen A L. Secretory otitis media and language development: a six-year follow-up study with case-control. Int J Pediatr Otorhinolaryngol. 1988;15:185-203. [pmid: 3397239].
Lous J, Fiellau-Nikolajsen M. Early otitis media with effusion and reading achievement. Allgemeinmedizin. 1988;17:81-84.
Lous J, Fiellau-Nikolajsen M, Jeppesen AL. Secretory Otitis Media and Verbal Intelligence: A Six-Year Prospective Case Control Study. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:393–395.
Lous J. Secretory otitis media and phonology when starting school. Scand Audiol. 1990;19:215-222. [pmid: 2075413].
Lous J. Silent reading and secretory otitis media in school children. Int J Pediatr Otorhinolaryngol. 1993;25:25-38. [pmid: 8436473].
Lous J. Otitis media and reading achievement: a review. Int J Pediatr Otorhinolaryngol. 1995;32:105-121. [pmid: 7657465].
Lous J. Secretory otitis media in schoolchildren. Is screening for secretory otitis media advisable?. Dan Med Bull. 1995;42:71-99. [pmid: 7729171].
Lous J. [More stringent guidelines for tympanostomy tubes in secretory otitis media in the USA]. Ugeskr Laeger. 1996;158:3793-3794. [pmid: 8686078].
Lous J. Secretory otitis media and reading achievement. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:401–405.
Lovdahl M J, Reher K E, Russlie H Q, Canafax D M. Determination of cefpodoxime levels in chinchilla middle ear fluid and plasma by high-performance liquid chromatography. Journal of Chromatography B: Biomedical Applications. 1994;653:227-232.
Lovejoy H M, McGuirt W F, Ayres P H, Hayes A W, Coggins C R, Sagartz J. Effects of low humidity on the rat middle ear. Laryngoscope. 1994;104:1055-1058. [pmid: 8072348].
Lovette S. Improved diagnosis of middle ear effusions employing the objective otoscope. Ann Otol Rhinol Laryngol. 1976;85:229-233. [pmid: 1267352].
Low W K. Middle ear pressures in patients with nasopharyngeal carcinoma and their clinical significance [see comments]. J Laryngol Otol. 1995;109:390-393. [pmid: 7797993].
Low W K, Fong K W. Hearing disability before and after radiotherapy for nasopharyngeal carcinoma. J Laryngol Otol. 1996;110:121-123. [pmid: 8729492].
Low W K, Lim T A, Fan Y F, Balakrishnan A. Pathogenesis of middle-ear effusion in nasopharyngeal carcinoma: a new perspective. J Laryngol Otol. 1997;111:431-434. [pmid: 9205601].
Low W K, Fong K W. Long-term post-irradiation middle ear effusion in nasopharyngeal carcinoma. Auris Nasus Larynx. 1998;25:319-321. [pmid: 9800000].
Lowery N, Kearns G L, Young R A, Wheeler J G. Serum sickness-like reactions associated with cefprozil therapy. J Pediatr. 1994;125:325-328. [pmid: 8040786].
Lozano F, Esteban F, Florez C, Corzo J E, Gomez-Mateos J. [Bacteremia caused by Enterococcus avium secondary to thrombosis of the lateral sinus and the internal jugular vein (letter)]. Enferm Infecc Microbiol Clin. 1996;14:458. [pmid: 8991452].
Lu H, Ma H. [Long-term effect of the modified type-III tympanoplasty]. Chung Hua Erh Pi Yen Hou Ko Tsa Chih - Chinese Journal of Otorhinolaryngology. 1994;29:42-44.
Lucas K G, Howrie D L, Phebus C K. Cardiorespiratory decompensation following methylprednisolone administration [see comments]. Pediatr Hematol Oncol. 1993;10:249-255. [pmid: 8217541].
Luchikhin LA, Derbeneva ML, Ostrovtsev IV. [Effectiveness of computerized tomography of the temporal bone in the diagnosis of chronic suppurative otitis media]. Vestn Otorinolaringol. 1995:31–34.
Lucic M, Haralampiev K, Purisic S, et al. Conservative surgery in the treatment of chronic exudative otitis and the rehabilitation of hearing. Symp Otorhinolaryngol Iugosl. 1985;20:187-191.
Lucic M. Exudative otitis media as a diagnostic problem. Symp Otorhinolaryngol Iugosl. 1986;21:77-80.
Ludman H. ABC of ENT. Deafness in childhood. Br Med J Clin Res Ed. 1981;282:381-383.
Ludman H. Neuronal activity in otology. J Laryngol Otol. 1986;100:989-1007. [pmid: 3760694].
Lukowski M, Bialaczewski L. [Evaluation of bone conduction after chronic ear surgery and after stapedectomy]. Otolaryngol Pol. 1994;48:282-7. [pmid: 8090493].
Luloff AK, Menyk P, Teele DW. Effect of persistent otitis media on the speech sound repertoire of infants. In: Lim DJ BC, Klein JO, Nelson JK, Ogra P, ed. Recent Advances in Otitis Media: Proceedings of the Fifth International Symposium: Decker Periodicals; 1993:531–533.
Lundy L B, Graham M D, Kartush J M, LaRouere M J. Temporal bone encephalocele and cerebrospinal fluid leaks. Am J Otol. 1996;17:461-469. [pmid: 8817026].
Luntz M, Keren G, Nusem S, Kronenberg J. Acute mastoiditis--revisited. Ear Nose Throat J. 1994;73:648-654. [pmid: 7988394].
Luntz M, Hodges A V, Balkany T, Dolan-Ash S, Schloffman J. Otitis media in children with cochlear implants. Laryngoscope. 1996;106:1403-1405. [pmid: 8914909].
Luntz M, Balkany T, Hodges A V, Telischi F F. Cochlear implants in children with congenital inner ear malformations. Arch Otolaryngol Head Neck Surg. 1997;123:974-977. [pmid: 9305249].
Luotonen M, Uhari M, Aitola L, Lukkaroinen A M, Luotonen J, Korkeamaki R L. Recurrent otitis media during infancy and linguistic skills at the age of nine years. Pediatr Infect Dis J. 1996;15:854-858. [pmid: 8895915].
Lustig L R, Jackler R K. Neurofibromatosis type I involving the external auditory canal. Otolaryngol Head Neck Surg. 1996;114:299-307. [pmid: 8637757].
Luxford W M, Sheehy J L. Myringotomy and ventilation tubes: a report of 1,568 ears. Laryngoscope. 1982;92:1293-1297. [pmid: 6890608].
Luxford W M, House W F. Cochlear implants in children: medical and surgical considerations. Ear Hear. 1985;6:20S-23S. [pmid: 3839471].
Lyn C, Jadusingh W A, Ashman H, Chen D, Abramson A, Soutar I. Hearing screening in Jamaica: prevalence of otitis media with effusion. Laryngoscope. 1998;108:288-290. [pmid: 9473084].
Ma K H, Tang P S, Chan K W. Aural tuberculosis. Am J Otol. 1990;11:174-177. [pmid: 2343901].
Maassen M M, Ludtke R, Lehner R, Reischl G, Zenner H P. [New methods of type II tympanoplasty in erosion of the long incus process]. HNO. 1997;45:133-139. [pmid: 9417436].
Maassen M M, Lehner R, Ludtke R, Strayle-Batra M, Zenner H P. Preoperative assessment of the implantable middle ear pump system using CT scans and conventional X-rays of the temporal bone. Ear Nose Throat J. 1997;76:457-463. [pmid: 9248139].
Mabey D. Importance of clinical trials in developing countries [comment] [see comments]. Lancet. 1996;348:1113-1114. [pmid: 8888161].
MacAdam A M, Rubio T. Tuberculous otomastoiditis in children. Am J Dis Child. 1977;131:152-156. [pmid: 299977].
MacAndie C, O'Reilly B F. Sensorineural hearing loss in chronic otitis media. Clin Otolaryngol Allied Sci. 1999;24:220-222. [pmid: 10384849].
MacDonald R R 3rd, Lusk R P, Muntz H R. Fasciaform myringoplasty in children. Arch Otolaryngol Head Neck Surg. 1994;120:138-143. [pmid: 8297569].
MacDonald C B, Bauer P W, Cox L C, McMahon L. Otologic findings in a pediatric cohort with sickle cell disease. Int J Pediatr Otorhinolaryngol. 1999;47:23-28. [pmid: 10206391].
Mace A L, Wallace K L, Whan M Q, Stelmachowicz P G. Relevant factors in the identification of hearing loss. Ear Hear. 1991;12:287-293. [pmid: 1723705].
Macias J D, Wackym P A, McCabe B F. Early diagnosis of otologic Wegener's granulomatosis using the serologic marker C-ANCA. Ann Otol Rhinol Laryngol. 1993;102:337-341. [pmid: 8489162].
Mackenzie I J. Factors affecting the extrusion rates of ventilation tubes. J-R-Soc-Med. 1984;77:751-753. [pmid: 6541254]. [pmcid: 1439984].
Mackenzie K, Dempster J H. External ear resonance in children with otitis media with effusion. Clin Otolaryngol Allied Sci. 1990;15:415-420. [pmid: 2282703].
Mackenzie I, Thompson S, Smith A, Bal I S, Hatcher J. Practical advice on field studies into hearing impairment in a developing country. Trop Doct. 1995;25:25-28. [pmid: 7886824].
Mackle G A, Giles M. The results of two years operation of the visiting specialist service to the Waikato mobile ear clinic. N Z Med J. 1995;108:410-413. [pmid: 7478335].
Macknin M L, Jones P K. Oral dexamethasone for treatment of persistent middle ear effusion. Pediatrics. 1985;75:329-335. [pmid: 4038553].
Macknin M L, Skibinski C, Beck G, Hughes G, Kinney S. Acoustic reflectometry detection of middle ear effusion. Pediatr Infect Dis J. 1987;6:866-868. [pmid: 3313253].
Macknin ML, Collard ME, Mendendorp SV. Acoustic reflectometry compared to tympanometry and pure tone thresholds. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:60–64.
MacLoughlin G J, Barreto D G, de la Torre C, Pinetta E A, del Castillo F, Palma L. Cefpodoxime proxetil suspension compared with cefaclor suspension for treatment of acute otitis media in paediatric patients. J-Antimicrob-Chemother. 1996;37:565-573. [pmid: 9182113].
Macmillan A S Jr. Radiologic diagnosis of neuro-otological problems by conventional radiology. Arch Otolaryngol. 1969;89:52-56. [pmid: 4302374].
Macnamara M, Phillips D, Proops D W. The bone anchored hearing aid (BAHA) in chronic suppurative otitis media (CSOM). Journal of Laryngology and Otology - Supplement. 1996;21:38-40.
Maddox H E d. Metastatic tumors of the temporal bone. Ann Otol Rhinol Laryngol. 1967;76:149-165. [pmid: 6020328].
Madeline L A, Elster A D. Suture closure in the human chondrocranium: CT assessment. Radiology. 1995;196:747-756. [pmid: 7644639].
Madell JR. Impact of otitis media on auditory function. In: Rosenfeld RM, Bluestone CD, eds. Evidence-Based Otitis Media. Saint Louis: B.C. Decker, Inc.; 1999:337–351.
Mafee M F, Singleton E L, Valvassori G E, Espinosa G A, Kumar A, Aimi K. Acute otomastoiditis and its complications: role of CT. Radiology. 1985;155:391-397. [pmid: 3983389].
Mafee M F, Valvassori G E, Kumar A, et al. Tumors and tumor-like conditions of the middle ear and mastoid: role of CT and MRI. An analysis of 100 cases. Otolaryngol Clin North Am. 1988;21:349-375. [pmid: 2833714].
Mafee M F, Levin B C, Applebaum E L, Campos M, James C F. Cholesteatoma of the middle ear and mastoid. A comparison of CT scan and operative findings. Otolaryngol Clin North Am. 1988;21:265-293. [pmid: 3357696].
Mafee M F. MRI and CT in the evaluation of acquired and congenital cholesteatomas of the temporal bone. J Otolaryngol. 1993;22:239-248. [pmid: 8230374].
Magid S L. Surgical treatment in allergic disorders of the ear, nose, and throat. Otolaryngol Clin North Am. 1971;4:583-589. [pmid: 4106823].
Magin R L, Oh D K, Zhang A, Webb A G, Thulin J D. Monitoring pH of otitis media effusion in chinchillas using fluorescence spectroscopy. IEEE Trans Biomed Eng. 1995;42:1027-1032. [pmid: 8582720].
Magit A E, Stool S E. Clinical guideline development for otitis media: a report on methodology. Otolaryngol Head Neck Surg. 1993;109:478-481. [pmid: 8414566].
Magit A E, Dolitsky J N, Doyle W J, Swarts J D, Seroky J T, Rosenfeld R M. An experimental study of cefixime in the treatment of Streptococcus pneumoniae otitis media. Int J Pediatr Otorhinolaryngol. 1994;29:1-9. [pmid: 8169042].
Magit A E. Guidelines for managing chronic otitis media with effusion. West J Med. 1995;163:153. [pmid: 7571563].
Magliulo G, Gagliardi M, Muscatello M, Natale A. Masking level difference before and after surgery. Br J Audiol. 1990;24:117-121. [pmid: 2350621].
Magliulo G, Vingolo G M, Petti R, Ronzoni R, Cristofari P. Acute mastoiditis in pediatric age. Int J Pediatr Otorhinolaryngol. 1995;31:147-151. [pmid: 7782172].
Magliulo G, Cristofari P, Terranova G. Glomus tumor in pediatric age. Int J Pediatr Otorhinolaryngol. 1996;38:77-80. [pmid: 9119596].
Magliulo G, Terranova G, Cristofari P, Ronzoni R. Sigmoid sinus thrombosis and imaging techniques. Ann Otol Rhinol Laryngol. 1996;105:991-993. [pmid: 8973287].
Magliulo G, Ronzoni R, Cristofari P. Medial meatal fibrosis: current approach. J Laryngol Otol. 1996;110:417-420. [pmid: 8762306].
Magnuson B, Falk B. Eustachian tube malfunction and middle ear disease in new perspective. J Otolaryngol. 1983;12:187-193. [pmid: 6876245].
Magnuson B, Falk B. Diagnosis and management of eustachian tube malfunction. Otolaryngol Clin North Am. 1984;17:659-671. [pmid: 6542637].
Magnuson K, Hellstrom S. Early structural changes in the rat tympanic membrane during pneumococcal otitis media. Eur Arch Otorhinolaryngol. 1994;251:393-398. [pmid: 7857626].
Magnuson K, Hermansson A, Hellstrom S. Healing of tympanic membrane after myringotomy during Streptococcus pneumoniae otitis media. An otomicroscopic and histologic study in the rat. Ann Otol Rhinol Laryngol. 1996;105:397-404. [pmid: 8651635].
Magnuson K, Hermansson A, Melhus A, Hellstrom S. The tympanic membrane and middle ear mucosa during non-typeable Haemophilus influenzae and Haemophilus influenzae type b acute otitis media: a study in the rat. Acta Otolaryngol. 1997;117:396-405. [pmid: 9199526].
Magomedov MM, Ivanets IV, Muratov DL. [Early diagnosis of neurosensory component in various forms of conductive hearing loss]. Vestn Otorinolaringol. 1997:25–29.
Mahindra S, Bery K, Malik G B, Sohail M A, Logani K B. Embryonal rhabdosarcoma of the middle ear and mastoid. J Laryngol Otol. 1978;92:253-258. [pmid: 632665].
Maiman L A, Becker M H, Liptak G S, Nazarian L F, Rounds K A. Improving pediatricians' compliance-enhancing practices. A randomized trial. Am-J-Dis-Child. 1988;142:773-779. [pmid: 3381783].
Mains B T, Toner J G. Pneumatic otoscopy: study of inter-observer variability. J Laryngol Otol. 1989;103:1134-1135. [pmid: 2614229].
Mair I W, Sohoel P, Elverland H H. Brain stem electric response audiometry and middle ear effusion. Scand Audiol. 1979;8:227-231. [pmid: 531476].
Mair I W S, Haugeto O K, Elverland H H, Schroder K E. Chronic secretory otitis media. Int J Pediatr Otorhinolaryngol. 1980;2:161-170. [pmid: 6892364].
Mair I W, Fjermedal O, Laukli E. Air conduction thresholds and secretory otitis media: a conventional and extra-high frequency audiometric comparison. Ann Otol Rhinol Laryngol. 1989;98:767-771. [pmid: 2802458].
Mair I W. Raised ABR threshold after suction aspiration of glue from the middle ear: three case studies [letter; comment]. J Laryngol Otol. 1996;110:106. [pmid: 8745798].
Majeed A, Harris T. Acute otitis media in children [editorial; comment]. Br Med J. 1997;315:321-322. [pmid: 9270442].
Majima Y. Tympanostomy tube therapy for pediatric otitis media with effusion. Otolaryngology. 1984;56:475-479.
Majima Y, Sakakura Y, Hamaguchi Y, et al. Rheological properties of middle ear effusion and their role on mucociliary clearance. Auris Nasus Larynx. 1985;12:S129-S131. [pmid: 3835886].
Majima Y, Hamaguchi Y, Hirata K, Takeuchi K, Morishita A, Sakakura Y. Hearing impairment in relation to viscoelasticity of middle ear effusions in children. Ann Otol Rhinol Laryngol. 1988;97:272-274. [pmid: 3377394].
Majkus V, Skovronsky O. Operation of chronic otitis media with formation of a local reservoir of antibiotics. Clinical and functional results. Practica Oto-Rhino-Laryngologica. 1971;33:265-270. [pmid: 5123784].
Makela P H, Sibakov M, Herva E, et al. Pneumococcal vaccine and otitis media. Lancet. 1980;2:547-551. [pmid: 6106735].
Makela PH, Leinonen M, Pukander J, Karma P. A study of the pneumococcal vaccine in prevention of clinically acute atttacks of recurrent otitis media. Rev-Infect-Dis. 1981:S124–S132.
Makino K, Amatsu M, Kinishi M, Mohri M. The clinical features and pathogenesis of myringitis granulosa. Arch Otorhinolaryngol. 1988;245:224-229. [pmid: 3178571].
Maldonado Y, Hestvik L, Wilson M, et al. Safety and immunogenicity of bovine rotavirus vaccine RIT 4237 in 3- months-old infants. J PEDIATR-(ST. LOUIS). 1986;109:931-935.
Males A G, Gray R F. Mastoid misery: quantifying the distress in a radical cavity. Clin Otolaryngol Allied Sci. 1991;16:12-14. [pmid: 2032350].
Malkiewicz J. The fine art of giving a physical: how to assess the ears and test hearing acuity. Rn. 1982;45:56-63. [pmid: 6918096].
Malm L, White P. Beta-agonists and surfactant in eustachian tube function. Acta-Otolaryngol-Suppl-Stockh. 1992:133–136.
Man A, Winerman I. Does drill noise during mastoid surgery affect the contralateral ear?. Am J Otol. 1985;6:334-335. [pmid: 4025532].
Manach Y. Natural history of otitis media with effusion. Medecine et Maladies Infectieuses. 1996;26:49-52.
Mandel E M, Bluestone C D, Cantekin E I, Ghorbanian S N, Rockette H E. Comparison of cefaclor and amoxicillin for acute otitis media with effusion. Ann-Otol-Rhinol-Laryngol-Suppl. 1981;90:48-52. [pmid: 6791563].
Mandel E M, Bluestone C D, Rockette H E, et al. Duration of effusion after antibiotic treatment for acute otitis media: comparison of cefaclor and amoxicillin. Pediatr-Infect-Dis. 1982;1:310-316. [pmid: 6760146].
Mandel EM, Bluestone CD, Paradise JL, et al. Efficacy of Myringotomy with and without Tympanostomy Tube Insertion in the Treatment of Chronic Otitis Media with Effusion in Infants and Children: Results for the First Year of a Randomized Clinical Trial. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:308–313.
Mandel E M, Rockette H E, Bluestone C D, Paradise J L, Noza R J. Efficacy of amoxicillin with and without decongestant-antihistamine for otitis media with effusion in children. Results of a double-blind, randomized trial. N Engl J Med. 1987;316:432-437. [pmid: 2880294].
Mandel EM, Rockette HE, Bluestone CD, Paradise JL, Nozza RJ. Efficacy of Myringotomy with and without Tympanostomy Tube Insertion for Chronic Otitis Media With Effusion: First Year Results in Two Randomized Clinical Trials. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:266–269.
Mandel E M, Rockette H E, Bluestone C D, Paradise J L, Nozza R J. Myringotomy with and without tympanostomy tubes for chronic otitis media with effusion. Arch Otolaryngol Head Neck Surg. 1989;115:1217-1224. [pmid: 2789777].
Mandel E M, Rockette H E, Paradise J L, Bluestone C D, Nozza R J. Comparative efficacy of erythromycin-sulfisoxazole, cefaclor, amoxicillin or placebo for otitis media with effusion in children. Pediatr Infect Dis J. 1991;10:899-906. [pmid: 1766705].
Mandel EM, Bluestone CD, Takahashi H, Casselbrant ML. Effect of adenoidectomy on eustachian tube function. Preliminary results of a randomized clinical trial. Adv-Otorhinolaryngol. 1992:227–231.
Mandel E M, Rockette H E, Bluestone C D, Paradise J L, Nozza R J. Efficacy of myringotomy with and without tympanostomy tubes for chronic otitis media with effusion. Pediatr Infect Dis J. 1992;11:270-277. [pmid: 1565550].
Mandel E M, Kardatzke D, Bluestone C D, Rockette H E. A comparative evaluation of cefaclor and amoxicillin in the treatment of acute otitis media. Pediatr Infect Dis J. 1993;12:726-732. [pmid: 8414799].
Mandel E M, Rockette H E, Bluestone C D, Paradise J L, Nozza R J. Antibiotic therapy for otitis media with effusion. A response from Pittsburgh [see comments]. JAMA. 1993;269:516-517. [pmid: 8419673].
Mandel E M, Casselbrant M L, Kurs-Lasky M. Acute otorrhea: bacteriology of a common complication of tympanostomy tubes. Ann-Otol-Rhinol-Laryngol. 1994;103:713-718. [pmid: 8085732].
Mandel E M, Casselbrant M L, Rockette H E, Bluestone C D, Kurs-Lasky M. Efficacy of 20- versus 10-day antimicrobial treatment for acute otitis media. Pediatrics. 1995;96:5-13. [pmid: 7596722].
Mandel E M, Casselbrant M L, Rockette H E, Bluestone C D, Kurs-Lasky M. Efficacy of antimicrobial prophylaxis for recurrent middle ear effusion. Pediatr Infect Dis J. 1996;15:1074-1082. [pmid: 8970215].
Mandel E M, Casselbrant M L, Kurs-Lasky M, Bluestone C D. Efficacy of ceftibuten compared with amoxicillin for otitis media with effusion in infants and children. Pediatr Infect Dis J. 1996;15:409-414. [pmid: 8724062].
Manders E, Tyberghein J. The effects of ventilation tube placement on hearing, speech, language, cognition and behaviour. Acta Otorhinolaryngol Belg. 1993;47:27-32. [pmid: 8470547].
Manfre L, Lagalla R, Ferrara S, Riggio E, Tortorici M, Cardinale A E. MRI of the inner ear: use of modified GRASS and fast spin-echo sequences. A preliminary study. Neuroradiology. 1996;38:669-674. [pmid: 8912326].
Mangabeira-Albernaz P L. The Mondini dysplasia--from early diagnosis to cochlear implant. Acta Otolaryngol. 1983;95:627-631. [pmid: 6688320].
Mangat K S, Morrison G A, Ganniwalla T M. T-tubes: a retrospective review of 1274 insertions over a 4-year period. Int J Pediatr Otorhinolaryngol. 1993;25:119-125. [pmid: 8436454].
Mann W. Echography of the infantile mastoid. Arch Otorhinolaryngol. 1978;220:291-294. [pmid: 581173].
Mann W, Jonas I, Riede U N, Beck C, Lohle E. A contribution to the pathogenesis of cholesteatoma. A histochemical and ultrastructural study. Arch Otorhinolaryngol. 1981;230:121-132. [pmid: 7295171].
Manni J J, Lema P N. Otitis media in Dar es Salaam, Tanzania. J Laryngol Otol. 1987;101:222-228. [pmid: 3572227].
Mannina J. Finding an effective hearing testing protocol to identify hearing loss and middle ear disease in school-aged children. Journal of School Nursing. 1997;13:23-28. [pmid: 9469080].
Manning SC. Sequelae of tympanostomy tubes (I). Pediatr Infect Dis J. 1990;9.
Manning S C, Brown O E, Roland P S, Phillips D L. Incidence of sensorineural hearing loss in patients evaluated for tympanostomy tubes. Arch Otolaryngol Head Neck Surg. 1994;120:881-884. [pmid: 8049054].
Manrique M J, Hernandez J, Huarte A, et al. Treatment of secretory otitis media with ambroxol. Acta Pediatrica Espanola. 1987;45:17-20.
Manrique M, Paloma V, Cervera-Paz F J, Ruiz de Erenchun I, Garcia-Tapia R. Pitfalls in cochlear implant surgery in children. Adv Otorhinolaryngol. 1995;50:45-50. [pmid: 7610967].
Mansbach A L. [Control of recurrent ENT infections in children]. Rev Med Brux. 1994;15:198-201. [pmid: 7938989].
Mansfield C J, Daniel H J, Sumpter E A, Barnes J, Coggins D, Young M. [Manner of birth and otitis media]. Archives Francaises de Pediatrie. 1993;50:97-100. [pmid: 8343033].
Mansfield E L, Cote D N. Barotrauma. J La State Med Soc. 1995;147:81-84. [pmid: 7722405].
Marais J, Armstrong M W. Parental knowledge and experiences after surgery for chronic otitis media. Br J Clin Pract. 1996;50:187-189. [pmid: 8759563].
Marchant C D, Shurin P A, Turcyzk V A, et al. A randomized controlled trial of cefaclor compared with trimethoprim-sulfamethoxazole for treatment of acute otitis media. J Pediatr. 1984;105:633-638. [pmid: 6384453].
Marchant C D, Shurin P A, Turczyk V A, Wasikowski D E, Tutihasi M A, Kinney S E. Course and outcome of otitis media in early infancy: a prospective study. J Pediatr. 1984;104:826-831. [pmid: 6539373].
Marchant CD, Shurlin PA, Tutihasi MA, Turczyk VA, Feinstein JC. Detection of Asymptomatic Otitis Media in Early Infancy. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:32–34.
Marchant CD, Shurin PA, Wiltshire JC, et al. Twice daily antimicrobial therapy for acute otitis media. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:281–283.
Marchant C D, Shurin P A, Johnson C E, et al. A randomized controlled trial of amoxicillin plus clavulanate compared with cefaclor for treatment of acute otitis media. J Pediatr. 1986;109:891-896. [pmid: 3534203].
Marchant C D, McMillan P M, Shurin P A, et al. Objective diagnosis of otitis media in early infancy by tympanometry and ipsilateral acoustic reflex thresholds. J Pediatr. 1986;109:590-595. [pmid: 3761072].
Marchant C D, Carlin S A, Johnson C E, Shurin P A. Measuring the comparative efficacy of antibacterial agents for acute otitis media: the “Pollyanna phenomenon”. J Pediatr. 1992;120:72-77. [pmid: 1731027].
Marchisio P, Principi N, Sala E, Lanzoni L, Sorella S, Massimini A. Comparative study of once-weekly azithromycin and once-daily amoxicillin treatments in prevention of recurrent acute otitis media in children. Antimicrob-Agents-Chemother. 1996;40:2732-2736. [pmcid: 163612]. [pmid: 9124831].
Marchisio P, Principi N, Sorella S, Sala E, Tornaghi R. Etiology of acute otitis media in human immunodeficiency virus-infected children. Pediatr Infect Dis J. 1996;15:58-61. [pmid: 8684878].
Marchisio P, Principi N, Passali D, et al. Epidemiology and treatment of otitis media with effusion in children in the first year of primary school. Acta-Otolaryngol-Stockh. 1998;118:557-562. [pmid: 9726683].
Marcus S M. Assessing non-consent bias with parallel randomized and nonrandomized clinical trials. J Clin Epidemiol. 1997;50:823-828. [pmid: 9253394].
Marget W, Thulin E. [Blood concentrations of different oral penicillin suspensions on the market (author's transl)]. Med-Klin. 1974;69:1611-1613. [pmid: 4215943].
Marghzar S. AuD should do more [letter]. ASHA. 1995;37:9-10. [pmid: 7779161].
Margolis C Z, Porter B, Barnoon S, Pilpel D. Reliability of the middle ear examination. Isr J Med Sci. 1979;15:23-28. [pmid: 570560].
Margolis R N, Heller J W. Screening tympanometry: criteria for medical referral. Audiology. 1987;26:197-208. [pmid: 3632475].
Margolis R H, Hunter L L. Audiologic evaluation of the otitis media patient. Otolaryngol Clin North Am. 1991;24:877-899. [pmid: 1870880].
Margolis RH, Hunter LL, Rykken JR, Giebink GS. Effects of otitis media on extended high-frequency hearing in children. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:540–543.
Margolis R H, Nelson D A. Acute otitis media with transient sensorineural hearing loss. A case study. Arch Otolaryngol Head Neck Surg. 1993;119:682-686. [pmid: 8499103].
Margolis R H, Hunter L L, Rykken J R, Giebink G S. Effects of otitis media on extended high-frequency hearing in children. Ann Otol Rhinol Laryngol. 1993;102:1-5. [pmid: 8420462].
Margolis R H, Hunter L L, Giebink G S. Tympanometric evaluation of middle ear function in children with otitis media. Ann Otol Rhinol Laryngol Suppl. 1994;163:34-38. [pmid: 8179267].
Margolis R H, Schachern P L, Hunter L L, Sutherland C. Multifrequency tympanometry in chinchillas. Audiology. 1995;34:232-247. [pmid: 8837783].
Marion M S, Hinojosa R, Libi S. Histopathology update. Am J Otolaryngol. 1995;16:194-195. [pmid: 7661317].
Maritz N G, Uys I C, Louw B. Otitis media and language performance in learning disabilities. South African Journal of Communication Disorders - die Suid-Afrikaanse Tydskrif vir Kommunikasieafwykings. 1988;35:17-23. [pmid: 3201286].
Marks N J, Mills R P, Shaheen O H. A controlled trial of cotrimoxazole therapy in serous otitis media. J Laryngol Otol. 1981;95:1003-1009. [pmid: 7028896].
Marks N J, Mills R P, Shaheen O H. Cotrimoxazole in the treatment of serous otisis. A follow-up report. J Laryngol Otol. 1983;97:213-215. [pmid: 6339654].
Marone S A M, Bento R F, Costa E G, Sennes L U, Bogar P, Miniti A. Neurosensorial hearing loss in otitis media with effusion. Revista Brasileira de Otorrinolaringologia. 1993;59:194-196.
Maroudias N, Economides J, Christodoulou P, Helidonis E. A study on the otoscopical and audiological findings in patients with Down's syndrome in Greece. Int J Pediatr Otorhinolaryngol. 1994;29:43-49. [pmid: 8169046].
Marsh R R, Handler S D. Hearing impairment in ventilator-dependent infants and children. Int J Pediatr Otorhinolaryngol. 1990;20:213-217. [pmid: 2089019].
Marshak G, Neriah Z B. Adenoidectomy versus tympanostomy in chronic secretory otitis media. Ann Otol Rhinol Laryngol Suppl. 1980;89:316-318. [pmid: 6778336].
Marshall F P, Cable H R. The effect of nitrous oxide on middle-ear effusions. J Laryngol Otol. 1982;96:893-897. [pmid: 7119559].
Marshall S G, Bierman C W, Shapiro G G. Otitis media with effusion in childhood. Annals of Allergy. 1984;53:370-378. [pmid: 6149711].
Marshall J, Narula A A. Persistent glue ear in children [letter; comment]. Br Med J. 1993;306:454. [pmid: 8461732].
Marshall SG KC, Pierson WE, Shapiro GG, Bierman CW. Prevalence of middle ear dysfunction and otitis media with effusion in atopic children. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:240.
Martin J A. Problems of diagnosis of hearing loss in the young child. Proceedings of the Royal Society of Medicine. 1971;64:571-574. [pmid: 5576923]. [pmcid: 1812552].
Martin F N, Butler E C, Burns P. A variation of the type B tympanogram. Laryngoscope. 1973;83:1783-1785. [pmid: 4758136].
Martin H C, Westwood G F, Bamford J M. Real ear to coupler differences in children having otitis media with effusion. Br J Audiol. 1996;30:71-78. [pmid: 8733786].
Martin B D, Macdonald S M. The management of ear disease: guidelines for Aboriginal health care programs. International Journal of Circumpolar Health. 1998;57:268-275. [pmid: 10093288].
Martin-Hirsch D P, Woodhead C J, Vize C E. Long-term ventilation of the middle ear using a tympanotomy technique. J Laryngol Otol. 1995;109:1151-1154. [pmid: 8551144].
Martinez S A, McNellis E L, Weber P C, Adkins W J. Bilateral acute coalescent mastoiditis in an immunocompromised infant with a rare leukocyte adhesion deficiency. Otolaryngol Head Neck Surg. 1999;120:926-928. [pmid: 10352452].
Martinez-Berriotxoa A, Montejo M, Aguirrebengoa K, Gonzalez de Zarate P, Aguirre C. [Otomastoiditis caused by Aspergillus in AIDS]. Enferm Infecc Microbiol Clin. 1997;15:200-202. [pmid: 9312279].
Marttila T I. Results of audiometrical screening in Finnish schoolchildren. Int J Pediatr Otorhinolaryngol. 1986;11:39-46. [pmid: 3710699].
Maruyama J, Aritomo H, Inaki S, Kobayashi J, Yanagihara N. [Clinical studies on acute otitis media in infants less than one year old]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1996;99:402-410.
Marx J, Osguthorpe J D, Parsons G. Day care and the incidence of otitis media in young children. Otolaryngol Head Neck Surg. 1995;112:695-699. [pmid: 7777354].
Masin J S, Hostoffer R W, Arnold J E. Otitis media following tympanostomy tube placement in children with IgG2 deficiency. Laryngoscope. 1995;105:1188-1190. [pmid: 7475873].
Mason J D, Mason S M, Gibbin K P. Raised ABR threshold after suction aspiration of glue from the middle ear: three case studies [see comments]. J Laryngol Otol. 1995;109:726-728. [pmid: 7561493].
Mason W H. The management of common infections in ambulatory children. Pediatr Ann. 1996;25:620-629. [pmid: 8937999].
Massias L, Buffe P, Cohen B, et al. Study of the distribution of oral ciprofloxacin into the mucosa of the middle ear and the cortical bone of the mastoid process. Chemotherapy. 1994;40:3-7. [pmid: 7805429].
Masters L, Marsh G Ed. Middle ear pathology as a factor in learning disabilities. Journal of Learning Disabilities. 1978;11:103-106. [pmid: 641419].
Matar G M, Sidani N, Fayad M, Hadi U. Two-step PCR-based assay for identification of bacterial etiology of otitis media with effusion in infected Lebanese children. J Clin Microbiol. 1998;36:1185-1188. [pmcid: 104796]. [pmid: 9574673].
Matas KE, Brown NC, Holman EJ. Measuring outcomes in nursing centers: otitis media as a sample case. Nurse Pract. 1996;21:116–118, 120, 122 passim.
Mathew T, Nordstrom K. On the equivalence of meta-analysis using literature and using individual patient data. Biometrics. 1999;55:1221-1223. [pmid: 11315071].
Matin M A, Khan A H, Khan F A, Haroon A A. A profile of 100 complicated cases of chronic suppurative otitis media. J R Soc Health. 1997;117:157-159. [pmid: 9195829].
Matsune S, Takahashi H, Sando I. Mucosa-associated lymphoid tissue in middle ear and Eustachian tube in children. Int J Pediatr Otorhinolaryngol. 1996;34:229-236. [pmid: 8839073].
Matsuoka A, Shitara T, Okamoto M, Furukawa K, Sano H. [Cholesteatoma in children--sex differences]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1993;96:1430-1437.
Matsuoka A. [Inflammatory middle ear diseases in children--sex differences]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1994;97:436-449.
Matt B H, Miller R P, Meyers R M, Campbell J M, Cotton R T. Incidence of perforation with Goode T-tube. Int J Pediatr Otorhinolaryngol. 1991;21:1-6. [pmid: 2037413].
Mattila P S, Tarkkanen J. B- and T-lymphocyte subpopulations in the adenoids of children with otitis media. APMIS. 1996;104:698-704. [pmid: 8980619].
Mattila P S, Tarkkanen J. Age-associated changes in the cellular composition of the human adenoid. Scand J Immunol. 1997;45:423-427. [pmid: 9105431].
Mattucci K F, Greenfield B J. Middle ear effusion--allergy relationships [see comments]. Ear Nose Throat J. 1995;74:752-756, 758. [pmid: 8536562].
Maw A R. Chronic otitis media with effusion (glue ear) and adenotonsillectomy: Prospective randomised controlled study. Br Med J. 1586;287:1586-1588. [pmid: 6416513].
Maw A R. Chronic otitis media with effusion (glue ear) and adenotonsillectomy: prospective randomised controlled study. Br Med J Clin Res Ed. 1983;287:1586-1588.
Maw A R. Chronic otitis media with effusion and adeno-tonsillectomy--a prospective randomized controlled study. Int J Pediatr Otorhinolaryngol. 1983;6:239-246. [pmid: 6373644].
Maw A R. Chronic otitis media with effusion (glue ear) and adenotonsillectomy: prospective randomised controlled study. Br Med J Clin Res Ed. 1983;287:1586-1588.
Maw A R, Jeans W D, Cable H R. Adenoidectomy. A prospective study to show clinical and radiological changes two years after operation. J Laryngol Otol. 1983;97:511-518. [pmid: 6864089].
Maw A R. Chronic otitis media with effusion and adeno-tonsillectomy. A prospective randomized controlled study. Int J Pediatr Otorhinolaryngol. 1983;6:239-246. [pmid: 6373644].
Maw AR. Chronic Otitis Media with Effusion and Adenotonsillectomy: A Prospective Randomized Controlled Study. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:299–302.
Maw A R. Age and adenoid size in relation to adenoidectomy in otitis media with effusion. Am J Otolaryngol. 1985;6:245-248. [pmid: 4040337].
Maw A R. Factors affecting adenoidectomy for otitis media with effusion (glue ear). J-R-Soc-Med. 1985;78:1014-1018. [pmid: 4067973]. [pmcid: 1290055].
Maw AR. The long term effect of adenoidectomy on established otitis media with effusion in children. Auris-Nasus-Larynx. 1985:S234–S236.
Maw A R, Herod F. Otoscopic, impedance, and audiometric findings in glue ear treated by adenoidectomy and tonsillectomy. A prospective randomised study. Lancet. 1986;1:1399-1402. [pmid: 2872514].
Maw A R. Glue ear (otitis media with effusion). Practitioner. 1987;231:1108-1112. [pmid: 3449839].
Maw AR, Parker A. Surgery of the tonsils and adenoids in relation to secretory otitis media in children. Acta-Otolaryngol-Suppl-Stockh. 1988:202–207.
Maw A R, Tiwari R S. Children with glue ear: how do they present?. Clin Otolaryngol Allied Sci. 1988;13:171-177. [pmid: 3402091].
Maw A R. Tonsils and adenoids. Their relation to secretory otitis media. Adv Otorhinolaryngol. 1988;40:81-88. [pmid: 3389234].
Maw AR. Early and Late Effects of Surgery for Otitis Media with Effusion. ; 1988.
Maw A R. Development of tympanosclerosis in children with otitis media with effusion and ventilation tubes. J Laryngol Otol. 1991;105:614-617. [pmid: 1919311].
Maw A R, Smith I M, Lance G N. Lateral cephalometric analysis of children with otitis media with effusion: a comparison with age and sex matched controls. J Laryngol Otol. 1991;105:71-77. [pmid: 2013733].
Maw A R, Parker A J, Lance G N, Dilkes M G. The effect of parental smoking on outcome after treatment for glue ear in children. Clin Otolaryngol Allied Sci. 1992;17:411-414. [pmid: 1458623].
Maw R, Bawden R. Spontaneous resolution of severe chronic glue ear in children and the effect of adenoidectomy, tonsillectomy, and insertion of ventilation tubes (grommets). Br Med J. 1993;306:756-760. [pmid: 8490338]. [pmcid: 1677213].
Maw A R, Bawden R, O'Keefe L, Gurr P. Does the type of middle ear aspirate have any prognostic significance in otitis media with effusion in children?. Clin Otolaryngol Allied Sci. 1993;18:396-399. [pmid: 8877207].
Maw A R, Parker A J. A model to refine the selection of children with otitis media with effusion for adenoidectomy. Clin Otolaryngol Allied Sci. 1993;18:164-170. [pmid: 8365001].
Maw A R, Bawden R. Does adenoidectomy have an adjuvant effect on ventilation tube insertion and thus reduce the need for re-treatment?. Clin Otolaryngol Allied Sci. 1994;19:340-343. [pmid: 7994892].
Maw A R, Bawden R. Factors affecting resolution of otitis media with effusion in children. Clin-Otolaryngol. 1994;19:125-130. [pmid: 8026089].
Maw A R, Bawden R. The long term outcome of secretory otitis media in children and the effects of surgical treatment: a ten year study. Acta-Otorhinolaryngol-Belg. 1994;48:317-324. [pmid: 7810300].
Maw A R, Bawden R. Tympanic membrane atrophy, scarring, atelectasis and attic retraction in persistent, untreated otitis media with effusion and following ventilation tube insertion. Int J Pediatr Otorhinolaryngol. 1994;30:189-204. [pmid: 7836032].
Maw A R. Glue ear [letter; comment]. Lancet. 1995;345:922. [pmid: 7707824].
Maw A R. Grommets: what GPs need to know. Practitioner. 1996;240:450-453. [pmid: 8759505].
Maw AR, Bawden R. Long-term sequelae of the tympanic membrane following otitis media with effusion and after ventilation tubes. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:379.
Maw R, Wilks J, Harvey I, Peters T J, Golding J. Early surgery compared with watchful waiting for glue ear and effect on language development in preschool children: a randomised trial. Lancet. 1999;353:960-963. [pmid: 10459904].
Mawson S, Mawson B, D. GJ, A. H. Terramycin [oxytetracycline] in the treatment of acute otitis media in children. Br Med J. 1953;1:817–819.
Mawson S R. Myringotomy. Br Med J. 1968;3:539-541. [pmid: 5676958].
Mawson S R, Brennand J. Long-term follow up of 129 glue ears. Proceedings of the Royal Society of Medicine. 1969;62:460-463. [pmid: 5770592]. [pmcid: 1810971].
Mawson S R, Lord I. Tympanoplasty in Britain. Ann Otol Rhinol Laryngol. 1972;81:686-689. [pmid: 4651112].
Mawson S R, Fagan P. Tympanic effusions in children. Long-term results of treatment by myringotomy, aspiration and indwelling tubes (grommets). J Laryngol Otol. 1972;86:105-119. [pmid: 5058477].
Mawson S R. Middle ear effusions: definitions. Ann Otol Rhinol Laryngol. 1976;85:12-14. [pmid: 773244].
Maxson S, Yamauchi T. Acute otitis media. Pediatr Rev. 1996;17:191–195; quiz 196.
Maxwell K S, Fitzgerald J E, Burleson J A, Leonard G, Carpenter R, Kreutzer D L. Interleukin-8 expression in otitis media. Laryngoscope. 1994;104:989-995. [pmid: 8052085].
Maxwell K, Leonard G, Kreutzer D L. Cytokine expression in otitis media with effusion. Tumor necrosis factor soluble receptor. Arch Otolaryngol Head Neck Surg. 1997;123:984-988. [pmid: 9305251].
May M, Fria T J, Blumenthal F, Curtin H. Facial paralysis in children: differential diagnosis. Otolaryngol Head Neck Surg. 1981;89:841-848. [pmid: 6799919].
Maynard J E, Fleshman J K, Tschopp C F. Otitis media in Alaskan Eskimo children. Prospective evaluation of chemoprophylaxis. JAMA. 1972;219:597-599. [pmid: 5066805].
McAskile K. The radical mastoidectomy. J Otolaryngol. 1980;9:143-148. [pmid: 6990009].
McCabe B F. Clinical aspects of the differential diagnosis of end-organ vertigo. Ann Otol Rhinol Laryngol. 1968;77:193-198. [pmid: 5300707].
McCabe B F. The incidence, site, treatment and fate of labyrinthine fistula. Clin Otolaryngol Allied Sci. 1978;3:239-242. [pmid: 737857].
McCaig L F, Hughes J M. Trends in antimicrobial drug prescribing among office-based physicians in the United States [see comments]. JAMA. 1995;273:214-219. [pmid: 7807660].
McCandless G A, Thomas G K. Impedance audiometry as a screening procedure for middle ear disease. Transactions - American Academy of Ophthalmology and Otolaryngology. 1974;78:ORL98-102. [pmid: 4825072].
McCarthy P E, Hosgood G, Pechman R D. Traumatic ear canal separations and para-aural abscessation in three dogs. J Am Anim Hosp Assoc. 1995;31:419-424. [pmid: 8542360].
McCarty J M, Phillips A, Wiisanen R. Comparative safety and efficacy of clarithromycin and amoxicillin/clavulanate in the treatment of acute otitis media in children. Pediatr Infect Dis J. 1993;12:S122-S127. [pmid: 8295813].
McCarty J. A multicenter, open label trial of azithromycin for the treatment of children with acute otitis media. Pediatr Infect Dis J. 1996;15:S10-S14. [pmid: 8878240].
McCracken G H Jr. Considerations in selecting an antibiotic for treatment of acute otitis media. Pediatr Infect Dis J. 1994;13:1054-1057. [pmid: 7845740].
McCracken G H Jr. Emergence of resistant Streptococcus pneumoniae: a problem in pediatrics. Pediatr Infect Dis J. 1995;14:424-428. [pmid: 7638032].
McCurdy J A. Letter: Impedance audiometry suggested. Pediatrics. 1974;54:384. [pmid: 4414266].
McCurdy J A Jr. The tonsillectomy-adenoidectomy dilemma. Am Fam Physician. 1977;16:137-141. [pmid: 900000].
McCurdy J A Jr. Middle ear effusion: current concepts. Am Fam Physician. 1978;17:107-111. [pmid: 645530].
McDermott J C. Immittance screening for aural problems in school children. J Sch Health. 1982;52:462-468. [pmid: 6923958].
McDermott J C. Physical and behavioral aspects of middle ear disease in school children. J Sch Health. 1983;53:463-466. [pmid: 6557254].
McDermott J C, Giebink G S, Le C T, Harford E R, Paparella M M. Children with persistent otitis media. Audiometric and tympanometric findings. Arch Otolaryngol. 1983;109:360-363. [pmid: 6847493].
McDonald T J, Neel H Bd, O'Connell E J. Managing ear infection in children. Postgrad Med. 1981;69:77-79, 8283. [pmid: 7195023].
McDonald J M, Seipp W S, Gordon E M, Heroy J. Audiologic findings in achondroplasia. Basic Life Sci. 1988;48:143-147. [pmid: 3240243].
McDonald J A, Saulsbury F T. Chronic Candida albicans otitis media in children with immunodeficiency. Pediatr Infect Dis J. 1997;16:529-531. [pmid: 9154553].
McDowell P R, Gaudin P B, Wu T C, Francis H. Pathologic quiz case. Adenovirus infection of the adenoids. Arch Otolaryngol Head Neck Surg. 1994;120:668-671. [pmid: 8198791].
McGee T M. Pediatric deafness. 3. Glue ear. J Otolaryngolog Soc Aust. 1970;3:93-96.
McGee T J, Clemis J D. Effects of conductive hearing loss on auditory brainstem response. Ann Otol Rhinol Laryngol. 1982;91:304-309. [pmid: 7092053].
McGee R, Silva P A, Stewart I A. Behaviour problems with otitis media with effusion: A report from the Dunedin Multidisciplinary Child Development Study. New Zealand Med J. 1982;95:655-657. [pmid: 6957791].
McGrae J D Jr. Keratitis, ichthyosis, and deafness (KID) syndrome with adult onset of keratitis component. Int J Dermatol. 1990;29:145-146. [pmid: 2323870].
McGregor D H, Cherian R, Kepes J J, Kepes M. Case reports: heterotopic brain tissue of middle ear associated with cholesteatoma. Am J Med Sci. 1994;308:180-183. [pmid: 8074137].
McGuiness R J. Carboxymethylcysteine in the glue ear syndrome. Br-J-Clin-Pract. 1977;31:105-106. [pmid: 921885].
McGuirt W F Jr, Stool S E. Cerebrospinal fluid fistula: the identification and management in pediatric temporal bone fractures. Laryngoscope. 1995;105:359-364. [pmid: 7715377].
McKennan K X. Endoscopic ‘second look’ mastoidoscopy to rule out residual epitympanic/mastoid cholesteatoma. Laryngoscope. 1993;103:810-814. [pmid: 8341108].
McKenzie E, Magian V, Stokes R. A study of the recommended pass/fail criteria for impedance audiometry in a school screening program. J Otolaryngol. 1982;11:40-45. [pmid: 7200525].
McLaughlin M R, Jannetta P J, Clyde B L, Subach B R, Comey C H, Resnick D K. Microvascular decompression of cranial nerves: lessons learned after 4400 operations [see comments]. J Neurosurg. 1999;90:1-8. [pmid: 10413149].
McLay K. Options for treating otitis media. Practitioner. 1996;240:42-47. [pmid: 8746259].
McLinn S E. Recurrence of otitis media after antibiotic therapy: comparison of cephradine and amoxycillin. J Int Med Res. 1979;7:546-550. [pmid: 391628].
McLinn S E. Cefaclor in treatment of otitis media and pharyngitis in children. Am-J-Dis-Child. 1980;134:560-563. [pmid: 6770673].
McLinn S E, Goldberg F, Kramer R, Saltstein E, Bomze J P, Deitch M W. Double-blind multicenter comparison of cyclacillin and amoxicillin for the treatment of acute otitis media. J Pediatr. 1982;101:617-621. [pmid: 6750067].
McLinn S E, Serlin S. Cyclacillin versus amoxicillin as treatment for acute otitis media. Pediatrics. 1983;71:196-199. [pmid: 6337365].
McLinn S E. Randomized, open label, multicenter trial of cefixime compared with amoxicillin for treatment of acute otitis media with effusion. Pediatr Infect Dis J. 1987;6:997-1001. [pmid: 3320928].
McLinn S E, Moskal M, Goldfarb J, et al. Comparison of cefuroxime axetil and amoxicillin-clavulanate suspensions in treatment of acute otitis media with effusion in children [published erratum appears in Antimicrob Agents Chemother 1994 Oct;38(10):2516]. Antimicrob-Agents-Chemother. 1994;38:315-318. [pmcid: 284446]. [pmid: 8192458].
McLinn S E, McCarty J M, Perrotta R, et al. Multicenter controlled trial comparing ceftibuten with amoxicillin /clavulanate in the empiric treatment of acute otitis media. Pediatr Infect Dis J. 1995;14:S108-S114. [pmid: 7567310].
McLinn S E, McCarty J M, Perrotta R, Pichichero M E, Reidenberg B E. Multicenter controlled trial comparing ceftibuten with amoxicillin/clavulanate in the empiric treatment of acute otitis media. Members of the Ceftibuten Otitis Media United States Study Group. Pediatr Infect Dis J. 1995;14:S108-S114. [pmid: 7567310].
McLinn S. A multicenter, double blind comparison of azithromycin and amoxicillin/ clavulanate for the treatment of acute otitis media in children. Pediatr Infect Dis J. 1996;15:S20-S23. [pmid: 8878242].
McLinn S, Williams D. Incidence of antibiotic-resistant Streptococcus pneumoniae and beta-lactamase-positive Haemophilus influenzae in clinical isolates from patients with otitis media. Pediatr Infect Dis J. 1996;15:S3-S9. [pmid: 8878239].
McMahan J T, Calenoff E, Croft D J, Barenholtz L, Weber L D. Chronic otitis media with effusion and allergy: modified RAST analysis of 119 cases. Otolaryngol Head Neck Surg. 1981;89:427-431. [pmid: 6791105].
McMahon S R, Rimsza M E, Bay R C. Parents can dose liquid medication accurately. Pediatrics. 1997;100:330-333. [pmid: 9282701].
McMillan J A. Upper respiratory tract infections in children. Curr Opin Pediatr. 1993;5:50-54. [pmid: 8374626].
McNeill R A. Phenethicillin and penicillin G in acute suppurative otitis media in childhood. Br Med J. 1962;1:360-362. [pmid: 20789335].
McNeill R A. Ossicular reconstruction in effective ear disease. Transactions - American Academy of Ophthalmology and Otolaryngology. 1974;78:ORL264-8. [pmid: 4853500].
McNicoll W D. Otitis media with effusion in children and its association with deformity of the vomero-ethmoid suture. J Laryngol Otol. 1983;97:203-212. [pmid: 6682134].
McPherson B, Holborow C A. A study of deafness in West Africa: the Gambian Hearing Health Project. Int J Pediatr Otorhinolaryngol. 1985;10:115-135. [pmid: 4093251].
McPherson B, Smyth V, Scott J. External ear resonance as a screening technique in children with otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1993;25:81-89. [pmid: 8436483].
McPherson B, Rajender Kumar P V, Wollman D. Hearing loss in Western Samoan children. Int J Pediatr Otorhinolaryngol. 1994;29:227-234. [pmid: 8056506].
McRae D, Gatland D J, Youngs R, Cook J. Aspiration of middle ear effusions prior to grommet insertion an etiological factor in tympanosclerosis. J-Otolaryngol. 1989;18:229-231. [pmid: 2769837].
Medellin G, Roark R, Berman S. The usefulness of symptoms to identify otitis media. Arch Pediatr Adolesc Med. 1996;150:98.
Meester S G, MacKay J. A parametric model for cluster correlated categorical data. Biometrics. 1994;50:954-963. [pmid: 7787008].
Meguro H, Fujii R, Terashima I. [Clinical evaluation of a new oral penem, SY5555, in the pediatric field]. Jpn J Antibiot. 1995;48:41-48. [pmid: 7699844].
Mehta S. Silent otitis media: an autopsy study in stillborns and neonates. Ear Nose Throat J. 1990;69:296, 299-300, 311317. [pmid: 2379475].
Meis J F, Neeleman C. [Problems of resistance in Streptococcus pneumoniae]. Ned Tijdschr Geneeskd. 1996;140:141-144. [pmid: 8618633].
Meistrup L K I, Thomsen J, Mygind N, et al. Penicillin treatment of acute middle ear infections in children. How long should treatment continue?. UGESKR LAEG. 1983;145:1201-1204. [pmid: 6410565].
Meistrup-Larsen K I, Mygind N, Thomsen J, Sorensen H, Vesterhauge S. Oral norephedrine in the treatment of acute otitis media. Results of a double-blind, placebo-controlled trial. Acta-Otolaryngol-Stockh. 1978;86:248-250. [pmid: 360764].
Meistrup-Larsen K I, Mygind N, Thomsen J, et al. Oral nor-ephedrine therapy in acute otitis media. Report of a double-blind, placebo-controlled clinical trial. UGESKR LAEG. 1980;142:2773-2775. [pmid: 7003877].
Meistrup-Larsen K I, Mygind N, Thomsen J, et al. Penicillin therapy in acute otitis media. Report of a double-blind, placebo-controlled clinical trial. UGESKR LAEG. 1980;142:2768-2772. [pmid: 6777929].
Meistrup-Larsen K I, Mygind N, Thomsen J, Larsen P K, Thomsen V F, Sorensen H. [Penicillin therapy of acute otitis media. A double-blind placebo-controlled study]. Ugeskr-Laeger. 1980;142:2768-2772. [pmid: 6777929].
Meistrup-Larsen K I, Mygind N, Thomsen J, Sorensen H, Vesterhauge S. [Peroral norephedrine therapy of acute otitis media. A double-blind placebo-controlled study]. Ugeskr-Laeger. 1980;142:2733-2735.
Meistrup-Larsen K I, Andersen M S, Helweg J, Deigaard J, Peitersen E. Variations in tympanograms in children attending group-care during a one-year period. ORL J Otorhinolaryngol Relat Spec. 1981;43:153-163. [pmid: 7231929].
Meistrup-Larsen K I, Sorensen H, Johnsen N J, Thomsen J, Mygind N, Sederberg-Olsen J. Two versus seven days penicillin treatment for acute otitis media. A placebo controlled trial in children. Acta-Otolaryngol-Stockh. 1983;96:99-104. [pmid: 6412508].
Meistrup-Larsen K I, Thomsen J, Mygind N, Sorensen H, Johnsen N J, Sederberg-Olsen J. [Penicillin therapy of acute otitis media in children. How long should treatment continue?]. Ugeskr-Laeger. 1983;145:1201-1204. [pmid: 6410565].
Melchor C, Shotton J C. Should nasopharyngeal biopsy be mandatory in adult unilateral glue ear? [letter; comment]. J Laryngol Otol. 1996;110:996-997. [pmid: 8977872].
Melcon Diez E, de Diego Sastre J I. [Ossicular reconstruction in the surgery of the middle ear: comparative study]. Acta Otorrinolaringol Esp. 1994;45:229-232. [pmid: 7917471].
Melhus A, Hermansson A, Prellner K. Nontypeable and encapsulated Haemophilus influenzae yield different clinical courses of experimental otitis media. Acta Otolaryngol. 1994;114:289-294. [pmid: 8073862].
Melhus A, Hermansson A, Akkoyunlu M, Forsgren A, Prellner K. Experimental recurrent otitis media induced by Haemophilus influenzae: protection and serum antibodies. Am J Otolaryngol. 1995;16:383-390. [pmid: 8572254].
Melhus A, Hermansson A, Forsgren A, Prellner K. Effect of Haemophilus influenzae type b conjugate vaccine in combination with peroral immunization with Escherichia coli on experimental otitis media. Int J Pediatr Otorhinolaryngol. 1996;36:1-12. [pmid: 8803686].
Melhus A, Hermansson A, Forsgren A, Prellner K. A resolved pneumococcal infection protects against nontypeable Haemophilus influenzae: an evaluation of different routes of whole cell immunization in protection against experimental acute otitis media. Int J Pediatr Otorhinolaryngol. 1997;39:119-131. [pmid: 9104620].
Mellinger-Birdsong A K. Estimates of numbers of civilians treated with nasopharyngeal radium irradiation in the United States. Otolaryngol Head Neck Surg. 1996;115:429-432. [pmid: 8903442].
Meltzer E O, Orgel H A, Jalowayski A A. Histamine levels and nasal cytology in children with chronic otitis media and rhinitis. Ann Allergy Asthma Immunol. 1995;74:406-410. [pmid: 7749971].
Memmini G, Casani A, Moggi C. [An update on the treatment of otitis media with effusion in children. The indications for transtympanic drainage]. Pediatr Med Chir. 1994;16:345-348. [pmid: 7816696].
Mendelman P M, Del Beccaro M A, McLinn S E, Todd W M. Cefpodoxime proxetil compared with amoxicillin-clavulanate for the treatment of otitis media [published erratum appears in J Pediatr 1993 Mar;122(3):502] [see comments]. J Pediatr. 1992;121:459-465. [pmid: 1517926].
Mendelson T, Salamy A, Lenoir M, McKean C. Brain stem evoked potential findings in children with otitis media. Arch Otolaryngol. 1979;105:17-20. [pmid: 760701].
Menyuk P. Design factors in the assessment of language development in children with otitis media. Ann Otol Rhinol Laryngol Suppl. 1979;88:78-87. [pmid: 115365].
Menyuk P. Effect of persistent otitis media on language development. Ann Otol Rhinol Laryngol Suppl. 1980;89:257-263. [pmid: 6778321].
Merchant S N, Rosowski J J, Ravicz M E. Middle ear mechanics of type IV and type V tympanoplasty: II. Clinical analysis and surgical implications. Am J Otol. 1995;16:565-575. [pmid: 8588661].
Merchant S N, Wang P, Jang C H, et al. Efficacy of tympanomastoid surgery for control of infection in active chronic otitis media. Laryngoscope. 1997;107:872-877. [pmid: 9217122].
Merchant S N, Ravicz M E, Voss S E, Peake W T, Rosowski J J. Toynbee Memorial Lecture 1997. Middle ear mechanics in normal, diseased and reconstructed ears. J Laryngol Otol. 1998;112:715-731. [pmid: 9850313].
Merifield D O, Parker N J, Nicholson N C. Therapeutic management of chronic suppurative otitis media with otic drops. Otolaryngol Head Neck Surg. 1993;109:77-82. [pmid: 8393167].
Mertens H, Schwenk B. Diagnosis and frequency of relapse of secretory otitis media in childhood. HNO. 1988;36:507-510. [pmid: 3235365].
Meurman O H, Sarkkinen H K, Puhakka H J, Virolainen E S. Local IgA-class antibodies against respiratory viruses in middle ear and nasopharyngeal secretions of children with secretory otitis media. Laryngoscope. 1980;90:304-311. [pmid: 6243732].
Meyer S, Hugo R, Louw B, Grimbeek R J. Screening for middle-ear disease in schools for hearing-impaired children. Int J Pediatr Otorhinolaryngol. 1989;17:163-170. [pmid: 2759781].
Meyer J, Duffy L, Faden H. Effect of oral antibiotics on nasopharyngeal colonization with nontypable Haemophilus influenzae [letter]. Pediatr Infect Dis J. 1995;14:164-165. [pmid: 7746711].
Meyer zum Gottesberge A. [Dimorphism of cerumen, facts and theory]. Laryngorhinootologie. 1995;74:606-610. [pmid: 8672199].
Meyerhoff W L. Medical management of hearing loss. Postgrad Med. 1977;62:103-112. [pmid: 909843].
Meyerhoff W L. Use of tympanostomy tubes in otitis media. Ann Otol Rhinol Laryngol. 1981;90:537-542. [pmid: 7316375].
Meyerhoff W L, Truelson J. Cholesteatoma staging. Laryngoscope. 1986;96:935-939. [pmid: 3747693].
Meyerhoff WL. Bluestone et al.: Audiometry and tympanometry in relation to middle ear effusions in children.: (Laryngoscope. 1973;83;594–604). Laryngoscope. 1996;106:684–687.
Mezzedimi C, Passali G C, Bellussi L, Passali D. Late consequences of otitis media with effusion: Changes on linguistic and psycho-intellective development in children affected by this disease. Otorinolaringologia Pediatrica. 1998;9:205-210.
Michael BN, Matar S, Siegel DM. Pathologic quiz case 1. Furuncular myiasis mimicking clinical mastoiditis. Arch Otolaryngol Head Neck Surg. 1995;121:1200, 1202–1203.
Michaels L, Soucek S, Liang J. The ear in the acquired immunodeficiency syndrome: I. Temporal bone histopathologic study. Am J Otol. 1994;15:515-522. [pmid: 8588607].
Michel O. [Self-expanding ear canal tamponade]. Laryngorhinootologie. 1994;73:169. [pmid: 8172640].
Miles V H, Fischer P R. Variations in the treatment of common infections [letter]. Pediatr Infect Dis J. 1997;16:826-827. [pmid: 9271053].
Millen S J, Meyer G. Surgical management of CSF otorhinorrhea following retrosigmoid removal of cerebellopontine angle tumors. Am J Otol. 1993;14:585-589. [pmid: 8296864].
Miller W E, Holman C B, Dockerty M B, Devine K D. Roentgenologic manifestations of malignant tumors of the nasopharynx. American Journal of Roentgenology, Radium Therapy and Nuclear Medicine. 1969;106:813-823.
Miller G F. Influence of an oral decongestant on Eustachian tube function in children. J-Allergy. 1970;45:187-193. [pmid: 4907721].
Miller M H. Neonatal and infant auditory screening programs. An evaluation of their current status. Clin Pediatr. 1971;10:340-345.
Miller J, Donaldson J. Primate model for studies of clinical problems of middle ear functions. Ann Otol Rhinol Laryngol. 1976;85:194-201. [pmid: 817637].
Miller S A, Omene J A, Bluestone C D, Torkelson D W. A point prevalence of otitis media in a Nigerian village. Int J Pediatr Otorhinolaryngol. 1983;5:19-29. [pmid: 6682410].
Miller M B, Koltai P J, Hetherington S V. Bacterial antigens and neutrophil granule proteins in middle ear effusions. Arch Otolaryngol Head Neck Surg. 1990;116:335-337. [pmid: 2306352].
Miller A J, Gianoli G J. Eustachian tube dysfunction. J La State Med Soc. 1996;148:329-333. [pmid: 8855597].
Mills R, Uttley A, McIntyre M. Relationship between acute suppurative otitis media and chronic secretory otitis media: role of antibiotics. J R Soc Med. 1984;77:754-757. [pmid: 6332914]. [pmcid: 1439987].
Mills R P, Cherry J R. Subjective tinnitus in children with otological disorders. Int J Pediatr Otorhinolaryngol. 1984;7:21-27. [pmid: 6539313].
Mills R P. Persistent middle ear effusions in children with recurrent acute otitis media. Clin Otolaryngol Allied Sci. 1987;12:97-101. [pmid: 3581497].
Mills R P. Management of retraction pockets of the pars tensa. J Laryngol Otol. 1991;105:525-528. [pmid: 1875132].
Mills R P, Padgham N D. Management of childhood cholesteatoma. J Laryngol Otol. 1991;105:343-345. [pmid: 2040834].
Mills R, Vaughan-Jones R. A prospective study of otitis media with effusion in adults and children. Clin Otolaryngol Allied Sci. 1992;17:271-274. [pmid: 1505097].
Mills R P. The influence of pathological and technical variables on hearing results in ossiculoplasty. Clin Otolaryngol Allied Sci. 1993;18:202-205. [pmid: 8365009].
Mills R P, Irani B S, Vaughan-Jones R J, Padgham N D. Maxillary sinusitis in children with otitis media with effusion. J Laryngol Otol. 1994;108:842-844. [pmid: 7989829].
Mills R P, Tay H L. Findings at initial surgery for childhood otitis media with effusion and subsequent outcome. Clin Otolaryngol Allied Sci. 1995;20:461-464. [pmid: 8582081].
Mills R. The management of childhood otitis media with effusion. J R Soc Med. 1996;89:132-134. [pmid: 8683515]. [pmcid: 1295695].
Mills R. Risk factors for chronicity in childhood otitis media with effusion. Clin Otolaryngol Allied Sci. 1999;24:343-345. [pmid: 10472472].
Milner R M, Weller C R, Brenman A K. Management of the hearing impaired child with serous otitis media. Int J Pediatr Otorhinolaryngol. 1985;9:233-239. [pmid: 4055258].
Milstein S. The history of mastoid surgery. Am J Otol. 1980;1:174-178. [pmid: 7006407].
Milton C M, Cousins V C. A radiological assessment of the usefulness of Macewen's triangle as a surgical landmark. J Laryngol Otol. 1986;100:1225-1234. [pmid: 3794526].
Milvio C. Nimesulide for the treatment of painful inflammatory process in the ear, nose and throat areas: a double-blind controlled study with benzydamine. J Int Med Res. 1984;12:327-332. [pmid: 6519348].
Minami T, Kubo N, Tomoda K, Yamashita T, Kumazawa T. Regional blood flow volume in the eustachian tube. Acta Oto-Laryngologica - Supplement. 1993;500:80-83.
Minatogawa T, Kumoi T, Inamori T, Oki K, Machizuka H. Hyogo ear bank experience with allograft tympanoplasty--review of tympanoplasties on 68 ears. Am J Otol. 1990;11:157-163. [pmid: 2343898].
Minatogawa T, Machizuka H, Kumoi T. Evaluation of mastoid obliteration surgery. Am J Otol. 1995;16:99-103. [pmid: 8579186].
Minja B M, Machemba A. Prevalence of otitis media, hearing impairment and cerumen impaction among school children in rural and urban Dar es Salaam, Tanzania. Int J Pediatr Otorhinolaryngol. 1996;37:29-34. [pmid: 8884404].
Minja B M. Aetiology of deafness among children at the Buguruni school for the deaf in Dar es Salaam, Tanzania. Int J Pediatr Otorhinolaryngol. 1998;42:225-231. [pmid: 9466225].
Mink A, Bauer M. Tubomanometry. Values in ears with traumatic and chronic perforations. Clin Otolaryngol. 1993;18:291-293. [pmid: 8877188].
Mironov AA. [An optimized variant of plastic repair in a total-cavity rehabilitative hearing-preserving operation on the middle ear]. Vestn Otorinolaringol. 1994:16–22.
Misbah S A, Griffiths H, Mitchell T, Freeland A, Haeney M R, Chapel H M. Antipolysaccharide antibodies in 450 children with otitis media. Clin Exp Immunol. 1997;109:67-72. [pmid: 9218826]. [pmcid: 1904702].
Mitchell D B, Ford G R, Albert D, Waldron J. Acoustic reflectometry as an aid to the diagnosis of glue ear. Br J Clin Pract. 1990;44:557-559. [pmid: 2102142].
Mitchell D K, Van R, Mason E H, Norris D M, Pickering L K. Prospective study of toxigenic Clostridium difficile in children given amoxicillin/clavulanate for otitis media. Pediatr Infect Dis J. 1996;15:514-519. [pmid: 8783348].
Mitrovic M, Haralampiev K, Dzinic M. Problems in diagnosis and treatment of cholesteatoma in children. Int J Pediatr Otorhinolaryngol. 1991;21:149-153. [pmid: 1889952].
Miura M, Takahashi H, Honjo I, Hasebe S, Tanabe M. Influence of the gas exchange function through the middle ear mucosa on the development of sniff-induced middle ear diseases. Laryngoscope. 1998;108:683-686. [pmid: 9591546].
Miyake H, Tanabe H, Tanahashi T, Ishigami H. Studies on mastoidplasty using autogenous bonemarrow and free skingraft. Nagoya J Med Sci. 1967;30:23-36. [pmid: 4864341].
Mizukami C, Yamamoto E. Endolymphatic hydrops and otitis media. Equilibrium Research. 1988;47:101-103.
Moar J J. Drowning--postmortem appearances and forensic significance. A case report. S Afr Med J. 1983;64:792-795. [pmid: 6635869].
Modai J. The clinical use of macrolides. J Antimicrob Chemother. 1988;22:145-153. [pmid: 3053568].
Mody M, Schwartz RG, Gravel JS, Wallace IF, Ellis MA, Lee WW. Speech perception and verbal memory in children with otitis media. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:339–342.
Mody M, Schwartz R G, Gravel J S, Ruben R J. Speech perception and verbal memory in children with and without histories of otitis media. Journal of Speech, Language, and Hearing Research. 1999;42:1069-1079.
Moerman M, Dierick J, Mestdagh J, Boedts D, Van Cauwenberge P. Mastoiditis caused by atypical mycobacteria. Int J Pediatr Otorhinolaryngol. 1993;28:69-76. [pmid: 8300316].
Moffat D A, da Cruz M J, Batten A, Hardy D G. Use of autologous osteocyte containing bone pate for closure of tegmental defects. Am J Otol. 1998;19:819-823. [pmid: 9831161].
Mogi G, Maeda S, Yoshida T, Watanabe N. Radioimmunoassay of IgE in middle ear effusions. Acta Otolaryngol. 1976;82:26-32. [pmid: 948982].
Mogi G, Maeda S, Yoshida T, Watanabe N. Otitis media with effusion: specific antibody activities against exotoxins in middle ear effusions. Laryngoscope. 1976;86:1043-1055. [pmid: 933685].
Mogi G. [Paranasal sinuses, middle ear, and allergy]. Arerugi - Japanese Journal of Allergology. 1995;44:1355-1360.
Moher D, Pham B, Klassen T P, Schulz K F, Berlin J A, Jadad A R, Liberati A. What contributions do languages other than English make on the results of meta-analyses?. J Clinical Epi. 2000;53:964-72.
Mohs E, Rodriguez-Solares A, Rivas E, el Hoshy Z. A comparative study of azithromycin and amoxycillin in paediatric patients with acute otitis media. J-Antimicrob-Chemother. 1993:73–79.
Moissenet D, Guet L, Valcin M, et al. [Molecular epidemiology of pneumococci with decreased susceptibility to penicillin isolated in a Parisian pediatric hospital]. Pathol Biol. 1996;44:423-429. [pmid: 8758488].
Mokry C. Otitis media in children [letter]. N Engl J Med. 1995;333:1151; discussion 1152.
Mol JG, Appelman CLM, Hordijk GJ, de Melker RA, Touw-Otten FWMM, Leppink GJ. Double Blind Randomized Clinical Trial on the Effect of Different Treatments in Recurrent Acute Otitis Media. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:226–227.
Molina Jimenez F J, Foguet Vidal A, Perez Alvarez F, Castillo Salinas F, Macia Marti J. [Conservative treatment of brain abscess in pediatrics: two case reports]. An Esp Pediatr. 1993;39:539-541. [pmid: 8166412].
Moller P. Negative middle ear pressure and hearing thresholds in secretory otitis media. A double-blind crossover study with Lunerin. Scand-Audiol. 1980;9:171-176. [pmid: 7003687].
Moller P. Tympanosclerosis of the ear drum in secretory otitis media. Acta Oto-Laryngologica - Supplement. 1984;414:171-177.
Moller P, Dingsor G. Otitis media with effusion: can erythromycin reduce the need for ventilating tubes?. J Laryngol Otol. 1990;104:200-202. [pmid: 2341774].
Moller H, Tos M. Point and period prevalence of otitis media with effusion evaluated by daily tympanometry. J Laryngol Otol. 1990;104:937-941. [pmid: 2280145].
Moller H, Tos M. Daily impedance audiometric screening of children. Validity of impedance tympanoscope ZS331 compared with impedance audiometer AZ7. Scand Audiol. 1992;21:9-14. [pmid: 1585133].
Molougney B, Ruthnum P, Chan E. Case reports: invasive Haemophilus influenzae type a infections. Can Commun Dis Rep. 1997;23:82-84. [pmid: 9190089].
Monsell E M, Harley R E. Eustachian tube dysfunction. Otolaryngol Clin North Am. 1996;29:437-444. [pmid: 8743342].
Montalt J, Barona R, Armengot M, Basterra J. [Secretory middle ear otitis with severe sensorineural deafness]. An Otorrinolaringol Ibero Am. 1997;24:27-37. [pmid: 9199099].
Montandon P, Benchaou M, Guyot J P. Modified canal wall-up mastoidectomy with mastoid obliteration for severe chronic otitis media. ORL J Otorhinolaryngol Relat Spec. 1995;57:198-201. [pmid: 7478453].
Montgomery W W. Surgery for acoustic neurinomas: a proposal. Ann Otol Rhinol Laryngol Suppl. 1984;112:59-62. [pmid: 6431883].
Moody S A, Alper C M, Doyle W J. Daily tympanometry in children during the cold season: association of otitis media with upper respiratory tract infections. Int J Pediatr Otorhinolaryngol. 1998;45:143-150. [pmid: 9849682].
Moon C N Jr, Hahn M. Pneumatic otoscopy and impedance studies in middle ear diagnosis. Laryngoscope. 1978;88:1439-1448. [pmid: 682800].
Moore D C, Best G F. A sensorineural component in chronic otitis media. Laryngoscope. 1980;90:1360-1366. [pmid: 7401838].
Moore D R, Hutchings M E, Meyer S E. Binaural masking level differences in children with a history of otitis media. Audiology. 1991;30:91-101. [pmid: 1877902].
Moore D R, Lippe W R, Rubel E W. Effects of middle ear pressure on frequency representation in the central auditory system. Hear Res. 1995;89:93-100. [pmid: 8600136].
Moran D M, Mutchie K D, Higbee M D, Paul L D. The use of an antihistamine-decongestant in conjunction with an anti-infective drug in the treatment of acute otitis media. J Pediatr. 1982;101:132-136. [pmid: 6177846].
Moran D M, Mutchie K D, Higbee M D, Paul L D. Use of an antihistamine-decongestant in conjunction with an anti-infective drug in the treatment of acute otitis media. J Pediatr. 1982;101:132-136. [pmid: 6177846].
Moran D G. A multicentre general practice study comparing pivampicillin (Pondocillin) and amoxycillin (Amoxil) in respiratory tract infections. J Int Med Res. 1983;11:370-374. [pmid: 6360752].
Morgan D W, Shenoi P M. Swimming in chlorinated water and its effect on Eustachian tube function. J Laryngol Otol. 1989;103:257-258. [pmid: 2703763].
Morgenstern N, Jones-Crymes B. Analysis of tympanometry of a severe to profound hearing-impaired population of school-age children. J Speech Hear Disord. 1979;44:230-235. [pmid: 502489].
Morimitsu T, Tono T, Makino K, Miyanaga S, Ushisako Y. Improvement of the surgical technique of anterior tympanoplasty in cholesteatoma. Rev Laryngol Otol Rhinol. 1995;116:369-371.
Morinaka S. Allergic otitis media with gelatinous mucoid fluid containing eosinophils. Otolaryngol Head Neck Surg. 1996;114:665-668. [pmid: 8643285].
Morita T, Muraki Y, Awakura T, Shimada A, Umemura T. Detection of Mycoplasma hyorhinis in porcine eustachitis. J Vet Med Sci. 1993;55:475-477. [pmid: 8357925].
Morita M, Matsunaga T. Sonotubometry with a tubal catheter as an index for the use of a ventilation tube in otitis media with effusion. Acta Oto-Laryngologica - Supplement. 1993;501:59-62.
Morita T, Fukuda H, Awakura T, et al. Demonstration of Mycoplasma hyorhinis as a possible primary pathogen for porcine otitis media. Vet Pathol. 1995;32:107-111. [pmid: 7771049].
Morita M, Harada T, Kubo T. Tubal function in otitis media with effusion and treatment with roxithromycin. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:213–215.
Morizono T, Giebink G S, Paparella M M, Sikora M A, Shea D. Sensorineural hearing loss in experimental purulent otitis media due to Streptococcus pneumoniae. Arch Otolaryngol. 1985;111:794-798. [pmid: 4062650].
Morris M S. Otitis media [letter; comment]. Arch Otolaryngol Head Neck Surg. 1995;121:1434-1436. [pmid: 7488379].
Morrison A W. Phenethicillin and benzylpenicillin in acute otitis media. Br Med J. 1961;2:8-11. [pmid: 13772875].
Morrison A W. The preoperative value of tympanometry. Acta Otorhinolaryngol Belg. 1974;28:442-449. [pmid: 4440474].
Morrongiello B A. Infants' monaural localization of sounds: effects of unilateral ear infection. J Acoust Soc Am. 1989;86:597-602. [pmid: 2768674].
Mortensen J E. Streptococcus pneumoniae, otitis media and antimicrobial breakpoints [letter; comment]. Pediatr Infect Dis J. 1997;16:537. [pmid: 9154560].
Morton R P, Woollons A C, McIvor N P. Nasopharyngeal carcinoma and middle ear effusion: natural history and the effect of ventilation tubes. Clin Otolaryngol Allied Sci. 1994;19:529-531. [pmid: 7895386].
Mosca F, Gagliardi P. Impedance audiometry in the follow-up of secretory otitis media. Quaderni di Medicina e Chirurgia. 1994;10:233-235.
Mostafa B E. Detection of adenoidal hypertrophy using acoustic rhinomanometry. Eur Arch Otorhinolaryngol Suppl. 1997;1:S27-S29.
Motohashi H, Kobayashi T, Toshima M, et al. A seven-year school screening for secretory otitis media. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:54–57.
Motohiro T, Sakata Y, Fujimoto T, et al. [Absorption, excretion and clinical trials of cefroxadine in the field of pediatrics (author's transl)]. Jpn-J-Antibiot. 1981;34:1703-1731. [pmid: 7038189].
Motohiro T, Tanaka K, Koga T, et al. [Fundamental and clinical studies of sulbactam/cefoperazone in the pediatric field]. Jpn-J-Antibiot. 1984;37:1898-1918. [pmid: 6094868].
Motohiro T, Aramaki M, Oda K, et al. [Pharmacokinetic and clinical studies on cefprozil granules in the pediatric field]. Jpn-J-Antibiot. 1992;45:1700-1735. [pmid: 1289589].
Motohiro T, Handa S, Yamada S, et al. [Pharmacokinetics and clinical effects of cefdinir 10% fine granules in pediatrics]. Jpn-J-Antibiot. 1992;45:74-86. [pmid: 1495197].
Moustafa H M, Khalifa M A. Tympano-cartilago-stapediopexy: a method to improve hearing in open technique tympanoplasty. J Laryngol Otol. 1990;104:942-944. [pmid: 2280146].
Moxham J, Wiles C M, Newham D, Edwards R H. Sternomastoid muscle function and fatigue in man. Clin Sci. 1980;59:463-468. [pmid: 7438710].
Muchnik C, Neeman R K, Hildesheimer M. Auditory brainstem response to bone-conducted clicks in adults and infants with normal hearing and conductive hearing loss. Scand Audiol. 1995;24:185-191. [pmid: 8552978].
Muenker G. Results after Treatment of Otitis Media with Effusion. Proceedings of the Second International Symposium: Recent Advances in Otitis Media with Effusion; 1980:308–311.
Muffat-Joly M, Barry B, Henin D, Fay M, Gehanno P, Pocidalo J J. Otogenic meningoencephalitis induced by Streptococcus pneumoniae in gerbils. Arch Otolaryngol Head Neck Surg. 1994;120:925-930. [pmid: 8074819].
Muhaimeid H, Zakzouk S, Bafaqeeh S. Epidemiology of chronic suppurative otitis media in Saudi children. Int J Pediatr Otorhinolaryngol. 1993;26:101-108. [pmid: 8444552].
Mukherjee D, Stephens D. Otitis media with effusion in intellectually disabled children. J Audiological Med. 1997;6:10-23.
Mukherji S K, Mancuso A A, Kotzur I M, et al. CT of the temporal bone: findings after mastoidectomy, ossicular reconstruction, and cochlear implantation. AJR. American Journal of Roentgenology. 1994;163:1467-1471. [pmid: 7992748].
Muller O. Comparison of azithromycin versus clarithromycin in the treatment of patients with upper respiratory tract infections. J-Antimicrob-Chemother. 1993:137–146.
Muller O. An open comparative study of azithromycin and roxithromycin in the treatment of acute upper respiratory tract infections. J Antimicrob Chemother. 1996;37:83-92. [pmid: 8818849].
Mumtaz M A, Schwartz R H, Grundfast K M, Baumgartner R C. Tuberculosis of the middle ear and mastoid. Pediatr Infect Dis. 1983;2:234-236. [pmid: 6866787].
Munker G, Tratzmuller A. Is there a drug therapy for secretory otitis media?. Laryngo Rhino Otologie. 1989;68:647-652. [pmid: 2575386].
Munro K J, Benton C L, Marchbanks R J. Sonotubometry findings in children at high risk from middle ear effusion. Clin Otolaryngol Allied Sci. 1999;24:223-227. [pmid: 10384850].
Muntz H R. An overview of middle ear disease in cleft palate children. Facial Plastic Surgery. 1993;9:177-180. [pmid: 8270210].
Muntz H R. The use of silly putty as an ear plug [letter]. Arch Otolaryngol Head Neck Surg. 1995;121:354. [pmid: 7873157].
Murakami T, Tsubaki J, Tahara Y, Nagashima T. Gradenigo's syndrome: CT and MRI findings. Pediatr Radiol. 1996;26:684-685. [pmid: 8781114].
Murph J R, Dusdieker L B, Booth B, Murph W E. Is treatment of acute otitis media with once-a-day amoxicillin feasible? Results of a pilot study [see comments]. Clin-Pediatr-Phila. 1993;32:528-534. [pmid: 8258205].
Murphy K W. Deafness after topical neomycin. Br Med J. 1970;2:114. [pmid: 5420228].
Murphy T P, Wallis D L. Hearing results in pediatric patients after canal-wall-up and canal-wall-down mastoid surgery. Otolaryngol Head Neck Surg. 1998;119:439-443. [pmid: 9807066].
Murray A B, Anderson D O, Cambon K G, Moghadam H K, Robinson G C. A survey of hearing loss in Vancouver school children. II. The association between secretory otitis media and enlarged adenoids, infection and nasal allergy. Cmaj. 1968;98:995-1001. [pmid: 5653667]. [pmcid: 1924161].
Mustain W D. Linguistic and educational implications of recurrent otitis media. Ear Nose Throat J. 1979;58:218-222. [pmid: 456302].
Mutlu C, Odabasi A O, Metin K, Basak S, Erpek G. Sensorineural hearing loss associated with otitis media with effusion in children. Int J Pediatr Otorhinolaryngol. 1998;46:179-184. [pmid: 10190588].
Myer C Md, Farrer S M, Drake A F, Cotton R T. Perilymphatic fistulas in children: rationale for therapy. Ear Hear. 1989;10:112-116. [pmid: 2707501].
Myer C M 3rd, France A. Ventilation tube placement in a managed care population. Arch Otolaryngol Head Neck Surg. 1997;123:226-228. [pmid: 9046295].
Myers E N, Donaldson W F. Editorial fairness and the “Cantekin affair” [see comments]. Pediatr Infect Dis J. 1993;12:265-267. [pmid: 8483618].
Mygind N, Meistrup-Larsen K I, Thomsen J, Thomsen V F, Josefsson K, Sorensen H. Penicillin in acute otitis media: a double-blind placebo-controlled trial. Clin-Otolaryngol. 1981;6:5-13. [pmid: 6791864].
Mygind N, Pedersen M. Nose-, sinus- and ear-symptoms in 27 patients with primary ciliary dyskinesia. Eur J Respir Dis - Supplement. 1983;127:96-101.
Mylanus E A, Snik A F, Cremers C W. Influence of the thickness of the skin and subcutaneous tissue covering the mastoid on bone-conduction thresholds obtained transcutaneously versus percutaneously. Scand Audiol. 1994;23:201-203. [pmid: 7997838].
Mšssinger P. Zur Behandlung der Otitis media mit Pulsatilla. Der Kinderarzt. 1985;16.
Naclerio R, Neely J G, Alford B R. A retrospective analysis of the intact canal wall tympanoplasty with mastoidectomy. Am J Otol. 1981;2:315-317. [pmid: 7258325].
Nadel D M, Silverstein H, Olds M J. A new prosthesis for reconstructing the incudostapedial joint. Am J Otol. 1997;18:540-543. [pmid: 9303148].
Nadkarni T D, Bhayani R, Goel A, Karapurkar A P. Bilateral otogenic cerebellar abscesses. J Postgrad Med. 1993;39:38-39. [pmid: 8295147].
Nadol J B Jr, Eavey R D. Acute and chronic mastoiditis: clinical presentation, diagnosis, and management. Curr Clin Top Infect Dis. 1995;15:204-229. [pmid: 7546369].
Nagorsky M J. Radiation injury of the temporal bone. Clin Plast Surg. 1993;20:531-534. [pmid: 8324991].
Naguib M B, Hunter R E, Henley C M. Cochlear polyamines: markers of otitis media-induced cochlear damage [published erratum appears in Laryngoscope 1995 Mar;105(3 Pt 1):329]. Laryngoscope. 1994;104:1003-1007. [pmid: 8052063].
Nahata M C, Koranyi K I, Luke D R, Foulds G. Pharmacokinetics of azithromycin in pediatric patients with acute otitis media. Antimicrob Agents Chemother. 1995;39:1875-1877. [pmcid: 162845]. [pmid: 7486938].
Naidich T P. “How I do it”--otology and neurotology. A specific issue and its solution. Air CT canalography for the evaluation of the internal auditory canals. Laryngoscope. 1980;90:526-530. [pmid: 6965750].
Naito T, Nakajima R, Nakamura T. Meatotympanoplasty with special reference to the postoperative hearing. Acta Otolaryngol. 1969;67:471-482. [pmid: 5378594].
Nakamura H, Miyazu M, Kasai K, Iwai N, Taneda Y. Studies on sultamicillin in the field of pediatrics. Jpn J Antibiot. 1988;41:1874-1894. [pmid: 3249361].
Namyslowski G, Czecior E, Orecka B, Glowacki J. [Otogenic sigmoid sinus thrombosis in the course of chronic otitis media]. Otolaryngol Pol. 1995;49:451-456.
Namyslowski G, Misiolek M. [Use of tarflen ventilation tubes in treatment of secretory otitis media in children]. Pediatr Pol. 1995;70:657-660. [pmid: 8668367].
Namyslowski G, Misiolek M, Kubik P, Orecka B. [Clinical analysis of indications to ventilation tube removal in otitis media with effusion]. Otolaryngol Pol. 1995;49:209-213. [pmid: 7566990].
Nanjyo S, Suga A. [Comparative study of clinical effects of cephalexin and aminobenzyl penicillin on acute suppurative inflammation of the middle ear by double blind test]. Jibiinkoka. 1970;42:719-724. [pmid: 4917278].
Narcy P, Bobin S, Manach Y. Sero-mucoid otitis media in children. Annales de Pediatrie. 1984;31:939-943. [pmid: 6543106].
Naremore R C. Influences of hearing impairment on early language development. Ann Otol Rhinol Laryngol Suppl. 1979;88:54-63. [pmid: 115363].
Narkio-Makela M, Jerop J, Meri S. Complement activation and expression of membrane regulators in the middle ear mucosa in otitis media with effusion. Clin Exp Immunol. 1999;116:401-409. [pmid: 10361226]. [pmcid: 1905301].
Nassar W Y, Allen B M. A double-blind comparative clinical trial of cephalexin and ampicillin in the treatment of childhood acute otitis media. Curr-Med-Res-Opin. 1974;2:198-203. [pmid: 4841306].
Nassif P S, Simpson S Q, Izzo A A, Nicklaus P J. Interleukin-8 concentration predicts the neutrophil count in middle ear effusion. Laryngoscope. 1997;107:1223-1227. [pmid: 9292607].
Nastasi K J, Blaiss M S. A seven-year-old boy with sinusitis, otitis media, and asthma [clinical conference]. Annals of Allergy. 1994;73:15-20. [pmid: 8030798].
Nathoo N, Nadvi S, van der Merwe R. Spontaneous drainage of an infratentorial extradural empyema: case report. Br J Neurosurg. 1997;11:75-77. [pmid: 9156024].
Naunton R F. Tympanostomy tubes: the conservative approach. Ann Otol Rhinol Laryngol. 1981;90:529-532. [pmid: 6119055].
Nayak A K, Karnad D, Mahajan M V, Shah A, Meisheri Y V. Cerebellar venous infarction in chronic suppurative otitis media. A case report with review of four other cases. Stroke. 1994;25:1058-1060. [pmid: 8165678].
Ndip R N, Obi M C, Obi C L, Nwawolo C, Igumbor E O, Obi A A. Antibiogram of bacterial isolates from cases of otitis media and lower respiratory tract infections. Afr J Med Med Sci. 1995;24:353-357. [pmid: 8886150].
Needleman H. Effects of hearing loss from early recurrent otitis media on speech and language development. In: BF J, ed. Hearing loss in children: A comprehensive text. Baltimore: University Park Press; 1972:640–649.
Needleman H. Effects of hearing loss from early recurrent otitis media on speech and language development. In: B J, ed. Hearing Loss in Children. Baltimore: University Park Press; 1977:640–649.
Neel H B 3rd, McDonald T J. Symposium. ENT for nonspecialists. Common otologic symptoms. Postgrad Med. 1975;57:59-63. [pmid: 1124256].
Neel H Bd, Keating L W, McDonald T J. Ventilation in secretory otitis media: effects on middle ear volume and eustachian tube function. Arch Otolaryngol. 1977;103:228-231. [pmid: 849200].
Neely J G. Classification of spontaneous cerebrospinal fluid middle ear effusion: review of forty-nine cases. Otolaryngol Head Neck Surg. 1985;93:625-634. [pmid: 3932931].
Neely J G, Kuhn J R. Diagnosis and treatment of iatrogenic cerebrospinal fluid leak and brain herniation during or following mastoidectomy. Laryngoscope. 1985;95:1299-1300. [pmid: 4058205].
Neff P A, Cantrell R W. Assessment by audiotympanometric testing: three case reports. Laryngoscope. 1977;87:1052-1065. [pmid: 875566].
Neil J F, Harrison S H, Morbey R D, Robinson G A, Tate G M, Tate H T. Deafness in acute otitis media. Br Med J. 1966;5479:75-77. [pmid: 4955162].
Nelson J D, Ginsburg C M, Mcleland O, Clahsen J, Culbertson M C J, Carder H. Concentrations of antimicrobial agents in middle ear fluid, saliva and tears. Int J Pediatr Otorhinolaryngol. 1981;3:327-334. [pmid: 6799415].
Nelson S M, Berry R I. Ear disease and hearing loss among Navajo children--a mass survey. Laryngoscope. 1984;94:316-323. [pmid: 6700346].
Nelson JD, McCracken GH, Jr. The perils of persistent effusion. Pediatr Infect Dis J. 1990;9.
Nelson C T, Mason E O Jr, Kaplan S L. Activity of oral antibiotics in middle ear and sinus infections caused by penicillin-resistant Streptococcus pneumoniae: implications for treatment. Pediatr Infect Dis J. 1994;13:585-589. [pmid: 7970944].
Nemzek W R, Brodie H A, Chong B W, et al. Imaging findings of the developing temporal bone in fetal specimens. Ajnr: American Journal of Neuroradiology. 1996;17:1467-1477. [pmid: 8883642].
Neustrom M R. Immunologic evaluation of the child with recurrent otitis media [letter]. Ear Nose Throat J. 1997;76:584. [pmid: 9282468].
Newberg L B, Ling V, Shamsuddin A M. Microscopic analysis of the mastoid bone in chronic serous otitis media. Laryngoscope. 1985;95:921-923. [pmid: 4040595].
Newton A P. The follow up of acute otitis media in general practice. J R Nav Med Serv. 1995;81:127-134. [pmid: 7500314].
Newton V E, Liu X, Ke X, Xu L, Bamford J M. Evaluation of the use of a questionnaire to detect hearing loss in babies in China. Int J Pediatr Otorhinolaryngol. 1999;48:125-129. [pmid: 10375037].
Ng P C, Hiu J, Fok T F, Nelson E A, Cheung K L, Wong W. Isolated congenital tuberculosis otitis in a preterm infant. Acta Paediatr. 1995;84:955-956. [pmid: 7488829].
Nguyen H D, Simonson T M, Fisher D J, et al. MR evaluation of acoustic schwannoma with fractional contrast doses. J Comput Assist Tomogr. 1995;19:23-27. [pmid: 7822543].
Nicklaus P, Dutcher P O, Kido D K, Hengerer A S, Nelson C N. New imaging techniques in diagnosis of cerebrospinal fluid fistula. Laryngoscope. 1988;98:1065-1068. [pmid: 3172952].
Niebuhr-Jorgensen M. Autoinflation as a treatment of otitis media in children younger than three years. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:212–213.
Niederman. Proceedings of the Fourth International Symposium of Recent Advances in Otitis Media. 1988:273–275.
Nield L S. Index of suspicion. Case 1. Diagnosis: Balance disturbance secondary to middle ear effusion. Pediatr Rev. 1994;15:369-370. [pmid: 7971596].
Nielsen K O, Bak-Pedersen K. Otosurgery of incipient adhesive otitis media in children. J Laryngol Otol. 1984;98:341-345. [pmid: 6715966].
Niemela M, Uhari M, Jounio-Ervasti K, Luotonen J, Alho O P, Vierimaa E. Lack of specific symptomatology in children with acute otitis media. Pediatr Infect Dis J. 1994;13:765-768. [pmid: 7808842].
Niemela M, Uhari M, Hannuksela A. Pacifiers and dental structure as risk factors for otitis media. Int J Pediatr Otorhinolaryngol. 1994;29:121-127. [pmid: 8056494].
Niemela M, Uhari M, Lautala P, Huggare J. Association of recurrent acute otitis media with nasopharynx dimensions in children. J Laryngol Otol. 1994;108:299-302. [pmid: 8182313].
Niemela M, Uhari M, Mottonen M. A pacifier increases the risk of recurrent acute otitis media in children in day care centers. Pediatrics. 1995;96:884-888. [pmid: 7478830].
Nieminen T, Virolainen A, Kayhty H, et al. Antibody-secreting cells and their relation to humoral antibodies in serum and in nasopharyngeal aspirates in children with pneumococcal acute otitis media. J Infect Dis. 1996;173:136-141. [pmid: 8537650].
Nienhuys T, Westwater A, Dillon H, McConnel F. Developmental and educational effects of conductive hearing loss among Australian aboriginal children and implications for educational management. Arctic Med Res. 1991;Suppl:642-645. [pmid: 1365249].
Nienhuys T, Sherwood J, Bush J. Hearing loss in a sample of central Sydney Aboriginal schoolchildren. Australian Journal of Audiology. 1991;13:13-19.
Nienhuys T G, Boswell J B, McConnel F B. Middle ear measures as predictors of hearing loss in Australian aboriginal schoolchildren. Int J Pediatr Otorhinolaryngol. 1994;30:15-27. [pmid: 8045691].
Niezgoda J A, Cianci P, Folden B W, Ortega R L, Slade J B, Storrow A B. The effect of hyperbaric oxygen therapy on a burn wound model in human volunteers. Plast-Reconstr-Surg. 1997;99:1620-1625. [pmid: 9145132].
Nigam A, Samuel P R. Hyperacusis and Williams syndrome. J Laryngol Otol. 1994;108:494-496. [pmid: 8027650].
Nikolaou A, Bourikas Z, Maltas V, Aidonis A. Ossiculoplasty with the use of autografts and synthetic prosthetic materials: a comparison of results in 165 cases. J Laryngol Otol. 1992;106:692-694. [pmid: 1328434].
Nilson B W, Poland R L, Thompson R S, Morehead D, Baghdassarian A, Carver D H. Acute otitis media: treatment results in relation to bacterial etiology. Pediatrics. 1969;43:351-358. [pmid: 4975539].
Niparko J K, Kemink J L, Graham M D, Kartush J M. Bioactive glass ceramic in ossicular reconstruction: a preliminary report. Laryngoscope. 1988;98:822-825. [pmid: 3398655].
Nishimura R, Baba Y, Murakami R, et al. MR evaluation of radiation otomastoiditis. Int J Radiat Oncol Biol Phys. 1997;39:155-160. [pmid: 9300750].
Nishioka K, Masuda Y, Okada S, Takata N, Tasaka S, Ogura Y. Bilateral sensorineural hearing loss associated with Mycoplasma pneumoniae infection. Laryngoscope. 1987;97:1203-1206. [pmid: 3657368].
Nishioka Sd A. Risk factors for acute otitis media [letter; comment]. Clin Infect Dis. 1997;24:283-284. [pmid: 9114173].
Nissen AJ, Bui H. Complications of chronic otitis media. Ear Nose Throat J. 1996;75.
Nissinen A, Gronroos P, Huovinen P, et al. Development of beta-lactamase-mediated resistance to penicillin in middle-ear isolates of Moraxella catarrhalis in Finnish children, 1978-1993. Clin Infect Dis. 1995;21:1193-1196. [pmid: 8589142].
Nissinen A, Leinonen M, Huovinen P, et al. Antimicrobial resistance of Streptococcus pneumoniae in Finland, 1987-1990. Clin Infect Dis. 1995;20:1275-1280. [pmid: 7620010].
Nittrouer S. The relation between speech perception and phonemic awareness: evidence from low-SES children and children with chronic OM. J Speech Hear Res. 1996;39:1059-1070. [pmid: 8898258].
Nizet V, Colina K F, Almquist J R, Rubens C E, Smith A L. A virulent nonencapsulated Haemophilus influenzae. J Infect Dis. 1996;173:180-186. [pmid: 8537657].
Noguera J T, Haase F R. Tympanoplasty. Results at twelve and twenty-four months. Journal of the Medical Society of New Jersey. 1969;66:507-509. [pmid: 5258063].
Noordzij J P, Dodson E E, Ruth R A, Arts H A, Lambert P R. Chronic otitis media and sensorineural hearing loss: is there a clinically significant relation?. Am J Otol. 1995;16:420-423. [pmid: 8588640].
Northern J L. Advanced techniques for measuring middle ear function. Pediatrics. 1978;61:761-767. [pmid: 662517].
Northern J L. Impedance screening. An integral part of hearing screening. Ann Otol Rhinol Laryngol Suppl. 1980;89:233-235. [pmid: 6778314].
Northern JL, Downs MP. Hearing in children. Baltimore: Williams & Wilkins; 1991.
Novak J. To pathogenesis of subjective tinnitus aurium in adhesive middle-ear processes. Sbornik Vedeckych Praci Lekarske Fakulty Karlovy Univerzity V Hradci Kralove. 1969;12:141-147.
Novick K K. Talking with toddlers. Psychoanal Study Child. 1986;41:277-286. [pmid: 3823274].
Nowak-Sadzikowska J, Heczko P B. [Moraxella catarrhalis as an important etiologic factor in infection of the lower bronchial tree]. Pneumonol Alergol Pol. 1994;62:530-532. [pmid: 7866327].
Nozza RJ. Auditory Deficit in Infants with Otitis Media with Effusion: More Than a “Mild” Hearing Loss. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:376–379.
Nozza R J. Audiologic considerations: Beyond the threshold. Ann Otol Rhinol Laryngol. 1990;99:34-36.
Nozza R J, Bluestone C D, Kardatzke D, Bachman R. Towards the validation of aural acoustic immittance measures for diagnosis of middle ear effusion in children. Ear Hear. 1992;13:442-453. [pmid: 1487106].
Nozza R J, Bluestone C D, Kardatzke D, Bachman R. Identification of middle ear effusion by aural acoustic admittance and otoscopy. Ear Hear. 1994;15:310-323. [pmid: 7958530].
Nozza R J. The effects of mild hearing loss on infant auditory function. Infant-Toddler Intervention. 1994;4:285-298.
Nozza R J. Critical issues in acoustic-immittance screening for middle ear effusion. Semin Hear. 1995;16:89-98.
Nozza RJ. The Assessment of Hearing and Middle-Ear Function in Children. In: Bluestone CD, Stool SE, and Kenna MA, editors. Pediatric otolaryngology. Philadelphia: W.B. Saunders Company. 1996. p. 165–206.
Nozza R J, Sabo D L, Mandel E M. A role for otoacoustic emissions in screening for hearing impairment and middle ear disorders in school-age children. Ear Hear. 1997;18:227-239. [pmid: 9201458].
Nsouli T M, Nsouli S M, Linde R E, O'Mara F, Scanlon R T, Bellanti J A. Role of food allergy in serous otitis media [see comments]. Annals of Allergy. 1994;73:215-219. [pmid: 8092554].
Nunez D A. Otitis media [letter; comment]. J R Soc Med. 1993;86:120. [pmid: 8433303].
Nunn D R, Derkay C S, Darrow D H, Magee W, Strasnick B. The effect of very early cleft palate closure on the need for ventilation tubes in the first years of life. Laryngoscope. 1995;105:905-908. [pmid: 7666722].
Nurbaev M. [Chronic purulent otitis media complicated with cholesteatoma, fistula and polyp of the external ear canal]. Vestn Otorinolaringol. 1993:47.
Nuutinen J, Karja J, Karjalainen P. Measurement of mucociliary function of the eustachian tube. Arch Otolaryngol. 1983;109:669-672. [pmid: 6225412].
Nuutinen J, Torkkeli T, Penttila I. The pH of secretions in sinusitis and otitis media. J Otolaryngol. 1993;22:79-82. [pmid: 8515521].
Nylen O, Alestig K, Fasth A, et al. Infections of the ear with nontuberculous mycobacteria in three children. Pediatr Infect Dis J. 1994;13:653-656. [pmid: 7970956].
O'Brien K L, Steinhoff M C, Edwards K, Keyserling H, Thoms M L, Madore D. Immunologic priming of young children by pneumococcal glycoprotein conjugate, but not polysaccharide, vaccines. Pediatr Infect Dis J. 1996;15:425-430. [pmid: 8724065].
O'Brien D M. Cases from the aerospace medicine resident's teaching file :65. Complicated diagnosis of left ear pain and facial weakness in an aviator [clinical conference]. Aviat Space Environ Med. 1996;67:787-789. [pmid: 8853838].
O'Connor A F, Moffat D A. Otogenic intracranial hypertension. Otitic hydrocephalus. J Laryngol Otol. 1978;92:767-775. [pmid: 701978].
O'Connor R D, Ort H, Leong A B, Cook D A, Street D, Hamburger R N. Tympanometric changes following nasal antigen challenge in children with allergic rhinitis. Annals of Allergy. 1984;53:468-471. [pmid: 6542329].
O'Doherty B. An open comparative study of azithromycin versus cefaclor in the treatment of patients with upper respiratory tract infections. J-Antimicrob-Chemother. 1996:71–81.
O'Neill J V, Katz A H, Skolnik E M. Otologic complications of radiation therapy. Otolaryngology and Head and Neck Surgery. 1979;87:359-363. [pmid: 492710].
O'Reilly M F. Functional analysis of episodic self-injury correlated with recurrent otitis media. J Appl Behav Anal. 1997;30:165-167. [pmid: 9103992]. [pmcid: 1284030].
O'shea J S, Langenbrunner D J, McCloskey D E, Pezzullo J C, Regan J B. Diagnostic and therapeutic studies in childhood serous otitis media. Results of treatment with an antihistamine-adrenergic combination. Ann-Otol-Rhinol-Laryngol-Suppl. 1980;89:285-289. [pmid: 6778329].
O'shea J S, Langenbrunner D J, McCloskey D E, Pezzullo J C, Regan J B. Childhood serous otitis media: fifteen months' observations of children untreated compared with those receiving an antihistamine-adrenergic combination. Clin-Pediatr-Phila. 1982;21:150-153. [pmid: 7035052].
O'shea J S, Regan J B, Langenbrunner D J, Pezzullo J C. Childhood otitis media with effusion: six-year follow-up. J Otolaryngol. 1986;15:303-305. [pmid: 3773046].
O'Tuama L A, Swanson M S. Development of paranasal and mastoid sinuses: a computed tomographic pilot study. J Child Neurol. 1986;1:46-49. [pmid: 3598107].
Obi C L, Enweani I B, Giwa J O. Bacterial agents causing chronic suppurative otitis media. East Afr Med J. 1995;72:370-372. [pmid: 7498006].
Ochsner S F. Eosinophilic granuloma of bone; experience with 20 cases. American Journal of Roentgenology, Radium Therapy and Nuclear Medicine. 1966;97:719-726.
Odabasi O, Basak O, Basak S, Mutlu C, Erpek G. Middle ear pathology in day-care centre children. Fam Pract. 1998;15:332-335. [pmid: 9792348].
Odio C M, Kusmiesz H, Shelton S, Nelson J D. Comparative treatment trial of augmentin versus cefaclor for acute otitis media with effusion. Pediatrics. 1985;75:819-826. [pmid: 4039433].
Ogale S B, Desouza C, Sheode J, Shah K L. The styloid process in ossicular chain reconstruction (a pilot study). J Laryngol Otol. 1988;102:136-137. [pmid: 3346590].
Ogale S B, Dutt S N, Thakur S, Pawar M. The styloid process in ossicular chain reconstruction. II: Long-term analysis. J Laryngol Otol. 1994;108:111-112. [pmid: 8163909].
Ogale S B, Mahajan S B, Dutt S, Sheode J H. Fate of middle ear implants. Auris Nasus Larynx. 1997;24:151-157. [pmid: 9134137].
Ogaro F O, Orinda V A, Onyango F E, Black R E. Effect of vitamin A on diarrhoeal and respiratory complications of measles. Trop-Geogr-Med. 1993;45:283-286. [pmid: 8116059].
Ogawa H, Hashigucci K, Kazuyama Y. [Association of Chlamydia pneumoniae infection with otitis media with effusion]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1993;96:29-34.
Ogino S, Harada T, Matsunaga T, Tominaga Y. Use of Tranilast [N-(3,4-dimethoxycinnamoyl) anthranilic acid] in secretory otitis media. Annals of Allergy. 1992;68:407-412. [pmid: 1375005].
Ogisi F O. Impedance screening for otitis media with effusion in Nigerian children. J Laryngol Otol. 1988;102:986-988. [pmid: 3264847].
Ogle J W, Lauer B A. Acute mastoiditis. Diagnosis and complications. Am J Dis Child. 1986;140:1178-1182. [pmid: 2876623].
Oh H M. Upper respiratory tract infections - otitis media, sinusitis and pharyngitis. Singapore Med J. 1995;36:428-431. [pmid: 8919162].
Oh P I, Maerov P, Pritchard D, Knowles S R, Einarson T R, Shear N H. A cost-utility analysis of second-line antibiotics in the treatment of acute otitis media in children. Clin Ther. 1996;18:160-182. [pmid: 8851461].
Ohashi Y, Nakai Y, Ohno Y, et al. Influenza A modification of endotoxin-induced otitis media with effusion in the guinea pig. Eur Arch Otorhinolaryngol. 1993;250:27-32. [pmid: 8466747].
Ohashi Y, Nakai Y, Ohno Y, Sugiura Y, Okamoto H. Effects of human middle ear effusions on the mucociliary system of the tubotympanum in the guinea pig. Eur Arch Otorhinolaryngol. 1995;252:35-41. [pmid: 7718226].
Ohnishi T, Mochizuki M, Hongo S. Complications of Otitis Media with Effusion in Japanese Children. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:360–364.
Ohnishi T, Shirahata Y, Fukami M, Hongo S. The atelectatic ear and its classification. Auris Nasus Larynx. 1985;12:S211-S213. [pmid: 3835911].
Ohnishi T. Sequelae of otitis media with effusion and its classification. Otolaryngology. 1985;57:29-35.
Ohsaki K, Shibata A, Yamashita S, et al. Demonstrations of de-and remineralization mechanism as revealed in synthetic auditory ossicle (Apaceram) of rats by laser-Raman spectrometry. Cell Mol Biol. 1995;41:1155-1167. [pmid: 8747096].
Oishi K, Tanaka H, Sonoda F, et al. A monoclonal antibody reactive with a common epitope of Moraxella (Branhamella) catarrhalis lipopolysaccharides. Clin Diagn Lab Immunol. 1996;3:351-354. [pmcid: 170345]. [pmid: 8705682].
Oja H, Alho O P, Laara E. Model-based estimation of the excess fraction (attributable fraction): day care and middle ear infection. Stat Med. 1996;15:1519-1534. [pmid: 8855478].
Ojala K, Palva A, Sorri M. Late changes in hearing results after mastoid obliteration with tympanoplasty. Arch Otolaryngol. 1982;108:569-573. [pmid: 7115187].
Ojala K, Sorri M. The preoperative state of infection in chronic otitis media correlated with postoperative hearing results. Arch Otorhinolaryngol. 1982;234:253-262. [pmid: 7115198].
Ojala K, Sorri M, Vainio-Mattila J. Bacteriological studies after obliterative mastoid operations. Clin Otolaryngol Allied Sci. 1982;7:81-86. [pmid: 7094386].
Ojala K, Sipila P, Sorri M, Karma P. Role of atopic allergy in chronic otitis media. Evaluation based on serum IgE and nasal/aural cytologic findings in patients with operated chronic ears. Acta Otolaryngol. 1982;93:55-60. [pmid: 7064696].
Ojala K, Sorri M. Late post-operative hearing results correlated with the severity of tissue changes in ears with chronic otitis media. J Laryngol Otol. 1983;97:131-139. [pmid: 6827180].
Ojala K, Sorri M, Vainio-Mattila J, Sipila P. Late results of tympanoplasty using ossicle or cortical bone. J Laryngol Otol. 1983;97:19-25. [pmid: 6337227].
Ojeda-Vargas M, Monzon-Moreno C, Gonzalez-Romero D, Martin-Sanchez A M. [Cerebral abscess of otic origin caused conjointly by Proteus mirabilis and Alcaligenes faecalis (letter)]. Enferm Infecc Microbiol Clin. 1995;13:635. [pmid: 8808483].
Okamoto Y, Kudo K, Ishikawa K, et al. Presence of respiratory syncytial virus genomic sequences in middle ear fluid and its relationship to expression of cytokines and cell adhesion molecules. J Infect Dis. 1993;168:1277-1281. [pmid: 8228363].
Okamura R. [Studies on total nerve fivers of chorda tympani nerve in man]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1996;99:28-37.
Okeke E N, Juryit Z, Ikeh E I. Open clinical trial of roxithromycin in patients of Plateau Hospitals, Jos in upper and lower respiratory tract infections. West Afr J Med. 1995;14:238-241. [pmid: 8634230].
Okeowo PA, Casselbrant ML, Flaherty MR, et al. Prevalence of otitis media with effusion in a group of preschool children in the United States. Ann Otol Rhinol Laryngol. 1983;96.
Okeowo P A. An assessment of the sequelae of untreated secretory otitis media in Nigerian children. J Trop Pediatr. 1985;31:216-218. [pmid: 4046101].
Okitsu T, Kobayashi T, Endo S, et al. Tympanograms of otitis media with effusion: an experimental study. Auris Nasus Larynx. 1985;12:S222-S224. [pmid: 3835915].
Okitsu T, Yoshida S, Shoji F, Taniguchi K. Acute otitis media accompanied by sensorineural hearing loss. Practica Otologica. 1992;85:351-358.
Okonska H, Krzeska-Malinowska I, Moszynski B. [Sensorineural hearing loss in the course of acute otitis media]. Otolaryngol Pol. 1995;49:138-142. [pmid: 7644217].
Okumura T, Takahashi H, Honjo I, Takagi A, Azato R. Magnetic resonance imaging of patients with large vestibular aqueducts. European Archives of Oto Rhino Laryngology. 1996;253:425-428. [pmid: 8891488].
Olalla I, Ortin M, Hermida G, et al. Autologous peripheral blood stem cell transplantation in a patient with previous invasive middle ear mucormycosis. Bone Marrow Transplant. 1996;18:1183-1184. [pmid: 8971393].
Olling S, Lind L, Roos K, Karlsson G, Granstrom G, Renvall U. Cytological and bacteriological aspects of secretory otitis media. APMIS. 1990;98:896-900. [pmid: 2123111].
Olofsson K, Hellstrom S, Hammarstrom M L. Abundance of intraepithelial gamma delta T cells in hypertrophic obstructive but not in chronically infected adenoids. Clin Exp Immunol. 1996;106:396-403. [pmid: 8918590].
Olopoenia L, Young M, White D, Barnes S, Rahbar F, Fomufod A. Intravenous immunoglobulin in symptomatic and asymptomatic children with perinatal HIV infection. J-Natl-Med-Assoc. 1997;89:543-547. [pmid: 9264222].
Olsen W O. Artificial mastoid calibration of bone vibrators. Arch Otolaryngol. 1967;85:314-318. [pmid: 6019247].
Olson A L, Klein S W, Charney E, et al. Prevention and therapy of serous otitis media by oral decongestant: a double-blind study in pediatric practice. Pediatrics. 1978;61:679-684. [pmid: 351537].
Oluwole M, Mills R P. Methods of selection for adenoidectomy in childhood otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1995;32:129-135. [pmid: 7657466].
Omura F, Makino K, Amatsu M, Itoh H. The role of middle ear effusions and epidermal growth factor in cholesteatoma formation in the gerbilline temporal bone. Eur Arch Otorhinolaryngol. 1995;252:428-432. [pmid: 8562039].
Ondrey F G, Juhn S K, Adams G L. Early-response cytokine expression in adult middle ear effusions. Otolaryngol Head Neck Surg. 1998;119:342-345. [pmid: 9781987].
Ones U, Sapan N, Somer A, et al. Prevalence of childhood asthma in Istanbul, Turkey. Allergy. 1997;52:570-575. [pmid: 9201370].
Onion D K, Taylor C. The epidemiology of recurrent otitis media. Am J Public Health. 1977;67:472-474. [pmid: 857688]. [pmcid: 1653632].
Oppenheimer P. Short-term steroid therapy. Treatment of serous otitis media in children. Arch Otolaryngol. 1968;88:138-140. [pmid: 5662924].
Orchik D J, Morff R, Dunn J W. Impedance audiometry in serous otitis media. Arch Otolaryngol. 1978;104:409-412. [pmid: 666650].
Orchik D J, Dunn J W, McNutt L. Tympanometry as a predictor of middle ear effusion. Arch Otolaryngol. 1978;104:4-6. [pmid: 619884].
Orchik D J, Morff R, Dunn J W. Middle ear status at myringotomy and its relationship to middle ear immitance measurements. Ear Hear. 1980;1:324-328. [pmid: 7192227].
Ordonez G E, Kime C E, Updegraff W R, et al. Effective treatment of acute, diffuse otitis externa. I. A controlled comparison of hydrocortisone-acetic acid, nonaqueous and hydrocortisone-neomycin-polymyxin B otic solutions. CURR-THER-RES,-CLIN-EXP. 1978;23:SS3-SS14.
Orlin M N, Effgen S K, Handler S D. Effect of otitis media with effusion on gross motor ability in preschool-aged children: preliminary findings. Pediatrics. 1997;99:334-337. [pmid: 9041283].
Orvidas L J, Fabry L B, Diacova S, McDonald T J. Hearing and otopathology in Crouzon syndrome. Laryngoscope. 1999;109:1372-1375. [pmid: 10499038].
Oski F A. Infant nutrition, physical growth, breastfeeding, and general nutrition. Curr Opin Pediatr. 1994;6:361-364. [pmid: 8061747].
Ostapkovich V Y. Influence of ear diseases on occupational hearing impairment. Zhurnal Ushnykh, Nosovykh i Gorlovykh Boleznei. 1983;43:14-18.
Ostergard C A, Carter D R. Positive middle ear pressure shown by tympanometry. Arch Otolaryngol. 1981;107:353-356. [pmid: 7224964].
Ostfeld E. Otitis media: the middle ear effusion total white cell count. Am J Otol. 1984;5:382-386. [pmid: 6540996].
Ostri B, Bak-Pedersen K. Surgical management of labyrinthine fistulae in chronic otitis media with cholesteatoma by a one-stage closed technique. ORL J Otorhinolaryngol Relat Spec. 1989;51:295-299. [pmid: 2812726].
Ostrovskii AI. [Reconstruction of the ossicle-tympanic system with a variable configuration prosthesis]. Vestn Otorinolaringol. 1995:37–39.
Ostrovskii AI. [Tympanoplasty in massive destruction of bony walls of the tympanic cavity]. Vestn Otorinolaringol. 1995:34–36.
Ottaviani A, Mantovani M, Scaricabarozzi I. A multicentre clinical study of nimesulide in inflammatory diseases of the ear, nose and throat. Drugs. 1993;46:96-99. [pmid: 7506201].
Otten F W, Grote J J. Otitis media with effusion and chronic upper respiratory tract infection in children: a randomized, placebo-controlled clinical study. Laryngoscope. 1990;100:627-633. [pmid: 1693411].
Ovchinnikov Iu M, Dobrotin VE, Tsukerberg LI, Filimonov GP, Fedorenko VD. [Role of computerized tomography in the diagnosis of osteomas of the sphenoid sinus with intracranial extension]. Vestn Otorinolaringol. 1994:11–14.
Ovesen T, Ledet T. Bacteria and endotoxin in middle ear fluid and the course of secretory otitis media. Clin Otolaryngol Allied Sci. 1992;17:531-534. [pmid: 1493632].
Ovesen T, Paaske P B, Elbrond O. Accuracy of an automatic impedance apparatus in a population with secretory otitis media: principles in the evaluation of tympanometrical findings. Am J Otolaryngol. 1993;14:100-104. [pmid: 8484473].
Ovesen T, Gaihede M, Ledet T. The effect of N-acetylcysteine on the in vitro growth of normal rabbit middle ear fibroblasts. Clin Otolaryngol. 1993;18:400-405. [pmid: 8877208].
Ovesen T, Gaihede M, Elbrond O. The influence of endotoxin upon middle ear fibroblasts cultured in normal middle ear gas and atmospheric air. APMIS. 1994;102:743-752. [pmid: 7826603].
Ovesen T, Gaihede M, Ledet T. In vitro growth and collagen synthesis in fibroblasts from the rabbit middle ear mucosa. Eur Arch Otorhinolaryngol. 1994;251:257-262. [pmid: 7986495].
Ovesen T, Paaske P, Ledet T, Elbrond O. Immunohistochemical quantitation of collagen types I, II, IV and V in the ventilated and non-ventilated rabbit middle ear with otitis media with effusion. Eur Arch Otorhinolaryngol. 1994;251:137-142. [pmid: 8080632].
Ovesen T. Implications of middle ear hyperoxia induced by ventilation tubes in otitis media with effusion. Apmis. Supplementum. 1995;54:1-36. [pmid: 8534521].
Ovesen T, Borglum JD. New aspects of secretory otitis media, eustachian tube function and middle ear gas. Ear Nose Throat J. 1998;77.
Owen MJ, Norcross K, Howie VM, Dussack L, Boone BD. Brainstem Auditory Evoked Potentials in Children with Tympanostomy Tubes. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:379–382.
Owen M J, Anwar R, Nguyen H K, Swank P R, Bannister E R, Howie V M. Efficacy of cefixime in the treatment of acute otitis media in children. Am-J-Dis-Child. 1993;147:81-86. [pmid: 8418608].
Owen M J, Baldwin C D, Swank P R, Pannu A K, Johnson D L, Howie V M. Relation of infant feeding practices, cigarette smoke exposure, and group child care to the onset and duration of otitis media with effusion in the first two years of life. J Pediatr. 1993;123:702-711. [pmid: 8229477].
Owen M J, Norcross-Nechay K, Howie V M. Brainstem auditory evoked potentials in young children before and after tympanostomy tube placement. Int J Pediatr Otorhinolaryngol. 1993;25:105-117. [pmid: 8436453].
Owen MJ, Johnson DL, Swank PR, Baldwin CD, Aker J, Howie VM. Duration of otitis media with effusion from birth to 3 years of age related to language and cognititve scores at 5 years. In: Lim DJ BC, Casselbrant M, Klein JO, Ogra P, ed. Recent Advances in Otitis Media: Proceedings of the Sixth International Symposium. Hamilton, Ontario: B.C. Decker Inc; 1996:329–331.
Owen MJ, Hornberger B, Pohl JF, Chonmaitree T, Howie VM. Bacteriologic and clinical efficacy of cetriaxone in the treatment of acute otitis media. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:238–241.
Owens R C Jr, Nightingale C H, Nicolau D P. Ceftibuten: an overview. Pharmacotherapy. 1997;17:707-720. [pmid: 9250548].
Oyeka C A, Oyeka I C, Okeke G N. Prevalence of bacterial otitis media in primary school children in Enugu Surburb, Enugu state, Nigeria. West Afr J Med. 1995;14:78-81. [pmid: 7495718].
Oyelami O A, Aladekomo T A, Ononye F O. A 10 year retrospective evaluation of cases of post neonatal tetanus seen in a paediatric unit of a university teaching hospital in south western Nigeria (1985 to 1994). Cent Afr J Med. 1996;42:73-75. [pmid: 8653773].
Oyiborhoro J M, Olaniyan S O, Newman C W, Balakrishnan S L. Efficacy of acoustic otoscope in detecting middle ear effusion in children. Laryngoscope. 1987;97:495-498. [pmid: 3561136].
Ozagar A, Koc A, Ciprut A, Tutkun A, Akdas F, Sehitoglu M A. Effects of topical otic preparations on hearing in chronic otitis media. Otolaryngol-Head-Neck-Surg. 1997;117:405-408. [pmid: 9339804].
Ozagar A, Koc A, Ciprut A, Tutkun A, Akdas F, Sehitoglu M A. Effects of topical otic preparations on hearing in chronic otitis media [see comments]. Otolaryngol Head Neck Surg. 1997;117:405-408. [pmid: 9339804].
Ozcelik T, Ataman M, Gedikoglu G. An unusual presentation: primary tuberculosis of the middle ear cleft. Tuber Lung Dis. 1995;76:178-179. [pmid: 7780105].
Ozcelik T, Ozgirgin N, Ozcelik U, Gocmen A, Gurcan B, Kiper N. Auditory nerve-brainstem responses in cystic fibrosis patients. Int J Pediatr Otorhinolaryngol. 1996;35:165-169. [pmid: 8735412].
Ozsoylu S. Therapy for acute otitis media [letter; comment]. Arch Pediatr Adolesc Med. 1996;150:1315. [pmid: 8954011].
Paap C M. Management of otitis media with effusion in young children. Ann Pharmacother. 1996;30:1291-1297. [pmid: 8913412].
Paavolainen M. Incidence, etiology and prognosis of acute purulent otitis media in Helsinki residents of various ages. Acta Otolaryngol. 1966;Suppl:360+.
Paden E P, Novak M A, Beiter A L. Predictors of phonologic inadequacy in young children prone to otitis media. J Speech Hear Disord. 1987;52:232-242. [pmid: 3455446].
Paden E P, Matthies M L, Novak M A. Recovery from OME-related phonologic delay following tube placement. J Speech Hear Disord. 1989;54:94-100. [pmid: 2915531].
Pagano M, Africano R, Lo Pinto G. [Wegener granulomatosis: a clinical case with parossistic positional vertigo due to involvement of the lateral semicircular canal]. Acta Otorhinolaryngol Ital. 1996;16:438-440. [pmid: 9199089].
Page J M. Audiology: a problem oriented approach. Otolaryngol Clin North Am. 1978;11:801-811. [pmid: 733261].
Pahor A L, Sozen N, Beetham R, Raine D N. Immunoelectrophoretic study of proteins in middle ear effusion. A study of secretory otitis media in children. J Laryngol Otol. 1976;90:1033-1040. [pmid: 1003029].
Pahor A L. An early history of secretory otitis media. J Laryngol Otol. 1978;92:543-560. [pmid: 355586].
Pal'chun VT, Kriukov AI, Uzdennikov AA, Ogorodnikov DS, Pakhomov IL. [The potentials for using paracetamol in otorhinolaryngology]. Vestn Otorinolaringol. 1994:43–46.
Palfrey J S, Hanson M A, Pleszczynska C, Norton S, Levine M D. Selective hearing screening for young children. Clin Pediatr. 1980;19:473-477.
Pallestrini E, Cimino A, Colletti V, et al. Comparative study of rufloxacin versus clarithromycin in the short term treatment of patients with otorhinolaryngological infections. Rivista Italiana Di Otorinolaringologia Audiologia e Foniatria. 1995;15:236-245.
Pallin J L, Behrends W H Jr, Gilmartin L J. Middle ear ventilation tubes. J Fla Med Assoc. 1978;65:717-719. [pmid: 568165].
Palmgren O. Long-term results of open cavity and tympanomastoid surgery of the chronic ear. Acta Otolaryngol. 1979;88:343-349. [pmid: 532609].
Palmisano J M, Moler F W, Revesz S M, Custer J R, Koopmann C. Chronic otitis media requiring ventilation tubes in tracheotomized ventilator dependent children. Int J Pediatr Otorhinolaryngol. 1994;30:177-182. [pmid: 7836030].
Palmu A, Puhakka H, Rahko T, Takala A K. Diagnostic value of tympanometry in infants in clinical practice. Int J Pediatr Otorhinolaryngol. 1999;49:207-213. [pmid: 10519700].
Palva T, Palva A, Salmivalli A. Radical mastoidectomy with cavity obliteration. Arch Otolaryngol. 1968;88:119-123. [pmid: 5662921].
Palva T, Palva A, Dammert K. Middle ear mucosa and chronic ear disease. Arch Otolaryngol. 1968;87:3-11. [pmid: 5634949].
Palva T, Palva A, Karja J. Myringoplasty. Ann Otol Rhinol Laryngol. 1969;78:1074-1080. [pmid: 5822990].
Palva T, Palva A, Karja J. Results with 2- or 3-legged wire columellization in chronic ear surgery. Ann Otol Rhinol Laryngol. 1971;80:760-765. [pmid: 5110883].
Palva T, Karja J, Palva A. Opening of the labyrinth during chronic ear surgery. Arch Otolaryngol. 1971;93:75-78. [pmid: 5538744].
Palva T, Karja J, Palva A. High-tone sensorineural losses following chronic ear surgery. Arch Otolaryngol. 1973;98:176-178. [pmid: 4742423].
Palva T, Palva A, Karja J. Ossicular reconstruction in chronic ear surgery. Arch Otolaryngol. 1973;98:340-348. [pmid: 4745309].
Palva T, Raunio V. The role of the middle ear mucosa in secretory otitis media. J Laryngol Otol. 1975;89:491-494. [pmid: 125307].
Palva T, Palva A. Mucosal histochemistry in secretory otitis. Ann Otol Rhinol Laryngol. 1975;84:112-116. [pmid: 46141].
Palva A. The problem of chronic otitis media in northern Finland. pp. 403–8. In: Shephard RJ, Itoh S, ed. Circumpolar health. Toronto, Univ of Toronto Press. 1976.
Palva A, Karma P, Karja J. Cholesteatoma in children. Arch Otolaryngol. 1977;103:74-77. [pmid: 836233].
Palva T, Holopainen E. Management of noncholesteatomatous suppurative middle ear disease in children. Adv Otorhinolaryngol. 1978;23:45-57. [pmid: 622916].
Palva T, Hayry P, Ylikoski J. Lymphocyte morphology in middle ear effusions. Ann Otol Rhinol Laryngol Suppl. 1980;89:143-146. [pmid: 6778297].
Palva T, Reitamo S, Konttinen Y T, Hayry P, Rinne J. Inflammatory cell subpopulations in the middle ear mucosa of ears with effusion. Int J Pediatr Otorhinolaryngol. 1981;3:71-78. [pmid: 6970738].
Palva T, Virtanen H. Ear surgery and mastoid air cell system. Arch Otolaryngol. 1981;107:71-73. [pmid: 7469894].
Palva T, Makinen J. Why does middle ear cholesteatoma recur?. Arch Otolaryngol. 1983;109:513-518. [pmid: 6870643].
Palva T, Lehtinen T, Halmepuro L. Immunoglobulin E in mucoid secretory otitis media. ORL J Otorhinolaryngol Relat Spec. 1985;47:220-223. [pmid: 4040626].
Palva T. Surgical treatment of chronic middle ear disease. II. Canal wall up and canal wall down procedures. Acta Otolaryngol. 1987;104:487-494. [pmid: 3434271].
Palva T, Johnsson L G, Jauhiainen T, Pyykko I, Saarnivaara L. The Otorhinolaryngology Department in Helsinki: organization and otologic research. ORL J Otorhinolaryngol Relat Spec. 1988;50:110-118. [pmid: 3374940].
Palva T. Surgical treatment of chronic middle ear disease. III. Revisions after tympanomastoid surgery. Acta Otolaryngol. 1988;105:82-89. [pmid: 3341165].
Palva T, Johnsson L G. Epitympanic compartment surgical considerations: reevaluation. Am J Otol. 1995;16:505-513. [pmid: 8588652].
Palva T, Ramsay H. Incudal folds and epitympanic aeration. Am J Otol. 1996;17:700-708. [pmid: 8892564].
Pan S, Wang Z, Jiang Y. [Acoustic characteristics of external auditory meatus after tympanoplasty with open mastoid reconstruction]. Chung Hua Erh Pi Yen Hou Ko Tsa Chih - Chinese Journal of Otorhinolaryngology. 1995;30:239-242.
Panda N K, Sreedharan S, Mann S B, Sharma S C. Prognostic factors in complicated and uncomplicated chronic otitis media. Am J Otolaryngol. 1996;17:391-396. [pmid: 8944298].
Paparella M M, Lim D J. Pathogenesis and pathology of the “idiopathic” blue ear drum. Arch Otolaryngol. 1967;85:249-258. [pmid: 6019240].
Paparella M M, Brady D R, Hoel R. Sensori-neural hearing loss in chronic otitis media and mastoiditis. Transactions - American Academy of Ophthalmology and Otolaryngology. 1970;74:108-115. [pmid: 5442952].
Paparella M M, Oda M, Hiraide F, Brady D. Pathology of sensorineural hearing loss in otitis media. Ann Otol Rhinol Laryngol. 1972;81:632-647. [pmid: 4631219].
Paparella M M. Otological manifestations of viral disease. Adv Otorhinolaryngol. 1973;20:144-154. [pmid: 4710506].
Paparella M M. Middle ear effusions: definitions and terminology. Ann Otol Rhinol Laryngol. 1976;85:8-11. [pmid: 1267372].
Paparella M M, Kim C S. Mastoidectomy update. Laryngoscope. 1977;87:1977-1988. [pmid: 337011].
Paparella MM. Labyrinthitis. pp. 81–92. In: Bess FH, ed. Childhood deafness: causation, assessment, and management. New York, Grune and Stratton. 1977;270.
Paparella M M, Rybak L, Meyerhoff W L. Air caloric testing in otitis media. (preliminary studies). Laryngoscope. 1979;89:708-714. [pmid: 109711].
Paparella M M, Goycoolea M V, Meyerhoff W L, Shea D. Endolymphatic hydrops and otitis media. Laryngoscope. 1979;89:43-58. [pmid: 423652].
Paparella M M, Shea D, Meyerhoff W L, Goycoolea M V. Silent otitis media. Laryngoscope. 1980;90:1089-1098. [pmid: 7392745].
Paparella M M, Jung T T. Experience with tympanoplasty for atelectatic ears. Laryngoscope. 1981;91:1472-1477. [pmid: 7346690].
Paparella M M. Insidious labyrinthine changes in otitis media. Acta Otolaryngol. 1981;92:513-520. [pmid: 7315269].
Paparella M M, Jung T T. Intact bridge tympanomastoidectomy (I.B.M.)--combining essential features of open vs. closed procedures. J Laryngol Otol. 1983;97:579-585. [pmid: 6875358].
Paparella M M, Jung T T. Intact-bridge tympanomastoidectomy. Otolaryngol Head Neck Surg. 1984;92:334-338. [pmid: 6431375].
Paparella M M, Morizono T, Le C T, et al. Sensorineural hearing loss in otitis media. Ann Otol Rhinol Laryngol. 1984;93:623-629. [pmid: 6508134].
Paparella M M, Sipila P, Juhn S K, Jung T T. Subepithelial space in otitis media. Laryngoscope. 1985;95:414-420. [pmid: 2984491].
Paparella M M, Abdelhammid M M, Schachern P A, Sahni R, Yoon T H, Da Costa S S. Otopathologic correlates of the continuum of otitis media. Ann Otol Rhinol Laryngol. 1990;99:17-22.
Paparella M M, Schachern P. New developments in treating otitis media. Ann Otol Rhinol Laryngol Suppl. 1994;163:7-10. [pmid: 8179274].
Paparella M M, Froymovich O. Surgical advances in treating otitis media. Ann Otol Rhinol Laryngol Suppl. 1994;163:49-53. [pmid: 8179271].
Papastavros T, Giamarellou H, Varledjides S. Obtaining specimens of discharge from the middle ear for cultures. Laryngoscope. 1985;95:1413-1414. [pmid: 4058225].
Papastavros T, Varlejides S. Reversible and permanent bone conduction threshold shift in cases of chronic suppurative otitis media. Am J Otol. 1986;7:338-346. [pmid: 3789119].
Papastavros T, Giamarellou H, Varlejides S. Preoperative therapeutic considerations in chronic suppurative otitis media. Laryngoscope. 1989;99:655-659. [pmid: 2725163].
Papatziamos G, van der Ploeg I, Hemlin C, Patwardhan A, Scheynius A. Increased occurrence of IgE+ and FcepsilonRI+ cells in adenoids from atopic children. Allergy. 1999;54:916-925. [pmid: 10505454].
Pappas D G, Wolcott G T. Clinical observations of tympanometric findings in external otitis. Eye, Ear, Nose and Throat Monthly. 1975;54:101-103.
Pappas D G. The origin of aural instruments. Am J Otol. 1979;1:121-124. [pmid: 400069].
Pappas D G. Incus reposition: goblet prosthesis. Laryngoscope. 1980;90:1466-1470. [pmid: 7401848].
Pappas J J, Bailey H A Jr, McGrew R N, Graham S S. Homograft septal cartilage for attic support in intact canal wall tympanomastoidectomy and tympanoplasty. Laryngoscope. 1981;91:1457-1462. [pmid: 7346687].
Pappas D G. Bondy's modified radical mastoidectomy revisited. Ear Nose Throat J. 1994;73:15-18. [pmid: 8162866].
Pappas D G, Flexer C, Shackelford L. Otological and habilitative management of children with Down syndrome. Laryngoscope. 1994;104:1065-1070. [pmid: 8072350].
Pappas D G. Hermann Hugo Rudolf Schwartze (1837–1910). Reintroduction of paracentesis and mastoid surgery. Ear Nose Throat J. 1996;75:708-709. [pmid: 8972993].
Papsin B C, Bailey C M, Albert D M, Bellman S C. Otitis media with effusion in paediatric cochlear implantees: the role of peri-implant grommet insertion. Int J Pediatr Otorhinolaryngol. 1996;38:13-19. [pmid: 9119589].
Papsin B C, Vellodi A, Bailey C M, Ratcliffe P C, Leighton S E. Otologic and laryngologic manifestations of mucopolysaccharidoses after bone marrow transplantation. Otolaryngol Head Neck Surg. 1998;118:30-36. [pmid: 9450825].
Paradise J L, Bluestone C D. Toward rational indications for tonsil and adenoid surgery. Hosp Pract. 1976;11:79-87. [pmid: 1072024].
Paradise J L, Smith C G, Bluestone C D. Tympanometric detection of middle ear effusion in infants and young children. Pediatrics. 1976;58:198-210. [pmid: 951134].
Paradise J L, Smith C G. Impedance screening for preschool children. State of the art. Ann Otol Rhinol Laryngol. 1979;88:56-65. [pmid: 426447].
Paradise J L, Bluestone C D, Rogers K D, Taylor F H. Efficacy of adenoidectomy in recurrent otitis media. Historical overview and preliminary results from a randomized, controlled trial. Ann-Otol-Rhinol-Laryngol-Suppl. 1980;89:319-321. [pmid: 6778337].
Paradise J L, Rogers K D. On otitis media, child development, and tympanostomy tubes: new answers or old questions?. Pediatrics. 1986;77:88-92. [pmid: 3940362].
Paradise J L, Bluestone C D, Rogers K D, et al. Efficacy of adenoidectomy for recurrent otitis media in children previously treated with tympanostomy-tube placement. Results of parallel randomized and nonrandomized trials. JAMA. 1990;263:2066-2073. [pmid: 2181158].
Paradise J L, Elster B A, Tan L. Evidence in infants with cleft palate that breast milk protects against otitis media. Pediatrics. 1994;94:853-860. [pmid: 7971001].
Paradise J L, Haggard M P, Lous J, Roberts J E, Schilder A G. Developmental implications of early-life otitis media. Int J Pediatr Otorhinolaryngol. 1995;32:S37-S44. [pmid: 7665298].
Paradise J L. Managing otitis media: a time for change. Pediatrics. 1995;96:712-715. [pmid: 7567336].
Paradise J L. Treatment guidelines for otitis media: the need for breadth and flexibility. Pediatr Infect Dis J. 1995;14:429-435. [pmid: 7638033].
Paradise JL, Smith CG, Sabo DL, et al. Tympanometric detection of middle ear effusion in the first versus the second year of life. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:155.
Paradise JL, Colborn DK, Bernard BS, et al. Comparison of the early results of tympanostomy tube placement and of nonsurgical management in infants with persistent otitis media. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:201.
Paradise JL, Smith CG, Sabo DL, et al. Consequences of differing tympanographic classification criteria in diagnosing middle ear effusion. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:154.
Paradise J L, Rockette H E, Colborn D K, et al. Otitis media in 2253 Pittsburgh-area infants: prevalence and risk factors during the first two years of life [see comments]. Pediatrics. 1997;99:318-333. [pmid: 9041282].
Paradise J L. Are the ear and the heart fellow travelers of a sort? [editorial; comment]. J Pediatr. 1997;131:179-180. [pmid: 9290600].
Paradise JL. Otitis media and child development: should we worry? Pediatr Infect Dis J. 1998;17:1076–1083; discussion 1099–1100.
Paradise J L, Bluestone C D, Colborn D K, et al. Adenoidectomy and adenotonsillectomy for recurrent acute otitis media: Parallel randomized clinical trials in children not previously treated with tympanostomy tubes. JAMA. 1999;282:945-953. [pmid: 10485679].
Paradise J L, Feldman H M, Colborn D K, et al. Parental stress and parent-rated child behavior in relation to otitis media in the first three years of life. Pediatrics. 1999;104:1264-1273. [pmid: 10585976].
Paradise J L, Dollaghan C A, Campbell T F, et al. Language, speech sound production, and cognition in three-year-old children in relation to otitis media in their first three years of life. Pediatrics. 2000;105:1119-1129. [pmid: 10790473].
Paradise J L, Feldman H M, Campbell T F, et al. Early vs late tube placement for persistent middle-ear effusion in the first 3 years of life: effects on language, speech sound production, and cognition at age 3 years (abstract). Pediatrics Res. 2000;47:216A.
Paraskaki I, Lebessi E, Deliyanni V, Kafetzis D A. Bacteriology of acute otitis media in a Greek pediatric population. J Chemother. 1995;7:142-144. [pmid: 8904136].
Paraskaki I, Lebessi E, Legakis N J. Epidemiology of community-acquired Pseudomonas aeruginosa infections in children. Eur J Clin Microbiol Infect Dis. 1996;15:782-786. [pmid: 8950554].
Parell G J. Goode T tubes [letter; comment]. Arch Otolaryngol Head Neck Surg. 1993;119:577. [pmid: 8484950].
Parikh A A, Brookes G B. Subtotal petrosectomy with external canal overclosure in the management of chronic suppurative otitis media. J Laryngol Otol. 1994;108:197-201. [pmid: 8169498].
Parikh A, Scadding G K. Treatment of persistent otitis media [letter; comment]. Lancet. 1996;348:1517. [pmid: 8942801].
Parikh A A, Brookes G B. Vestibular nerve section following previous mastoidectomy. J Laryngol Otol. 1996;110:836-840. [pmid: 8949292].
Parisier S C, Edelstein D R, Han J C, Weiss M H. Management of labyrinthine fistulas caused by cholesteatoma. Otolaryngol Head Neck Surg. 1991;104:110-115. [pmid: 1706085].
Parisier S C, Chute P M, Popp A L, Hanson M B. Surgical techniques for cochlear implantation in the very young child. Otolaryngol Head Neck Surg. 1997;117:248-254. [pmid: 9334773].
Park IY, Kim HN, Chung MH, Park KH, Yim SB. Diagnostic Reliability of Impedance Audiometry in Case of Otitis Media with Effusion. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:52–54.
Park M S, Kim Y B. Sustained release of antibiotic from a fibrin-gelatin-antibiotic mixture. Laryngoscope. 1997;107:1378-1381. [pmid: 9331317].
Parker R. Routine radiography in early cholesteatomatous middle ear disease. J Laryngol Otol. 1975;89:151-158. [pmid: 1123566].
Parker A J, Maw A R. Treatment of glue ear in relation to radiographic palatal airway size: a predictor for outcome following adenoidectomy?. J Laryngol Otol. 1989;103:66-70. [pmid: 2646383].
Parker A J, Maw A R, Powell J E. Rhinomanometry in the selection for adenoidectomy and its relation to preoperative radiology. Int J Pediatr Otorhinolaryngol. 1989;17:155-161. [pmid: 2759780].
Parker A J, Maw A R. No peak-peak tympanometric conversion following surgery for otitis media with effusion in relation to airway size: a new treatment strategy?. Clin Otolaryngol Allied Sci. 1989;14:27-32. [pmid: 2920453].
Parker A J, Powell J E, Maw A R. Nasal mucociliary clearance and resolution of otitis media with effusion in children following adenoidectomy. Rhinology. 1992;30:97-101. [pmid: 1411103].
Parker G S, Tami T A, Maddox M R, Wilson J F. The effect of water exposure after tympanostomy tube insertion. Am J Otolaryngol. 1994;15:193-196. [pmid: 8024107].
Parker P C, Boles R G. Pseudomonas otitis media and bacteremia following a water birth [letter]. Pediatrics. 1997;99:653. [pmid: 9093328].
Parkin J L, Wood G S, Wood R D, McCandless G A. Drill- and suction-generated noise in mastoid surgery. Arch Otolaryngol. 1980;106:92-96. [pmid: 7352914].
Parks R R, Huang C C, Haddad J Jr. Evidence of oxygen radical injury in experimental otitis media. Laryngoscope. 1994;104:1389-1392. [pmid: 7968170].
Parks R R, Huang C C, Haddad J Jr. Superoxide dismutase in an animal model of otitis media. Eur Arch Otorhinolaryngol. 1995;252:153-158. [pmid: 7662350].
Parks R R, Huang C C, Haddad J Jr. Middle ear catalase distribution in an animal model of otitis media. Eur Arch Otorhinolaryngol. 1996;253:445-449. [pmid: 8950543].
Parnes L S, Gagne J P, Hassan R. Cochlear implants and otitis media: considerations in two cleft palate patients. J Otolaryngol. 1993;22:345-348. [pmid: 8283503].
Parsons D S, Wald E R. Otitis media and sinusitis: similar diseases. Otolaryngol Clin North Am. 1996;29:11-25. [pmid: 8834269].
Parving A. Epidemiology of hearing loss and aetiological diagnosis of hearing impairment in childhood. Int J Pediatr Otorhinolaryngol. 1983;5:151-165. [pmid: 6874238].
Parving A. Aetiological diagnosis in hearing-impaired children--clinical value and application of a modern examination programme. Int J Pediatr Otorhinolaryngol. 1984;7:29-38. [pmid: 6539314].
Parving A, Christensen B. Children younger than 4 years of age, referred to an audiological department. Int J Pediatr Otorhinolaryngol. 1992;23:161-170. [pmid: 1563932].
Parving A, Hauch A M. The causes of profound hearing impairment in a school for the deaf - a longitudinal study. Br J Audiol. 1994;28:63-69. [pmid: 7841890].
Passali D, De Seta E, G C I, Bianchini Ciampoli M. Use of trace elements in the treatment of secretory otitis media: Preliminary results. Clin Ter. 1983;106:367-377. [pmid: 6685601].
Passali D, Zavattini G. Multicenter study on the treatment of secretory otitis media with ambroxol. Importance of a surface-tension-lowering substance. Respiration. 1987;51:52-59. [pmid: 3602599].
Passali D, Bellussi L. The pharmacological treatment of secretory otitis media with particular care to stimulation of surface-tension-lowering substances. Fernstrom Foundation Series. 1989;12.
Passali D. Hypertrophy of adenoids and tubal functionality. Adv Otorhinolaryngol. 1992;47:232-240. [pmid: 1456140].
Passali D, Fokkens W J, van Cauwenberge P, Ferrara A, Scadding G K. Allergy in children. Int J Pediatr Otorhinolaryngol. 1995;32:S81-S86. [pmid: 7665306].
Passali D, Bellussi L, De Lauretis A. Relapsing infective-phlogistic pathology of Waldeyer's ring and its relationship with secretory otitis media. Acta Oto-Laryngologica - Supplement. 1996;523:138-141.
Passali D, Bellussi L. Rationale for the use of a surfactant stimulating drug in the treatment of secretory otitis media. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:229–231.
Patel J, Chonmaitree T, Schmalstieg F. Effect of modulation of polymorphonuclear leukocyte migration with anti-CD18 antibody on pathogenesis of experimental otitis media in guinea pigs. Infect Immun. 1993;61:1132-1135. [pmcid: 302850]. [pmid: 8094380].
Patel J A, Reisner B, Vizirinia N, Owen M, Chonmaitree T, Howie V. Bacteriologic failure of amoxicillin-clavulanate in treatment of acute otitis media caused by nontypeable Haemophilus influenzae. J Pediatr. 1995;126:799-806. [pmid: 7752010].
Pathak I, Bryce G. Wegener's granulomatosis masquerading as mastoiditis and lateral-sinus thrombosis. J Otolaryngol. 1997;26:207-209. [pmid: 9176807].
Patterson M, Paparella M M. Otitis media with effusion and early sequelae. Otolaryngol Clin North Am. 1999 Jun;32:391-400. [pmid: 10393775].
Paul R, Lynn T F, Lohr-Flanders M. History of middle ear involvement and speech/language development in late talkers. J Speech Hear Res. 1993;36:1055-1062. [pmid: 8246471].
Paul A K, Rao A N, Ramesh G N, Kattikaran J, Sudha. Histiocytosis X presenting as chronic discharging ears [letter]. Indian Pediatr. 1995;32:501. [pmid: 8635821].
Paulman P M, Dirks B. Screening for middle ear fluid in a rural pre-school population. Nebr Med J. 1982;67:158-159.
Paulman P M, Halm D E. Screening for middle ear fluid in an urban pre-school population. Nebr Med J. 1984;69:307.
Pavlopoulou J, Leotsacos P, Sereti E, Anastasiou A, Syriopoulou V. Randomized controlled study of clarithromycin versus cefaclor suspensions in the treatment of acute otitis media in children. J Chemother. 1995:150–153.
Pearce P S, Saunders M A, Creighton D E, Sauve R S. Hearing and verbal-cognitive abilities in high-risk preterm infants prone to otitis media with effusion. J Dev Behav Pediatr. 1988;9:346-351. [pmid: 3220954].
Pearlman R C, Niles L A. The incidence of hearing disorders in the schoolchildren of Trinidad. Am J Otol. 1981;2:311-314. [pmid: 7258324].
Pearse P A, Bridges-Webb C. Otitis media in general practice [see comments]. Med J Aust. 1993;158:542-544. [pmid: 8487719].
Pearson B W. Symposium. ENT for nonspecialists. The ear: structure and function. Postgrad Med. 1975;57:50-54. [pmid: 1124255].
Pearson C R, Riden D K, Garth R J, Thomas M R. Two cases of lateral sinus thrombosis presenting with extracranial head and neck abscesses. J Laryngol Otol. 1994;108:779-782. [pmid: 7964144].
Pearson C R, Thomas M R, Cox H J, Garth R J. A cost-benefit analysis of the post-operative use of antibiotic ear drops following grommet insertion. J Laryngol Otol. 1996;12:87-90.
Pearson N, O'Brien J, Thomas H, Ewings P, Gallier L, Bussey A. Collecting morbidity data in general practice: the Somerset morbidity project [see comments]. Br Med J. 1996;312:1517-1520. [pmid: 8646146].
Peck J E. Hearing loss in Hunter's syndrome--mucopolysaccharidosis II. Ear Hear. 1984;5:243-246. [pmid: 6432613].
Pedersen M, Mygind N. Rhinitis, sinusitis and otitis media in Kartagener's syndrome (primary ciliary dyskinesia). Clin Otolaryngol Allied Sci. 1982;7:373-380. [pmid: 6984375].
Pedersen C B, Zachau-Christiansen B. Otitis media in Greenland children: acute, chronic and secretory otitis media in three- to eight-year-olds. J Otolaryngol. 1986;15:332-335. [pmid: 3806764].
Pedersen C B, Zachau-Christiansen B. Chronic otitis media and sequelae in the population of Greenland. Scand J Soc Med. 1988;16:15-19. [pmid: 3347822].
Peever M V, Ward J A. Successful assault on ear disease: intensive daily treatment by nurses and health workers. Med J Aust. 1980;1:1-4. [pmid: 7393020].
Pellett F S, Cox L C, MacDonald C B. Use of acoustic reflectometry in the detection of middle ear effusion. J Am Acad Audiol. 1997;8:181-187. [pmid: 9188075].
Pelton S I, Teele D W, Shurin P A, Klein J O. Disparate cultures of middle ear fluids. Results from children with bilateral otitis media. Am J Dis Child. 1980;134:951-953. [pmid: 6968508].
Pelton S I. Defining resistance: breakpoints and beyond implications for pediatric respiratory infection. Diagn Microbiol Infect Dis. 1996;25:195-199. [pmid: 8937844].
Pelton SI. New concepts in the pathophysiology and management of middle ear disease in childhood. Drugs. 1996;52:62–66; discussion 66–67.
Peng J C, Hoppe F. [Is reuse of autologous ear ossicles in cholesteatoma or chronic suppurative otitis media justified?]. Laryngorhinootologie. 1994;73:375-380. [pmid: 7916783].
Pensak M L, Glasscock M Ed, Gulya A J, Hays J W, Smith H P, Dickens J R. Cerebellopontine angle lipomas. Arch Otolaryngol Head Neck Surg. 1986;112:99-101. [pmid: 3484424].
Per-Lee J H. Long-term middle ear ventilation. Laryngoscope. 1981;91:1063-1073. [pmid: 7242199].
Perez de Tagle J R, Fenton J E, Fagan P A. Mastoid surgery in the only hearing ear. Laryngoscope. 1996;106:67-70. [pmid: 8544631].
Perez Martin J. [Serous otitis media and allergy in children (editorial)]. Rev Alerg Mex. 1995;42:79-80. [pmid: 8581448].
Perez Obon J, Fernandez Liesa R, Marin Garcia J, et al. [Cerebral abscess as a complication of the chronic otitis]. Acta Otorrinolaringol Esp. 1994;45:107-110. [pmid: 8086201].
Perez Obon J, Marin G, Fernandez Liesa R, et al. [Report of a case of pneumocephalus secondary to otologic surgery]. Acta Otorrinolaringol Esp. 1995;46:223-226. [pmid: 7619560].
Perez-Carmona N J, Garcia M A, Fuentes-Rejon T. [Serous otitis media. Comparative study of carbinoxamine- pseudoephedrine vs astemizole-pseudoephedrine]. Rev-Alerg-Mex. 1997;44:70-73. [pmid: 9377115].
Perkins R. Tympanomastoid reconstruction: an operative procedure for anatomical and functional restoration of the radicalized ear. Laryngoscope. 1976;86:416-430. [pmid: 768667].
Perriello VA, Ford RF, McLean WC, Schoeny ZG, Sande MA. Otitis media: a review. Virginia Medical. 1977;104:319–320, 325–328.
Perrin J M, Charney E, MacWhinney J B Jr, McInerny T K, Miller R L, Nazarian L F. Sulfisoxazole as chemoprophylaxis for recurrent otitis media. A double-blind crossover study in pediatric practice. N Engl J Med. 1974;291:664-667. [pmid: 4153093].
Perrin P, Perrin C, Boulange M. Seromucous otitis: Physiopathology and role of impedance measurement. Presse Thermale et Climatique. 1988;125:10-12.
Perry B P, Zieno S A, Yonkers A J, Moore G F. Outcome-oriented managed care comparing efficacies of cefaclor and amoxicillin in acute and recurrent acute otitis media. Ear Nose Throat J. 1995;74:840-844. [pmid: 8556984].
Persico M, Podoshin L, Fradis M, et al. Recurrent acute otitis media--prophylactic penicillin treatment: a prospective study. Part I. Int J Pediatr Otorhinolaryngol. 1985;10:37-46. [pmid: 3935589].
Persico M, Barker G A, Mitchell D P. Purulent otitis media--a “silent” source of sepsis in the pediatric intensive care unit. Otolaryngol Head Neck Surg. 1985;93:330-334. [pmid: 3927226].
Pestalozza G, Cusmano G. Evaluation of tympanometry in diagnosis and treatment of otitis media of the newborn and of the infant. Int J Pediatr Otorhinolaryngol. 1980;2:73-82. [pmid: 7188056].
Pestalozza G, Cusmano G, Tessitore E, Bonelli A. Transtympanic drains in the treatment of serous otitis in children; anatomical versus functional long term results. Int J Pediatr Otorhinolaryngol. 1983;5:31-38. [pmid: 6682411].
Pestalozza G Cioce C Romagnoli M Otitis media in newborns: Long-term follow-up, bacteriologic and cytologic investigations. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984.
Pestalozza G, Cioce C, Facchini M. Azithromycin in upper respiratory tract infections: a clinical trial in children with otitis media. Scan-J Infect Dis-Suppl. 1992:22–25.
Peters S A, Grievink E H, van Bon W H, Schilder A G. The effects of early bilateral otitis media with effusion on educational attainment: a prospective cohort study. Journal of Learning Disabilities. 1994;27:111-121. [pmid: 8195687].
Peters S A, Grievink E H, van Bon W H, van den Bercken J H, Schilder A G. The contribution of risk factors to the effect of early otitis media with effusion on later language, reading, and spelling [see comments]. Dev Med Child Neurol. 1997;39:31-39. [pmid: 9003727].
Peterson M K. Impedance audiometry and the brain-damaged child. Dev Med Child Neurol. 1978;20:800-802. [pmid: 729934].
Petinou K, Mody M, Schwartz RD, Gravel JS, Ellis MA, Lee WW. Impact of otitis media on early speech development: phonetic inventories. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:408–410.
Petinou K, Schwartz R G, Mody M, Gravel J S. The impact of otitis media with effusion on early phonetic inventories: A longitudinal prospective investigation. Clinical Linguistics and Phonetics. 1999;13:351-367.
Pettigrew A M. Histopathology of the temporal bone after open mastoid surgery. Clin Otolaryngol Allied Sci. 1980;5:227-234. [pmid: 7408223].
Pfaltz C R, Griesemer C. Complications of acute middle ear infections. Ann Otol Rhinol Laryngol Suppl. 1984;112:133-137. [pmid: 6431873].
Pfurtscheller G. Physiological reality of EEG spectral estimates. pp. 98–101. In: Dolce G, Kunkel H, ed. CEAN: computerized EEG analysis. Stuttgart, Fischer. 1975;150.
Phelps P D. Preservation of hearing in the labyrinth invaded by cholesteatoma. J Laryngol Otol. 1969;83:1111-1114. [pmid: 5379692].
Phelps P D, Lloyd G A. The radiology of carcinoma of the ear. Br J Radiol. 1981;54:103-109. [pmid: 6257318].
Phillips M J, Knight N J, Manning H, Abbott A L, Tripp W G. IgE and secretory otitis media. Lancet. 1974;2:1176-1178. [pmid: 4139593].
Phillips S G, Miyamoto R T. Congenital conductive hearing loss in Apert syndrome. Otolaryngol Head Neck Surg. 1986;95:429-433. [pmid: 3106904].
Phillips D E, Maw A R, Harvey K. The nasopharynx and adenoid in children with glue ear compared with normal controls. Clin Otolaryngol Allied Sci. 1987;12:255-260. [pmid: 3665134].
Phillips D E, Bates G J, Parker A J, Griffiths M V, Green J. Digital and mirror assessment of the adenoids at operation. Clin Otolaryngol Allied Sci. 1989;14:131-133. [pmid: 2721013].
Piasecki K, Wysocki J. Mastoid emissary in Indian skulls. Folia Morphologica (Warszawa). 1998;57:269-274.
Pichichero M E, Berghash L R, Hengerer A S. Anatomic and audiologic sequelae after tympanostomy tube insertion or prolonged antibiotic therapy for otitis media [see comments]. Pediatr Infect Dis J. 1989;8:780-787. [pmid: 2594453].
Pichichero M E, Berghash L R, Hengerer A S. Anatomic and audiologic sequelae after tympanostomy tube insertion or prolonged antibiotic therapy for otitis media. Pediatr Infect Dis J. 1989;8:780-787. [pmid: 2594453].
Pichichero M, Aronovitz G H, Gooch W M, et al. Comparison of cefuroxime axetil, cefaclor, and amoxicillin-clavulanate potassium suspensions in acute otitis media in infants and children. South-Med-J. 1990;83:1174-1177. [pmid: 2218657].
Pichichero M E. Sequelae of tympanostomy tubes (I: Reply). Pediatr Infect Dis J. 1990;9:527-528. [pmid: 2371088].
Pichichero ME. Assessing the treatment alternatives for acute otitis media [published erratum appears in Pediatr Infect Dis J 1994 Jun;13(6):488]. Pediatr Infect Dis J. 1994;13:S27–S34; discussion S50–S54.
Pichichero M E, Pichichero C L. Persistent acute otitis media: II. Antimicrobial treatment [see comments]. Pediatr Infect Dis J. 1995;14:183-188. [pmid: 7761182].
Pichichero M E, Pichichero C L. Persistent acute otitis media: I. Causative pathogens. Pediatr Infect Dis J. 1995;14:178-183. [pmid: 7761181].
Pichichero M E, McLinn S, Aronovitz G, et al. Cefprozil treatment of persistent and recurrent acute otitis media. Pediatr Infect Dis J. 1997;16:471-478. [pmid: 9154539].
Pichichero M E, Cohen R. Shortened course of antibiotic therapy for acute otitis media, sinusitis and tonsillopharyngitis. Pediatr Infect Dis J. 1997;16:680-695. [pmid: 9239773].
Pickett BP, Shinn JB, Smith MF. Ear drop ototoxicity: reality or myth? Am J Otol. 1997;18:782–789; discussion 789–791.
Pignataro O, Pignataro L D, Gallus G, Calori G, Cordaro C I. Otitis media with effusion and S-carboxymethylcysteine and/or its lysine salt: a critical overview. Int J Pediatr Otorhinolaryngol. 1996;35:231-241. [pmid: 8762596].
Piippo T, Stefansson S, Pitkajarvi T, Lundberg C. Double-blind comparison of cefixime and cefaclor in the treatment of acute otitis media in children. Scand-J Infect Dis. 1991;23:459-465. [pmid: 1957129].
Piletta P A, Calza A M, Masouye I, Harms M, Saurat J H. Hypohidrotic ectodermal dysplasia with recurrent otitis and sebaceous gland hypertrophy of the face. Dermatology. 1995;191:355-358. [pmid: 8573945].
Pillsbury H Cd, Arenberg I K, Ferraro J, Ackley R S. Endolymphatic sac surgery. The Danish sham surgery study: an alternative analysis. Otolaryngol Clin North Am. 1983;16:123-127. [pmid: 6856298].
Pillsbury H C, Grose J H, Hall J Wd. Otitis media with effusion in children. Binaural hearing before and after corrective surgery. Arch Otolaryngol Head Neck Surg. 1991;117:718-723. [pmid: 1863436].
Pinto S L, Mejia G V, Smoler J, Ortega I. Differential factors of otitis media in children and adults. Laryngoscope. 1968;78:441-450. [pmid: 5642498].
Pinto S L, Smoler J, Vivar G, Ortega I. What do you mean by otitis media?. Laryngoscope. 1969;79:1891-1901. [pmid: 5361620].
Pirodda A. How a labyrinthine fistula may sometimes be useful for surgery. Ear Nose Throat J. 1995;74:170-172. [pmid: 7729341].
Piskorski P, Keefe D H, Simmons J L, Gorga M P. Prediction of conductive hearing loss based on acoustic ear-canal response using a multivariate clinical decision theory. J Acoust Soc Am. 1999;105:1749-1764. [pmid: 10089599].
Pit S, Jamal F, Cheah F K. Microbiology of cerebral abscess: a four-year study in Malaysia. Journal of Tropical Medicine and Hygiene. 1993;96:191-196. [pmid: 8505776].
Pitkaranta A, Hovi T, Karma P. Interferon production by leukocytes in children with otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1996;34:25-33. [pmid: 8770670].
Pitkaranta A, Virolainen A, Jero J, Arruda E, Hayden F G. Detection of rhinovirus, respiratory syncytial virus, and coronavirus infections in acute otitis media by reverse transcriptase polymerase chain reaction [see comments]. Pediatrics. 1998;102:291-295. [pmid: 9685428].
Pitts N E, Gilbert G S, Knirsch A K, Noguchi Y. Worldwide clinical experience with sultamicillin. APMIS. Supplementum. 1989;97:23-34. [pmid: 2660868].
Plana B M, Canet J M S, Cencillo C P, Solanes J B, Algarra J M, Mallea J C. Secretory otitis media in six-year-old children. Revista Espanola de Pediatria. 1997;53:436-440.
Platonov A E, Wurzner R, Beloborodov B, et al. Paradoxical reconstitution of complement activity following plasma transfusion of an individual with deficiency of the seventh component of complement. Immunology. 1994;81:142-148. [pmid: 8132211]. [pmcid: 1422279].
Plemmons R M, McAllister C K, Liening D A, Garces M C. Otitis media and mastoiditis due to Mycobacterium fortuitum: case report, review of four cases, and a cautionary note. Clin Infect Dis. 1996;22:1105-1106. [pmid: 8783722].
Plester D. Surgical treatment of Meniere's disease. Proceedings of the Royal Society of Medicine. 1967;60:964-966. [pmid: 6057976]. [pmcid: 1901502].
Plester D, Pusalkar A, Steinbach E. Middle ear tuberculosis. J Laryngol Otol. 1980;94:1415-1421. [pmid: 7441053].
Plinkert P K, Ptok M. Influence of eustachian tube dysfunction on transiently evoked and distortion product otoacoustic emissions. HNO. 1994;42:434-440. [pmid: 7928435].
Plinkert P K, Ptok M. [Changes in transitory evoked otoacoustic emissions and acoustic distortion products in disorders of eustachian tube ventilation]. HNO. 1994;42:434-440. [pmid: 7928435].
Plinkert P K. [Pathological changes in the middle ear and delayed speech development. Preventable sequelae of disordered tube function and seromucotympanum]. HNO. 1995;43:53-57. [pmid: 7713765].
Pluzhnikov MS, Lopotko AI. [Low-intensity laser irradiation in otorhinolaryngology]. Vestn Otorinolaringol 1996:5–14.
Podoshin L, Fradis M, Ben David J. Ototoxicity of ear drops in patients suffering from chronic otitis media. J Laryngol Otol. 1989;103:46-50. [pmid: 2537872].
Podoshin L, Fradis M, Ben-David Y, Faraggi D. The efficacy of oral steroids in the treatment of persistent otitis media with effusion [see comments]. Arch Otolaryngol Head Neck Surg. 1990;116:1404-1406. [pmid: 2248740].
Podoshin L, Fradis M, Ben-David Y, Faraggi D. The efficacy of oral steroids in the treatment of persistent otitis media with effusion. Arch Otolaryngol Head and Neck Surgery. 1990;116:1404-1406.
Podoshin L, Fradis M, Ben-David Y, Bashara L, Malatskey S. [Chronic otitis media]. Harefuah 1995;129:238–242, 295.
Podoshin L, Fradis M, Ben-David J, Malatskey S. Results of surgery for chronic otitis media: a 5–year study. Rev Laryngol Otol Rhinol. 1995;116:109-113.
Podoshin L, Brodzki A, Fradis M, Ben David J, Larboni J, Srugo I. [Local treatment of purulent chronic otitis media with ciprofloxacin]. Harefuah 1998;134:32–36, 78.
Podvinec M. [Co-tetroxazin (Tibirox) and doxycycline (Vibramycin) in treatment of upper respiratory tract infections: a double-blind study]. Ther-Umsch. 1982;39:815-820. [pmid: 6760445].
Poehlman G S. Chronic otitis media with effusion. Prim Care. 1996;23:687-699. [pmid: 8890139].
Poliakova TS, Magomedov MM, Al-Sagir MK. [Dimethyl sulfoxide in the treatment of patients with inflammatory diseases of external and middle ear]. Vestn Otorinolaringol. 1993:47–49.
Politzer A. A Text-Book of the Diseases of the Ear for Students and Practioners 5 ed. London: Bailliere, Tindall & Cox; 1909.
Pollazzon P, Narne S, Guariso G. The importance of acoustic impedance measurements in middle ear pathology during acute viral respiratory illness in the first year of life. Int J Pediatr Otorhinolaryngol. 1981;3:319-325. [pmid: 7327848].
Ponsioen B P. [Antibiotics in otitis media with effusion (letter; comment)]. Ned Tijdschr Geneeskd. 1997;141:702. [pmid: 9198775].
Ponte C, Cenjor C, Parra A, et al. Antimicrobial treatment of an experimental otitis media caused by a beta-lactamase positive isolate of Haemophilus influenzae. J Antimicrob Chemother. 1999;44:85-90. [pmid: 10459814].
Poole M D. Treatment of otorrhea associated with tubes or perforations. Ear Nose Throat J. 1993;72:225-226. [pmid: 8482269].
Poole M D. It's time to bring back diagnostic tympanocentesis [see comments]. Ear Nose Throat J. 1994;73:49-50. [pmid: 8162874].
Poole M D. Otitis media complications and treatment failures: Implications of pneumococcal resistance. Pediatr Infect Dis J. 1995;14:S23-S26. [pmid: 7792127].
Popova AE, Anisimova TI, Naumov AV, Khoroshevich EG, Loginova BN. [The use of pilastin for treating patients with chronic suppurative otitis media]. Vestn Otorinolaringol. 1996:42–43.
Porter T A. Otoadmittance measurements in a residential deaf population. American Annals of the Deaf (Silver Spring, MD). 1974;119:47-52.
Portmann M. “Open” or “closed” technique in surgery of the middle ear. Ann Otol Rhinol Laryngol. 1968;77:927-937. [pmid: 4878625].
Portmann M. Principles of management for sequelae of otitis. Journal of Laryngology and Otology - Supplement. 1983;8:68-70.
Portmann M, Portmann D, Rohou S, et al. [Efficacy and tolerability of morniflumate in acute otitis in infants: results of a randomized study versus placebos]. Rev-Laryngol-Otol-Rhinol-Bord. 1990;111:507-510. [pmid: 2087618].
Portmann M, Darrouzet V. Use of the MUSCO NT3 tympanic isopressor in tubal dysfunction. Study of 30 cases. Rev Laryngol Otol Rhinol. 1990;111:177-179.
Portoian-Shuhaiber S, Cullinan T R. Middle ear disease assessed by impedance in primary school children in south London. Lancet. 1984;1:1111-1112. [pmid: 6144838].
Post J C, Preston R A, Aul J J, et al. Molecular analysis of bacterial pathogens in otitis media with effusion [see comments]. JAMA. 1995;273:1598-1604. [pmid: 7745773].
Post J C, Aul J J, White G J, et al. PCR-based detection of bacterial DNA after antimicrobial treatment is indicative of persistent, viable bacteria in the chinchilla model of otitis media. Am J Otolaryngol. 1996;17:106-111. [pmid: 8820185].
Potsic W P, Cohen M, Winchester R, Whitaker L. The types of hearing loss and ear pathology noted in screening craniofacial patients. Cleft Palate Journal. 1979;16:164-166. [pmid: 284864].
Potsic W P, Winawer M R, Marsh R R. Tympanoplasty for the anterior-superior perforation in children. Am J Otol. 1996;17:115-118. [pmid: 8694113].
Poulsen G, Tos M. Tubal function in chronic secretory otitis media in children. ORL J Otorhinolaryngol Relat Spec. 1977;39:57-67. [pmid: 561933].
Poulsen G, Tos M. Screening tympanometry in newborn infants and during the first six months of life. Scand Audiol. 1978;7:159-166. [pmid: 756080].
Poulsen G, Tos M. Repetitive tympanometric screenings of two-year-old children. Scand Audiol. 1980;9:21-28. [pmid: 7192429].
Povedano-Rodriguez V, Seco-Pinero M J, Jurado-Ramos A, Lopez-Villarejo P. [Efficacy of topical ciprofloxacin in the treatment of chronic otorrhea]. Acta-Otorrinolaringol-Esp. 1995;46:15-18. [pmid: 7734157].
Powell R H, Burrell S P, Cooper H R, Proops D W. The Birmingham bone anchored hearing aid programme: paediatric experience and results. Journal of Laryngology and Otology - Supplement. 1996;21:21-29.
Pownell P H, Wright C G, Robinson K S, Meyerhoff W L. The effect of cyclophosphamide on development of experimental cholesteatoma. Arch Otolaryngol Head Neck Surg. 1994;120:1114-1116. [pmid: 7917193].
Poyner T F, Dass B K. Comparative efficacy and tolerability of fusidic acid/hydrocortisone cream (Fucidinregistered trade mark H cream) and miconazole /hydrocortisone cream (Daktacortregistered trade mark cream) in infected eczema. J Eur Acad Dermatology Venereology. 1996;7(Suppl1):S23-S29.
Prado S, Paparella M M. Sensorineural hearing loss secondary to bacterial infection. Otolaryngol Clin North Am. 1978;11:40-41. [pmid: 662353].
Prasansuk S, Hinchcliffe R. Tympanic membrane perforation descriptors and hearing levels in otitis media. Audiology. 1982;21:43-51. [pmid: 7055479].
Pratt L W. Nonsuppurative otitis media. Journal of the Maine Medical Association. 1966;57:31-33. [pmid: 5903464].
Pratt L L, Murray J. The placement of middle ear ventilation tubes: some indications and complications. Laryngoscope. 1973;83:1022-1026. [pmid: 4719353].
Pratt L L. Complications associated with the surgical treatment of cholesteatoma. Laryngoscope. 1983;93:289-291. [pmid: 6834952].
Prellner K, Rydell R. Acute mastoiditis. Influence of antibiotic treatment on the bacterial spectrum. Acta Otolaryngol. 1986;102:52-56. [pmid: 3739692].
Prellner K, Brorsson B. [Consensus on otitis. Answers to an inquiry show changed therapeutic practices]. Lakartidningen. 1993;90:1584-1586. [pmid: 8483361].
Prellner K, Fogle-Hansson M, Jorgensen F, Kalm O, Kamme C. Prevention of recurrent acute otitis media in otitis-prone children by intermittent prophylaxis with penicillin. Acta-Otolaryngol-Stockh. 1994;114:182-187. [pmid: 8203201].
Prellner K. Clinical aspects on antibiotic resistance: upper respiratory tract infections. Microb Drug Resist. 1995;1:143-147. [pmid: 9158748].
Prellner K, Kahlmeter G, Marchisio P, van Cauwenberge P B. Microbiology of acute otitis media and therapeutic consequences. Int J Pediatr Otorhinolaryngol. 1995;32:S145-S156. [pmid: 7665284].
Premachandra D J, Woodward B, Milton C M, Sergeant R J, Fabre J W. Long-term results of mastoid cavities grafted with cultured epithelium prepared from autologus epidermal cells to prevent chronic otorrhea. Laryngoscope. 1993;103:1121-1125. [pmid: 8412448].
Prescott C A, Robartes W J. Tympanoplasty surgery at the Red Cross War Memorial Children's Hospital 1986-1988. Int J Pediatr Otorhinolaryngol. 1991;21:227-234. [pmid: 1869376].
Presswood G, Zamboni W A, Stephenson L L, Santos P M. Effect of artificial airway on ear complications from hyperbaric oxygen. Laryngoscope. 1994;104:1383-1384. [pmid: 7968168].
Preston G. Hearing health needs for aboriginal and Torres Strait Islander people. Aust Fam Physician. 1994;23:51-53. [pmid: 8141683].
Preston D Y. Chronic suppurative otitis media without cholesteatoma management. ORL - Head and Neck Nursing. 1995;13:17-22. [pmid: 8630764].
Principi N, Marchisio P, Bigalli L, Massironi E. Amoxicillin twice daily in the treatment of acute otitis media in infants and children. Eur J Pediatr. 1986;145:522-525. [pmid: 3545844].
Principi N, Marchisio P, Massironi E, Grasso RM, Filiberti G. Prophylaxis of recurrent acute otitis media and middle-ear effusion. Comparison of amoxicillin with sulfamethoxazole and trimethoprim [published erratum appears in Am J Dis Child 1990 Nov;144(11):1180]. Am-J-Dis-Child. 1989;143:1414–1418.
Principi N, Marchisio P. Cefixime vs amoxicillin in the treatment of acute otitis media in infants and children. Drugs. 1991:25–29.
Principi N. Multicentre comparative study of the efficacy and safety of azithromycin compared with amoxicillin/clavulanic acid in the treatment of paediatric patients with otitis media. Eur J Clin Microbiol Infect Dis. 1995;14:669-676. [pmid: 8565983].
Pringle M B, Thompson A, Reddy K. A comparison of speech audiometry and pure tone audiometry in patients with secretory otitis media. J Laryngol Otol. 1993;107:787-789. [pmid: 8228591].
Pringle M B. Grommets, swimming and otorrhoea--a review. J Laryngol Otol. 1993;107:190-194. [pmid: 8509692].
Prior A J. Facial palsy caused by otitis media with effusion: the pathophysiology discussed. ORL J Otorhinolaryngol Relat Spec. 1995;57:348-350. [pmid: 8789487].
Probst R. The nasopharyngeal bacterial flora in children with otitis media with effusion. Eur Arch Otorhinolaryngol (1996) 253:260–263 [letter; comment]. Eur Arch Otorhinolaryngol. 1997;254:19.
Proctor L R, Kennedy D W. High-risk newborns who fail hearing screenign: implications of otological problems. Seminars in Hearing. 1990;11:167-176.
Proschel U, Eysholdt U. Evoked otoacoustic emissions in children in relation to middle ear impedance. Folia Phoniatrica. 1993;45:288-294. [pmid: 8253453].
Ptok M. Conservative therapy, rehabilitation and early therapeutical promotion of auditory defects in early childhood. Fortschritt und Fortbildung in der Medizin. 1997;21.
Puczynski MS, Stankiewicz JA, Cunningham DG, Mortimer JC. Follow-up visit after acute otitis media. Br J Clin Pract. 1985;39.
Puczynski M S, Stankiewicz J A, O'Keefe J P. Single dose amoxicillin treatment of acute otitis media. Laryngoscope. 1987;97:16-18. [pmid: 3796171].
Pugliese W M, Mesches D N, Wiersum J, Henriquez C L 3rd, Krivda J F. Double-blind study: Cleocin Palmitate and Erythrocin Pediatric in otitis media in children. Curr-Ther-Res-Clin-Exp. 1972;14:31-34. [pmid: 4621563].
Puhakka H, Haapaniemi J, Tuohimaa P, Ruuskanen O, Eskola J. Peroral prednisolone in the treatment of middle-ear effusion in children: a double-blind study. Auris-Nasus-Larynx. 1985:S268–S271.
Puhakka H J, Haapaniemi J, Tuohimaa P, Bondesson G. Clinical efficacy and tolerance of bacampicillin and amoxycillin suspensions in children with acute otitis media. J Int Med Res. 1989;17:41-47. [pmid: 2651176].
Pukander JS, Karma PH. Persistence of Middle Ear Effusion and Its Risk Factors After an Acute Attack of Otitis Media with Effusion. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:8–11.
Pukander JS, Paloheimo SH, Sipila MM. Cefetamet pivoxil in pediatric otitis media. Chemotherapy. 1992:25–28.
Pukander JS, Sipila MM, MJ K, PH K. The Bayesian approach to the evaluation of risk factors affecting the prolongation of middle ear effusion after acute otitis media. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:33–35.
Pukander JS, Paloheimo SH. Cefetamet pivoxil syrup in the treatmetn of acute otitis media in children. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:248–251.
Pukander JS, Jero JP, Kaprio EA, Sorri MJ. Clarithromycin vs. amoxicillin suspensions in the treatment of pediatric patients with acute otitis media. Pediatr Infect Dis J. 1993;12:S118–S121.
Pukander J, Rautianen M. Penetration of azithromycin into middle ear effusions in acute and secretory otitis media in children. J Antimicrob Chemother. 1996;37:53-61. [pmid: 8818846].
Pulec J L, Kamio T, Graham M D. Eustachian tube lymphatics. Ann Otol Rhinol Laryngol. 1975;84:483-492. [pmid: 50760].
Pulec J L. Surgically treatable sensorineural hearing loss. Postgrad Med. 1977;62:121-130. [pmid: 302941].
Pulec J L. Serous otitis media. Ear Nose Throat J. 1993;72:193. [pmid: 8482260].
Pulec J L, Deguine C. Secretory otitis media (glue ear). Ear Nose Throat J. 1993;72:254. [pmid: 8486102].
Pulec J L. Training in tympanoplasty [editorial]. Ear Nose Throat J. 1993;72:188. [pmid: 8482259].
Pulec JL. Facial nerve neuroma. Ear Nose Throat J. 1994;73:721–722, 725–739, 743–752.
Pulec J L. Tonsillectomy for serous otitis media [editorial]. Ear Nose Throat J. 1994;73:359. [pmid: 8076531].
Pulec J L, Deguine C. Short incus and posterior perforation healed with a retracted neomembrane. Ear Nose Throat J. 1994;73:71. [pmid: 8168447].
Pulec J L. Allergy: a commonly neglected etiology of serous otitis media [editorial; comment]. Ear Nose Throat J. 1995;74:739. [pmid: 8536557].
Pulec J L. Hearing results in tympanoplasty [editorial]. Ear Nose Throat J. 1995;74:147. [pmid: 7729334].
Pulec JL. The appropriateness of tympanostomy tubes for children [letter; comment]. JAMA. 1995;273:700; discussion 700–701.
Pulec J L. Labyrinthine fistula from cholesteatoma: surgical management. Ear Nose Throat J. 1996;75:143-148. [pmid: 8721018].
Pulec J L, DeGuine C. Blue ear drum. Ear Nose Throat J. 1996;75:124. [pmid: 8721012].
Pulec J L, DeGuine C. Extensive cholesterol granuloma. Ear Nose Throat J. 1996;75:272. [pmid: 8935522].
Pulec J L, Deguine C. Classification of chronic suppurative otitis media: type III. Ear Nose Throat J. 1996;75:576. [pmid: 8870360].
Pulec J L, DeGuine C. Classification of chronic suppurative otitis media: type I. Ear Nose Throat J. 1996;75:400. [pmid: 8764696].
Pulec J L, Deguine C. Atelectasis and chronic suppurative otitis media. Ear Nose Throat J. 1997;76:290. [pmid: 9170708].
Pulec J L, Deguine C. Attic cholesteatoma with facial palsy. Ear Nose Throat J. 1997;76:68. [pmid: 9046690].
Pulec J L, Deguine C. Attic cholesteatoma producing a natural modified radical mastoidectomy. Ear Nose Throat J. 1998;77:10. [pmid: 9473825].
Pyman C. Current management of chronic suppurative otitis media. Med J Aust. 1968;2:1033-1037. [pmid: 5727857].
Pyman B C, Clark G M. Anatomic and surgical considerations in the design of a new receiver-stimulator suitable for implantation in young children. Ann Otol Rhinol Laryngol Suppl. 1995;166:428-430. [pmid: 7668737].
Quaranta A, Cassano P, Cervellera G. Clinical value of the tonal masking level difference. Audiology. 1978;17:232-238. [pmid: 666658].
Quaranta A, Salonna I. Oto-audiologic evaluation in children with recurrent otitis media. Otorinolaringologia Pediatrica. 1990;1:83-87.
Quaranta A, Bartoli R, Lozupone E, Resta L, Iurato S. Cholesteatoma in children: histopathologic findings in middle ear ossicles. ORL J Otorhinolaryngol Relat Spec. 1995;57:296-298. [pmid: 8587786].
Quaranta A, Onofri M, Sallustio V, Iurato S. Comparison of long-term hearing results after vestibular neurectomy, endolymphatic mastoid shunt, and medical therapy. Am J Otol. 1997;18:444-448. [pmid: 9233483].
Quevedo A, Sossouhounto R, Kissling M. Cefetamet pivoxil in otitis media. ORL-J-Otorhinolaryngol-Relat-Spec. 1993;55:93-96. [pmid: 8446394].
Quick CA, Wagner D. Trimethoprim-sulfamethoxazole in the treatment of infections of the ears, nose, and throat. J Infect Dis. 1973:Suppl:696–700.
Quick C A. Comparison of penicillin and trimethoprim-sulfamethoxazole in the treatment of ear, nose and throat infections. Can-Med-Assoc-J. 1975;112:83-86. [pmid: 805651].
Quinn S M. Aboriginal hearing loss and ear disease in the Australian Northern Territory. Australian Journal of Audiology. 1983;5:41-44.
Quinn M K. Otitis media: a personal perspective from a son [letter; comment]. Am Fam Physician. 1996;54:1212, 1216. [pmid: 8816567].
Qvarnberg Y, Holopainen E, Palva T. Aspiration cytology in acute otitis media. Acta Otolaryngol. 1984;97:443-449. [pmid: 6464702].
Qvarnberg YH, Sipila PT, Thoroddsen SE. Efficacy and safety of lorocarbef versus amoxicillin in the treatment of bacterial acute otitis media with effusion. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:252–254.
Qvarnberg Y, Valtonen H. Bacteria in middle ear effusions in children treated with tympanostomy; a 10-year series. Acta Otolaryngol. 1995;115:653-657. [pmid: 8928638].
Rach G H, Zielhuis G A, van d e n B r o e k P. The influence of chronic persistent otitis media with effusion on language development of 2- to 4-year-olds. Int J Pediatr Otorhinolaryngol. 1988;15:253-261. [pmid: 3192363].
Rach GH, Zielhuis GA, Van Den Broek P. Effect of Otitis Media with Effusion on Language Development of Preschool Children: Preliminary Results of a Controlled Randomized Longitudinal Study. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:391–393.
Rach G H, Zielhuis G A, van B a a r l e P W, van d e n B r o e k P. The effect of treatment with ventilating tubes on language development in preschool children with otitis media with effusion. Clin-Otolaryngol. 1991;16:128-132. [pmid: 2070526].
Raffin B, Lacher G, Devars F, Benassayag C, Boudard P, Traissac L. Anatomical and surgical particularities of cholesteatomas in children. Arch Otorhinolaryngol. 1989;246:271-273. [pmid: 2590033].
Ragheb S M, Gantz B J, McCabe B F. Hearing results after cholesteatoma surgery: the Iowa experience. Laryngoscope. 1987;97:1254-1263. [pmid: 3669835].
Raghuram J, Ong Y Y, Wong S Y. Tetanus in Singapore: report of three cases. Ann Acad Med Singapore. 1995;24:869-873. [pmid: 8838999].
Rahko T, Koivikko A, Silvonniemi P. The occurrence of secretory otitis media in allergic children. Clin Otolaryngol Allied Sci. 1979;4:267-270. [pmid: 476991].
Rahko T, Karma P, Sipila M. Sensorineural hearing loss and acute otitis media in children. Acta Otolaryngol. 1989;108:107-112. [pmid: 2763829].
Rahko T, Laitila P, Sipila M, Manninen M, Karma P. Hearing and acute otitis media in 13-year-old children. Acta Otolaryngol. 1995;115:190-192. [pmid: 7610802].
Raigal M a r t i n M Y, Minue L o r e n z o C, Calvo C o r b e l l a E, de l a C o r t e G a r c i a M. [Amoxicillin: choice in the treatment of acute otitis media (letter)]. Aten Primaria. 1995;16:293-294.
Raine C H, Singh S D. Tympanoplasty in children. A review of 114 cases. J Laryngol Otol. 1983;97:217-221. [pmid: 6833846].
Raine N M, Whittet H B. Emla cream and induced vertigo [letter; comment]. Br J Hosp Med. 1994;51:614-615. [pmid: 7952755].
Rakover Y, Shneyour A, Rosen G, Lensky Y. Comparison of the proteins of middle ear effusion with human mast cell proteins. J Laryngol Otol. 1995;109:1146-1150. [pmid: 8551143].
Rakover Y, Keywan K, Rosen G. Safety of topical ear drops containing ototoxic antibiotics. J Otolaryngol. 1997;26:194-196. [pmid: 9176804].
Ralph J C. The case for the tympanometer in private practice. Pediatr Infect Dis. 1982;1:2-3. [pmid: 7177891].
Ramages L J, Gertler R. Aural tuberculosis: a series of 25 patients. J Laryngol Otol. 1985;99:1073-1080. [pmid: 4056591].
Raman R. Should cotton buds be banned? [letter]. Trop Doct. 1997;27:250.
Raman R. Cotton-wick method for better drainage of middle ear [letter]. Trop Doct. 1997;27:191-192. [pmid: 9227034].
Ramanikanth T V, Smith M C, Ramamoorthy R, Ramalingam K K. Postauricular cerebellar encephalocoele secondary to chronic suppurative otitis media and mastoid surgery. J Laryngol Otol. 1990;104:982-985. [pmid: 2280157].
Rambo J H. Musculoplasty: advantages and disadvantages. Transactions - American Otological Society. 1965;53:164-188.
Rambo J H. Musculoplasty for restoration of hearing in chronic suppurative ears. Arch Otolaryngol. 1969;89:184-190. [pmid: 5782674].
Ramet J. A safety and efficacy comparative study of clarithromycin and amoxillin/clavulanate suspensions in the short course treatment of children with acute otitis media. Acta Therapeutica. 1995;21:231-241.
Ramet J, Casneuf J, Demay M, et al. Comparative safety and efficacy of clarithromycin and azithromycin suspensions in the short course treatment of children with acute otitis media. Clinical Drug Investigation. 1995;9:61-66.
Ramirez-Camacho R A, Jimenez D. Comparative study in tympanoplasties with nitrous oxide anesthesia. Laryngoscope. 1984;94:220-222. [pmid: 6694496].
Ramirez-Camacho R, Corcuera M T, Gomez-Aguado F, Garcia B e r r o c a l J R, Pinilla M. [Imaging analysis by computer tomography in chronic middle ear otitis diagnosis]. An Otorrinolaringol Ibero Am. 1996;23:375-382. [pmid: 8967559].
Rampelberg O, Gerard J M, Namias B, Gerard M. ENT manifestations of relapsing polychondritis. Acta Otorhinolaryngol Belg. 1997;51:73-77. [pmid: 9241371].
Ramsden R T, Moffat D A, Gibson W P, Jay M M. S-carboxymethylcysteine in the treatment of glue ear: a double blind trial. J Laryngol Otol. 1977;91:847-851. [pmid: 336818].
Ramsey BW, Marcuse EK, Foy HM, et al. Use of bacterial antigen detection in the diagnosis of pediatric lower respiratory tract infections. Pediatrics. 1986;78.
Randall J E, Hendley J O. A decongestant-antihistamine mixture in the prevention of otitis media in children with colds. Pediatrics. 1979;63:483-485. [pmid: 440849].
Randolph C C, Fraser B. Incidence and progress of middle ear effusion in allergy practice as detected by acoustic otoscope reflectometry. Allergy Proc. 1994;15:157-162. [pmid: 7926716].
Rapin I. Conductive hearing loss: effects on children's language and scholastic skills. A review of the literature. Ann Otol Rhinol Laryngol. 1979;88:3-12.
Rasmussen N, Johnsen N J, Bohr V A. Otologic sequelae after pneumococcal meningitis: a survey of 164 consecutive cases with a follow-up of 94 survivors. Laryngoscope. 1991;101:876-882. [pmid: 1865737].
Rasmussen F. Protracted secretory otitis media. The impact of familial factors and day-care center attendance. Int J Pediatr Otorhinolaryngol. 1993;26:29-37. [pmid: 8444544].
Rasmussen F. Recurrence of acute otitis media at preschool age in Sweden. J Epidemiol Community Health. 1994;48:33-35. [pmid: 8138765].
Raymond J R. Adenoidotonsillectomy [letter] [see comments]. Ear Nose Throat J. 1994;73:856. [pmid: 7828483].
Rayner M G, Zhang Y, Gorry M C, Chen Y, Post J C, Ehrlich G D. Evidence of bacterial metabolic activity in culture-negative otitis media with effusion. JAMA. 1998;279:296-299. [pmid: 9450714].
Reed D, Struve S, Maynard J E. Otitis media and hearing deficiency among Eskimo children: a cohort study. American Journal of Public Health and the Nations Health. 1967;57:1657-1662.
Reed D, Dunn W. Epidemiologic studies of otitis media among Eskimo children. Public Health Rep. 1970;85:699-706. [pmid: 4988671].
Reed B D, Lutz L J. Household smoking exposure--association with middle ear effusions. Fam Med. 1988;20:426-430. [pmid: 3243392].
Rees G L, Freeland A P. The effect of anaesthesia on tympanograms of children undergoing grommet insertion [see comments]. Clin Otolaryngol Allied Sci. 1992;17:200-202. [pmid: 1505083].
Rees G L, Freeland A P. The effect of anaesthesia on tympanograms of children undergoing grommet insertion. Clin Otolaryngol Allied Sci. 1992;17:200-202. [pmid: 1505083].
Reichler M R, Rakovsky J, Sobotova A, et al. Multiple antimicrobial resistance of pneumococci in children with otitis media, bacteremia, and meningitis in Slovakia. J Infect Dis. 1995;171:1491-1496. [pmid: 7769283].
Reid R Jr, Bradley J S, Hindler J. Pneumococcal meningitis during therapy of otitis media with clarithromycin. Pediatr Infect Dis J. 1995;14:1104-1105. [pmid: 8786899].
Reimer A, Andreasson L, Harris S, Ivarsson A, Tjernstrom O. Tubal function and surgery in chronic otitis media. A study on the predictive value of testing tubal function, valsalva's manoeuvre and volume of ear spaces. Acta Oto Laryngologica Supplement. 1988;106:127-130.
Reimer M. [Why not wait and see in spontaneously perforated otitis? (letter)]. Lakartidningen. 1996;93:2923-2924. [pmid: 8815347].
Reina P r i e t o J, Hervas P a l a z o n J. [Otitis media due to Vibrio alginolyticus: the risks of the Mediterranean Sea (letter)]. An Esp Pediatr. 1993;39:361-363. [pmid: 8256965].
Reisman R E, Bernstein J. Allergy and secretory otitis media: clinical and immunologic studies. Pediatr Clin North Am. 1975;22:251-257. [pmid: 1096054].
Reisner K. Tomography in inner and middle ear malformations: value, limits, results. Radiology. 1969;92:11-20. [pmid: 5303921].
Reiss M, Reiss G. Indication for operative treatment of middle ear diseases - Aspects of laterality. Wien Klin Wochenschr. 1998;110:408-410. [pmid: 9658544].
Reisser C, Mielenz H, Junemann K. [Initial clinical experience with taurolidin instillation into the area of the middle area]. HNO. 1994;42:643-646. [pmid: 8002372].
Rennels M B, Edwards K M, Keyserling H L, et al. Safety and immunogenicity of heptavalent pneumococcal vaccine conjugated to CRM197 in United States infants. Pediatrics. 1998;101:604-611. [pmid: 9521941].
Renou G, Ketari M, Toutee J P, Benzaken J. [Medical treatment of seromucous otitis]. Rev-Laryngol-Otol-Rhinol-Bord. 1989;110:327-328. [pmid: 8638061].
Renou G, Ketari M, Toutee J P, Benzaken J. Medical treatment of sero-mucous otitis. Rev Laryngol Otol Rhinol. 1989;110:327-328.
Renvall U, Holmquist J. Tympanometry revealing middle ear pathology. Ann Otol Rhinol Laryngol. 1976;85:209-215. [pmid: 1267350].
Renvall U, Liden G, Jungert S, Nilsson E. Long-term observation of ears with reduced middle ear pressure. Acta Otolaryngol. 1978;86:104-109. [pmid: 567926].
Renvall U, Jarlstedt J, Holmquist J. Identification of middle ear disease. Acta Otolaryngol. 1980;90:283-289. [pmid: 7193395].
Renvall U, Liden G. Screening Procedure for Detection of Middle Ear and Cochlear Disease. Proceedings of the Second International Symposium: Recent Advances in Otitis Media with Effusion; 1980:214–216.
Renvall U, Aniansson G, Liden G. Spontaneous improvement in ears with middle ear disease. Int J Pediatr Otorhinolaryngol. 1982;4:245-250. [pmid: 7118451].
Renvall U, Berg U. Reliability of tympanogram. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:143–146.
Reul J, Weber U, Kotlarek F, Isensee C, Thron A. [Cerebral vein and sinus thrombosis--an important cause of benign intracranial pressure increase in childhood]. Klinische Padiatrie. 1997;209:116-120. [pmid: 9244818].
Reves R, Budgett R, Miller D, Wadsworth J, Haines A. Study of middle ear disease using tympanometry in general practice. Br Med J Clin Res Ed. 1985;290:1953-1956.
Revesz G, Ribari O. Differential diagnosis and treatment of pseudo-otosclerosis. Acta Chirurgica Academiae Scientiarum Hungaricae. 1969;10:253-267. [pmid: 5384160].
Rhee C K, Jung T T, Miller S, Weeks D. Experimental otitis media with effusion induced by platelet activating factor. Ann Otol Rhinol Laryngol. 1993;102:600-605. [pmid: 8352483].
Rhee C K, Park Y S, Long S A, Jung T T, Davamony D. Effects of platelet activating factor on vascular permeability of the middle ear mucosa. Ann Otol Rhinol Laryngol. 1997;106:604-607. [pmid: 9228864].
Ribaric K, Padovan I, Prevec T S. Frequency following response evoked by vibratory stimuli in profoundly deaf subjects. Acta Otolaryngol. 1984;97:467-471. [pmid: 6331705].
Richards S H. Tympanoplasty results following the mobile-bridge technique. Transactions - American Academy of Ophthalmology and Otolaryngology. 1972;76:153-159. [pmid: 5024600].
Richardson H C, Elliott C, Hill J. The feasibility of recording transiently evoked otoacoustic emissions immediately following grommet insertion. Clin Otolaryngol Allied Sci. 1996;21:445-448. [pmid: 8932951].
Richardson M P, Reid A, Williamson T J, Tarlow M J, Rudd P T. Acute otitis media and otitis media with effusion in children with bacterial meningitis. J Laryngol Otol. 1997;111:913-916. [pmid: 9425476].
Richier M A, Choulot J J, Petriat B, et al. [Acute mastoiditis in children: is there a current outbreak? (letter)]. Arch Pediatr. 1994;1:959-960. [pmid: 7842080].
Richner B, Hof E, Prader A. Hearing impairment following therapy of Haemophilus influenzae meningitis. Helvetica Paediatrica Acta. 1979;34:443-447. [pmid: 316810].
Riding K H, Reichert T J, Stool S E. Otologic evaluation at a school for the deaf. Transactions - Pennsylvania Academy of Ophthalmology and Otolaryngology. 1978;31:98-102. [pmid: 675785].
Riedner E D, Levin L S. Hearing patterns in Morquio's syndrome (mucopolysaccharidosis IV). Arch Otolaryngol. 1977;103:518-520. [pmid: 409383].
Rigner P, Ruth M. Treatment with ventilation tubes in children: A two-year follow-up study. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:202–204.
Riley D N, Herberger S, McBride G, Law K. Myringotomy and ventilation tube insertion: a ten-year follow-up. J Laryngol Otol. 1997;111:257-261. [pmid: 9156062].
Rindernecht S. Antibiotic resistance: an emergency we can't ignore. Iowa Med. 1995;85:127-128. [pmid: 7737828].
Riordan J M. The cost of not breastfeeding: a commentary. Journal of Human Lactation. 1997;13:93-97. [pmid: 9233193].
Rippere V. Glue ear [letter] [see comments]. J R Soc Med. 1993;86:681. [pmid: 8258818].
Rippers V. Glue ear [letter]. J R Soc Med. 1995;88:60. [pmid: 7884779].
Riquelme Perez M, Gasquez Abad C I, Mena Mateo E, Mugarza Hernandez D. [Acute otitis media in a pediatrics consulting office]. An Esp Pediatr. 1996;44:433-436. [pmid: 8928965].
Risavi R, Sprem N, Jurkovic J. Restauration of hearing in the treatment of serous otitis. Symp Otorhinolaryngol Iugosl. 1985;20:193-197.
Ristic B, Haralampiev K, Filipovski R. [Complications in secretory otitis media treated with aeration-drainage tubes]. Srp Arh Celok Lek. 1993;121:127-129. [pmid: 7725152].
Ritter F N, Arbor A. Chronic suppurative otitis media and the pathologic labyrinthine fistula. Laryngoscope. 1970;80:1025-1035. [pmid: 5450297].
Rivier A, Carrel O, Laurent A, Wegmuller H. [Nature and antibiotic sensitivity of bacterial species isolated in secretory otitis in a cohort of children]. Rev Med Suisse Romande. 1996;116:121-123. [pmid: 8701197].
Rizer F M, Luxford W M. The management of congenital cholesteatoma: surgical results of 42 cases. Laryngoscope. 1988;98:254-256. [pmid: 3343874].
Rizer F M. Overlay versus underlay tympanoplasty. Part I: historical review of the literature. Laryngoscope. 1997;107:1-25. [pmid: 9395343].
Roark R, Petrofski J, Berson E, Berman S. Practice variations among pediatricians and family physicians in the management of otitis media. Arch Pediatr Adolesc Med. 1995;149:839-844. [pmid: 7633535].
Roark R, Berman S. Continuous twice daily or once daily amoxicillin prophylaxis compared with placebo for children with recurrent acute otitis media. Pediatr Infect Dis J. 1997;16:376-381. [pmid: 9109139].
Robb M P, Psak J L, Pang-Ching G K. Chronic otitis media and early speech development: a case study. Int J Pediatr Otorhinolaryngol. 1993;26:117-127. [pmid: 8444554].
Robert J E, Burchinal M R, Medley L P, et al. Otitis media, hearing sensitivity, and maternal responsiveness in relation to language during infancy. J Pediatr. 1995;126:481-489. [pmid: 7869215].
Roberts C J. Middle-ear deafness in schoolchildren. Practitioner. 1969;203:645-649. [pmid: 5367088].
Roberts M E. Comparative study of pure-tone, impedance, and otoscopic hearing screening methods. A survey of native Indian children in British Columbia. Arch Otolaryngol. 1976;102:690-694. [pmid: 985203].
Roberts J E, Sanyal M A, Burchinal M R, Collier A M, Ramey C T, Henderson F W. Otitis media in early childhood and its relationship to later verbal and academic performance. Pediatrics. 1986;78:423-430. [pmid: 3748675].
Roberts J E, Burchinal M R, Koch M A, Footo M M, Henderson F W. Otitis media in early childhood and its relationship to later phonological development [see comments]. J Speech Hear Disord. 1988;53:424-432. [pmid: 3184903].
Roberts J E, Burchinal M R, Koch M A, Footo M M, Henderson F W. Otitis media in early childhood and its relationship to later phonological development. J Speech Hear Disord. 1988;53:424-432. [pmid: 3184903].
Roberts JE, Burchinal MR, Koch MA, Collier AM, Henderson FW. Otitis Media in Early Childhood and Its Relationship to Later Speech and Language. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:385–388.
Roberts J E, Bruchinal M R, Koch M A, Footo M M, Henderson F W. Otitis media in early childhood and its relationship to later phonological development. J Speech Hear Dis. 1988;53:416-424.
Roberts J E, Burchinal M R, Collier A M, Ramey C T, Koch M A, Henderson F W. Otitis meida in early childhood and cognititive, academic, and classroom performance of the school-aged child. Pediatrics. 1989;83:477-485. [pmid: 2927985].
Roberts J E, Burchinal M R, Davis B P, Collier A M, Henderson F W. Otitis media in early childhood and later language. J Speech Hear Res. 1991;34:1158-1168. [pmid: 1749246].
Roberts JE, Burchinal MR, Henderson FW. Otitis media and school age outcomes. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:561–565.
Roberts J E, Burchinal M R, Campbell F. Otitis media in early childhood and patterns of intellectual development and later academic performance. J Pediatr Psychol. 1994;19:347-367. [pmid: 7520937].
Roberts D G, Johnson C E, Carlin S A, Turczyk V, Karnuta M A, Yaffee K. Resolution of middle ear effusion in newborns. Arch Pediatr Adolesc Med. 1995;149:873-877. [pmid: 7633540].
Roberts J E, Burchinal M R, Medley L P, et al. Otitis media, hearing sensitivity, and maternal responsiveness in relation to language during infancy. J Pediatr. 1995;126:481-489. [pmid: 7869215].
Roberts J E, Burchinal M R, Clarke-Klein S M. Otitis media in early childhood and cognitive, academic, and behavior outcomes at 12 years of age. J Pediatr Psychol. 1995;20:645-660. [pmid: 7500236].
Roberts JE, Zeisel S, Medley L, et al. Otitis media, hearing sensitivity, and language development to two-year-olds. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:325–328.
Roberts K. A preliminary account of the effect of otitis media on 15-month-olds' categorization and some implications for early language learning. Journal of Speech, Language, and Hearing Research. 1997;40:508-518.
Roberts JE, Wallace IF. Language and otitis media. In: Roberts JE, Wallace IF, Henderson FW, eds. Otitis media in young children: medical, developmental and educational considerations. Baltimore (MD): Brooks; 1997:133–161.
Roberts J E, Burchinal M R, Zeisel S A, et al. Otitis media, the caregiving environment, and language and cognitive outcomes at 2 years. Pediatrics. 1998;102:346-354. [pmid: 9685437].
Roberts J E, Burchinal M R, Jackson S C, et al. Otitis media in early childhood in relation to preschool language and school readiness skills among African American children. Pediatrics. 2000;106:1-11. [pmid: 10878140].
Robertson M S. Chronic secretoty otitis media: treatment with trans-tympanic indwelling polythene tubes. N Z Med J. 1968;68:390-391. [pmid: 5249846].
Robertson K, Kumar A. Atypical presentations of aural tuberculosis. Am J Otolaryngol. 1995;16:294-302. [pmid: 7503371].
Robertson L M, Marino R V, Namjoshi S. Does swimming decrease the incidence of otitis media?. J Am Osteopath Assoc. 1997;97:150-152. [pmid: 9107124].
Robinson G C, Anderson D O, Moghadam H K, Cambon K G, Murray A B. A survey of hearing loss in Vancouver school children. I. Methodology and prevalence. Cmaj. 1967;97:1199-1207. [pmid: 6058163]. [pmcid: 1923616].
Robinson B G, Spencer R M. Electrode skin lesions following evoked response audiometry. J Laryngol Otol. 1972;86:363-367. [pmid: 5021720].
Robinson D O, Allen D V. Racial differences in tympanometric results. J Speech Hear Disord. 1984;49:140-144. [pmid: 6716986].
Robinson D O, Allen D V, Root L P. Infant tympanometry: differential results by race. J Speech Hear Disord. 1988;53:341-346. [pmid: 3398485].
Robinson P J, Lodge S, Goligher J, Bowley N, Grant H R. Secretory otitis media and mastoid air cell development. Int J Pediatr Otorhinolaryngol. 1993;25:13-18. [pmid: 8436456].
Rocher P, Carlier R, Attal P, Doyon D, Bobin S. [Contribution and role of the scanner in the preoperative evaluation of chronic otitis. Radiosurgical correlation apropos of 85 cases]. Ann Otolaryngol Chir Cervicofac. 1995;112:317-323. [pmid: 8745698].
Rockette HE CM. Methodologic issues in screening for otitis media. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:42–44.
Rockley T J, Rhys Evans P H. Secretory otitis media--evidence for an inherited aetiology. J Laryngol Otol. 1986;100:389-393. [pmid: 3958583].
Rockley TJ. Family studies in serous otitis media. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:22–24.
Roddey O F Jr, Earle R J, Haggerty R. Myringotomy in acute otitis media. A controlled study. JAMA. 1966;197:849-853. [pmid: 4161606].
Rodriguez W J, Schwartz R H, Sait T, et al. Erythromycin-sulfisoxazole vs amoxicillin in the treatment of acute otitis media in children. A double-blind, multiple-dose comparative study. Am-J-Dis-Child. 1985;139:766-770. [pmid: 3895889].
Rodriguez W J, Khan W H, Sait T, et al. Sultamicillin (sulbactam/ampicillin) versus amoxycillin in the treatment of acute otitis media in children. J Int Med Res. 1990;18:78D-84D.
Rodriguez W J, Khan W, Sait T, et al. Cefixime vs. cefaclor in the treatment of acute otitis media in children: a randomized, comparative study. Pediatr Infect Dis J. 1993;12:70-74. [pmid: 8417429].
Rodriguez W J, Schwartz R H, Thorne M M. Increasing incidence of penicillin- and ampicillin-resistant middle ear pathogens. Pediatr Infect Dis J. 1995;14:1075-1078. [pmid: 8745021].
Rodriguez W J, Schwartz R H, Akram S, Khan W N. Streptococcus pneumoniae resistant to penicillin: incidence and potential therapeutic options. Laryngoscope. 1995;105:300-304. [pmid: 7877420].
Rodriguez A F. An open study to compare azithromycin with cefaclor in the treatment of children with acute otitis media. J Antimicrob Chemother. 1996;37:63-69. [pmid: 8818847].
Roede J, Strutz J. [Timely therapy of chronic otitis media]. Z Arztl Fortbild. 1994;88:367-371.
Roger G, Schlegel N, Chauvin P, Denoyelle F, Garabedian E N. [Predictive factors of residual cholesteatoma in children]. Ann Otolaryngol Chir Cervicofac. 1995;112:262-274. [pmid: 8561409].
Rohn G N, Meyerhoff W L, Wright C G. Ototoxicity of topical agents. Otolaryngol Clin North Am. 1993;26:747-758. [pmid: 8233487].
Rohrich R J, Rowsell A R, Johns D F, et al. Timing of hard palatal closure: a critical long-term analysis. Plast Reconstr Surg. 1996;98:236-246. [pmid: 8764711].
Roizen N J, Martich V, Ben-Ami T, Shalowitz M U, Yousefzadeh D K. Sclerosis of the mastoid air cells as an indicator of undiagnosed otitis media in children with Down's syndrome. Clin Pediatr. 1994;33:439-443.
Roland P, Finitzo T, Friel-Patti S, Brown KC, Meyerhoff WL. Relationships and Correlations Among Auditory Brainstem Response (Electrophysiology), Otoscopy, and Tympanometry in Six and Twelve Months of Infants With and Without Otitis Media. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:54–57.
Roland P S, Finitzo T, Friel-Patti S, et al. Otitis media. Incidence, duration, and hearing status. Arch Otolaryngol Head Neck Surg. 1989;115:1049-1053. [pmid: 2765220].
Roland P S, Meyerhoff W L. Intraoperative electrophysiological monitoring of the facial nerve: is it standard of practice?. Am J Otolaryngol. 1994;15:267-270. [pmid: 7978025].
Roland P S. Clinical ototoxicity of topical antibiotic drops. Otolaryngology and Head and Neck Surgery. 1994;110:598-602.
Rose A S, Prazma J, Randell S H, Baggett H C, Lane A P, Pillsbury H C. Nitric oxide mediates mucin secretion in endotoxin-induced otitis media with effusion. Otolaryngol Head Neck Surg. 1997;116:308-316. [pmid: 9121782].
Rosell Barbera D, Cruz Caballero M. Tympanometry. Anales Espanoles de Pediatria Supplement. 1991;35:35-37.
Rosen C, Forsgren A, Lofkvist T, Walder M. Acute otitis media in older children and adults treated with phenoxymethyl penicillin or erythromycin stearate. Bacteriological and immunological aspects. Acta-Otolaryngol-Stockh. 1983;96:247-253. [pmid: 6416018].
Rosen C, Christensen P, Hovelius B, Prellner K. Effect of pneumococcal vaccination on upper respiratory tract infections in children. Design of a follow-up study. Scand-J Infect Dis-Suppl. 1983:39–44.
Rosen C, Christensen P, Henrichsen J, et al. Beneficial effect of pneumococcal vaccination on otitis media in children over two years old. Int J Pediatr Otorhinolaryngol. 1984;7:239-246. [pmid: 6480233].
Rosen I A, Hakansson A, Aniansson G, et al. Antibodies to pneumococcal polysaccharides in human milk: lack of relationship to colonization and acute otitis media. Pediatr Infect Dis J. 1996;15:498-507. [pmid: 8783346].
Rosenberg S I, Silverstein H, Hoffer M, Nichols M. Use of endoscopes for chronic ear surgery in children. Arch Otolaryngol Head Neck Surg. 1995;121:870-872. [pmid: 7619412].
Rosenfeld R M, Mandel E M, Bluestone C D. Systemic steroids for otitis media with effusion in children [see comments]. Arch Otolaryngol Head Neck Surg. 1991;117:984-989. [pmid: 1832876].
Rosenfeld R M, Post J C. Meta-analysis of antibiotics for the treatment of otitis media with effusion. Otolaryngol Head Neck Surg. 1992;106:378-386. [pmid: 1533027].
Rosenfeld R M. Antimicrobial therapy for otitis media with effusion: the Pittsburgh response [letter; comment]. JAMA. 1993;270:449-450. [pmid: 8320777].
Rosenfeld R M, Doyle W J, Swarts J D, Seroky J, Greene I. Efficacy of ceftibuten for acute otitis media caused by Hemophilus influenzae: an animal study. Ann Otol Rhinol Laryngol. 1993;102:222-226. [pmid: 8457124].
Rosenfeld R M, Vertrees J E, Carr J, et al. Clinical efficacy of antimicrobial drugs for acute otitis media: metaanalysis of 5400 children from thirty-three randomized trials [see comments]. J Pediatr. 1994;124:355-367. [pmid: 8120703].
Rosenfeld R M. Comprehensive management of otitis media with effusion. Otolaryngol Clin North Am. 1994;27:443-455. [pmid: 8065752].
Rosenfeld R M. Antibiotics for otitis media: a clarification [letter; comment]. JAMA. 1994;271:430. [pmid: 8295316].
Rosenfeld R M. Nonsurgical management of surgical otitis media with effusion. J Laryngol Otol. 1995;109:811-816. [pmid: 7494110].
Rosenfeld RM. What to expect from medical treatment of otitis media. Pediatr Infect Dis J. 1995;14:731–737; quiz 738.
Rosenfeld R M. An evidence-based approach to treating otitis media. Pediatr Clin North Am. 1996;43:1165-1181. [pmid: 8973506].
Rosenfeld J A, Clarity G. Acute otitis media in children. Prim Care. 1996;23:677-686. [pmid: 8890138].
Rosenfeld RM, Mandell JR, McMahan A. Auditory function in normal-hearing children with middle ear effusion. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:354–356.
Rosenfeld R M, Goldsmith A J, Tetlus L, Balzano A. Quality of life for children with otitis media. Arch Otolaryngol Head Neck Surg. 1997;123:1049-1054. [pmid: 9339979].
Rosenfeld R M, Goldsmith A J, Madell J R. How accurate is parent rating of hearing for children with otitis media?. Arch Otolaryngol Head Neck Surg. 1998;124:989-992. [pmid: 9738807].
Rosenfeld RM. Natural history of untreated otitis media. In: Rosenfeld RM, Bluestone CD, eds. Evidence-Based Otitis Media. Saint Louis: B.C. Decker Inc.; 1999a:157–177.
Rosenfeld RM. What to expect from medical therapy. In: Rosenfeld RM, Bluestone CD, eds. Evidence-Based Otitis Media. Saint Louis: B.C. Decker Inc.; 1999b:179–205.
Rosner B, Glynn R J. Multivariate methods for clustered ordinal data with applications to survival analysis. Stat Med. 1997;16:357-372. [pmid: 9044526].
Rossi D F. Hearing deficiency in Pueblo Indian children. Results of a mass screening program. Rocky Mountain Medical Journal. 1972;69:65-69. [pmid: 5083714].
Rothera M P, Grant H R. Long-term ventilation of the middle ear using the Goode T-tube. J Laryngol Otol. 1985;99:335-337. [pmid: 4040147].
Rotimi V O, Olabiyi D A, Banjo T O, Okeowo P A. Randomised comparative efficacy of clindamycin, metronidazole, and lincomycin, plus gentamicin in chronic suppurative otitis media. West-Afr-J-Med. 1990;9:89-97. [pmid: 2268574].
Rotta A T, Asmar B I. Moraxella catarrhalis bacteremia and preseptal cellulitis. South Med J. 1994;87:541-542. [pmid: 8153789].
Roush J, Bryant K, Mundy M, Zeisel S, Roberts J. Developmental changes in static admittance and tympanometric width in infants and toddlers. J Am Acad Audiol. 1995;6:334-338. [pmid: 7548933].
Rovers M M, Hofstad E A, Franken-van den Brand K I, et al. Prognostic factors for otitis media with effusion in infants. Clin Otolaryngol Allied Sci. 1998;23:543-546. [pmid: 9884810].
Rovers M M, Zielhuis G A, Straatman H, Ingels K, van der Wilt G J, van den Broek P. Prognostic factors for persistent otitis media with effusion in infants. Arch Otolaryngol Head Neck Surg. 1999;125:1203-1207. [pmid: 10555690].
Rowe D S. Acute suppurative otitis media. Pediatrics. 1975;56:285-294. [pmid: 240150].
Rowe L D. Tonsils and adenoids. When is surgery indicated?. Prim Care. 1982;9:355-369. [pmid: 6922567].
Roydhouse N. A controlled study of adenotonsillectomy. Arch-Otolaryngol. 1970;92:611-616. [pmid: 4922436].
Roydhouse N. Letter: Secretory otitis media. N Z Med J. 1975;82:319. [pmid: 1060949].
Roydhouse N. Adenoidectomy for otitis media with mucoid effusion. Ann-Otol-Rhinol-Laryngol-Suppl. 1980;89:312-315. [pmid: 6778335].
Roydhouse N. Bromhexine for otitis media with effusion. N-Z-Med-J. 1981;94:373-375. [pmid: 7033848].
Roydhouse N. Medical treatment of otitis media with effusion. Eur J Respir Dis. 1983;62.
Roydhouse N. Antibiotic treatment of otitis media with effusion. N-Z-Med-J. 1991;104:380-382. [pmid: 1923078].
Roydhouse N. Otitis media with effusion [letter; comment] [see comments]. N Z Med J. 1996;109:263. [pmid: 8692454].
Ruah C, Penha R, Schachern P, Paparella M. Tympanic membrane and otitis media. Acta Otorhinolaryngol Belg. 1995;49:173-180. [pmid: 7610910].
Ruben R J, Rozycki D. Diagnostic screening for the deaf child. Arch Otolaryngol. 1970;91:429-432. [pmid: 5442734].
Ruben R J, Rozycki D L. Clinical aspects of genetic deafness. Ann Otol Rhinol Laryngol. 1971;80:255-263. [pmid: 5550780].
Ruben R J, Math R. Serous otitis media associated with sensorineural hearing loss in children. Laryngoscope. 1978;88:1139-1154. [pmid: 672347].
Ruben R J, Hanson D G. Summary of discussion and recommendations made during the workshop on otitis media and development. Ann Otol Rhinol Laryngol Suppl. 1979;88:107-111. [pmid: 115358].
Ruben R J, Hanson D G. Introduction: Otitis media and child development. Ann Otol Rhinol Laryngol. 1979;88:1-2.
Ruben R J, Rapin I. Plasticity of the developing auditory system. Ann Otol Rhinol Laryngol. 1980;89:303-311. [pmid: 7416679].
Ruben R J. An inquiry into the minimal amount of auditory deprivation which results in a cognitive effect in man. Acta Otolaryngol. 1981;414:157-164.
Ruben R J. Otorhinolaryngologic disorders of adolescents: a review. Int J Pediatr Otorhinolaryngol. 1985;9:1-30. [pmid: 2993184].
Ruben RJ. Sequelae of antibiotic therapy for acute otitis media and otitis media with effusion. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:369–373.
Ruben R J, Wallace I F, Gravel J. Long-term communication deficiencies in children with otitis media during their first year of life. Acta Otolaryngol. 1997;117:206-207. [pmid: 9105449].
Ruben R J, Haggard M P, Bagger-Sjoback D, et al. Complications and sequelae. Ann Otol Rhinol Laryngol. 1998;107:81-94. [pmid: 9439394].
Ruben R J. Persistency of an effect: otitis media during the first year of life with nine years follow-up. Int J Pediatr Otorhinolaryngol. 1999;49:S115-S118. [pmid: 10577788].
Rubin M. Hearing aids for infants and toddlers. In: M R, ed. Hearing aids: current developments and concepts. Baltimore: University Park Press; 1976:95–101.
Rubin J S, Wei W I. Acute mastoiditis: a review of 34 patients. Laryngoscope. 1985;95:963-965. [pmid: 3894842].
Ruckenstein M J, Macdonald R E, Clarke J T, Forte V. The management of otolaryngological problems in the mucopolysaccharidoses: a retrospective review. J Otolaryngol. 1991;20:177-183. [pmid: 1908026].
Ruckley R W, Blair R L. Thermal myringotomy (an alternative to grommet insertion in childhood secretory otitis media?). J Laryngol Otol. 1988;102:125-128. [pmid: 3346587].
Rudin R, Holmquist J. Frequency of pathologic changes in the middle ear. Ann Otol Rhinol Laryngol. 1980;89.
Ruggles R L, Abols I. Care of the ear canal and mastoid. Ann Otol Rhinol Laryngol. 1983;92:566-567. [pmid: 6660748].
Ruohola A, Heikkinen T, Jero J, et al. Oral prednisolone is an effective adjuvant therapy for acute otitis media with discharge through tympanostomy tubes. J Pediatr. 1999;134:459-463. [pmid: 10190921].
Ruokonen J, Holopainen E, Palva T, Backman A. Secretory otitis media and allergy. With special reference to the cytotoxic leucocyte test. Allergy. 1981;36:59-68. [pmid: 7194586].
Ruokonen J, Paganus A, Lehti H. Elimination diets in the treatment of secretory otitis media. Int J Pediatr Otorhinolaryngol. 1982;4:39-46. [pmid: 7201458].
Rushton H C, Tong M C, Yue V, Wormald P J, van Hasselt C A. Prevalence of otitis media with effusion in multicultural schools in Hong Kong. J Laryngol Otol. 1997;111:804-806. [pmid: 9373542].
Ruuskanen O, Heikkinen T. Otitis media: Etiology and diagnosis. Pediatr Infect Dis J. 1994;13:S23-S26. [pmid: 8159511].
Ruuskanen O, Heikkinen T. Viral-bacterial interaction in acute otitis media. Pediatr Infect Dis J. 1994;13:1047-1049. [pmid: 7845738].
Rvachew S, Slawinski E B, Williams M, Green C L. The impact of early onset otitis media on babbling and early language development. J Acoust Soc Am. 1999;105:467-475. [pmid: 9921670].
Ryan R M, Brown P M, Cameron J M, Fowler S M, Grant H R, Topham J H. Royal College of Surgeons comparative ENT audit 1990. Clin Otolaryngol Allied Sci. 1993;18:541-546. [pmid: 8877238].
Ryan A F, Baird A. Growth factors during proliferation of the middle ear mucosa. Acta Otolaryngol. 1993;113:68-74. [pmid: 8442425].
Rybak L P. Treatable sensorineural hearing loss. Am J Otol. 1985;6:482-489. [pmid: 3878093].
Ryczko B, Brodsky L, Stanievich J F, Pordell R. Spontaneous cerebrospinal fluid otorrhea in a deaf infant. Int J Pediatr Otorhinolaryngol. 1988;16:245-251. [pmid: 3235289].
Ryding M, Konradsson K, Prellner K. Sequelae of recurrent acute otitis media. Ten-year follow-up of a prospectively studied cohort of children. Acta Paediatr. 1208;86:1208-1213. [pmid: 9401515].
Ryding M, Konradsson K, Kalm O, Prellner K. Recurrent acute otitis media: clinical and audiologic follow-up to ten years of age. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:365–366.
Ryding M, Konradsson K, Kalm O, Prellner K. Sequelae of recurrent acute otitis media. Ten-year follow-up of a prospectively studied cohort of children. Acta Paediatr. 1997;86:1208-1213. [pmid: 9401515].
Rydzewski B, Skrobisz W, Miarzynska M. [Thrombosis of the sigmoid sinus and transverse sinus with an unusual course]. Otolaryngol Pol. 1995;49:71-74. [pmid: 7644204].
Rydzewski B, Dutkiewicz W, Lukowiak G. [Meningiomas of the middle ear]. Otolaryngol Pol. 1996;50:329-334. [pmid: 9045175].
Rynnel-Dagoo B, Ahlbom A, Schiratzki H. Effects of adenoidectomy: a controlled two-year follow-up. Ann-Otol-Rhinol-Laryngol. 1978;87:272-278. [pmid: 646300].
Rynnel-Dagoo B, Freijd A. Nasopharyngeal lymphoid tissue--a threat to the middle ear?. Acta Oto-Laryngologica - Supplement. 1988;454:208-209.
Rynnel-Dagoo B, Forsgren J, Samuelson A. Immunological and bacteriological studies on mucosa-associated lymphatic tissue in children with SOM. Adv Otorhinolaryngol. 1992;47:120-123. [pmid: 1456119].
Rynnel-Dagoo B, Forsgren J, Freijd A, Lindberg K. Rationale for antibiotic therapy in pediatric ear, nose and throat infections: immunologic issues. Pediatr Infect Dis J. 1994;13:S15–S20; discussion S20–S22.
Rynnel-Dagoo B. Are there microbiological markers to predict recurrent acute otitis media?. Acta Oto-Laryngologica - Supplement. 1997;529:19-21.
Rzymski K, Kosowicz J. The skull in gonadal dysgenesis. A roentgenometric study. Clin Radiol. 1975;26:379-384. [pmid: 1201635].
Sabater F, Maristany M, Mensa J, Villar E, Traserra J. [Prospective double-blind randomized study of the efficacy and tolerance of topical ciprofloxacin vs topical gentamicin in the treatment of simple chronic otitis media and diffuse external otitis]. Acta-Otorrinolaringol-Esp. 1996;47:217-220. [pmid: 8924287].
Sabin S L, Lee D, Har-el G. Low velocity gunshot injuries to the temporal bone. J Laryngol Otol. 1998;112:929-933. [pmid: 10211214].
Sabirova MM, Shametov I. [A case of tympanogenic labyrinthitis in acute otitis media]. Vestn Otorinolaringol. 1995:53–54.
Sachdeva O P, Gulati S P, Kakar V, Sachdeva A. Tuberculosis of middle ear cleft. Indian J Chest Dis Allied Sci. 1993;35:137-139. [pmid: 8125538].
Sacket D L. How to read clinical journals. V: To distinguish useful from useless or even harmful therapy. Can Med Assoc J. 1981;124:1156-1162. [pmid: 7016293]. [pmcid: 1705333].
Sade J. The muco-ciliary system in relation to middle ear pathology and sensorineural hearing loss. In: Sensorineural hearing loss. CIBA Found Symp. 1970:79–99.
Sade J, Konak S, Hinchcliffe R. Ethnic factors in the pathogenesis of chronic otitis media in Israel. A preliminary investigation. J Laryngol Otol. 1971;85:349-353. [pmid: 5572825].
Sade J, Meyer F A, King M, Silberberg A. Clearance of middle ear effusions by the mucociliary system. Acta Otolaryngol. 1975;79:277-282. [pmid: 1136766].
Sade J, Halevy A, Hadas E. Clearance of middle ear effusions and middle ear pressures. Ann Otol Rhinol Laryngol. 1976;85:58-62. [pmid: 1267369].
Sade J, Weissman Z. Middle ear mucosa and secretory otitis media. Arch Otorhinolaryngol. 1977;215:195-205. [pmid: 577691].
Sade J. Inflammatory and non-inflammatory factors related to secretory otitis media. Int J Pediatr Otorhinolaryngol. 1979;1:41-59. [pmid: 576015].
Sade J, Hadas E. Prognostic evaluation of secretory otitis media as a function of mastoidal pneumatisation. Arch Otorhinolaryngol. 1979;225:39-44. [pmid: 575287].
Sade J, Weinberg J, Berco E, Brown M, Halevy A. The marsupialized (radical) mastoid. J Laryngol Otol. 1982;96:869-875. [pmid: 7119556].
Sade J, Yaniv E, Gassner S, Levy M. Stapes-replacing prosthesis (S.R.P.). J Laryngol Otol. 1983;97:677-684. [pmid: 6886527].
Sade J, Yaniv E, Avraham S, Fuchs C, Sacs B. Missing stapes and stapes-replacing prosthesis. Am J Otol. 1985;6:257-262. [pmid: 4003537].
Sade J, Shatz A. Cholesteatoma in children. J Laryngol Otol. 1988;102:1003-1006. [pmid: 3209933].
Sade J, Luntz M, Pitashny R. Diagnosis and treatment of secretory otitis media. Otolaryngol Clin North Am. 1989;22:1-14. [pmid: 2649851].
Sade J, Fuchs C. A comparison of mastoid pneumatization in adults and children with cholesteatoma. Eur Arch Otorhinolaryngol. 1994;251:191-195. [pmid: 7917249].
Sade J. The nasopharynx, eustachian tube and otitis media [see comments]. J Laryngol Otol. 1994;108:95-100. [pmid: 7802761].
Sade J, Fuchs C. Secretory otitis media in adults: I. The role of mastoid pneumatizationas a risk factor. Ann Otol Rhinol Laryngol. 1996;105:643-647. [pmid: 8712636].
Sade J, Ar A. Middle ear and auditory tube: middle ear clearance, gas exchange, and pressure regulation. Otolaryngol Head Neck Surg. 1997;116:499-524. [pmid: 9141402].
Sade J, Fuchs C. Secretory otitis media in adults: II. The role of mastoid pneumatization as a prognostic factor. Ann Otol Rhinol Laryngol. 1997;106:37-40. [pmid: 9006359].
Saeed S, Ramsden R. Hearing loss. Practitioner. 1994;238:454-460. [pmid: 8208663].
Saez-Llorens X. Pathogenesis of acute otitis media. Pediatr Infect Dis J. 1994;13:1035-1038. [pmid: 7845736].
Saffer M, Lubianca Neto J F, Piltcher O B, Petrillo V F. Chronic secretory otitis media: negative bacteriology. Acta Otolaryngol. 1996;116:836-839. [pmid: 8973717].
Sagnelli M, Marzullo C, Pollastrini L, Marullo M N. Secretory otitis media: Current concepts and prognostic influence of adenoidectomy. OTITE MEDIA SECRETORIA: ASPETTI ATTUALE E RUOLO TERAPEUTICO DELLA ADENOIDECTOMIA. MED RIV ENCICL MED ITAL. 1990;10:16-22.
Sagnelli M, Marzullo C, Pollastrini L, Marullo M N. [Secretory otitis media: current aspects and therapeutic role of adenoidectomy]. Medicina-Firenze. 1990;10:16-22. [pmid: 2199743].
Sagraves R, Maish W, Kameshka A. Update on otitis media. Part 2. Treatment. Am Pharm. 1993;NS33:29-35. [pmid: 8430615].
Said H, Phang K S, Razi A, Khuzaiyah R, Patawari P H, Esa R. Rhabdomyosarcoma of the middle ear and mastoid in children. J Laryngol Otol. 1988;102:614-619. [pmid: 3411216].
Saim A, Saim L, Saim S, Ruszymah B H, Sani A. Prevalence of otitis media with effusion amongst pre-school children in Malaysia. Int J Pediatr Otorhinolaryngol. 1997;41:21-28. [pmid: 9279632].
Saito T, Iwaki E, Kohno Y, et al. Prevention of persistent ear drum perforation after long-term ventilation tube treatment for otitis media with effusion in children. Int J Pediatr Otorhinolaryngol. 1996;38:31-39. [pmid: 9119591].
Sak R J, Ruben R J. Recurrent middle ear effusion in childhood: implications of temporary auditory deprivation for language and learning. Ann Otol Rhinol Laryngol. 1981;90:546-551. [pmid: 7316377].
Sak R J, Ruben R J. Effects of recurrent middle ear effusion in preschool years on language and learning. J Dev Behav Pediatr. 1982;3:7-11. [pmid: 7200492].
Sakagami M, Kitamura K, Doi K, Mishiro Y, Kubo T. [Tympanoplasty in cholesteatoma otitis media with normal hearing]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1994;97:1437-1442.
Sakagami M, Ogasawara H, Node M, Seo T, Mishiro Y, Okumura S. [Tympanoplasty on only hearing ears]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1996;99:973-977.
Sakaguchi M, Taguchi K, Ishiyama T, Netsu K, Katsuno S. Tympanometric changes following acute otitis media in Japanese children. Eur Arch Otorhinolaryngol. 1994;251:113-116. [pmid: 8024758].
Sakai M, Miyake H, Shinkawa A, Mahapatra A K, Chien C. Assessment of postoperative hearing in 528 middle ear and mastoid surgery cases in Tokai University Hospital. Tokai J Exp Clin Med. 1982;7:251-264. [pmid: 7101329].
Sakai M, Shinkawa A, Saito S, Miyake H. Late results of hearing in children treated with tympanostomy tube. Auris Nasus Larynx. 1985;12:S38-S39. [pmid: 3835931].
Sakai M, Koga K, Kawashiro N, Araki A, Morikawa Y. Long Term Follow-up of Children with Otitis Media with Effusion. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:39–41.
Sakakihara J, Honjo I, Fujita A, Kurata K, Takahashi H. Eustachian tube compliance in sniff-induced otitis media with effusion. A preliminary study. Acta Otolaryngol. 1993;113:187-190. [pmid: 8475734].
Sakikawa Y, Kobayashi H, Nomura Y. Changes in middle ear pressure in daily life. Laryngoscope. 1995;105:1353-1357. [pmid: 8523991].
Sakoa B. [Suppurative otitis media, bacteriologic study and therapeutic management]. Vestn Otorinolaringol. 1995:12–14.
Sakurai T, Rokugo M. Pathophysiology of otitis media with effusion: clinical evaluation through some qualitative methods. Auris Nasus Larynx. 1985;12:S111-S113. [pmid: 3835881].
Sakurai T. CT scan findings in blue ear drum. Acta Oto-Laryngologica - Supplement. 1987;435:117-121.
Sala O, Babighian G. Automatic versus standard audiometry. Audiology. 1973;12:21-27. [pmid: 4681961].
Salam M A, Wengraf D. Glue under pressure: A bad prognostic sign for recurrence of otitis media with effusion. J Laryngol Otol. 1992;106:974-976. [pmid: 1479274].
Salam M A, Cable H R. The use of antibiotic/steroid ear drops to reduce post-operative otorrhoea and blockage of ventilation tubes. A prospective study. J Laryngol Otol. 1993;107:188-189. [pmid: 8509691].
Salami A, Dellepiane M, Tinelli E, Zavattini G. Ambroxol in the treatment of secretory otitis media. Valsalva. 1984;60:421-430.
Salata J A, Derkay C S. Water precautions in children with tympanostomy tubes. Arch Otolaryngol Head Neck Surg. 1996;122:276-280. [pmid: 8607955].
Salazar J C, Daly K A, Giebink G S, et al. Low cord blood pneumococcal immunoglobulin G (IgG) antibodies predict early onset acute otitis media in infancy. Am J Epidemiol. 1997;145:1048-1056. [pmid: 9169914].
Salazar Cabrera A N, Berron Perez R, Ortega Martell J A, Onuma Takane E. [Asthma and cyclic neutropenia]. Allergol Immunopathol. 1996;24:25-28.
Salonen E M, Vaheri A, Meri S, Lehtinen T, Palva T. Plasmin and fibronectin degradation in chronic secretory otitis media. Arch Otolaryngol Head Neck Surg. 1989;115:48-53. [pmid: 2521200].
Salvo Gonzalo S, Grijalba Uche M, Mazon Ramos A, Vila Mendiburu I. [Acute otitis media caused by Nocardia asteroides]. Acta Otorrinolaringol Esp. 1996;47:314-316. [pmid: 8962736].
Salzberg R. [Comparative clinical and bacteriological studies with Bactrim and ampicillin in the pediatrics]. Schweiz-Rundsch-Med-Prax. 1972;61:1051-1052. [pmid: 4563621].
Samet J M, Lewit E M, Warner K E. Involuntary smoking and children's health. Future Child. 1994;4:94-114. [pmid: 7859045].
Samuel D, Thomas D M, Tierney P A, Patel K S. Atlanto-axial subluxation (Grisel's syndrome) following otolaryngological diseases and procedures. J Laryngol Otol. 1995;109:1005-1009. [pmid: 7499935].
Samuelson A, Freijd A, Jonasson J, Lindberg A A. Turnover of nonencapsulated Haemophilus influenzae in the nasopharynges of otitis-prone children. J Clin Microbiol. 1995;33:2027-2031. [pmcid: 228329]. [pmid: 7559942].
Sanchez T G, Ognibene R Z, Gondin M, Bento R F. Audiometric findings after ear ventilation tubes extrusion. Revista Brasileira de Otorrinolaringologia. 1992;58:99-102.
Sanders J W. Symposium on sensorineural hearing loss in children: early detection and intervention. Impedance measurement. Otolaryngol Clin North Am. 1975;8:109-124. [pmid: 164001].
Sandstad B. Re: “Validity of parental report of a child's medical history in otitis media research” [letter; comment]. Am J Epidemiol. 1995;142:100-101. [pmid: 7785667].
Sanna M, Shea C M, Gamoletti R, Russo A. Surgery of the ‘only hearing ear’ with chronic ear disease. J Laryngol Otol. 1992;106:793-798. [pmid: 1431516].
Sano S, Kamide Y, Schachern P A, Paparella M M. Micropathologic changes of pars tensa in children with otitis media with effusion. Arch Otolaryngol Head Neck Surg. 1994;120:815-819. [pmid: 8049041].
Santoni P, Parisi G, Menegus T, Avesani L. Otitis media with effusion in children: Clinical-therapeutical evaluation using letosteine. Otorinolaryngologia. 1987;37:541-548.
Sarkkinen H, Ruuskanen O, Meurman O, Puhakka H, Virolainen E, Eskola J. Identification of respiratory virus antigens in middle ear fluids of children with acute otitis media. J Infect Dis. 1985;151:444-448. [pmid: 2982961].
Sassen M L, Brand R, Grote J J. Breast-feeding and acute otitis media. Am J Otolaryngol. 1994;15:351-357. [pmid: 7978038].
Sassen M L, van Aarem A, Grote J J. Validity of tympanometry in the diagnosis of middle ear effusion. Clin Otolaryngol Allied Sci. 1994;19:185-189. [pmid: 7923836].
Sassen M L, Veen S, Schreuder A M, et al. Otitis media, respiratory tract infections and hearing loss in pre-term and low birthweight infants. Clin Otolaryngol Allied Sci. 1994;19:179-184. [pmid: 7923835].
Sassen M L, Brand H, Grote J J. Risk factors for otitis media with effusion in children 0 to 2 years of age. Am J Otolaryngol. 1997;18:324-330. [pmid: 9282249].
Sataloff R T, Colton C M. Otitis media: a common childhood infection. Am J Nurs. 1981;81:1480-1483. [pmid: 6910987].
Sataloff R T, Hawkshaw M, Emerich K A. How I do it: myringotomy tubes for malformed ears. Ear Nose Throat J. 1994;73:337-338. [pmid: 8045240].
Sato H. Treatment of otitis media with effusion with transtympanic iontophoresis. Otolaryngology. 1987;59:357-361.
Sato H, Nakamura H, Honjo I, Fujita A, Takahashi H, Hayashi M. Clinical evaluation of Tsumura-Saireito in children with otitis media with effusion. A comparative randomized controlled study with Cepharanthin. PRACT OTOL. 1988;81:1383-1387.
Sato H, Takahashi H, Honjo I. Transtympanic iontophoresis of dexamethasone and fosfomycin. Arch Otolaryngol Head Neck Surg. 1988;114:531-533. [pmid: 3355690].
Sato I, Shimada K, Ezure H, Sato H, Kohno T, Sato T. Three-dimensional structure of the perimysium in sternocleidomastoid muscle. Okajimas Folia Anat Jpn. 1995;71:381-387. [pmid: 7739848].
Sato K, Quartey M K, Liebeler C L, Giebink G S. Timing of penicillin treatment influences the course of Streptococcus pneumoniae-induced middle ear inflammation. Antimicrob Agents Chemother. 1995;39:1896-1898. [pmcid: 162851]. [pmid: 7486944].
Sato K, Quartey M K, Liebeler C L, Le C T, Giebink G S. Roles of autolysin and pneumolysin in middle ear inflammation caused by a type 3 Streptococcus pneumoniae strain in the chinchilla otitis media model. Infect Immun. 1996;64:1140-1145. [pmcid: 173895]. [pmid: 8606070].
Sato K, Kawana M, Yamamoto Y, Fujioka O, Nakano Y. Evaluation of mastoid air cell system by three-dimensional reconstruction using sagittal tomography of the temporal bone. Auris Nasus Larynx. 1997;24:47-51. [pmid: 9148728].
Saunte C. Clinical trial with Lunerin mixture and Lunerin mite in children with secretory otitis media. J Int Med Res. 1978;6:50-55. [pmid: 342302].
Sauvage J P, Heurtebise F, Puyraud S. [Hammock myringoplasty (technique, results)]. Rev Laryngol Otol Rhinol. 1996;117:247-251.
Savara B S, Takeuchi Y. Anatomical location of cephalometric landmarks on the sphenoid and temporal bones. Angle Orthod. 1979;49:141-149. [pmid: 286567].
Savic D, Jasovic A, Djeric D. The relations of the mastoid segment of the facial canal to surrounding structures in congenital middle ear malformations. Int J Pediatr Otorhinolaryngol. 1989;18:13-19. [pmid: 2807750].
Sawaki S. [Clinical evaluation of cephalexin (Lilly) in oto-laryngological infections by a double blind method]. Saishin-Igaku. 1970;25:1556-1562. [pmid: 4916002].
Sawaki S, Kitamura K, Sato Y, Takahashi M. [Double-blind studies of the effect of ampicillin-cloxacillin (Rectocillin) on acute otorhinolaryngological infections (author's transl)]. Jpn-J-Antibiot. 1976;29:340-343. [pmid: 775145].
Sawyer C E, Evans R L, Boline P D, Branson R, Spicer A. A feasibility study of chiropractic spinal manipulation versus sham spinal manipulation for chronic otitis media with effusion in children. J Manipulative Physiol Ther. 1999;22:292-298. [pmid: 10395431].
Scadding G K, Martin J A, Alles R, Hawk L, Darby Y. Glue ear guidelines [letter; comment]. Lancet. 1993;341:57. [pmid: 8093306].
Scadding G K, Hawk L J, Martin J A, Darby Y, Alles R S. Persistent glue ear in children [letter; comment]. Br Med J. 1993;306:455. [pmid: 8461738].
Scaglione F, Cogo R, Pintucci J P, et al. Brodimoprim concentrations in bronchial mucosa, bronchial secretions and middle ear effusions. J Chemother. 1993;5:490-493. [pmid: 8195843].
Scaldwell WA. Effect of otitis media upon reading scores of Indian children in Ontario. J Am Indian Educ. 1989:32–39.
Schaad U B, Farine J C, Fux T H, et al. Prospective placebo-controlled double-blind evaluation of a bacterial lysate in respiratory and ear-nose-throat infections in childhood. PROSPEKTIVE PLACEBO-KONTROLLIERTE DOPPELBLINDSTUDIE MIT EINEM BAKTERIENLYSAT BEI INFEKTIONEN DER ATEMWEGE UND DES ORL-BEREICHES IM KINDESALTER. HELV PAEDIATR ACTA. 1986;41:7-17. [pmid: 3755127].
Schaad UB. Multicentre evaluation of azithromycin in comparison with co-amoxiclav for the treatment of acute otitis media in children. J-Antimicrob-Chemother. 1993:81–88.
Schappert SM. Office visits for otitis media: United States, 1975-90. Advance data from vital and health statistics Hyattsville (MD): National Center for Health Statistics; 1992.
Schappert SM. National ambulatory medical care survey: 1994 summary. Advance data from vital and health statistics Hyattsville (MD): National Center for Health Statistics; 1996.
Schappert SM. Ambulatory care visits to physician offices, hospital outpatient departments, and emergency departments: United States, 1995 Hyattsville (MD): U.S. Department of Health and Human Services; 1997.
Schechter NL. Common pain problems in the general pediatric setting [see comments]. Pediatr Ann. 1995;24:139, 143–146.
Scheinpflug L, Vorwerk U, Begall K. [Effect size on resonance of the outer ear canal by simulation of middle ear lesions using a temporal bone preparation]. Laryngorhinootologie. 1995;74:39-42. [pmid: 7888021].
Schilder A G, Zielhuis G A, Straatman H S, van den Broek P. An epidemiological approach to the etiology of middle ear disease in The Netherlands. Eur Arch Otorhinolaryngol. 1992;249:370-373. [pmid: 1489534].
Schilder AGM, Zielhuis GA, van den Broek P. Long-term effects of otitis media with effusion otologic findings. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:585–588.
Schilder A G, Van Manen J G, Zielhuis G A, Grievink E H, Peters S A, Van Den Broek P. Long-term effects of otitis media with effusion on language, reading and spelling. Clin Otolaryngol Allied Sci. 1993;18:234-241. [pmid: 8365017].
Schilder A G, Zielhuis G A, Van Den Broek P. The otological profile of a cohort of Dutch 7.5–8-year-olds. Clin Otolaryngol Allied Sci. 1993;18:48-54. [pmid: 8448892].
Schilder A G, Snik A F, Straatman H, van den Broek P. The effect of otitis media with effusion at preschool age on some aspects of auditory perception at school age. Ear Hear. 1994;15:224-231. [pmid: 8076720].
Schilder A G, Zielhuis G A, Haggard M P, van den Broek P. Long-term effects of otitis media with effusion: otomicroscopic findings. Am J Otol. 1995;16:365-372. [pmid: 8588632].
Schilder A G, Hak E, Straatman H, Zielhuis G A, van Bon W H, van den Broek P. Long-term effects of ventilation tubes for persistent otitis media with effusion in children. Clin Otolaryngol Allied Sci. 1997;22:423-429. [pmid: 9372253].
Schilder A G M. Assessment of complications of the condition and of the treatment of otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1999;49:247-251.
Schiller A. Reconstruction of the sound conducting mechanism by the malleomyringoplasty and prosthesis method. S Afr Med J. 1971;45:339-344. [pmid: 5574513].
Schlieper A, Kisilevsky H, Mattingly S, Yorke L. Mild conductive hearing loss and language development: a one year follow-up study. J Dev Behav Pediatr. 1985;6:65-68. [pmid: 3988943].
Schloss M D, Rishikof E, Sorger S, Dempsey E E, Grace M. A double-blind study comparing erythromycin-sulfisoxazole (Pediazole (R)) t.i.d. with placebo in chronic otitis media with effusion. TODAY'S THER TRENDS. 1988;5:43-56.
Schloss MD, Dempsey EE, Rishikof E, Sorger S, Grace MGA. Double Blind Study Comparing Erythromycin-Sulfisoxazole (Pediazole) T.I.D. to Placebo in Chronic Otitis Media with Effusion. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:261–263.
Schloss M D, Terraza O. Cholesteatoma in children. J Otolaryngol. 1991;20:43-45. [pmid: 2030536].
Schmidt S H, Hellstrom S. Phenol anesthesia of the tympanic membrane in purulent otitis media: a structural analysis in the rat. Eur Arch Otorhinolaryngol. 1993;249:470-472. [pmid: 8442942].
Schmidt S H, Hellstrom S. Experimental cholesteatoma in the rat. Acta Otolaryngol. 1994;114:430-434. [pmid: 7526596].
Schmuziger N, Hauser R, Probst R. Influence of eustachian tube dysfunction on transiently evoked and distortion-product otoacoustic emissions. HNO. 1996;44:319-323. [pmid: 8767128].
Schmuziger N, Hauser R, Probst R. [Transitory evoked otoacoustic emissions and distortion product emissions in disorders of middle ear ventilation]. HNO. 1996;44:319-323. [pmid: 8767128].
Schnore S K, Sangster J F, Gerace T M, Bass M J. Are antihistamine-decongestants of value in the treatment of acute otitis media in children?. J-Fam-Pract. 1986;22:39-43. [pmid: 3510268].
Scholz H, Noack R. Multicenter, randomized, double-blind comparison of erythromycin estolate versus amoxicillin for the treatment of acute otitis media in children. AOM Study Group. Eur J Clin Microbiol Infect Dis. 1998;17:470-478. [pmid: 9764549].
Schonweiler R, Schonweiler B, Schmelzeisen R. [Hearing capacity and speech production in 417 children with facial cleft abnormalities]. HNO. 1994;42:691-696. [pmid: 7844001].
Schonweiler R. [Synopsis of results with 1,300 children with language developmental delay from the etiopathogenetic, audiologic and speech pathology viewpoint]. Folia Phoniatr Logop. 1994;46:18-26. [pmid: 8162133].
Schriberg L D, Flipsen P J, Thielke H, et al. Risk for speech disorder associated with early recurrent otitis media with effusion: two retrospective studies. J Speech Lang Hear Res. 2000;43:79-99. [pmid: 10668654].
Schuknecht H F, Gacek R R. Surgery on only-hearing ears. Transactions - American Academy of Ophthalmology and Otolaryngology. 1973;77:ORL257-66. [pmid: 4354491].
Schuknecht H F, Kirchner J C. Cochlear otosclerosis: fact or fantasy. Laryngoscope. 1974;84:766-782. [pmid: 4827586].
Schuknecht H F, Zaytoun G M, Moon C N Jr. Adult-onset fluid in the tympanomastoid compartment. Diagnosis and management. Arch Otolaryngol. 108. 1982:759-765.
Schuller D E. Prophylaxis of otitis media in asthmatic children. Pediatr-Infect-Dis. 1983;2:280-283. [pmid: 6889154].
Schulte D L, Driscoll C L, McDonald T J, Facer G W, Beatty C W. Irradiated rib cartilage graft for reconstruction of the tympanic membrane: preliminary results. Am J Otol. 1998;19:141-144. [pmid: 9520048].
Schuring A G, Lippy W H. Validating the excision of cholesteatoma. Otolaryngol Head Neck Surg. 1985;93:288-292. [pmid: 3927221].
Schuring A G, Lippy W H. The ossicle-cup prosthesis: five years later. Otolaryngol Head Neck Surg. 1986;95:219-221. [pmid: 3108763].
Schuring A G. An otologic informed consent. Am J Otol. 1988;9:243-245. [pmid: 3177607].
Schuring A G. Validating the excision of cholesteatoma. Otolaryngol Clin North Am. 1989;22:1041-1053. [pmid: 2616167].
Schuring A G, Lippy W H, Rizer F M, Schuring L T. Staging for cholesteatoma in the child, adolescent, and adult. Ann Otol Rhinol Laryngol. 1990;99:256-260. [pmid: 2327694].
Schuring A G. Cholesteatoma and imaging. Am J Otol. 1991;12:394-395. [pmid: 1789312].
Schwager K, Carducci F. [Endocranial complications of acute and chronic otitis media in children and adolescents]. Laryngorhinootologie. 1997;76:335-340. [pmid: 9333276].
Schwartz D M, Schwartz R H, Redfield N P. Treatment of negative middle ear pressure and serous otitis media with Politzer's technique. An old procedure revisited. Arch Otolaryngol. 1978;104:487-490. [pmid: 687213].
Schwartz R H. New concepts in otitis media. Am Fam Physician. 1979;19:91-98. [pmid: 312593].
Schwartz RH, Puglese J. Use of a short course of prednisone for treating middle-ear effusions: A double-blind crossover study. J Allergy Clin Immunol. 1979;63.
Schwartz R H, Puglese J, Schwartz D M. Use of a short course of prednisone for treating middle ear effusion. A double-blind crossover study. Ann-Otol-Rhinol-Laryngol-Suppl. 89. 1980:296-300.
Schwartz D M, Schwartz R H. Tympanometric findings in young infants with middle ear effusion: some further observations. Int J Pediatr Otorhinolaryngol. 1980;2:67-72. [pmid: 7188055].
Schwartz D M, Schwartz R H. Acoustic immittance findings in acute otitis media. Ann Otol Rhinol Laryngol Suppl. 1980;89:211-213. [pmid: 6778309].
Schwartz R H, Movassaghi N, Marion E D. Rhabdomyosarcoma of the middle ear: a wolf in sheep's clothing. Pediatrics. 1980;65:1131-1133. [pmid: 7375237].
Schwartz RH, Puglese J, Schwartz DM. Use of a short course of prednisone for treating middle ear effusion: A double-blind crossover study. Ann Otol Rhinol Laryngol. 1980;89.
Schwartz R H, Schwartz D M, Grundfast K M. Intranasal beclomethasone in the treatment of middle ear effusion: A pilot study. Annals of Allergy. 1980;45:284-287. [pmid: 7436055].
Schwartz R H, Rodriquez W J, Grundfast K M. Pharmacologic compliance with antibiotic therapy for acute otitis media: influence on subsequent middle ear effusion. Pediatrics. 1981;68:619-622. [pmid: 7198220].
Schwartz R H, Stool S E, Rodriguez W J, Grundfast K M. Acute otitis media: toward a more precise definition. Clin Pediatr. 1981;20:549-554.
Schwartz R H, Rodriguez W J, Schwartz D M. Office myringotomy for acute otitis media: its value in preventing middle ear effusion. Laryngoscope. 1981;91:616-619. [pmid: 7219006].
Schwartz R H. Otitis media with effusion: Results of treatment with a short course of oral prednisone or intranasal beclomethasone aerosol. Otolaryngology and Head and Neck Surgery. 1981;89:386-391.
Schwartz R H, Puglise J, Rodriguez W J. Sulphamethoxazole prophylaxis in the otitis-prone child. Arch-Dis-Child. 1982;57:590-593. [pmid: 7051984].
Schwartz R H, Rodriguez W J. Trimethoprim-sulfamethoxazole treatment of persistent otitis media with effusion. Pediatr-Infect-Dis. 1982;1:333-335. [pmid: 7155965].
Schwartz RH. Diagnosis of middle ear effusion in office practice. Pediatr Infect Dis. 1982;1.
Schwartz R H, Rodriguez W J, McAveney W, Grundfast K M. Cerumen removal. How necessary is it to diagnose acute otitis media?. Am J Dis Child. 1983;137:1064-1065. [pmid: 6685431].
Schwartz R H, Grundfast K M, Feldman B, Linde R E, Hermansen K L. Cholesteatoma medial to an intact tympanic membrane in 34 young children. Pediatrics. 1984;74:236-240. [pmid: 6540436].
Schwartz R H, Rodriguez W J, Grundfast K M. Duration of middle ear effusion after acute otitis media. Pediatr Infect Dis. 1984;3:204-207. [pmid: 6539913].
Schwartz R H, Hayden G F, Rodriguez W J, Sait T, Chhabra O, Golub J. Leukocyte counts in children with acute otitis media. Pediatr Emerg Care. 1986;2:10-14. [pmid: 3774566].
Schwartz D M, Schwartz R H. Validity of acoustic reflectometry in detecting middle ear effusion. Pediatrics. 1987;79:739-742. [pmid: 3575031].
Schwartz R H. Recalcitrant “acute” otitis media secondary to glue ear [letter]. Pediatr Infect Dis J. 1993;12:356. [pmid: 8483638].
Schwartz B, Giebink G S, Henderson F W, Reichler M R, Jereb J, Collet J P. Respiratory infections in day care. Pediatrics. 1994;94:1018-1020. [pmid: 7971043].
Schwartz R H, Rodriguez W J. Criteria for studies of antibiotic therapy for acute otitis media [letter; comment]. J Pediatr. 1995;126:677-678. [pmid: 7699558].
Schwartz R H, Freij B J, Ziai M, Sheridan M J. Antimicrobial prescribing for acute purulent rhinitis in children: a survey of pediatricians and family practitioners. Pediatr Infect Dis J. 1997;16:185-190. [pmid: 9041598].
Schwartz H C, Sedhom A. Pneumarthrosis of the temporomandibular joint: report of case. Journal of Oral and Maxillofacial Surgery. 1997;55:287-289. [pmid: 9054919].
Scimeca P G, James-Herry A G. Severe, acute thrombocytopenia complicating Mycoplasma infection [letter]. Pediatr Hematol Oncol. 1994;11:557-559. [pmid: 7826851].
Scola E. Our experience with the tympanic isopressor (musco NT3) in the treatment of the pathology of the medium ear caused by a tubaric trouble. Otorinolaringologia Pediatrica. 1990;1:153-155.
Scott T A, Jackler R K. Acute mastoiditis in infancy: a sequela of unrecognized acute otitis media. Otolaryngol Head Neck Surg. 1989;101:683-687. [pmid: 2512557].
Scott B A, Strunk C L Jr. Post-tympanostomy otorrhea: a randomized clinical trial of topical prophylaxis. Otolaryngol-Head-Neck-Surg. 1992;106:34-41. [pmid: 1734364].
Scott B A, Strunk C L Jr. Posttympanostomy otorrhea: the efficacy of canal preparation. Laryngoscope. 1992;102:1103-1107. [pmid: 1405960].
Sculerati N, Ledesma-Medina J, Finegold D N, Stool S E. Otitis media and hearing loss in Turner syndrome. Arch Otolaryngol Head Neck Surg. 1990;116:704-707. [pmid: 2340123].
Sculerati N, Oddoux C, Clayton C M, Lim J W, Oster H. Hearing loss in Turner syndrome. Laryngoscope. 1996;106:992-997. [pmid: 8699915].
Sebring R H, Herrerias C T. The political anatomy of a guideline: a collaborative effort to develop the AHCPR-sponsored practice guideline on otitis media with effusion. Jt Comm J Qual Improv. 1996;22:403-411. [pmid: 8806043].
Sebring R H. Quality improvement: an ACQIP exercise on the management of otitis media. Pediatr Rev. 1996;17:251-256. [pmid: 8710724].
Secord G J, Erickson M T, Bush J P. Neuropsychological sequelae of otitis media in children and adolescents with learning disabilities. J Pediatr Psychol. 1988;13:531-542. [pmid: 3216275].
Sederberg-Olsen JF, Sederberg-Olsen AE, Jensen AM. Late Results of Treatment with Grommets for Middle Ear Condition. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:269–271.
Sederberg-Olsen J F, Sederberg-Olsen A E, Jensen A M. Late results of treatment with ventilation tubes for secretory otitis media in ENT practice. Acta Otolaryngol. 1989;108:448-455. [pmid: 2589073].
Sederberg-Olsen JF, Sederberg-Olsen AE. [Patient compliance in clinical research in the primary and secondary sectors.]. Acta-Otolaryngol-Suppl-Stockh. 1992:129–131.
Sederberg-Olsen J. [Acute otitis media (letter)]. Ugeskr Laeger. 1994;156:4367-4368. [pmid: 8066943].
Sederberg-Olsen J, Sederberg-Olsen N, Thomsen J, Balle V. Problems in recruiting patients to controlled trials on children with secretory otitis media: a demographic comparison of excluded versus included patients. Int J Pediatr Otorhinolaryngol. 1998;43:229-233. [pmid: 9663944].
Seikel K, Shelton S, McCracken G H Jr. Middle ear fluid concentrations of amoxicillin after large dosages in children with acute otitis media. Pediatr Infect Dis J. 1997;16:710-711. [pmid: 9239776].
Sejrsen B, Jakobsen J, Skovgaard L T, Kjaer I. Growth in the external cranial base evaluated on human dry skulls, using nerve canal openings as references. Acta Odontol Scand. 1997;55:356-364. [pmid: 9477028].
Selesnick S H, Patwardhan A. Acute facial paralysis: evaluation and early management. Am J Otolaryngol. 1994;15:387-408. [pmid: 7872475].
Selesnick S H, Carew J F, DiBartolomeo J R. Herniation of the temporomandibular joint into the external auditory canal: a complication of otologic surgery. Am J Otol. 1995;16:751-757. [pmid: 8572137].
Seleznev K G, Shchetinina E A, Trophimenko N P, Nikonov G I, Baskova I P. Use of the medicinal leech in the treatment of ear diseases. ORL J Otorhinolaryngol Relat Spec. 1992;54:1-4. [pmid: 1584585].
Selikowitz M. Short-term efficacy of tympanostomy tubes for secretory otitis media in children with Down syndrome. Dev Med Child Neurol. 1993;35:511-515. [pmid: 8504893].
Selkin S G. The nasopharynx and serous otitis. A new technique for examination and photodocumentation. Int J Pediatr Otorhinolaryngol. 1983;6:291-296. [pmid: 6687123].
Sell S H, Wilson D A, Stamm J M, Chazen E M. Treatment of otitis media caused by Hemophilus influenzae: evaluation of three antimicrobial regimens. South-Med-J. 1978;71:1493-1497. [pmid: 310164].
Sellari-Franceschini S, Berrettini S, Bruschini P, Scazzeri F, Nenci R, Ferrito G. Neuroma of the facial nerve masked by chronic otitis media. Am J Otol. 1994;15:441-444. [pmid: 8579158].
Sellars S L. The closure of tympanic membrane perforations by cautery--a reappraisal. J Laryngol Otol. 1969;83:487-491. [pmid: 5781790].
Sellars S L. The glue ear and rubella risk children. Proceedings of the Royal Society of Medicine. 1969;62:111-112. [pmid: 5813222]. [pmcid: 1810737].
Sellars S L. The origins of mastoid surgery. S Afr Med J. 1974;48:234-242. [pmid: 4592320].
Sellick R J. A simple test of hearing. Practitioner. 1973;210:396-400. [pmid: 4693310].
Semenov FV. [The use of a combined prosthesis for the auditory ossicle chain of the author's own design in tympanoplasty]. Vestn Otorinolaringol. 1996:44.
Semenov FV, Gorbonosov IB, Evglevskii AA, Volik AK. [Use of benzofurocaine in stimulation of regenerative processes in the surgical treatment of patients with chronic suppurative otitis media]. Vestn Otorinolaringol. 1996:45–48.
Semenov FV, Lazareva LA. [Use of YAG-ND laser in the treatment of not healing trepanation cavities after cleansing surgery of the middle ear]. Vestn Otorinolaringol. 1996:14–17.
Semerak A, Praisler J. Audiometric findings in middle-ear secretory-catarrh. Ceskoslovenska Otolaryngologie. 1980;29:5-14. [pmid: 7189449].
Semmler A, Rieger C, Lesinski R. [A case report of malignant hyperthermia in a 14-month-old boy]. Anaesthesiol Reanim. 1994;19:21-22. [pmid: 8141960].
Semones E. Therapy for acute otitis media [letter; comment]. Arch Pediatr Adolesc Med. 1996;150:1315. [pmid: 8954012].
Sen S, Guha S, Biswas A, Ghosh L M. A comparative study of methods of evaluating Eustachian tube function in chronic suppurative otitis media. Indian J Otol. 1999;5:67-70.
Sener R N. Arachnoid cysts and pneumosinus dilatans. Comput Med Imaging Graph. 1997;21:125-129. [pmid: 9152578].
Sennaroglu L, Kaya S, Gursel B, Saatci I. Role of MRI in the diagnosis of otitic hydrocephalus. Am J Otol. 1996;17:784-786. [pmid: 8892577].
Sente M, Ivkic M, Rakic N, Berkes B. [Personal experience in the treatment of chronic secretory otitis in children]. Med Pregl. 1993;46:195-197. [pmid: 7869975].
Sente M. [The effect of adenoidectomy on eustachian tube function]. Med Pregl. 1996;49:45-47. [pmid: 8643070].
Senturia B H. Classification of middle ear effusions. Ann Otol Rhinol Laryngol. 1970;79:358-370. [pmid: 5437649].
Sequi Canet J M, Tomas Vila M, Marco Algarra J, Paredes Cencillo C, Brines Solanes J. Diagnosis of middle ear effusion by means of acoustic reflectometry. An Esp Pediatr. 1996;45:483-486. [pmid: 9036778].
Serra A, Cavallo G, Nicolosi V M, Sutera C, Nicoletti G. [Etiology and rational therapy of acute otitis media in adults]. G Batteriol Virol Immunol. 1994;86:121-125. [pmid: 8706971].
Serrarols Soldevila M, Anglada Arisa A, Ledesma Castelltort A. [Old diseases and new antibiotics]. Aten Primaria. 1993;12:679-681. [pmid: 8117890].
Sethi B R. Kartagener's syndrome and its otological manifestations. J Laryngol Otol. 1975;89:183-188. [pmid: 47376].
Severien C, Lehners T H. Epidemiology of invasive Haemophilus influenzae disease in a German city. Klinische Padiatrie. 1994;206:108-111. [pmid: 8196307].
Shaaban K M, Hamadnalla I. The effect of duration of breast feeding on the occurrence of acute otitis media in children under three years. East Afr Med J. 1993;70:632-634. [pmid: 8187659].
Shaan M, Landolfi M, Taibah A, Russo A, Szymanski M, Sanna M. Modified Bondy technique. Am J Otol. 1995;16:695-697. [pmid: 8588680].
Shaffer H L, Gates G A, Meyerhoff W L. Acute mastoiditis and cholesteatoma. Otolaryngology. 1978;86:ORL394-399. [pmid: 112528].
Shah N. Secretory otitis media. A clinical survey. J Laryngol Otol. 1968;82:739-744. [pmid: 5671214].
Shah N. Glue ear: diagnosis and management. Proceedings of the Royal Society of Medicine. 1975;68:37-38. [pmid: 1187666]. [pmcid: 1863708].
Shamboul K M. An unusual prevalence of complications of chronic suppurative otitis media in young adults. J Laryngol Otol. 1992;106:874-877. [pmid: 1474307].
Shanks J E. Tympanometry. Ear Hear. 1984;5:268-280. [pmid: 6542036].
Shapiro S L. Disarticulation of the incus. Eye, Ear, Nose and Throat Monthly. 1967;46:922-927.
Shapiro G G, Bierman C W, Furukawa C T, et al. Treatment of persistent eustachian tube dysfunction in children with aerosolized nasal dexamethasone phosphate versus placebo. Ann-Allergy. 1982;49:81-85. [pmid: 7103152].
Shapiro AM, Bluestone CD. Otitis media reassessed. Up-to-date answers to some basic questions. Postgrad Med. 1995;97:73–76, 79–82.
Share D L, Chalmers D, Silva P A, Stewart I A. Reading disability and middle ear disease. Arch Dis Child. 1986;61:400-401. [pmid: 3707193].
Sharpe W D. Chronic radium intoxication: clinical and autopsy findings in long-term New Jersey survivors. Environ Res. 1974;8:243-383. [pmid: 4141963].
Shaw J O, Stark E W, Gannaway S D. The influence of nitrous oxide anaesthetic on middle-ear fluid. J Laryngol Otol. 1978;92:131-135. [pmid: 627766].
Shaw C B, Obermyer N, Wetmore S J, Spirou G A, Farr R W. Incidence of adenovirus and respiratory syncytial virus in chronic otitis media with effusion using the polymerase chain reaction. Otolaryngol Head Neck Surg. 1995;113:234-241. [pmid: 7675483].
Shea M C, Glasscock M Ed. Tragal cartilage as an ossicular substitute. Arch Otolaryngol. 1967;86:308-317. [pmid: 6034659].
Shea M C Jr, Gardner G Jr. Mastoid obliteration using homograft bone. Preliminary report. Arch Otolaryngol. 1970;92:358-365. [pmid: 4917080].
Shea J J. Autoinflation treatment of serous otitis media in children. J Laryngol Otol. 1971;85:1254-1258. [pmid: 5130576].
Shea M C. Stapes fixation in chronic middle ear disease. Laryngoscope. 1976;86:230-232. [pmid: 1053363].
Sheard N F. Breast-feeding protects against otitis media. Nutr Rev. 1993;51:275-277. [pmid: 8247421].
Sheehy J L, Patterson M E. Intact canal wall tympanoplasty with mastoidectomy. A review of eight years' experience. Laryngoscope. 1967;77:1502-1542. [pmid: 6034865].
Sheehy J L, Crabtree J A. Tympanoplasty: staging the operation. Laryngoscope. 1973;83:1594-1621. [pmid: 4758763].
Sheehy J L. Cholesteatoma surgery in children. Acta Otorhinolaryngol Belg. 1980;34:98-106. [pmid: 7193397].
Sheehy J L. TORPs and PORPs: causes of failure--a report on 446 operations. Otolaryngol Head Neck Surg. 1984;92:583-587. [pmid: 6438591].
Sheeran P W, Smith A L, Mendelman P L. The susceptibility of Haemophilus influenzae middle ear and sinus isolates to sulphisoxazole [letter]. J Antimicrob Chemother. 1994;33:360-363. [pmid: 8182026].
Sheikha A, Kameswaran M, Okafor B C, al-Saigh A A. Otological manifestations of thalassaemia intermedia: evidence of temporal bone involvement and report of a unique cholesteatoma-like lesion. J Laryngol Otol. 1992;106:316-321. [pmid: 1613342].
Sheldon T, Freemantle N. Persistent glue ear in children [letter; comment]. Br Med J. 1993;306:650-651. [pmid: 8461832].
Shelton C, Sheehy J L. Tympanoplasty: review of 400 staged cases. Laryngoscope. 1990;100:679-681. [pmid: 2362526].
Shenderey K, Marsh B T, Talbot D J. A multi-centre general practice comparison of a fixed-dose combination of pivmecillinam plus pivampicillin with amoxycillin in respiratory tract infections. Pharmatherapeutica. 1985;4:300-305. [pmid: 4070323].
Sheppard I J, Moir A A, Thomas R S, Narula A A. Organization of day-case adenoidectomy in the management of chronic otitis media with effusion--preliminary results. J R Soc Med. 1993;86:76-78. [pmid: 8433311]. [pmcid: 1293853].
Shigemi H, Kaneda N, Hori F, Watanabe N, Mogi G. Congenital middle ear cholesteatoma: report of 3 cases. Auris Nasus Larynx. 1991;18:291-296. [pmid: 1799333].
Shilkin R. Maternal postnatal depression and infant gastrooesophageal reflux [letter; comment]. Journal of Paediatrics and Child Health. 1994;30:287-288. [pmid: 8074925].
Shimizu K. Clinical experience with gentamicin in Japan. J Infect Dis. 1969;119:448-452. [pmid: 5788734].
Shinkawa H, Ishidoya M, Okitsu T. Changes in tympanograms after middle ear inflation. Eur Arch Otorhinolaryngol. 1990;247:125-128. [pmid: 2317361].
Shinkawa A, Sakai M, Tamura Y, Takahashi H, Ishida K. Canal-down tympanoplasty; one-stage tympanoplasty with mastoid obliteration, for non-cholesteatomatous chronic otitis media associated with osteitis. Tokai J Exp Clin Med. 1998;23:19-23. [pmid: 9972532].
Shinkwin C A, Murty G E, Simo R, Jones N S. Per-operative antibiotic/steroid prophylaxis of tympanostomy tube otorrhoea: chemical or mechanical effect?. J Laryngol Otol. 1996;110:531-533. [pmid: 8763370].
Shiwa M, Kojima H, Kamide Y, Moriyama H. Involvement of interleukin-1 in middle ear cholesteatoma. Am J Otolaryngol. 1995;16:319-324. [pmid: 7503375].
Shojaku H, Watanabe Y, Mizukoshi K, et al. Epidemiological study of severe cases of Meniere's disease in Japan. Acta Oto-Laryngologica - Supplement. 1995;520:415-418.
Shone G R, Griffith I P. Titanium grommets: a trial to assess function and extrusion rates. J Laryngol Otol. 1990;104:197-199. [pmid: 2341773].
Shriberg L D, Smith A J. Phonological correlates of middle-ear involvement in speech-delayed children: a methodological note. J Speech Hear Res. 1983;26:293-297. [pmid: 6887817].
Shriberg L D, Friel-Patti S, Flipsen P J, Brown R L. Otitis media, fluctuant hearing loss, and speech-language outcomes: a preliminary structural equation model. J Speech Lang Hear Res. 2000;43:100-120. [pmid: 10668655].
Shubich I. Otitis media with effusion and allergy control in children: a prospective study. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:173–174.
Shurin PA, Pelton SI, Klein JO. Otitis media in the newborn infant. The Annals of Otology, Rhinology and Larynogology; 1976:216–222.
Shurin PA. Antibacterial therapy and middle ear effusionsThe Annals of Otology, Rhinology and Larynogology; 1976:250–253.
Shurin P A, Pelton S I, Finkelstein J. Tympanometry in the diagnosis of middle-ear effusion. N Engl J Med. 1977;296:412-417. [pmid: 834211].
Shurin P A, Pelton S I, Donner A, Klein J O. Persistence of middle-ear effusion after acute otitis media in children. N Engl J Med. 1979;300:1121-1123. [pmid: 431635].
Shurin P A, Pelton S I, Donner A, Finkelstein J, Klein J O. Trimethoprim-sulfamethoxazole compared with ampicillin in the treatment of acute otitis media. J Pediatr. 1980;96:1081-1087. [pmid: 6966331].
Shurin PA, Marchant CD, Johnson CE, Morledge T, Wegman D, Fehribch J. Tympanometric determination of the outcome of acute otitis media. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:20–22.
Shurin P A, Rehmus J M, Johnson C E, et al. Bacterial polysaccharide immune globulin for prophylaxis of acute otitis media in high-risk children [see comments]. J Pediatr. 1993;123:801-810. [pmid: 8229496].
Shurin P A. Evaluation of antimicrobial drugs for acute otitis media [editorial]. Int J Pediatr Otorhinolaryngol. 1996;34:219-223. [pmid: 8839071].
Shy C. Summary report of the panel. Panel of the Workshop on Public Health Response to Nasopharyngeal Radium Irradiation. Otolaryngol Head Neck Surg. 1996;115:442-446. [pmid: 8903445].
Shyu W C, Haddad J, Reilly J, et al. Penetration of cefprozil into middle ear fluid of patients with otitis media. Antimicrob-Agents-Chemother. 1994;38:2210-2212. [pmcid: 284715]. [pmid: 7811050].
Siddiqui N, Toynton S, Mangat K S. Results of middle ear ventilation with ‘Mangat’ T-tubes. Int J Pediatr Otorhinolaryngol. 1997;40:91-96. [pmid: 9225174].
Sie K C Y. Cholesteatoma in children. Pediatr Clin North Am. 1245;43:1245-1252. [pmid: 8973511].
Sih T, Moura R, Caldas Sl. Profilaxia das otites médias de repeti‡,,o: um perfil brasileiro / Prophylaxis of recurrent otitis media: a brazilian profile. Rev.-bras.-otorrinolaringol. 1990;56:145-146.
Sih T, Moura R, Caldas S, Schwartz B. Prophylaxis for recurrent acute otitis media: a Brazilian study. Int J Pediatr Otorhinolaryngol. 1993;25:19-24. [pmid: 8436464].
Siim C, Tos M. Partial and total reconstruction of old radical cavities. Long-term results. Arch Otolaryngol Head Neck Surg. 1987;113:635-643. [pmid: 3566947].
Silman S, Silverman C A, Arick D S. Acoustic-immittance screening for detection of middle-ear effusion in children. J Am Acad Audiol. 1992;3:262-268. [pmid: 1421458].
Silman S, Silverman C A, Arick D S. Pure-tone assessment and screening of children with middle-ear effusion. J Am Acad Audiol. 1994;5:173-182. [pmid: 8075413].
Silva P A, Kirkland C, Simpson A, Stewart I A, Williams S M. Some developmental and behavioral problems associated with bilateral otitis media with effusion. Journal of Learning Disabilities. 1982;15:417-421. [pmid: 6891396].
Silva P A, Chalmers D, Stewart I. Some audiological, psychological, educational and behavioral characteristics of children with bilateral otitis media with effusion: a longitudinal study. Journal of Learning Disabilities. 1986;19:165-169. [pmid: 3958605].
Silva A B, Hotaling A J. A protocol for otolaryngology-head and neck resident training in pneumatic otoscopy. Int J Pediatr Otorhinolaryngol. 1997;40:125-131. [pmid: 9225178].
Silver A J, Mawad M E, Hilal S K, Sane P, Ganti S R. Computed tomography of the nasopharynx and related spaces. Part II: Pathology. Radiology. 1983;147:733-738. [pmid: 6302735].
Silver A J, Sane P, Hilal S K. CT of the nasopharyngeal region. Normal and pathologic anatomy. Radiol Clin North Am. 1984;22:161-176. [pmid: 6538690].
Silver F M, Orobello P W Jr, Mangal A, Pensak M L. Asymptomatic osteomas of the middle ear. Am J Otol. 1993;14:189-190. [pmid: 8503496].
Silverglade D. Dental pain without dental etiology: a manifestation of referred pain from otitis media. ASDC J Dent Child. 1980;47:358-359. [pmid: 6931843].
Silverman C A, Silman S. Acoustic-immittance characteristics of children with middle-ear effusion: longitudinal investigation. J Am Acad Audiol. 1995;6:339-345. [pmid: 7548934].
Silverstein H. Ossicular reconstruction. In chronic seromucinous otitis media. Arch Otolaryngol. 1971;93:42-45. [pmid: 5538739].
Silverstein H, Fabian R L, Stoll S E, Hong S W. Penetrating wounds of the tympanic membrane and ossicular chain. Transactions - American Academy of Ophthalmology and Otolaryngology. 1973;77:ORL125-35. [pmid: 4581395].
Silverstein H, McDaniel A B, Lichtenstein R. A comparison of PORP, TORP, and incus homograft for ossicular reconstruction in chronic ear surgery. Laryngoscope. 1986;96:159-165. [pmid: 3753735].
Silverstein H, Kuhn J, Choo D, Krespi Y P, Rosenberg S I, Rowan P T. Laser-assisted tympanostomy. Laryngoscope. 1996;106:1067-1074. [pmid: 8822707].
Simmons F B. Patients with bilateral loss of caloric response. Ann Otol Rhinol Laryngol. 1973;82:175-178. [pmid: 4540812].
Simoes E A, Groothuis J R, Tristram D A, et al. Respiratory syncytial virus-enriched globulin for the prevention of acute otitis media in high risk children [see comments]. J Pediatr. 1996;129:214-219. [pmid: 8765618].
Simon M W. Children with unilateral acute otitis media may have a temperature differential when both ears are measured by an infrared ear thermometer [letter]. Pediatr Emerg Care. 1996;12:324. [pmid: 8966139].
Simon M W. Five- vs 10-day treatment of acute otitis media with ceftibuten in infants and children. Advances in Therapy. 1997;14:312-317.
Simon M W. Diagnostic and therapeutic tympanocentesis [letter]. Clin Pediatr. 1997;36:309.
Simonet M, De B r i e l D, Boucot I, Minck R, Veron M. Coryneform bacteria isolated from middle ear fluid. J Clin Microbiol. 1993;31:1667-1668. [pmcid: 265604]. [pmid: 8315016].
Sinanan E G. Re: Article on granular myringitis: a review [letter; comment]. J Otolaryngol. 1993;22:207. [pmid: 8371335].
Singh B. The management of lateral sinus thrombosis. J Laryngol Otol. 1993;107:803-808. [pmid: 8228594].
Singh B, Maharaj T J. Radical mastoidectomy: its place in otitic intracranial complications. J Laryngol Otol. 1993;107:1113-1118. [pmid: 8288998].
Singhal S, Sharma S C, Singhal K C. Adverse reactions to gentamycin in patients with ear, nose or throat infections. Indian J Physiol Pharmacol. 1992;36:189-192. [pmid: 1473850].
Sipila P, Ryhanen P, Karma P. T cells as marked with acid alpha-naphthyl acetate esterase staining in secretory otitis media. Acta Oto-Laryngologica - Supplement. 1979;360:216-220.
Sipila P, Sutinen S, Sutinen S H, Karma P. Ultrastructural morphology of mucoid effusion in secretory otitis media. Acta Oto Laryngologica. 1980;90:342-352. [pmid: 7211328].
Sirakova T, Kolattukudy P E, Murwin D, et al. Role of fimbriae expressed by nontypeable Haemophilus influenzae in pathogenesis of and protection against otitis media and relatedness of the fimbrin subunit to outer membrane protein A. Infect Immun. 1994;62:2002-2020. [pmcid: 186460]. [pmid: 7909539].
Siri Arce M T, Bercovich W M, Prado Jim,nez V. Barroihlet Amen bar G. Estudio prospectivo, comparativo de la eficacia de sulfametopirazina-trimetoprim (kelfiprim) en relac¢n a ampicilina oral, en lactantes con otitis media aguda / Comparative and prospective study of sulfamethopyrazine efficacy (kelfiprim) in relation to oral ampicillin in infants with acute otitis media. Rev.-chil.-infectologia. 1984;1:70-76.
Skarzynski H, Zawadowski J, Niemczyk K, Balcerzak J. [The external drainage in chronic exudative otitis media: distant results]. Otolaryngol Pol. 1993;47:525-528. [pmid: 8164958].
Skinner D W, Lesser T H, Richards S H. A 15 year follow-up of a controlled trial of the use of grommets in glue ear. Clin Otolaryngol Allied Sci. 1988;13:341-346. [pmid: 3243009].
Skoner D P, Doyle W J, Fireman P. Eustachian tube obstruction (ETO) after histamine nasal provocation--a double-blind dose-response study. J-Allergy-Clin-Immunol. 1987;79:27-31. [pmid: 3805544].
Skoner D P, Angelini B L, Jones A, Seroky J, Doyle W J, Fireman P. Suppression of in vivo cell-mediated immunity during experimental influenza A virus infection of adults. Int J Pediatr Otorhinolaryngol. 1996;38:143-153. [pmid: 9119602].
Skull S A, Morris P S, Yonovitz A, et al. Middle ear effusion: rate and risk factors in Australian children attending day care. Epidemiol Infect. 1999;123:57-64. [pmid: 10487642].
Slaby D. Familial early profound deafness in an Athabascan kindred. Alaska Med. 1982;24:18-19. [pmid: 7103010].
Sleeckx J P, Shea J J, Pitzer F J. Epitympanic ossicular fixation. Arch Otolaryngol. 1967;85:619-631. [pmid: 6024491].
Sleeman M. Conductive deafness in children. N Z Med J. 1966;65:118-119. [pmid: 5218624].
Sloth H, Lildholdt T. Tests of eustachian tube function and ear surgery. Clin Otolaryngol Allied Sci. 1989;14:227-230. [pmid: 2743611].
Sloyer J L Jr, Ploussard J H, Karr L J, Schiffman G D. Immunologic response to pneumococcal polysaccharide vaccine in infants. Ann-Otol-Rhinol-Laryngol-Suppl. 1980;89:351-356. [pmid: 6778345].
Sloyer JLJ, Ploussard JH, Howie VM. Efficacy of pneumococcal polysaccharide vaccine in preventing acute otitis media in infants in Huntsville, Alabama. Rev-Infect-Dis. 1981:S119–S123.
Sluchanko AP, Sodnomzhamsoev DD. [Hemangioma of the tympanic cavity in a patient with chronic suppurative otitis media]. Vestn Otorinolaringol. 1996:45.
Sly R M, Zambie M F, Fernandes D A, Frazer M. Tympanometry in kindergarten children. Annals of Allergy. 1980;44:1-7. [pmid: 7352686].
Smeak D D, Crocker C B, Birchard S J. Treatment of recurrent otitis media that developed after total ear canal ablation and lateral bulla osteotomy in dogs: nine cases (1986-1994). J Am Vet Med Assoc. 1996;209:937-942. [pmid: 8790545].
Smith C R, Brown A K Jr, Hartvigsen R E. Auditory and nonauditory bone-conduction responses. Arch Otolaryngol. 1967;85:617-618. [pmid: 6024490].
Smith K R Jr. Idiopathic bilateral sigmoid sinus occlusion in a child: case report. J Neurosurg. 1968;29:427-430. [pmid: 5699507].
Smith M F. Composite reconstruction of the open mastoidectomy ear. Transactions - American Academy of Ophthalmology and Otolaryngology. 1970;74:1166-1182. [pmid: 4924045].
Smith R, Moran W B. Tympanic membrane keratoma (cholesteatoma) in children with no prior otologic surgery. Laryngoscope. 1977;87:237-245. [pmid: 839921].
Smith M W, Herzon F S. Electroacoustic assessment of the semipermeable tympanic ventilating tube. A physical model. Arch Otolaryngol. 1980;106:350-351. [pmid: 7378021].
Smith C G, Paradise J L, Young T I. Modified schema for classifying positive-pressure tympanograms. Pediatrics. 1982;69:351-354. [pmid: 7063292].
Smith C W. Smith-McGuckin spot. J R Soc Med. 1985;78:18-26. [pmid: 4038519].
Smith P G, Stroud M H, Goebel J A. Soft-wall reconstruction of the posterior external ear canal wall. Otolaryngol Head Neck Surg. 1986;94:355-359. [pmid: 3083364].
Smith S, Anders B. Tuberculosis mastoiditis caused by Mycobacterium bovis. Pediatr Infect Dis J. 1994;13:538-539. [pmid: 8078744].
Smith A W, Hatcher J, Mackenzie I J, et al. Randomised controlled trial of treatment of chronic suppurative otitis media in Kenyan schoolchildren [see comments]. Lancet. 1996;348:1128-1133. [pmid: 8888166].
Smith A W, Hatcher J, Mackenzie I J, et al. Randomised controlled trial of treatment of chronic suppurative otitis media in Kenyan schoolchildren. Lancet. 1996;348:1128-1133. [pmid: 8888166].
Smith D W, Olszyk V B. Auditory behavioral thresholds for Japanese macaques using insert earphones. Am J Primatol. 1997;41:323-329. [pmid: 9093695].
Smith S C, Haggard M P, Bennett K E, et al. Communication tactics used by parents of children with OME (glue ear). Psychol Health Med. 1999;4:333-344.
Smith-Vaughan H C, Leach A J, Shelby-James T M, Kemp K, Kemp D J, Mathews J D. Carriage of multiple ribotypes of non-encapsulated Haemophilus influenzae in aboriginal infants with otitis media. Epidemiol Infect. 1996;116:177-183. [pmid: 8620909].
Smith-Vaughan H C, Sriprakash K S, Mathews J D, Kemp D J. Nonencapsulated Haemophilus influenzae in Aboriginal infants with otitis media: prolonged carriage of P2 porin variants and evidence for horizontal P2 gene transfer. Infect Immun. 1997;65:1468-1174. [pmcid: 175155]. [pmid: 9119489].
Smyth G D, Kerr A G, Goodey R J. Current thoughts on combined approach tympanoplasty. I. Indications and preoperative assessment. J Laryngol Otol. 1971;85:205-212. [pmid: 5550603].
Smyth G D. The surgical treatment of chronic otitis media in children. J Otolaryngol. 1976;5:446-452. [pmid: 796481].
Smyth G D, Hassard T H. Tympanoplasty in children. Am J Otol. 1980;1:199-205. [pmid: 7457584].
Smyth G D. TORPs--how have they fared after five years?. J Laryngol Otol. 1983;97:991-993. [pmid: 6644167].
Smyth G D. Etiologic aspects and pathogenesis of persistent middle ear effusion. Am J Otol. 1984;5:286-290. [pmid: 6232855].
Smyth G D. Cholesteatoma surgery: the influence of the canal wall. Laryngoscope. 1985;95:92-96. [pmid: 3965838].
Sneed W F. Lateral sinus thrombosis. Am J Otol. 1983;4:258-262. [pmid: 6829741].
Snik A F, Mylanus E A, Cremers C W. Speech recognition with the bone-anchored hearing aid determined objectively and subjectively. Ear Nose Throat J. 1994;73:115-117. [pmid: 8168444].
Snik A F, Mylanus E A, Cremers C W. Bone-anchored hearing aids in patients with sensorineural hearing loss and persistent otitis externa. Clin Otolaryngol. 1995;20:31-35. [pmid: 7788931].
Snow J C, Kripke B J, Strong M S. Management of general anesthesia for mastoid-tympanoplasty: anesthesia and surgical considerations. Laryngoscope. 1973;83:1786-1793. [pmid: 4758137].
Snow J B Jr, Naunton R F. Research in the auditory and vestibular systems. The recommendations of the National Institute on Deafness and Other Communication Disorders National Strategic Research Plan. ORL J Otorhinolaryngol Relat Spec. 1993;55:154-158. [pmid: 8391676].
Snow J B Jr. News from the National Institute on Deafness and Other Communication Disorders [news]. Am J Otol. 1994;15:132-136. [pmid: 8172291].
Snow J B Jr. News from the National Institute on Deafness and Other Communication Disorders. Am J Otol. 1997;18:285-287. [pmid: 9149818].
Sobol S M, Reichert T J, Faw K D, Stroud M H, Spector G J, Ogura J H. Intramembranous and mesotympanic cholesteatomas associated with an intact tympanic membrane in children. Ann Otol Rhinol Laryngol. 1980;89:312-317. [pmid: 7416680].
Soda Merhy A, Hernandez Goribar M. Treatment of otitis media with trimethoprim-sulfamethoxypirazine. Investigacion Medica Internacional. 1985;12:103-107.
Sofianou D, Selviarides P, Sofianos E, Tsakris A, Foroglou G. Etiological agents and predisposing factors of intracranial abscesses in a Greek university hospital. Infection. 1996;24:144-146. [pmid: 8740108].
Sokolovski A. Ossicular reconstruction in the absence of stapedial crura. Clin Otolaryngol Allied Sci. 1978;3:273-277. [pmid: 737861].
Solter M, Paljan D. Variations in shape and dimensions of sigmoid groove, venous portion of jugular foramen, jugular fossa, condylar and mastoid foramina classified by age, sex and body side. Zeitschrift fur Anatomie und Entwicklungsgeschichte. 1973;140:319-335. [pmid: 4749136].
Somekawa Y, Kobayashi K, Yamaguchi T, et al. Long-term result of grommets in children with secretory otitis media. Journal of Otolaryngolgoy. 1985;88:261-266.
Somers T, Houben V, Goovaerts G, Govaerts P J, Offeciers F E. Histology of the perforated tympanic membrane and its muco-epithelial junction. Clin Otolaryngol. 1997;22:162-166. [pmid: 9160932].
Song C, Huang P, Li C. [Restoration of external auditory canal by filling mastoid cavity with carbon pellet]. Chung Hua Erh Pi Yen Hou Ko Tsa Chih - Chinese Journal of Otorhinolaryngology. 1996;31:33-35.
Sorensen C H, Holm-Jensen S, Tos M. The post-winter prevalence rate of middle ear effusion in four-year-old children, judged by tympanometry. Int J Pediatr Otorhinolaryngol. 1981;3:119-128. [pmid: 7287314].
Sorensen C H, Holm-Jensen S. Middle ear effusion and risk factors. J Otolaryngol. 1982;11:46-51. [pmid: 7200526].
Sorensen C H. Quantitative aspects of IgD and secretory immunoglobulins in middle ear effusions. Int J Pediatr Otorhinolaryngol. 1983;6:247-253. [pmid: 6687122].
Sorensen C H, Andersen L P, Tos M, Thomsen J, Holm-Jensen S. Nasopharyngeal bacteriology and secretory otitis media in young children. Acta Otolaryngol. 1988;105:126-131. [pmid: 3257598].
Sorensen C H, Sorensen U B, Henrichsen J. Local production of IgG to pneumococcal C-polysaccharide in upper airway secretions from children with recurrent acute otitis media. Microb Pathog. 1989;6:183-191. [pmid: 2739559].
Sorrell M J, Tribble J, Reinisch L, Werkhaven J A, Ossoff R H. Bacteria identification of otitis media with fluorescence spectroscopy. Lasers Surg Med. 1994;14:155-163. [pmid: 8183049].
Sorri M, Sipila P, Palva A, Karma P. Can secretory otitis media be prevented by oral decongestants?. ACTA OTO-LARYNGOL. 1982;94:115-116.
Sorri M, Rantakallio P. Respiratory tract disease and hearing loss. Scandinavian Audiology Supplementum. 1986;26:85-87. [pmid: 3472334].
Sorri M, Rantakallio P. Secretory otitis media and hearing loss. Acta Oto Laryngologica Supplement. 1989;107:94-99.
Sorri M, Maki-Torkko E, Alho O P. Otitis media and long-term follow-up of hearing. Acta-Otolaryngol-Stockh. 1995;109:811-816.
Sorri M, Alho O P, Oja H. Dynamic multivariate modelling: day care and consultation rate for acute otitis media. Acta Otolaryngol. 1996;116:299-301. [pmid: 8725536].
Soteras Olle J, Palomar Garcia V. [The mucosal subepithelial space in the middle ear in prolonged tubal dysfunction]. Acta Otorrinolaringol Esp. 1995;46:405-408. [pmid: 8554818].
Soucek S, Michaels L. The ear in the acquired immunodeficiency syndrome: II. Clinical and audiologic investigation. Am J Otol. 1996;17:35-39. [pmid: 8694132].
Soushko Y A, Borissenko O N, Yalovoi S F. [Application of osseous allografts in surgery of the middle ear. Authors' experience]. Rev Laryngol Otol Rhinol. 1993;114:129-133.
Sox H, Stern S, Owens D, Abrams HL. Assessment of diagnostic technology in health care: Rationale, methods, problems, and directions. Washington, D.C.: National Academy Press; 1989.
Spauwen P H M, Ritsma R J, Huffstadt B J C, Schutte H K, Brown I F. The inferiorly based pharyngoplasty: Effects on chronic otitis media with effusion. Cleft Palate Journal. 1988;25:26-32. [pmid: 3422596].
Spauwen P H, Goorhuis-Brouwer S M, Schutte H K. Cleft palate repair: Furlow versus von Langenbeck. J-Craniomaxillofac-Surg. 1992;20:18-20. [pmid: 1564114].
Spector G J, Smith P G. Endolymphatic sac surgery for Meniere's disease. Ann Otol Rhinol Laryngol. 1983;92:113-118. [pmid: 6838098].
Spector S L. Overview of comorbid associations of allergic rhinitis. J Allergy Clin Immunol. 1997;99:S773-S780. [pmid: 9042070].
Spencer M G. Suction tube noise and myringotomy. J Laryngol Otol. 1980;94:383-386. [pmid: 7190179].
Spencer M J. Diagnosis of middle ear effusion and infection. Am J Nurs. 1981;81:1482. [pmid: 6910988].
Sperati G. [Francesco II of Valois: a historical case of otogenic meningitis (corrected and republished in Acta Otorhinolaryngol Ital 1996 Feb;16(1):62–5)]. Acta Otorhinolaryngol Ital. 1995;15:317-319. [pmid: 8928665].
Sperati G. [The historic corner. Francesco II of Valois: a historic case of otogenic meningitis (corrected and republished article originally printed in Acta Otorhinolaryngol Ital 1995 Aug;15(4):317–9)]. Acta Otorhinolaryngol Ital. 1996;16:62-65. [pmid: 8984844].
Sperber S J, Doyle W J, McBride T P, Sorrentino J V, Riker D K, Hayden F G. Otologic effects of interferon beta serine in experimental rhinovirus colds. Arch Otolaryngol Head Neck Surg. 1992;118:933-936. [pmid: 1323974].
Spiewak W. [A case of coexisting tuberculous otitis media and pulmonary tuberculosis]. Pneumonol Alergol Pol. 1995;63:436-439. [pmid: 8520565].
Spigno G, Teatini G P. Assessment of the effectiveness of carbocysteine in the treatment of catarrhal otitis. Otorinolaryngologia. 1981;31:461-464.
Spilman D A, O'sullivan N L, Montgomery P C. A study of lymphocyte adherence to middle ear mucosal tissue. Adv Exp Med Biol. 1995;371B:745-748. [pmid: 7502890].
Spilseth P. Appropriateness of tympanostomy tubes. Family Practice Research Journal. 1992;12:43-52. [pmid: 1549947].
Spindler J J, Marsh B T, Talbot D J. Respiratory infections in general practice: A clinical comparison of Pivmecillinam-plus-pivampicillin (Miraxid) and Cephalexin (Ceporex). CLIN. TRIALS J. 1985;22:293-299.
Spingarn A T, Isaacs R S, Levenson M J. Complications of acute streptococcal otitis media: a resurgence. Otolaryngol Head Neck Surg. 1994;111:644-646. [pmid: 7970804].
Spraggs P D, Robinson P J, Ryan R, East C A, Graham J M. A prospective randomised trial of the use of sodium bicarbonate and hydrogen peroxide ear drops to clear a blocked tympanostomy tube. Int J Pediatr Otorhinolaryngol. 1995;31:207-214. [pmid: 7782178].
Sprem N, Branica S. Effects of sulphur dioxide and smoke on the incidence of secretory otitis media [see comments]. Arh Hig Rada Toksikol. 1993;44:229-232. [pmid: 8311696].
Sprem N, Branica S. Effect of climatic elements on the frequency of secretory otitis media. Eur Arch Otorhinolaryngol. 1993;250:286-288. [pmid: 8217131].
St Geme J Wd, Falkow S, Barenkamp S J. High-molecular-weight proteins of nontypable Haemophilus influenzae mediate attachment to human epithelial cells. Proc Natl Acad Sci USA. 1993;90:2875-2879. [pmcid: 46199]. [pmid: 8464902].
St. Geme J Wd. Nontypeable Haemophilus influenzae disease: epidemiology, pathogenesis, and prospects for prevention. Infect Agents Dis. 1993;2:1-16. [pmid: 8162349].
Stahl J P, Archimbaud A, Baud P, et al. Treatment of acute otitis media in children: Comparison of cefuroxime axetil and amoxicillin-clavulanate suspensions. Medecine Et Maladies Infectieuses. 1995;25:147-153.
Stamm A C, Pinto J A, Coser P L, Marigo C. Nonspecific necrotizing petrositis: an unusual complication of otitis in children. Laryngoscope. 1984;94:1218-1222. [pmid: 6433126].
Stange G. Delay in language development due to moist tubotympanal catarrh. Sprache Stimme Gehor. 1982;6:10-12.
Stangerup S E, Tos M. The etiologic role of acute suppurative otitis media in chronic secretory otitis. Am J Otol. 1985;6:126-131. [pmid: 3872600].
Stangerup S E, Sederberg-Olsen J, Balle V H. [Treatment with the Otovent device in tubal dysfunction and secretory otitis media in children]. Ugeskr-Laeger. 1991;153:3008-3009. [pmid: 1801386].
Stangerup S E, Sederberg-Olsen J, Balle V. Autoinflation as a treatment of secretory otitis media. A randomized controlled study. Arch Otolaryngol Head Neck Surg. 1992;118:149-152. [pmid: 1540344].
Stangerup SE, Sederberg-Olsen JF, Balle V. Autoinflation as the initial treatment of tubal dysfunction. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:267–269.
Stangerup S E, Tos M, Arnesen R, Larsen P. A cohort study of point prevalence of eardrum pathology in children and teenagers from age 5 to age 16. Eur Arch Otorhinolaryngol. 1994;251:399-403. [pmid: 7857627].
Stangerup S E, Schwer S, Pedersen K, Brofeldt S, Niebuhr M. Prevalence of eardrum pathology in a cohort born in 1955. J Laryngol Otol. 1995;109:281-285. [pmid: 7782680].
Stangerup S E, Tjernstrom O, Harcourt J, Klokker M, Stokholm J. Barotitis in children after aviation; prevalence and treatment with Otovent. J Laryngol Otol. 1996;110:625-628. [pmid: 8759532].
Stapells D R, Ruben R J. Auditory brain stem responses to bone-conducted tones in infants. Ann Otol Rhinol Laryngol. 1989;98:941-949. [pmid: 2589762].
Stark E W, Borton T E. Klippel-Feil syndrome and associated hearing loss. Arch Otolaryngol. 1973;97:415-419. [pmid: 4703539].
Stasche N, Foth H J, Hormann K. [Laser Doppler vibrometry of the tympanic membrane. Possibilities for objective middle ear diagnosis]. HNO. 1993;41:1-6. [pmid: 8449781].
Stasche N, Foth H J, Hormann K, Baker A, Huthoff C. Middle ear transmission disorders--tympanic membrane vibration analysis by laser-Doppler-vibrometry [see comments]. Acta Otolaryngol. 1994;114:59-63. [pmid: 8128855].
StataCorp. Stata Statistical Software: Release 6.0. : College Station, TX: Stata Corporation; 1999.
Stechenberg B W, Anderson D, Chang M J, et al. Cephalexin compared to ampicillin treatment of otitis media. Pediatrics. 1976;58:532-536. [pmid: 787913].
Steele C H. An otolaryngologist views the tonsil and adenoid problem. American Journal of Orthodontics. 1968;54:485-491. [pmid: 5240644].
Stenberg A E, Nylen O, Windh M, Hultcrantz M. Otological problems in children with Turner's syndrome. Hear Res. 1998;124:85-90. [pmid: 9822905].
Stenfelt S P, Hakansson B E. A miniaturized artificial mastoid using a skull simulator. Scand Audiol. 1998;27:67-76. [pmid: 9638825].
Stenfors L E, Raisanen S. Quantitative analysis of the bacterial findings in otitis media. J Laryngol Otol. 1990;104:749-757. [pmid: 2123229].
Stenfors L E, Raisanen S. Immunoglobulin-coated bacteria in effusions from secretory and chronic suppurative otitis media. Am J Otolaryngol. 1991;12:161-164. [pmid: 1928600].
Stenfors L E, Raisanen S. Immunoglobulin- and complement-coated bacteria in middle ear effusions during the early course of acute otitis media. Scand J Infect Dis. 1992;24:759-763. [pmid: 1287810].
Stenfors L E, Raisanen S. Opsonization and phagocytosis of bacteria during various middle ear infections. Int J Pediatr Otorhinolaryngol. 1993;27:137-145. [pmid: 8258481].
Stenfors L E, Raisanen S. Secretory IgA-, IgG- and C3b-coated bacteria in the nasopharynx of otitis-prone and non-otitis-prone children. Acta Otolaryngol. 1993;113:191-195. [pmid: 8475735].
Stenqvist M, Anniko M, Pettersson A. Effect of Pseudomonas aeruginosa exotoxin A on inner ear function. Acta Otolaryngol. 1997;117:73-79. [pmid: 9039485].
Stenstrom C, Lundgren K, Ingvarsson L, Bertilson S O. Amoxycillin/clavulanate versus amoxycillin in recurrent otitis media and therapeutic failure in children. Acta-Otolaryngol-Stockh. 1991;111:120-129. [pmid: 1901686].
Stenstrom C, Bylander-Groth A, Ingvarsson L. Eustachian tube function in otitis-prone and healthy children. Int J Pediatr Otorhinolaryngol. 1991;21:127-138. [pmid: 1889949].
Stenstrom R, Bernard P A, Ben-Simhon H. Exposure to environmental tobacco smoke as a risk factor for recurrent acute otitis media in children under the age of five years. Int J Pediatr Otorhinolaryngol. 1993;27:127-136. [pmid: 8258480].
Stenstrom C, Ingvarsson L. General illness and need of medical care in otitis prone children. Int J Pediatr Otorhinolaryngol. 1994;29:23-32. [pmid: 8169044].
Stenstrom C, Ingvarsson L. Late effects on ear disease in otitis-prone children: a long-term follow-up study. Acta Otolaryngol. 1995;115:658-663. [pmid: 8928639].
Stenstrom RJ, Bernard PAM, Feldman W, Durieux-Smith A, Pless IB, Beauregard Y. Long-term sequelae of ventilation tube insertion for the treatment of otitis media with effusion and recurrent acute otitis media. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:373–375.
Stenstrom C, Ingvarsson L. Otitis-prone children and controls: a study of possible predisposing factors. 2. Physical findings, frequency of illness, allergy, day care and parental smoking. Acta Otolaryngol. 1997;117:696-703. [pmid: 9349865].
Stenstrom C, Ingvarsson L. Otitis-prone children and controls: a study of possible predisposing factors. 1. Heredity, family background and perinatal period. Acta Otolaryngol. 1997;117:87-93. [pmid: 9039487].
Stephenson H, Haggard M, Zielhuis G, van den Broek P, Schilder A. Prevalence of tympanogram asymmetries and fluctuations in otitis media with effusion: implications for binaural hearing. Audiology. 1993;32:164-174. [pmid: 8489477].
Stephenson H, Higson J, Haggard M. Binaural hearing in adults with histories of otitis media in childhood. Audiology. 1995;34:113-123. [pmid: 8561689].
Stephenson H. Evaluation of self-report by adults of childhood otitis media histories. Audiology. 1995;34:124-134. [pmid: 8561690].
Stephenson H, Higson J M, Haggard M P, Dutson M, Rogers M, Schilder A G. The acoustic reflex in adults with histories of otitis media in childhood. Ear Hear. 1997;18:62-72. [pmid: 9058038].
Stern S J, Fazekas-May M. Cholesteatoma in the pediatric population: prognostic indicators for surgical decision making. Laryngoscope. 1992;102:1349-52. [pmid: 1453840].
Steuer M K, Hofstadter F, Probster L, Beuth J, Strutz J. Are ABH antigenic determinants on human outer ear canal epithelium responsible for Pseudomonas aeruginosa infections?. ORL J Otorhinolaryngol Relat Spec. 1995;57:148-152. [pmid: 7603694].
Stevens D. Ear, nose and throat problems in childhood. Practitioner. 1981;225:1593-1601. [pmid: 7335589].
Stewart T J, Belal A. Surgical anatomy and pathology of the round window. Clin Otolaryngol Allied Sci. 1981;6:45-62. [pmid: 7273452].
Stewart I A, Jenkin L, Kirkland C, Silva P A, Simpson A. A preliminary evaluation of the use of an automatic impedance tympanometer in the diagnosis of otitis media with effusion in children: a report from the Dunedin Multidisciplinary Health and Development Research Unit. N Z Med J. 1983;96:252-255. [pmid: 6572840].
Stewart I, Kirkland C, Simpson A, Silva P, Williams S. Some Developmental Characteristics Associated with Otitis Media with Effusion. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:329–332.
Stewart I A, Guy A M, Allison R S, Thomson N J. Bromhexine in the treatment of otitis media with effusion. Clin-Otolaryngol. 1985;10:145-149. [pmid: 3896583].
Stewart IA, Jenkin L, Silva PA, Williams S. Controlled trial of tympanostomy tubes in otitis media with effusion: developmental and behavioral effects. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:557–560.
Stewart L A, Parmar M K. Meta-analysis of the literature or of individual patient data: is there a difference?. Lancet. 1993;341:418-422. [pmid: 8094183].
Stewart M G, Troendle-Atkins J, Starke J R, Coker N J. Nontuberculous mycobacterial mastoiditis. Arch Otolaryngol Head Neck Surg. 1995;121:225-228. [pmid: 7840932].
Stewart L A, Clarke M J. Practical methodology of meta-analyses (overviews) using updated individual patient data. Cochrane Working Group. Stat Med. 1995;14:2057-2079. [pmid: 8552887].
Stewart M G, Ohlms L A, Friedman E M, et al. Is parental perception an accurate predictor of childhood hearing loss? A prospective study. Otolaryngol Head Neck Surg. 1999;120:340-344. [pmid: 10064635].
Stewart I A. Evaluation of factors affecting outcome of surgery for otitis media with effusion in clinical practice. Int J Pediatr Otorhinolaryngol. 1999;49:243-245.
Stickler G B, Rubenstein M M, McBean J B, Hedgecock L D, Hugstad J A, Griffing T. Treatment of acute otitis media in children. IV. A fourth clinical trial. Am-J-Dis-Child. 1967;114:123-130. [pmid: 4952777].
Stingle W H. Middle ear effusion. Bull N Y Acad Med. 1981;57:582-590. [pmid: 6944133].
Stocks R M, Wang W C, Thompson J W, Stocks M C, 2nd, Horwitz E M. Malignant infantile osteopetrosis: otolaryngological complications and management. Arch Otolaryngol Head Neck Surg. 1998;124:689-694. [pmid: 9639480].
Stollman M H, Snik A F, Schilder A G, van den Broek P. Measures of binaural hearing in children with a history of asymmetric otitis media with effusion. Audiol Neurootol. 1996;1:175-185. [pmid: 9390800].
Stool S E, Belafsky M L. Pediatric otolaryngology. Curr Probl Pediatr. 1971;2:1-51. [pmid: 5163978].
Stool S E, Anticalgia J. Electric otoscopy-a basic pediatric skill. Clin Pediatrics. 1973;12:420-426.
Stool S E, Craig H B, Laird M A. Screening for middle ear disease in a school for the deaf. Ann Otol Rhinol Laryngol Suppl. 1980;89:172-177. [pmid: 6778301].
Stool S E, Black F O, Craig H, Laird M. Otologic care in a school for the deaf. Otolaryngol Head Neck Surg. 1981;89:651-657. [pmid: 6793978].
Stool SE, Flaherty MR. Validation of diagnosis of otitis media with effusion. Ann Otol Rhinol Laryngol. 1983;96.
Stool S E. Medical relevancy of immittance measurements. Ear Hear. 1984;5:309-313. [pmid: 6542037].
Stool S E, Field M J. The impact of otitis media. Pediatr Infect Dis J. 1989;8:S11-S14. [pmid: 2494641].
Stool SE, Berg AO, Berman S, et al.. Otitis media with effusion in young children. Clinical Practice Guideline, Number 12. Rockville (MD): Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services; 1994a July.
Stool SE, Berg AO, Berman S, et al.. Managing otitis media with effusion in ytoung children. Quick Reference Guide for Clinicians. Rockville (MD): Agency for Health Care Policy and Research, Public Health Servies, U.S. Department fo Health and Human Services; 1994b July.
Stool S, Mount M R, Medellin G. Diagnosing otitis media: a workshop. Compr Ther. 1996;22:776-781. [pmid: 9030456].
Storgaard M, Larsen K, Blegvad S, et al. Interleukin-8 and chemotactic activity of middle ear effusions. J Infect Dis. 1997;175:474-477. [pmid: 9203677].
Storms W W, Southern D L, Feiss G, Simpson B, Furst J A, Smith J A. Efficacy of triamcinolone acetonide aerosol nasal inhaler in children with perennial allergic rhinitis. Pediatric Asthma, Allergy and Immunology. 1996;10:59-64.
Stott N C, West R R. Randomised controlled trial of antibiotics in patients with cough and purulent sputum. Br-Med-J. 1976;2:556-559. [pmid: 786428]. [pmcid: 1688091].
Strachan D P, Jarvis M J, Feyerabend C. Passive smoking, salivary cotinine concentrations, and middle ear effusion in 7 year old children [see comments]. Br Med J. 1989;298:1549-1552. [pmid: 2503113]. [pmcid: 1836817].
Strachan D P. Impedance tympanometry and the home environment in seven-year-old children. J Laryngol Otol. 1990;104:4-8. [pmid: 2313175].
Strachan D, Hope G, Hussain M. Long-term follow-up of children inserted with T-tubes as a primary procedure for otitis media with effusion. Clin Otolaryngol Allied Sci. 1996;21:537-541. [pmid: 9118577].
Strachan D, McPherson B, Smyth V, Scott J. Hearing screening for children with otitis media with effusion using external ear resonance. J Audiological Med. 1996;5:73-82.
Straka J A, Caparosa R J. Eosinophilic granuloma of the temporal bone. Laryngoscope. 1972;82:41-44. [pmid: 5008760].
Stratieva O V, Arefyeva N A, Smakaeva D F. On diagnosis of exudative otitis media. Zhurnal Ushnykh, Nosovykh i Gorlovykh Boleznei Issue. 1997;1:38-42.
Stream R W, Stream K S, Walker J R, Breningstall G. Emerging characteristics of the acoustic reflex in infants. Otolaryngology. 1978;86:ORL-628-36.
Stuart J E, Quayle C J, Lewis A N. Follow-up studies of aboriginal children with ear disease and hearing loss at Cherbourg (Queensland). Med J Aust. 1975;1(Spec suppl):38-40. [pmid: 1128358].
Stuart J. Guidelines on the management of paediatric middle ear disease [letter]. Med J Aust. 1994;160:451. [pmid: 8007880].
Studebaker G A. The standardization of bone-conduction thresholds. Laryngoscope. 1967;77:823-835. [pmid: 6026275].
Stutman HR, Arguedas AG. Comparison of cefprozil with other antibiotic regimens in the treatment of children with acute otitis media. Clin-Infect-Dis. 1992:S204–208; discussion.
Stutman HR. Cefprozil. Pediatr Ann. 1993;22:167–168, 171–176.
Su C Y, Hsu S P, Chee C Y. Electromyographic study of tensor and levator veli palatini muscles in patients with nasopharyngeal carcinoma. Implications for eustachian tube dysfunction. Cancer. 1993;71:1193-1200. [pmid: 8435792].
Su C Y, Hsu S P, Lui C C. Computed tomography, magnetic resonance imaging, and electromyographic studies of tensor veli palatini muscles in patients with nasopharyngeal carcinoma. Laryngoscope. 1993;103:673-678. [pmid: 8502102].
Su C Y. Valve section of the eustachian tube. J Laryngol Otol. 1995;109:486-490. [pmid: 7642986].
Sugita R, Deguchi K, Kimura S, et al. [Efficacy of cefditoren pivoxil in the treatment of acute otitis media due to benzylpenicillin-insensitive Streptococcus pneumoniae]. Jpn J Antibiot. 1996;49:386-398. [pmid: 8786629].
Sullivan TD, LaScolea LJ, Jr. Neisseria meningitidis bacteremia in children: quantitation of bacteremia and spontaneous clinical recovery without antibiotic therapy. Pediatrics. 1987;80.
Sumerson J M. Auditory and vestibular findings in dyslexic children. Transactions - Pennsylvania Academy of Ophthalmology and Otolaryngology. 1985;37:196-200. [pmid: 3874452].
Sumitsawan Y, Tharavichitkul P, Prawatmuang W, Ingsuwan B, Sriburi P. Ofloxacin otic solution as treatment of chronic suppurative otitis media and diffuse bacterial otitis externa. J Med Assoc Thai. 1995;78:455-459. [pmid: 7561571].
Summerfield M J. Deafness in adults. N Z Med J. 1978;87:440-442. [pmid: 277814].
Sundberg L, Cederberg A, Eden T, Ernstson S. The effect of erythromycin on the nasopharyngeal pathogens in children with secretory otitis media. Acta-Otolaryngol-Stockh. 1984;97:379-383. [pmid: 6609521].
Sundberg L. Antibiotic treatment of secretory otitis media. Acta Oto-Laryngologica - Supplement. 1984;407:26-29.
Sundberg L, Cederberg A. Penetration of clarithromycin and its 14-hydroxy metabolite into middle ear effusion in children with secretory otitis media. J Antimicrob Chemother. 1994;33:299-307. [pmid: 8182011].
Sunderland R, McVey D L, Atkin K J. Cefixime versus co-amoxiclav in the treatment of pediatric upper respiratory tract infections and otitis media. A multicenter clinical study of empirical treatment in general practice in the United Kingdom. Curr Ther Res, Clin Exp. 1994;55:22-29.
Sung B S, Chonmaitree T, Broemeling L D, et al. Association of rhinovirus infection with poor bacteriologic outcome of bacterial-viral otitis media. Clin-Infect-Dis. 1993;17:38-42. [pmid: 8394749].
Supance JS, Kaleida PH, Casselbrant ML, et al. Antibitoic or myringotomy, or both, for aucte otitis media. Ann Otol Rhinol Laryngol. 1983;96.
Supiyaphun P, Tonsakulrungruang K, Chochaipanichnon L, Chongtateong A, Samart Y. The treatment of chronic suppurative otitis media and otitis externa with 0.3 per cent ofloxacin otic solution: a clinico-microbiological study. J Med Assoc Thai. 1995;78:18-21. [pmid: 7622972].
Surico G, Muggeo P, Muggeo V, et al. Ear involvement in childhood langerhans' cell histiocytosis. Head Neck. 2000;22:42-47. [pmid: 10585604].
Surr R K, Schuchman G I. Measurement of the acoustic reflex without a pressure seal. Arch Otolaryngol. 1976;102:160-161. [pmid: 1267693].
Sutbeyaz Y, Yakan B, Ozdemir H, Karasen M, Doner F, Kufrevioglu I. Effect of SC-41930, a potent selective leukotriene B4 receptor antagonist, in the guinea pig model of middle ear inflammation. Ann Otol Rhinol Laryngol. 1996;105:476-480. [pmid: 8638901].
Sutton G J, Gleadle P, Rowe S J. Tympanometry and otoacoustic emissions in a cohort of special care neonates [published erratum appears in Br J Audiol 1996 Apr;30(2):152]. Br J Audiol. 1996;30:9-17. [pmid: 8839362].
Suzuki M. A long-term follow-up of secretory otitis media in children. Otolaryngology. 1984;56:469-473.
Suzuki T, Somekawa Y, Yamanaka N, Niida Y, Kataura A. Lactoferrin in middle ear effusion. Auris Nasus Larynx. 1985;12:S154-S155. [pmid: 3915202].
Suzuki M, Kodera K. Long term follow-up of secretory otitis media in children: the effects of adenotonsillectomy with insertion of a ventilation tube. Auris Nasus Larynx. 1985;12:S237-S238. [pmid: 3835919].
Suzuki K, Bakaletz L O. Synergistic effect of adenovirus type 1 and nontypeable Haemophilus influenzae in a chinchilla model of experimental otitis media. Infect Immun. 1994;62:1710-1718. [pmcid: 186390]. [pmid: 8168932].
Suzuki K, Baba S. Antimicrobial ear drop medication therapy. Acta Oto-Laryngologica - Supplement. 1996;525:68-72.
Suzuki M, Arimura Y, Minoshima S, et al. [A case of myeloperoxidase-specific antineutrophil cytoplasmic antibody (MPO-ANCA)-related glomerulonephritis associated with Cogan's syndrome]. Nippon Jinzo Gakkai Shi. Japanese Journal of Nephrology. 1996;38:423-427.
Suzuki C, Sando I, Fagan J J, Kamerer D B, Knisely A S. Histopathological features of a cochlear implant and otogenic meningitis in Mondini dysplasia. Arch Otolaryngol Head Neck Surg. 1998;124:462-466. [pmid: 9559698].
Suzuki M, Kawauchi H, Mogi G. Clinical efficacy of an antiallergic drug on otitis media with effusion in association with allergic rhinitis. Auris Nasus Larynx. 1999;26:123-129. [pmid: 10214889].
Svinhufvud M, Hermansson A, Prellner K. Active immunisation and resistance to experimental acute pneumococcal otitis media. Int J Pediatr Otorhinolaryngol. 1993;25:91-103. [pmid: 8436484].
Swanson J A, Hoecker J L. Concise review for primary-care physicians. Mayo Clin Proc. 1996;71:179-183. [pmid: 8577193].
Swart S M, Lemmer R, Parbhoo J N, Prescott C A. A survey of ear and hearing disorders amongst a representative sample of grade 1 schoolchildren in Swaziland. Int J Pediatr Otorhinolaryngol. 1995;32:23-34. [pmid: 7607818].
Swarts MC, Doyle WJ. Medicinal plants used for the treatment of otitis media. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:257–260.
Swarts J D, Alper C M, Seroky J T, Chan K H, Doyle W J. In vivo observation with magnetic resonance imaging of middle ear effusion in response to experimental underpressures. Ann Otol Rhinol Laryngol. 1995;104:522-528. [pmid: 7598363].
Swartz J D, Goodman R S, Russell K B, Ladenheim S E, Wolfson R J. High-resolution computed tomography of the middle ear and mastoid. Part III: Surgically altered anatomy and pathology. Radiology. 1983;148:461-464. [pmid: 6867343].
Swartz J D, Goodman R S, Russell K B, Marlowe F I, Wolfson R J. High-resolution computed tomography of the middle ear and mastoid. Part II: Tubotympanic disease. Radiology. 1983;148:455-459. [pmid: 6867342].
Swartz J D. High-resolution computed tomography of the middle ear and mastoid. Part I: Normal radioanatomy including normal variations. Radiology. 1983;148:449-454. [pmid: 6867341].
Swartz J D, Russell K B, Wolfson R J, Marlowe F I. High resolution computed tomography in evaluation of the temporal bone. Head and Neck Surgery. 1984;6:921-931. [pmid: 6724959].
Swartz J D, Swartz N G, Korsvik H, et al. Computerized tomographic evaluation of the middle ear and mastoid for posttraumatic hearing loss. Ann Otol Rhinol Laryngol. 1985;94:263-266. [pmid: 4014947].
Swischuk L E. Diplopia after head injury. Pediatr Emerg Care. 1999;15:233-234. [pmid: 10389966].
Syms M J, Tsai P D, Holtel M R. Management of lateral sinus thrombosis. Laryngoscope. 1999;109:1616-1620. [pmid: 10522931].
Syrogiannopoulos G A, Goumas P D, Haliotis F A, Lygatsikas C G, Spyropoulos C D, Beratis N G. Cefuroxime axetil in the treatment in acute otitis media in children. J Chemother. 1992;4:221-224. [pmid: 1403077].
Syrogiannopoulos G A, Goumas P D, Haliotis F A, Lygatsikas C G, Spyropoulos C D, Beratis N G. Cefuroxime axetil in the treatment of acute otitis media in children. J Chemother. 1992;4:221-224. [pmid: 1403077].
Szanton V L. Allergy and serous otitis media. W V Med J. 1967;63:108-110. [pmid: 5233005].
Szmeja Z, Golusinski W, Mielcarek-Kuchta D, Laczkowska-Przybylska J. [Use of mucolytic preparations (Mucosolvan) in selected diseases of the upper respiratory tract. Part II]. Otolaryngol-Pol. 1997;51:480-486. [pmid: 9557050].
Szpunar J. Biological reconstruction of the ossicular chain. Arch Otolaryngol. 1967;86:303-307. [pmid: 6034658].
Szpunar J, Miszke A. Fibrous ankylosis of the incudostapedial joint. Arch Otolaryngol. 1970;92:138-140. [pmid: 5428307].
Szucs E, Diependaele R, Clement P A. The accuracy of tympanometry assessed by its sensitivity and specificity. Acta Otorhinolaryngol Belg. 1995;49:287-292. [pmid: 7484149].
Szyfter W, Wierzbicka M. [Drug addiction complicating treatment of chronic otitis media]. Otolaryngol Pol. 1994;48:489-493. [pmid: 7808758].
Tachibana F, Shimada T, Hori Y, Wada Y, Ishitani Y, Koike Y. Platelet-activating factor and leukotrienes in acute otitis media, secretory otitis media, and chronic otitis media on the acute excerbation. Auris Nasus Larynx. 1996;23:20-25. [pmid: 8809319].
Tajima T, Kobayashi M, Negishi S, et al. [Pharmacokinetic, bacteriological and clinical studies on cefditoren pivoxil in children]. Jpn J Antibiot. 1993;46:589-595. [pmid: 8371494].
Tajima T, Kondo Y, Negishi S, et al. [Pharmacokinetic, bacteriological and clinical studies on cefozopran in children]. Jpn-J-Antibiot. 1994;47:1457-1463. [pmid: 7853676].
Takada R, Harabuchi Y, Himi T, Kataura A. Antibodies specific to outer membrane antigens of Moraxella catarrhalis in sera and middle ear effusions from children with otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1998;46:185-195. [pmid: 10190589].
Takahashi H, Hayashi M, Honjo I. Direct measurement of middle ear pressure through the eustachian tube. Arch Otorhinolaryngol. 1987;243:378-381. [pmid: 3566621].
Takahashi H, Fujita A, Honjo I. Effect of adenoidectomy on otitis media with effusion, tubal function, and sinusitis. Am J Otolaryngol. 1989;10:208-213. [pmid: 2742055].
Takahashi H, Honjo I, Fujita A, Kurata K. Transtympanic endoscopic findings in patients with otitis media with effusion. Arch Otolaryngol Head Neck Surg. 1990;116:1186-1189. [pmid: 2206504].
Takahashi H, Honjo I, Yagi N, Kurata K. Viscosity of effusion in the middle ear and eustachian tube in patients with otitis media with effusion. Auris Nasus Larynx. 1990;17:11-16. [pmid: 2390028].
Takahashi H, Honjo I, Hayashi M, Fujita A, Kurata K. Middle ear pressures of children with otitis media with effusion. Ann Otol Rhinol Laryngol. 1991;100:469-471. [pmid: 2058988].
Takahashi H, Sugimaru T, Honjo I, et al. Assessment of the gas exchange function of the middle ear using nitrous oxide. A preliminary study. Acta Otolaryngol. 1994;114:643-646. [pmid: 7879623].
Takahashi H, Honjo I, Fujita A. Eustachian tube compliance in cleft palate--a preliminary study. Laryngoscope. 1994;104:83-86. [pmid: 8295462].
Takahashi H, Honjo I, Fujita A. Endoscopic findings at the pharyngeal orifice of the eustachian tube in otitis media with effusion. Eur Arch Otorhinolaryngol. 1996;253:42-44. [pmid: 8932429].
Takahashi H, Miura M, Honjo I, Fujita A. Cause of eustachian tube constriction during swallowing in patients with otitis media with effusion. Ann Otol Rhinol Laryngol. 1996;105:724-728. [pmid: 8800060].
Takahashi H, Honjo I, Fujita A, Kurata K. Effects of adenoidectomy on sinusitis. Acta Otorhinolaryngol Belg. 1997;51:85-87. [pmid: 9241373].
Takahashi H, Honjo I, Naito Y, et al. Gas exchange function through the mastoid mucosa in ears after surgery. Laryngoscope. 1997;107:1117-1121. [pmid: 9261018].
Takahashi H, Honjo I, Hasebe S, Sudo M, Tanabe M. The diagnostic and prognostic value of eardrum mobility in otitis media with effusion. Eur Arch Otorhinolaryngol. 1999;256:189-191. [pmid: 10337509].
Takahashi H, Honjo I, Hasebe S, Sudo M, Tanabe M. Soft-wall reconstruction of posterior canal wall for surgery of noninflamed ears: a preliminary report. Am J Otol. 1999;20:31-35. [pmid: 9918168].
Takala A K, Jero J, Kela E, Ronnberg P R, Koskenniemi E, Eskola J. Risk factors for primary invasive pneumococcal disease among children in Finland. JAMA. 1995;273:859-864. [pmid: 7869556].
Takamatsu I, Ogahara N, Fujimoto M, Nagahara T, Tsukuda M. [Two pediatric cases of facial palsy caused by masked mastoiditis]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1996;99:985-990.
Takasaka T, Hozawa K, Shoji F, et al. Tympanostomy tube treatment in recurrent otitis media with effusion. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:197–199.
Takata GS, Chan LS, Shekelle P, Morton SC, Mason W, Marcy SM. Evidence assessment of management of acute otitis media: I. The role of antibiotics in treatment of uncomplicated acute otitis media. Pediatrics. (In Press).
Takeshita K. Hearing impaired child as a developmental disability. Equilibrium Research. 1995;54:19-25.
Takeuchi K, Majima Y, Hirata K, Morishita A, Hattori M, Sakakura Y. Prognosis of secretory otitis media in relation to viscoelasticity of effusions in children. Ann Otol Rhinol Laryngol. 1989;98:443-446. [pmid: 2729829].
Takeuchi K, Saida S, Majima Y, Sakakura Y. The effect of middle ear effusions from children on in vitro ciliary activity. Eur Arch Otorhinolaryngol. 1990;247:323-325. [pmid: 2393565].
Takeuchi K, Majima Y, Hirata K, Hattori M, Sakakura Y. Quantitation of tubotympanal mucociliary clearance in otitis media with effusion. Ann Otol Rhinol Laryngol. 1990;99:211-214. [pmid: 2310137].
Takeuchi K, Majima Y, Hirata K, Morishita A, Hattori M, Sakakura Y. Viscoelastic properties of middle ear effusions from pediatric otitis media with effusion and their relation to gross appearance. Eur Arch Otorhinolaryngol. 1990;247:60-62. [pmid: 2310553].
Takeuchi K, Maesako K, Yuta A, Sakakura Y. Interleukin-8 gene expression in middle ear effusions. Ann Otol Rhinol Laryngol. 1994;103:404-407. [pmid: 8179258].
Takeuchi K, Fujita Y, Tomemori T, Yuta A, Iriyoshi N, Sakakura Y. Analysis of T cell receptor beta chain repertoire in middle ear effusions. Ann Otol Rhinol Laryngol. 1996;105:213-217. [pmid: 8615585].
Takoudes T G, Haddad J Jr. Hydrogen peroxide in acute otitis media in guinea pigs. Laryngoscope. 1997;107:206-210. [pmid: 9023244].
Talan D A, Moran G J. Infectious diseases: antimicrobial therapy. Acad Emerg Med. 1994;1:180-182. [pmid: 7621182].
Talan DA. Infectious disease issues in the emergency department. Clin Infect Dis. 1996;23:1–12, quiz 13–14.
Talmi Y P, Sadov R, Dulitzky F, Finkelstein Y, Zohar Y. Teratoma of the mastoid region in a newborn. J Laryngol Otol. 1988;102:1033-1035. [pmid: 3209938].
Talmi Y P, Mardinger O, Horowitz Z, et al. Incidence of secretory otitis media following maxillectomy. Oral Surgery, Oral Medicine, Oral Pathology, Oral Radiology, and Endodontics. 1998;86:524-528.
Talo H, Macknin ML, Medendorp SV. Tympanic membrane temperatures compared to rectal and oral temperatures. Clin Pediatr. 1991;30:30–33; discussion 34–35.
Tammisto T, Toikka O. Spontaneous EMG activity for detection of arousal during general anaesthesia--comparison between recordings from frontal and neck musculature. Eur J Anaesthesiol. 1991;8:109-114. [pmid: 1678703].
Tan Z, Lu Y, Huang Z, et al. Inflammatory lesions and hearing state of sound conducting apparatus of middle ear. Bull Hunan Med Coll. 1984;9:287-290.
Tan C T, Escoubet B, Van den Abbeele T, Friedlander G, Tran Ba Huy P, Herman P. Modulation of middle ear epithelial function by steroids: clinical relevance. Acta Otolaryngol. 1997;117:284-288. [pmid: 9105467].
Tanabe M, Takahashi H, Honjo I, Hasebe S, Sudo M. Factors affecting recovery of mastoid aeration after ear surgery. Eur Arch Otorhinolaryngol. 1999;256:220-223. [pmid: 10392294].
Tanaka K, Saito J, Ohashi M, Terayama Y, Maguchi S. Histopathology of otitis media with effusion: electron microscope study of human temporal bones. Auris Nasus Larynx. 1985;12:S177-S179. [pmid: 3835899].
Tanaka K, Saito J, Ohashi M, Terayama Y. Histopathology of otitis media with effusion. An electron microscopic study of human temporal bones. Arch Otorhinolaryngol. 1986;243:269-273. [pmid: 3778304].
Tanaka T, Kurono Y, Kawauchi H, Mogi G. Effect of oxatomide on otitis media with effusion--an experimental study. Acta Otolaryngol. 1995;115:532-538. [pmid: 7572131].
Tanimura F. Determination of lipid A in human middle ear effusions with the competitive ELISA technique. Arch Otorhinolaryngol. 1989;246:79-82. [pmid: 2730421].
Tankel J W, Cheesman A D. Symptom relief by adenoidectomy and relationship to adenoid and post-nasal airway size. J Laryngol Otol. 1986;100:637-640. [pmid: 3722997].
Tarabichi M, Schloss M. Actinomycosis otomastoiditis. Arch Otolaryngol Head Neck Surg. 1993;119:561-562. [pmid: 8484946].
Tarantino V, Stura M, Marenco G, Cremonesi G, Leproux G B. Therapeutic role of bromhexine in the treatment of child otitis media. Randomised double-blind study versus placebo. OTORINOLARINGOLOGIA. 1989;39:187-191.
Tarasov DI, Merkulova EP. [The role of paracentesis in treating acute otitis media in young children]. Vestn Otorinolaringol. 1994:39–41.
Tavin M E, Gordon M, Ruben R J. Hearing results with the use of different tympanostomy tubes: a prospective study. Int J Pediatr Otorhinolaryngol. 1988;15:39-50. [pmid: 3372141].
Tay H L, Mills R P. Predictive factors for the resolution of childhood otitis media with effusion following initial surgical treatment. Clin Otolaryngol Allied Sci. 1994;19:385-387. [pmid: 7834877].
Tay H L, Mills R P. The assessment of hearing results following surgery for otitis media with effusion using the Glasgow Benefit Plot. J Laryngol Otol. 1994;108:733-735. [pmid: 7964132].
Tay H L, Mills R P. Tympanic membrane atelectasis in childhood otitis media with effusion. J Laryngol Otol. 1995;109:495-498. [pmid: 7642987].
Taylor R B, Pugliese W M, Wiersum J, Mesches D N, Henriquez C. A comparison of lincomycin with penicillin in acute otitis media in children. Am-J-Dis-Child. 1969;117:139-141. [pmid: 4884569].
Taylor L. The differential diagnosis of deafness. Practitioner. 1971;207:767-775. [pmid: 5143899].
Taylor PH, Dareshani N. s-Carboxy-methyl-cysteine syrup in secretory otitis media. Br-J-Clin-Pract. 1975;29:177–178, 180.
Taylor C, Onion D K. The first six months after otitis media. A preliminary report. Journal of the Maine Medical Association. 1975;66:280-281. [pmid: 1194772].
Te G O, Rizer F M, Schuring A G. Pediatric tympanoplasty of iatrogenic perforations from ventilation tube therapy. Am J Otol. 1998;19:301-305. [pmid: 9596179].
Teach S J, Fleisher G R, Rosenberg N, et al. Efficacy of an observation scale in detecting bacteremia in febrile children three to thirty-six months of age, treated as outpatients. J Pediatr. 1995;126:877-881. [pmid: 7776087].
Teach S J, Fleisher G R. Efficacy of an observation scale in detecting bacteremia in febrile children three to thirty-six months of age, treated as outpatients. Occult Bacteremia Study Group [see comments]. J Pediatr. 1995;126:877-881. [pmid: 7776087].
Teach S J, Fleisher G R. Duration of fever and its relationship to bacteremia in febrile outpatients three to 36 months old. Pediatr Emerg Care. 1997;13:317-319. [pmid: 9368242].
Teatini G P. Audiological evaluation of the efficacy of flurbiprofen in serous otitis media. Drugs Exp Clin Res. 1984;10:713-717.
Teele D W, Klein J O, Rosner B A. Epidemiology of otitis media in children. Ann Otol Rhinol Laryngol Suppl. 1980;89:5-6. [pmid: 6778349].
Teele DW, Klein JO, Bratton L, et al. Use of pneumococcal vaccine for prevention of recurrent acute otitis media in infants in Boston. The Greater Boston Collaborative Otitis Media Study Group. Rev-Infect-Dis. 1981:S113–S118.
Teele D W, Klein J O, Rosner B A. Otitis media with effusion during the first three years of life and development of speech and language. Pediatrics. 1984;74:282-287. [pmid: 6540437].
Teele D W, Teele J. Detection of middle ear effusion by acoustic reflectometry. J Pediatr. 1984;104:832-838. [pmid: 6539374].
Teele D W, Klein J O, Rosner B. Epidemiology of otitis media during the first seven years of life in children in greater Boston: a prospective, cohort study [see comments]. J Infect Dis. 1989;160:83-94. [pmid: 2732519].
Teele D W, Klein J O, Rosner B. Epidemiology of otitis media during the first seven years of life in children in greater Boston: A prospective, cohort study. J Infect Dis. 1989;160:83-94. [pmid: 2732519].
Teele D W, Stewart I A, Teele J H, Smith D K, Tregonning S J. Acoustic reflectometry for assessment of hearing loss in children with middle ear effusion. Pediatr Infect Dis J. 1990;9:870-872. [pmid: 2277742].
Teele D W, Klein J O, Chase C, Menyuk P, Rosner B A. Otitis media in infancy and intellectual ability, school achievement, speech, and language at age 7 years. Greater Boston Otitis Media Study Group. J Infect Dis. 1990;162:685-694. [pmid: 2387994].
Teele D W, Greig M H. Antimicrobial therapy of acute otitis media [see comments] [published erratum appears in N Z Med J 1994 Sep 14;107(985):363]. N Z Med J. 1994;107:61-63. [pmid: 8192759].
Teele D W, Greig M H. The management of acute otitis media [letter; comment]. N Z Med J. 1994;107:186. [pmid: 8177582].
Teele D W. Long term sequelae of otitis media: Fact or fantasy?. Pediatr Infect Dis J. 1994;13:1069-1073. [pmid: 7845743].
Teichgraeber J F, Per-Lee J H, Turner J S Jr. Lateral sinus thrombosis: a modern perspective. Laryngoscope. 1982;92:744-751. [pmid: 7087642].
Tejani N R, Chonmaitree T, Rassin D K, Howie V M, Owen M J, Goldman A S. Use of C-reactive protein in differentiation between acute bacterial and viral otitis media. Pediatrics. 1995;95:664-669. [pmid: 7724300].
Telischi F F, Arnold D J, Sittler S. Inflammatory neuroma of the facial nerve associated with chronic otomastoiditis. Otolaryngol Head Neck Surg. 1995;113:319-322. [pmid: 7675501].
TerKonda R P, Levine S C, Duvall A J 3rd, Giebink G S. Atypical mycobacterial otomastoiditis. Laryngoscope. 1995;105:1275-1278. [pmid: 8523976].
Terris MH, Magit AE, Davidson TM. Otitis media with effusion in infants and children. Primary care concerns addressed from an otolaryngologist's perspective. Postgrad Med. 1995;97:137–138, 143–144, 147 passim.
Terzis T F, Robinson J M. Use of hearing aids by patients with closed mastoid cavity. J Laryngol Otol. 1991;105:174-177. [pmid: 2019800].
Thelin J W, Thelin S J, Keith R W, Novak K K, Keenan W J. Effect of middle-ear dysfunction and disease on hearing and language in high-risks infants. Int J Pediatr Otorhinolaryngol. 1979;1:125-136. [pmid: 553890].
Theoharides T C, Manolidis S S, Vliagoftis H, Manolidis L S. Treatment of secretory otitis media with local instillation of hydroxyzine. Int-Arch-Allergy-Immunol. 1994;103:95-101. [pmid: 8260856].
Therien F. Otitis and hearing loss among northern Quebec Inuit. Arctic Med Res. 1988;47:657-658. [pmid: 3272707].
Thielke HM, Shriberg LD. Effects of recurrent otitis media on language, speech, and educational achievement in Menominee Indian children. J Am Indian Education. 1990:25–33.
Thieme R E, Caldwell S A, Lum G M. Acute interstitial nephritis associated with loracarbef therapy. J Pediatr. 1995;127:997-1000. [pmid: 8523206].
Thiringer K, Kankkunen A, Liden G, Niklasson A. Perinatal risk factors in the aetiology of hearing loss in preschool children. Dev Med Child Neurol. 1984;26:799-807. [pmid: 6519362].
Thomas JR, Allard JB. Diagnosis and treatment of serous otitis media. Mo Med 1979;76:479–481, 488.
Thomas D M, Wright J L, Soucek S, Shalom A S. Ehlers-Danlos syndrome: aural manifestations and treatment. Am J Otolaryngol. 1996;17:432-433. [pmid: 8944307].
Thompson J, Wright PF, Greene JW, et al. Natural History of Acute and Serous Otitis Media During the First Two Years of Life. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:324–326.
Thompson J W. Transmastoid encephaloceles. A case report. Int J Pediatr Otorhinolaryngol. 1988;15:179-184. [pmid: 3397238].
Thompson A C, Crowther J A. Effect of nasal packing on eustachian tube function. J Laryngol Otol. 1991;105:539-540. [pmid: 1875135].
Thompson E M, Shaughnessy A F. Oral cephalosporins: newer agents and their place in therapy. Am Fam Physician. 1994;50:401-405. [pmid: 8042575].
Thomsen J, Mygind N, Meistrup-Larsen K I, Sorensen H, Vesterhauge S. Oral decongestant in acute otitis media. Results of a double-blind trial. Int J Pediatr Otorhinolaryngol. 1979;1:103-108. [pmid: 399953].
Thomsen J, Meistrup-Larsen K I, Sorensen H, Larsen P K, Mygind N. Penicillin and acute otitis: short and long-term results. Ann-Otol-Rhinol-Laryngol-Suppl. 1980;89:271-274. [pmid: 6778324].
Thomsen J, Tos M. Spontaneous improvement of secretory otitis. A long-term study. Acta Otolaryngol. 1981;92:493-499. [pmid: 7198368].
Thomsen J, Meistrup-Larsen K, Mygind N, Sorensen H, Johnsen NJ, Sederberg-Olsen J. Penicillin treatment for acute otitis media in children: when, how much, how frequently, how long? . Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:278–281.
Thomsen J, Sederberg-Olsen J, Stangerup S E, Balle V, Vejlsgaard R. Long-term antibiotic treatment of children with secretory otitis media: a double-blind placebo-controlled study. Acta-Otolaryngol-Suppl-Stockh. 1988;142:883-889.
Thomsen J, Sederberg-Olsen J, Stangerup S E, Balle V, Vejlsgaard R. Long-term antibiotic treatment of children with secretory otitis media: A double-blind placebo-controlled study. Acta Oto Laryngologica Supplement. 1988;106:49-50.
Thomsen J, Sederberg-Olsen JF, Stangerup SE Balle V, Vejlsgaard R. Long Term Antibiotic Treatment of Children with Secretory Otitis Media: Double Blind, Placebo Controlled Study. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:244–247.
Thomsen J, Sederberg-Olsen J, Balle V, Vejlsgaard R, Stangerup S E, Bondesson G. Antibiotic treatment of children with secretory otitis media. A randomized, double-blind, placebo-controlled study [see comments]. Arch Otolaryngol Head Neck Surg. 1989;115:447-451. [pmid: 2647105].
Thomsen J, Sederberg-Olsen J, Balle V, Vejlsgaard R, Stangerup S E, Bondesson G. Antibiotic treatment of children with secretory otitis media. A randomized, double-blind, placebo-controlled study. Arch Otolaryngol Head and Neck Surgery. 1989;115:447-451.
Thomsen J. Antibiotics for Secretory otitis media (I: Reply). Arch Otolaryngol Head and Neck Surgery. 1990;116:628-629.
Thomsen J, Balle V, Sederberg-Olsen JF, Stangerup SE, ejlsgaard R. Antibiotic treatment of children with secretory otitis media. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:254–256.
Thomsen J, Sederberg-Olsen J, Balle V, Hartzen S. Antibiotic treatment of children with secretory otitis media. Amoxicillin-clavulanate is superior to penicillin V in a double-blind randomized study. Arch Otolaryngol Head Neck Surg. 1997;123:695-699. [pmid: 9236587].
Thomson I S. Exudative otitis media, grommets and cholesteatoma. J Laryngol Otol. 1974;88:947-953. [pmid: 4470582].
Thomson M. Otitis media. How are First Nations children affected?. Can Fam Physician. 1994;40:1943-1950. [pmid: 7841826].
Thoroddsen E, Marr C, Efthymiopoulos C, Thorarinsson H. Concentration of cefuroxime in middle ear effusion of children with acute otitis media. Pediatr Infect Dis J. 1997;16:959-962. [pmid: 9380472].
Thoroddsen E. Measuring antibiotic levels in otitis media. Ear-Nose-Throat-J. 1998;77:13-15. [pmid: 9674329].
Tideholm B, Jonsson S, Carlborg B, Welinder R, Grenner J. Continuous 24-hour measurement of middle ear pressure. Acta Otolaryngol. 1996;116:581-588. [pmid: 8831846].
Tierney P, Chan B, Samuel D, Thomas M, Patel K. Neutrophil elastase-alpha 1-antitrypsin in middle ear fluid in chronic otitis media with effusion. Clin Otolaryngol Allied Sci. 1995;20:230-233. [pmid: 7554333].
Tierney P A, Pracy P, Blaney S P, Bowdler D A. An assessment of the value of the preoperative computed tomography scans prior to otoendoscopic ‘second look’ in intact canal wall mastoid surgery. Clin Otolaryngol Allied Sci. 1999;24:274-276. [pmid: 10472459].
Tilanus S C, van Stenis D, Snik A F. Otoacoustic emission measurements in evaluation of the immediate effect of ventilation tube insertion in children. Ann Otol Rhinol Laryngol. 1995;104:297-300. [pmid: 7717621].
Tilyard M W, Dovey S M, Walker S A. Otitis media treatment in New Zealand general practice. N Z Med J. 1997;110:143-145. [pmid: 9152355].
Timms D J. Effect of rapid maxillary expansion on hearing loss [letter]. Angle Orthod. 1997;67:244-246. [pmid: 9267572].
Tiwari S, Singh S M, Jain S. Chronic bilateral suppurative otitis media caused by Aspergillus terreus. Mycoses. 1995;38:297-300. [pmid: 8559193].
Tjellstrom A, Lindstrom J, Hallen O, Albrektsson T, Branemark P I. Direct bone anchorage of external hearing aids. Journal of Biomedical Engineering. 1983;5:59-63. [pmid: 6827820].
Tjellstrom A, Granstrom G. One-stage procedure to establish osseointegration: a zero to five years follow-up report. J Laryngol Otol. 1995;109:593-598. [pmid: 7561463].
To S S, Pahor A L, Robin P E. A prospective trial of unilateral grommets for bilateral secretory otitis media in children. Clin-Otolaryngol. 1984;9:115-117. [pmid: 6380827].
Todd N W, Feldman C M. Allergic airway disease and otitis media in children. Int J Pediatr Otorhinolaryngol. 1985;10:27-35. [pmid: 4077387].
Todd N W, Bowman C M. Otitis media at Canyon Day, Arizona: A 16 year follow-up in Apache Indians. Arch Otolarygol. 1985;111:606-608.
Todd N W. At-risk populations for hearing impairment in infants and young children. Int J Pediatr Otorhinolaryngol. 1994;29:11-21. [pmid: 8169043].
Todd N W, Heindel N H, PerLee J H. Bony anatomy of the anterior epitympanic space. ORL J Otorhinolaryngol Relat Spec. 1994;56:146-153. [pmid: 8202313].
Todd D H, Stool S E. Otitis media with effusion: a condensed review. Ambulatory Child Health. 1995;115:193-195.
Todd J L, Todd N W. Conotruncal cardiac anomalies and otitis media [see comments]. J Pediatr. 1997;131:215-219. [pmid: 9290606].
Tom L W, Tsao F, Marsh R R, Kessler A, Konkle D F. Effect of anesthetic gas on middle ear fluid. Laryngoscope. 1994;104:832-836. [pmid: 8022245].
Tomiyama M. [Clinical observation of acute otitis media in children]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1993;96:1133-1140.
Tomiyama M. [The effect of cefaclor and cefixime on nasopharyngeal pathogens in children]. Nippon-Jibiinkoka-Gakkai-Kaiho. 1995;98:659-668. [pmid: 7782974].
Tomoda K, Yamashita T, Kumazawa T. Scanning electron microscopic study of human eustachian tube epithelium: aging and pathologic changes. Auris Nasus Larynx. 1985;12:S169-S172. [pmid: 3835897].
Tomoda K, Machiki K, Yoshie N, Kubo N. Assessment of Histamine-Gamma Globulin Conjugate and Neurotropin Combined Therapy for Otitis Media with Effusion. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:251–253.
Tomonaga K, Kurono Y, Mogi G. The role of nasal allergy in otitis media with effusion. A clinical study. Acta Oto-Laryngologica - Supplement. 1988;458:41-47.
Tonder O, Gundersen T. Nature of the fluid in serous otitis media. Arch Otolaryngol. 1971;93:473-478. [pmid: 4101937].
Toner J G, Kerr A G. Severe sensorineural hearing loss presenting as profound deafness. J Laryngol Otol. 1987;101:601-604. [pmid: 3598362].
Toner J G, Smyth G D. Surgical treatment of cholesteatoma: a comparison of three techniques. Am J Otol. 1990;11:247-249. [pmid: 2399942].
Toner J G, Mains B. Pneumatic otoscopy and tympanometry in the detection of middle ear effusion. Clin Otolaryngol Allied Sci. 1990;15:121-123. [pmid: 2350887].
Toner J C, Smyth G D, Kerr A G. Realities in ossiculoplasty. J Laryngol Otol. 1991;105:529-533. [pmid: 1875133].
Tong M C, Woo J K, van-Hasselt C A. A double-blind comparative study of ofloxacin otic drops versus neomycin-polymyxin B-hydrocortisone otic drops in the medical treatment of chronic suppurative otitis media. J Laryngol Otol. 1996;110:527-530. [pmid: 8763369].
Tong M C, Woo J K, van Hasselt C A. A double-blind comparative study of ofloxacin otic drops versus neomycin-polymyxin B-hydrocortisone otic drops in the medical treatment of chronic suppurative otitis media. J Laryngol Otol. 1996;110:309-314. [pmid: 8733449].
Toohill R J. The psychosomatic aspects of children with vocal nodules. Arch Otolaryngol. 1975;101:591-595. [pmid: 1164221].
Toral Marti¢n R, Hern ndez Tepichin G, Rizo Garnica L. Diclofenaco pot sico en el tratamiento de la otitis media aguda / Diclofenac potassium in the treatment of the acute otitis media. Acta-pediatr-Mex. 1990;11:170-177.
Tos M. Bony fixation of the malleus and incus. Acta Otolaryngol. 1970;70:95-104. [pmid: 5472110].
Tos M. Results of tympanoplasty with modified radical mastoidectomy. Acta Otolaryngol. 1972;74:61-65. [pmid: 5068760].
Tos M. Assessment of the results of tympanoplasty. J Laryngol Otol. 1972;86:487-500. [pmid: 5032992].
Tos M. Tympanoplasty in chronic adhesive otitis media. Acta Otolaryngol. 1972;73:53-60. [pmid: 5061257].
Tos M. Results of tympanoplasty. Acta Otolaryngol. 1973;75:286-287. [pmid: 4702620].
Tos M, Bak-Pedersen K. New aspects in the pathogenesis of chronic secretory otitis media. Acta Otolaryngol. 1973;75:269-270. [pmid: 4702613].
Tos M, Bak-Pedersen K. Density of mucous glands in a biopsy material of chronic secretory otitis media. Acta Otolaryngol. 1973;75:55-60. [pmid: 4120236].
Tos M. Permanent middle-ear aeration in tympanoplasty. ORL J Otorhinolaryngol Relat Spec. 1974;36:170-178. [pmid: 4477898].
Tos M, Bak-Pedersen K. Density of mucous glands in chronic otitis media. Arch Otolaryngol. 1974;99:180-184. [pmid: 4851297].
Tos M. Tympanoplasty for bony ossicular fixation. Arch Otolaryngol. 1974;99:422-427. [pmid: 4208398].
Tos M, Falbe Hansen J Jr. Tympanoplasty on only hearing ears. J Laryngol Otol. 1975;89:1057-1064. [pmid: 1202116].
Tos M. Treatment of labyrinthine fistulae by a closed technique. ORL J Otorhinolaryngol Relat Spec. 1975;37:41-47. [pmid: 1094367].
Tos M, Bak-Pedersen K. Density of goblet cells in chronic secretory otitis media: findings in a biopsy material. Laryngoscope. 1975;85:377-383. [pmid: 1113605].
Tos M, Poulsen G. Secretory otitis media. Late results of treatment with grommets. Arch Otolaryngol. 1976;102:672-675. [pmid: 985199].
Tos M, Poulsen G, Borch J. Tympanometry in 2-year-old children. ORL J Otorhinolaryngol Relat Spec. 1978;40:77-85. [pmid: 570690].
Tos M. Reconstruction of old radical cavities. Clin Otolaryngol Allied Sci. 1978;3:255-261. [pmid: 737859].
Tos M. Frequency of secretory otitis and histology of the normal middle ear mucosa. Int J Pediatr Otorhinolaryngol. 1979;1:241-248. [pmid: 575954].
Tos M, Poulsen G, Hancke A B. Screening tympanometry during the first year of life. Acta Otolaryngol. 1979;88:388-394. [pmid: 532614].
Tos M, Poulsen G, Borch J. Etiologic factors in secretory otitis. Arch Otolaryngol. 1979;105:582-588. [pmid: 573610].
Tos M, Poulsen G. Tympanometry in 2-year-old children. Seasonal influence on frequency of secretory otitis and tubal function. ORL J Otorhinolaryngol Relat Spec. 1979;41:1-10. [pmid: 572952].
Tos M. Middle ear pressure following tympanoplasty for various middle ear diseases. Pressure related to follow-up period and retractions. Acta Oto-Laryngologica - Supplement. 1979;360:148-151.
Tos M, Poulsen G. Screening tympanometry in infants and two-year-old children. Ann Otol Rhinol Laryngol Suppl. 1980;89:217-222. [pmid: 6778311].
Tos M, Poulsen G. Attic retractions following secretory otitis. Acta Otolaryngol. 1980;89:479-486. [pmid: 7192477].
Tos M. Stability of myringoplasty based on late results. ORL J Otorhinolaryngol Relat Spec. 1980;42:171-181. [pmid: 7190662].
Tos M. Spontaneous improvement of secretory otitis and impedance screening. Arch Otolaryngol. 1980;106:345-349. [pmid: 7378020].
Tos M. Upon the relationship between secretory otitis in childhood and chronic otitis and its sequelae in adults. J Laryngol Otol. 1981;95:1011-1022. [pmid: 7197705].
Tos M, Holm-Jensen S, Sorensen C H. Changes in prevalence of secretory otitis from summer to winter in four-year-old children. Am J Otol. 1981;2:324-327. [pmid: 7196158].
Tos M, Holm-Jensen S, Sorensen C H, Mogensen C. Spontaneous course and frequency of secretory otitis in 4-year-old children. Arch-Otolaryngol. 1982;108:4-10. [pmid: 7198436].
Tos M. Mastoid pneumatization. A critical analysis of the hereditary theory. Acta Otolaryngol. 1982;94:73-80. [pmid: 7124391].
Tos M, Melchiors H, Thomsen J, Plate S. Changes of the drum in untreated secretory otitis and chronic tubal dysfunction. Acta Oto Laryngologica. 1982;94.
Tos M. Significance of pneumatization in sequelae of otitis. Journal of Laryngology and Otology - Supplement. 1983;8:49-52.
Tos M. Epidemiology and spontaneous improvement of secretory otitis. Acta Otorhinolaryngol Belg. 1983;37:31-43. [pmid: 6684381].
Tos M, Holm-Jensen S, Stangerup S E, Sorensen C H. Changes in point prevalence of secretory otitis in preschool children. ORL J Otorhinolaryngol Relat Spec. 1983;45:226-234. [pmid: 6683833].
Tos M, Bonding P, Poulsen G. Tympanosclerosis of the drum in secretory otitis after insertion of grommets. A prospective, comparative study. J Laryngol Otol. 1983;97:489-496. [pmid: 6683295].
Tos M. Epidemiology and natural history of secretory otitis. Am J Otol. 1984;5:459-462. [pmid: 6542752].
Tos M, Lau T, Plate S. Sensorineural hearing loss following chronic ear surgery. Ann Otol Rhinol Laryngol. 1984;93:403-409. [pmid: 6465785].
Tos M, Stangerup S E. Mastoid pneumatization in secretory otitis. Further support for the environmental theory. Acta Otolaryngol. 1984;98:110-118. [pmid: 6540511].
Tos M, Stangerup S E, Hvid G. Mastoid pneumatization. Evidence of the environmental theory. Arch Otolaryngol. 1984;110:502-507. [pmid: 6540078].
Tos M, Stangerup S E, Holm-Jensen S, Sorensen C H. Spontaneous course of secretory otitis and changes of the eardrum. Arch Otolaryngol. 1984;110:281-289. [pmid: 6538784].
Tos M, Stangerup SE, Andreassen UK, Hvid G, Thomsen J, Holm-Jensen S. Natural History of Secretory Otitis Media. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:36–40.
Tos M, Stangerup S E. The causes of asymmetry of the mastoid air cell system. Acta Otolaryngol. 1985;99:564-570. [pmid: 4024906].
Tos M, Stangerup S E, Andreassen U K. Size of the mastoid air cells and otitis media. Ann Otol Rhinol Laryngol. 1985;94:386-392. [pmid: 4040726].
Tos M, Stangerup S E. Secretory otitis and pneumatization of the mastoid process: sexual differences in the size of mastoid cell system. Am J Otolaryngol. 1985;6:199-205. [pmid: 4040334].
Tos M, Stangerup S E, Larsen P. Dynamics of eardrum changes following secretory otitis. A prospective study. Arch Otolaryngol Head Neck Surg. 1987;113:380-385. [pmid: 3814387].
Tos M. Etiologic factors in secretory otitis. Adv Otorhinolaryngol. 1988;40:57-64. [pmid: 3389231].
Tos M, Stangerup SE, Hvid SG, Andreassen UK. Epidemiology and Natural History of Secretory Otitis. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:29–34.
Tos M, Stangerup S E. Hearing loss in tympanosclerosis caused by grommets. Arch Otolaryngol Head Neck Surg. 1989;115:931-935. [pmid: 2751852].
Tos M, Lau T. Late results of surgery in different cholesteatoma types. ORL J Otorhinolaryngol Relat Spec. 1989;51:33-49. [pmid: 2710533].
Tos M, Lau T. Stability of tympanoplasty in children. Otolaryngol Clin North Am. 1989;22:15-28. [pmid: 2704560].
Tos M. Sensorineural hearing loss in acute and chronic middle ear diseases. Acta Oto Laryngologica Supplement. 1989;107:87-93.
Tos M, Hvid G, Stangerup S E, Andreassen U K. Prevalence and progression of sequelae following secretory otitis. Ann Otol Rhinol Laryngol. 1990;99:36-38.
Tos M, Stangerup S E, Hvid G, Andreassen U K. Point prevalence of secretory otitis at different ages. Ann Otol Rhinol Laryngol. 1990;99:14-16.
Tos M, Stangerup S E, Larsen P. Incidence and progression of myringo-incudo-pexy after secretory otitis. Acta Otolaryngol. 1992;112:512-517. [pmid: 1441993].
Tos M. Importance of eustachian tube function in middle ear surgery. Ear Nose Throat J. 1998;77:744-747. [pmid: 9787517].
Toso C, Williams D M. Management of otitis media with effusion. J Am Pharm Assoc. 1996;NS36:591-592.
Tota J, Sebok J. Histological findings in infantile otoantritis. ORL J Otorhinolaryngol Relat Spec. 1976;38:284-293. [pmid: 1034248].
Tovi F, Gatot A, Lantsberg S. [Masked mastoiditis]. Harefuah. 1993;125:82–85, 127.
Tovi F, Gatot A, Lantsberg S. [Latent, non-suppurative mastoiditis. Apropos of 62 cases]. Ann Otolaryngol Chir Cervicofac. 1995;112:275-258. [pmid: 8561410].
Towsend E H. Otitis media in pediatric practice. NY State J Med. 1964;64:1591-1597.
Toyonaga Y, Ishihara T, Tezuka T, Nakamura H. [Bacteriological, pharmacokinetic and clinical studies of SY5555 dry syrup in the pediatric field]. Jpn-J-Antibiot. 1995;48:71-91. [pmid: 7699846].
Tracy J M, Demain J G, Hoffman K M, Goetz D W. Intranasal beclomethasone as an adjunct to treatment of chronic middle ear effusion. Ann-Allergy-Asthma-Immunol. 1998;80:198-206. [pmid: 9494455].
Tranchino G, Castagna G. The timpanometry in the application of the transtympanic drainages. Otorinolaringologia Pediatrica. 1990;1:100-102.
Trevor P B, Martin R A. Tympanic bulla osteotomy for treatment of middle-ear disease in cats: 19 cases (1984-1991). J Am Vet Med Assoc. 1993;202:123-128. [pmid: 8420899].
Triglia J M. Otitis media with effusion in children: Diagnosis. Medecine et Maladies Infectieuses. 1996;26:40-48.
Trout K S. How to read clinical journal: IV. To determine etiology or causation. Can Med Assoc J. 1981;124:985-990. [pmid: 7260801]. [pmcid: 1705401].
Trujillo H, Callejas R, Mejia G I, Castrillon L. Bacteriology of middle ear fluid specimens obtained by tympanocentesis from 111 Colombian children with acute otitis media. Pediatr Infect Dis J. 1989;8:361-363. [pmid: 2787494].
Trujillo L. Prevention of conductive hearing loss in cleft palate patients. Folia Phoniatr Logop. 1994;46:123-126. [pmid: 8019593].
Truy E, Disant F, Tiollier J, Froehlich P, Morgon A. A clinical study of human type IV collagen as tympanic membrane grafting material. Preliminary noncomparative study. Arch Otolaryngol Head Neck Surg. 1994;120:1329-1332. [pmid: 7980896].
Truy E, Morgon A, Veuillet E, Floret D, Belay-Genesseaux D, Fabry J. Neglected secretory otitis media screening. Positive predictive value of various tests usable with 4-year-old children in a school context. J Audiological Med. 1995;4:161-172.
Tsakris A, Psifidis A, Douboyas J. Complicated suppurative otitis media in a Greek diver due to a marine halophilic Vibrio sp. J Laryngol Otol. 1995;109:1082-1084. [pmid: 8551126].
Tsirulnikov E M, Vartanyan I A, Gersuni G V, Rosenblyum A S, Pudov V I, Gavrilov L R. Use of amplitude-modulated focused ultrasound for diagnosis of hearing disorders. Ultrasound Med Biol. 1988;14:277-285. [pmid: 3046092].
Tsumuraya E, Ishibashi Y, Suzuki N, et al. The problems of serous otitis media associated with sensorineural hearing loss in children. Pract Otol. 1981;74:2201-2208.
Tsuruhara K, Moreano A, Juhn S K, Kumazawa T. The determination of phospholipids in middle ear effusion from experimental otitis media in the chinchilla. Acta Oto-Laryngologica - Supplement. 1993;500:84-87.
Tsuruta Y, Hata F, Yane K, et al. Tissue transmigration of CZON (Cosmosin) to middle ear mucosa, maxillary sinus mucosa, and palatine tonsils. Auris Nasus Larynx. 1994;21:232-236. [pmid: 7779025].
Tsushima T, Menyuk P, Teele DW. Effects of otitis media on syllable realization in the speech of children. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:573–575.
Tsushima T, Menyuk P, Teele DW. Effects of otitis media on syllable realization in the speech of children. In: Lim DJ BC, Klein JO, Nelson JD, Ogra P, ed. Recent Advances in Otitis Media: Proceedings of the Fifith International Symposium: Decker Periodicals; 1993:573–575.
Tu T Y, Chen C S, Lien C F, Chang P. [Ventilation tube insertion for treating adult otitis media with effusion]. Chung Hua i Hsueh Tsa Chih - Chinese Medical Journal. 1993;51:276-280.
Tu T Y, Amiel C, Tran Ba Huy P, Herman P. Stimulation of sodium transport by oxidants in middle ear epithelium in primary culture. Acta Otolaryngol. 1995;115:291-295. [pmid: 7610824].
Tucker W E. Otitis media with effusion [letter; comment]. N Z Med J. 1996;109:367. [pmid: 8890870].
Tugwell P. How to read clinical journals: III. To learn the clinical course and prognosis of disease. Can Med Assoc J. 1981;124:869-872. [pmid: 7214286]. [pmcid: 1705372].
Tully S B, Bar-Haim Y, Bradley R L. Abnormal tympanography after supine bottle feeding. J Pediatr. 1995;126:S105-S111. [pmid: 7776069].
Tuohimaa P, Palva T. The effect of tonsillectomy and adenoidectomy on the intra-tympanic pressure. J Laryngol Otol. 1987;101:892-896. [pmid: 3668370].
Turik M A, Johns D Jr. Comparison of ceaclor and cefuroxime axetil in the treatment of acute otitis media with effusion in children who failed amoxicillin therapy. J Chemother. 1998;10:306-312. [pmid: 9720470].
Turner J L. Hearing results in malleostapediopexy. Arch Otolaryngol. 1969;89:499-503. [pmid: 5764103].
Turner R B, Darden P M. Effect of topical adrenergic decongestants on middle ear pressure in infants with common colds. Pediatr Infect Dis J. 1996;15:621-624. [pmid: 8823858].
Tusa R J, Saada A A Jr, Niparko J K. Dizziness in childhood. J Child Neurol. 1994;9:261-274. [pmid: 7930404].
Tutkun A. Ciprofloxacin [letter; comment]. Arch Otolaryngol Head Neck Surg. 1994;120:886. [pmid: 8049055].
Tutkun A, Ozagar A, Koc A, Batman C, Uneri C, Sehitoglu M A. Treatment of chronic ear disease. Topical ciprofloxacin vs topical gentamicin. Arch Otolaryngol Head Neck Surg. 1995;121:1414-1416. [pmid: 7488373].
Tutuncuoglu S, Uran N, Kavas I, Ozgur T. Gradenigo syndrome: a case report. Pediatr Radiol. 1993;23:556. [pmid: 8309765].
Tyberghein J. Hearing in children. Acta Otorhinolaryngol Belg. 1984;38:246-254. [pmid: 6542739].
U.S. BOTC. Statistical abstract of the United States, 1998 Springfield (VA): National Technical Information Services; 1996.
U.S. BOTC. Statistical abstract of the United States, 1998 Springfield (VA): National Technical Information Services; 1998.
Udaipurwala I H, Iqbal K, Saqulain G, Jalisi M. Pathological profile in chronic suppurative otitis media--the regional experience. JPMA - Journal of the Pakistan Medical Association. 1994;44:235-237.
Ueyama T, Kurono Y, Shirabe K, Takeshita M, Mogi G. High incidence of Haemophilus influenzae in nasopharyngeal secretions and middle ear effusions as detected by PCR. J-Clin-Microbiol. 1995;33:1835-1838. [pmcid: 228280]. [pmid: 7665655].
Uhari M, Hietala J, Tuokko H. Risk of acute otitis media in relation to the viral etiology of infections in children. Clin Infect Dis. 1995;20:521-524. [pmid: 7756470].
Uhari M, Niemela M, Hietala J. Prediction of acute otitis media with symptoms and signs. Acta Paediatr. 1995;84:90-92. [pmid: 7734909].
Uhari M, Kontiokari T, Koskela M, Niemela M. Xylitol chewing gum in prevention of acute otitis media: double blind randomised trial. Br Med J. 1996;313:1180-1184. [pmid: 8916749].
Uhari M, Mantysaari K, Niemela M. A meta-analytic review of the risk factors for acute otitis media [see comments]. Clin Infect Dis. 1996;22:1079-1083. [pmid: 8783714].
Uhari M, Kontiokari T, Niemela M. A novel use of xylitol sugar in preventing acute otitis media [see comments]. Pediatrics. 1998;102:879-884. [pmid: 9755259].
Ulualp S O, Sahin D, Yilmaz N, Anadol V, Peker O, Gursan O. Increased adenoid mast cells in patients with otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1999;49:107-114. [pmid: 10504016].
Ulug T, Sahinoglu K, Ozturk A, Ari Z. Surgical landmarks during mastoidal and petrosal operations. Okajimas Folia Anat Jpn. 1998;75:163-166. [pmid: 9871399].
Umetani Y, Minatogawa T, Kumoi T. The use of allograft stapes. Auris Nasus Larynx. 1985;12:67-72. [pmid: 4074210].
Ungureanu V, Nistor I, Gheorghe M. [Streptococcus pneumoniae strains isolated in acute otitis media in children]. Bacteriol Virusol Parazitol Epidemiol. 1996;41:51-55. [pmid: 8963118].
Uno Y, Saito R. Bone resorption in human cholesteatoma: morphological study with scanning electron microscopy. Ann Otol Rhinol Laryngol. 1995;104:463-468. [pmid: 7771720].
Updike C, Thornburg J D. Reading skills and auditory processing ability in children with chronic otitis media in early childhood. Ann Otol Rhinol Laryngol. 1992;101:530-537. [pmid: 1610072].
Urano M. Efficacy of acoustic otoscope in screening for children with otitis media with effusion. Jibi Inkoka Tokeibu Geka. 1990;62:583-586.
Urano M. [Surgical evaluation and clinical features of cholesteatoma in children]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1994;97:1250-1259.
Urquhart A C, McIntosh W A, Bodenstein N P. Drill-generated sensorineural hearing loss following mastoid surgery [see comments]. Laryngoscope. 1992;102:689-692. [pmid: 1602918].
Urwin G, Krohn JA, Deaver-Robinson K, Wenger JD, Farley MM. Invasive disease due to Haemophilus influenzae serotype f: clinical and epidemiologic characteristics in the H. influenzae serotype b vaccine era. The Haemophilus influenzae Study Group [see comments]. Clin Infect Dis. 1996;22:1069–1076.
Utrata J. Xanthogranuloma of the mastoid leading to a diagnosis of Hand-Schuller-Christian disease. Int Surg. 1972;57:511-513. [pmid: 5038831].
Utrata J. Gradenigo's syndrome--bilateral occurrence. Eye, Ear, Nose and Throat Monthly. 1973;52:142-144.
Valavanis A, Kubik S, Oguz M. Exploration of the facial nerve canal by high-resolution computed tomography: anatomy and pathology. Neuroradiology. 1983;24:139-147. [pmid: 6298657].
Vallejo Valdezate L A, Herrero Laso J L, Acuna Garcia M A, Duran Diez C D. [Middle ear pressure changes following adenoidectomy. Contribution to the etiopathogenic study of serous otitis media]. An Otorrinolaringol Ibero Am. 1995;22:249-279. [pmid: 7625598].
Valles Fontanet J, Oliva Izquierdo T. [Bacteriological study of serous otitis]. Acta Otorrinolaringol Esp. 1995;46:91-92. [pmid: 7598974].
Vallino-Napoli L D. Audiologic and otologic characteristics of Pfeiffer syndrome. Cleft Palate Craniofac J. 1996;33:524-529. [pmid: 8939381].
Valtonen M, Piippo T, Pitkajarvi T, Pyykonen M L. Comparison of amoxycillin given two and three times a day in acute respiratory tract infections in children. Scand J Prim Health Care. 1986;4:201-204. [pmid: 3797879].
Van B F L, Dunk J H M, Van H M A. Acute otitis media: Paracentesis, antibiotics or neither?. Ned Tijdschr Geneeskd. 1982;126:462-467. [pmid: 7078672].
van Alphen L, Caugant D A, Duim B, O'Rourke M, Bowler L D. Differences in genetic diversity of nonecapsulated Haemophilus influenzae from various diseases. Microbiology. 1997;143:1423-1431. [pmid: 9141705].
Van Baarle P W, Huygen P L, Brinkman W F. Findings in surgery for chronic otitis media. A retrospective data-analysis of 2225 cases followed for 2 years. Clin Otolaryngol Allied Sci. 1983;8:151-158. [pmid: 6883778].
van Balen F A, de Melker R A. Validation of a portable tympanometer for use in primary care. Int J Pediatr Otorhinolaryngol. 1994;29:219-225. [pmid: 8056505].
van Balen F A, de Melker R A, Touw-Otten F W. Double-blind randomised trial of co-amoxiclav versus placebo for persistent otitis media with effusion in general practice [see comments]. Lancet. 1996;348:713-716. [pmid: 8806290].
van Balen F A. [Antibiotics in otitis media with effusion (letter; comment)]. Ned Tijdschr Geneeskd. 1997;141:401-402. [pmid: 9157309].
Van Balen F A, Aarts A M, De Melker R A. Tympanometry by general practitioners: reliable?. Int J Pediatr Otorhinolaryngol. 1999;48:117-123. [pmid: 10375036].
Van Borsel J, Curfs L M, Fryns J P. Hyperacusis in Williams syndrome: a sample survey study. Genet Couns. 1997;8:121-126. [pmid: 9219010].
Van Boven B, Feenstra L. Value of acoustic otoscopy as recent technic in tracing secretal otitis media. Belgisch-Tijdschrift-voor-Geneeskunde. 1993;49:1401-1404.
Van Boven B, Feenstra L. Waarde van de akoestische otoscopie als recente techniek bij de opsporing van secetoire otitis media. Belgisch-Tijdschrift-voor-Geneeskunde. 1993;49:1401-1404.
van Buchem F L, Dunk J H, van't-Hof M A. Therapy of acute otitis media: myringotomy, antibiotics, or neither? A double-blind study in children. Lancet. 1981;2:883-887. [pmid: 6117681].
van Buchem F L, Peeters M F, van-'t-Hof M A. Acute otitis media: a new treatment strategy. Br Med J Clin Res Ed. 1985;290:1033-1037.
van Buchem FL, Knottnerus JA, Peeters MF. Otitis media in children [letter]. N Engl J Med. 1995;333:1151; discussion 1152.
Van Buchem F L, Peeters M F. [Neuro-otological complications of middle ear infection; the importance of early recognition (letter; comment)]. Ned Tijdschr Geneeskd. 1996;140:2009. [pmid: 8965934].
Van Camp K J, Shanks J E, Margolis R H. Simulation of pathological high impedance tympanograms. J Speech Hear Res. 1986;29:505-514. [pmid: 3795893].
Van Cauwenberge P, Cauwe F, Kluyskens P. The long-term results of the treatment with transtympanic ventilation tubes in children with chronic secretory otitis media. Int J Pediatr Otorhinolaryngol. 1979;1:109-116. [pmid: 576016].
Van Cauwenberge P, Derycke A. The relationship between nasal and middle ear pathology. Acta Otorhinolaryngol Belg. 1983;37:830-841. [pmid: 6686917].
Van Cauwenberge P, Van Cauwenberge K, Kluyskens P. The influence of otitis media with effusion on speech and language development and psycho-intellectual behaviour of the preschool child--results of a cross-sectional study in 1,512 children. Auris Nasus Larynx. 1985;12:S228-S230. [pmid: 3879718].
Van Cauwenberge P, Rysselaere M, Kluyskens P. New perspectives in the direct microscopic examination of middle ear effusions. Am J Otolaryngol. 1985;6:191-195. [pmid: 2409830].
van Cauwenberge P B, Vander Mijnsbrugge A M, Ingels K J. The microbiology of acute and chronic sinusitis and otitis media:a review. Eur Arch Otorhinolaryngol. 1993;250:S3-S6. [pmid: 8476583].
van Cauwenberge P B, Bellussi L, Maw A R, Paradise J L, Solow B. The adenoid as a key factor in upper airway infections. Int J Pediatr Otorhinolaryngol. 1995;32:S71-S80. [pmid: 7665305].
Van Cauwenberge PB, Vinck B, De Vel E, Dhooge I. Typanometry and click-evoked otoacoustic emissions in secretory otitis media: are C-EOAEs really consistently absent in type B tympanograms? Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:139–141.
Van Cauwenberge P B, Dhooge I, Downs M P, et al. Diagnosis and screening. Ann Otol Rhinol Laryngol. 1998;107:60-66.
Van Cauwenberge P, Watelet J B, Dhooge I. Uncommon and unusual complications of otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1999;49:119-125.
Van de Calseyde P, Blaton V, Ampe W, Goethals H, Peeters H. The protein pattern of middle ear effusion in serous otitis media behind an intact drum. Acta Otolaryngol. 1971;71:153-158. [pmid: 5577010].
Van den Borne B, Mens L H, Snik A F, Spies T H, Van den Broek P. Stapedius reflex and EABR thresholds in experienced users of the Nucleus cochlear implant. Acta Otolaryngol. 1994;114:141-143. [pmid: 8203194].
Van Den Broek P, Rach G H, Zielhuis G A. Does otitis media with effusion impair language acquisition in young children?. Ned Tijdschr Geneeskd. 1885;132:1885-1888. [pmid: 3185781].
van den Broek P, Zielhuis G A, Van der Wilt G J. Treatment of persistent otitis media [letter; comment]. Lancet. 1996;348:1517-1518. [pmid: 8942802].
van der Baan S, Seldenrijk C A, Henzen-Logmans S C, Drexhage H A. Serous otitis media and immunological reactions in the middle ear mucosa. Acta Otolaryngol. 1988;106:428-434. [pmid: 3061276].
van der Meer J W, van de Lisdonk E H. Treatment of otitis media [letter; comment]. Clin Infect Dis. 1995;21:1069. [pmid: 8645827].
van der Merwe J, Wagenfeld D J. The negative effects of mucolytics in otitis media with effusion. S-Afr-Med-J. 1987;72:625-626. [pmid: 3317935].
Van Der Vyver M, Van Der Merwe A, Tesner H E C. The effects of otitis media on articulation in children with cerebral palsy. Int J Rehabil Res. 1988;11:386-389.
van Dyk J C, Terespolsky S A, Meyer C S, van Niekerk C H, Klugman K P. Penetration of cefpodoxime into middle ear fluid in pediatric patients with acute otitis media. Pediatr Infect Dis J. 1997;16:79-81. [pmid: 9002110].
Van Dyke D C, Yeager D J, McInerney J F, Schellinger D, Fox A A. Speech and language disorders in children. Am Fam Physician. 1984;29:257-268. [pmid: 6203392].
Van Ginkel C J, Bruintjes T D, Huizing E H. Allergy due to topical medications in chronic otitis externa and chronic otitis media. Clin Otolaryngol. 1995;20:326-328. [pmid: 8548964].
Van Hare G F, Shurin P A, Marchant C D, et al. Acute otitis media caused by Branhamella catarrhalis: biology and therapy. Rev-Infect-Dis. 1987;9:16-27. [pmid: 3493519].
van Nieuwkerk E B, van der Baan S, Richters C D, Kamperdijk E W. Isolation and characterization of dendritic cells from adenoids of children with otitis media with effusion. Clin Exp Immunol. 1992;88:345-349. [pmid: 1572100]. [pmcid: 1554297].
van Nieuwkerk E B, van der Baan S, Hoefsmit E C, Kamperdijk E W. Localization and morphology of antigen-presenting cells in the adenoid of children with otitis media with effusion. Clin Immunol Immunopathol. 1995;74:59-69. [pmid: 7994928].
van Rooy C H, Swart J G, Op't Hof J, Vlantis A C, Ahmed M R, Venter P H. Diagnosis and treatment of ear disease among children in the Ellisras district. An outreach programme. S Afr Med J. 1995;85:675-677. [pmid: 7482088].
Vanclooster C, Debruyne F, Vantrappen G, Desloovere C, Feenstra L. Labyrinthine fistulae: a retrospective analysis. Acta Otorhinolaryngol Belg. 1997;51:119-121. [pmid: 9241379].
Vanderschueren-Lodeweyckx M, Debruyne F, Dooms L, Eggermont E, Eeckels R. Sensorineural hearing loss in sporadic congenital hypothyroidism. Arch Dis Child. 1983;58:419-422. [pmid: 6859932].
Varga A, Picano E, Sicari R, Gliozheni E, Palmieri C, Marzilli M. Relative role of coronary stenosis severity and morphology in determining pharmacologic stress echo positivity. Am J Cardiol. 1998;82:166-171. [pmid: 9678286].
Varsano I, Volovitz B, Mimouni F. Sulfisoxazole prophylaxis of middle ear effusion and recurrent acute otitis media. Am-J-Dis-Child. 1985;139:632-635. [pmid: 3890523].
Varsano I, Frydman M, Amir J, Alpert G. Single intramuscular dose of ceftriaxone as compared to 7-day amoxicillin therapy for acute otitis media in children. A double-blind clinical trial. Chemotherapy. 1988:39–46.
Varsano I B, Volovitz B M, Grossman J E. Effect of naproxen, a prostaglandin inhibitor, on acute otitis media and persistence of middle ear effusion in children. Ann-Otol-Rhinol-Laryngol. 1989;98:389-392. [pmid: 2655526].
Varsano I, Volovitz B, Horev Z, et al. Intramuscular ceftriaxone compared with oral amoxicillin-clavulanate for treatment of acute otitis media in children. Eur J Pediatr. 1997;156:858-863. [pmid: 9392401].
Vartanyan I A, Tsirul'nikov E M. Auditory perception of focused ultrasound (anatomical, physiological, electrophysiological, psychophysical, and clinical physiological aspects). Human Physiology. 1985;11:170-177. [pmid: 3879236].
Vartiainen E, Karjalainen S. Autologous ossicle and cortical bone in ossicular reconstruction. Clin Otolaryngol Allied Sci. 1985;10:307-310. [pmid: 3913544].
Vartiainen E, Harma R, Karjalainen S. Surgery of chronic adhesive otitis media. Clin Otolaryngol Allied Sci. 1985;10:163-164. [pmid: 4040822].
Vartiainen E, Karja J, Harma R. Re-operation after failure of surgery for chronic ears. J Laryngol Otol. 1986;100:1027-1030. [pmid: 3760683].
Vartiainen E, Karja J. Bilateral chronic otitis media. Arch Otorhinolaryngol. 1986;243:190-193. [pmid: 3753297].
Vartiainen E, Karja J, Karjalainen S. Surgery of chronic otitis media in young patients. J Laryngol Otol. 1986;100:515-519. [pmid: 3701198].
Vartiainen E, Karjalainen S, Karja J. Postoperative evaluation of chronic otitis media caused by pseudomonas aeruginosa. J Laryngol Otol. 1986;100:141-144. [pmid: 3950473].
Vartiainen E, Karjalainen S. Factors influencing sensorineural hearing loss in chronic otitis media. Am J Otolaryngol. 1987;8:13-15. [pmid: 3578673].
Vartiainen E, Nuutinen J. Long-term hearing results of one-stage tympanoplasty for chronic otitis media. Eur Arch Otorhinolaryngol. 1992;249:329-331. [pmid: 1418943].
Vartiainen E. Results of surgical treatment for chronic noncholesteatomatous otitis media in the pediatric population. Int J Pediatr Otorhinolaryngol. 1992;24:209-216. [pmid: 1399309].
Vartiainen E, Kansanen M. Tympanomastoidectomy for chronic otitis media without cholesteatoma. Otolaryngol Head Neck Surg. 1992;106:230-234. [pmid: 1589211].
Vartiainen E, Nuutinen J. Long-term results of surgical treatment in different cholesteatoma types. Am J Otol. 1993;14:507-511. [pmid: 8122717].
Vartiainen E. Fate of patients with bilateral cholesteatoma. Am J Otolaryngol. 1993;14:49-52. [pmid: 8434720].
Vartiainen E. Findings in revision myringoplasty. Ear Nose Throat J. 1993;72:201-204. [pmid: 8482263].
Vartiainen E, Virtaniemi J. Findings in revision operations for failures after cholesteatoma surgery. Am J Otol. 1994;15:229-232. [pmid: 8172307].
Vartiainen E, Vartiainen J. Age and hearing function in patients with chronic otitis media. J Otolaryngol. 1995;24:336-339. [pmid: 8699598].
Vartiainen E, Virtaniemi J, Vartiainen J. Long-term post-operative follow-up of patients with chronic otitis media. Does it make sense?. Clin Otolaryngol Allied Sci. 1995;20:352-354. [pmid: 8548970].
Vartiainen E, Vartiainen J. Hearing results of surgery for chronic otitis media without cholesteatoma. Ear Nose Throat J 1995;74:165–166, 169.
Vartiainen E, Vartiainen J. Hearing results of surgery for acquired cholesteatoma. Ear Nose Throat J. 1995;74:160–162, 164.
Vartiainen E. Factors associated with recurrence of cholesteatoma. J Laryngol Otol. 1995;109:590-592. [pmid: 7561462].
Vartiainen E, Vartiainen J. Hearing levels of young patients 10 years after mastoidectomy. Int J Pediatr Otorhinolaryngol. 1996;37:9-15. [pmid: 8884402].
Vartiainen E, Vartiainen J. Effect of aerobic bacteriology on the clinical presentation and treatment results of chronic suppurative otitis media. J Laryngol Otol. 1996;110:315-318. [pmid: 8733450].
Vartiainen E, Kansanen M, Vartiainen J. The contralateral ear in patients with chronic otitis media. Am J Otol. 1996;17:190-192. [pmid: 8723943].
Vartiainen E, Seppa J. Results of bone conduction following surgery for chronic ear disease. Eur Arch Otorhinolaryngol. 1997;254:384-386. [pmid: 9332894].
Vartiainen E. Changes in the clinical presentation of chronic otitis media from the 1970s to the 1990s. J Laryngol Otol. 1998;112:1034-1037. [pmid: 10197139].
Vartiainen E, Karjalainen S. Prevalence and etiology of unilateral sensorineural hearing impairment in a Finnish childhood population. Int J Pediatr Otorhinolaryngol. 1998;43:253-259. [pmid: 9663947].
Vasiliu D I. Contributions to the morphophysiological study of the auditory apparatus. When does the pneumatization of cephalic cavities appear? When does hearing appear in humans?. Revue Roumaine de Physiologie. 1969;6:159-167. [pmid: 5821598].
Vaughan-Jones R, Mills R P. The Welch Allyn Audioscope and Microtymp: their accuracy and that of pneumatic otoscopy, tympanometry and pure tone audiometry as predictors of otitis media with effusion. J Laryngol Otol. 1992;106:600-602. [pmid: 1527455].
Veldman J E, Braunius W W. Revision surgery for chronic otitis media: a learning experience. Report on 389 cases with a long-term follow-up. Ann Otol Rhinol Laryngol. 1998;107:486-491. [pmid: 9635458].
Venker J. The restoration of the ossicular-chain by means of cartilage. Practica Oto-Rhino-Laryngologica. 1968;30:29-34. [pmid: 5635554].
Venker J. The missing incus. ORL J Otorhinolaryngol Relat Spec. 1973;35:237-240. [pmid: 4583009].
Ventry I M. Effects of conductive hearing loss: fact or fiction. J Speech Hear Disord. 1980;45:143-156. [pmid: 7442148].
Vermeersch H, Kluyskens P, Vanderstock L. The temporal bone as route of infection in recurrent meningitis. J Otolaryngol. 1980;9:199-201. [pmid: 6968832].
Vernon-Feagans L, Manlove E E, Volling B L. Otitis media and the social behavior of day-care-attending children. Child Dev. 1996;67:1528-1539. [pmid: 8890498].
Vernon-Feagans L, Emanuel D, Blood I. Otitis media and day care: factors that affect children's language. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:331–334.
Vernon-Feagans L, Emanuel D C, Blood I. The effect of otitis media and quality of daycare on children's language development. J Appl Devel Psychol. 1997;18:395-409.
Vernon-Feagans L. Impact of Otitis Media on Speech, Language, Cognition, and Behavior. In: Rosenfeld RM, Bluestone CD, eds. Evidence-Based Otitis Media. Saint Louis: B.C. Decker Inc.; 1999:353–373.
Verse T, Pirsig W, Heymer B. [A case of sarcoidosis of the mastoid]. Laryngorhinootologie. 1997;76:312-314. [pmid: 9280419].
Vincent R, Gratacap B, Causse JB, Gherini S. Argon laser and Gherini-Causse Endo-Otoprobe in otologic surgery. Ear Nose Throat J. 1996;75:770, 773–778, 780.
Vinther B, Elbrond O, Pedersen C B. A population study of otitis media in childhood. Acta Oto-Laryngologica - Supplement. 1979;360:135-137.
Vinther B, Brahe Pedersen C, Elbrond O. Otitis media in childhood. Sociomedical aspects with special reference to day-care conditions. Clin Otolaryngol Allied Sci. 1984;9:3-8. [pmid: 6539180].
Virapongse C, Sarwar M, Kier E L, Sasaki C, Pillsbury H. Temporal bone disease: a comparison between high resolution computed tomography and pluridirectional tomography. Radiology. 1983;147:743-748. [pmid: 6844610].
Virapongse C, Sarwar M, Bhimani S, Sasaki C, Shapiro R. Computed tomography of temporal bone pneumatization: 2. Petrosquamosal suture and septum. Ajnr: American Journal of Neuroradiology. 1985;6:561-568. [pmid: 3927672].
Virolainen E, Puhakka H, Aantaa E, Tuohimaa P, Ruuskanen O, Meurman O H. Prevalence of secretory otitis media in seven to eight year old school children. Ann Otol Rhinol Laryngol Suppl. 1980;89:7-10. [pmid: 6778355].
Virolainen A, Salo P, Jero J, Karma P, Eskola J, Leinonen M. Comparison of PCR assay with bacterial culture for detecting Streptococcus pneumoniae in middle ear fluid of children with acute otitis media. J Clin Microbiol. 1994;32:2667-2670. [pmcid: 264139]. [pmid: 7852553].
Virolainen A, Jero J, Kayhty H, Karma P, Leinonen M, Eskola J. Antibodies to pneumolysin and pneumococcal capsular polysaccharides in middle ear fluid of children with acute otitis media. Acta Otolaryngol. 1995;115:796-803. [pmid: 8749202].
Virolainen A, Jero J, Kayhty H, Karma P, Eskola J, Leinonen M. Nasopharyngeal antibodies to pneumococcal pneumolysin in children with acute otitis media. Clin Diagn Lab Immunol. 1995;2:704-707. [pmcid: 170225]. [pmid: 8574834].
Virolainen A, Vero J, Kayhty H, Karma P, Leinonen M, Eskola J. Nasopharyngeal antibodies to pneumococcal capsular polysaccharides in children with acute otitis media. J Infect Dis. 1995;172:1115-1118. [pmid: 7561192].
Virolainen A, Jero J, Chattopadhyay P, Karma P, Eskola J, Leinonen M. Comparison of serum antibodies to pneumolysin with those to pneumococcal capsular polysaccharides in children with acute otitis media. Pediatr Infect Dis J. 1996;15:128-133. [pmid: 8822285].
Virtanen H, Palva T, Jauhiainen T. The prognostic value of Eustachian tube function measurements in tympanoplastic surgery. Acta Otolaryngol. 1980;90:317-323. [pmid: 7211325].
Vishniakov VV. [Bioceramic prosthesis of the ear ossicles in tympanoplasty]. Vestn Otorinolaringol. 1993:49–51.
Visness C M, Kennedy K I, Labbok M. Day care, infant feeding, and ear infections [letter; comment]. Am J Public Health. 1995;85:267-268. [pmid: 7856792].
Vivian R. [Recurrent secretory otitis media and adenoidism. A retrospective study of the results observed with the medical and surgical therapy of 1250 children]. Recenti Prog Med. 1994;85:481-484. [pmid: 7809461].
Vlachou S, Ferekidis E, Tsakanikos M, Apostolopoulos N, Adamopoulos G. Prognostic value of multiple-frequency tympanometry in acute otitis media. ORL J Otorhinolaryngol Relat Spec. 1999;61:195-200. [pmid: 10450053].
Vlahos L, Yiotakis J, Gouliamos A, Kotoulas G, Adamopoulos G. Localized mastoiditis simulating a facial nerve schwannoma on MRI. J Laryngol Otol. 1994;108:1008-1009. [pmid: 7829940].
Vogelgesang MW BH. Ventilation tubes in the pediatric population. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:306–308.
Volkova MO, Kostiukova NN, Kvetnaia AS. [The role of hyaluronidase in the occurrence of a generalized pneumococcal infection]. Zh Mikrobiol Epidemiol Immunobiol. 1994;Suppl:118–122.
Von T, Deitz J C, McLaughlin J, DeButts S, Richardson M. The effects of chronic otitis media on motor performance in 5- and 6-year-old children. Am J Occup Ther. 1988;42:421-426. [pmid: 3207145].
von Scheel J. [Prevention of adhesions in the middle ear]. Laryngorhinootologie. 1996;75:254. [pmid: 8688134].
von Schoenberg M, Wengraf C L, Gleeson M. Results of middle ear ventilation with Goode's tubes. Clin Otolaryngol Allied Sci. 1989;14:503-508. [pmid: 2612029].
von Unge M, Bagger-Sjoback D. Tympanic membrane changes in experimental otitis media with effusion. Am J Otol. 1994;15:663-669. [pmid: 8572069].
von Unge M, Decraemer W F, Dirckx J J, Bagger-Sjoback D. Shape and displacement patterns of the gerbil tympanic membrane in experimental otitis media with effusion. Hear Res. 1995;82:184-196. [pmid: 7775284].
von Unge M, Decraemer W F, Bagger-Sjoback D, Van den Berghe D. Tympanic membrane changes in experimental purulent otitis media. Hear Res. 1997;106:123-136. [pmid: 9112112].
Voronkin VF, Efimtsev Iu P. [The use of computed tomography of the temporal bone for the early diagnosis and prognosis of otogenic intracranial complications]. Vestn Otorinolaringol. 1994:22–24.
Vorwerk U, Penk S, Brosz M, Begall K. [Evaluation of deprivation manifestations of the auditory system in patients with unilateral middle ear deafness before and after surgical therapy]. Laryngorhinootologie. 1996;75:195-198. [pmid: 8688124].
Vrabec J T. Delayed facial palsy after tympanomastoid surgery. Am J Otol. 1999;20:26-30. [pmid: 9918167].
Vrionis FD, Foley KT, Robertson JH, Shea JJ, 3rd. Use of cranial surface anatomic fiducials for interactive image-guided navigation in the temporal bone: a cadaveric study. Neurosurgery. 1997;40:755–763; discussion 763–764.
Wachtendorf CA, Lopez LL, Cooper JC, Hearne EM, Gates GA. The efficacy of school screening for otitis media. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:242.
Wacker D F, Howe M L. Middle ear cilia activity as a determinant of tympanostomy tube placement. Otolaryngol Head Neck Surg. 1986;95:434-437. [pmid: 3106905].
Wada H, Koike T, Kobayashi T. Clinical applicability of the sweep frequency measuring apparatus for diagnosis of middle ear diseases. Ear Hear. 1998;19:240-249. [pmid: 9657598].
Wadman B. [The Riskronden answers (letter)]. Lakartidningen. 1996;93:2924. [pmid: 8815349].
Wake M, Robinson J M, Witcombe J B, Bazerbachi S, Stansbie J M, Phelps P D. Detection of recurrent cholesteatoma by computerized tomography after ‘closed cavity’ mastoid surgery. J Laryngol Otol. 1992;106:393-395. [pmid: 1613362].
Wake M, Smallman L A. Ciliary beat frequency of nasal and middle ear mucosa in children with otitis media with effusion. Clin Otolaryngol Allied Sci. 1992;17:155-157. [pmid: 1587032].
Wakefield A J, Murch S H, Anthony A, et al. Ileal-lymphoid-nodular hyperplasia, non-specific colitis, and pervasive developmental disorder in children [see comments]. Lancet. 1998;351:637-641. [pmid: 9500320].
Walby A P, Barrera A, Schuknecht H F. Cochlear pathology in chronic suppurative otitis media. Ann Otol Rhinol Laryngol Suppl. 1983;103:1-19. [pmid: 6404208].
Wald E R. Changing trends in the microbiology of otitis media with effusion. Pediatr Infect Dis. 1984;3:380-383. [pmid: 6540869].
Wald E R. Resistance to penicillin in Streptococcus pneumoniae [letter; comment]. J Pediatr. 1996;129:178. [pmid: 8757587].
Wald E R. Conjunctivitis in infants and children. Pediatr Infect Dis J. 1997;16:S17-S20. [pmid: 9041623].
Walker A, Chernoff R, Joffe A, Wilson M E. Child abuse, sudden infant death syndrome, infectious disease, and vaccinations. Curr Opin Pediatr. 1994;6:225-231. [pmid: 8032405].
Walker J B, Hussey E K, Treanor J J, Montalvo A Jr, Hayden F G. Effects of the neuraminidase inhibitor zanamavir on otologic manifestations of experimental human influenza. J Infect Dis. 1997;176:1471-1422.
Walker P. Ventilation tube duration versus site of placement. Aust-N-Z-J-Surg. 1997;67:571-572. [pmid: 9287928].
Wall L G, Shuster L I, Buhrer K, Lutes R A. Reliability and performance of the acoustic reflectometer. J Fam Pract. 1986;23:443-447. [pmid: 3772317].
Wallace R B, Marsh B T, Talbot D J. A multi-centre general practice clinical evaluation of pivmecillinam plus pivampicillin (‘Miraxid’) and co-trimoxazole (‘Septrin’) in respiratory tract infections. Curr-Med-Res-Opin. 1985;9:659-665. [pmid: 3907987].
Wallace I F, Gravel J S, McCarton C M, Ruben R J. Otitis media and language development at 1 year of age. J Speech Hear Disord. 1988;53:245-251. [pmid: 3398478].
Wallace I F, Gravel J S, McCarton C M, Stapells D R, Bernstein R S, Ruben R J. Otitis media, auditory sensitivity, and language outcomes at one year. Laryngoscope. 1988;98:64-70. [pmid: 3336264].
Wallace IF, Gravel JS, McCarton CM, Stapells DR, Bernstein RS, Ruben RJ. Otitis Media and Its Effect on Language in Infancy. Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:388–391.
Wallace S P, Prutting C A, Gerber S E. Degeneration of speech, language, and hearing in a patient with mucopolysaccharidosis VII. Int J Pediatr Otorhinolaryngol. 1990;19:97-107. [pmid: 2115509].
Wallace IF, Gravel JS, Ganon EC, Ruben RJ. Two-year language outcomes as a function of otitis media and parental linguistic styles. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:527–530.
Wallace I F, Gravel J S, Schwartz R G, Ruben R J. Otitis media, communication style of primary caregivers, and language skills of 2 year olds: a preliminary report. J Dev Behav Pediatr. 1996;17:27-35. [pmid: 8675711].
Wallenborn P A Jr. What's new in otology?. Medical Times. 1970;98:147-157. [pmid: 5469234].
Walsh R M, Davies M M, McGlashan J A, Bowdler D A. The role of the Davis graft technique in the treatment of chronic post-mastoidectomy otorrhoea. Clin Otolaryngol. 1996;21:162-167. [pmid: 8735404].
Walsh F P, Cox L C, MacDonald C B. Historic perspective of the acoustic otoscope. J Am Acad Audiol. 1998;9:35-40. [pmid: 9493940].
Walz P H, Mullaney T P, Render J A, Walker R D, Mosser T, Baker J C. Otitis media in preweaned Holstein dairy calves in Michigan due to Mycoplasma bovis. J Vet Diagn Invest. 1997;9:250-254. [pmid: 9249163].
Wanamaker H H, Arandia H Y. Epinephrine hypersensitivity-induced cardiovascular crisis in otologic surgery. Otolaryngol Head Neck Surg. 1994;111:841-844. [pmid: 7527511].
Wandstrat T L, Kaplan B. Pharmacoeconomic impact of factors affecting compliance with antibiotic regimens in the treatment of acute otitis media. Pediatr Infect Dis J. 1997;16:S27-S29. [pmid: 9041626].
Wang J, Liu S. [Causes of erroneous diagnosis in SOM]. Chung Hua Erh Pi Yen Hou Ko Tsa Chih - Chinese Journal of Otorhinolaryngology. 1994;29:201-203.
Wang D Y, Bernheim N, Kaufman L, Clement P. Assessment of adenoid size in children by fibreoptic examination. Clin Otolaryngol Allied Sci. 1997;22:172-177. [pmid: 9160934].
Ward N O, Berry D W. Is there a role for primary care in the specialist's office?. Arch Otolaryngol Head Neck Surg. 1993;119:721-722. [pmid: 8318200].
Wardrop P A, Pillsbury H Cd. Mycobacterium avium acute mastoiditis. Arch Otolaryngol. 1984;110:686-687. [pmid: 6477264].
Warnaar A, Snoep G, Stals F S. A swollen cheek, an unusual course of acute mastoiditis. Int J Pediatr Otorhinolaryngol. 1989;17:179-183. [pmid: 2759783].
Warner-Smith B. Otitis media in general practice [letter; comment] [see comments]. Med J Aust. 1993;159:70. [pmid: 8316136].
Watanabe H, Shin T, Fukaura J, Nakaaki K, Tsuda K. Measurement of young children's total actual speaking time by a newly devised accumulator as an assessment of otitis media with effusion. Auris Nasus Larynx. 1985;12:S239-S240. [pmid: 3915204].
Watanabe H, Shin T, Fukaura J, Nakaaki K, Tsuda K. Total actual speaking time in infants and children with otitis media with effusion. Int J Pediatr Otorhinolaryngol. 1985;10:171-180. [pmid: 4093256].
Watanabe T, Fujiyoshi T, Tomonaga K, Mogi G. Adenoids and otitis media with effusion in children. Adv Otorhinolaryngol. 1992;47:290-296. [pmid: 1456150].
Watanabe N, Bondo J, Mogi G. Three-dimensional investigation of the postoperative condition after ossiculoplasty with hydroxylapatite corp. (Running title; 3-D investigation of Corp). Rev Laryngol Otol Rhinol. 1995;116:23-26.
Watkin P M. Otological disease in Turner's syndrome. J Laryngol Otol. 1989;103:731-738. [pmid: 2769041].
Watkin P M, Baldwin M, Laoide S. Parental suspicion and identification of hearing impairment. Arch Dis Child. 1990;65:846-850. [pmid: 2400221].
Watson T J. Identification and follow up of children with exudative otitis media. Proceedings of the Royal Society of Medicine. 1969;62:455-456. [pmid: 5770590]. [pmcid: 1810994].
Watson C, Mangat K S. A comparison of audiometric performance and complications of T tubes and Shepard grommets. J Laryngol Otol. 1988;102:677-679. [pmid: 3418217].
Watson D S, Clapin M. Ear health of aboriginal primary school children in the Eastern Goldfields Region of Western Australia. Aust J Public Health. 1992;16:26-30. [pmid: 1627706].
Watson C. Persistent glue ear in children [letter; comment] [see comments]. Br Med J. 1993;306:454. [pmid: 8461733].
Watson R M, Coward T J, Forman G H. Results of treatment of 20 patients with implant-retained auricular prostheses. Int J Oral Maxillofac Implants. 1995;10:445-449. [pmid: 7672847].
Watson P, Voss L, Barber C, Aickin R, Bremner D, Lennon D. The microbiology of chronic otitis media with effusion in a group of Auckland children [see comments]. N Z Med J. 1996;109:182-184. [pmid: 8657383].
Watters G W, Jones J E, Freeland A P. The predictive value of tympanometry in the diagnosis of middle ear effusion. Clin Otolaryngol Allied Sci. 1997;22:343-345. [pmid: 9298609].
Weatherton M A, Ferguson A G. A comparison of individual units of an artificial mastoid. J Speech Hear Res. 1974;17:165-168. [pmid: 4836037].
Webb R L, Clark G M, Shepherd R K, Franz B K, Pyman B C. The biologic safety of the Cochlear Corporation multiple-electrode intracochlear implant. Am J Otol. 1988;9:8-13. [pmid: 3364540].
Weber P C, Rosner D. An unusual cause of eustachian tube dysfunction. Otolaryngol Head Neck Surg. 1997;117:S142-S144. [pmid: 9419129].
Webster D B, Webster A B. Effects of neonatal conductive hearing loss on brainstem auditory nuclei. Ann Otol. 1979;88:684-688.
Webster A, Bamford J M, Thyer N J, Ayles R. The psychological, educational and auditory sequelae of early, persistent secretory otitis media. J Child Psychol Psychiatry. 1989;30:529-546. [pmid: 2768356].
Wehrs R E. Three years' experience with the homograft tympanic membrane. Transactions - American Academy of Ophthalmology and Otolaryngology. 1972;76:142-146. [pmid: 5024597].
Wehrs R E. Results of reconstructive mastoidectomy with homograft knee cartilage. Laryngoscope. 1978;88:1912-1917. [pmid: 581602].
Wehrs R E. Hearing results in tympanoplasty. Laryngoscope. 1985;95:1301-1306. [pmid: 4058206].
Weigel M T, Parker M Y, Goldsmith M M, Postma D S, Pillsbury H C. A prospective randomized study of four commonly used tympanostomy tubes. Laryngoscope. 1989;99:252-256. [pmid: 2645490].
Weiglein A H, Anderhuber W, Jakse R, Einspieler R. Imaging of the facial canal by means of multiplanar angulated 2-D-high-resolution CT-reconstruction. Surg Radiol Anat. 1994;16:423-427. [pmid: 7725200].
Weiglein A H. Postnatal development of the facial canal. An investigation based on cadaver dissections and computed tomography. Surg Radiol Anat. 1996;18:115-123. [pmid: 8782317].
Weiner G M, Williams B. Prevention of intracranial problems in ear and sinus surgery: a possible role for cefotaxime. J Laryngol Otol. 1993;107:1005-1007. [pmid: 7904618].
Weiner G M, O'Connell J E, Pahor A L. The role of surgery in tuberculous mastoiditis: appropriate chemotherapy is not always enough. J Laryngol Otol. 1997;111:752-753. [pmid: 9327015].
Weippl G, Michos N, Stocker H. Clinical experience and results of treatment with suprofen in pediatrics. 4th communication: Assessment of pain in babies and infants/Analgesic effect of suprofen syrup in otitis media. Arzneimittelforschung. 1985;35:1732-1734. [pmid: 3879175].
Weir M R, Lampe R M. Assessing middle ear disease: beyond visual otoscopy. Am Fam Physician. 1984;30:201-210. [pmid: 6541863].
Weiss M H, Liberatore L A, Kraus D H, Budnick A S. Otitis media with effusion in head and neck cancer patients. Laryngoscope. 1994;104:5-7. [pmid: 8295456].
Weiss J C, Yates G R, Quinn L D. Acute otitis media: making an accurate diagnosis [see comments]. Am Fam Physician. 1996;53:1200-1206. [pmid: 8629566].
Welling D B, Hinojosa R, Gantz B J, Lee J T. Insertional trauma of multichannel cochlear implants. Laryngoscope. 1993;103:995-1001. [pmid: 8361322].
Welling D B, Forrest L A, Goll F, 3rd. Safety of ototopical antibiotics [see comments]. Laryngoscope. 1995;105:472-474. [pmid: 7760659].
Wells N, King J, Hedstrom C, Youngkins J. Does tympanic temperature measure up?. MCN Am J Matern Child Nurs. 1995;20:95-100. [pmid: 7723615].
Welsh L W, Welsh J J, Healy M P. Effect of sound deprivation on central hearing. Laryngoscope. 1983;93:1569-1575. [pmid: 6645758].
Welsh L W, Welsh J J, Healy M P. Early sound deprivation and long-term hearing. Ann Otol Rhinol Laryngol. 1996;105:877-881. [pmid: 8916863].
Welty T, Hawk R, Rogers K. A program for correction of ear perforations in Navajo Indian children. Public Health Rep. 1977;92:167-170. [pmid: 847088]. [pmcid: 1431990].
Wendler-Shaw PD, Menyuk P, Teele DW. Effects of otitis media in the first year of life on language production in the second year of life. In: Lim DJ BC, Klein JO, Nelson JK, Ogra P, ed. Recent Advances in Otitis Media: Proceedings of the Fifith International Syposium. Hamilton, Ontario: Decker Periodicals; 1993:534–536.
Wendt L K, Jonsell R. Illness and use of medicines in relation to caries development and to immigrant status in infants and toddlers living in Sweden. Swed Dent J. 1996;20:151-159. [pmid: 8899952].
Wenig B M. Schneiderian-type mucosal papillomas of the middle ear and mastoid. Ann Otol Rhinol Laryngol. 1996;105:226-233. [pmid: 8615588].
Wennmo C, Petersen H, Flisberg K. Cholesteatoma surgery with the canal-wall-down technique. ORL J Otorhinolaryngol Relat Spec. 1996;58:39-41. [pmid: 8718537].
Werkhaven J A, Reinisch L, Sorrell M, Tribble J, Ossoff R H. Noninvasive optical diagnosis of bacteria causing otitis media. Laryngoscope. 1994;104:264-268. [pmid: 8127180].
Westover DE, Daly KA, Margolis RH, et al. Chronic otitis media with effusion morbidity in a prospective cohort: study design implications and a preliminary report of long-term outcomes in children treated with tympanostomy tubes. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:11–14.
Wetmore S J, Abramson M. Bullous myringitis with sensorineural hearing loss. Otolaryngology and Head and Neck Surgery. 1979;87:66-70. [pmid: 503473].
Wetmore R F, Henry W J, Konkle D F. Acoustical factors of noise created by suctioning middle ear fluid. Arch Otolaryngol Head Neck Surg. 1993;119:762-766. [pmid: 8318206].
Weymuller E A, Reed D G. Otological problems of the Alaskan native population. Laryngoscope. 1972;82:1793-1798. [pmid: 5076411].
Wheeler M T. Tympanometry in children with treated acute otitis media. Lancet. 1986;1:529-532. [pmid: 2869263].
White B, Golden WL, Casselbrant ML, Steele MW. Otitis media study of infant twins. Ann Otol Rhinol Laryngol. 1983;96.
White D W. Recurrent alternating facial palsy in a child [letter]. Am J Otol. 1993;14:97-98. [pmid: 8424489].
White L L, Holimon T D, Tepedino J T, Portner T S, Wan J Y, Thompson J W. Antimicrobials prescribed for otitis media in a pediatric Medicaid population. Am J Health Syst Pharm. 1996;53:2963-2969. [pmid: 8974159].
Whitehurst L R. Common problems in the medical care of pilots. Am Fam Physician. 1979;20:133-138. [pmid: 573054].
Whittemore K R Jr, Merchant S N, Rosowski J J. Acoustic mechanisms: canal wall-up versus canal wall-down mastoidectomy. Otolaryngol Head Neck Surg. 1998;118:751-761. [pmid: 9627232].
Whittet H B, Marks N, Heyworth T, Parker R. Persistent glue ear in children [letter; comment]. Br Med J. 1993;306:454. [pmid: 8461734].
Wickham M H, Marven S S, Narula A A. Three ‘silent’ mastoid abscesses. Br J Clin Pract. 1990;44:242-243. [pmid: 2206818].
Widemar L, Svensson C, Rynnel-Dagoo B, Schiratzki H. The effect of adenoidectomy on secretory otitis media: a 2-year controlled prospective study. Clin Otolaryngol Allied Sci. 1985;10:345-350. [pmid: 3830481].
Wielinga E W, Smyth G D. Comparison of the Goode T-tube with the Armstrong tube in children with chronic otitis media with effusion. J Laryngol Otol. 1990;83:1174-1177.
Wiet RJ, DeBlanc GB, Stewart J, Weider DJ. Natural History of Otitis Media in the American Native. Proceedings of the Second International Symposium: Recent Advances in Otitis Media with Effusion; 1980:14–19.
Wiet RJ, Monsell EM, Hotaling AJ. Hearing and balance disorders. How to recognize, when to refer. Postgrad Med. 1985;77:119–127, 130.
Wilairatana P, Looareesuwan S. Melioidotic otitis media. Southeast Asian J Trop Med Public Health. 1994;25:776-777. [pmid: 7667731].
Wilber L A, Goodhill V. Real ear versus artificial mastoid methods of calibration of bone-conduction vibrators. J Speech Hear Res. 1967;10:405-416. [pmid: 6081925].
Wilber L A. Comparability of two commercially available artificial mastoids. J Acoust Soc Am. 1972;52:1265-1266. [pmid: 4638042].
Wilde A D, England J, Jones A S. An alternative to regular dressings for otitis externa and chronic supperative otitis media?. J Laryngol Otol. 1995;109:101-103. [pmid: 7535834].
Wiley T L, Smith P S U. Acoustic-immittance measures and middle-ear screening. Semin Hear. 1995;16:60-79.
Willett D N, Rezaee R P, Billy J M, Tighe M B, DeMaria T F. Relationship of endotoxin to tumor necrosis factor-alpha and interleukin-1 beta in children with otitis media with effusion. Ann Otol Rhinol Laryngol. 1998;107:28-33. [pmid: 9439385].
Williams D M, Thomas R S. Fibrous dysplasia. J Laryngol Otol. 1975;89:359-374. [pmid: 1127331].
Williams R G, Haughton P M. Tympanometric diagnosis of middle ear effusions. J Laryngol Otol. 1977;91:959-962. [pmid: 591781].
Williams S R, Robinson P J, Brightwell A P. Management of the inflammatory aural polyp. J Laryngol Otol. 1989;103:1040-1042. [pmid: 2607199].
Williams M J. Blunt trauma leading to facial nerve paralysis. J Emerg Med. 1991;9:27-28. [pmid: 1955677].
Williams R L, Chalmers T C, Stange K C, Chalmers F T, Bowlin S J. Use of antibiotics in preventing recurrent acute otitis media and in treating otitis media with effusion. A meta-analytic attempt to resolve the brouhaha [published erratum appears in JAMA 1994 Feb 9;271(6):430] [see comments]. JAMA. 1993;270:1344-1351. [pmid: 8141875].
Williams M, Purdy S, Barber C. High frequency probe tone tympanometry in infants with middle ear effusion. Australian Journal of Otolaryngology. 1995;2:169-173.
Williams K R, Blayney A W, Lesser T H. Mode shapes of a damaged and repaired tympanic membrane as analysed by the finite element method. Clin Otolaryngol. 1997;22:126-131. [pmid: 9160924].
Williamson A d, Amedee R G, Klimek L. The management of otitis media with effusion. J La State Med Soc. 1991;143:7-9. [pmid: 2072002].
Williamson I G, Dunleavey J, Robinson D. Risk factors in otitis media with effusion. A 1 year case control study in 5–7 year old children. Fam Pract. 1994;11:271-274. [pmid: 7843516].
Williamson I G, Dunleavey J, Bain J, Robinson D. The natural history of otitis media with effusion--a three-year study of the incidence and prevalence of abnormal tympanograms in four South West Hampshire infant and first schools. J Laryngol Otol. 1994;108:930-934. [pmid: 7829943].
Williamson I, Sheridan C. The development of a test of speech reception disability for use in 5- to 8-year-old children with otitis media with effusion. Eur J Disord Commun. 1994;29:27-37. [pmid: 8032104].
Williamson I, Sheridan C, Galker E, Lous J. A video-based performance in noise test for measuring audio-visual disability in young school children: test development, with validation by trained teachers, parents and audiometry as relative standards for disability. Int J Pediatr Otorhinolaryngol. 1999;49:127-133. [pmid: 10504019].
Willis R. Stapedectomy complications. J Laryngol Otol. 1976;90:31-40. [pmid: 1255002].
Wilmot J F, Cable H R. Persistent effusion following acute otitis media: tympanometry and pneumatic otoscopy in diagnosis. J R Coll Genl Practitioners. 1988;38:149-152.
Wilson T G. The otolaryngological hazards of the perinatal period. Proceedings of the Royal Society of Medicine. 1967;60:407-414. [pmid: 6067058]. [pmcid: 1901751].
Wilson J. Deafness in developing countries. Approaches to a global program of prevention. Arch Otolaryngol. 1985;111:2-9. [pmid: 3155613].
Wilson J. Hearing impairment in developing countries. J Otolaryngol. 1990;19:368-371. [pmid: 2149152].
Wind J. Tympanic effusions. A retrospective and prospective investigation into their aetiology and treatment. Acta Otorhinolaryngol Belg. 1984;38:610-618. [pmid: 6543631].
Windle-Taylor P C, Bailey C M. Tuberculous otitis media: a series of 22 patients. Laryngoscope. 1980;90:1039-1044. [pmid: 6770207].
Winter G B. Commentary: what about the ethics?. Br Med J. 1996;313:1183-1184. [pmid: 8916750].
Wintermeyer S M, Nahata M C. Chronic suppurative otitis media. Ann Pharmacother. 1994;28:1089-1099. [pmid: 7803887].
Wintermeyer S M, Nahata M C. Alcaligenes xylosoxidans subsp xylosoxidans in children with chronic otorrhea. Otolaryngol Head Neck Surg. 1996;114:332-334. [pmid: 8637765].
Wintermeyer S M, Hart M C, Nahata M C. Efficacy of ototopical ciprofloxacin in pediatric patients with otorrhea. Otolaryngol Head Neck Surg. 1997;116:450-453. [pmid: 9141393].
Wischnack L L, Jacobson R M, Poland G A, Jacobsen S J, Harrison J M, Murtaugh P A. The surprisingly high acceptability of low-efficacy vaccines for otitis media: a survey of parents using hypothetical scenarios. Pediatrics. 1995;95:350-354. [pmid: 7862472].
Wiseman L R, Benfield P. Cefprozil. A review of its antibacterial activity, pharmacokinetic properties, and therapeutic potential. Drugs. 1993;45:295-317. [pmid: 7681376].
Wiseman J B, Arriaga M A, Houston G D, Boyd E M. Facial paralysis and inflammatory pseudotumor of the facial nerve in a child. Otolaryngol Head Neck Surg. 1995;113:826-828. [pmid: 7501405].
Witsell D L, Garrett C G, Yarbrough W G, Dorrestein S P, Drake A F, Weissler M C. Effect of Lactobacillus acidophilus on antibiotic-associated gastrointestinal morbidity: a prospective randomized trial. J-Otolaryngol. 1995;24:230-233. [pmid: 8551535].
Witt L. The appropriateness of tympanostomy tubes for children [letter; comment]. JAMA. 1995;273:700; discussion 700–701.
Woldag K, Kosling S. [Therapy refractory inflammation of the ENT area. Wegener's granulomatosis]. HNO. 1997;45:40-41. [pmid: 9132399].
Wolfaardt J F, Wilkes G H, Parel S M, Tjellstrom A. Craniofacial osseointegration: the Canadian experience. Int J Oral Maxillofac Implants. 1993;8:197-204. [pmid: 8359877].
Wolfowitz B L. Tuberculous mastoiditis. Arch Otolaryngol. 1972;95:109-113. [pmid: 5060055].
Wolfowitz B. Spontaneous CSF otorrhea simulating serous otitis. Arch Otolaryngol. 1979;105:496-499. [pmid: 572669].
Wolthers O D. Tympanometric screening in children on admission to a paediatric ward: a preliminary study. Int J Pediatr Otorhinolaryngol. 1990;19:251-257. [pmid: 2210951].
Wong J, Hawke M. The cytopathology of middle ear effusions (a new technique). J Otolaryngol. 1983;12:356-360. [pmid: 6686616].
Wong B J, Lee J, Hashisaki G T, Berns M W, Neev J. Thermal imaging of the temporal bone in CO2 laser surgery: an experimental model. Otolaryngol Head Neck Surg. 1997;117:610-615. [pmid: 9419087].
Wong D L, Rutka J A. Do aminoglycoside otic preparations cause ototoxicity in the presence of tympanic membrane perforations?. Otolaryngol Head Neck Surg. 1997;116:404-410. [pmid: 9121801].
Woodhead J C, Milavetz G. Prednisone treatment of otitis media with effusion. AJDC. 1986;140:318.
Woodrow P K, Gajarawala J, Yaghoobian J, Pinck R L. CT detection of subarachnoid pneumocephalus secondary to mastoid fracture. Journal of Computed Tomography. 1981;5:199-201. [pmid: 7273833].
Woods C R, Smith A L, Wasilauskas B L, Campos J, Givner L B. Invasive disease caused by Neisseria meningitidis relatively resistant to penicillin in North Carolina. J Infect Dis. 1994;170:453-456. [pmid: 8035036].
Woodwell DA, Schappert SM. National ambulatory medical care survey: 1993 summary. Advance data from vital and health statistics Hyattsville (MD): National Center for Health Statistics; 1995.
Woodwell DA. National ambulatory medical care survey: 1995 summary. Advance data from vital and health statistics Hyattsville (MD): National Center for Health Statistics; 1997a.
Woodwell DA. National ambulatory medical care survey. Advance data from vital and health statistics Hyattsville (MD): National Center for Health Statistics; 1997b.
Woolford T J, Morris D P, Saeed S R, Rothera M P. The implant-site split-skin graft technique for the bone-anchored hearing aid. Clin Otolaryngol Allied Sci. 1999;24:177-180. [pmid: 10384841].
Woolley A L, Oser A B, Lusk R P, Bahadori R S. Preoperative temporal bone computed tomography scan and its use in evaluating the pediatric cochlear implant candidate. Laryngoscope. 1997;107:1100-1106. [pmid: 9261015].
Woollons A C, Morton R P. When does middle ear effusion signify nasopharyngeal cancer?. N Z Med J. 1994;107:507-509. [pmid: 7830981].
Wormald P J, Browning G G, Robinson K. Is otoscopy reliable? A structured teaching method to improve otoscopic accuracy in trainees. Clin Otolaryngol Allied Sci. 1995;20:63-67. [pmid: 7788938].
Wortzman G, Conrad K, Farkashidy J. Temporal bone: a tomographic anatomic study. Journal of the Canadian Association of Radiologists. 1977;28:95-105. [pmid: 323267].
Woznicki GW, Grzegorowski M, Woznicka D. Tympanometric evaluation of otitis media in children with insulin-dependent diabetes mellitus. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:146–147.
Wright H N, Cannella F. Differential effect of conductive hearing loss on the threshold-duration function. J Speech Hear Res. 1969;12:607-615. [pmid: 5811851].
Wright J L. Acute leukaemia presenting as acute mastoiditis. J Laryngol Otol. 1971;85:1087-1091. [pmid: 5097132].
Wright J L, Schuknecht H F. Atrophy of the spiral ligament. Arch Otolaryngol. 1972;96:16-21. [pmid: 5032052].
Wright J L, Grimaldi P M. Otogenic intracranial complications. J Laryngol Otol. 1973;87:1085-1096. [pmid: 4752961].
Wright J L, Etholm B. Anomalies of the middle-ear muscles. J Laryngol Otol. 1973;87:281-288. [pmid: 4694554].
Wright P F, Bryant J D, Karzon D T. Comparison of influenza B/Hong Kong virus infections among infants, children, and young adults. J Infect Dis. 1980;141:430-435. [pmid: 7373080].
Wright P, Thompson J, McConnell KB, Sitton AB, Bess FH. Audiologic and Speech Evaluation of a Prospectively Followed Cohort of Normal Children: The Impact of Otitis Media. Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:338–341.
Wright P F, McConnell K B, Thompson J M, Vaughn W K, Sell S H. A longitudinal study of the detection of otitis media in the first two years of life. Int J Pediatr Otorhinolaryngol. 1985;10:245-252. [pmid: 3830948].
Wright P F, Sell S H, McConnell K B, et al. Impact of recurrent otitis media on middle ear function, hearing, and language. J Pediatr. 1988;113:581-587. [pmid: 3411407].
Wright C G, Meyerhoff W L. Pathology of otitis media. Ann Otol Rhinol Laryngol Suppl. 1994;163:24-26. [pmid: 8179265].
Wright T W, Linscheid R L, O'Duffy J D. Acute flexor tenosynovitis in association with Clostridium difficile infection: a case report. Journal of Hand Surgery - American Volume. 1996;21:304-306.
Wu C H, Hsu C J, Hsieh F J. Preliminary use of endoluminal ultrasonography in assessment of middle ear with effusion. J Ultrasound Med. 1998;17:427-430. [pmid: 9669300].
Wuillemin W A, Vischer M W, Tobler A, Fey M F. Relapse of acute myeloblastic leukaemia presenting as temporal bone chloroma with facial nerve paralysis [letter]. Ann Oncol. 1993;4:339-340. [pmid: 8518228].
Wullstein S R. Osteoplastic epitympanotomy. Ann Otol Rhinol Laryngol. 1974;83:663-669. [pmid: 4414959].
Wuolijoki E, Flygare U, Hilden M, et al. Treatment of respiratory tract infections with erythromycin acistrate and two formulations of erythromycin base. J-Antimicrob-Chemother. 1988:107–112.
Xue M, Liu Y, Li L. [Measuring of immune complexes and antinuclear antibodies in effusion of secretory otitis media]. Chung Hua Erh Pi Yen Hou Ko Tsa Chih - Chinese Journal of Otorhinolaryngology. 1994;29:228-230.
Yagi N, Nakatani H. Stapedial muscle electromyography in various diseases. Arch Otolaryngol Head and Neck Surgery. 1987;113:392-396.
Yagi N, Nakatani H. Stapedial electromyograms recorded by electrocochleography. Ann Otol Rhinol Laryngol. 1988;97:87-91. [pmid: 3341707].
Yagi H, el Bahari S, Mohamed H A, et al. The Marrara syndrome: a hypersensitivity reaction of the upper respiratory tract and buccopharyngeal mucosa to nymphs of Linguatula serrata. Acta Trop. 1996;62:127-134. [pmid: 9025980].
Yaginuma Y, Kobayashi T, Sai Y, Takasaka T. [Predictive value of electrogustometry in the preoperative diagnosis of severity of middle ear pathology]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1996;99:1635-1640.
Yaginuma Y, Kobayashi T, Takasaka T. The habit of sniffing in nasal diseases as a cause of secretory otitis media. Am J Otol. 1996;17:108-110. [pmid: 8694111].
Yamada O, Yamane H, Kodera K. Simultaneous recordings of the brain stem response and the frequency-following response to low-frequency tone. Electroencephalogr Clin Neurophysiol. 1977;43:362-370. [pmid: 70337].
Yamada O, Gonnella J S, Suzuki J I, Potsic W P. An organic and functional staging classification. A measurement of disability in otolaryngology. Arch Otolaryngol. 1981;107:617-619. [pmid: 6945081].
Yamada K, Kaga K, Suzuki J. Temporal bone pathology in patients without caloric response. Acta Otolaryngol. 1994;114:586-594. [pmid: 7879614].
Yamaguchi T, Urasawa T, Kataura A. Secretory immunoglobulin A antibodies to respiratory viruses in middle ear effusion of chronic otitis media with effusion. Ann Otol Rhinol Laryngol. 1984;93:73-75. [pmid: 6538393].
Yamamoto E, Mizukami C. Development of the vestibular aqueduct in Meniere's disease. Acta Oto-Laryngologica - Supplement. 1993;504:46-50.
Yamamoto E, Tasaka Y, Mizukami C, Ogata T, Okumura T, Tanabe M. Tympanoplasty on the only hearing ear with chronic otitis media. Adv Otorhinolaryngol. 1997;51:35-40. [pmid: 9017068].
Yamanaka N, Somekawa Y, Suzuki T, Kataura A. Immunologic and cytologic studies in otitis media with effusion. Acta Otolaryngol. 1987;104:481-486. [pmid: 3434270].
Yamanaka N, Faden H. Local antibody response to P6 of nontypable Haemophilus influenzae in otitis-prone and normal children. Acta Otolaryngol. 1993;113:524-529. [pmid: 8379309].
Yamanaka N, Faden H. Antibody response to outer membrane protein of nontypeable Haemophilus influenzae in otitis-prone children. J Pediatr. 1993;122:212-218. [pmid: 8429433].
Yamashita T, Schuknecht H F. Apical endolymphatic hydrops. Arch Otolaryngol. 1982;108:463-466. [pmid: 7103821].
Yamashita K. Pneumatic endoscopy of the Eustachian tube. Endoscopy. 1983;15:257-259. [pmid: 6684022].
Yamashita K, Miyazaki T. Diagnostic significance of endoscopy of the eustachian tube. Auris Nasus Larynx. 1985;12:S55-S57. [pmid: 3835937].
Yanagihara N, Yagi T. Limitation of long term ventilation tube: in view of complications and hearing restoration. Auris Nasus Larynx. 1985;12:S244-S246. [pmid: 3835921].
Yanagisawa E, Carlson R D. Telescopic video-otoscopy using a compact home video color camera. Laryngoscope. 1987;97:1350-1355. [pmid: 3669847].
Yang W, Wang R, Sun J. [Ultracytochemical observation of secretory cells and surfactant-like lamellar bodies in mucosa of eustachian tube]. Chung Hua Erh Pi Yen Hou Ko Tsa Chih - Chinese Journal of Otorhinolaryngology. 1995;30:224-226.
Yaniv E, Traub P, Conradie R. Middle ear tuberculosis--a series of 24 patients. Int J Pediatr Otorhinolaryngol. 1986;12:59-63. [pmid: 3818191].
Yaniv E. Tuberculous otitis: an underdiagnosed disease. Am J Otolaryngol. 1987;8:356-360. [pmid: 3434672].
Yaniv E. Tuberculous otitis media: a clinical record. Laryngoscope. 1987;97:1303-1306. [pmid: 3669842].
Yankelowitz S, Gravel J, Wallace I, Karma P. A clinical research form for use in the documentation of middle ear effusion. Ear Hear. 1991;12:296-298. [pmid: 1783232].
Yanta M J, Brown O E, Fancher J R. Bilateral ear canal stenosis from retained Goode T-tubes. Int J Pediatr Otorhinolaryngol. 1996;37:173-178. [pmid: 8894815].
Yates P D, Upile T, Axon P R, de Carpentier J. Aspergillus mastoiditis in a patient with acquired immunodeficiency syndrome. J Laryngol Otol. 1997;111:560-561. [pmid: 9231092].
Yawn BP, Yawn RA, Lydick E. The relative community burden of otitis media and varicella. Clin Ther. 1996;18:877–886; discussion 876.
Yazawa Y, Kitahara M. Computerized tomography of the petrous bone in Meniere's disease. Acta Oto-Laryngologica - Supplement. 1994;510:67-72.
Yazawa Y, Kitano H, Suzuki M, Kodama A, Kitajima K. [Long-term results of Feldmann's osteoplastic approach for chronic middle ear disease]. Nippon Jibiinkoka Gakkai Kaiho [Journal of the Oto-Rhino-Laryngological Society of Japan]. 1996;99:1746-1750.
Yellon R F, Leonard G, Marucha P, et al. Demonstration of interleukin 6 in middle ear effusions. Arch Otolaryngol Head Neck Surg. 1992;118:745-748. [pmid: 1627297].
Yellon R F, Rose E, Kenna M A, et al. Sensorineural hearing loss from quinolinic acid: a neurotoxin in middle ear effusions. Laryngoscope. 1994;104:176-181. [pmid: 8302120].
Yellon R F, Doyle W J, Whiteside T L, Diven W F, March A R, Fireman P. Cytokines, immunoglobulins, and bacterial pathogens in middle ear effusions [published erratum appears in Arch Otolaryngol Head Neck Surg 1995 Dec;121(12):1402]. Arch Otolaryngol Head Neck Surg. 1995;121:865-869. [pmid: 7619411].
Yoffe N, Ostfeld E. [Disturbances in eustachian tube function--role of experimental studies]. Harefuah. 1993;125:376-378. [pmid: 8253409].
Young R F, Frazee J. Gas within intracranial abscess cavities: an indication for surgical excision. Ann Neurol. 1984;16:35-39. [pmid: 6147117].
Young Y H, Lin K L, Ko J Y. Otitis media with effusion in patients with nasopharyngeal carcinoma, postirradiation. Arch Otolaryngol Head Neck Surg. 1995;121:765-768. [pmid: 7598854].
Young Y H, Cheng P W, Ko J Y. A 10-year longitudinal study of tubal function in patients with nasopharyngeal carcinoma after irradiation. Arch Otolaryngol Head Neck Surg. 1997;123:945-948. [pmid: 9305244].
Youngs R P, Gatland D J. Is aspiration of middle ear effusions prior to ventilation tube insertion really necessary?. J-Otolaryngol. 1988;142:773-779.
Youngs R. Temporal bone histopathology of open mastoidectomy cavities. J Laryngol Otol. 1993;107:569-573. [pmid: 8345310].
Youssef T F, Poe D S. Endoscope-assisted second-stage tympanomastoidectomy. Laryngoscope. 1997;107:1341-1344. [pmid: 9331310].
Yu W K, Shimo G. Otitic hydrocephalus. Canadian Journal of Otolaryngology. 1975;4:712-719.
Yuan Z, Russlie H Q, Canafax D M. Sensitive assay for measuring amoxicillin in human plasma and middle ear fluid using solid-phase extraction and reversed-phase high-performance liquid chromatography. Journal of Chromatography B: Biomedical Applications. 1995;674:93-99.
Yuen P W, Lau S K, Chau P Y, et al. Ofloxacin eardrop treatment for active chronic suppurative otitis media: prospective randomized study. Am J Otol. 1994;15:670-673. [pmid: 8572070].
Yuen P W, Wei W I. Tympanomastoidectomy for chronic suppurative otitis media of irradiated ears of nasopharyngeal carcinoma patients. J Otolaryngol. 1994;23:302-304. [pmid: 7996633].
Yuen A P, Chau P Y, Wei W I. Bacteriology of chronic suppurative otitis media: ofloxacin susceptibility. J Otolaryngol. 1995;24:206-208. [pmid: 7674449].
Yune H Y, Hall J R, Hutton C E, Klatte E C. Roentgenologic diagnosis in chronic temporomandibular joint dysfunction syndrome. American Journal of Roentgenology, Radium Therapy and Nuclear Medicine. 1973;118:401-414.
Yung M W, Morris T M. Tuning-fork tests in diagnosis of serous otitis media. Br Med J Clin Res Ed. 1981;283:1576.
Yung M M. The use of rigid endoscopes in cholesteatoma surgery. J Laryngol Otol. 1994;108:307-309. [pmid: 8182315].
Yung M W. Small cavity mastoidectomy--5 year review. Clin Otolaryngol Allied Sci. 1996;21:24-29. [pmid: 8674218].
Yung M M, Karia K R. Mastoid obliteration with hydroxyapatite--the value of high resolution CT scanning in detecting recurrent cholesteatoma. Clin Otolaryngol Allied Sci. 1997;22:553-557. [pmid: 9466070].
Yung M W. Type IV tympanoplasty revisited. Am J Otol. 1998;19:700-703. [pmid: 9831139].
Yung M W. The effect of nasal continuous positive airway pressure on normal ears and on ears with atelectasis. Am J Otol. 1999;20:568-572. [pmid: 10503577].
Yung M M. The Yung percutaneous mastoid vent: a medium-term follow-up study. Arch Otolaryngol Head Neck Surg. 1999;125:964-968. [pmid: 10488980].
Zachau-Christiansen B, Pedersen C B. Chronic middle ear inflammation and its sequelae in the population of Greenland. Arctic Med Res. 1988;47:666-668. [pmid: 3272709].
Zahraa J, Johnson D, Lim-Dunham J E, Herold B C. Unusual features of osteoarticular tuberculosis in children. J Pediatr. 1996;129:597-602. [pmid: 8859268].
Zakzouk S M. Deaf children in Saudi Arabia. Saudi Medical Journal. 1982;3:185-190.
Zakzouk S M, al-Muhaimeed H S. Hearing impairment among "at risk' children [published erratum appears in Int J Pediatr Otorhinolaryngol 1997 Apr 11;39(3):255]. Int J Pediatr Otorhinolaryngol. 1996;34:75-85. [pmid: 8770675].
Zanetti D, Antonelli A R. Treatment of the draining mastoid cavity. Adv Otorhinolaryngol. 1997;51:41-45. [pmid: 9017069].
Zangemeister W H, Bock O. The influence of pneumatization of mastoid bone on caloric nystagmus response. A clinical study and a mathematical model. Acta Otolaryngol. 1979;88:105-109. [pmid: 474108].
Zappia J J, Bunge F A, Koopmann C F Jr, McClatchey K D. Facial nerve paresis as the presenting symptom of leukemia. Int J Pediatr Otorhinolaryngol. 1990;19:259-264. [pmid: 2210952].
Zargi M, Boltezar I H. Effects of recurrent otitis media in infancy on auditory perception and speech. Am J Otolaryngol. 1992;13:366-372. [pmid: 1443393].
Zbaren P, Pradervand M. Randomized double-blind study between co-tetroxacine and amoxicilline in common ENT-infections. SCHWEIZ-RUNDSCH-MED-PRAX. 1983;72:1491-1493. [pmid: 6361727].
Zechner G, Tarkkanen J, Holopainen E. Histomorphological and histochemical studies of chronically infected middle ear mucous membrane. Ann Otol Rhinol Laryngol. 1968;77:54-65. [pmid: 5645141].
Zechner G. Secretory otitis media. Acta Otorhinolaryngol Belg. 1983;37:138-141. [pmid: 6683921].
Zeisel S A, Roberts J E, Gunn E B, et al. Prospective surveillance for otitis media with effusion among black infants in group child care. J Pediatr. 1995;127:875-880. [pmid: 8523182].
Zeisel S A, Roberts J E, Neebe E C, Riggins R Jr, Henderson F W. A longitudinal study of otitis media with effusion among 2- to 5-year-old African-American children in child care. Pediatrics. 1999;103:15-19. [pmid: 9917433].
Zemskov AM, Poliakova SD. [Dependence of immunological reactivity on blood groups and microflora in patients with chronic purulent otitis media]. Vestn Otorinolaringol. 1996:39–42.
Zemskov AM, Zemskov VM, Poliakova SD, Bzhovoskii E. [Methods for assessing the efficacy of immunocorrection]. Zh Mikrobiol Epidemiol Immunobiol. 1997:51–53.
Zenni M K, Cheatham S H, Thompson J M, et al. Streptococcus pneumoniae colonization in the young child: association with otitis media and resistance to penicillin [see comments]. J Pediatr. 1995;127:533-537. [pmid: 7562272].
Zenone T, Souquet P J, Bohas C, Vital Durand D, Bernard J P. Unusual manifestations of giant cell arteritis: pulmonary nodules, cough, conjunctivitis and otitis with deafness. Eur Respir J. 1994;7:2252-2254. [pmid: 7713213].
Zhang X, Huang X. [Study on mechanism of eustachian tube active opening ventilation and pump-like function]. Chung Hua Erh Pi Yen Hou Ko Tsa Chih - Chinese Journal of Otorhinolaryngology. 1994;29:166-169.
Zhang Q, Jessurun J, Schachern P A, Paparella M M, Fulton S. Outgrowing schwannomas arising from tympanic segments of the facial nerve. Am J Otolaryngol. 1996;17:311-315. [pmid: 8870936].
Zheng C, Guyot J P, Montandon P. Ossiculoplasty by interposition of a minor columella between the tympanic membrane and stapes head. Am J Otol. 1996;17:200-202. [pmid: 8723946].
Zielhuis G A, Rach G H, van den Broek P. Predisposing factors for otitis media with effusion in young children. Adv Otorhinolaryngol. 1988;40:65-69. [pmid: 3389232].
Zielhuis G A, Rach G H, van den Broek P. Screening for otitis media with effusion in preschool children. Lancet. 1989;1:311-314. [pmid: 2563465].
Zielhuis G A, Heuvelmans-Heinen E W, Rach G H, van den Broek P. Environmental risk factors for otitis media with effusion in preschool children. Scand J Prim Health Care. 1989;7:33-38. [pmid: 2727458].
Zielhuis G A, Straatman H, Rach G H, van den Broek P. Analysis and presentation of data on the natural course of otitis media with effusion in children. Int J Epidemiol. 1990;19:1037-1044. [pmid: 2083987].
Zielhuis G A, Rach G H, van den Broek P. The natural course of otitis media with effusion in preschool children. Eur Arch Otorhinolaryngol. 1990;247:215-221. [pmid: 2375863].
Zielhuis G A, Rach G H, Van den Broek P. The occurrence of otitis media with effusion in Dutch pre-school children. Clin Otolaryngol Allied Sci. 1990;15:147-153. [pmid: 2350892].
Zielhuis G A, Straatman H, van't Hof-Grootenboer A E, van Lier H J, Rach G H, van den Broek P. The choice of a balanced allocation method for a clinical trial in otitis media with effusion. Stat Med. 1990;9:237-246. [pmid: 2343219].
Zielhuis GA, Rach GH, Schilder AGM, Van Den Broek P. Screening for otitis media with effusion in preschool children. Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:53.
Zielhuis G A, Gerritsen A A, Gorissen W H, et al. Hearing deficits at school age; the predictive value of otitis media in infants. Int J Pediatr Otorhinolaryngol. 1998;44:227-234. [pmid: 9780068].
Zielnik B. [Otitis media with effusion in children]. Otolaryngol Pol. 1995;49:214-219. [pmid: 7566991].
Zieno S A. CHAMPUS recapture in the treatment of ear infections. Mil Med. 1993;158:273-274. [pmid: 8479638].
Zimmerman R A, Bilaniuk L T, Hackney D B, Goldberg H I, Grossman R I. Magnetic resonance imaging of traumatic sinus and mastoid bleeding. Acta Radiologica - Supplementum. 1986;369:367-369. [pmid: 2980498].
Zimmerman W D, Ganzel T M, Windmill I M, Nazar G B, Phillips M. Peripheral hearing loss following head trauma in children. Laryngoscope. 1993;103:87-91. [pmid: 8421426].
Zini C, Sanna M, Bacciu S, Delogu P, Gamoletti R, Scandellari R. Molded tympanic heterograft. An eight-year experience. Am J Otol. 1985;6:253-256. [pmid: 4003536].
Zini C, Sanna M, Jemmi G, Gandolfi A. Transmastoid extralabyrinthine approach in traumatic facial palsy. Am J Otol. 1985;6:216-221. [pmid: 4003528].
Zinkus P W, Gottlieb M I, Schapiro M. Developmental and psychoeducational sequelae of chronic otitis media. Am J Dis Child. 1978;132:1100-1104. [pmid: 82400].
Zinkus P W, Gottlieb M I. Patterns of perceptual and academic deficits related to early chronic otitis media. Pediatrics. 1980;66:246-253. [pmid: 7402809].
Zlomaniec J, Bryc S, Czerwonka R. Recurrent otitis media in children and obstructed nasal patency in endoscopic-radiographic examination. Annales Universitatis Mariae Curie-Sklodowska - Sectio d - Medicina. 1994;49:67-70. [pmid: 8771831].
Zocconi E. Antibiotics and oral steroids in the treatment of otitis media with effusion. Pediatr Med Chir. 1994;16:273-275. [pmid: 7971452].
Zocconi E. [Antibiotics and cortisone in the treatment of otitis media with effusion]. Pediatr Med Chir. 1994;16:273-275. [pmid: 7971452].
Zora J A, Silk H J, Tinkelman D G. Evaluation of postimmunization pneumococcal titers in children with recurrent infections and normal levels of immunoglobulin [see comments]. Annals of Allergy. 1993;70:283-288. [pmid: 8466092].