# References

Abraham S S, Wallace I F, Gravel J S. Early otitis media and phonological development at age 2 years. Laryngoscope. 1996;106:727-732. [pmid: 8656958].
Alho O P, Koivunen P, Luotonen J, Linder T E, Grenier B. Diagnostic criteria for otitis media in children. Oto Rhino Laryngologia Nova. 1998;8:123-128.
Amedee R G. The effects of chronic otitis media with effusion on the measurement of transiently evoked otoacoustic emissions. Laryngoscope. 1995;105:589-595. [pmid: 7769941].
Aniansson G. Screening diagnosis of secretory otitis media. Scand Audiol Suppl. 1986;26:65-69. [pmid: 3472329].
Avery C A, Gates G A, Prihoda T J. Efficacy of acoustic reflectometry in detecting middle ear effusion. Ann Otol Rhinol Laryngol. 1986;95:472-476. [pmid: 3532904].
Babonis T R, Weir M R, Kelly P C. Impedance tympanometry and acoustic reflectometry at myringotomy [published erratum appears in Pediatrics 1991 Jun;87(6):945]. Pediatrics. 1991;87:475-480. [pmid: 2011423].
Barnett ED, Klein JO, Hawkins KA, Cabral HJ, Kenna M, Healy G. Comparison of spectral gradient acoustic reflectometry and other diagnostic techniques for detection of middle ear effusion in children with middle ear disease. Pediatr Infect Dis J. 1998;17:556–559; discussion 580.
Beery Q C, Andrus W S, Bluestone C D, Cantekin E I. Tympanometric pattern classification in relation to middle ear effusions. Ann Otol Rhinol Laryngol. 1975;84:56-64. [pmid: 1111435].
Begg C B, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1999;50:1088-1101. [pmid: 7786990].
Ben-David J, Podoshin L, Fradis M. Tympanometry and audiometry in diagnosis of middle-ear effusions. Ear Nose Throat J. 1981;60:120-123. [pmid: 7194176].
Berman S. Medical management of children with otitis media with effusion. In: Quie PG, ed. The Report on Pediatric Infectious Diseases. New York: Churchill Livingstone; 1993:37–38.
Berman S, Roark R, Luckey D. Theoretical cost effectiveness of management options for children with persisting middle ear effusions. Pediatrics. 1994;93:353-363. [pmid: 8115191].
Birch L, Elbrond O. Prospective epidemiological investigation of secretory otitis media in children attending day-care centers. ORL J Otorhinolaryngol Relat Spec. 1984;46:229-234. [pmid: 6541331].
Black M M, Gerson L F, Freeland C A, Nair P, Rubin J S, Hutcheson J J. Language screening for infants prone to otitis media. J Pediatr Psychol. 1988;13:423-433. [pmid: 3199297].
Black M M, Sonnenschein S. Early exposure to otitis media: a preliminary investigation of behavioral outcome. J Dev Behav Pediatr. 1993;14:150-155. [pmid: 7688005].
Block SL, Mandel E, McLinn S, et al. Spectral gradient acoustic reflectometry for the detection of middle ear effusion by pediatricians and parents [published erratum appears in Pediatr Infect Dis J 1998 Nov;17(11):1011]. Pediatr Infect Dis J. 1998;17:560–564; discussion 580.
Block S L, Pichichero M E, McLinn S, Aronovitz G, Kimball S. Spectral gradient acoustic reflectometry: detection of middle ear effusion in suppurative acute otitis media. Pediatr Infect Dis J. 1999;18:741-744. [pmid: 10462354].
Bluestone C D, Beery Q C, Paradise J L. Audiometry and tympanometry in relation to middle ear effusions in children. Laryngoscope. 1973;83:594-604. [pmid: 4700869].
Bluestone C D, Cantekin E I. Design factors in the characterization and identification of otitis media and certain related conditions. Ann Otol Rhinol Laryngol Suppl. 1979;88:13-28. [pmid: 115359].
Bluestone CD. Definitions, Terminology, and Classification. In: Rosenfeld RM, Bluestone CD, eds. Evidence-Based Otitis Media. Saint Louis: B.C. Decker, Inc.; 1999:85–103.
Boswell J B, Nienhuys T G. Reflectometric screening for otitis media: inconsistencies in a sample of Australian aboriginal children. Int J Pediatr Otorhinolaryngol. 1993;25:49-60. [pmid: 8436480].
Buhrer K, Wall L G, Schuster L. The acoustic reflectometer as a screening device: a comparison. Ear Hear. 1985;6:307-314. [pmid: 4076555].
Cantekin E I, Beery Q C, Bluestone C D. Tympanometric patterns found in middle ear effusions. Ann Otol Rhinol Laryngol Suppl. 1977;86:16-20. [pmid: 407828].
Cantekin E I, Bluestone C D, Fria T J, Stool S E, Beery Q C, Sabo D L. Identification of otitis media with effusion in children. Ann Otol Rhinol Laryngol Suppl. 1980;89:190-196. [pmid: 6778304].
Cantekin E I. Algorithm for diagnosis of otitis media with effusion. Ann Otol Rhinol Laryngol. 1983;92:6.
Carlson LH and Stool SE. Diagnosis. In: Rosenfeld RM and Bluestone CD, editors. Evidence-Based Otitis Media. Saint Louis, B.C.: Decker Inc.; 1999. p. 105–116.
Casselbrant M L, Brostoff L M, Cantekin E I, et al. Otitis media with effusion in preschool children. Laryngoscope. 1985;95:428-436. [pmid: 4039020].
Casselbrant M L, Brostoff L M, Cantekin E I, Ashoff V M, Bluestone C D. Incidence, prevalence, and natural history of otitis media in children in Pittsburgh. Ann Otol Rhinol Laryngol. 1990;99:28-29.
Chan LS, Takata GS, Shekelle P, Morton SC, Mason W, Marcy SM. Evidence assessment of management of acute otitis media: II. Research gaps and priorities for future research. Pediatrics. (In Press).
Chang S O, Jang Y J, Rhee C K. Effects of middle ear effusion on transient evoked otoacoustic emissions in children. Auris Nasus Larynx. 1998;25:243-247. [pmid: 9799989].
DerSimonian R, Laird N. Meta-analysis in clinical trial. Control Clin Trials. 1986;7:177-188. [pmid: 3802833].
Douniadakis D E, Nikolopoulos T P, Tsakanikos M D, Vassiliadis S V, Apostolopoulos N J. Evaluation of acoustic reflectometry in detecting otitis media in children. Br J Audiol. 1993;27:409-414. [pmid: 8054898].
Downs MP, Walker DD, Northern JL, Gugenheim S. Identification of Children with Language Delays Due to Recurrent Otitis Media. . Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:382–384.
Duncan R B. Malleus handle probe: a middle ear diagnostic procedure. Ann Otol Rhinol Laryngol. 1982;91:281-284. [pmid: 7092049].
Egger M, Smith G D, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. Br Med J. 1997;315:629-634. [pmid: 9310563].
Ernstson S, Sundberg L. Erythromycin in the treatment of otitis media with effusion (OME). J Laryngol Otol. 1984;98:767-769. [pmid: 6540792].
Feagans L, Sanyal M, Henderson F, Collier A, Appelbaum M. Relationship of middle ear disease in early childhood to later narrative and attention skills. J Pediatr Psychol. 1987;12:581-594. [pmid: 3430288].
Feagans L, Kipp E, Blood I. The effects of otitis media on the attention skills of day-care-attending toddlers. Dev Psychol. 1994;30:701-708.
Feldman HM, Paradise JL, Colborn DK, et al. Word production at age 2 years in relation to otitis media during the first two years of life. . Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:328.
Feldman H M, Dollaghan C A, Campbell T F, et al. Parent-reported language and communication skills at one and two years of age in relation to otitis media in the first two years of life. Pediatrics. 1999;104:e52. [pmid: 10506277].
Fields M J, Allison R S, Corwin P, White P S, Doherty J. Microtympanometry, microscopy and tympanometry in evaluating middle ear effusion prior to myringotomy. N Z Med J. 1993;106:386-387. [pmid: 8367097].
Fiellau-Nikolajsen M. Tympanometry in 3-year-old children. Type of care as an epidemiological factor in secretory otitis media and tubal dysfunction in unselected populations of 3-year-old children. ORL J Otorhinolaryngol Relat Spec. 1979;41:193-205. [pmid: 574241].
Fiellau-Nikolajsen M, Lous J. Prospective tympanometry in 3-year-old children. A study of the spontaneous course of tympanometry types in a nonselected population. Archives of Otolaryngology. 1979;105:461-466. [pmid: 464883].
Fiellau-Nikolajsen M, Lous J. Tympanometry in three-year-old children. A cohort study on the prognostic value of tympanometry and operative findings in middle ear effusion. ORL J Otorhinolaryngol Relat Spec. 1979;41:11-25. [pmid: 572953].
Fiellau-Nikolajsen M. Tympanometry and middle ear effusion: a cohort-study in three-year-old children. Int J Pediatr Otorhinolaryngol. 1980;2:39-49. [pmid: 7188053].
Fiellau-Nikolajsen M. Tympanometry in three-year-old children. Prevalence and spontaneous course of MEE. Ann Otol Rhinol Laryngol Suppl. 1980;89:223-227. [pmid: 6778312].
Fiellau-Nikolajsen M. Serial tympanometry and middle ear status in 3-year-old children. ORL J Otorhinolaryngol Relat Spec. 1980;42:220-232. [pmid: 7190666].
Fiellau-Nikolajsen M, Falbe-Hansen J, Knudstrup P. Tympanometry in three-year-old children. III. Correlation between tympanometry and findings at paracentesis in a prospectively followed population of otherwise healthy children aged 3–4 years. Scand Audiol. 1980;9:49-54. [pmid: 7444320].
Fiellau-Nikolajsen M. Tympanometry in three-year-old children. The 3-year follow-up of a cohort study. ORL J Otorhinolaryngol Relat Spec. 1981;43:89-103. [pmid: 7194464].
Fiellau-Nikolajsen M. Epidemiology of secretory otitis media. A descriptive cohort study. Ann Otol Rhinol Laryngol. 1983;92:172-177. [pmid: 6838108].
Finitzo T, Friel-Patti S, Chinn K, Brown O. Tympanometry and otoscopy prior to myringotomy: issues in diagnosis of otitis media. Int J Pediatr Otorhinolaryngol. 1992;24:101-110. [pmid: 1428589].
Fischler R S, Todd N W, Feldman C M. Otitis media and language performance in a cohort of Apache Indian children. Am J Dis Child. 1985;139:355-360. [pmid: 4038844].
Freeark K, Frank S J, Wagner A E, Lopez M, Olmsted C, Girard R. Otitis media, language development, and parental verbal stimulation. J Pediatr Psychol. 1992;17:173-185. [pmid: 1593393].
Freyss G E, Narcy P P, Manac'h Y, Toupet M G. Acoustic reflex as a predictor of middle ear effusion. Ann Otol Rhinol Laryngol Suppl. 1980;89:196-199. [pmid: 6778305].
Fria T J, Sabo D L. Auditory brainstem responses in children with otitis media with effusion. Ann Otol Rhinol Laryngol Suppl. 1980;89:200-206. [pmid: 6778307].
Fria T J, Cantekin E I, Probst G. Validation of an automatic otoadmittance middle ear analyzer. Ann Otol Rhinol Laryngol. 1980;89:253-256. [pmid: 7416672].
Fried M, Kelly J, Zubick H, Vernick D, Strome M. Acoustic reflectivity for diagnosis of middle ear effusions: Comparison with results of myringotomy. New Dimensions Otorhinolaryngol- Head Neck Surg. 1985;2:931-932.
Friel-Patti S, Finitzo-Hieber T, Conti G, Brown K C. Language delay in infants associated with middle ear disease and mild, fluctuating hearing impairment. Pediatr Infect Dis. 1982;1:104-109. [pmid: 7177899].
Gates G A, Avery C A, Prihoda T J, Cooper J C Jr. Effectiveness of adenoidectomy and tympanostomy tubes in the treatment of chronic otitis media with effusion. N Engl J Med. 1987;317:1444-1451. [pmid: 3683478].
Gates GA. Cost-effectiveness considerations in otitis media treatment. In: Lim D, Bluestone CD, Casselbrant M, Klein J, Ogra P, eds. Proceedings of the Sixth International Symposium. Fort Lauderdale, FL: B.C. Decker Inc.; 1996a:1–4.
Gates G A. Cost-effectiveness considerations in otitis media treatment. Otolaryngol Head Neck Surg. 1996b;114:525-530. [pmid: 8643261].
Gersdorff M, Scholtes JL, Yousif A, Robillard TH. Secretory otitis media, tympanometry and general anesthesia. In: Sade J, ed. Acute and secretory otitis media. Amsterdam: Kugler publications; 1986:39–44.
Gravel J S, Wallace I F. Listening and language at 4 years of age: effects of early otitis media. J Speech Hear Res. 1992;35:588-595. [pmid: 1608250].
Gravel JS, Wallace IF, Ellis MA, Lee WW, Mody M, Ruben RJ. Higher-order auditory abilities at nine years of age and early otitis media. . Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:356–358.
Gravel J S, Wallace I F. Effects of otitis media with effusion on hearing in the first 3 years of life. J Sp Lang Hear Res. 2000;43:631-644.
Grimaldi P M. The value of impedance testing in diagnosis of middle ear effusion. J Laryngol Otol. 1976;90:141-152. [pmid: 1249493].
Haapaniemi J J. Pure-tone audiometric and impedance measurements in school-aged children in Finland. Eur Arch Otorhinolaryngol. 1997;254:269-273. [pmid: 9248733].
Hall MJ, Lawrence L. Ambulatory surgery in the Unites States, 1995. Advance data from vital and health statistics; no 296. . Hyattsville (MD): National Center for Health Statistics; 1997.
Harsten G, Nettelbladt U, Schalen L, Kalm O, Prellner K. Language development in children with recurrent acute otitis media during the first three years of life. Follow-up study from birth to seven years of age. J Laryngol Otol. 1993;107:407-412. [pmid: 8326219].
Haughton P M. Validity of tympanometry for middle ear effusions. Archives of Otolaryngology. 1977;103:505-513. [pmid: 901276].
Hedges LV, Olkin I. Statistical Methods for meta-analysis. San Diego: Academic Press; 1985.
Holm-Jensen S, Sorensen C H, Tos M. Repetitive tympanometric screenings in 4-year-old children. Seasonal influence on secretory otitis and tubal dysfunction. ORL J Otorhinolaryngol Relat Spec. 1981;43:164-174. [pmid: 7194998].
Holmquist J, Al Fadala S, Qattan Y. Prevalence of secretory otitis media among school children in Kuwait. J Laryngol Otol. 1987;101:116-119. [pmid: 3572214].
Hutchings M E, Meyer S E, Moore D R. Binaural masking level differences in infants with and without otitis media with effusion. Hear Res. 1992;63:71-78. [pmid: 1464577].
Jaeschke R, Guyatt G, Sackett D L. Users' guides to the medical literature: III. How to use an article about diagnostic test: A. Are the results of study valid?. J Am Med Assoc. 1994;271:389-391.
Johnson L P, Parkin J L, Stevens M H, et al. Action of general anesthesia on middle ear effusions. Archives of Otolaryngology. 1980;106:100-102. [pmid: 7352900].
Jonathan D A. Sonotubometry: its role in childhood glue ear. Clinical Otolaryngology and Allied Sciences. 1989;14:151-154. [pmid: 2721016].
Jung T T K. Classification of otitis media and surgical principles. Otolaryngol Clin North Am. Jun. 1999;32:369-383. [pmid: 10393773].
Juni P, Witschi A, Bloch R, Egger M. The hazards of scoring the quality of clinical trials for meta-analysis. J Am Med Assoc. 1999;282:1054-1060.
Kaleida PH, Stool SE, Karabin JC. Assessment of otoscopic accuracy in diagnosis of middle-ear effusion in children (“otoscopic validation”). . Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:41.
Kaplan G J, Fleshman J K, Bender T R, Baum C, Clark P S. Long-term effects of otitis media: a ten-year cohort study of Alaskan Eskimo children. Pediatrics. 1973;52:577-85. [pmid: 4742253].
Karma P H, Penttila M A, Sipila M M, Kataja M J. Otoscopic diagnosis of middle ear effusion in acute and non-acute otitis media. I. The value of different otoscopic findings. Int J Pediatr Otorhinolaryngol. 1989;17:37-49. [pmid: 2707977].
Kemaloglu Y K, Sener T, Beder L, Bayazit Y, Goksu N. Predictive value of acoustic reflectometry (angle and reflectivity) and tympanometry. Int J Pediatr Otorhinolaryngol. 1999;48:137-142. [pmid: 10375039].
Kennedy T L, Gore L B. Middle ear effusions and the nitrous oxide myth. Laryngoscope. 1982;92:169-172. [pmid: 7162312].
Klein JO, Chase C, Teele DW, Menyuk P, Rosner BA, Group tGBOMS. Otitis media and the developoment of speech, language and cognititve abilities at seven years of age. In: Lim DJ BC, Klein JO, Nelson JD, ed. Recent advances in otitis media with effusion. Philadelphia: Decker; 1988:396–397.
Klein J O, Bluestone C D. Management of otitis media in the era of managed care. Adv Pediatr Infect Dis. 1996;12:351-386. [pmid: 9033984].
Knishkowy B, Palti H, Adler B, Tepper D. Effect of otitis media on development: a community-based study. Early Hum Dev. 1991;26:101-111. [pmid: 1743115].
Koivunen P, Alho O P, Uhari M, Niemela M, Luotonen J. Minitympanometry in detecting middle ear fluid. J Pediatr. 1997;131:419-422. [pmid: 9329419].
Kozak LJ, Hall MJ, Pokras R, Lawrence L. Ambulatory Surgery in the Unites States, 1994. Advance Data from vital and health statistics. . Hyattsville (MD): National Center for Health Statistics; 1997 Mar.
Laird N M, Mosteller F. Some statistical methods for combining experimental results. Int J Technol Assess Health Care. 1990;6:5-30. [pmid: 2361819].
Lamothe A, Boudreault V, Blanchette M, Tetreault L, Poliquin J. Serous otitis media: a six week prospective study. J Otolaryngol. 1981;10:371-379. [pmid: 7199093].
Leiberman A, Bartal N. Untreated persistent middle ear effusion. J Laryngol Otol. 1986;100:875-878. [pmid: 3746102].
Lijmer J G, Mol B W, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282:1061-1066. [pmid: 10493205].
Lous J, Fiellau-Nikolajsen M. Epidemiology and middle ear effusion and tubal dysfunction. A one-year prospective study comprising monthly tympanometry in 387 non-selected 7-year-old children. Int J Pediatr Otorhinolaryngol. 1981;3:303-317. [pmid: 6976949].
Lous J, Fiellau-Nikolajsen M. Early otitis media with effusion and reading achievement. Allgemeinmedizin. 1988;17:81-84.
Lovette S. Improved diagnosis of middle ear effusions employing the objective otoscope. Ann Otol Rhinol Laryngol. 1976;85:229-233. [pmid: 1267352].
Luloff AK, Menyk P, Teele DW. Effect of persistent otitis media on the speech sound repertoire of infants. In: Lim DJ BC, Klein JO, Nelson JK, Ogra P, ed. Recent Advances in Otitis Media: Proceedings of the Fifth International Symposium: Decker Periodicals; 1993:531–533.
Macknin M L, Skibinski C, Beck G, Hughes G, Kinney S. Acoustic reflectometry detection of middle ear effusion. Pediatr Infect Dis J. 1987;6:866-868. [pmid: 3313253].
Madell JR. Impact of otitis media on auditory function. In: Rosenfeld RM, Bluestone CD, eds. Evidence-Based Otitis Media. Saint Louis: B.C. Decker, Inc.; 1999:337–351.
Mains B T, Toner J G. Pneumatic otoscopy: study of inter-observer variability. J Laryngol Otol. 1989;103:1134-1135. [pmid: 2614229].
Mandel E M, Rockette H E, Bluestone C D, Paradise J L, Nozza R J. Myringotomy with and without tympanostomy tubes for chronic otitis media with effusion. Arch-Otolaryngol-Head-Neck-Surg. 1989;115:1217-1224. [pmid: 2789777].
Mandel E M, Rockette H E, Bluestone C D, Paradise J L, Nozza R J. Efficacy of myringotomy with and without tympanostomy tubes for chronic otitis media with effusion. Pediatr Infect Dis J. 1992;11:270-7. [pmid: 1565550].
Marchant C D, McMillan P M, Shurin P A, et al. Objective diagnosis of otitis media in early infancy by tympanometry and ipsilateral acoustic reflex thresholds. J Pediatr. 1986;109:590-595. [pmid: 3761072].
Marchisio P, Principi N, Passali D, et al. Epidemiology and treatment of otitis media with effusion in children in the first year of primary school. Acta-Otolaryngol-Stockh. 1998;118:557-562. [pmid: 9726683].
Mathew T, Nordstrom K. On the equivalence of meta-analysis using literature and using individual patient data. Biometrics. 1999;55:1221-1223. [pmid: 11315071].
Maw A R, Bawden R. Factors affecting resolution of otitis media with effusion in children. Clin-Otolaryngol. 1994;19:125-130. [pmid: 8026089].
Mills R, Vaughan-Jones R. A prospective study of otitis media with effusion in adults and children. Clin Otolaryngol Allied Sci. 1992;17:271-274. [pmid: 1505097].
Mitchell D B, Ford G R, Albert D, Waldron J. Acoustic reflectometry as an aid to the diagnosis of glue ear. Br J Clin Pract. 1990;44:557-559. [pmid: 2102142].
Mody M, Schwartz R G, Gravel J S, Ruben R J. Speech perception and verbal memory in children with and without histories of otitis media. J Speech Lang Hear Res. 1999;42:1069-1079. [pmid: 10515506].
Moher D, Pham B, Klassen T P, Schulz K F, Berlin J A, Jadad A R, Liberati A. What contributions do languages other than English make on the results of meta-analyses?. J Clinical Epi. 2000;53:964-72.
Moller H, Tos M. Point and period prevalence of otitis media with effusion evaluated by daily tympanometry. J Laryngol Otol. 1990;104:937-41. [pmid: 2280145].
Nozza R J, Bluestone C D, Kardatzke D, Bachman R. Towards the validation of aural acoustic immittance measures for diagnosis of middle ear effusion in children. Ear Hear. 1992;13:442-453. [pmid: 1487106].
Nozza R J, Bluestone C D, Kardatzke D, Bachman R. Identification of middle ear effusion by aural acoustic admittance and otoscopy. Ear Hear. 1994;15:310-323. [pmid: 7958530].
Nozza RJ. The Assessment of Hearing and Middle-Ear Function in Children. In: Bluestone CD, Stool SE, and Kenna MA, editors. Pediatric otolaryngology. Philadelphia: W.B. Saunders Company. 1996. p. 165–206.
Nozza R J, Sabo D L, Mandel E M. A role for otoacoustic emissions in screening for hearing impairment and middle ear disorders in school-age children. Ear Hear. 1997;18:227-239. [pmid: 9201458].
Orchik D J, Dunn J W, McNutt L. Tympanometry as a predictor of middle ear effusion. Arch Otolaryngol. 1978;104:4-6. [pmid: 619884].
Orchik D J, Morff R, Dunn J W. Impedance audiometry in serous otitis media. Arch Otolaryngol. 1978;104:409-412. [pmid: 666650].
Orchik D J, Morff R, Dunn J W. Middle ear status at myringotomy and its relationship to middle ear immitance measurements. Ear Hear. 1980;1:324-328. [pmid: 7192227].
Ovesen T, Paaske P B, Elbrond O. Accuracy of an automatic impedance apparatus in a population with secretory otitis media: principles in the evaluation of tympanometrical findings. Am J Otolaryngol. 1993;14:100-104. [pmid: 8484473].
Owen MJ, Johnson DL, Swank PR, Baldwin CD, Aker J, Howie VM. Duration of otitis media with effusion from birth to 3 years of age related to language and cognititve scores at 5 years. In: Lim DJ BC, Casselbrant M, Klein JO, Ogra P, ed. Recent Advances in Otitis Media: Proceedings of the Sixth International Symposium. Hamilton, Ontario: B.C. Decker Inc; 1996:329–331.
Oyiborhoro J M, Olaniyan S O, Newman C W, Balakrishnan S L. Efficacy of acoustic otoscope in detecting middle ear effusion in children. Laryngoscope. 1987;97:495-498. [pmid: 3561136].
Palmu A, Puhakka H, Rahko T, Takala A K. Diagnostic value of tympanometry in infants in clinical practice. Int J Pediatr Otorhinolaryngol. 1999;49:207-213. [pmid: 10519700].
Paradise J L, Smith C G, Bluestone C D. Tympanometric detection of middle ear effusion in infants and young children. Pediatrics. 1976;58:198-210. [pmid: 951134].
Paradise J L, Bluestone C D, Rogers K D, et al. Efficacy of adenoidectomy for recurrent otitis media in children previously treated with tympanostomy-tube placement. Results of parallel randomized and nonrandomized trials. JAMA. 1990;263:2066-73. [pmid: 2181158].
Paradise J L. Treatment guidelines for otitis media: the need for breadth and flexibility. Pediatr Infect Dis J. 1995;14:429-35. [pmid: 7638033].
Paradise JL, Smith CG, Sabo DL, et al. Tympanometric detection of middle ear effusion in the first versus the second year of life. . Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:155.
Paradise J L, Rockette H E, Colborn D K, et al. Otitis media in 2253 Pittsburgh-area infants: prevalence and risk factors during the first two years of life [see comments]. Pediatrics. 1997;99:318-333. [pmid: 9041282].
Paradise JL. Otitis media and child development: should we worry? Pediatr Infect Dis J. 1998;17:1076–1083; discussion 1099–1100.
Paradise J L, Dollaghan C A, Campbell T F, et al. Language, speech sound production, and cognition in three-year-old children in relation to otitis media in their first three years of life. Pediatrics. 2000;105:1119-1129. [pmid: 10790473].
Park IY, Kim HN, Chung MH, Park KH, Yim SB. Diagnostic Reliability of Impedance Audiometry in Case of Otitis Media with Effusion. . Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:52–54.
Patterson M, Paparella M M. Otitis media with effusion and early sequelae. Otolaryngol Clin North Am. Jun. 1999;32:391-400. [pmid: 10393775].
Paul R, Lynn T F, Lohr-Flanders M. History of middle ear involvement and speech/language development in late talkers. J Speech Hear Res. 1993;36:1055-1062. [pmid: 8246471].
Pellett F S, Cox L C, MacDonald C B. Use of acoustic reflectometry in the detection of middle ear effusion. J Am Acad Audiol. 1997;8:181-187. [pmid: 9188075].
Petinou K, Mody M, Schwartz RD, Gravel JS, Ellis MA, Lee WW. Impact of otitis media on early speech development: phonetic inventories. . Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:408–410.
Petinou K, Schwartz R G, Mody M, Gravel J S. The impact of otitis media with effusion on early phonetic inventories: A longitudinal prospective investigation. Clin Linguistics Phonetics. 1999;13:351-367.
Portoian-Shuhaiber S, Cullinan T R. Middle ear disease assessed by impedance in primary school children in south London. Lancet. 1984;1:1111-1112. [pmid: 6144838].
Poulsen G, Tos M. Screening tympanometry in newborn infants and during the first six months of life. Scand Audiol. 1978;7:159-166. [pmid: 756080].
Poulsen G, Tos M. Repetitive tympanometric screenings of two-year-old children. Scand Audiol. 1980;9:21-28. [pmid: 7192429].
Rahko T, Laitila P, Sipila M, Manninen M, Karma P. Hearing and acute otitis media in 13-year-old children. Acta Otolaryngol. 1995;115:190-192. [pmid: 7610802].
Reed D, Struve S, Maynard J E. Otitis media and hearing deficiency among Eskimo children: a cohort study. Am J Public Health Nations Health. 1967;57:1657-1662. [pmid: 6069077]. [pmcid: 1227698].
Rees G L, Freeland A P. The effect of anaesthesia on tympanograms of children undergoing grommet insertion [see comments]. Clin Otolaryngol Allied Sci. 1992;17:200-202. [pmid: 1505083].
Renvall U, Liden G, Jungert S, Nilsson E. Long-term observation of ears with reduced middle ear pressure. Acta Otolaryngol. 1978;86:104-9. [pmid: 567926].
Renvall U, Aniansson G, Liden G. Spontaneous improvement in ears with middle ear disease. Int J Pediatr Otorhinolaryngol. 1982;4:245-250. [pmid: 7118451].
Renvall U, Berg U. Reliability of tympanogram. . Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:143–146.
Reves R, Budgett R, Miller D, Wadsworth J, Haines A. Study of middle ear disease using tympanometry in general practice. Br Med J Clin Res Ed. 1985;290:1953-1956.
Roberts J E, Sanyal M A, Burchinal M R, Collier A M, Ramey C T, Henderson F W. Otitis media in early childhood and its relationship to later verbal and academic performance. Pediatrics. 1986;78:423-430. [pmid: 3748675].
Roberts JE, Burchinal MR, Koch MA, Collier AM, Henderson FW. Otitis Media in Early Childhood and Its Relationship to Later Speech and Language. . Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:385–388.
Roberts J E, Bruchinal M R, Koch M A, Footo M M, Henderson F W. Otitis media in early childhood and its relationship to later phonological development. J Speech Hear Dis. 1988;53:416-424.
Roberts J E, Burchinal M R, Collier A M, Ramey C T, Koch M A, Henderson F W. Otitis meida in early childhood and cognititive, academic, and classroom performance of the school-aged child. Pediatrics. 1989;83:477-485. [pmid: 2927985].
Roberts J E, Burchinal M R, Davis B P, Collier A M, Henderson F W. Otitis media in early childhood and later language. J Speech Hear Res. 1991;34:1158-1168. [pmid: 1749246].
Roberts D G, Johnson C E, Carlin S A, Turczyk V, Karnuta M A, Yaffee K. Resolution of middle ear effusion in newborns. Arch Pediatr Adolesc Med. 1995;149:873-877. [pmid: 7633540].
Roberts J E, Burchinal M R, Clarke-Klein S M. Otitis media in early childhood and cognitive, academic, and behavior outcomes at 12 years of age. J Pediatr Psychol. 1995;20:645-660. [pmid: 7500236].
Roberts J E, Burchinal M R, Medley L P, et al. Otitis media, hearing sensitivity, and maternal responsiveness in relation to language during infancy. J Pediatr. 1995;126:481-489. [pmid: 7869215].
Roberts JE, Zeisel S, Medley L, et al. Otitis media, hearing sensitivity, and language development to two-year-olds. . Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:325–328.
Roberts J E, Burchinal M R, Zeisel S A, et al. Otitis media, the caregiving environment, and language and cognitive outcomes at 2 years. Pediatrics. 1998;102:346-354. [pmid: 9685437].
Roberts J E, Burchinal M R, Jackson S C, et al. Otitis media in early childhood in relation to preschool language and school readiness skills among African American children. Pediatrics. 2000;106:1-11. [pmid: 10878140].
Roberts JE, Wallace IF. Language and otitis media. In: Roberts JE, Wallace IF, Henderson FW, eds. Otitis media in young children: medical, developmental and educational considerations. Baltimore (MD): Brooks; 1997:133–161.
Robinson D O, Allen D V, Root L P. Infant tympanometry: differential results by race. J Speech Hear Disord. 1988;53:341-346. [pmid: 3398485].
Rosenfeld R M, Mandel E M, Bluestone C D. Systemic steroids for otitis media with effusion in children [see comments]. Arch Otolaryngol Head Neck Surg. 1991;117:984-989. [pmid: 1832876].
Rosenfeld R M, Post J C. Meta-analysis of antibiotics for the treatment of otitis media with effusion. Otolaryngol Head Neck Surg. 1992;106:378-386. [pmid: 1533027].
Rosenfeld R M. Comprehensive management of otitis media with effusion. Otolaryngol Clin North Am. 1994;27:443-455. [pmid: 8065752].
Rosenfeld RM. Natural history of untreated otitis media. In: Rosenfeld RM, Bluestone CD, eds. Evidence-Based Otitis Media. Saint Louis: B.C. Decker Inc.; 1999a:157–177.
Rosenfeld RM. What to expect from medical therapy. In: Rosenfeld RM, Bluestone CD, eds. Evidence-Based Otitis Media. Saint Louis: B.C. Decker Inc.; 1999b:179–205.
Ruben R J, Wallace I F, Gravel J. Long-term communication deficiencies in children with otitis media during their first year of life. Acta Otolaryngol. 1997;117:206-207. [pmid: 9105449].
Ryding M, Konradsson K, Kalm O, Prellner K. Sequelae of recurrent acute otitis media. Ten-year follow-up of a prospectively studied cohort of children. Acta Paediatr. 1997;86:1208-1213. [pmid: 9401515].
Sacket D L. How to read clinical journals. V: To distinguish useful from useless or even harmful therapy. Can Med Assoc J. 1981;124:1156-1162. [pmid: 7016293]. [pmcid: 1705333].
Sassen M L, van Aarem A, Grote J J. Validity of tympanometry in the diagnosis of middle ear effusion. Clin Otolaryngol Allied Sci. 1994;19:185-189. [pmid: 7923836].
Schappert SM. Office visits for otitis media: United States, 1975-90. Advance data from vital and health statistics. . Hyattsville (MD): National Center for Health Statistics; 1992.
Schappert SM. National ambulatory medical care survey: 1994 summary. Advance data from vital and health statistics. . Hyattsville (MD): National Center for Health Statistics; 1996.
Schappert SM. Ambulatory care visits to physician offices, hospital outpatient departments, and emergency departments: United States, 1995. . Hyattsville (MD): U.S. Department of Health and Human Services; 1997.
Schwartz D M, Schwartz R H. Validity of acoustic reflectometry in detecting middle ear effusion. Pediatrics. 1987;79:739-742. [pmid: 3575031].
Shaw J O, Stark E W, Gannaway S D. The influence of nitrous oxide anaesthetic on middle-ear fluid. J Laryngol Otol. 1978;92:131-135. [pmid: 627766].
Silman S, Silverman C A, Arick D S. Acoustic-immittance screening for detection of middle-ear effusion in children. J Am Acad Audiol. 1992;3:262-268. [pmid: 1421458].
Silman S, Silverman C A, Arick D S. Pure-tone assessment and screening of children with middle-ear effusion. J Am Acad Audiol. 1994;5:173-182. [pmid: 8075413].
Silva A B, Hotaling A J. A protocol for otolaryngology-head and neck resident training in pneumatic otoscopy. Int J Pediatr Otorhinolaryngol. 1997;40:125-131. [pmid: 9225178].
Silverman C A, Silman S. Acoustic-immittance characteristics of children with middle-ear effusion: longitudinal investigation. J Am Acad Audiol. 1995;6:339-345. [pmid: 7548934].
Sly R M, Zambie M F, Fernandes D A, Frazer M. Tympanometry in kindergarten children. Annals of Allergy. 1980;44:1-7. [pmid: 7352686].
Sorri M, Maki-Torkko E, Alho O P. Otitis media and long-term follow-up of hearing. Acta Otolaryngol Stockh. 1995;109:811-816.
Sox H, Stern S, Owens D, Abrams HL. Assessment of diagnostic technology in health care: Rationale, methods, problems, and directions. . Washington, D.C.: National Academy Press; 1989.
StataCorp. Stata Statistical Software: Release 6.0. : College Station, TX: Stata Corporation; 1999.
Stewart L A, Parmar M K. Meta-analysis of the literature or of individual patient data: is there a difference?. Lancet. 1993;341:418-422. [pmid: 8094183].
Stewart L A, Clarke M J. Practical methodology of meta-analyses (overviews) using updated individual patient data. Cochrane Working Group. Stat Med. 1995;14:2057-2079. [pmid: 8552887].
Stool S E, Field M J. The impact of otitis media. Pediatr Infect Dis J. 1989;8:S11-S14. [pmid: 2494641].
Stool SE, Berg AO, Berman S, et al. Otitis media with effusion in young children. Clinical Practice Guideline, Number 12. . Rockville (MD): Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services; 1994a July.
Stool SE, Berg AO, Berman S, et al. Managing otitis media with effusion in ytoung children. Quick Reference Guide for Clinicians. . Rockville (MD): Agency for Health Care Policy and Research, Public Health Servies, U.S. Department fo Health and Human Services; 1994b July.
Szucs E, Diependaele R, Clement P A. The accuracy of tympanometry assessed by its sensitivity and specificity. Acta Otorhinolaryngol Belg. 1995;49:287-292. [pmid: 7484149].
Takahashi H, Honjo I, Hasebe S, Sudo M, Tanabe M. The diagnostic and prognostic value of eardrum mobility in otitis media with effusion. Eur Arch Otorhinolaryngol. 1999;256:189-191. [pmid: 10337509].
Takata GS, Chan LS, Shekelle P, Morton SC, Mason W, Marcy SM. Evidence assessment of management of acute otitis media: I. The role of antibiotics in treatment of uncomplicated acute otitis media. Pediatrics. (In Press).
Teele D W, Klein J O, Rosner B A. Epidemiology of otitis media in children. Ann Otol Rhinol Laryngol Suppl. 1980;89:5-6. [pmid: 6778349].
Teele D W, Klein J O, Rosner B A. Otitis media with effusion during the first three years of life and development of speech and language. Pediatrics. 1984;74:282-287. [pmid: 6540437].
Teele D W, Klein J O, Chase C, Menyuk P, Rosner B A. Otitis media in infancy and intellectual ability, school achievement, speech, and language at age 7 years. Greater Boston Otitis Media Study Group. J Infect Dis. 1990;162:685-694. [pmid: 2387994].
Thomsen J, Tos M. Spontaneous improvement of secretory otitis. A long-term study. Acta Otolaryngol. 1981;92:493-499. [pmid: 7198368].
Tom L W, Tsao F, Marsh R R, Kessler A, Konkle D F. Effect of anesthetic gas on middle ear fluid. Laryngoscope. 1994;104:832-836. [pmid: 8022245].
Toner J G, Mains B. Pneumatic otoscopy and tympanometry in the detection of middle ear effusion. Clin Otolaryngol Allied Sci. 1990;15:121-123. [pmid: 2350887].
Tos M, Poulsen G. Tympanometry in 2-year-old children. Seasonal influence on frequency of secretory otitis and tubal function. ORL J Otorhinolaryngol Relat Spec. 1979;41:1-10. [pmid: 572952].
Tos M, Poulsen G, Hancke A B. Screening tympanometry during the first year of life. Acta Otolaryngol. 1979;88:388-94. [pmid: 532614].
Tos M. Spontaneous improvement of secretory otitis and impedance screening. Arch Otolaryngol. 1980;106:345-349. [pmid: 7378020].
Tos M, Poulsen G. Screening tympanometry in infants and two-year-old children. Ann Otol Rhinol Laryngol Suppl. 1980;89:217-222. [pmid: 6778311].
Tos M, Holm-Jensen S, Sorensen C H. Changes in prevalence of secretory otitis from summer to winter in four-year-old children. Am J Otol. 1981;2:324-327. [pmid: 7196158].
Tos M, Holm-Jensen S, Sorensen C H, Mogensen C. Spontaneous course and frequency of secretory otitis in 4-year-old children. Arch-Otolaryngol. 1982;108:4-10. [pmid: 7198436].
Tos M. Epidemiology and spontaneous improvement of secretory otitis. Acta Otorhinolaryngol Belg. 1983;37:31-43. [pmid: 6684381].
Tos M. Epidemiology and natural history of secretory otitis. Am J Otol. 1984;5:459-462. [pmid: 6542752].
Tos M, Stangerup SE, Andreassen UK, Hvid G, Thomsen J, Holm-Jensen S. Natural History of Secretory Otitis Media. . Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:36–40.
Tos M, Stangerup SE, Hvid SG, Andreassen UK. Epidemiology and Natural History of Secretory Otitis. . Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:29–34.
Trout K S. How to read clinical journal: IV. To determine etiology or causation. Can Med Assoc J. 1981;124:985-990. [pmid: 7260801]. [pmcid: 1705401].
Tsushima T, Menyuk P, Teele DW. Effects of otitis media on syllable realization in the speech of children. In: Lim DJ BC, Klein JO, Nelson JD, Ogra P, ed. Recent Advances in Otitis Media: Proceedings of the Fifth International Symposium: Decker Periodicals; 1993:573–575.
Tugwell P. How to read clinical journals: III. To learn the clinical course and prognosis of disease. Can Med Assoc J. 1981;124:869-872. [pmid: 7214286]. [pmcid: 1705372].
U.S. BOTC. Statistical abstract of the United States, 1998. . Springfield (VA): National Technical Information Services; 1996.
U.S. BOTC. Statistical abstract of the United States, 1998. . Springfield (VA): National Technical Information Services; 1998.
van Balen F A, de Melker R A. Validation of a portable tympanometer for use in primary care. Int J Pediatr Otorhinolaryngol. 1994;29:219-225. [pmid: 8056505].
van Balen F A, de Melker R A, Touw-Otten F W. Double-blind randomised trial of co-amoxiclav versus placebo for persistent otitis media with effusion in general practice [see comments]. Lancet. 1996;348:713-716. [pmid: 8806290].
Vaughan-Jones R, Mills R P. The Welch Allyn Audioscope and Microtymp: their accuracy and that of pneumatic otoscopy, tympanometry and pure tone audiometry as predictors of otitis media with effusion. J Laryngol Otol. 1992;106:600-602. [pmid: 1527455].
Vernon-Feagans L, Manlove E E, Volling B L. Otitis media and the social behavior of day-care-attending children. Child Dev. 1996;67:1528-1539. [pmid: 8890498].
Vernon-Feagans L, Emanuel D, Blood I. Otitis media and day care: factors hat affect children's language. . Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media with Effusion; 1996:331–334.
Vernon-Feagans L. Impact of Otitis Media on Speech, Language, Cognition, and Behavior. In: Rosenfeld RM, Bluestone CD, eds. Evidence-Based Otitis Media. Saint Louis: B.C. Decker Inc.; 1999:353–373.
Wallace I F, Gravel J S, McCarton C M, Ruben R J. Otitis media and language development at 1 year of age. J Speech Hear Disord. 1988;53:245-251. [pmid: 3398478].
Wallace IF, Gravel JS, McCarton CM, Stapells DR, Bernstein RS, Ruben RJ. Otitis Media and Its Effect on Language in Infancy. . Proceedings of the Fourth International Symposium: Recent Advances in Otitis Media with Effusion; 1988:388–391.
Wallace I F, Gravel J S, McCarton C M, Stapells D R, Bernstein R S, Ruben R J. Otitis media, auditory sensitivity, and language outcomes at one year. Laryngoscope. 1988;98:64-70. [pmid: 3336264].
Wallace IF, Gravel JS, Ganon EC, Ruben RJ. Two-year language outcomes as a function of otitis media and parental linguistic styles. . Proceedings of the Fifth International Symposium: Recent Advances in Otitis Media with Effusion; 1992:527–530.
Wallace I F, Gravel J S, Schwartz R G, Ruben R J. Otitis media, communication style of primary caregivers, and language skills of 2 year olds: a preliminary report. J Dev Behav Pediatr. 1996;17:27-35. [pmid: 8675711].
Watters G W, Jones J E, Freeland A P. The predictive value of tympanometry in the diagnosis of middle ear effusion. Clin Otolaryngol Allied Sci. 1997;22:343-345. [pmid: 9298609].
Webster A, Bamford J M, Thyer N J, Ayles R. The psychological, educational and auditory sequelae of early, persistent secretory otitis media. J Child Psychol Psychiatry. 1989;30:529-546. [pmid: 2768356].
Wendler-Shaw PD, Menyuk P, Teele DW. Effects of otitis media in the first year of life on language production in the second year of life. In: Lim DJ BC, Klein JO, Nelson JK, Ogra P, ed. Recent Advances in Otitis Media: Proceedings of the Fifith International Syposium. Hamilton, Ontario: Decker Periodicals; 1993:534–536.
Williams R G, Haughton P M. Tympanometric diagnosis of middle ear effusions. J Laryngol Otol. 1977;91:959-962. [pmid: 591781].
Williams R L, Chalmers T C, Stange K C, Chalmers F T, Bowlin S J. Use of antibiotics in preventing recurrent acute otitis media and in treating otitis media with effusion. A meta-analytic attempt to resolve the brouhaha [published erratum appears in JAMA 1994 Feb 9;271(6):430] [see comments]. JAMA. 1993;270:1344-1351. [pmid: 8141875].
Williamson I G, Dunleavey J, Bain J, Robinson D. The natural history of otitis media with effusion--a three-year study of the incidence and prevalence of abnormal tympanograms in four South West Hampshire infant and first schools. J Laryngol Otol. 1994;108:930-934. [pmid: 7829943].
Wilmot J F, Cable H R. Persistent effusion following acute otitis media: tympanometry and pneumatic otoscopy in diagnosis. J R Coll Genl Practitioners. 1988;38:149-152.
Woodwell DA, Schappert SM. National ambulatory medical care survey: 1993 summary. Advance data from vital and health statistics. . Hyattsville (MD): National Center for Health Statistics; 1995.
Woodwell DA. National ambulatory medical care survey: 1995 summary. Advance data from vital and health statistics. . Hyattsville (MD): National Center for Health Statistics; 1997a.
Woodwell DA. National ambulatory medical care survey. Advance data from vital and health statistics. . Hyattsville (MD): National Center for Health Statistics; 1997b.
Wright P, Thompson J, McConnell KB, Sitton AB, Bess FH. Audiologic and Speech Evaluation of a Prospectively Followed Cohort of Normal Children: The Impact of Otitis Media. . Proceedings of the Third International Symposium: Recent Advances in Otitis Media with Effusion; 1984:338–341.
Wright P F, Sell S H, McConnell K B, et al. Impact of recurrent otitis media on middle ear function, hearing, and language. J Pediatr. 1988;113:581-587. [pmid: 3411407].
Zargi M, Boltezar I H. Effects of recurrent otitis media in infancy on auditory perception and speech. Am J Otolaryngol. 1992;13:366-372. [pmid: 1443393].
Zeisel S A, Roberts J E, Gunn E B, et al. Prospective surveillance for otitis media with effusion among black infants in group child care. J Pediatr. 1995;127:875-880. [pmid: 8523182].
Zielhuis G A, Rach G H, van den Broek P. The natural course of otitis media with effusion in preschool children. Eur Arch Otorhinolaryngol. 1990;247:215-221. [pmid: 2375863].