# Results

## Key question 1: What is the Natural History (Spontaneous Resolution Rate over Time without Treatment) for

- OME persisting after a discrete episode of acute otitis media,
- newly diagnosed OME of unknown duration (unilateral or bilateral),
- OME persisting for weeks or months (unilateral or bilateral),
- unilateral OME lasting 3 months or longer,
- bilateral OME lasting 3 months or longer?

### Literature Review

After initial screening of 4,879 titles or abstracts, we identified 449 articles for review. After secondary screening of the 449 articles, we identified 141 articles that fell within the scope of this question. Tertiary screening identified 38 articles on prospective cohort studies for potential abstraction. After reassessing articles included in the systematic review by Rosenfeld (1999), we included three more articles for potential abstraction. We eliminated one article on r OME following acute otitis media which was addressed in a recent evidence analysis. A total of 26 prospective cohort studies and one retrospective-prospective cohort study were identified among these 40 articles. Table 17 lists the studies and cohorts examined. Abstraction was possible from 33 of the 40 articles. Table 18 lists the studies referred to by Rosenfeld (1999) and their disposition in the present evidence-based analysis. Table 19 lists the articles excluded because relevant data could not be abstracted.

Table 17. Cohorts and Articles Relevant to Question 1 (n=40)

Cohort Identifier | Relevant Articles (ID, authors, year) | Comments
Birch | 862 Birch and Elbrønd (1984) | 0.75- to 7-year old children followed from 1/1982 to 4/1982.
Casselbrant I | 1000 Casselbrant, Brostoff, Ashoff, and Bluestone (1985) | 2- to 5-year old children followed from 9/1981 to 8/1983.
| 2929 Casselbrant, Brostoff, Ashoff, and Bluestone (1990)
Casselbrant II | 2929 Casselbrant, Brostoff, Ashoff, and Bluestone (1990) | 5- to 12-year old children followed from 9/1984 to 5/1985.
Ernston | 1202 Erston and Sundberg (1984) | Children 1- to 11-years old embedded in a controlled trial.
Fiellau-Nikolajsen I | 1237 Fiellau-Nikolajsen and Lous (1979) | Children in Hjoerring, Denmark first examined in 1976.
| 1235 Fiellau-Nikolajsen (1979)
| 1242 Fiellau-Nikolajsen (1981)
| 3051 Lous and Fiellau-Nikolajsen (1988) ^a^
Fiellau-Nikolajsen II | 1235 Fiellau-Nikolajsen (1979) | Children in Hjoerring, Denmark first examined in 1978.
| 1245 Fiellau-Nikolajsen (1983)
Fiellau-Nikolajsen III | 1777 Lous and Fiellau-Nikolajsen (1981) | Children in Hirtshals and Sindal, Denmark first examined in 1978.
Holmquist | 1494 Holmquist, Fadala, and Qattan (1987) | 7- to 9.5-year old children followed 2/1983 to 4/1983.
Lamothe | 1714 Lamothe, Boudreault, Blancette, Tetreault, and Poliquin (1981) | First graders followed over a 6 week period in 1979.
Leiberman | 1735 Leiberman and Bartal (1986) | 2- to 12-year old children who had a follow-up exam after a 2.5 year delay in ventilating tube placement.
Marchisio | 9 Marchisio, Principi, Salpietro, Boschi, Chetri, Caramia, Longhi, Reali, Meloni, DeSantis, Sacher, and Cupido (1998) | Primary school children followed for 12 weeks after the initial exam, and then a subset were randomized to a placebo group for another 8 weeks of follow-up.
Mills | 1927 Mills and Vaughan-Jone (1992) | Prospective single cohort embedded in a comparative cohort of children 1- to 14-years old who had a follow-up exam about 2 months after the initial visit.
Portoian-Shuhaiber | 2184 Portoian-Shuhaiber and Cullinan (1984) | 5- to 6-year old children followed for 10 weeks in 1979.
Renvall I | 2240 Renvall, Lidén, Jungert, and Nilsson (1978) | 10- to 11- year old children examined after a 3-year interval.
Renvall II | 2242 Renvall, Anniansson, and Lidén (1982) | 4-year old children followed over a 12 week period in 1980.
Reves | 2243 Reves, Budgett, Miller, Wadsworth, and Haines (1985) | 3- to 6-year old children followed 11/1983 to 2/1984.
Roberts | 2262 Roberts, Johnson, Carlin, Turczyk, Karnutta, and Yaffee (1995) | Newborns followed for 2 months after birth.
Robinson | 2270 Robinson, Allen, and Root (1988) | Infants followed for 6 weeks.
Sly I | 2457 Sly, Zambie, Fernandes, and Frazer (1980) | 4- to 5-year old children recruited in 2/1977.
Sly II | 2457 Sly, Zambie, Fernandes, and Frazer (1980) | 4- to 5-year old children recruited in 9/1977.
Tos I | 1486 Holm-Jensen, Sørenson, and Tos (1981) | Children born in 1975 and followed from 5/1979 to 2/1985.
| 2636 Tos (1981) ^a^
| 543 Tos, Holm-Jensen, Sørenson, and Mogensen (1982)
| 2639 Tos (1983) ^a^
| 2642 Tos (1984) ^a^
| 4834 Tos (1984) ^a^
| 4835 Tos (1988) ^a^
Tos II | 2629 Tos (1979) | Children born in 1976 and followed from 11/1977 to 2/1985.
| 2190 Poulsen and Tos (1980)
| 2631 Tos (1980) ^a^
| 2634 Tos (1980)
| 2593 Thomsen and Tos (1981)
| 2639 Tos (1983) ^a^
| 2642 Tos (1984) ^a^
| 4834 Tos (1984) ^a^
| 4835 Tos (1988) ^a^
Tos III | 2189 Poulsen and Tos (1978) | Children born in 1977 and followed from 1–2/1977 to 2/1985.
| 2627 Tos (1979)
| 2631 Tos (1980) ^a^
| 2634 Tos (1980)
| 2639 Tos (1983) ^a^
| 2642 Tos (1984) ^a^
| 4834 Tos (1984) ^a^
| 4835 Tos (1988) ^a^
Tos IV | 1946 Moller and Tos (1990) | Children checked daily for 30 days.
van Balen | 91 van Balen, De Melker, Touw-Otten (1996) | 6-month to 6-year old children followed for 3 months in the early 1990's.
Williamson | 2791 Williamson (1994) | 5- to 8-year old children followed from 1988-1989 to 1991.
Wilmot | 2795 Wilmot (1988) | 6-month to 10-year old children were followed for 12 months after developing OME after AOM.
Zielhuis | 2863 Zielhuis, Rach, and van den Broek (1990) | 2- to 4-years old children followed from 1982-1983.

a The article did not include abstractable data relevant to the specific Question 1 outcome measures.

Table 18. Disposition of Articles From Rosenfeld's Natural History Assessment

ID Number | Author | Year | Included | Excluded | Reason for Exclusion From Assessment
1000 | Casselbrant | 1985 | X
1238, 1240 | Fiellau-Nikolajsen | 1980 | | X | 1238 is a study of tympanometry as a diagnostic tool. 1240 is the same cohort as in 1245 and does not present sufficient data tracking individual cases or episodes of OME.
2242 | Renvall | 1982 | X
2593 | Thomsen | 1981 | X | | 2593 uses same cohort as 2190, 2629, 2631, 2639, 2642, 4834, and 4835.
2627 | Tos | 1979 | X
2634 | Tos | 1980 | X
543 | Tos | 1982 | X | | 543 uses same cohort as 1486, 2636, 2639, 2642, 4834, and 4835.
2791 | Williamson | 1994 | X
2863 | Zielhuis | 1990 | X
2857 | Zeisel | 1995 | | X | 2857 included 13% with purulent OME. Antibiotic administration and other interventions for either purulent or non-purulent OME. Insufficient data track individual cases or episodes of OME.
2243 | Reves | 1985 | X
91 | van Balen | 1996 | X | | Randomized controlled trial with an initial 3-month watchful waiting period of children with OME.
1777 | Lous | 1981 | X

Table 19. Question 1: Articles Excluded During Data Abstraction

ID# | Author | Year | Reason Not Included
705 | Aniansson | 1985 | Screening study over 2 years. Some retest of same subjects, but no control over treatment.
3051 | Lous | 1988 | Data not abstractable as presented. Available counts are in essential agreement with articles 1235, 1237, and 1242 apart from minor differences in number of tympanogram types, e.g. type A in Jan 1975 (629 in articles 1235, 1237, and 3051 and 631 in article 1242) and types B, C1, and C2 in Jun-July 1976 (32, 31,, and 42 respectively in articles 1235, 1242, and 3051 and 37, 28, and 40 respectively in article 1237).
2578 | Teele | 1980 | Data not abstractable; data on persistent OME after AOM are not presented and cannot be derived.
2631 | Tos | 1980 | Article does not present any new information other than the actual initial counts of tympanogram types for the 1976 and 1977 Tos cohorts utilized in the evidence tables for article 2629 and 2627.
2636 | Tos | 1981 | Data not abstractable as presented relative to the data on 3- and 6-month follow-up presented in article 1486. Individual cases of type B, C1, or C2 tympanograms cannot be tracked from 2/1979 to 11/1979 or 2/1980.
2639 | Tos | 1983 | The only relevant new information is that the authors mention that in the 1976 cohort, 50% of tympanogram type B changed to types A or C over the first 3 months of the study. However, the number with type B who presented for the 3-month follow-up exam is not given so per cent change cannot be calculated.
2642 | Tos | 1984 | Article does not present any abstractable data relevant to Q1.
4834 | Tos | 1984 | Article does not present any new data relevant to Q1.
4835 | Tos | 1988 | Article does not present any new data relevant to Q1.
2795 | Wilmot | 1988 | Article presented data on OME following AOM which was eliminated as a condition of interest because it had been studied in a recent evidence analysis.

### Findings

Evidence Table 1 presents the study characteristics, population characteristics, risk factors, and findings for the 27 cohort studies described in 34 articles that responded to this question. Table 20 presents the study quality scores for the studies included in Evidence Table 1. The quality scores (see Methods) for these studies fell at the low end of the possible range of 1(lowest) -to 6(highest). Three of the cohort studies had a score of 4, sixteen had a score of 3, seven had a score of 2, and one had a score of 1.

Table 20. Study Quality for Studies Included in Evidence Table on Natural History

ID | Author | Year | Study Quality Score^a^
862 | Birch | 1984 | 3 (1,1,1,0,0,0)
1000 | Casselbrant | 1985 | 3 (1,1,1,0,0,0)
2929 | Casselbrant | 1990 | 3 (1,1,1,0,0,0)
1202 | Ernstson | 1984 | 2 (1,0,0,1,0,0)
1235 | Fiellau-Nikolajsen | 1979 | 4 (1,1,1,0,0,1)
1237 | Fiellau-Nikolajsen | 1979 | 4 (1,1,1,0,0,1)
1242 | Fiellau-Nikolajsen | 1981 | 4 (1,1,1,0,0,1)
1245 | Fiellau-Nikolajsen | 1983 | 3 (1,1,1,0,0,0)
1486 | Holm-Jensen | 1981 | 3 (1,1,1,0,0,0)
1494 | Holmquist | 1987 | 3 (1,1,1,0,0,0)
1714 | Lamothe | 1981 | 4 (1,1,1,1,0,0)
1735 | Leiberman | 1986 | 2 (1,1,0,0,0,0)
1777 | Lous | 1981 | 3 (1,1,1,0,0,0)
9 | Marchisio | 1998 | 3 (1,1,1,0,0,0)
1927 | Mills | 1992 | 1 (1,0,0,0,0,0)
1946 | Moller | 1990 | 3 (1,1,1,0,0,0)
2184 | Portoian-Shuhaiber | 1984 | 3 (1,1,1,0,0,0)
2189 | Poulsen | 1978 | 3 (1,1,1,0,0,0)
2190 | Poulsen | 1980 | 3 (1,1,1,0,0,0)
2240 | Renvall | 1978 | 3 (1,1,1,0,0,0)
2242 | Renvall | 1952 | 4 (1,1,1,1,0,0)
2243 | Reves | 1985 | 3 (1,1,1,0,0,0)
2262 | Roberts | 1995 | 4 (1,1,1,0,1,0)
2270 | Robinson | 1988 | 1 (1,1,0,0,0,0)
2457 | Sly | 1980 | 3 (1,1,1,0,0,0)
2593 | Thomsen | 1981 | 3 (1,1,1,0,0,0)
2627 | Tos | 1979 | 3 (1,1,1,0,0,0)
2629 | Tos | 1979 | 3 (1,1,1,0,0,0)
2634 | Tos | 1980 | 3 (1,1,1,0,0,0)
543 | Tos | 1982 | 3 (1,1,1,0,0,0)
91 | van Balen | 1996 | 3 (1,1,1,0,0,0)
2791 | Williamson | 1994 | 2 (1,1,0,0,0,0)
2863 | Zielhuis | 1990 | 3 (1,1,1,0,0,0)

a The six components of study quality are: a prospective cohort study; outcome clearly defined; time point at which outcome measured clearly defined; subjects followed without any intervention; blinded assessment of outcome; and point and variability estimates provided for main outcome measures. 1 indicates presence and 0 indicates absence

Although we accepted these 27 studies for the natural history analysis, half of them (thirteen) failed to document that the subjects had received no medical or surgical treatment during the course of the study that could affect the outcome of OME. In the three studies that claimed that their subjects received no treatment, the investigators failed to document how adherence was maintained or confirmed. In studies of eleven cohorts, the authors mentioned that children received antibiotics or underwent surgical procedures that could affect OME outcome. In those studies that reported numbers of children who received treatment, the proportion was relatively small compared to the total number studied. Except in two studies, results were not stratified by treatment condition, even in those articles that reported treatments received by study subjects. Further, the majority of studies, but not all, used tympanometry as the sole diagnostic test of OME. However, the criteria for each tympanogram type in these studies are similar (Table 21). Table 21 lists the pressure and immittance parameters for tympanogram types for those studies that used tympanometry as the sole diagnostic criteria for OME.

Table 21a. Tympanogram Definitions in Natural History Cohorts Utilizing Tympanometry as the Sole Diagnostic Method

Tympanogram Type | C | | C1 | | C2
Cohort^a^ | Pressure (mmH_2_O) | immitance | Pressure (mmH_2_O) | immitance | Pressure (mmH_2_O) | immitance | Comments
Birch | ≤ -100
Fiellau-Nikolajsen I | | | -100 to -199 | >0.1^d^ | -200 to -400 | >0.1^d^
Fiellau-Nikolajsen II | | | | | | | middle-ear effusion=flat curve or <= -100 with absent middle ear reflexes
Fiellau-Nikolajsen III | ≤ -100
Holmquist | 100 to -300
Portoian-Shuhaiber | | | | | | | abnormal defined as an abnormal tympanometric curve and/or absent acoustic reflex
Tos I | | | -100 to -199 | | -200 to -350
Tos II | | | -100 to -199 | | -200 to -350
Tos III | -100 to -300 | >0.1^e^ | -100 to -199 | | -200 to -350
Tos IV AZ 7 | | | -100 to -199 | | >-200
ZS 331 | | | -100 to -199 | | >-200
Reves | < -100 | >0.3^b^
Robinson | | | | | | | types As, B, C, and Cs are failures
Sly I and II
van Balen | | | -199 to -100 | ≥ 0.2mmho^c^ | -399 to -200 | ≥ 0.2mmho^c^
Williamson | | | -100 to -199 | | -200 to -400
Zielhuis | | | -100 to -199 | ≥ 0.2ml^c^ | -200 to -399 | ≥ 0.2ml^c^

a see Table 17 for associated cohort articles

b impedance

c admittance

d relative gradient

e impedance slope

Table 21. Tympanometry Definitions in Natural History Cohorts Utilizing Tympanometry as the Sole Diagnostic Method

Tympanogram Type | A | | As | | B
Cohort^a^ | Pressure (mmH_2_O) | immitance | Pressure (mmH_2_O) | immitance | Pressure (mmH_2_O) | immitance | Comments
Birch | > -100 | | | | | < 0.25ml^c, 1^ | ^1^stapedial reflex absent and max compliance unreadable; Madsen Electronics tympanoscope, model ZS 330, 226 Hz probe tone
Fiellau-Nikolajsen I | > -100 | > 0.1 ^d^ | | | 200 to -400^1^ | ≤ 0.1^d^ | ^1^or indeterminable
Fiellau-Nikolajsen II | | | | | | | middle-ear effusion=flat curve or <= -100 with absent middle ear reflexes
Fiellau-Nikolajsen III | > -100 | | | | | multiple criteria^1^ | ^1^type B=otoadmittance < 0.20millimhos, absolute gradient < 0.04millimhos and absence of ipsilateral acoustic reflex; Grason-Stadler Middle Ear Analyzer 1722
Holmquist | 50 to -99 | | | | flat curve | | Madsen ZA 330, 226 Hz probe tone
Portoian-Shuhaiber | | | | | | | abnormal defined as an abnormal tympanometric curve and/or absent acoustic reflex; Grason-Stadler Middle-ear Analyser (Model 1722)
Tos I | 0 to -99 | | | | flat curve | | Madsen ZO 70 tympanometer, 220 Hz probe tone
Tos II | 0 to -99 | | | | flat curve | | Madsen ZO 70 tympanometer, 220 Hz probe tone
Tos III | >-100 | | | | flat curve^1^ | | ^1^<= 0.1^e^; Madsen ZO 70 impedance meter
Tos IV AZ7 | 99 to -99 | | | | flat curve without impedance minimum^1^ | | ^1^or with a measurable impedance minimum and relative gradient < 0.1; Impedance audiometer AZ 7 (Interacoustics)
ZS 331 | 99 to -99 | | | | flat training^1^ | | ^1^or compliance below 0.25ml^c^ and absent ipsilateral stapedial reflex; Impedance tympanoscope ZS 331 (Madsen Electronics)
Reves | -100 to 50 | >0.3^b^ | | | < -100 | low^b^ | tympanometer 85 AR 11 (American Electro Medics)
Robinson | -149 to +50 | >0.2ml^c^ | | | | | types As, B, C, and Cs are failures; Maico MA 610 portable impedance screener, 226 Hz probe tone
Sly I and II | | | | | flat curve^1^ | | ^1^or compliance < 0.3ml^c^ or peak compliance occurred at or below -100 mmH_2_0; Teledyne Avionics acoustic impedance meter model TA-1D
van Balen | -99 to 200 | ≥ 0.2mmho^c^ | | | ≤ -400 | < 0.2mmho^c^
Williamson | 200 to -99 | | | | flat curve | | Grayson-Stadler [sic] Earscan impedance audiometer
Zielhuis | ≥ -99 | ≥ 0.2ml^c^ | | | ≤ -400 | < 0.2ml^c^ | Grason-Stadler-model 27

a see Table 17 for associated cohort articles

b impedance

c admittance

d relative gradient

e impedance slope

Tables 22 and 23 provide OME resolution rates by ear, as reported in the majority of the studies, and by child for those studies in which data could be stratified by unit of analysis (ear vs. child), age group, and OME type respectively. For clarity, we have listed only those resolution intervals with onset at the study's inception. For clarity, when tympanometry was the diagnostic method, counts for tympanogram type B transition to A are shown when provided, while other tympanogram transitions are shown in Evidence Table 1.

Table 22a. OME Resolution by Ears on Newly Diagnosed OME of Unknown Duration, 6 month to 3 year old cohorts

| | | | Ears Resolved Interval^a^
Cohort ID | Diagnostic Method^b^ | antibiotic^c^ | surgery^c^ | <6wk | <3m | <6m | <9m | <24m | Article(s)
6-month to 3-year old cohorts
Robinson | tymp | unknown | unknown | 10 of 25^ d^ (40.0%) | | | | | 2270 Robinson 1988
| | | | | | | | | ^1^ 2634 Tos 1980;
| | | | | | | | | ^2^ 2190 Poulson 1980;
| | | | | 6/51^ 1^ | 15/59^ 2^ | 19/51^ 3^ | 9/48^ 4^ | ^3^ 2629 Tos 1979;
Tos II | tymp | unknown | yes | | (12%) | (25%) | (37%) | (19%) | ^4^ 2593 Thomsen 1981
Tos IIe^e^ | tymp | unknown | yes | | 6/51^ 1^ (12%) | 16/51^1^ (31%) | 24/51^1^ (47%) | | ^1^ 2634 Tos 1980

a interval calculated from cohort inception and not cumulative, unless otherwise noted

b oto=otoscopy, tymp=tympanometry (type B to A transition)

c Did any of the patients receive antibiotic or surgery?

d interval is minimum of 6wk so may be greater

e cumulative resolution rate

Table 22b. OME Resolution by Ears on Newly Diagnosed OME of Unknown Duration, > 3 year old cohorts

| | | | Ears Resolved Interval^a^
Cohort ID | Diagnostic Method^b^ | antibiotic^c^ | surgery^c^ | <2wk | <3wk | <1m | <6wk | <3m | <4m | <6m | <8m | <1y | <3y | Article(s)
>3-year old cohorts
Fiellau-Nikolajsen I^d^ | tymp | unknown | yes | | | 14/94^1^ (15%) | | 22/91^1^ (24%) | | 32/69^1^ (46%) | | | 33/65^2^ (51%) | ^1^1237 Fiellau-Nikolajsen 1979; ^2^1242 Fiellau-Nikolajsen 1981
Fiellau-Nikolajsen II^d^ | tymp | unknown | unknown | | | 7/64 (11%) | | 16/62 (26%) | | | | | | 1235 Fiellau-Nikolajsen 1979
Holmquist | tymp | unknown | unknown | | | | | 251/511 (49%) | | | | | | 1494 Holmquist 1987
Lamothe | pneum oto | no | no | | 24/64 (38%) | | 25/53 (47%) | | | | | | | 1714 Lamothe 1981
Lamothe^d^ | pneum oto | no | no | | 24/64 (38%) | | 38/53 (72%) | | | | | | | 1714 Lamothe 1981
Renvall I | tymp | unknown | unknown | | | | | | | | | | 282/335 (84%) | 2240 Renvall 1978
Renvall II^d^ | tymp | no | no | | | | 10/40 (25%) | 16/40 (40%) | | | | | | 2242 Renvall 1982
Sly | tymp | no | no | 1/9 (11%) | | 4/9 (44%) | 6/9 (67%) | | | | | | | 2457 Sly 1980
Sly II | tymp | no | no | 0/5 (0%) | | 0/5 (0%) | 0/5 (0%) | | | | | | | 2457 Sly 1980
Tos I | tymp | unknown | unknown | | | | | 3/92^1^ (3%); 3/87^2^ (4%) | | 14/93^1^ (15%); 14/87^2^ (16%) | | | | ^1^1486 Holm-Jensen 1981; ^2^543 Tos 1982
Tos I^d^ | tymp | unknown | unknown | | | | | 3/87^1^ (3%) | | 17/87^1^ (20%) | | | | ^1^543 Tos 1982
Williamson | tymp | unknown | yes | | | | | | 35/67 (52%) | | 52/67 (78%) | 61/67 (91%) | | 2791 Williamson 1994

a interval calculated from cohort inception and not cumulative, unless otherwise noted

b oto=otoscopy, pneum oto=pneumatic otoscopy, tymp=tympanometry (type B to A transition)

c Did any of the patients receive antibiotic or surgery?

d cumulative resolution rates

Table 22c. OME Resolution by Ears on Newly Diagnosed OME of Unknown Duration, Age not stratifiable

| | | | Ears Resolved Interval^a^
Cohort ID | Diagnostic Method^b^ | antibiotic^c^ | surgery^c^ | <1m | <2m | <3m | <4m | <5m | <6m | <3y | Article(s)
Age not stratifiable
Casselbrant I^d^ | algorithm | yes | yes | 92/137 (67%) | 109/137 (80%) | 130/137 (95%) | 134/137 (98%) | 136/137 (99%) | 137/137 (100%) | | 1000 Casselbrant 1985
Renvall I | tymp | unknown | unknown | | | | | | | 282/335 (84%) | 2240 Renvall 1978

a interval calculated from cohort inception and not cumulative, unless otherwise noted

b algorithm=algorithm based on pneumatic otoscopy, tympanometry, and acoustic reflex, tymp=tympanometry (type B to A transition)

c Did any of the patients receive antibiotic or surgery?

d cumulative resolution rate

Table 23. OME Resolution by [underlined: Child]on Newly Diagnosed OME of Unknown Duration, Age not stratifiable

| | | | Resolved interval^a^
Cohort ID | Diagnostic Method^b^ | antibiotic^c^ | surgery^c^ | <2m | <3m | Article(s)
Age not stratifiable
Mills | pnem oto, tymp | unknown | unknown | 57/192 (30%) | | 1927 Mills 1992
Reves | tymp | unknown | unknown | | 40/68 (59%) | 2243 Reves 1985
van Balen | tymp | unknown | unknown | | 223/443 (50%) | 91 van Balen 1996

a interval calculated from cohort inception unless otherwise noted

b oto=otoscopy, tymp=tympanometry (type B to A transition)

c Did any of the patients receive antibiotic or surgery?

Table 22. OME Resolution by Ears on Newly Diagnosed OME of Unknown Duration, <6-month old cohorts

| | | | Ears Resolved Interval^a^
Cohort ID | Diagnostic Method^b^ | antibiotic^c^ | surgery^c^ | <2wk | <2m | <3m | <6m | Article(s)
<6-month old cohorts
Roberts^e^ | oto | unknown | unknown | 22/24 (92%) | 24/24 (100%) | | | 2262 Roberts 1995
Tos III | Tymp | unknown | unknown | | | 1/4^d^ (25%) | 1/4 ^d^ (25%) | 2627 Tos 1979

a interval calculated from cohort inception and not cumulative, unless otherwise noted

b oto=otoscopy, tymp=tympanometry (type B to A transition)

c Did any of the patients receive antibiotic or surgery?

d interval started at 6-month follow-up

e cumulative resolution rate

Table 23. OME Resolution by [underlined: Child]on Newly Diagnosed OME of Unknown Duration, >3 year old cohorts

| | | | Resolved interval^a^
Cohort ID | Diagnostic method^b^ | antibiotic^c^ | surgery^c^ | <2wk | <1m | <6wk | <10wk | <3m | <4m | <6m | <8m | <1y | Article(s)
>3-year old cohorts
Fiellau-Nikolajsen II | tymp | unknown | unknown | | 28/81 (35%) | | | 46/80 (58%) | | 53/78 (68%) | | | 1245 Fiellau-Nikolajsen 1983
Marchisio | pneum oto, tymp | unknown | no | | | | | 325/451 (72%) | | | | | 9 Marchisio 1998
Portoian-Shuhaiber | tymp | unknown | unknown | | | | 65/130 (50%) | | | | | | 2184 Portoian-Shuhaiber 1984
Sly I | tymp | no | no | 1/7 (14%) | 3/7 (43%) | 5/7 (71%) | | | | | | | 2457 Sly 1980
Sly II | tymp | no | no | 0/3 (0%) | 0/3 (0%) | 0/3 (0%) | | | | | | | 2457 Sly 1980
Williamson | tymp | unknown | yes | | | | | | 22/50 (44%) | | 38/50 (76%) | 45/50 90%)

a interval calculated from cohort inception unless otherwise noted

b oto=otoscopy, tymp=tympanometry (type B to A transition)

c Did any of the patients receive antibiotic or surgery?

Data from a number of studies were reported in a format that made them unusable for quantitative syntheses. Ten studies were eliminated from quantitative syntheses, because they failed to stratify by age (i.e. less than and greater than 3 years old). Day-to-day variability in tympanogram types was described in a cohort of kindergarten children examined on each weekday for 30 days (Moller and Tos,1990). Ernston and Sundberg (1984) described a group of children who participated in a controlled trial of children with OME that persisted for at least 3 months; they found that 15.3 percent (11 of 72) of such children had OME resolution by five weeks followup. A study of children with OME that persisted for 3 months or more, showed 45 percent (49 of 109) OME resolution at 2.5 year followup (Leiberman and Bartal,1986). However, the investigators acknowledged that middle-ear effusion noted after such a long interval could be either persistent or recurrent. Birch and Elbrønd (1984) and Zielhuis, Rach, and van den Broek (1990) derived equations to describe the OME resolution rates they observed in their cohorts, but we were unable to abstract actual counts from these articles.

We performed two sets of meta-analyses that matched age groups, unit of analysis, outcome type, and time to resolution in three or more cohorts. All meta-analyses presented here used the ‘ear’ as the unit of analysis. Few studies considered the child or the episode as the unit of analysis and no meta-analyses were possible.

Resolution at 6-Week Followup The first set of meta-analyis contains two meta-analyses (Table 24). The meta-analyses showed that if the criteria for resolution were tympanogram type B or C transition to A or by otoscopy, 42.3 percent (95% CI: 24.1%, 60.6%) of ears with newly diagnosed OME of unknown duration in children older than 3 years had resolution by the 6-week exam. If the criteria for resolution were modified to tympanogram type B transition to A or otoscopy, the proportion of ears in children older than 3 years old with resolution at 6-week followup was 37.2 percent (95% CI: 1.8%, 72.5%). Spontaneous resolution rates were significantly different among the cohorts for both definitions. In these studies, the OME resolution rates were calculated by determining the proportion of children without OME at followup, whether or not their baseline OME had resolved and recurred at an earlier point. Thus, these are not cumulative resolution rates (Sly, Zambie, Fernandes et al., 1980; Lamothe, Boudreault, Blanchette et al., 1981).

Table 24. Meta-Analysis for <6 Weeks Resolution Rate for Newly Diagnosed OME of Unknown Duration In Children Older Than 3 Years of Age

ArticleID | Author | Criterion | Age at diagnosis | Antibiotic used? | Surgery performed? | Followup interval | Number ears resolved | Total number ears | Resoluation rate in % | Random Effects Pooled Estimate (95% CI) | Test of Heterogeity Q statistic (P-value)
2457 | Sly-1980 | B or C to A | 5yr | no | unknown | <6wk | 18 | 32 | 56.3
2457 | Sly-1980 | B or C to A | 5yr | no | unknown | <6wk | 11 | 22 | 50.0
1714 | Lamothe-1981 | Otoscopy | 6yr | no | unknown | <6wk | 25 | 53 | 47.2
| Total | | | | | | 54 | 107 | 44.9 | 42.3 (24.1, 60.6) | 7.85 (p=0.02)
ArticleID | Author | Criterion | Age at diagnosis | Antibiotic used? | Surgery performed? | Followup interval | Number ears resolved | Total number ears | Resoluation rate in % | Random Effects Pooled Estimate (95% CI) | Test of Heterogeity Q statistic (P-value)
2457 | Sly-1980 | B to A | 5yr | no | unknown | <6wk | 6 | 9 | 66.7
2457 | Sly-1980 | B to A | 5yr | no | unknown | <6wk | 0 | 5 | 0.0
1714 | Lamothe-1981 | Otoscopy | 6yr | no | unknown | <6wk | 25 | 53 | 47.2
| Total | | | | | | 31 | 67 | 46.3 | 37.2 (1.8, 72.5) | 16.4 (p<0.001)

Note: Lamothe's study used otoscopy and is included in all meta-analyses

Resolution at 3-Month Followup The second set of meta-analyses are shown in Table 25. The first two meta-analyses assessed resolution of OME by ear by the time of 3-month followup in children older than 3 years. If the criteria for resolution were tympanogram type B or C transition to A, the proportion of ears with resolution of newly diagnosed OME of unknown duration was 42.7 percent (95% CI: 29.3%, 56.1%) among children older than 3 years. If the criteria for OME resolution were tympanogram type B transition to A, then the proportion of ears with resolution was 22.5 percent (95% CI: 5.9%, 39.0%). Spontaneous resolution rates were not significantly different among the studies in either comparison, except for Tos, Holm-Jensen, Sörenson, and Mogensen (1982) which had lower resolution rates. Because Fiellau-Nikolajsen and Lous (1979), Fiellau-Nikolajsen (1979), and Renvall, Anniansson, and Lidèn (1982) terminated followup whenever a child had a type A or normal tympanogram and because Tos, Holm-Jensen, Sörenson, and Mogensen (1982) provided data for calculation of the cumulative OME resolution rate, this estimate represents a cumulative resolution rate. The last three meta-analyses in Table 25 show the derivation of the cumulative resolution rates.

Table 25. Meta-Analysis for <3 Months Cumulative Resolution Rate for Newly Diagnosed OME of Unknown Duration In Children Older Than 3 Years of Age

ArticleID | Author | Criterion | Age at diagnosis | Antibiotic used? | Surgery performed? | Followup interval | Number ears resolved | Total number ears | Resoluation rate in % | Random Effects Pooled Estimate (95% CI) | Test of Heterogeity Q statistic (P-value)
1237 | Fiellau-Nikolajsen-1979 | B or C to A | 3–4yr | unknown | unknown | <3mo | 154 | 348 | 44.3
1235 | Fiellau-Nikolajsen-1979 | B or C to A | 3–4yr | unknown | unknown | <3mo | 83 | 200 | 41.5
543 | Tos-1982 | B or C to A | 4yr | unknown | unknown | <3mo | 103 | 393 | 26.2
2242 | Renvall-1982 | otoscopy | 4yr | no | unknown | <12wk | 86 | 144 | 59.7
| Total | | | | | | 426 | 1085 | 39.3 | 42.7 (29.3,56.1) | 63.01 (p<0.001)
ArticleID | Author | Criterion | Age at diagnosis | Antibiotic used? | Surgery performed? | Followup interval | Number ears resolved | Total number ears | Resoluation rate in % | Random Effects Pooled Estimate (95% CI) | Test of Heterogeity Q statistic (P-value)
1237 | Fiellau-Nikolajsen-1979 | B to A | 3–4yr | unknown | unknown | <3mo | 22 | 91 | 24.2
1235 | Fiellau-Nikolajsen-1979 | B to A | 3–4yr | unknown | unknown | <3mo | 16 | 62 | 25.8
543 | Tos-1982 | B to A | 4yr | unknown | unknown | <3mo | 3 | 87 | 3.4
2242 | Renvall-1982 | otoscopy | 4yr | no | unknown | <12wk | 16 | 40 | 40.0
| Total | | | | | | 57 | 280 | 20.4 | 22.5 (5.9,39.0) | 44.28 (p<0.001)

Resolution Rates for Younger Age Groups Only two studies examined the resolution rates for each of the age groups of less than 6 months and 3-months to 3-years (see Tables 22 and 23). Thus, no meta-analyses for children under 3 years of age were performed.

The Role of Influencing Factors in Resolution Similarly, because very few studies assessed the role of factors that might influence resolution, no meta-analyses were performed. The results of individual studies are summarized here:

- Lamothe, Boudreault, Blanchette, and colleagues (1981) and Fiellau-Nikolajsen and Lous (1979) assessed the effects of gender and found quicker resolution among females than males.
- Fiellau-Nikolajsen (1979) noted that children who received at-home care had quicker resolution of OME than did children in daycare.
- Sly, Zambie, Fernandes, and colleagues (1980) compared OME resolution in small cohorts first studied in February with those first studied in September and found resolution to be more rapid in the February cohort.
- Lamothe, Boudreault, Blanchette, and colleagues (1981) also assessed the effect of the side of the affected ear and noted more rapid resolution in affected right ears than affected left ears.
- Portoain-Shuhaiber and Cullinan (1984) stratified by racial/ethnic origin and noted quicker resolution of OME in African children than in Indian or Caucasian children.
- Moller and Tos (1990) found that different tympanometry instruments, which they described as impedance tympanoscopy and impedance audiometry, gave different rates of OME among the same group of children.
- Zielhuis, Rach, and van den Broek (1990) found that season and age at the end of the episode had a statistically significant effect on OME resolution rates, while gender, upper respiratory tract infection, and history of AOM did not, although they presented only percentages without denominators.

### Summary

We found sufficient data only to analyze the rates of resolution of OME among children older than 3 years old. No data existed on the role of such factors as duration of OME, initial occurrence of AOM, or presence of OME in one vs. both ears. Data on the roles of gender, at-home vs. day care, race/ethnicity, time of year, age of onset, or side of ear were too limited to draw any conclusions.

## Key Question 2: What Are the Effects of Early-Life OM on Long-Term Speech and Language Development?

- Do infants and preschool children with longer-duration early-life OME as compared to those with shorter duration OME have greater delays in speech and language development (receptive or expressive) later in life?
- Is OME-associated conductive hearing loss in the first 3 years of life a risk factor for speech and language developmental delays?
- What are the risk factors that interact with the effect of OME on speech and language development in infants and preschool children?

### Literature Review

After secondary screening of the 449 articles retrieved for review, we identified 112 articles that fell within the scope of this question. Tertiary screening identified 20 studies that fulfilled the 5 criteria for analysis. (Table 26) The five criteria included the following:

Table 26. List of Cohort Studies Included for Question 2

ID# | Author | Year | Cohort
1623 | Kaplan | 1973 | Eskimo villages in the Yukon and Kuskokwim River Delta areas of Southwestern Alaska
1255 | Fischler | 1985 | Four Indian reservations in Arizona
4657 | Roberts | 1986 | Frank Porter Graham Child Development Center, Chapel Hill, NC
3118 | Roberts | 1988 | Frank Porter Graham Child Development Center, Chapel Hill, NC
4806 | Roberts | 1988 | Frank Porter Graham Child Development Center, Chapel Hill, NC
4656 | Roberts | 1989 | Frank Porter Graham Child Development Center, Chapel Hill, NC
3117 | Roberts | 1991 | Frank Porter Graham Child Development Center, Chapel Hill, NC
4319 | Roberts | 1995 | Frank Porter Graham Child Development Center, Chapel Hill, NC
1373 | Gravel | 1992 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
4728 | Gravel | 1996 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
1941 | Mody | 1999 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
2295 | Ruben | 1997 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
1219 | Feagans | 1987 | Medical and Day Care Intervention Project in Pennsylvania
2135 | Paul | 1993 | Portland Language Development Project (PLDP), Oregon
4651 | Klein | 1988 | The Greater Boston Otitis Media Study Group, MA
2583 | Teele | 1990 | The Greater Boston Otitis Media Study Group, MA
1435 | Harsten | 1993 | University Hospital of Lund, Sweden
877 | Black | 1993 | University of Maryland Medical System, Baltimore, MD
4675 | Owen | 1996 | University of Texas Medical Branch, TX
1277 | Freeark | 1992 | University-based pediatric clinic in Michigan

1) OM was diagnosed/assessed before the age of 3 years, 2) speech or language outcome was measured at or before the age of 22 years, 3) a prospective cohort study design was used, 4) OM was graded, and 5) speech or language outcome was measured beyond 3 years of age. Of the 20 studies, 17 were prospective cohort studies and three (Freeark, 1992; Fischler, 1985; Paul, 1993) were retrospective-prospective studies in which OM history was retrospectively obtained, but outcome measures were prospectively obtained. We did not exclude any studies based on their quality.

When we reviewed the studies included in the 1994 OME Guideline for inclusion in our analysis (Stool, Berg, Berman et al., 1994), we excluded six of the studies. The Friel-Patti and Finitzo (1990) study was excluded, because it was not a prospective cohort study and did not report outcomes for children over 3 years of age. The Friel-Patti (1982) study was excluded because no outcomes were measured in children over 3 years of age. The studies of Lous and Fiellau-Nikolajsen (1988) and Rach, Ziehlhuis, van Baarle, and colleagues (1991 were excluded, because the investigators did not measure OM severity before the age of 3 years. The Rach, Zielhuis, and van den Broek (1988) study was excluded, because it was not a prospective cohort study. The study by Wright, Sell, McConnell, and colleagues (1988) was excluded, because no outcomes were measured in children over 3 years of age. Finally, unlike the OME Guideline (Stool, Berg, Berman et al., 1994), we included the studies by Klein (1988) and Freeark (1992), because study quality was not one of our rejection criteria.

Table 27 lists the author, year and cohort of 22 prospective cohort studies that were excluded from our analysis because they did not report outcomes for children older than 3 years of age. These 22 studies actually included only 12 cohorts. Relevant findings for seven of these 12 cohorts were included in our assessment.

Table 27. List of Cohort Studies Not Included for Question 2 (For Reason of Not Reporting Findings Beyond 3 Years of Age)

ID# | Author | Year | Cohort
3119 | Roberts | 1995 | Frank Porter Graham Child Development Center, Chapel Hill, NC
4841 | Wallace | 1988 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
2739 | Wallace | 1988 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
2740 | Wallace | 1988 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
4842 | Wallace | 1992 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
667 | Abraham | 1996 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
4796 | Petinou | 1996 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
2742 | Wallace | 1996 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
3096 | Petinou | 1999 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
4671 | Luloff | 1993 | Longitudinal study investigating the efficacy of drug prophylaxis on otitis media in greater Boston area, MA
4673 | Tsushima | 1993 | Longitudinal study investigating the efficacy of drug prophylaxis on otitis media in greater Boston area, MA
4674 | Wendler-Shaw | 1993 | Longitudinal study investigating the efficacy of drug prophylaxis on otitis media in greater Boston area, MA
875 | Black | 1988 | Maryland Otitis Media Study Group, Baltimore
4708 | Downs | 1988 | Not specified
2719 | Vernon-Feagans | 1996 | Ongoing study of health and day-care in a semi-rural area of northeastern United States
1288 | Friel-Patti | 1982 | Parkland Memorial Hospital, Dallas, TX
4713 | Feldman | 1996 | Pittsburgh-area Child Development/Otitis Media Study Group, PA
4642 | Paradise | 2000 | Pittsburgh-area Child Development/Otitis Media Study Group, PA
2819 | Wright | 1988 | Pneumococcal vaccine study in Nashville, TN
1677 | Knishkowy | 1991 | PROD (Promotion of Growth and Development) Program, Western Jerusalem
2579 | Teele | 1984 | The Greater Boston Otitis Media Study Group, MA
4664 | Feagans | 1994 | Three day-care facilities in central Pennsylvania, PA

### Findings

Evidence Table 2 presents the study characteristics, population characteristics, risk factors, and outcome findings for the 20 cohort studies that responded to this question. Speech and language outcomes were examined in a total of 12 cohorts of children. Of these 12 cohorts, nine included children primarily from specific populations, such as a particular ethnic or racial group or a particular socioeconomic group. It is also important to reiterate that cohorts were excluded if they consisted exclusively of children with craniofacial defects, primary mucosal disorders, immunodeficiencies, or a genetic disorder. None of the studies specifically assessed children who already had speech, language, or other developmental delays. One of the studies focused specifically on persistent bilateral OM.

For the purpose of responding to this question, we defined early life otitis media as positive otitis media history prior to 3 years of age. Table 28 summarizes the definitions of positive or negative history of otitis media used in these studies and the diagnostic method for OM. The definition of positive or negative OM history varied among the studies. Some studies used percentage of visits during a specified time, some used number of visits with OM, some used days spent with effusion, while others combined various criteria.

Table 28. Definition of Early Life Positive or Negative OM History in Assessing Long-term Speech and Language Development

ID# | Author Year | Definition of Positive/Negative OM History | Definition of OM | OM Diagnosis Method
877 | Black 1993 | OM History defined by number of episodes of OM within the first year of life documented by otologic examination.; - Positive OM History: At least 2 episodes of OM within the first year. A child could receive credit for only one bout of OM within each 29-day period.; - Negative OM History: Had not experienced otitis media during first year of life | Not provided | - Based on otologic examination; - Examiner not provided
1219 | Feagans 1987 | OM History described by frequency and duration of OM from 0 to 3 years. They were treated as continuous variables for correlation with outcome. No grouping of children by positive or negative history was done.; - Frequency was calculated by counting the number of different episodes; - Duration was calculated by counting the total number of days the child had effusion during the first 36 months of life. | Not provided. | - Based on pneumatic otoscopy. Beginning 1978 tympanometry was used to corroborate the diagnosis; - OM diagnosed by two pediatricians and two nurse practitioners
1255 | Fischler 1985 | OM History defined by number of OM episodes by age 2 years and over age 2.; - The study defined three groups of children by OM history by number of episodes before and after age 2.; - For our assessment, we used groups 1 and 2 as positive OM history, i.e. (>=2 attacks by age 2) and group 3 as negative OM history (<2 attacks by age 2). | Any mention of one of the following:; - Acute suppurative OM: history of ear pain or fussiness with or without fever or ear drainage (less than 5 days), and physical evidence of redness with or without immobility, bulging, or a small perforation of the TM.; - Serous OM: history of ear fullness, popping, or hearing loss, or an asymptomatic history; and physical evidence of TM retraction and/or immobility, with or without gray or yellow color or bubbles behind the TM; - Chronic OM: history of ear drainage and perforation present for more than two weeks; and physical evidence of perforation. | - By medical record review of documented physician's clinical diagnosis.
1277 | Freeark 1992 | OM history severity defined by a) number of separate episodes of OM and b) total number of days of effusion over the first 3 years of life.; - High OM: above median of OM severity; - Low OM: below median of OM severity | Not specified | - By whom, not specified; How diagnosed, not specified. (OM history obtained from medical records).
1373 | Gravel 1992 | OM groups were defined by otoscopic histories during the first year of life.; - OM positive: when bilateral OM was detected at 30% or more of the baby's first year visits.; - OM negative: when middle ear status was rated as normal in both ears during 80% or more of the first year visits. | Not specified | - Pediatric nurse practitioners completed pneumo-otoscopic examinations during each scheduled well-baby visit
4728 | Gravel 1996 | Same as 1373 | Same as 1373 | Same as 1373
1435 | Harsten 1993 | OM groups were defined by the number of AOM episodes during the first 3 years of life.; - OM positive: developed six or more episodes of AOM during a 12-month period.; - OM negative: no AOM episodes and less than six other acute respiratory tract infections. | - AOM was defined as an acute episode of earache in a child with red bulging eardrum(s) or purulent discharge, occasionally febrile and with signs of upper respiratory tract infection. | - By otomicropscopy performed by an otolaryngologist
1623 | Kaplan 1973 | OM groups were based on age of onset of first episode of otorrhea.; - The study defined 3 groups: group 1-onset of first otorrhea episode during first year of life; group 2-onset of first otorrhea episode at 2–10 years, and group 3-no history of OM; - For our assessment, we used group 1 as positive OM history and group 3 as negative OM history. | - Used only episodes of OM with otorrhea. | - A research nurse visited the cohort children and obtained information concerning middle ear abnormality and upper respiratory tract illness and reviewed medical records for status between visits.
4651 | Klein 1988 | OM history was measured by time spent with effusion during the first 2 years of life and used a ‘window’ of 23 days to each observation of effusion, whether accompanied by signs of illness or not. It could be shortened or extended by multiple examinations.; - Group 1: time spent with effusion <32 days during first 2 years of life.; - Group 2: time spent with effusion between 33–108 days during first 2 years of life.; - Group 3: time spent with effusion >108 days. | - Criteria for effusion: otorrhea, gas-liquid levels visible on otoscopy or marked reduction of mobility. Tympanometric criterion: type B curve. | - By pediatricians using pneumatic otoscopy until age 3 and both pneumatic otoscopy and tympanometry in years 4 through 7.
1941 | Mody 1999 | OM history defined by pneumatic otoscopy findings during first year of life; - OM positive: children who had 30% or more of the 13 first-year visits with OM bilaterally; - OM negative: children who had 80% or more of the 13 first-year visits with normal middle ear findings bilaterally. | - Used a 9-item otoscopic checklist to determine “clear”, “suspicious,” or “positive” for OM | - By trained and validated pediatric nurse practitioner using a pneumatic otoscope under the supervision of a pediatric otolaryngologist.; - The PNP recorded a description of TM characteristics for each ear, using a 9-item otoscopic checklist and made the determination of “clear,” “suspicious,” or “positive” for OM.
4675 | Owen 1996 | OME history was measured by days or duration with OME durng the first 3 years of life. Middle ear status was monitored by home visits every 2 to 4 weeks, irrespective of symptoms for the first 3 years of life.; - At each visit, each ear received a diagnosis of normal or OME. If two consecutive visits showed OME, the intervening days were counted as days with OME. If one visit showed OME and the next normal status, or vice versa, half of the intervening days were counted as days with OME. OME duration was defined as the proportion time a subject spent with OME (total OME days divided by total days) in the period examined.; - Subjects who experienced 6 continuous weeks of OME in the first year of life were identified as at high risk. | - OME diagnosis was based on type B tympanogram or >= 5 acoustic reflectivity or visible purulent otorrhea without an otoscope. | - By trained technicians using automated screening tympanometers with a 26 Hz probe tone. Acoustic reflectivity was also measured using acoustic otoscope at 30% of visits.
2135 | Paul 1993 | OM history was measured by middle ear involvement defined as either the placement of myringotomy tubes or the presence of six or more ear infections treated by a physician before the second birthday by parent report.; - Positive OM: had middle ear involvement; - Negative OM: lack of such middle ear involvement | - Based on parental reporting | - Based on parental reporting
4657 | Roberts 1986 | OM history was based on total OME duration in days during first 3 years of life. Duration of each episode of unilateral and bilateral was calculated by subtracting the data of onset of OME from the resolution date. Days of total OME was analyzed both as a continuous and categorical variable.; - Group 1: days with total OME representing the lower third of the subjects; - Group 2: days with total OME representing the middle third of the subjects; - Group 3: days with total OME representing the upper third of the subjects. | - When middle ear fluid was seen or when the mobility of the tympanic membrane was markedly reduced or absent, OME was diagnosed.; - Type B tympanograms with a flat or gradually rising shape were considered indicative of OME.; - Type C tympanograms showing a maximum compliance of less than –100 mm H_2_O were considered indicative of negative middle ear pressure and of an increase likelihood of effusion | - By pediatricians and pediatric nurse practitioners based on pneumatic otoscopy. 60% of the time tympanometry was used to corroborate the OME diagnosis.
4656 | Roberts 1989 | Same as 4657 | Same as 4657 | Same as 4657
3118, 4806 | Roberts 1988 | Same as 4657 | Same as 4657 | Same as 4657
3117 | Roberts 1991 | Same as 4657 | Same as 4657 | Same as 4657
4318 | Roberts 1995 | Same as 4657 | Same as 4657 | Same as 4657
2295 | Ruben 1997 | OM history was based on the findings of pneumatic otoscopy at every scheduled and sick visit during the first year of life; - The OM – group were those who were bilaterally free of OM at 80% or more of their first year visits and had no more than one episode of OM during the first year.; - The OM+ group had bilateral OM at 30% or more of their first year visits, and had from 2 to 6 episodes during the first year. | Not specified | - Pneumatic otoscopy by a trained and validated pediatric nurse practitioner.
2583 | Teele 1990 | OM history was measured by the number of days with middle ear effusion (MEE) by age 3 years. Unless documented to be shorter, each episode of MEE lasted 29 days. | - Diagnosis of MEE required either visualization of a gas-liquid mixture through an intact tympanic memberane, otorrhea, or marked reduction in mobility of the TM to both positive and negative pressure.; - Children whose TM(s) showed reduced mobility in response to positive pressure and normal mobility to negative pressure were considered to have only subatmospheric middle ear pressure.; - The criteria for effusion using tympanometric devices included a tracing that showed no peak or a tracing that sagged below the baseline (for model 1720B) | - In private practice, three board-certified pediatricians performed 81% of all exams; in urban health center three board-certified pediatricians performed 66% of all exams.; - Each center used otoadmittance meters, initially a Grason-Stadler model 1720B. Later, for children 4–7 years, used a Grason-Stadler model 1722.; - To resolve ambiguous diagnoses, otoadmittance was used sporadically at 0–3 years of age, but frequently at 4–7 years.

The age during which the outcome was measured also varied. This age ranged from one to 3 years. The diagnostic method and the examiner also varied. Several studies based diagnosis on chart review or parents' record. A few studies used pneumatic otoscopy performed by pediatricians, otolaryngologists, or trained professionals.

The quality of the studies included in the evidence table is summarized in Table 29. Of the 20 studies, five (25 percent) received a score of six of a possible of eight points; four (20 percent) scored five points; six (30 percent) scored four points; four (20 percent) scored three points, and one (5 percent) scored two points.

Table 29. Study Quality for Studies Included in Evidence Table on Speech and Language Development

ID | Author(s) Year | Study Quality Score ^a^
877 | Black 1993 | 3 (0,0,0,0,1,1,0,1)
1219 | Feagans 1987 | 5 (1,1,1,0,0,1,0,1)
1255 | Fischler 1985 | 5 (1,1,0,0,1,1,1,0)
1277 | Freeark 1992 | 4 (1,0,0,0,0,1,1,1)
1373 | Gravel 1992 | 5 (1,1,0,0,1,1,1,0)
4728 | Gravel 1996 | 3 (0,1,0,0,0,1,1,0)
1435 | Harsten 1993 | 6 (1,1,1,0,1,1,1,0)
1623 | Kaplan 1973 | 6 (1,1,0,0,1,1,1,1)
4651 | Klein 1988 | 4 (1,0,1,0,0,1,0,1)
1941 | Mody 1999 | 4 (1,1,0,0,0,1,0,1)
4675 | Owen 1996 | 4 (1,1,0,0,0,1,0,1)
2135 | Paul 1993 | 3 (0,0,1,0,0,1,0,1)
4657 | Roberts 1986 | 6 (1,0,1,0,1,1,1,1)
4656 | Roberts 1989 | 6 (1,0,1,0,1,1,1,1)
4806 | Roberts 1988 | 4 (1,0,1,0,0,1,0,1)
3118 | Roberts 1988 | 4 (1,0,1,0,0,1,0,1)
3117 | Roberts 1991 | 2 (0,0,0,0,0,1,0,1)
4319 | Roberts 1995 | 3 (0,0,0,0,0,1,1,1)
2295 | Ruben 1997 | 5 (1,1,0,0,1,1,1,0)
2583 | Teele 1990 | 6 (1,0,1,0,1,1,1,1)

a The eight components of study quality score are: (1) study cohort clearly defined; (2) subjects assembled at a uniform time point; (3) pathway of subject entry clearly described; (4) complete follow-up achieved; (5) withdrawals/drop-outs described; (6) objective outcomes used; (7) outcome assessment blinded; and (8) extraneous factors adjusted. ‘1’ indicates presence and ‘0’ indicates absence.

Table 30 presents a summary of the key characteristics of the 20 cohort studies including the cohort, age of OM history, age at outcome measure, major outcome statistical analysis, outcome measure of interest, diagnostic procedure(s), and notes. The table is organized by the outcome measures for this key question, namely cognition, expressive language, receptive language, expressive speech, and receptive speech. Since multiple outcomes could be included in one study, a study may appear in several rows. The entries in the “Test” column should be interpreted with caution, because subtests versus global tests were not distinguished.

Table 30. Key Characteristics of the Cohort Studies for Question 2

ID# | Author Year | Cohort | Age of OM History | Age at Outcome Measure | Major Outcome statistic | Outcome Measure | Test | Notes
4675 | Owen 1996 | Texas | 0–3 years | 5 years | Correlation | Cognition | Stanford Binet
4319 | Roberts 1995 | North Carolina | 2 months- 3 years | 12 years | Correlation | Cognition | WISC-R
1623 | Kaplan 1973 | Alaska | 0–1 year | 10 years | Mean (range) | Cognition | WISC | Stratified by concurrent hearing status
877 | Black 1993 | Maryland | 8–22 months | 4–6 years | Mean (SD) | Cognition | McCarthy
1373 | Gravel 1992 | New York | 0–1 year | 4 years | Mean (SD) | Cognition | Stanford-Binet
4657 | Roberts 1986 | North Carolina | 2 months- 3 years | 3.5–6 years | Mean (SD) | Cognition | McCarthy
4656 | Roberts 1989 | North Carolina | 2 months- 3 years | 8 years | Mean (SD) | Cognition | WISC-R
4651 | Klein 1988 | Massachusetts | 0–2 years | 7 years | Multivariate | Cognition | WISC-R
2583 | Teele 1990 | Massachusetts | 0–2 years | 7 years | Multivariate | Cognition | WISC-R | Adjusted for SES and gender
3118/4806 | Roberts 1988 | North Carolina | 2 months- 3 years | 2.5–8 years | Correlation | Expressive language | Elicited language play
3117 | Roberts 1991 | North Carolina | 2 months- 3 years | 4.5–6 years | Correlation | Expressive language | CELF | Stratified by socioeconomic status
4675 | Owen 1996 | Texas | 0–3 years | 5 years | Correlation | Expressive language | Goldman-Fristoe test
1255 | Fischler 1985 | Arizona | 0–2 years | 6–8 years | Mean (SD) | Expressive language | TOLD
1373 | Gravel 1992 | New York | 0–1 year | 4 years | Mean (SD) | Expressive language | SICD-R in months
2135 | Paul 1993 | Oregon | 0–2 years | 4 years | Mean (SD) | Expressive language | MLU | Stratified by normal/late talkers
1219 | Feagans 1987 | Pennsylvania | 0–3 years | 5–7 years | Multivariate | Expressive language | MLU, Paraphrase | Reported for total group only
2583 | Teele 1990 | Massachusetts | 0–2 years | 7 years | Multivariate | Expressive language | WUG test | Mean adjusted for SES and gender
2295 | Ruben 1997 | New York | 0–1 year | 2–9 years, yearly | Percent difference | Expressive language | Unknown
1277 | Freeark 1992 | Michigan | 0–3 years | 3–4 years | Proportion | Expressive language | Verbal Scale Index | Stratified by Parent Verbal Stimulation (PVS)
4728 | Gravel 1996 | New York | 0–1 year | 9 years | Raw data not reported | Expressive language | WRAML | Only statistical testing was reported
3117 | Roberts 1991 | North Carolina | 2 months- 3 years | 4.5–6 years | Correlation | Receptive language | CELF | Stratified by socioeconomic status (SES)
3117 | Roberts 1991 | North Carolina | 2 months- 3 years | 4.5–6 years | Correlation | Receptive language | PPVT-R | Stratified by SES
4675 | Owen 1996 | Texas | 0–3 years | 5 years | Correlation | Receptive language | CAVAT
1255 | Fischler 1985 | Arizona | 0–2 years | 6–8 years | Mean (SD) | Receptive language | TOLD
877 | Black 1993 | Maryland | 8–22 months | 4–6 years | Mean (SD) | Receptive language | PPVT-R
1373 | Gravel 1992 | New York | 0–1 year | 4 years | Mean (SD) | Receptive language | SICD-R in months
2583 | Teele 1990 | Massachusetts | 0–2 years | 7 years | Multivariate | Receptive language | WUG test | Adjusted for SES and gender
2295 | Ruben 1997 | New York | 0–1 year | 2–9 years, yearly | Percent difference | Receptive language | Unknown
4728 | Gravel 1996 | New York | 0–1 year | 9 years | No raw data | Receptive language | CELF-R | Statistical significance only
3118/4806 | Roberts 1988 | North Carolina | 2 months- 3 years | 2.5–8 years | Correlation | Expressive speech | Goldman-Fristoe
2135 | Paul 1993 | Oregon | 0–2 years | 4 years | Mean (SD) | Expressive speech | Goldman-Fristoe | Stratified by normal/late talkers
2583 | Teele 1990 | Massachusetts | 0–2 years | 7 years | Multivariate | Expressive speech | Goldman-Fristoe | Adjusted for SES and gender
2295 | Ruben 1997 | New York | 0–1 year | 2–9 years, yearly | Percent difference | Expressive speech | Unknown
3118/4806 | Roberts 1988 | North Carolina | 2 months- 3 years | 2.5–8 years | Correlation | Receptive speech | Articulation tests
1941 | Mody 1999 | New York | 0–1 year | 9 years | Mean (SD) | Receptive speech | Synthetic speech syllables
1435 | Harsten 1993 | Sweden | 0–3 years | 4 years | Proportion | Receptive speech | Linguistic analysis
4728 | Gravel 1996 | New York | 0–1 year | 9 years | No raw data | Receptive speech | Pediatric Speech Intelligibility | Only statistical testing result was reported

CAVAT= Carrow Elicited Language Inventory

CELF= Clinical Evaluation of Language Functions

MLU= Mean Length of Utterance

PPVT-R= Peabody Picture Vocabulary Test-Revised

SD= Standard Deviation

SICD-R= Sequenced Inventory of Communication Development-Revised

TOLD= Test of Language Development

WISC-R= Wechsler Intelligence Scale for Children-Revised

WRAML= Wide Range Assessment of Memory and Learning

WUG= “WUG” test (Berko-Gleason)

The factor we used to determine which studies to examine further by meta-analysis was the major outcome measure, which indicates the type of statistical measured used. Whenever three or more studies reported the same outcome measure, we considered pooling the data. Based on this strategy, we conducted three possible meta-analyses to derive the pooled difference between positive and negative early-life otitis media for: expressive language development, receptive language development, and development of cognitive verbal intelligence.

Expressive Language Development Table 31 presents the findings of the three cohort studies that addressed expressive language development. All three studies measured OM history prior to 3 years of age. Although the pooled standardized mean difference showed an increase of about 14.5 percent (95% C.I.: -49.2%, 20.2%) of a standard deviation in the expressive language measure for the group of children with no early-life OM history compared with those with a positive history, this pooled estimate is not significantly different from zero. Thus, the available data do not support the hypothesis that an OM history prior to 3 years of age has an effect on expressive language development. However, the 95% confidence intervals on our pooled results do not exclude a clinically important effect size of almost 0.5, meaning no strong conclusions can be drawn. The Chi-squared test of heterogeneity showed that the standardized difference was not significantly different among the studies. However, the ages at which outcome was measured and the tests used were not uniform across the studies.

Table 31. Meta-Analysis for Expressive Language Development

ID Number | Author-Year | Cohort | Age of OM history | Age of outcome measure | Name of Test | Positive OM History | | | Negative OM History | | | Standardized Mean Difference (95% CI)
| | | | | | N | Mean | SD | N | Mean | SD
1255 | Fischler-1985 ^a^ | Arizona | 0–2yr | 6–8 yrs | TOLD | 33 | 60.0 | 20.4 | 71 | 64.8 | 28.8 | - 0.18 (-0.59, 0.23)
1373 | Gravel-1992 | New York | 0–1yr | 4yrs | SICD-R | 8 | 36.0 | 5.2 | 12 | 39.0 | 6.2 | - 0.49 (-1.40, 0.42)
2135 | Paul-1993 ^a^ | Oregon | 0–2yr | 4yrs | MLU | 8 | 57.8 | 3.8 | 13 | 54.6 | 10.7 | 0.35 (-0.54, 1.24)
Random Effects estimate | | | | | | | | | | | | -0.14 (-0.49, 0.20)
Test of standardized mean difference equals 0: z=0.82; p=0.413.
Test of heterogeneity: Chi-squared=1.77 (degrees of freedom=2); p-value=0.412.

a Retrospective-prospective studies.

OM=Otitis media

TOLD=Test of Language Development

SICD-R=Sequenced Inventory of Communication Development-Revised

MLU=Mean Length of Utterance

N=Number of subjects

SD=Standard deviation

CI=Confidence interval

Receptive Language Development Table 32 presents the findings of the four cohort studies that addressed receptive language development. All four studies measured OM history at less than 3 years of age. Although the pooled standardized mean difference showed an increase of about 10.3 percent (95% C.I.: -28.9%, 49.5%) of a standard deviation of the receptive language measure in the group of children with no early-life otitis media history, this pooled estimate is not significantly different from zero. Thus, the available data do not support the hypothesis that an OM history prior to 3 years of age has an effect on receptive language development. However, the 95% confidence intervals on our pooled results do not exclude a clinically important effect size of almost 0.5, meaning no strong conclusions can be drawn. The Chi-squared test of heterogeneity showed that the standardized mean difference was not significantly different among the studies. However, the age at which outcome was measured and the test used were not uniform across the four studies. In addition, although the racial/ethnic composition was not reported precisely, one of the studies included primarily African-American children, another primarily American Indian children, and the third primarily Caucasian children in private practice.

Table 32. Meta-Analysis for Receptive Language Development

ID Number | Author-Year | Cohort | Age of OM history | Age of outcome measure | Name of Test | Positive OM History | | | Negative OM History | | | Standardized Mean Difference (95% CI)
| | | | | | N | Mean | SD | N | Mean | SD
877 | Black-1993 | Maryland | 8–22 mos | 4–6 yrs | PPVT-R | 21 | 83 | 17 | 10 | 72 | 18 | 0.62 (-0.15, 1.39)
1255 | Fischler ^a^ -1985 | Arizona | 0–2yr | 6–8 yrs | TOLD | 33 | 67 | 28 | 71 | 73 | 32 | -0.19 (-0.61, 0.22)
1373 | Gravel-1992 | New York | 0–1yr | 4yr | SICD-R | 8 | 36 | 5 | 13 | 38 | 5 | -0.38 (-1.27, 0.51)
2579 | Teele-1990 | Boston | 0–2yr | 3yr | PPVT-R | 52 | 101 | 17 | 80 | 96 | 15 | 0.31 (-0.04, 0.67)
Random effects estimate | | | | | | | | | | | | 0.10 (-0.29, 0.49)
Test of standardized mean difference equals 0: z=0.52; p=0.606.
Test of heterogeneity: Chi-squared=6.22 (degrees of freedom=3); p=0.102.

a Retrospective-prospective study.

PPVT-R=Peabody Picture Vocabulary Test-Revised

TOLD=Test of Language Development

SICD-R=Sequenced Inventory of Communication Development-Revised

N=Number of subjects

SD=Standard deviation

CI=Confidence interval

Cognitive Verbal Intelligence Table 33 presents the findings of the three cohort studies that addressed development of cognitive verbal intelligence. All three studies examined cognitive verbal intelligence, and all measured OM history at less than 3 years of age. Although the pooled standardized mean difference showed an increase of about 23 percent (95% C.I.: -20%, 65%) of a standard deviation in the expressive language measure in the group of children with no early life OM history, this pooled estimate is not significantly different from zero. Thus, the available data do not support the hypothesis that an OM history prior to 3 years of age has an effect on the development of cognitive verbal intelligence. However, the 95% confidence intervals on our pooled results do not exclude a clinically important effect size of almost 0.5, meaning no strong conclusions can be drawn. The Chi-squared test of heterogeneity showed that the standardized mean difference was not significantly different among studies. However, the age at which outcome was measured and the test used were not uniform across the studies. Further, two of the study populations were primarily African-American. The third study population was of lower socioeconomic status.

Table 33. Meta-Analysis for Cognitive Verbal Intelligence

ID Number | Author-Year | Cohort | Age of OM history | Age of outcome measure | Name of Test | Positive OM History | | | Negative OM History | | | Standardized Mean Difference (95% CI)
| | | | | | N | Mean | SD | N | Mean | SD
877 | Black-1993 | MD | 8–22 mos | 4–6 yrs | McCarthy | 21 | 46.7 | 11.5 | 10 | 41.0 | 10.7 | 0.49 (-0.27, 1.26)
1373 | Gravel-1992 | NY | 0–1yr | 4yrs | Stanford-Binet | 9 | 88.3 | 15.9 | 13 | 84.3 | 9.4 | 0.31 (-0.55, 1.17)
4657 | Roberts-1986 | NC | 2mos-3yrs | 3.5–6yrs | McCarthy | 19 | 52.0 | 8.0 | 19 | 52.0 | 9.0 | 0.00 (-0.64, 0.64)
Random effects estimate | | | | | | | | | | | | 0.23 (-0.20, 0.65)
Test of standardized mean difference equals 0: z=1.05; p=0.292.
Test of heterogeneity: Chi-squared=0.99 (degrees of freedom=2); p=0.609.

OM=Otitis media

N=Number of subjects

SD=Standard deviation

CI=Confidence interval

### Summary

The data do not support an effect of early-life OME on language development or cognitive verbal intelligence. However, differences among the cohorts and study conditions and the wide 95% confidence intervals make it difficult to conclude that there is no effect. We found insufficient data to assess early-life OME on speech development.

## Key Question 3: What are the Effects of Early-Life OM on Long-Term Hearing?

- Do infants and preschool children with longer duration early life OME as compared to those with shorter duration OME have permanent (or sensorineural) hearing loss later in life? One specific formulation of this question is: Is OME-associated conductive hearing loss in the first 3 years of life a risk factor for permanent (or sensorineural) hearing loss later in life?
- What are the risk factors that interact with the effect of OME on hearing later in life (unilateral or bilateral) in infants and preschool children?

### Literature Review

After secondary screening of the 449 articles we retrieved for review, we identified 186 articles that fell within the scope of this question. Tertiary screening identified 12 studies that fulfilled the five criteria for analysis. The five criteria included 1) OM was diagnosed/assessed before the age of 3 years, 2) hearing outcome was measured at or before the age of 22 years, 3) a prospective cohort study design was used, 4) OM was graded, and 5) hearing outcome was measured after 3 years of age. Of the 12 cohort studies, four were excluded from further analysis. The reasons for exclusion of the four studies are presented in Table 34. Table 35 lists the eight studies included in the evidence table and considered for analysis. Table 36 lists the author, year, and cohort of 10 studies that were not included in the analysis because they failed to report findings for children over 3 years of age.

Table 34. Cohort Studies at Tertiary Screening and Reasons for Exclusion

ID# | Author-Year | Rejection Reason
2221 | Rahko-1995 | Otitis media not measured at less than 3 years of age
2762 | Webster-1989 | Case control study
4728 | Gravel-1996 | No significant difference observed but no hearing data reported
4846 | Wright-1984 | Hearing data at 3–4 years not abstractable.

Table 35. List of Cohort Studies Included for Question 3

ID# | Author-Year | Cohort
147 | Sorri-1995 | Birth cohort from Northern Finland
1255 | Fischler-1985 | Four Indian reservations in Arizona
1373 | Gravel-1992 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
1435 | Harsten-1993 | University Hospital of Lund, Sweden
1623 | Kaplan-1973 | Eskimo villages in the Yukon and Kuskokwim River Delta areas of Southwestern Alaska
2233 | Reed-1967 | Eskimo villages in the Yukon and Kuskokwim River Delta areas of Southwestern Alaska
2309 | Ryding-1997 | University Hospital of Lund, Sweden
2854 | Zargi-1992 | University of Ljubljana, Ljubljana, Slovenia

Table 36. List of Cohort Studies Excluded from Question 3 (For Reason of Not Reporting Findings Beyond 3 Years of Life)

ID# | Author-Year | Cohort
2264 | Roberts-1998 | Frank Porter Graham Child Development Center, Chapel Hill, NC
4808 | Roberts-1988 | Frank Porter Graham Child Development Center, Chapel Hill, NC
667 | Abraham-1996 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
2740 | Wallace-1988 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
4680 | Gravel-2000 | LIFE (Longitudinal Infant Follow-up and Evaluation) Program of the Rose F. Kennedy Center, Albert Einstein College of Medicine, Bronx, NY
1288 | Friel-Patti-1982 | Parkland Memorial Hospital, Dallas, TX
2819 | Wright-1988 | Pneumococcal vaccine study in Nashville, TN
1677 | Knishkowy-1991 | PROD (Promotion of Growth and Development) Program, Western Jerusalem
1544 | Hutchings-1992 | Six general practices in Oxford, England
4838 | Vernon-Feagans-1996 | Three day-care facilities in central Pennsylvania, PA

### Findings

Evidence Table 3 presents the study characteristics, population characteristics, risk factors, and findings of the eight cohort studies considered for this question.

Table 37 summarizes the definitions of positive and negative history of OM used in these studies and the diagnostic method for OM. The definitions of positive and negative OM history varied from one study to another. These variations were similar to those identified in the studies of speech and language development.

Table 37. Definition of Early Life Positive or Negative OM History in Assessing Long-term Hearing Development

ID# | Author Year | Definition of Positive/Negative OM History | Definition of OM | OM Diagnosis Method
147 | Sorri 1995 | OM history was obtained from all possible sources (health care centers, hospitals, and private surgeries). Only children with clear-cut differences in their history were considered.; - RAOM group: had >=4 recurrent episodes until the age of 2 years.; - SOM group: had been treated for a long standing (>=3 months) secretory middle ear effusion during the first two years of life.; - No OM group: had not experienced an acute otitis media episode until the age of 7 years. | Not specified | Not specified
1255 | Fischler 1985 | - OM History defined by number of OM episodes by age 2 years and over age 2.; - The study defined three groups of children by OM history by number of episodes before and after age 2.; - For our assessment, we used groups 1 and 2 as positive OM history, i.e. (>=2 attacks by age 2) and group 3 as negative OM history (<2 attacks by age 2). | Any mention of one of the following:; - Acute suppurative OM: history of ear pain or fussiness with or without fever or ear drainage (less than 5 days), and physical evidence of redness with or without immobility, bulging, or a small perforation of the TM.; - Serous OM: history of ear fullness, popping, or hearing loss, or an asymptomatic history; and physical evidence of TM retraction and/or immobility, with or without gray or yellow color or bubbles behind the TM; - Chronic OM: history of ear drainage and perforation present for more than two weeks; and physical evidence of perforation. | - By medical record review of documented physician's clinical diagnosis.
1373 | Gravel 1992 | OM groups were defined by otoscopic histories during the first year of life.; - OM positive: when bilateral OM was detected at 30% or more of the baby's first year visits.; - OM negative: when middle ear status was rated as normal in both ears during 80% or more of the first year visits. | Not specified | - Pediatric nurse practitioners completed pneumo-otoscopic examinations during each scheduled well-baby visit
1435 | Harsten 1993 | OM groups were defined by the number of AOM episodes during the first 3 years of life.; - OM positive: developed six or more episodes of AOM during a 12-month period.; - OM negative: no AOM episodes and less than six other acute respiratory tract infections. | - AOM was defined as an acute episode of earache in a child with red bulging eardrum(s) or purulent discharge, occasionally febrile and with signs of upper respiratory tract infection. | - By otomicropscopy performed by an otolaryngologist
1623 | Kaplan 1973 | OM groups were based on age of onset of first episode of otorrhea.; - The study defined 3 groups: group 1-onset of first otorrhea episode during first year of life; group 2-onset of first otorrhea episode at 2–10 years, and group 3-no history of OM; - For our assessment, we used group 1 as positive OM history and group 3 as negative OM history. | - Used only episodes of OM with otorrhea. | - A research nurse visited the cohort children and obtained information concerning middle ear abnormality and upper respiratory tract illness and reviewed medical records for status between visits.
2233 | Reed 1967 | Same study population as 1623. This article reported findings at 3–5 years. Article 1623 reported findings at 10 years of age. | Same as 1623 | Same as 1623
2309 | Ryding 1997 | OM history groups were defined by the number of recurrent AOM during the first 3 years of life.; - rAOM group: children with >=6 episodes of purulent AOM during a 12-month period.; - Healthy group: children with no AOM and <6 other RTI episodes during the study period. | - AOM was defined as an acute episode of earache in a child with red bulging eardrum(s) or purulent discharge, occasionally febrile and with signs of upper respiratory tract infection | - AOM was diagnosed by otomicropscopy, performed by an otolaryngologist.
2854 | Zargi 1992 | OM history based on parental interviews and by review of hospital charts and other medical documentation.; - Experimental group: children treated for recurrent acute unilateral or bilateral suppurative OM at 0–2 years of age.; - Control group: children who experienced <=1 episode of OM in the first 2 years of life | Not specified | Not specified

The study quality of the eight studies included in Evidence Table 3 is summarized in Table 38. Of the eight studies, 1 (12.5 percent) received a score of 6 of a possible of 8 points; 4 (50 percent) scored 5 points; 2 (25 percent) scored 4 points; and one (12 percent) scored 2 points.

Table 38. Study Quality for Studies Included in Evidence Table on Hearing

ID | Author Year | Study Quality Score^a^
147 | Sorri 1995 | 4 (0,1,0,0,1,1,0,1)
1255 | Fischler 1985 | 5 (1,1,0,0,1,1,1,0)
1373 | Gravel 1992 | 5 (1,1,0,0,1,1,0,1)
1435 | Harsten 1993 | 6 (1,1,1,0,1,1,1,0)
1623 | Kaplan 1973 | 5 (1,1,0,0,1,1,1,0)
2233 | Reed 1967 | 4 (1,1,0,0,0,1,0,1)
2309 | Ryding 1997 | 5 (0,1,1,0,0,1,1,1)
2854 | Zargi 1992 | 2 (1,0,0,0,0,1,0,0)

a The eight components of study quality score are: (1) study cohort clearly defined; (2) subjects assembled at a uniform time point; (3) pathway of subject entry clearly described; (4) complete follow-up achieved; (5) withdrawals/drop-outs described; (6) objective outcomes used; (7) outcome assessment blinded; and (8) extraneous factors adjusted. ‘1’ indicates presence and ‘0’ indicates absence.

The age at which OM history was taken, age at outcome measure, and type of outcome measure for the 8 cohort studies are displayed in Table 39. With the various combinations of age at outcome and type of outcome measure that characterized the studies, only one combination, percentage of conductive hearing loss at 6 to10 years of age, was considered sufficiently clinically similar to justify statistical pooling: four studies reported this outcome measure at this age range. Three of the four studies (Fischler 1985, Harsten 1993 and Sorri 1995) reported treatment, including oral antibiotics, myringotomy, and tympanostomy tube, for OM episodes; Kaplan (1973) did not address treatment. Sorri (1995) used 20 dB as the air-conduction threshold above which hearing loss was defined. The other three studies used 25 dB as the threshold.

Table 39. Characteristics and Outcome Measures of Cohort Studies for Question 3

ID Number | Author Year | Age at OM history | Age at outcome measure | Outcome measured in % hearing loss | Outcome measured in mean pure tone | Other outcome measure
147 | Sorri 1995 | 0–2yrs | 7yrs | >20 dB pure tone averages, type not specified | Mean air-conduction (AC) threshold, right/left ear
1255 | Fischler 1985 | 0–2yrs | 6–8yrs | >25 dB at 500Hz;
| | | | >20 dB at 1000 Hz;
| | | | >20 dB at 2000 Hz;
| | | | >25 dB at 4000 Hz;
| | | | >25 dB at 6000 Hz.
| | | | Pure tone type not specified.
1373 | Gravel 1992 | 0–1yrs | 4 yrs | | Mean pure tone averages obtained at octave frequencies from 500 through 4000 Hz at a minimum, right/left ear | Pediatric Speech Intelligibility sentence (PSI S) to competing messages (CM) ratio
1435 | Harsten 1993 | 0–3yrs | 4yrs | >=25 dB tone-audiometry at any frequency, type not specified.
1435 | Harsten 1993 | 0–3yrs | 7yrs | >=25 dB tone-audiometry at any frequency, type not specified.
1623 | Kaplan 1973 | 0–1yrs | 10yrs | >=25 dB air and bone conduction
2233 | Reed 1967 | 0–2yrs | 3–5yrs | >25 dB pure tone air averages
2309 | Ryding 1997 | 0–3yrs | 10yrs | | Median level of air conduction hearing, right/left ear
2854 | Zargi 1992 | 0–2yrs | 6–8yrs | >10 dB for air-conduction hearing loss | Sensorineural hearing loss

dB=decibel

PSI=Pediatric Speech Intelligibility

S=Primary sentence

CM=Competing messages

We conducted two meta-analyses, one including all four studies and another that excluded the Sorri 1995 studies, which used a different threshold for hearing loss from that of the other three studies. The meta-analysis findings are reported in Table 40. The pooled risk of conductive hearing loss among 346 children who had early-life OM was 22 percent (95% CI: 7% to 36%), compared with 6 percent (95% CI: 1% to 12%) among 237 children who did not have a history of early-life OM. The pooled difference in rate of hearing loss between those with an early-life OM history and those without was 11 percent (95% CI: 3% to 19%), and the pooled risk ratio was 2.6 (95% CI: 1.6 to 4.2). Thus, an early-life history of OM was significantly associated with conductive hearing loss. Neither the studies pooled for the rate difference nor the studies pooled for the risk ratio were statistically heterogeneous. Figure 1 presents the shrinkage plot and Figure 2 presents the funnel plot for the rate difference and Figure 3 and Figure 4 present similar plots for the risk ratio of hearing loss. These figures show that negative early-life OM history is more favorable in term of conductive hearing loss at age 6 to 10 years. The funnel plots for the risk difference and the risk ratio ( Figure 2 and Figure 4, respectively) showed no indication of publication bias. Neither the adjusted rank correlation tests (Begg, 1999) nor the regression asymmetry test (Egger, 1997) indicated publication bias for either statistic (p>0.99 for the risk difference; p=0.31 for the risk ratio; p=0.71 for the risk difference; p=0.28 for the risk ratio; respectively). However, these results should be interpreted with caution. Only four studies were included in the analysis. Moreover, each of these cohorts included relatively homogeneous populations of children, one from Finland, another from Sweden, one primarily of American Indian children, and another primarily of Eskimo children. The sensitivity analysis that excluded the Sorri (1995) study did not change the conclusions. However, the exclusion of the Sorri study reduced the variability of the rate difference and lowered the pooled difference in rate of conductive hearing loss between those with a positive OM history and those without from 11 percent (95% CI: 3% to 19%) to 8 percent (95% CI: 4% to 13%).

Table 40. Meta-analysis for Effects of Early Life Otitis Media on Long-term Conductive Hearing Loss^a^

Author Year | Age of OM history | Age at Hearing Testing | OM+ Sample Size | OM-Sample Size | OM+ Percent Hearing Loss | OM-Percent Hearing Loss | Rate Difference in % | 95% CI of Rate Difference in % | Risk Ratio | 95% CI of Risk Ratio
Sorri 1995 | 0–2yrs | 7yrs | 64 | 35 | 51.6 | 20.0 | 31.6 | (13.5, 49.6) | 2.6 | (1.3, 5.2)
Fischler 1985 | 0–2yrs | 6–8yrs | 96 | 70 | 9.4 | 1.4 | 7.9 | ( 1.5, 14.4) | 6.6 | (0.8, 50.6)
Harsten 1993 | 0–3yrs | 7yrs | 24 | 56 | 8.3 | 5.4 | 3.0 | (- 9.6, 15.5) | 1.6 | (0.3, 8.7)
Kaplan 1973 | 0–1yrs | 10yrs | 162 | 76 | 19.8 | 7.9 | 11.9 | ( 3.2, 20.5) | 2.5 | (1.1, 5.7)
Random effects estimates | | | 346 | 237 | 21.7 | 6.4 | 11.3 | ( 3.3, 19.3) | 2.6 | (1.6, 4.2)
Test of heterogeneity Chi-square test value | | | | | 40.3 | 10.5 | 7.3 | | 1.1
Test of heterogeneity Chi-square test p-value | | | | | <0.001 | 0.015 | 0.064 | | 0.768
The following analysis excluded article by Sorri.
Fischler 1985 | 0–2yrs | 6–8yrs | 96 | 70 | 9.4 | 1.4 | 7.9 | (1.5,14.4) | 6.6 | (0.8,50.6)
Harsten 1993 | 0–3yrs | 7yrs | 24 | 56 | 8.3 | 5.4 | 3.0 | (-9.6,15.5) | 1.6 | (0.3,8.7)
Kaplan 1973 | 0–1yrs | 10yrs | 162 | 76 | 19.8 | 7.9 | 11.9 | (3.2,20.5) | 2.5 | (1.1,5.7)
Random effects estimates | | | 282 | 202 | 13.0 | 4.2 | 8.4 | (3.6,13.2) | 2.6 | (1.3,5.2)
Test of heterogeneity Chi-square test value | | | | | 6.8 | 4.4 | 1.4 | | 1.1
Test of heterogeneity Chi-square test p-value | | | | | 0.034 | 0.114 | 0.508 | | 0.566

a Hearing Loss was at >20–25 dB threshold at any frequency with or without treatment measured at 6–10 years of age.

Sorri, Fischler and Harsten did not specify type of pure-tone test used in defining hearing loss. Kaplan used air and bone conduction.

Abbreviations: OM+: positive otitis media history; OM-: negative otitis media history; CI: confidence interval.

Figure 1. Shrinkage Plot for Rate Difference in Conductive Hearing Loss at 6-10 Years Presence of early life OM versus Absence of early life OM

Figure 2. Funnel Plot for Rate Difference in Conductive Hearing Loss at 6-10 Years Presence of early life OM versus Absence of early life OM

Figure 3. Shrinkage Plot for Relative Risk of Conductive Hearing Loss at Age 6-10 Years Positive Early Life OM versus Negative Early Life OM

Figure 4. Funnel Plot for Log Relative Risk of Conductive Hearing Loss at Age 6–10 Years Positive Early Life OM versus Negative Early Life OM

### Summary

The results support that history of early-life OME is associated with increased risk for conductive hearing loss. However, the number of studies with similar outcome measures is small. We found insufficient data to assess the early-life OM on permanent hearing loss.

## Key Question 4: Diagnostic Methods for OME

What are the sensitivity, specificity, and predictive values for alternative methods of diagnosing OME compared with one of the reference standards?

These methods include, but are not limited to:

- signs/symptoms
- non-pneumatic otoscopy
- pneumatic otoscopy, validated or non-validated examiner
- binaural micro-tympanoscopy
- portable tympanometry
- professional tympanometry
- quantitative tympanometry
- acoustic reflectometry (specify model and year)
- otoacoustic emissions
- audiometry, air or bone conduction thresholds.

### Literature Review

After secondary and tertiary screening of the 449 articles we retrieved for review, we identified 75 articles that fell within the scope of this question. When we compared our list with the 1994 OME Guideline (Stool, Berg, Berman et al., 1994), we found five studies that were included in the 1994 OME Guideline but not in our assessment. We excluded the Kaleida (1992) and the Shurin, Pelton and Finkelstein (1977) studies, because data were not abstractable. The McDermott and Giebink, Le, and colleagues (1983) and the Teele and Teele (1984) studies were excluded, because they did not address the scope of this question. The Lampe, Weir, Spier, and colleagues (1985) study was excluded, because it was a duplicate of another study. We included three studies that were rejected by the developers of the 1994 OME Guideline, because we did not reject any studies based on study quality. These were the studies by Haughton (1977), Karma (1989), and Marchart (1986).

Of the 75 articles accepted for data abstraction, we included 52 studies in our assessment (listed in Table 41). Table 42 lists the reasons for exclusion of the 23 remaining articles. Evidence Table 4 presents the study characteristics, the characteristics of the study population, and the study findings of each of the 52 studies included.

Table 41. List of Cohort Studies Included for Question 4

ID Number | Author, Year
759 | Avery 1986
766 | Babonis 1991
784 | Barnett 1998
810 | Beery 1975
817 | Ben-David 1981
886 | Block 1998
888 | Bluestone 1973
889 | Bluestone 1979
989 | Cantekin 1977
990 | Cantekin 1980
1238 | Fiellau-Nikolajsen 1980
1241 | Fiellau-Nikolajsen 1980
1245 | Fiellau-Nikolajsen 1983
1250 | Finitzo 1992
1280 | Freyss 1980
1282 | Fria 1980
4879 | Fried 1985
4878 | Gersdorff 1986
1384 | Grimaldi 1976
1397 | Haapaniemi 1997
1446 | Haughton 1977
3022 | Johnson 1980
1600 | Jonathan 1989
1632 | Karma 1989
1646 | Kemaloglu 1999
1650 | Kennedy 1982
1685 | Koivunen 1997
1785 | Lovette 1976
1804 | Macknin 1987
1817 | Mains 1989
1837 | Marchant 1986
1936 | Mitchell 1990
2012 | Nozza 1992
2013 | Nozza 1994
2048 | Orchik 1978
2049 | Orchik 1978
2050 | Orchik 1980
2055 | Ovesen 1993
2058 | Oyiborhoro 1987
2118 | Paradise 1976
4790 | Paradise 1996
4793 | Park 1988
2236 | Rees 1992
4804 | Renvall 1996
2344 | Sassen 1994
2412 | Shaw 1978
2545 | Szucs 1995
2601 | Tom 1994
2607 | Toner 1990
2675 | van Balen 1994
2713 | Vaughan-Jones 1992
2758 | Watters 1997

Table 42. Reason for Exclusion of Diagnostic Studies After Full-Length Article Review

ID Number | Author(s) Year | Rejection Reason
2877 | Alho 1998 | Data not abstractable
694 | Amedee 1995 | Diagnostic procedure and gold standard greater than 24 hours apart.
887 | Block 1999 | Not addressing OME
912 | Boswell 1993 | No gold standard
968 | Buhrer 1985 | No gold standard
1015 | Chang 1998 | Not a diagnostic study
1149 | Douniadakis 1993 | No gold standard
1167 | Duncan 1982 | Diagnostic procedure and gold standard greater than 24 hours apart.
1233 | Fields 1993 | Diagnostic procedure and gold standard greater than 24 hours apart.
1236 | Fiellau-Nikolajsen 1979 | Diagnostic procedure and gold standard greater than 24 hours apart.
1239 | Fiellau-Nikolajsen 1980 | Diagnostic procedure and gold standard greater than 24 hours apart.
1281 | Fria 1980 | Procedure not in scope
4749 | Kaleida 1992 | Data not abstractable
2014 | Nozza 1997 | Not all referrals had gold standard
2070 | Palmu 1999 | Only 42/242 ears had myringotomy
2145 | Pellett 1997 | No gold standard
2385 | Schwartz 1987 | No gold standard
2434 | Silman 1992 | No gold standard
2435 | Silman 1994 | No gold standard
2438 | Silva 1997 | Data not abstractable
2442 | Silverman 1995 | No gold standard
2556 | Takahashi 1999 | Data not abstractable
2786 | Williams 1977 | Diagnostic procedure and gold standard greater than 24 hours apart.

Of the 52 studies, 33 (63 percent) scored three points or fewer on our six-point quality scale. Of the 19 studies that scored more than three points, 15 studies scored four points, three studies scored five points, and one study scored six points. Most of the studies in this group are of poor quality, a finding that replicates those of Lijmer, Mol, Heisterkamp and colleagues (Lijmer, Mol, Heisterkamp et al., 1999).

### Findings

Evidence Table 4 presents the sensitivity, specificity, positive predictive value, negative predictive value, accuracy, and prevalence of OME in the cohort for each comparison of diagnostic methods and reference standards listed within the scope of this assessment.

Table 43 summarizes the number of comparisons for each diagnostic method and reference standard pair. On the basis of these numbers we selected groups of three or more studies for meta-analysis, from which we derived pooled random effect estimate, 95% confidence intervals, and measure of heterogeneity for sensitivity, specificity, positive predictive value, negative predictive value, accuracy, and prevalence.

Table 43. Number of Articles by Diagnostic Method and Reference Standard

Diagnostic Method | Reference Standard
| Myringotomy | Tympanocentesis | Validated pneumatic otoscopy | Total
Acoustic reflectometry | 6 | 1 | 3 | 10
Audiometry-air and bone conduction thresholds | 2 | | | 2
Audiometry-air conduction threshold | 4 | 1 | | 5
Binaural micro-tympanoscopy | 2 | | | 2
Non-pneumatic otoscopy | 4 | | | 4
Pneumatic otoscopy-examiner validation not specified | 3 | | | 3
Pneumatic otoscopy-unvalidated examiner | 9 | | | 9
Pneumatic otoscopy-validated examiner | 1 | | | 1
Portable tympanometer | 8 | | | 8
Professional tympanometry | 35 | 6 | 6 | 47
Quantitative tympanometry | 4 | | | 4
Signs/symptoms | 2 | | | 2
Total | 80 | 8 | 9 | 97

Note: A record can be counted more than once within a cell (i.e. controlling for intervention group.)

Tables 44 through 52 present the results of the meta-analyses that compare sensitivity, specificity, and prevalence rate for acoustic reflectometry at <=5 or >5 RU (reflective units), pneumatic otoscopy, portable tympanometry, professional tympanometry using acoustic reflex at 500 or 1000 Hz, professional tympanometry using static compensated acoustic admittance at 0.1, professional tympanometry using static compensated acoustic admittance at 0.2, professional tympanometry using static compensated acoustic admittance at 0.3, professional tympanometry using B curve as abnormal, and professional tympanometry using B or C2 curves as abnormal, respectively, using myringotomy as the reference standard. Findings excluding duplicates are summarized in Table 53. The receiver-operator characteristic points that correspond to sensitivity versus (1-specificity) are plotted in Figure 5. The receiver operator characteristic points showed that pneumatic otoscopy was closest to the optimal operating point where both sensitivity and specificity would be 100 percent.

Table 45. Pneumatic Otoscopy versus Myringotomy

| | | | | Random Effect Estimate | | Test of Heterogeneity
Measure | Author-Year | X | N | % | % | 95% CI | Q | P-Value
Sensitivity | Paradise-1976 | 136 | 138 | 98.6
| Cantekin-1977 | 213 | 230 | 92.6
| Bluestone-1979 | 242 | 256 | 94.5
| Karma-1989 | 726 | 753 | 96.4
| Mains-1989 | 102 | 116 | 87.9
| Toner-1990 | 108 | 124 | 87.1
| Finitzo-1992 | 107 | 115 | 93.0
| Total | 1634 | 1732 | 94.3 | 93.8 | (91.4, 96.3) | 28.8 | <0.001
Specificity | Paradise-1976 | 56 | 75 | 74.7
| Cantekin-1977 | 113 | 140 | 80.7
| Bluestone-1979 | 131 | 169 | 77.5
| Karma-1989 | 277 | 339 | 81.7
| Mains-1989 | 84 | 93 | 90.3
| Toner-1990 | 87 | 98 | 88.8
| Finitzo-1992 | 28 | 48 | 58.3
| Total | 776 | 962 | 80.7 | 80.5 | (75.1, 86.0) | 27.2 | <0.001
Prevalence | Paradise-1976 | 138 | 213 | 64.8
| Cantekin-1977 | 230 | 370 | 62.2
| Bluestone-1979 | 256 | 425 | 60.2
| Karma-1989 | 753 | 1092 | 69.0
| Mains-1989 | 116 | 209 | 55.5
| Toner-1990 | 124 | 222 | 55.9
| Finitzo-1992 | 115 | 163 | 70.6
| Total | 1732 | 2694 | 64.3 | 62.8 | (58.3, 67.2) | 30.7 | <0.001

Table 46. Portable Tympanometry (Mixed Criteria) versus Myringotomy

| | | | | Random Effect Estimate | | Test of Heterogeneity
Measure | Author-Year | X | N | % | % | 95% CI | Q | P-Value
Sensitivity | Orchik-1978 | 21 | 39 | 53.8
| Babonis-1991 | 92 | 118 | 78.0
| Rees-1992 | 260 | 260 | 100.0
| Vaughan-Jones-1992 | 120 | 135 | 88.9
| van Balen-1994 | 147 | 156 | 94.2
| Koivunen-1997 | 52 | 66 | 78.8
| Total | 692 | 774 | 89.4 | 84.5 | (76.0, 93.1) | 39.6 | <0.001
Specificity | Orchik-1978 | 35 | 37 | 94.6
| Babonis-1991 | 84 | 102 | 82.4
| Rees-1992 | 9 | 50 | 18.0
| Vaughan-Jones-1992 | 41 | 65 | 63.1
| van Balen-1994 | 37 | 77 | 48.1
| Koivunen-1997 | 137 | 175 | 78.3
| Total | 343 | 506 | 67.8 | 64.4 | (44.3, 84.4) | 167.1 | <0.001
Prevalence | Orchik-1978 | 39 | 76 | 51.3
| Babonis-1991 | 118 | 220 | 53.6
| Rees-1992 | 260 | 310 | 83.9
| Vaughan-Jones-1992 | 135 | 200 | 67.5
| van Balen-1994 | 156 | 233 | 67.0
| Koivunen-1997 | 66 | 241 | 27.4
| Total | 774 | 1280 | 60.5 | 58.5 | (40.3, 76.7) | 268.9 | <0.001

Table 47. Professional Tympanometry (Acoustic Reflex at 500 or 1000 Hz) versus Myringotomy

| | | | | Random Effect Estimate | | Test of Heterogeneity
Measure | Author-Year | X | N | % | % | 95% CI | Q | P-Value
Sensitivity | Orchik-1978 | 35 | 39 | 89.7
| Orchik-1980 | 34 | 39 | 87.2
| Nozza-1992 | 71 | 81 | 87.7
| Nozza-1994 | 106 | 124 | 85.5
| Total | 246 | 283 | 86.9 | 87.1 | (83.2, 91.0) | 0.6 | 0.901
Specificity | Orchik-1978 | 29 | 37 | 78.4
| Orchik-1980 | 26 | 37 | 70.3
| Nozza-1992 | 26 | 30 | 86.7
| Nozza-1994 | 61 | 94 | 64.9
| Total | 142 | 198 | 71.7 | 74.8 | (64.6, 85.0) | 8.2 | 0.041
Prevalence | Orchik-1978 | 39 | 76 | 51.3
| Orchik-1980 | 39 | 76 | 51.3
| Nozza-1992 | 81 | 111 | 73.0
| Nozza-1994 | 124 | 218 | 56.9
| Total | 283 | 481 | 58.8 | 58.6 | (48.5, 68.6) | 14.9 | 0.002

Table 48. Professional Tympanometry (Static Compensated Acoustic Admittance at 0.1) versus Myringotomy

| | | | | Random Effect Estimate | | Test of Heterogeneity
Measure | Author-Year | X | N | % | % | 95% CI | Q | P-Value
(A) Including both Nozza articles
Sensitivity | Fiellau-Nikolajsen-1980 | 9 | 46 | 19.6
| Nozza-1992 | 25 | 81 | 30.9
| Nozza-1994 | 37 | 137 | 27.0
| Barnett-1998 | 95 | 175 | 54.3
| Total | 166 | 439 | 37.8 | 33.2 | (17.5, 48.9) | 38.1 | <0.001
Specificity | Fiellau-Nikolajsen-1980 | 42 | 42 | 100.0
| Nozza-1992 | 29 | 30 | 96.7
| Nozza-1994 | 109 | 112 | 97.3
| Barnett-1998 | 104 | 124 | 83.9
| Total | 284 | 308 | 92.2 | 95.0 | (88.5, 100) | 13.9 | 0.003
Prevalence | Fiellau-Nikolajsen-1980 | 46 | 88 | 52.3
| Nozza-1992 | 81 | 111 | 73.0
| Nozza-1994 | 137 | 249 | 55.0
| Barnett-1998 | 175 | 299 | 58.5
| Total | 439 | 747 | 58.8 | 59.7 | (51.8, 67.7) | 14.2 | 0.003
(B) Excluding Nozza-1992 study
Sensitivity | Fiellau-Nikolajsen-1980 | 9 | 46 | 19.6
| Nozza-1994 | 37 | 137 | 27.0
| Barnett-1998 | 95 | 175 | 54.3
| Total | 141 | 358 | 39.4 | 33.9 | (12.7, 55.0) | 36.9 | <0.001
Specificity | Fiellau-Nikolajsen-1980 | 42 | 42 | 100.0
| Nozza-1994 | 109 | 112 | 97.3
| Barnett-1998 | 104 | 124 | 83.9
| Total | 255 | 278 | 91.7 | 94.1 | (83.9, 100) | 13.7 | 0.001
Prevalence | Fiellau-Nikolajsen-1980 | 46 | 88 | 52.3
| Nozza-1994 | 137 | 249 | 55.0
| Barnett-1998 | 175 | 299 | 58.5
| Total | 358 | 636 | 56.3 | 56.3 | (52.5, 60.2) | 1.4 | 0.510

Table 49. Professional Tympanometry (Static Compensated Acoustic Admittance at 0.2) versus Myringotomy

| | | | | Random Effect Estimate | | Test of Heterogeneity
Measure | Author-Year | X | N | % | % | 95% CI | Q | P-Value
(A) Including Both Nozza Studies
Sensitivity | Fiellau-Nikolajsen-1980 | 21 | 46 | 45.7
| Nozza-1992 | 74 | 81 | 91.4
| Nozza-1994 | 63 | 137 | 46.0
| Barnett-1998 | 110 | 175 | 62.9
| Total | 268 | 439 | 61.0 | 61.8 | (39.0, 84.7) | 93.4 | <0.001
Specificity | Fiellau-Nikolajsen-1980 | 40 | 42 | 95.2
| Nozza-1992 | 21 | 30 | 70.0
| Nozza-1994 | 103 | 112 | 92.0
| Barnett-1998 | 93 | 124 | 75.0
| Total | 257 | 308 | 83.4 | 84.5 | (74.0. 95.0) | 23.0 | <0.001
Prevalence | Fiellau-Nikolajsen-1980 | 46 | 88 | 52.3
| Nozza-1992 | 81 | 111 | 73.0
| Nozza-1994 | 137 | 249 | 55.0
| Barnett-1998 | 175 | 299 | 58.5
| Total | 439 | 747 | 58.8 | 59.7 | (51.8, 67.7) | 14.2 | 0.003
(B) Excluding Nozza-1992 Study
Sensitivity | Fiellau-Nikolajsen-1980 | 21 | 46 | 45.7
| Nozza-1994 | 63 | 137 | 46.0
| Barnett-1998 | 110 | 175 | 62.9
| Total | 194 | 358 | 54.2 | 52.2 | (39.5, 64.8) | 10.7 | 0.005
Specificity | Fiellau-Nikolajsen-1980 | 40 | 42 | 95.2
| Nozza-1994 | 103 | 112 | 92.0
| Barnett-1998 | 93 | 124 | 75.0
| Total | 236 | 278 | 84.9 | 87.7 | (76.8. 98.5) | 17.9 | <0.001
Prevalence | Fiellau-Nikolajsen-1980 | 46 | 88 | 52.3
| Nozza-1994 | 137 | 249 | 55.0
| Barnett-1998 | 175 | 299 | 58.5
| Total | 358 | 636 | 56.3 | 56.3 | (52.5, 60.2) | 1.4 | 0.510

Table 50. Professional Tympanometry (Static123 Compensated Acoustic Admittance at 0.3) versus Myringotomy

| | | | | Random Effect Estimate | | Test of Heterogenneity
Measure | Author-Year | X | N | % | % | 95% CI | Q | P-Value
(A) Including both Nozza articles
Sensitivity | Orchik-1978 | 35 | 39 | 89.7
| Fiellau-Nikolajsen-1980 | 16 | 46 | 34.8
| Nozza-1992 | 59 | 81 | 72.8
| Nozza-1994 | 96 | 137 | 70.1
| Total | 206 | 303 | 68.0 | 67.4 | (49.2, 85.7) | 41.6 | <0.001
Specificity | Orchik-1978 | 15 | 37 | 40.5
| Fiellau-Nikolajsen-1980 | 10 | 42 | 23.8
| Nozza-1992 | 24 | 30 | 80.0
| Nozza-1994 | 90 | 112 | 80.4
| Total | 139 | 221 | 62.9 | 56.4 | (27.5, 85.3) | 69.4 | <0.001
Prevalence | Orchik-1978 | 39 | 76 | 51.3
| Fiellau-Nikolajsen-1980 | 46 | 88 | 52.3
| Nozza-1992 | 81 | 111 | 73.0
| Nozza-1994 | 137 | 249 | 55.0
| Total | 303 | 524 | 57.8 | 58.2 | (48.1, 68.3) | 15.9 | 0.001
(B) Excluding Nozza-1992 study
Sensitivity | Orchik-1978 | 35 | 39 | 89.7
| Fiellau-Nikolajsen-1980 | 16 | 46 | 34.8
| Nozza-1994 | 96 | 137 | 70.1
| Total | 147 | 222 | 66.2 | 65.4 | (39.1, 91.7) | 41.5 | <0.001
Specificity | Orchik-1978 | 15 | 37 | 40.5
| Fiellau-Nikolajsen-1980 | 10 | 42 | 23.8
| Nozza-1994 | 90 | 112 | 80.4
| Total | 115 | 191 | 60.2 | 48.6 | (10.2, 87.0) | 64.7 | <0.001
Prevalence | Orchik-1978 | 39 | 76 | 51.3
| Fiellau-Nikolajsen-1980 | 46 | 88 | 52.3
| Nozza-1994 | 137 | 249 | 55.0
| Total | 222 | 413 | 53.8 | 53.8 | (49.0, 58.6) | 0.4 | 0.811

Table 51. Professional Tympanometry (B curve as abnormal) versus Myringotomy

| | | | | Random Effect Estimate | | Test of Heterogeneity
Measure | Author-Year | X | N | % | % | 95% CI | Q | P-Value
Sensitivity | Orchik-1978 | 46 | 84 | 54.8
| Shaw-1978 | 48 | 49 | 98.0
| Johnson-1980 | 55 | 74 | 74.3
| Ben-David-1981 | 195 | 250 | 78.0
| Kennedy-1982 | 44 | 51 | 86.3
| Gersdorff-1986 | 61 | 81 | 75.3
| Park-1988 | 182 | 248 | 73.4
| Mitchell-1990 | 57 | 65 | 87.7
| Toner-1990 | 107 | 124 | 86.3
| Finitzo-1992 | 65 | 72 | 90.3
| Vaughan-Jones-1992 | 91 | 135 | 67.4
| Ovessen-1993 | 310 | 342 | 90.6
| Sassen-1994 | 225 | 279 | 80.6
| Tom-1994 | 100 | 153 | 65.4
| Renvall-1996 | 87 | 101 | 86.1
| Watters-1997 | 679 | 745 | 91.1
| Total | 2352 | 2853 | 82.4 | 80.9 | (76.1, 85.7) | 196.6 | <0.001
Specificity | Orchik-1978 | 52 | 58 | 89.7
| Shaw-1978 | 3 | 10 | 30.0
| Johnson-1980 | 31 | 41 | 75.6
| Ben-David-1981 | 39 | 61 | 63.9
| Kennedy-1982 | 21 | 24 | 87.5
| Gersdorff-1986 | 27 | 47 | 57.4
| Park-1988 | 15 | 38 | 39.5
| Mitchell-1990 | 10 | 19 | 52.6
| Toner-1990 | 91 | 98 | 92.9
| Finitzo-1992 | 19 | 22 | 86.4
| Vaughan-Jones-1992 | 61 | 65 | 93.8
| Ovessen-1993 | 37 | 51 | 72.5
| Sassen-1994 | 59 | 101 | 58.4
| Tom-1994 | 47 | 60 | 78.3
| Renvall-1996 | 25 | 26 | 96.2
| Watters-1997 | 166 | 210 | 79.0
| Total | 703 | 931 | 75.5 | 74.5 | (66.9, 82.0) | 147.8 | <0.001
Prevalence | Orchik-1978 | 84 | 142 | 59.2
| Shaw-1978 | 49 | 59 | 83.1
| Johnson-1980 | 74 | 115 | 64.3
| Ben-David-1981 | 250 | 311 | 80.4
| Kennedy-1982 | 51 | 75 | 68.0
| Gersdorff-1986 | 81 | 128 | 63.3
| Park-1988 | 248 | 286 | 86.7
| Mitchell-1990 | 65 | 84 | 77.4
| Toner-1990 | 124 | 222 | 55.9
| Finitzo-1992 | 72 | 94 | 76.6
| Vaughan-Jones-1992 | 135 | 200 | 67.5
| Ovessen-1993 | 342 | 393 | 87.0
| Sassen-1994 | 279 | 380 | 73.4
| Tom-1994 | 153 | 213 | 71.8
| Renvall-1996 | 101 | 127 | 79.5
| Watters-1997 | 745 | 955 | 78.0
| Total | 2853 | 3784 | 75.4 | 73.6 | (69.1, 78.1) | 156.6 | <0.001

Table 44. Acoustic Reflectometry (>=5 vs <5 RU) versus Myringotomy

| | | | | Random Effect Estimate | | Test of Heterogeneity
Measure | Author-Year | X | N | % | % | 95% CI | Q | P-Value
Sensitivity | Fried-1985 | 44 | 62 | 71.0
| Macknin-1987 | 84 | 128 | 65.6
| Babonis-1991 | 68 | 118 | 57.6
| Total | 196 | 308 | 63.6 | 64.2 | (57.0, 71.5) | 3.6 | 0.168
Specificity | Fried-1985 | 36 | 40 | 90.0
| Macknin-1987 | 43 | 70 | 61.4
| Babonis-1991 | 90 | 102 | 88.2
| Total | 169 | 212 | 79.7 | 80.4 | (65.0, 95.9) | 18.4 | <0.001
Prevalence | Fried-1985 | 62 | 102 | 60.8
| Macknin-1987 | 128 | 198 | 64.6
| Babonis-1991 | 118 | 220 | 53.6
| Total | 308 | 520 | 59.2 | 59.6 | (52.5, 66.7) | 5.4 | 0.067

Table 52. Professional Tympanometry (B or C2 curve as abnormal) versus Myringotomy

| | | | | Random Effect Estimate | | Test of Heterogeneity
Measure | Author-Year | X | N | % | % | 95% CI | Q | P-Value
Sensitivity | Orchik-1978 | 31 | 39 | 79.5
| Fiellau-Nikolajsen-1980 | 42 | 46 | 91.3
| Kennedy-1982 | 51 | 51 | 100.0
| Vaughan-Jones-1992 | 120 | 135 | 88.9
| Ovessen-1993 | 323 | 342 | 94.4
| Sassen-1994 | 253 | 279 | 90.7
| Total | 820 | 892 | 91.9 | 93.8 | (91.1, 96.4) | 9.44 | 0.093
Specificity | Orchik-1978 | 32 | 37 | 86.5
| Fiellau-Nikolajsen-1980 | 37 | 42 | 88.1
| Kennedy-1982 | 11 | 24 | 45.8
| Vaughan-Jones-1992 | 41 | 65 | 63.1
| Ovessen-1993 | 27 | 51 | 52.9
| Sassen-1994 | 33 | 101 | 32.7
| Total | 181 | 320 | 56.6 | 61.8 | (41.5, 82.1) | 89.8 | <0.001
Prevalence | Orchik-1978 | 39 | 76 | 51.3
| Fiellau-Nikolajsen-1980 | 46 | 88 | 52.3
| Kennedy-1982 | 51 | 75 | 68.0
| Vaughan-Jones-1992 | 135 | 200 | 67.5
| Ovessen-1993 | 342 | 393 | 87.0
| Sassen-1994 | 279 | 380 | 73.4
| Total | 892 | 1212 | 73.6 | 67.3 | (56.3, 78.2) | 90.1 | <0.001

Table 53. Summary of Meta Analysis for Diagnostic Comparisons, Excluding Duplicated Studies by Same Author

| | | | | | Random Effect Estimate | | Test of Heterogeneity
Measure | ID | Diagnostic Comparison versus Myringotomy | Number Articles | Number Cases | Measure % | % | 95% CI | Q | P-Value
Sensitivity | 1 | Acoustic reflectometry (>=5 vs <5) | 3 | 308 | 63.6 | 64.2 | (57.0, 71.5) | 3.6 | 0.168
| 2 | Pneumatic otoscopy | 7 | 1732 | 94.3 | 93.8 | (91.4, 96.3) | 28.8 | <0.001
| 3 | Portable tympanometry | 6 | 774 | 89.4 | 84.5 | (76.0, 93.1) | 39.6 | <0.001
| 5 | Professional tympanometry (using static compensated acoustic admittance at 0.1) | 3 | 358 | 39.4 | 33.9 | (12.7, 55.0) | 36.9 | <0.001
| 6 | Professional tympanometry (using static compensated acoustic admittance at 0.2) | 3 | 359 | 54.2 | 52.2 | (39.5, 64.8) | 10.7 | 0.005
| 7 | Professional tympanometry (using static compensated acoustic admittance at 0.3) | 3 | 222 | 66.2 | 65.4 | (39.1, 91.7) | 41.5 | <0.001
| 8 | Professional tympanometry (using flat or B curve as abnormal) | 16 | 2853 | 82.4 | 80.9 | (76.1, 85.7) | 196.6 | <0.001
| 9 | Professional tympanometry (using flat or B or C2 curve as abnormal) | 6 | 892 | 91.9 | 93.8 | (91.1, 96.4) | 9.4 | 0.093
Specificity | 1 | Acoustic reflectometry (>=5 vs <5) | 3 | 212 | 79.7 | 80.4 | (65.0, 95.9) | 18.4 | <0.001
| 2 | Pneumatic otoscopy | 7 | 962 | 80.7 | 80.5 | (75.1, 86.0) | 27.2 | <0.001
| 3 | Portable tympanometry | 6 | 506 | 67.8 | 64.4 | (44.3, 84.4) | 167.1 | <0.001
| 5 | Professional tympanometry (using static compensated acoustic admittance at 0.1) | 3 | 278 | 91.7 | 94.1 | (83.9, 100) | 13.7 | 0.001
| 6 | Professional tympanometry (using static compensated acoustic admittance at 0.2) | 3 | 278 | 84.9 | 87.7 | (76.8, 98.5) | 17.9 | <0.001
| 7 | Professional tympanometry (using static compensated acoustic admittance at 0.3) | 3 | 191 | 60.2 | 48.6 | (10.2, 87.0) | 64.7 | <0.001
| 8 | Professional tympanometry (using flat or B curve as abnormal) | 16 | 931 | 75.5 | 74.5 | (66.9, 82.0) | 147.8 | <0.001
| 9 | Professional tympanometry (using flat or B or C2 curve as abnormal) | 6 | 320 | 56.6 | 61.8 | (41.5, 82.1) | 89.8 | <0.001
Prevalence | 1 | Acoustic reflectometry (>=5 vs <5) | 3 | 520 | 59.2 | 59.6 | (52.5, 66.7) | 5.4 | 0.067
| 2 | Pneumatic otoscopy | 7 | 2694 | 64.3 | 62.8 | (58.3, 67.2) | 30.7 | <0.001
| 3 | Portable tympanometry | 6 | 1280 | 60.5 | 58.5 | (40.3, 76.7) | 268.9 | <0.001
| 5 | Professional tympanometry (using static compensated acoustic admittance at 0.1) | 3 | 636 | 56.3 | 56.3 | (52.5, 60.2) | 1.4 | 0.510
| 6 | Professional tympanometry (using static compensated acoustic admittance at 0.2) | 3 | 636 | 56.3 | 56.3 | (52.5, 60.2) | 1.4 | 0.510
| 7 | Professional tympanometry (using static compensated acoustic admittance at 0.3) | 3 | 413 | 53.8 | 53.8 | (49.0, 58.6) | 0.4 | 0.811
| 8 | Professional tympanometry (using flat or B curve as abnormal) | 16 | 3784 | 75.4 | 73.6 | (69.1, 78.1) | 156.6 | <0.001
| 9 | Professional tympanometry (using flat or B or C2 curve as abnormal) | 6 | 1212 | 73.6 | 67.3 | (56.3, 78.2) | 90.1 | <0.001

Note: Comparison #4 had only two studies and thus not included in the summary

Figure 5. Receiver Operator Characteristic (ROC) Plot for 8 Diagnostic Procedures Versus Myringotomy

Among the nine diagnostic methods, pneumatic otoscopy and professional tympanometry (using flat or B or C2 curve as abnormal) had the highest sensitivity at 93.8 percent (95% CI: 91.4, 96.3) and 93.8 percent (95% CI: 91.1, 96.4) compared with myringotomy, respectively. The diagnostic test with the highest specificity was professional tympanometry (using static compensated acoustic admittance at 0.1) at 95.0 percent (95% CI: 88.5, 100).

If we consider both sensitivity and (1 minus specificity) in the receiver-operator characteristic display in Figure 5 , pneumatic otoscopy is closest to the optimal operating point where both sensitivity and specificity are 100 percent. The pooled sensitivity was 94 percent (95% CI: 91%, 96%), and the pooled specificity was 80 percent (95% CI: 75%, 86%). These findings were based on 2,694 children from 7 studies that reported a pooled prevalence of OME of 63 percent (95% CI: 58%, 67%). The estimated prevalence rates ranged from 56 percent to 71 percent, which indicated significant heterogeneity (p<0.001). We used the pooled sensitivity and specificity for pneumatic otoscopy and derived the positive and negative predictive values for various prevalence levels. Figure 6 provides such a plot.

Figure 6. Positive and Negative Predictive Values (PPV and NPV) of Pneumatic Otoscopy by Prevalence of Otitis Media with Effusion Based on Pooled Estimate of Sensitivity at 93.8 % and Specificity at 80.5%

Table 54 shows an analysis of the study quality of the diagnostic tests included in the meta-analyses. With the exception of the study by Babonis (Babonis, Weir, Kelly, 1991), which scored five, all studies scored four or less out of a maximum of six possible points. The majority of the studies did not fulfill criterion four on representativeness of patient sample in clinical practice or criterion five on determination of reproducibility of test results. Among the seven studies used to derive the pooled estimates of sensitivity and specificity for pneumatic otoscopy, two studies scored the minimum of one point, two scored two points, one scored three points, and two scored four points.

Table 54. Study Quality and Test Performer of Diagnostic Studies Used in Meta-Analysis

Diagnostic Comparison | Author-Year | Study Quality^a^ | Test Performer
1. Acoustic reflectometry (>=5 vs <5 RU) with myringotomy | Fried-1985 | 1(100000) | Not specified
| Macknin-1987 | 4(111001) | Pediatrician
| Babonis-1991 | 5(111011) | One of the authors, specialty not specified
2. Pneumatic otoscopy with myringotomy | Paradise-1976 | 4(111001) | Pediatrician
| Cantekin-1977 | 1(100000) | Not specified
| Bluestone-1979 | 2(100001) | Not specified
| Karma-1989 | 3(100101) | Otolaryngologist/pediatrician
| Mains-1989 | 1(100000) | Senior registrar and senior house officer
| Toner-1990 | 2(100001) | One of the authors, specialty not specified
| Finitzo-1992 | 4(111001) | Pediatric otolaryngologist
3. Portable tympanometry (mixed criteria) with myringotomy | Orchik-1978 | 4(111001) | Not specified
| Babonis-1991 | 5(111011) | One of the authors, specialty not specified
| Rees-1992 | 1(100000) | Not specified
| Vaughan-Jones-1992 | 2(100001) | Not specified
| van Balen-1994 | 4(111010) | General practitioner with special training from ENT
| Koivunen-1997 | 3(110001) | department Trained nurse
4. Professional tympanometer (using acoustic reflex at 500 or 1000 Hz) with myringotomy | Orchik-1978 | 4(111001) | Not specified
| Orchik-1980 | 4(111001) | Not specified
| Nozza-1992 | 4(111001) | Audiologist/nurses
| Nozza-1994 | 4(111001) | Clinically certified and licensed audiologist
5. Professional tympanometer (using static compensated acoustic admittance at 0.1) with myringotomy | Fiellau-Nikolajsen-1980 | 4(111001) | Author
| Nozza-1992 | 4(111001) | Audiologist/nurses
| Nozza-1994 | 4(111001) | Clinically certified and licensed audiologist
| Barnett-1998 | 4(111001) | Research assistant
6. Professional tympanometer (using static compensated acoustic admittance at 0.2) with myringotomy | Fiellau-Nikolajsen-1980 | 4(111001) | Author
| Nozza-1992 | 4(111001) | Audiologist/nurses
| Nozza-1994 | 4(111001) | Clinically certified and licensed audiologist
| Barnett-1998 | 4(111001) | Research assistant
7. Professional tympanometer (using static compensated acoustic admittance at 0.3) with myringotomy | Orchik-1978 | 4(111001) | Not specified
| Fiellau-Nikolajsen-1980 | 4(111001) | Author
| Nozza-1992 | 4(111001) | Audiologist/nurses
| Nozza-1994 | 4(111001) | Clinically certified and licensed audiologist
8. Professional tympanometer (using flat or B curve as abnormal) with myringotomy | Orchik-1978 | 4(111001) | Not specified
| Shaw-1978 | 1(100000) | Not specified
| Johnson-1980 | 2(110000) | Audiologist
| Ben-David-1981 | 1(100000) | Not specified
| Kennedy-1982 | 1(100000) | Audiologist
| Gersdorff-1986 | 1(100000) | Not specified
| Park-1988 | 1(100000) | Not specified
| Mitchell-1990 | 1(100000) | Not specified
| Toner-1990 | 2(100001) | Not specified
| Finitzo-1992 | 4(111001) | Certified audiologist
| Vaughan-Jones-1992 | 2(100001) | Not specified
| Ovessen-1993 | 4(111001) | Otolaryngologist
| Sassen-1994 | 3(111000) | Not specified
| Tom-1994 | 4(111001) | Certified audiologists
| Renvall-1996 | 1(100000) | Not specified
| Watters-1997 | 2(110000) | Paediatric audiologist
9. Professional tympanometer (using flat or B or C2 curve as abnormal) with myringotomy | Orchik-1978 | 4(111001) | Not specified
| Fiellau-Nikolajsen-1980 | 4(111001) | Author
| Kennedy-1982 | 1(100000) | Audiologist
| Vaughan-Jones-1992 | 2(100001) | Not specified
| Ovessen-1993 | 4(111001) | Otolaryngologist
| Sassen-1994 | 3(111000) | Not specified

a The first number is the total score of the six components. The six components of study quality score are: (1) appropriate reference standard; (2) test and reference standard assessed independently of each other; (3) blinded reading of results; (4) patient sample included an appropriate spectrum as in clinical practice; (5) reproducibility and interpretation of test results determined; and (6) description of test method sufficient to permit replication. ‘1’ indicates presence and ‘0’ indicates absence of the criterion.]

In Table 54, we also compare the qualifications of the examiner performing the diagnostic test for each study. Of the seven studies in the comparison between pneumatic otoscopy and myringotomy, two studies did not specify the test performer, one study specified that a senior registrar and a senior house officer performed the test, and the remaining four specified that either a pediatrician or an otolaryngologist performed the test. However, whether the test performer was trained or untrained was not specified.

### Summary

The meta-analyses revealed that pneumatic otoscopy and professional tympanometry had the highest sensitivity compared with myringotomy. While the diagnostic test with the highest specificity was professional tympanometry (using static compensated acoustic admittance at 0.1), pneumatic otoscopy optimized both sensitivity and specificity. However, the poor quality of many of the studies included in the analysis must be considered. Moreover, most studies failed to provide enough information to assess the qualifications of testers.