# Appendix G. Literature Search Strategy

## Search Strategy

Database: Medline <1966 to January 2000>
1 | [OMEMastoidOM] | 0
2 | [OME module] | 0
3 | otitis media with effusion/ | 2834
4 | otitis media with effusion.mp. | 3056
5 | (allergic otitis media or fluid ear or glue ear or middle | 1774
| ear effusion or mucoid otitis media or nonsuppurative
| otitis media or secretory otitis media or serous otitis
| media or tubotympanitis or tympanic hydrops).mp.
6 | ((catarrh$ adj otitis) or (exudative adj catarrh$) or | 19
| hydrotubotympan$ or (tubotympanic adj catarrh$)).mp.
7 | hydrotubotympan$.mp. | 0
8 | tympanic hydrops.mp. | 0
9 | (tympanic and hydrops).mp. [mp=title, abstract, registry | 26
| number word, mesh subject heading]
10 | 3 or 4 or 5 or 6 or 7 or 8 or 9 | 3793
11 | [Mastoid] | 0
12 | mastoid/ or mastoid.ti. | 2502
13 | [OME or Mastoid] | 0
14 | 10 or 12 | 6190
15 | [explode OM] | 0
16 | exp otitis media/ | 11895
17 | [OME or Mastoid or explode OM] | 0
18 | 10 or 12 or 16 | 13982
19 | [Natural History] | 0
20 | ((cure$ or clear$ or disappear$ or heal$ or improve$ or | 3563
| recover$ or resolve$) adj spontaneous$).mp.
21 | (natural course or natural history or placebo$ or | 208132
| resolution or self limit$ or untreated).mp. or placebos/
22 | (duration adj5 effusion).mp. | 83
23 | [The system is UNABLE to search the following terms: “NO”, | 0
| “WITHOUT”]
24 | 20 or 21 or 22 | 211317
25 | [(OME or Mastoid) AND Natural History] | 0
26 | 14 and 24 | 344
27 | [excl-editorial] | 0
28 | (comment or editorial or letter or practice guideline or | 1212431
| review).pt.
29 | 26 not 28 | 313
30 | [excl-animal] | 0
31 | animal/ | 2955143
32 | human/ | 6660577
33 | [substitute final set NOT animal] | 0
34 | [subsitute final set AND human] | 0
35 | [OR above two sets] | 0
36 | 29 not 31 | 285
37 | 29 and 32 | 290
38 | 36 or 37 | 290
39 | [Excl-ageover12] | 0
40 | adolescence/ or adult/ or middle age/ or aged/ | 2984241
41 | infant, newborn/ or infant/ or child, preschool/ or child/ | 1108287
42 | [substitute final set NOT > 12 years] | 0
43 | [substitute final set AND 12 years or less] | 0
44 | [OR above two sets] | 0
45 | 38 not 40 | 199
46 | 38 and 41 | 224
47 | 45 or 46 | 253
48 | [excl-cleft] | 0
49 | aural atresia.ti. or cleft palate/ or cystic fibrosis/ or | 136770
| Down syndrome/ or exp Hiv infections/ or
| immunodeficien$.ti. or immotile cilia syndrome$.ti.
50 | 47 not 49 | 247
51 | limit 50 to english language | 231
52 | [Speech and Language] | 0
53 | American speech-language-hearing association/ or exp | 128500
| audiometry, speech/ or exp child language/ or exp
| communication/ or communication disorders/
54 | exp language/ or language development/ or exp language | 80623
| Disorders/ or language tests/ or language therapy/ or exp
| “rehabilitation of speech and language disorders”/
55 | exp speech/ or exp speech disorders/ or speech-language | 34953
| Pathology/ or speech perception/ or exp speech production
| measurement/ or exp voice/ or exp voice disorders/
56 | (speech or language).mp,hw. | 58421
57 | 53 or 54 or 55 or 56 | 164960
58 | [(OME or Mastoid or explode OM) AND Speech and Language] | 0
59 | 18 and 57 | 479
60 | [excl-editorial] | 0
61 | (comment or editorial or letter or practice guideline or | 1212431
| review).pt.
62 | 59 not 61 | 389
63 | [excl-animal] | 0
64 | animal/ | 2955143
65 | human/ | 6660577
66 | [substitute final set NOT animal] | 0
67 | [subsitute final set AND human] | 0
68 | [OR above two sets] | 0
69 | 62 not 64 | 383
70 | 62 and 65 | 388
71 | 69 or 70 | 389
72 | [Excl-ageover12] | 0
73 | adolescence/ or adult/ or middle age/ or aged/ | 2984241
74 | infant, newborn/ or infant/ or child, preschool/ or child/ | 1108287
75 | [substitute final set NOT > 12 years] | 0
76 | [substitute final set AND 12 years or less] | 0
77 | [OR above two sets] | 0
78 | 71 not 73 | 265
79 | 71 and 74 | 303
80 | 78 or 79 | 345
81 | [excl-cleft] | 0
82 | aural atresia.ti. or cleft palate/ or cystic fibrosis/ or | 136770
| Down syndrome/ or exp Hiv infections/ or
| immunodeficien$.ti. or immotile cilia syndrome$.ti.
83 | 80 not 82 | 299
84 | limit 83 to english language | 263
85 | [Hearing] | 0
86 | exp hearing/ or exp hearing aids/ or exp hearing disorders/ | 64186
| or exp hearing impaired persons/ or exp hearing tests/ or
| exp rehabilitation of hearing impaired/
87 | hearing.mp,hw. | 40614
88 | 86 or 87 | 69788
89 | [(OME or Mastoid or explode OM) and Hearing] | 0
90 | 18 and 88 | 3208
91 | [excl-editorial] | 0
92 | (comment or editorial or letter or practice guideline or | 1212431
| review).pt.
93 | 90 not 92 | 2938
94 | [excl-animal] | 0
95 | animal/ | 2955143
96 | human/ | 6660577
97 | [substitute final set NOT animal] | 0
98 | [subsitute final set AND human] | 0
99 | [OR above two sets] | 0
100 | 93 not 95 | 2794
101 | 93 and 96 | 2840
102 | 100 or 101 | 2847
103 | [Excl-ageover12] | 0
104 | adolescence/ or adult/ or middle age/ or aged/ | 2984241
105 | infant, newborn/ or infant/ or child, preschool/ or child/ | 1108287
106 | [substitute final set NOT > 12 years] | 0
107 | [substitute final set AND 12 years or less] | 0
108 | [OR above two sets] | 0
109 | 102 not 104 | 1438
110 | 102 and 105 | 1689
111 | 109 or 110 | 2223
112 | [excl-cleft] | 0
113 | aural atresia.ti. or cleft palate/ or cystic fibrosis/ or | 136770
| Down syndrome/ or exp Hiv infections/ or
| immunodeficien$.ti. or immotile cilia syndrome$.ti.
114 | 111 not 113 | 2115
115 | limit 114 to english language | 1638
116 | [Diagnosis] | 0
117 | exp acoustics/du or diagnosis/ or exp diagnosis, | 2375966
| computer-assisted/ or diagnosis, differential/ or exp
| diagnostic errors/ or exp “diagnostic techniques and
| procedures”/ or exp “laboratory techniques and procedures”/
| or nursing diagnosis/
118 | (acoustic reflectomet$ or audiomet$ or diagnosis or | 548679
| diagnostic or otoacoustic emission$ or otoscop$ or
| tympanomet$ or tympanoscop$).mp.
119 | 117 or 118 | 2611782
120 | [*Also search Otitis media with effusion/di] | 0
121 | [(OME or Mastoid) and Diagnosis] | 0
122 | 14 and 119 | 2324
123 | [OME with suheading diagnosis] | 0
124 | [diagnosis-ome] | 0
125 | Otitis media with effusion/di [Diagnosis] | 454
126 | [(OME or Mastoid) and Diagnosis OR OME with subheading | 0
| diagnosis]
127 | 122 or 125 | 2445
128 | [excl-editorial] | 0
129 | (comment or editorial or letter or practice guideline or | 1212431
| review).pt.
130 | 127 not 129 | 2238
131 | [excl-animal] | 0
132 | animal/ | 2955143
133 | human/ | 6660577
134 | [substitute final set NOT animal] | 0
135 | [subsitute final set AND human] | 0
136 | [OR above two sets] | 0
137 | 130 not 132 | 2087
138 | 130 and 133 | 2114
139 | 137 or 138 | 2119
140 | [Excl-ageover12] | 0
141 | adolescence/ or adult/ or middle age/ or aged/ | 2984241
142 | infant, newborn/ or infant/ or child, preschool/ or child/ | 1108287
143 | [substitute final set NOT > 12 years] | 0
144 | [substitute final set AND 12 years or less] | 0
145 | [OR above two sets] | 0
146 | 139 not 141 | 1072
147 | 139 and 142 | 1323
148 | 146 or 147 | 1601
149 | [excl-cleft] | 0
150 | aural atresia.ti. or cleft palate/ or cystic fibrosis/ or | 136770
| Down syndrome/ or exp Hiv infections/ or
| immunodeficien$.ti. or immotile cilia syndrome$.ti.
151 | 148 not 150 | 1542
152 | limit 151 to english language | 1272
153 | [Q1 or Q2 or Q3 or Q4] | 0
154 | 51 or 84 or 115 or 152 | 2379