# Appendix F. Experts' Opinion on Influence of Non-Condition Factors on Outcomes

## Key Question 1: Natural History of OME

Non-treatment factors Influencing outcomes for key Question 1 | Does this factor influence the natural history of OME? 1=yes, 0=no, 9=don't know | | | | | | | | | | | | Basis of the opinion 1=j/e; 2=tc; 3=lit; 4=1+2; 5=1+3; 6=2+3; 7=1+2+3; -9=blank
Expert number (randomly assigned)* | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12
[underlined: Demographic]
age of child | 1 | 1 | 1 | 1 | 1 | 1 | 9 | 9 | 1 | 1 | 9 | 1 | 5 | 2 | 7 | 3 | 2 | 7 | -9 | -9 | 3 | 4 | -9 | 3
gender | 1 | 0 | 0 | 0 | 0 | 9 | 0 | 9 | 1 | 1^h^ | 9 | 1 | 3 | 1 | -9 | 3 | 2 | 1 | -9 | -9 | 3 | 4 | -9 | 3
ethnicity/Race | 9 | 1 | 9 | 1 | 1 | 0 | 1 | 9 | 1 | 1 | 9 | 1 | 3^a^ | 2 | -9 | 3 | 3 | 7 | -9 | -9 | 3 | 7 | -9 | 3
socioeconomic status | 1 | 0 | 1 | 9 | 9 | 1 | 0 | 9 | 1 | 1 | 9 | 0 | 5 | 1 | 6 | -9 | -9 | 7 | -9 | -9 | 3 | 7 | -9 | 2
[underlined: Environmental]
# hours attending child care center | 1 | 1 | 1 | 1 | 1 | 1 | 0 | -9 | 1^d^ | 1 | 1 | 1 | 3 | 3 | 3 | 3 | 3 | 7 | -9 | -9 | 3 | 7 | 1 | 3
tobacco smoke exposure | 9 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 9 | 1 | 1 | 1 | 3^b^ | 3 | 3 | 3 | 2 | 7 | -9 | 2 | 3 | 7 | 3 | 3
season of the year | 1 | 1 | 1 | 1 | 9 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 5 | 2 | 3 | 3 | -9 | 7 | -9 | 2 | 3 | 5 | 2 | 3
number of children in household | 1 | 0 | 1 | 1 | 1 | 0 | 0 | 9 | 1 | 1 | 1 | 1 | 3 | 1 | 2 | 3 | 3 | 1 | -9 | -9 | 3 | -9 | 2 | 2
not breast-fed | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 9 | 1 | 1 | 1 | 1 | 3 | 2 | 3 | 3 | 2 | 7 | -9 | -9 | 3 | -9 | 2 | 3
barotrauma challenges | 9 | 1 | 1 | 1 | 1 | 1 | 9 | 9 | 9 | 9 | 1 | 0 | 9^c^ | 2 | 2 | 3 | 2 | 1 | -9 | -9 | -9 | -9 | 1 | 2
[underlined: Symptoms/Signs]
laterality, unilateral versus bilateral | 1 | 0 | 0 | 1 | 9 | 1 | 0 | 9 | 1 | 0 | 9 | 9 | 5 | 1 | 2 | 3 | 1 | 7 | -9 | -9 | 3 | -9 | -9 | -9
hearing level, conductive vs sensorineural | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 1 | 0 | 9 | 9 | 2 | 2 | 2 | 2 | 2 | 1 | -9 | -9 | 3 | -9 | -9 | -9
[underlined: Other clinical factors]
total duration of OME (>=3 mos) | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 9 | 1 | 1 | 1 | 1 | 2 | 3 | 7 | 3 | 3 | 7 | -9 | -9 | 3 | 5 | 3 | 3
age at first OM | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 9 | 1 | 1 | 9 | 1 | 3 | 2 | 5 | 3 | 3 | 7 | -9 | -9 | 3 | 5 | -9 | 3
age of onset of previous OME | 9 | 1 | 0 | 9 | 9 | 9 | 1 | 9 | 1 | 9 | 9 | 1 | 9 | 2 | 5 | -9 | -9 | 1 | -9 | -9 | 3 | -9 | -9 | 3
number of previous OMEs | 1 | 1 | 1 | 1 | 9 | 1 | 1 | 9 | 1 | 1 | 1 | 1 | 2 | 2 | 4 | 1 | -9 | 7 | -9 | -9 | 3 | 5 | 2 | 3
family history of OME | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 9 | 1 | 1 | 9 | 1 | 5 | 2 | 2 | 3 | 2 | 7 | -9 | -9 | 3 | 3 | -9 | 3
otitis prone (AOM) | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 9 | 1 | 1 | 1 | 1 | 2 | 4 | 4 | 3 | 2 | 7 | -9 | -9 | 3 | -9 | 1 | 3
allergies | 1 | 1 | 1 | 9 | 1 | 1 | 1 | 9 | 9 | 1 | 1 | 1 | 1 | 4 | 7 | -9 | 2 | 7 | -9 | -9 | 3 | 3 | 2 | 3
prior tubes | 9 | 1 | 1 | 1 | 1 | 0 | 1 | 9 | 9 | 1 | 1 | 1 | 9 | 4 | 4 | 1 | 2 | 1 | -9 | -9 | 3 | 5 | 1 | 3
prior adenoidectomy | 1 | 1 | 1 | 0 | 9 | 1 | 1 | 9 | 9 | 9 | 9 | 1 | 3 | 3 | 4 | 1 | -9 | 5 | -9 | -9 | 3 | -9 | -9 | 3
developmental delay | 0 | 0 | 9 | 0 | 9 | 0 | 0 | 0 | 9^e^ | 0 | 9 | 0 | 2 | 4 | -9 | 2 | -9 | 1 | -9 | 2 | -9 | 4 | -9 | 2
[underlined: Parent/caretaker]
parent/caregiver preference for tx | 0 | 9 | 9 | 0 | 9 | 0 | 0 | 0 | 9 | 1 | 9 | 0 | 2 | -9 | 2 | 2 | -9 | 1 | -9 | 3 | 1 | 4 | -9 | 2
parent/caregiver education | 0 | 9 | 0 | 0 | 9 | 0 | 0 | 9 | 9 | 9 | 1 | 0 | 2 | -9 | 2 | 2 | -9 | 1 | -9 | -9 | 1 | -9 | 2 | 2
[underlined: Examiner]
Skill to diagnose (validated) | 0 | 1 | 9 | 0 | 0 | 1 | 1 | 0 | 9 | 9 | 9 | 1 | 2 | 4 | 2 | 2 | 2 | 2 | -9 | 2 | 1 | -9 | -9 | 3
Type of examiner | 0 | 1 | 0 | 0 | 0 | 1 | 0 | 0 | 9 | 9 | 9 | 9 | 2 | 1 | 2 | 2 | 2 | 2 | -9 | 4 | 1 | -9 | -9 | -9
Setting (Public,private,PPO,HMO) | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 0 | 9 | 2 | 1 | 2 | 2 | 2 | 1 | -9 | 2 | 1 | -9 | 2 | -9
[underlined: Monitoring during course of illness]
When | 0 | 1 | -9 | 0 | 9 | 0 | 0 | 0 | 9^f^ | 9 | 1 | 1 | 2 | 5 | -9 | 2 | -9 | 1 | -9 | 2 | -9 | -9 | 2 | 3
Frequency | 0 | 1 | -9 | 0 | 9 | 0 | 0 | 0 | 9^f^ | 9 | 1 | 0 | 2 | 4 | -9 | 2 | -9 | 1 | -9 | 2 | -9 | -9 | 2 | 2
Primary provider | 0 | 9 | 0 | 0 | 9 | 0 | 0 | 0 | 9^f^ | 9 | 1 | 1 | 2 | -9 | 2 | 2 | -9 | 1 | -9 | 2 | -9 | -9 | 2 | 2
[underlined: Type of monitoring method]
tympanometry | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0 | 9^f^ | 9 | 1 | 1 | 2 | 2 | 2 | 2 | 2 | 1 | -9 | 2 | -9 | -9 | 1 | 3
acoustic reflectometry | 0 | 0 | 0 | 0 | 9 | 0 | 9 | 0 | 9^f^ | 9 | 1 | 1 | 2 | 2 | 2 | 2 | -9 | 1 | -9 | 2 | -9 | -9 | 2 | 3
ototscopy | 0 | 0 | 0 | 0 | 9 | 0 | 0 | 0 | 9^f^ | 9 | 1 | 0 | 2 | 2 | 2 | 2 | -9 | 1 | -9 | 2 | -9 | -9 | 1 | 3
pneumatic otoscopy | 0 | 0 | 0 | 0 | 9 | 0 | 0 | 0 | 9^f^ | 9 | 1 | 1 | 2 | 2 | 2 | 2 | -9 | 1 | -9 | 2 | -9 | -9 | 1 | 3
MRI | 0 | 0 | 0 | 0 | 9 | 0 | 1 | 0 | 9^f^ | 9 | 1 | 9 | 2 | 2 | 2 | 2 | -9 | 1 | -9 | 2 | -9 | -9 | 3 | -9

* Experts 1–11 are members of the technical expert panel; Expert 12 is an internal expert.

a may be higher in Inuit, Native American; may be SES

b fellow traveler with low SES

c not important

d size of child care center?

e If head/neck syndrome, then yes

f don't understand how these relate to natural history

h variable

## Key Question 2: Speech and Language Development

Non-treatment or non-condition factors Influencing outcomes for key Questions 2 | Does this factor influence an independent effect on speech and language development separate from its effects on OME or unspecified OM? 1=yes, 0=no, 9=don't know | | | | | | | | | | | | Basis of the opinion 1=j/e; 2=tc; 3=lit; 4=1+2; 5=1+3; 6=2+3; 7=1+2+3; -9=blank
Expert number (randomly assigned) | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12
[underlined: Demographic]
age at first OM | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 9 | 9 | 9 | 9 | 9 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | -9 | 3 | -9 | -9 | 1
gender | 1 | 1 | 0 | 1 | 0 | 1 | 0 | 9 | 9 | 1 | 9 | 1 | 3 | 3 | 2 | 2 | 2 | 1 | -9 | -9 | 3 | 6 | -9 | 1
ethnicity/race | 0 | 9 | 0 | 1 | 0 | 0 | 1 | 9 | 9 | 1 | 9 | 9 | 2 | 1 | 2 | 2 | 2 | 1 | -9 | -9 | 3 | 6 | -9 | 1
socioeconomic status | 1 | 9 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 9 | 1 | 3 | 2 | 2 | 3 | 3 | 1 | -9 | 2 | 3 | 7 | -9 | 1
[underlined: Environmental]
# hours attending child care center | 9 | 1 | 0 | 0 | 9 | 1 | 1 | 9 | 9 | 1 | 9 | 1 | -9 | 2 | 2 | 2 | -9 | 1 | -9 | -9 | 3 | 6 | -9 | 1
quality of child care | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 9 | 1 | 2 | 2 | 2 | 3 | 1 | 1 | -9 | 3 | 3 | 6 | -9 | 1
early intervention program | 9 | 1 | 0 | 1 | 1 | 1 | 1 | 9 | 1 | 1 | 9 | 0 | -9 | 2 | 2 | 2 | 1 | 2 | -9 | -9 | 1 | 6 | -9 | 1
tobacco smoke exposure | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 9 | 0 | 0 | 1 | 1 | 2 | 2 | 2 | 1 | 3 | 2 | -9 | -9 | 2 | -9 | 1 | 1
number of children in household | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 9 | 9 | 0 | 1 | 1 | 2 | 1 | 2 | 1 | 3 | 1 | -9 | -9 | 3 | -9 | 1 | 1
not breast-fed | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 9 | 9 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | -9 | 3 | -9 | -9 | 1
[underlined: Symptoms/Signs]
laterality, unilateral vs bilateral | 9^a^ | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 9 | -9 | 1 | 1 | -9 | 2 | 7 | 3 | 2 | 2 | -9 | 3 | 3 | -9 | 1 | 1
hearing level, conductive vs sensorineural | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 9 | 1 | 1 | 9 | 1 | 3 ^d^ | 3 | 7 | 3 | 2 | 5 | -9 | -9 | 3 | 6 | -9 | 1
[underlined: Other clinical factors]
total duration of OME (>=3 mos) | 9 | 0 | 0 | 0 | 1 | 1 | 1 | 9 | 1 | 1 | 1 | 1 | -9 | 2 | 2 | -9 | 2 | 1 | -9 | -9 | 3 | 2 | 1 | 1
number of previous OMEs | 9 | 0 | 0 | 0 | 0 | 1 | 1 | 9 | 9 | 1 | 9 | 1 | -9 | 2 | 2 | -9 | 2 | 1 | -9 | -9 | 3 | 2 | -9 | 1
duration of MEE | 9 | 0 | 0 | 0 | 1 | 1 | 1 | 9 | 1 | 1 | 1 | 9 | -9 | 2 | 2 | -9 | 2 | 1 | -9 | -9 | 3 | 3 | 1 | 1
allergies | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 9 | 0 | 1 | 1 | -9 | 2 | 2 | -9 | 1 | 1 | -9 | -9 | 3 | 6 | 1 | 1
developmental delay | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 9 | 1 | -9^e^ | 3 | 7 | 1 | 3 | 1 | -9 | 3 | 3 | 7 | -9 | 1
OM complications | 9^b^ | 1 | 0 | 0 | 1 | 9 | 0 | 1 | 9 | 0 | 9 | 9 | -9 | 2 | 2 | 2 | 3 | 1 | -9 | 3 | 3 | -9 | -9 | 1
chronic illness of any type | 9^c^ | 1 | 1 | 9 | 1 | 1 | 1 | 1 | 9 | 0 | 9 | -9 | -9 | 2 | 4 | 2 | 1 | 1 | -9 | 3 | 3 | -9 | -9 | 1
[underlined: Parent/caretaker]
parent/caregiver education | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 9 | 1 | 3 | 2 | 2 | 3 | 3 | 1 | -9 | 3 | 3 | 3 | -9 | 1
quality of parent-child interaction | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 9 | 1 | 2 | 2 | 2 | 3 | 3 | 1 | -9 | 3 | 3 | 3 | -9 | 1
[underlined: Examiner]
skill to diagnose (validated) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 1 | 2 | 2 | 2 | 1 | 1 | 1 | -9 | 2 | 2 | 1 | -9 | 1
type of examiner | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 1 | 1 | -9 | 2 | 2 | 1 | -9 | 1
setting (Public,private,PPO,HMO) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 1 | 1 | -9 | 2 | 2 | 1 | -9 | 1
[underlined: Monitoring]
recheck times | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | -9 | 1
frequency of recheck | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | -9 | 1
primary provider | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | -9 | 1
ambient noise | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 9 | 0 | 0 | 9 | 1 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | -9 | 2 | 1 | -9 | 1
child temperament | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 9 | 9 | 9 | 1 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 1 | 1 | 1 | -9 | 1
presence of active ear disease | 1 | 0 | 0 | 0 | 1 | 1 | 0 | 9 | 9 | 0 | 9 | 1 | 1^f^ | 2 | 2 | 1 | 1 | 2 | -9 | -9 | 1 | 1 | -9 | 1
[underlined: Monitoring method]
tympanometry | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | -9 | 1
acoustic reflectometry | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | -9 | 1
pneumatic otoscopy | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | -9 | 1
MRI | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | -9 | 1
equipment to measure auditory brainstem | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | -9 | 1
responses/brainstem auditory evoked responses audiometry) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | -9 | 1

a question too vague, how long?

b depends on hearing;

c too vague-what kind of illness at what age?

d if hearing deficit severe or prolonged;

e by definition;

f would depend on duration and age

## Key Question 3: Long-term Hearing Loss

Non-treatment or non-condition factors Influencing outcomes for Key Questions 3 | Does this factor have an independent effect on long-term hearing separate from its effects on OME or unspecified OM? ^k^ 1=yes, 0=no, 9=don't know | | | | | | | | | | | | Basis of the opinion 1=j/e; 2=tc; 3=lit; 4=1+2; 5=1+3; 6=2+3; 7=1+2+3; -9=blank
Expert number (randomly assigned) | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12
[underlined: Demographic]
age at first OM | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 9 | 0 | 9 | 0 | 2 | 2 | 4 | 1 | 4 | 1 | -9 | -9 | 1 | 1 | -9 | 1
gender | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 4 | 1 | -9 | -9 | 1 | 3 | -9 | 1
ethnicity/race | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 9 | 9 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 4 | 1 | -9 | -9 | 1 | 3 | -9 | 1
socioeconomic status | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 9 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 3 | 1 | -9 | 2 | 1 | 3 | -9 | 1
[underlined: Environmental]
# hours attending child care center | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 4 | 1 | -9 | -9 | 1 | 2 | -9 | 1
quality of child care | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 9 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 4 | 1 | -9 | 3 | 1 | 2 | -9 | 1
early intervention program | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 9 | 1 | 2 | 2 | 2 | 1 | 4 | 1 | -9 | 2 | 1 | 2 | -9 | 1
tobacco smoke exposure | 0 | 9 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 9 | 1 | 9 | 2 | 1 | 2 | 1 | 4 | 1 | -9 | -9 | 1 | 1 | 1 | 1
number of children in household | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 0 | 1 | 0 | 2 | 2 | 2 | 1 | 4 | 1 | -9 | -9 | 1 | 1 | 1 | 1
not breast-fed | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 9 | 0 | 9 | 9 | 2 | 2 | 2 | 1 | 4 | 1 | -9 | -9 | 1 | 1 | -9 | 1
[underlined: Symptoms/Signs]
laterality, unilateral vs bilateral | -9^a^ | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1 | -9 | 2 | 2 | 1 | 2 | 1 | -9 | 3 | 3 | 3 | 1 | 1
hearing level, conductive vs sensorineural | -9^a^ | 1 | 1 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 9 | 1 | -9 | 2 | 6 | 1 | 2 | 1 | -9 | 3 | 3 | 3 | -9 | 1
[underlined: Other clinical factors]
total duration of OME (>=3 mos) | 9 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 1 | 1 | 1 | 1 | -9 | 2 | 2 | 1 | 2 | 1 | -9 | -9 | 3 | 1 | 1 | 1
number of previous OMEs | 9 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 1 | 1 | 9 | 1 | -9 | 2 | 2 | 1 | 2 | 1 | -9 | -9 | 3 | 1 | -9 | 1
duration of MEE | 9 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 1 | 1 | 9 | 1 | -9 | 2 | 2 | 1 | 2 | 1 | -9 | -9 | 3 | 1 | -9 | 1
allergies | 0 | 0 | 1 | 0 | 0 | 0 | 9 | 9 | 9 | 0 | 1 | 0 | 2 | 2 | 4 | 1 | 2 | 1 | -9 | -9 | 3 | -9 | 1 | 1
developmental delay | -9 | 1 | 1 | 9 | 0 | 0 | 1 | 1 | 1 | 0 | 9 | 1 | -9 | 2 | 7 | 1 | 2 | 1 | -9 | 3 | 3 | 3 | -9 | 1
OM complications | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 9 | 1 | 3 | 2 | 7 | 3 | 4 | 1 | -9 | 3 | 3 | 3 | -9 | 1
chronic illness of any type | 0 | 0 | 1 | 9 | 0 | 0 | 1 | 9 | 1 | 0 | 9 | 9 | 2 | 2 | 4 | 1 | 2 | 1 | -9 | -9 | 3 | 1 | -9 | 1
[underlined: Parent/caretaker]
parent/caregiver education | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 3 | 2 | 1 | -9 | 1
quality of parent-child interaction | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 3 | 2 | 1 | -9 | 1
[underlined: Examiner]
skill to diagnose (validated) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 3 | 2 | 1 | -9 | 1
type of examiner | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 3 | 2 | 1 | -9 | 1
setting (Public,private,PPO,HMO) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 3 | 2 | 1 | -9 | 1
[underlined: Monitoring]
recheck times | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | -9 | 1
frequency of recheck | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | -9 | 1
primary provider | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | -9 | 1
ambient noise | 0 | 1 | 1 | 0 | 0 | 1 | 0 | 9 | 0 | 0 | 9 | 9 | 2 | 3 | 7 | 1 | 2 | 1 | -9 | -9 | 2 | 1 | -9 | 1
child temperament | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 2 | 2 | 4 | 1 | 2 | 1 | -9 | 2 | 2 | 1 | 1 | 1
presence of active ear disease | 9^b^ | 0 | 1 | 0 | 1 | 0 | 0 | 1 | 1 | 1 | 9 | 1 | -9 | 2 | 2 | 1 | 3 | 1 | -9 | 3 | 1 | 3 | -9 | 1
[underlined: Monitoring method]
tympanometry | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 3 | 1 | 1 | -9 | 1
acoustic reflectometry | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 3 | 1 | 1 | -9 | 1
pneumatic otoscopy | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 3 | 1 | 1 | -9 | 1
MRI | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 3 | 1 | 1 | -9 | 1
equipment to measure auditory brainstem | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 3 | 1 | 3 | -9 | 1
responses/brainstem auditory evoked responses audiomety) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 9 | 0 | 2 | 2 | 2 | 1 | 2 | 1 | -9 | 3 | 1 | 3 | -9 | 1

a questions need to be rephrased;

b question illogical.

## Key Question 4: Accuracy of Diagnostic Methods

Non-treatment or non-condition factors Influencing outcomes for Key Question 4 | Does this factor have an independent effect on the accuracy of a diagnostic method separate from its effects on OME or unspecified OM? 1=yes, 0=no, 9=don't know -9=blank | | | | | | | | | | | | Basis of the opinion 1=j/e; 2=tc; 3=lit; 4=1+2; 5=1+3; 6=2+3; 7=1+2+3; -9=blank
Expert number (randomly assigned)* | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12
[underlined: Demographic]
age of child | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 7 | 4 | 3 | 2 | 4 | -9 | 1 | 4 | 1 | 2 | 2
[underlined: Symptoms/Signs]
laterality, unilateral versus bilateral | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 0 | 0 | 9 | 1 | 0 | 2 | 4 | 4 | 2 | 2 | 4 | -9 | 3 | 2 | -9 | 1 | 2
[underlined: Other clinical factors]
age at first OM | 0 | 1 | 1 | 0 | 0 | 1 | 0 | 1 | 1 | 0 | 9 | 1 | 2 | 4 | 4 | 2 | 2 | 1 | -9 | 1 | 4 | -9 | -9 | 3
anesthetic | 0 | 1 | 9 | 1 | 1 | 1 | 0 | 1 | 9 | 0 | 9 | 1 | 2 | 4 | -9 | 1 | 2 | 1 | -9 | 3 | -9 | -9 | -9 | 3
developmental delay | 0 | 1 | 1 | 1^m^ | 9 | 0 | 0 | 0 | 9 | 1 | 9 | 9 | 2 | 4 | 4 | 1 | -9 | 4 | -9 | 1 | -9 | 1 | -9 | -9
[underlined: Type of examiner]
family physician | -9^l^ | 1 | 0 | 1 | 0 | 1 | 0 | 1 | 1 | 9 | 9 | 9 | -9 | 1 | 2 | 1 | 2 | 1 | -9 | 1 | 4 | -9 | -9 | -9
otolaryngologist | -9^l^ | 1 | 0 | 1 | 0 | 1 | 1 | 1 | 1 | 9 | 9 | 9 | -9 | 4 | 2 | 1 | 2 | 1 | -9 | 3 | 4 | -9 | -9 | -9
pediatrician | -9^l^ | 1 | 0 | 1 | 0 | 1 | 0 | 1 | 1 | 9 | 9 | 9 | -9 | 1 | 2 | 1 | 2 | 1 | -9 | 1 | 4 | -9 | -9 | -9
nurse practitioner | -9^l^ | 1 | 0 | 1 | 0 | 1 | 0 | 1 | 1 | 9 | 9 | 9 | -9 | 1 | 2 | 1 | 2 | 1 | -9 | 1 | 4 | -9 | -9 | -9
physician assistant | -9^l^ | 1 | 0 | 1 | 0 | 1 | 0 | 9 | 1 | 9 | 9 | 9 | -9 | 1 | 2 | 1 | 2 | 1 | -9 | -9 | 1 | -9 | -9 | -9
others | -9^l^ | 1 | 0 | 1 | 0 | -9 | 0 | 9 | 1^n^ | 9 | 9 | 9 | -9 | 1 | 2 | 1 | 2 | -9 | -9 | -9 | 1 | -9 | -9 | -9

* Experts 1–11 are members of the technical expert panel; Expert 12 is an internal expert.

l Wrong question - ability of each of these may vary depending on training, skill, and experience. Eg. some nurse practitioners are better at diagnosis than some otolaryngologists-but one would not generalize from this.

m real issue is ‘child cooperation or anxiety’

n audiologist