# Appendix B. Scope for Key Questions and Voting Options for Technical Experts

Domain | Key Question 1: Natural History | Key Questions 2 and 3: Speech/Language/Hearing | Key Question 4: Diagnostic Methods
Disease Entity | Type of OME (self-identified but note diagnostic method); - OME after AOM; - newly diagnosed OME, unknown duration; - established OME, duration weeks or months; - bilateral OME, duration 3 months of longer | All types of OME and unspecified OM as long as MEE is present | All type of OME and unspecified OM as long as MEE is present
| Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows:
Patient Population | Age at diagnosis: 0–3 years old | Age at diagnosis: 0–3 years old | Age: 0–3 years
| Age at followup: through 12 years | Age at followup: through 8 years
| Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows:
Setting | Provider type: all | Provider type: all | Provider type: all
| Time period: 1966 forward | Time period: 1966 forward | Time period: 1966 forward
| Practice setting: all | Practice setting: all | Practice setting: all
| Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows:
Exclusion factors | None | None | None
| Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows:
Intervention | - Natural history; - No treatment/no intervention/placebo | - Treated versus not treated; - With or without antibiotics; - With or without tympanostomy tubes; - With or without adenoidectomy; - With or without tonsillectomy; - With or without myringotomy | Not applicable
| Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows:
Diagnostic Methods | Not applicable | Not applicable | - Signs/symptoms; - Non-pneumatic otoscopy; - Pneumatic otoscopy; - Binocular micro-tympanoscopy; - Portable tympanometer; - Professional tympanometer; - Quantitative tympanometry; - Acoustic reflectometry; - Otoacoustic emissions; - Audiometry
| | | Accept as written?; - abstain; - yes; - no, revise as follows:
Gold Standard | Not applicable | Not applicable | - Tympanocentesis only; - MRI only; - Tympanocentesis or MRI
| | | Accept as written?; - abstain; - yes; - no, revise as follows:
Non-treatment factors Influencing outcomes for Key Questions 1, 2, and 3 | Demographic; - age of child; - ethnicity/Race, Eskimo or Native American; - socioeconomic status | Demographic; - age of child; - ethnicity/Race, Eskimo or Native American; - socioeconomic status | Demographic; - age of child; - ethnicity/Race, Eskimo or Native American; - socioeconomic status
OR
| Environmental; - attendance at day care center; - tobacco smoke exposure; - season of the year | Environmental; - attendance at day care center; - tobacco smoke exposure; - season of the year | Environmental; - attendance at day care center; - tobacco smoke exposure; - not breast fed
Non-condition factors Influencing diagnostic performance for Key Question 4
| Symptoms/Signs; - laterality, unilateral versus bilateral; - hearing level | Symptoms/Signs; - laterality, unilateral versus bilateral; - hearing level | Symptoms/Signs; - laterality, unilateral versus bilateral; - hearing level
| Other clinical factors; - duration of OME prior to intervention; - otitis prone^1^; - previous OME; - early onset of previous OME; - craniofacial anomaly; - immunodeficiency; - genetic syndrome | Other clinical factors; - duration of OME prior to intervention; - otitis prone^1^; - previous OME; - early onset of previous OME; - craniofacial anomaly; - immunodeficiency; - genetic syndrome | Other clinical factors; - allergies; - inhalational general anesthetic; - duration of OME prior to intervention; - otitis prone^1^; - previous OME; - early onset of previous OME; - craniofacial anomaly; - immunodeficiency; - genetic syndrome; - adenoid hyperplasia
| Parent/caretaker; - parent/caretaker availability; - parent/caretaker preference; - parent/caretaker education | Parent/caretaker; - parent/caretaker availability; - parent/caretaker preference; - parent/caretaker education
| Examiner; - Type of examiner (family physician, otolaryngologist, pediatrician, nurse practitioner, physician assistant, etc.); - Skill to diagnose (validated examiner/observer); - Setting (Public, private, PPO, HMO, etc) | Examiner; - Type of examiner (family physician, otolaryngologist, pediatrician, nurse practitioner, physician assistant, etc.); - Skill to diagnose (validated examiner/observer); - Setting (Public, private, PPO, HMO, etc) | Examiner; - Type of examiner (family physician, otolaryngologist, pediatrician, nurse practitioner, physician assistant, etc.); - Skill to diagnose (validated examiner/observer); - Setting (Public, private, PPO, HMO, etc)
| Monitoring during episode or course of therapy; - When; - Frequency; - Primary person (parent or provider); - Type (tympanometry, acoustic reflectometry, pneumatic otoscopy) | Monitoring during episode or course of therapy; - When; - Frequency; - Primary person (parent or provider); - Type (tympanometry, acoustic reflectometry, pneumatic otoscopy)
| Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows:
Outcome Measures | - Partial OME resolution; - Complete OME resolution; - Relapse; - Recurrence | - Hearing levels; - Speech; - Language | - Sensitivity; - Specificity; - Positive predictive value; - Negative predictive value
| Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows:
Literature Source | - MEDLINE; - EMBASE; - Cochrane Library; - References from reference lists; - References from Technical Expert Panel and Peer Reviewers | - MEDLINE; - EMBASE; - Cochrane Library; - References from reference lists; - References from Technical Expert Panel and Peer Reviewers | - MEDLINE; - EMBASE; - Cochrane Library; - References from reference lists; - References from Technical Expert Panel and Peer Reviewers
| Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows:
Language | - English language exclusively | - English language exclusively | - English language exclusively
| Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows:
Study Design | - Randomized Controlled Trials, blinded and unblended; - Non-randomized Controlled Trials, blinded and unblended; - Prospective Cohort Studies; - Retrospective Cohort Studies | - Randomized Controlled Trials, blinded and unblended; - Non-randomized Controlled Trials, blinded and unblended; - Prospective Cohort Studies; - Retrospective Cohort Studies; - Case-Control Studies | - Diagnostic Studies
| Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows:
Wording of Key Questions (see Causal Pathways) | Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows: | Accept as written?; - abstain; - yes; - no, revise as follows:
Key words for literature search
Other items for consideration/ Specific references/studies