# Appendixes

Appendix A. The 20 Suggested Questions on Diagnosis and Treatment of Otitis Media with Effusion (OME)

Appendix B. Scope for Key Questions and Voting Options for Technical Experts

Appendix C. Technical Expert Panel Comments on Scope

Appendix D. Final Version of Scope

Appendix E. Questionnaire for Polling Experts' Opinion on Influence of Non-Condition Factors on Outcomes

Appendix F. Experts' Opinion on Influence of Non-Condition Factors on Outcomes

Appendix G. Literature Search Strategy

Appendix H. OME Screening Form Instructions

Appendix I. Peer Review Comments and Responses [Editorial comments were excluded]