# Bibliography

Reference list is bibliography.