# References

Skin tests used in type I allergy testing Position paper Sub-Committee on Skin Tests of the European Academy of Allergology and Clinical Immunology [Review] [290 refs] Allergy 1989 44Suppl 10:1 59
Corrected abstracts: American Academy of Allergy, Asthma and Immunology 56th annual meeting J Allergy Clin Immunol 2000 Mar 105(3):593 648 10766570
Aberg N Asthma and allergic rhinitis in Swedish conscripts Clin Exp Allergy 1989 Jan 19(1)59 63 2784709
Aberg N, Hesselmar B, Aberg B et al Increase of asthma, allergic rhinitis and eczema in Swedish schoolchildren between 1979 and 1991. [see comments] Clin Exp Allergy 1995 Sep 25(9)815 9 8564719
Adelroth E, Rak S, Haahtela T et al Recombinant humanized mAb-E25, an anti-IgE mAb, in birch pollen-induced seasonal allergic rhinitis J Allergy Clin Immunol 2000 Aug 106(2)253 9 10932067
Adkinson NF, Jr Immunotherapy for allergic rhinitis. [letter; comment] N Engl J Med 1999 Aug 12 341(7)522 4
Allen DB Systemic effects of intranasal steroids: an endocrinologist's perspective. [Review] [55 refs] J Allergy Clin Immunol 2000 Oct 106(4 Suppl):S179 S190 11032642
Anderson HR, Pottier AC, Strachan DP Asthma from birth to age 23: incidence and relation to prior and concurrent atopic disease Thorax 1992 Jul 47(7)537 42 1412098
Anderson WV, Marshall NE, Clark MC A double-blind controlled trial of disodium cromoglycate in seasonal allergic rhinitis Practitioner 1972 May 208(247)676 9 4627165
Arlian LG, Platts-Mills TA The biology of dust mites and the remediation of mite allergens in allergic disease. [Review] [96 refs] J Allergy Clin Immunol 2001 Mar 107(3 Suppl):S406 S413 11242601
Backhouse CI, Finnamore VP, Gosden CW Treatment of seasonal allergic rhinitis with flunisolide and terfenadine J Int Med Res 1986 14(1)35 41 3082694
Backhouse CI, Rosenberg R Prophylaxis of whole season hay fever symptomatology: a comparison of terfenadine with chlorpheniramine Br J Clin Pract 1987 Nov 41(11)995 9 2904272
Backman A, Holopainen E, Salo OP Sodium cromoglycate in chronic allergic rhinitis Acta Allergologica 1977Suppl 13:55 9
Balle V, Illum P Disodium cromoglycate nasal spray in the treatment of perennial rhinitis Acta Otolaryngol 1977 Sep 84(3-4):287 91 410230
Banov CH, Lieberman P, Vasomotor Rhinitis Study Groups Efficacy of azelastine nasal spray in the treatment of vasomotor (perennial nonallergic) rhinitis Ann Allergy Asthma Immunol 2001 Jan 86(1)28 35 11206234
Beckman DB, Grammer LC Pharmacotherapy to prevent the complications of allergic rhinitis. [Review] [81 refs] Allergy Asthma Proc 1999 Jul 20(4)215 23 10476319
Bellanti JA, Wallerstedt DB Allergic rhinitis update: Epidemiology and natural history. [Review] [18 refs] Allergy Asthma Proc 2000 Nov 21(6)367 70 11191103
Bende M, Rundcrantz H Treatment of perennial secretory rhinitis ORL J Otorhinolaryngol Relat Spec 1985 47(6)303 6 2934671
Bernstein DI, Creticos PS, Busse WW et al Comparison of triamcinolone acetonide nasal inhaler with astemizole in the treatment of ragweed-induced allergic rhinitis J Allergy Clin Immunol 1996 Mar 97(3)749 55 8613630
Blair H Natural history of childhood asthma. 20-year follow-up Archives of Disease in Childhood 1977 Aug 52(8)613 9 921306
Blair H, Herbert RL Treatment of seasonal allergic rhinitis with 2 percent sodium cromoglycate (BP) solution Clin Allergy 1973 Sep 3(3)283 8 4149729
Blair H, Viner AS A double blind trial of a 2% solution of sodium cromoglycate in perennial rhinitis Clin Allergy 1975 Jun 5(2)139 43 806396
Borish LC, Nelson HS, Corren J et al Efficacy of soluble IL-4 receptor for the treatment of adults with asthma J Allergy Clin Immunol 2001 Jun 107(6)963 70 11398072
Borum P, Larsen FS Seasonal allergic rhinitis treated with a beta-2-adrenostimulant Allergy 1987 Feb 42(2)141 5 3035960
Bousquet J, Lockey R, Malling HJ. Allergen immunotherapy: therapeutic vaccines for allergic diseases. A WHO position paper. [Review] [58 refs]. J Allergy Clin Immunol. (4 Pt 1). 1998 Oct;102:558-62. [pmid: 9802362].
Bousquet J, Lockey R, Malling H WHO Position Paper. Allergen Immunotherapy: Therapeutic Vaccines for allergic diseases Allergy 1998 53(suppl 54).
Bradley CM, Nicholson AN Studies on the central effects of the H1-antagonist, loratadine Eur J Clin Pharmacol 1987 32(4)419 21 2886343
Brain DJ, Singh KP, Trotter CM et al Sodium cromoglycate 2 per cent solution in perennial rhinitis: a clinical and histological study J Laryngol Otol 1974 Oct 88(10)1001 17 4220041
Brogden RN, Speight TM, Avery GS Sodium cromoglycate (cromolyn sodium). II. Allergic rhinitis and other conditions. [Review] [31 refs] Drugs 1974 7(3)283 96 4153068
Broms P, Malm L Oral vasoconstrictors in perennial non-allergic rhinitis Allergy 1982 Feb 37(2)67 74 7137522
Bronsky EA, Dockhorn RJ, Meltzer EO et al Fluticasone propionate aqueous nasal spray compared with terfenadine tablets in the treatment of seasonal allergic rhinitis J Allergy Clin Immunol 1996 Apr 97(4)915 21 8655886
Bronsky EA, Druce H, Findlay SR et al. A clinical trial of ipratropium bromide nasal spray in patients with perennial nonallergic rhinitis. J Allergy Clin Immunol. (5 Pt 2). 1995 May;95:1117-22. [pmid: 7751528].
Brostoff J, Lockhart JD Controlled trial of terfenadine and chlorpheniramine maleate in perennial rhinitis Postgrad Med J 1982 Jul 58(681)422 3 6126871
Bryan SA, O'Connor BJ, Matti S et al Effects of recombinant human interleukin-12 on eosinophils, airway hyper-responsiveness, and the late asthmatic response. [see comments] Lancet 2000 Dec 23 356(9248)2149 53
Buckley CE, Buchman E, Falliers CJ et al Terfenadine treatment of fall hay fever Ann Allergy 1988 Feb 60(2)123 8 3124674
Chapman MD, Wood RA The role and remediation of animal allergens in allergic diseases. [Review] [92 refs] J Allergy Clin Immunol 2001 Mar 107(3 Suppl):S414 S421 11242602
Coffman DA A controlled trial of disodium cromoglycate in seasonal allergic rhinitis Br J Clin Pract 1971 Sep 25(9)403 6 4398799
Collins JG Prevalence of selected chronic conditions: United States, 1990-1992 Vital Health Stat 10 1997 Jan(194):1 89
Condemi J, Schulz R, Lim J Triamcinolone acetonide aqueous nasal spray versus loratadine in seasonal allergic rhinitis: efficacy and quality of life Ann Allergy Asthma Immunol 2000 May 84(5)533 8 10831008
Corren J. Allergic rhinitis: treating the adult. [Review] [45 refs]. J Allergy Clin Immunol. (6 Pt 2). 2000 Jun;105:S610-S615. [pmid: 10856166].
Corren J. Intranasal corticosteroids for allergic rhinitis: how do different agents compare?. [Review] [43 refs]. J Allergy Clin Immunol. (4 Pt 1). 1999 Oct;104:S144-S149. [pmid: 10518811].
Corren J, Harris AG, Aaronson D et al. Efficacy and safety of loratadine plus pseudoephedrine in patients with seasonal allergic rhinitis and mild asthma [published erratum appears in J Allergy Clin Immunol 1998 Jun;101(6 Pt 1):792]. J Allergy Clin Immunol. (6 Pt 1). 1997 Dec;100:781-8. [pmid: 9438487].
D'Ambrosio FP, Gangemi S, Merendino RA et al Comparative study between fluticasone propionate and cetirizine in the treatment of allergic rhinitis [published erratum appears in Allergol Immunopathol (Madr) 1999 May-Jun;27(3):173] Allergol Immunopathol (Madr) 1998 Nov 26(6)277 82 9934406
Darnell R, Pecoud A, Richards DH A double-blind comparison of fluticasone propionate aqueous nasal spray, terfenadine tablets and placebo in the treatment of patients with seasonal allergic rhinitis to grass pollen Clin Exp Allergy 1994 Dec 24(12)1144 50 7889428
Demoly P, Michel F, and Bousquet J. In vivo methods for study of allergy. Skin tests, techniques and interpretation. In: Middleton E, Reed C, Ellis Eet al., editors. Allergy, Principles and Practice. St. Louis: Mosby Co. 1998:p. 530-9.
Druce HM, Spector SL, Fireman P et al Double-blind study of intranasal ipratropium bromide in nonallergic perennial rhinitis Ann Allergy 1992 Jul 69(1)53 60 1385682
Druce HM, Thoden WR, Mure P et al Brompheniramine, loratadine, and placebo in allergic rhinitis: a placebo-controlled comparative clinical trial J Clin Pharmacol 1998 Apr 38(4)382 9 9590467
Druce HM, Wright RH, Kossoff D et al Cholinergic nasal hyperreactivity in atopic subjects J Allergy Clin Immunol 1985 Sep 76(3)445 52 4031317
Durham SR, Walker SM, Varga EM et al Long-term clinical efficacy of grass-pollen immunotherapy [see comments] N Engl J Med 1999 Aug 12 341(7)468 75
Dykewicz MS, Fineman S, Skoner DP et al. Diagnosis and management of rhinitis: complete guidelines of the Joint Task Force on Practice Parameters in Allergy, Asthma and Immunology. American Academy of Allergy, Asthma, and Immunology. Ann Allergy Asthma Immunol. (5 Pt 2). 1998 Nov;81:478-518. [pmid: 9860027].
Engstrom I, Oberger E, Blyckert A et al Disodium cromoglycate in the treatment of seasonal allergic rhinoconjunctivitis in children Ann Allergy 1971 Oct 29(10)505 9 4999756
Fagerberg E, Zetterstrom O A trial of disodium cromoglycate in perennial rhinitis Acta Allergologica 1975 Jul 30(2-3):63 72 808082
Falliers CJ, Brandon ML, Buchman E et al Double-blind comparison of cetirizine and placebo in the treatment of seasonal rhinitis Ann Allergy 1991 Mar 66(3)257 62 1672494
Fireman P. Therapeutic approaches to allergic rhinitis: treating the child. [Review] [24 refs]. J Allergy Clin Immunol. (6 Pt 2). 2000 Jun;105:S616-S621. [pmid: 10856167].
Fleming DM, Crombie DL Prevalence of asthma and hay fever in England and Wales Br Med J (Clin Res Ed) 1987 Jan 31 294(6567)279 83
Frew AJ, Plummeridge MJ Alternative agents in asthma. [Review] [82 refs] J Allergy Clin Immunol 2001 Jul 108(1)3 10 11447376
Frostad AB The treatment of seasonal allergic rhinitis with a 2% aqueous solution of sodium cromoglycate delivered by a metered dose nasal spray Clin Allergy 1977 Jul 7(4)347 53 412610
Gastpar H, Dieterich HA Comparative study of the efficacy and tolerance of terfenadine and clemastine in patients with seasonal allergic rhinitis Arzneimittelforschung 1982 32(9a):1211 3 6129872
Gehanno P, Deschamps E, Garay E et al Vasomotor rhinitis: clinical efficacy of azelastine nasal spray in comparison with placebo ORL J Otorhinolaryngol Relat Spec 2001 Mar 63(2)76 81 11244365
Gehanno P, Desfougeres JL Fluticasone propionate aqueous nasal spray compared with oral loratadine in patients with seasonal allergic rhinitis Allergy 1997 Apr 52(4)445 50 9188929
Georgitis JW Nasal atropine sulfate: efficacy and safety of 0.050% and 0.075% solutions for severe rhinorrhea Arch Otolaryngol Head Neck Surg 1998 Aug 124(8)916 20 9708720
Georgitis JW, Banov C, Boggs PB et al Ipratropium bromide nasal spray in non-allergic rhinitis: efficacy, nasal cytological response and patient evaluation on quality of life Clin Exp Allergy 1994 Nov 24(11)1049 55 7874603
Girard JP, Bertrand J Study of 2% solution of sodium cromoglycate in perennial rhinitis assessed by subjective and objective parameters Clin Allergy 1975 Sep 5(3)301 9 810269
Graf P, Enerdal J, Hallen H Ten days' use of oxymetazoline nasal spray with or without benzalkonium chloride in patients with vasomotor rhinitis Arch Otolaryngol Head Neck Surg 1999 Oct 125(10)1128 32 10522506
Grant JA, Nicodemus CF, Findlay SR et al. Cetirizine in patients with seasonal rhinitis and concomitant asthma: prospective, randomized, placebo-controlled trial [see comments]. J Allergy Clin Immunol. (5 Pt 1). 1995 May;95:923-32. [pmid: 7751511].
Green M Double-blind study of nasal decongestion with oxymetazoline and phenylephrine in asthmatic children with rhinitis Rev Allergy 1966 Sep 20(9)863 8 4162601
Grossman J, Banov C, Boggs P et al. Use of ipratropium bromide nasal spray in chronic treatment of nonallergic perennial rhinitis, alone and in combination with other perennial rhinitis medications. J Allergy Clin Immunol. (5 Pt 2). 1995 May;95:1123-7. [pmid: 7538520].
Gundel RH, Wegner CD, Letts LG Adhesion molecules in a primate model of allergic asthma: clinical implications for respiratory care. [Review] [75 refs] Springer Semin Immunopathol 1993 15(1)75 88 8362345
Gutkowski A, Del Carpio J, Gelinas B et al Comparative study of the efficacy, tolerance and side-effects of dexchlorpheniramine maleate 6 mg b.i.d. with terfenadine 60 mg b.i.d J Int Med Res 1985 13(5)284 8 3932106
Handelman NI, Friday GA, Schwartz HJ et al Cromolyn sodium nasal solution in the prophylactic treatment of pollen-induced seasonal allergic rhinitis J Allergy Clin Immunol 1977 Mar 59(3)237 42 402406
Hasegawa M, Saito Y, Watanabe K The effect of sodium cromoglycate on the antigen-induced nasal reaction in allergic rhinitis as measured by rhinomanometry and symptomatology Clin Allergy 1976 Jul 6(4)359 63 822964
Henderson LL, Swedlund HA, Van Dellen RG et al Evaluation of IgE tests in an allergy practice J Allergy Clin Immunol 1971 Dec 48(6)361 5 4157465
Hetherington HD Hay fever in a student population. A trial of disodium cromoglycate Med J Aust 1973 Mar 10 1(10)493 4 4633689
Hilberg O Effect of terfenadine and budesonide on nasal symptoms, olfaction, and nasal airway patency following allergen challenge Allergy 1995 Aug 50(8)683 8 7503405
Hindmarch I, Shamsi Z Antihistamines: models to assess sedative properties, assessment of sedation, safety and other side-effects. [Review] [42 refs] Clin Exp Allergy 1999 Jul 29Suppl 3:133 42
Holopainen E, Backman A, Salo OP Effect of disodium cromoglycate on seasonal allergic rhinitis Lancet 1971 Jan 9 1(7689)55 7
Holopainen E, Viner T, Backman A et al Clinical trial of a two per cent solution of DSCG in perennial rhinitis Acta Allergologica 1975 Oct 30(4)216 26 812328
Hopper I, Dawson JP The effect of disodium cromoglycate in perennial rhinitis J Laryngol Otol 1972 Jul 86(7)725 30 4625581
Hopper JL, Jenkins MA, Carlin JB et al Increase in the self-reported prevalence of asthma and hay fever in adults over the last generation: a matched parent-offspring study Aust J Public Health 1995 Apr 19(2)120 4 7786934
Howarth PH Allergic rhinitis: a rational choice of treatment. [Review] [90 refs] Respir Med 1989 May 83(3)179 88 2574486
Howarth PH. Leukotrienes in rhinitis. [Review] [50 refs]. Am J Respir Crit Care Med. (2 Pt 2). 2000 Feb;161:S133-S136. [pmid: 10673242].
Hugonot L, Hugonot R, Beaumont D A double-blind comparison of terfenadine and mequitazine in the symptomatic treatment of acute pollinosis J Int Med Res 1986 14(3)124 30 3087801
Illum P, Meistrup-Larsen U, Moesner J et al Disodium cromoglycate (Lomudal) in the treatment of hay fever Acta Allergologica 1973 Dec 28(5)416 24 4150611
Ingels K, Durdurez JP, Cuvelier C et al Nasal biopsy is superior to nasal smear for finding eosinophils in nonallergic rhinitis Allergy 1997 Mar 52(3)338 41 9140527
Ioannidis JP, Lau J Can quality of clinical trials and meta-analyses be quantified? [letter; comment] Lancet 1998 Aug 22 352(9128)590 1
Jen A, Baroody F, de Tineo M et al As-needed use of fluticasone propionate nasal spray reduces symptoms of seasonal allergic rhinitis J Allergy Clin Immunol 2000 Apr 105(4)732 8 10756223
Jenssen AO Measurement of resistance to air flow in the nose in a trial with sodium cromoglycate (BP)solution in allergen-induced nasal stenosis Clin Allergy 1973 Sep 3(3)277 82 4204881
Jessen M, Bylander A Treatment of non-allergic nasal hypersecretion with ipratropium and beclomethasone Rhinology 1990 Jun 28(2)77 81 2143592
Johansen LV, Bjerrum P, Illum P Treatment of seasonal allergic rhinitis--a double blind, group comparative study of terfenadine and dexchlorpheniramine Rhinology 1987 Mar 25(1)35 40 2883715
Jokinen K, Sipila P Intranasal ipratropium in the treatment of vasomotor rhinitis Rhinology 1983 Dec 21(4)341 5 6229864
Jones AS Non-allergic perennial rhinitis. [Review] [56 refs] Biomed Pharmacother 1988 42(8)499 503 3066410
Jordana G, Dolovich J, Briscoe MP et al Intranasal fluticasone propionate versus loratadine in the treatment of adolescent patients with seasonal allergic rhinitis J Allergy Clin Immunol 1996 Feb 97(2)588 95 8621843
Juni P, Witschi A, Bloch R et al The hazards of scoring the quality of clinical trials for meta-analysis. [see comments] JAMA 1999 Sep 15 282(11)1054 60
Juniper EF, Guyatt GH, Ferrie PJ et al First-line treatment of seasonal (ragweed) rhinoconjunctivitis. A randomized management trial comparing a nasal steroid spray and a nonsedating antihistamine [see comments] CMAJ 1997 Apr 15 156(8)1123 31
Juniper EF, Kline PA, Hargreave FE et al Comparison of beclomethasone dipropionate aqueous nasal spray, astemizole, and the combination in the prophylactic treatment of ragweed pollen-induced rhinoconjunctivitis J Allergy Clin Immunol 1989 Mar 83(3)627 33 2494249
Kay AB Overview of 'allergy and allergic diseases: with a view to the future'. [Review] [105 refs] Br Med Bull 2000 56(4)843 64 11359624
Kay AB Allergy and allergic diseases. First of two parts. [Review] [62 refs] N Engl J Med 2001 Jan 4 344(1)30 7 11136958
Kay AB Allergy and allergic diseases. Second of two parts. [Review] [95 refs] N Engl J Med 2001 Jan 11 344(2)109 13 11150362
Kay GG. The effects of antihistamines on cognition and performance. [Review] [9 refs]. J Allergy Clin Immunol. (6 Pt 2). 2000 Jun;105:S622-S627. [pmid: 10856168].
Kirkegaard J, Mygind N, Molgaard F et al Ordinary and high-dose ipratropium in perennial nonallergic rhinitis J Allergy Clin Immunol 1987 Apr 79(4)585 90 2951426
Kirkegaard J, Mygind N, Molgaard F et al. Ipratropium treatment of rhinorrhea in perennial nonallergic rhinitis. A Nordic multicenter study. Acta Otolaryngol Suppl. 1988;449:93-5. [pmid: 2974229].
Knight A, Underdown BJ, Demanuele F et al Disodium cromoglycate in ragweed-allergic rhinitis J Allergy Clin Immunol 1976 Aug 58(2)278 83 7585
Lau J, Ioannidis JP, Schmid CH Quantitative synthesis in systematic reviews Ann Intern Med 1997 Nov 1 127(9)820 6
Leckie MJ, ten Brinke A, Khan J et al Effects of an interleukin-5 blocking monoclonal antibody on eosinophils, airway hyper-responsiveness, and the late asthmatic response. [see comments] Lancet 2000 Dec 23 356(9248)2144 8
Leiferman KM, Yunginger JW, Larson JB et al The effect of immune milk as a treatment for ragweed pollinosis Ann Allergy 1975 Dec 35(6)367 71 1106262
Leone C, Teodoro C, Pelucchi A et al. Bronchial responsiveness and airway inflammation in patients with nonallergic rhinitis with eosinophilia syndrome. J Allergy Clin Immunol. (6 Pt 1). 1997 Dec;100:775-80. [pmid: 9438486].
Levit KR, Lazenby HC, Cowan CA et al National health expenditures, 1990 Health Care Financ Rev 1991 13(1)29 54
Lijmer JG, Mol BW, Heisterkamp S et al Empirical evidence of design-related bias in studies of diagnostic tests. [see comments]. [erratum appears in JAMA 2000 Apr 19;283(15):1963] JAMA 1999 Sep 15 282(11)1061 6
Lockey RF Adverse reactions associated with skin testing and immunotherapy. [Review] [11 refs] Allergy Proc 1995 Nov 16(6)293 6 8747313
Lofkvist T, Rundcrantz H, Svensson G Treatment of vasomotor rhinitis with intranasal disodium cromoglycate (SCG). Results from a double-blind cross-over study Acta Allergologica 1977 Feb 32(1)35 43 402781
Lohr KN, Carey TS Assessing "best evidence": issues in grading the quality of studies for systematic reviews. [Review] [36 refs] Joint Commission Journal on Quality Improvement 1999 Sep 25(9)470 9 10481816
Lund VJ Seasonal allergic rhinitis--a review of current therapy. [Review] [7 refs] Allergy 1996 51(28 Suppl):5 7 8651475
Malmberg H, Grahne B, Holopainen E et al Ipratropium (Atrovent) in the treatment of vasomotor rhinitis of elderly patients Clin Otolaryngol 1983 Aug 8(4)273 6 6228347
Malmberg H, Holopainen E, Grahne B et al Astemizole in the treatment of hay fever Allergy 1983 May 38(4)227 31 6408940
Manners B, Ezeoke A Serum IgE levels and the use of sodium cromoglycate (BP) in hay fever: a study of forty-six patients from a single general practice Clin Allergy 1973 Sep 3(3)311 8 4204882
McDowell MK, Spitz E Treatment of chronic perennial allergic rhinitis: a double-blind trial of cromolyn sodium Ann Allergy 1977 Sep 39(3)169 74 409315
McLeod RL, Mingo GG, Herczku C et al Combined histamine H1 and H3 receptor blockade produces nasal decongestion in an experimental model of nasal congestion Am J Rhinol 1999 Sep 13(5)391 9 10582118
McMenamin P Costs of hay fever in the United States in 1990. [see comments] Ann Allergy 1994 Jul 73(1)35 9 8030800
Meltzer EO. An overview of current pharmacotherapy in perennial rhinitis. [Review] [106 refs]. J Allergy Clin Immunol. (5 Pt 2). 1995 May;95:1097-110. [pmid: 7538519].
Meltzer EO Quality of life in adults and children with allergic rhinitis. [Review] [46 refs] J Allergy Clin Immunol 2001 Jul 108(1 Suppl):S45 S53 11449206
Meltzer EO Role for cysteinyl leukotriene receptor antagonist therapy in asthma and their potential role in allergic rhinitis based on the concept of "one linked airway disease". [Review] [81 refs] Ann Allergy Asthma Immunol 2000 Feb 84(2)176 85 10719774
Meltzer EO, Orgel HA, Bronsky EA et al Ipratropium bromide aqueous nasal spray for patients with perennial allergic rhinitis: a study of its effect on their symptoms, quality of life, and nasal cytology J Allergy Clin Immunol 1992 Aug 90(2)242 9 1386857
Moneret-Vautrin DA, Hsieh V, Wayoff M et al Nonallergic rhinitis with eosinophilia syndrome a precursor of the triad: nasal polyposis, intrinsic asthma, and intolerance to aspirin Ann Allergy 1990 Jun 64(6)513 8 2346237
Mosbech H, Osterballe O Does the effect of immunotherapy last after termination of treatment? Follow-up study in patients with grass pollen rhinitis Allergy 1988 Oct 43(7)523 9 3148282
Munch EP, Soborg M, Norreslet TT et al A comparative study of dexchlorpheniramine maleate sustained release tablets and budesonide nasal spray in seasonal allergic rhinitis Allergy 1983 Oct 38(7)517 24 6139040
Mygind N, Nielsen LP, Hoffmann HJ et al Mode of action of intranasal corticosteroids. [Review] [141 refs] J Allergy Clin Immunol 2001 Jul 108(1 Suppl):S16 S25 11449202
Mygind N, Dahl R, Bisgaard H Leukotrienes, leukotriene receptor antagonists, and rhinitis. [Review] [39 refs] Allergy 2000 May 55(5)421 4 10843421
Naclerio RM, Proud D, Moylan B et al A double-blind study of the discontinuation of ragweed immunotherapy J Allergy Clin Immunol 1997 Sep 100(3)293 300 9314339
Nelson BL, Jacobs RL Response of nonallergic rhinitis with eosinophilia (NARES) syndrome to 4% cromoly sodium nasal solution J Allergy Clin Immunol 1982 Aug 70(2)125 8 6808048
Nelson HS, Oppenheimer J, Buchmeier A et al An assessment of the role of intradermal skin testing in the diagnosis of clinically relevant allergy to timothy grass J Allergy Clin Immunol 1996 Jun 97(6)1193 201 8648012
Ng ML, Warlow RS, Chrishanthan N et al Preliminary criteria for the definition of allergic rhinitis: a systematic evaluation of clinical parameters in a disease cohort (I) Clin Exp Allergy 2000 Sep 30(9)1314 31 10971479
Nightingale CH Treating allergic rhinitis with second-generation antihistamines. [Review] [95 refs] Pharmacotherapy 1996 Sep 16(5)905 14 8888086
Nolen TM Sedative effects of antihistamines: safety, performance, learning, and quality of life. [see comments]. [Review] [63 refs] Clin Ther 1997 Jan 19(1)39 55 9083707
Ortolani C, Foresi A, Di Lorenzo G et al A double-blind, placebo-controlled comparison of treatment with fluticasone propionate and levocabastine in patients with seasonal allergic rhinitis. FLNCO2 Italian Study Group Allergy 1999 Nov 54(11)1173 80 10604553
Pastorello EA, Ortolani C, Gerosa S et al Antihistaminic treatment of allergic rhinitis: a double-blind study with terfenadine versus dexchlorpheniramine Pharmatherapeutica 1987 5(2)69 75 2889217
Pedersen PA, Weeke ER Asthma and allergic rhinitis in the same patients Allergy 1983 Jan 38(1)25 9 6837893
Pedersen S Assessing the effect of intranasal steroids on growth. [Review] [29 refs] J Allergy Clin Immunol 2001 Jul 108(1 Suppl):S40 S44 11449205
Posey WC, Nelson HS Controlled trials with four per cent cromolyn spray in seasonal allergic rhinitis Clin Allergy 1977 Sep 7(5)485 96 412612
Raphael GD, Baraniuk JN, Kaliner MA How and why the nose runs J Allergy Clin Immunol 1991 Feb 87(2)457 67 1993805
Ratner PH, van Bavel JH, Martin BG et al A comparison of the efficacy of fluticasone propionate aqueous nasal spray and loratadine, alone and in combination, for the treatment of seasonal allergic rhinitis J Fam Pract 1998 Aug 47(2)118 25 9722799
Reid MJ, Lockey RF, Turkeltaub PC et al Survey of fatalities from skin testing and immunotherapy 1985-1989 J Allergy Clin Immunol 1993 Jul 92(1 Pt 1):6 15 8335856
Renvall U, Lindqvist N A double-blind clinical study with Monydrin tablets in patients with non-allergic chronic rhinitis J Int Med Res 1979 7(3)235 9 378733
Rice DP, Hodgson TA, Kopstein AN The economic costs of illness: a replication and update Health Care Financ Rev 1985 7(1)61 80 10311399
Robinson AC, Cherry JR, Daly S Double-blind cross-over trial comparing beclomethasone dipropionate and terfenadine in perennial rhinitis Clin Exp Allergy 1989 Sep 19(5)569 73 2571403
Ross RN The costs of allergic rhinitis Am J Manag Care 1996 2(3)285 90
Ross RN, Nelson HS, Finegold I Effectiveness of specific immunotherapy in the treatment of allergic rhinitis: an analysis of randomized, prospective, single- or double-blind, placebo-controlled studies Clin Ther 2000 Mar 22(3)342 50 10963288
Scadding GK, Richards DH, Price MJ Patient and physician perspectives on the impact and management of perennial and seasonal allergic rhinitis Clin Otolaryngol 2000 Dec 25(6)551 7 11122298
Schenkel EJ, Skoner DP, Bronsky EA et al Absence of growth retardation in children with perennial allergic rhinitis after one year of treatment with mometasone furoate aqueous nasal spray Pediatrics 2000 Feb 105(2):
Schoenwetter W, Lim J Comparison of intranasal triamcinolone acetonide with oral loratadine for the treatment of patients with seasonal allergic rhinitis Clin Ther 1995 May 17(3)479 92 7585852
Settipane GA Allergic rhinitis--update Otolaryngology - Head & Neck Surgery 1986 Apr 94(4)470 5 3086809
Settipane RA, Lieberman P Update on nonallergic rhinitis. [Review] [93 refs] Ann Allergy Asthma Immunol 2001 May 86(5)494 507 11379801
Settipane RJ, Hagy GW, Settipane GA Long-term risk factors for developing asthma and allergic rhinitis: a 23-year follow-up study of college students. [Review] [11 refs] Allergy Proc 1994 Jan 15(1)21 5 8005452
Shaikh WA. Ephedrine-saline nasal wash in allergic rhinitis. J Allergy Clin Immunol. (5 Pt 1). 1995 Nov;96:597-600. [pmid: 7499675].
Shore L Disodium cromoglycate (Rynacrom) in the treatment of nasal allergy in children S Afr Med J 1972 Mar 11 46(11)279 81 4622925
Silberg WM, Lundberg GD, Musacchio RA Assessing, controlling, and assuring the quality of medical information on the Internet: Caveant lector et viewor--Let the reader and viewer beware. [see comments] JAMA 1997 Apr 16 277(15)1244 5
Sipila P, Sorri M, Pukander J Double-blind comparison of nedocromil sodium (1% nasal spray) and placebo in rhinitis caused by birch pollen Clin Otolaryngol 1987 Oct 12(5)365 70 2827920
Sjogren I, Jonsson L, Koling A et al The effect of ipratropium bromide on nasal hypersecretion induced by methacholine in patients with vasomotor rhinitis. A double-blind, cross-over, placebo-controlled and randomized dose-response study Acta Otolaryngol 1988 Nov 106(5-6):453 9 2974675
Skoner DP Allergic rhinitis: definition, epidemiology, pathophysiology, detection, and diagnosis. [Review] [39 refs] J Allergy Clin Immunol 2001 Jul 108(1 Suppl):S2 S8 11449200
Skoner DP, Rachelefsky GS, Meltzer EO et al Detection of growth suppression in children during treatment with intranasal beclomethasone dipropionate Pediatrics 2000 Feb 105(2):
Smith JM. Epidemiology and natural history of asthma, allergic rhinitis and atopic dermatitis (eczema). In: Middleton E, editors. Allergy: principles and practice. St. Louis: Mosby. 1983:p. 891-929.
Sorri M, Jokinen K, Palva A. Disodium chromoglycate therapy in perennial rhinitis. Acta Otolaryngol Suppl. 1979;360:30-2. [pmid: 110027].
Spector SL Overview of comorbid associations of allergic rhinitis. [Review] [95 refs] J Allergy Clin Immunol 1997 Feb 99(2):S773 S780 9042070
Sunderman J, Crawford WA Sodium cromoglycate in the treatment of chronic allergic rhinitis Med J Aust 1973 Jun 16 1(24)1189 90
Svensson G Topical treatment of seasonal allergic rhinitis with a beta-adrenoceptor stimulant (KWD 2131) Rhinology 1982 Sep 20(3)159 66 6127780
Svensson C, Greiff L, Andersson M et al Antiallergic actions of high topical doses of terbutaline in human nasal airways Allergy 1995 Nov 50(11)884 90 8748720
Svensson G, Hegardt B, Lofkvist T Effects of topical use of beta-adrenoceptor stimulants of nasal mucosa. Rhinomanometric evaluations in experiments with terbutaline and KWD 2131 Acta Otolaryngol 1980 Sep 90(3-4):297 303 6110308
Svensson G, Hegardt B, Lofkvist T Influence of a beta-adrenoceptor stimulant, KWD 2131, in nasal histamine provocation tests. Rhinomanometric evaluations in normal persons and patients with hay fever Acta Otolaryngol 1981 Nov 92(5-6):535 41 6171989
Tanner LA, Reilly M, Meltzer EO et al Effect of fexofenadine HCL on quality of life and work, classroom, and daily activity impairment in patients with seasonal allergic rhinitis Am J Manag Care 1999 Apr 5(4 Suppl):s235 s247
Thoden WR, Druce HM, Furey SA et al Brompheniramine maleate: a double-blind, placebo-controlled comparison with terfenadine for symptoms of allergic rhinitis Am J Rhinol 1998 Jul 12(4)293 9 9740926
Thompson AK, Juniper E, Meltzer EO Quality of life in patients with allergic rhinitis. [Review] [39 refs] Ann Allergy Asthma Immunol 2000 Nov 85(5)338 47 11101172
Thorne MG, Bradbeer WH Disodium chromoglycate in the treatment of perennial allergic rhinitis Acta Allergologica 1972 Sep 27(4)307 20 4630999
van Bavel J, Findlay SR, Hampel FC, Jr. et al Intranasal fluticasone propionate is more effective than terfenadine tablets for seasonal allergic rhinitis [published erratum appears in Arch Intern Med 1995 Feb 13;155(3):276] Arch Intern Med 1994 Dec 12 154(23)2699 704
van Cauwenberge P, Bachert C, Passalacqua G et al Consensus statement on the treatment of allergic rhinitis. European Academy of Allergology and Clinical Immunology Allergy 2000 Feb 55(2)116 34 10726726
van der Bijl WJ Report on a trial of SCG 2% nasal solution (metered dose) in hayfever Rhinology 1977 Jun 15(2)97 102 411165
Warland A, Kapstad B The effect of disodium cromoglycate in perennial allergic rhinitis. A controlled clinical study Acta Allergologica 1977 Jun 32(3)195 9 409052
Wegner CD, Gundel RH, Reilly P et al Intercellular adhesion molecule-1 (ICAM-1) in the pathogenesis of asthma Science 1990 Jan 26 247(4941)456 9
Weiler JM, Bloomfield JR, Woodworth GG et al Effects of fexofenadine, diphenhydramine, and alcohol on driving performance. A randomized, placebo-controlled trial in the Iowa driving simulator [see comments] Ann Intern Med 2000 Mar 7 132(5)354 63
Weiner JM, Abramson MJ, Puy RM Intranasal corticosteroids versus oral H1 receptor antagonists in allergic rhinitis: systematic review of randomised controlled trials Br Med J 1998 Dec 12 317(7173)1624 9
White MV. Muscarinic receptors in human airways. [Review] [36 refs]. J Allergy Clin Immunol. (5 Pt 2). 1995 May;95:1065-8. [pmid: 7751523].
Wight RG, Jones AS, Beckingham E et al A double blind comparison of intranasal budesonide 400 micrograms and 800 micrograms in perennial rhinitis Clin Otolaryngol 1992 Aug 17(4)354 8 1526057
Wilson II, Coombes JA Rynacrom (sodium cromoglycate) in intractable perennial rhinitis N Z Med J 1975 Oct 22 82(550)265 6
Wittig HJ, Belloit J, De F, I et al Age-related serum immunoglobulin E levels in healthy subjects and in patients with allergic disease J Allergy Clin Immunol 1980 Oct 66(4)305 13 7419833
Wood RA, Phipatanakul W, Hamilton RG et al A comparison of skin prick tests, intradermal skin tests, and RASTs in the diagnosis of cat allergy J Allergy Clin Immunol 1999 May 103(5 Pt 1):773 9 10329809
Wood SF Astemizole and terfenadine compared in hay fever Practitioner 1986 Jan 230(1411)41 4 2869481
Woodcock A, Custovic A Allergen avoidance: does it work?. [Review] [101 refs] Br Med Bull 2000 56(4)1071 86 11359638