# Appendix

## Evidence Report Staff, Technical Expert Advisory Group, and Peer Reviewers

### New England Medical Center EPC Project Staff

- EPC/Project Director
- Joseph Lau, MD

- Assistant Project Director
- Caroline McFadden, MD

- Primary Technical Expert
- Aidan Long, MD

- Project Manager
- Deirdre DeVine, M Litt

- Statistician
- Norma Terrin, PhD

- Research Associate
- Priscilla Chew, MPH

### EPC Technical Expert Panel

- Joseph Lau, MD
- Project Director
- Division of Clinical Care Research
- New England Medical Center
- Boston, Massachusetts

- Aidan Long, MD
- Primary Technical Expert
- Director of Allergy
- Massachusetts General Hospital
- Boston, MA

- Harry Handelsman, DO
- Medical Officer
- Center for Practice and Technology Assessment
- Agency for Healthcare Research and Quality
- Rockville, MD

- William Berger, MD, MBA
- American College of Allergy, Asthma and Immunology
- Mission Viejo Medical Center
- Mission Viejo, CA

- John W. Georgitis, MD, FAAAAI
- American Academy of Allergy, Asthma and Immunology
- Wake Forest University School of Medicine
- Winston-Salem, NC

- Barbara Yawn, MD, MSc
- American Academy of Family Physicians
- Olmsted Medical Center
- Rochester, MN

#### Peer Reviewers

The American Academy of Family Physicians, partner organization for the evidence report, nominated individuals to participate in the peer review of the report, as did the other organizations of the EPC Technical Expert Panel, the American College of Allergy, Asthma and Immunology, and the American Academy of Allergy, Asthma and Immunology.

We are grateful to the peer reviewers for generously offering their time and knowledge.

#### External Reviewers

- American Academy of Family Physicians
- Doug Campos-Outcalt, MD
- Stuart Stoloff, MD

- American College of Allergy, Asthma & Immunology
- Daniel Ein, MD
- Richard G. Gower, MD

- American Academy of Allergy, Asthma & Immunology
- Harold S. Nelson, MD, FAAAAI
- Michael J. Schumacher, MD
- FAAAAI