# List of Abbreviations and Acronyms Used in the Report and Evidence Tables

Abd C | Abdominal circumference
abn | Abnormal
ACOG | American College of Obstetricians and Gynecologists
AFI | Amniotic fluid index
AFV | Amniotic fluid volume
AHRQ | Agency for Healthcare Research and Quality
APT | Antepartum testing
ARD | Atad Ripener Device
AROM | Artificial rupture of the membranes
BP | Biophysical profile
bpm | Beats per minute
BPS | Biophysical profile score
BW | birthweight
cc | Cubic centimeter(s)
CDSR | Cochrane Database of Systematic Reviews
CE | Cost-effectiveness
CI | Confidence interval
cm | Centimeter
C-section | Cesarean section
CST | Contraction stress test
CTG | Cardiotocography
DARE | Database of Abstracts of Reviews of Effectiveness
EBW | Estimated birthweight
E:C | Estrogen-to-creatinine ratio
EFW | Estimated fetal weight
FB | Fetal breathing
FBM | Fetal breathing movements
fFN | Fetal fibronectin
FHR | Fetal heart rate
FM | Fetal movement
f/u | Followup
g | Gram(s)
GP | General practitioner
HCUP | Healthcare Cost and Utilization Project
HMO | Health maintenance organization
hr | Hour(s)
IQ | Interquartile
IU | International Units(s)
IUGR | Intrauterine growth retardation
kg | Kilogram(s)
LGA | Large for gestational age
LMP | Last menstrual period
MBP | Modified biophysical profile
MFM | Maternal and family medicine
µg | Microgram(s)
mg | Milligram
min | Minute(s)
mIU | Milli-Inerantional Unit(s)
ml | Milliliter(s)
mm | Millimeter(s)
mmHg | Millimeters of mercury
MPD | Maximum pool depth
mU | Milliunit(s)
NA | Not applicable
NCHS | National Center for Health Statistics
ng | Nanogram(s)
NICHD | National Institute of Child Health and Human Development
NICU | Neonatal intensive care unit
NIS | Nationwide Inpatient Sample
nl | Normal
No. | Number
NR | Not reported
NS | Nipple stimulation
NST | Nonstress test
OB/GYN | Obstetrician/gynecologist
OCP | Oral contraceptive pill
OCT | Oxytocin challenge test
OST | Oxytocin stress test
OR | Odds ratio
PGE_2_ | Prostaglandin E_2_(dinoprostone)
PROM | Premature rupture of the membranes
RCOG | Royal College of Obstetricians and Gynaecologists
RCT(s) | Randomized controlled trial(s)
ROC | Receiver operating characteristic
RR | Relative risk
SD | Standard deviation
S:D | Systolic-to-diastolic ratio
sec | Second(s)
SEM | Standard error of the mean
SGA | Small for gestational age
SROM | Spontaneous rupture of the membranes
U/S | Ultrasound
UTI | Urinary tract infection
vs. | Versus
wk | Week(s)