# Bibliography

Abotalib ZM, Soltlan MH, Chowdhury N, et al Obstetric outcome in uncomplicated prolonged pregnancy Int J Gynecol Obstet 1996 55(3):225 30
Acker DB, Sachs BP, Friedman EA Risk factors for shoulder dystocia Obstet Gynecol 1985 66(6):762 8 4069477
Ultrasonography in pregnancy. Technical Bulletin No. 187. 1993.
Induction of labor. Technical Bulletin No. 217. 1995.
Routine ultrasound in low-risk pregnancy. 1997. [pmcid: 176006].
Fetal macrosomia. ACOG Practice Bulletin No. 22. 2000.
Adair CD, Weeks JW, Barrilleaux PS, et al. Labor induction with oral versus vaginal misoprostol: A randomized, double-blind trial. Am J Obstet Gynecol. 1998;178.
Adetoro OO, Agah A The implications of childbearing in postpubertal girls in Sokoto, Nigeria Int J Gynaecol Obstet 1988 27(1):73 7 2905303
Agarwal N, Mathur T, Gupta N, et al Role of intra-amniotic instillation of betamethasone in prolonged pregnancy Indian J Med Res 1981 73(3):335 41 7275229
Ahlden S, Andersch B, Stigsson L, et al Prediction of sepsis neonatorum following a full-term pregnancy Gynecol Obstet Invest 1988 25(3):181 5 3391428
Ahmed AI, Versi E Prolonged pregnancy. [Review] Curr Opin Obstet Gynecol 1993 5(5):669 74 8241445
Al-Najashi SS, Al-Mulhim AA Prolongation of pregnancy in multiple pregnancy Int J Gynecol Obstet 1996 54(2):131 5
Alberico S, Fadalti M, Grimaldi E, et al Eligibility criteria for labor induction with prostaglandins Clin Exp Obstet Gynecol 1997 24(2):61 6 9342463
Alexander JM, McIntire DD, Leveno KJ Forty weeks and beyond: pregnancy outcomes by week of gestation Obstet Gynecol 2000 96(2):291 4 10908780
Alexander JM, Mcintire DD, Leveno KJ Prolonged pregnancy: induction of labor and cesarean births Obstet Gynecol 2001 97(6911-5).
Alfirevic Z, Howarth G, Gaussmann A. Oral misoprostol for induction of labor (Cochrane Review). In: The Cochrane Library, Issue 2, 2000. Oxford: Update Software.
Alfirevic Z, Luckas M, Walkinshaw SA, et al A randomised comparison between amniotic fluid index and maximum pool depth in the monitoring of post-term pregnancy Br J Obstet Gynaecol 1997 104(2):207 11 9070140
Alfirevic Z, Neilson JP. Biophysical profile for fetal assessment in high risk pregnancies (Cochrane Review). In: The Cochrane Library, Issue 2, 2001. Oxford: Update Software.
Alfirevic Z, Walkinshaw SA Management of post-term pregnancy: to induce or not? [Review] Br J Hosp Med 1994 52(5):218 21 7820319
Alfirevic Z, Walkinshaw SA A randomised controlled trial of simple compared with complex antenatal fetal monitoring after 42 weeks of gestation Br J Obstet Gynaecol 1995 102(8):638 43 7654642
Allott HA, Palmer CR Sweeping the membranes: A valid procedure in stimulating the onset of labour? Br J Obstet Gynaecol 1993 100(10):898 903 8217970
Almstrom H, Granstrom L, Ekman G Serial antenatal monitoring compared with labor induction in post-term pregnancies Acta Obstet Gynecol Scand 1995 74(8):599 603 7660763
Amano K, Saito K, Shoda T, et al Elective induction of labor at 39 weeks of gestation: A prospective randomized trial J Obstet Gynaecol Res 1999 25(1):33 7 10067011
Amiel-Tison C Cerebral handicap in full-term newborns related to late pregnancy and/or labor Eur J Obstet Gynecol Reprod Biol 1988 28(2):157 63 3402657
Anderson T Cochrane made simple. Routine ultrasound in early pregnancy Pract Midwife 1998 1(12):13 4 10214284
Anderson T Cochrane made simple. Post-term pregnancy Pract Midwife 1999 2(11):10 2
Anderson T Post-term pregnancy. [Review] Pract Midwife 1999 2(11):10 2
Anonymous. Task force on cerebral palsy and neonatal asphyxia. In: The Society of Obstetricians and Gynaecologists of Canada: Policy Statement, Committee Opinion, Clinical Practice Guidelines. Ottawa, ON : SOGC, 1996. 72 P.
Anonymous Prolonged pregnancy: the management debate BMJ 1988 297(6650):715 7 3147736 1834111
Anonymous Induction and augmentation of labor: ACOG Technical bulletin number 157 (replaces No. 110, November 1987) Int J Gynecol Obstet 1992 39(2):139 42
Anonymous The management of postpartum haemorrhage Drug Ther Bull 1992 30(23):89 92 1446579
Anonymous Post-term induction: don't kill the messenger Lancet 1992 340(8823):
Anonymous Postterm pregnancy Int J Gynecol Obstet 1996 53(1):89 90
Anonymous ACOG practice patterns. Management of postterm pregnancy. Number 6, October 1997. American College of Obstetricians and Gynecologists Int J Gynaecol Obstet 1997 60(1):86 91
Anonymous Managing post-term pregnancy. [Review] Drug Ther Bull 1997 35(3):17 8 9282415
Anonymous Electronic fetal heart rate monitoring: research guidelines for interpretation. The National Institute of Child Health and Human Development Research Planning Workshop J Obstet Gynecol Neonat Nurs 1997 26(6):635 40
Apgar J, Everett GA, Fitzgerald JA Dietary zinc deprivation affects parturition and outcome of pregnancy in the ewe Nutr Res 1993 13(3):319 30
Arabin B, Becker R, Mohnhaupt A, et al Prediction of fetal distress and poor outcome in prolonged pregnancy using Doppler ultrasound and fetal heart rate monitoring combined with stress tests (II) Fetal Diagn Ther 1994 9(1):1 6 8142046
Arabin B, Snyjders R, Mohnhaupt A, et al Evaluation of the fetal assessment score in pregnancies at risk for intrauterine hypoxia Am J Obstet Gynecol 1993 169(3):549 54 8372860
Arias F Predictability of complications associated with prolongation of pregnancy Obstet Gynecol 1987 70(1):101 6 3299174
Ariceta JM, Matorras R, Diez J, et al Sequential vacuum extractor and forceps delivery J Obstet Gynaecol 1994 14(5):312 16
Arntzen KJ, Brekke O-L, Vatten L, et al Reduced production of PGEinf 2 and PGF(2alpha) from decidual cell cultures supplemented with N-3 polyunsaturated fatty acids Prostaglandins Other Lipid Mediat 1998 56(2-3):183 95 9785387
Arrowsmith S, Hamlin EC, Wall LL Obstructed labor injury complex: Obstetric fistula formation and the multifaceted morbidity of maternal birth trauma in the developing world Obstet Gynecol Surv 1996 51(9):568 74 8873157
Atad J, Hallak M, Auslender R, et al A randomized comparison of prostaglandin E2, oxytocin, and the double-balloon device in inducing labor Obstet Gynecol 1996 87(2):223 7 8559528
Augensen K, Bergsjø P, Eikeland T, et al Randomised comparison of early versus late induction of labour in post-term pregnancy BMJ 1987 294(6581):1192 5 3109575 1246355
Ayres-de-Campos D, Bernardes J, Costa-Pereira A, et al Inconsistencies in classification by experts of cardiotocograms and subsequent clinical decision Br J Obstet Gynaecol 1999 106(12):1307 10 10609727
Babinszki A, Kerenyi T, Torok O, et al Perinatal outcome in grand and great-grand multiparity: effects of parity on obstetric risk factors Am J Obstet Gynecol 1999 181(3):669 74 10486482
Bailey SM, Sarmandal P, Grant JM A comparison of three methods of assessing inter-observer variation applied to measurement of the symphysis-fundal height Br J Obstet Gynaecol 1989 96(11):1266 71 2611167
Baines DL, Folkesson HG, Norlin A, et al The influence of mode of delivery, hormonal status and postnatal Oinf 2 environment on epithelial sodium channel (ENaC) expression in perinatal guinea-pig lung J Physiol 2000 522(1):147 57 10618159
Bakimer R, Blank M, Kosashvilli D, et al Antiphospholipid syndrome and the idiotypic network Lupus 1995 4(3):204 8 7655490
Bakos O, Backstrom T Induction of labor: a prospective, randomized study into amniotomy and oxytocin as induction methods in a total unselected population Acta Obstet Gynecol Scand 1987 66(6):537 41 3321873
Barrett JF, Tyrrell S, Lilford RJ Prolonged pregnancy BMJ 1987 294(6563):56 7 3101801
Barss VA, Frigoletto FD, Diamond F Stillbirth after nonstress testing Obstet Gynecol 1985 65(4):541 4 3982728
Bartnicki J, Ratanasiri T, Meyenburg M, et al Postterm pregnancy: computer analysis of the antepartum fetal heart rate patterns Int J Gynaecol Obstet 1992 37(4):243 6 1350538
Barton DPJ, Robson MS, Turner MJ, et al Prolonged spontaneous labour in primigravidae whose labour was actively managed: Results of an audit J Obstet Gynaecol 1992 12(5):304 8
Baskett TF Gestational age and fetal biophysical assessment Am J Obstet Gynecol 1988 158(2):332 4 3341411
Baskett TF, Allen AC Perinatal implications of shoulder dystocia Obstet Gynecol 1995 86(1):14 7 7784010
Bastian H, Keirse MJ, Lancaster PA Perinatal death associated with planned home birth in Australia: population based study BMJ 1998 317(7155):384 8 28632 9694754
Battaglia C, Artini PG, Ballestri M, et al Hemodynamic, hematological and hemorrheological evaluation of post-term pregnancy Acta Obstet Gynecol Scand 1995 74(5):336 40 7778423
Battaglia C, Larocca E, Lanzani A, et al Doppler velocimetry in prolonged pregnancy Obstet Gynecol 1991 77(2):213 6 1988884
Beck I, Clayton JK Hazards of prostaglandin pessaries in postmaturity Lancet 1982 2(8290):
Belizan JM, Villar J, Nardin JC, et al Diagnosis of intrauterine growth retardation by a simple clinical method: measurement of uterine height Am J Obstet Gynecol 1978 131(6):643 6 686050
Bell RJ, Permezel M, MacLennan A, et al A randomized, double-blind, placebo-controlled trial of the safety of vaginal recombinant human relaxin for cervical ripening Obstet Gynecol 1993 82(3):328 33 8355929
Benacerraf BR, Frigoletto FD Fetal respiratory movements: only part of the biophysical profile Obstet Gynecol 1986 67(4):556 7 3960429
Benedetti TJ, Easterling T Antepartum testing in postterm pregnancy J Reprod Med 1988 33(3):252 8 3283352
Benifla JL, Goffinet F, Darai E, et al Emergency cervical cerclage after 20 weeks' gestation: A retrospective study of 6 years' practice in 34 cases Fetal Diagn Ther 1997 12(5):274 8 9430207
Bennett BB Uterine rupture during induction of labor at term with intravaginal misoprostol Obstet Gynecol 1997 89(5 Pt 2):832 3 9166339
Berghella V, Rogers RA, Lescale K Stripping of membranes as a safe method to reduce prolonged pregnancies Obstet Gynecol 1996 87(6):927 31 8649700
Bergsjo P, Bakketeig LS, Eikhom SN Case-control analysis of post-term induction of labor Acta Obstet Gynecol Scand 1982 61(4):317 24 7148405
Bergsjø P, Huang GD, Yu SQ, et al Comparison of induced versus non-induced labor in post-term pregnancy. A randomized prospective study Acta Obstet Gynecol Scand 1989 68(8):683 7 2698591
Bernardes J, Costa-Pereira A, Ayres-de-Campos D, et al Evaluation of interobserver agreement of cardiotocograms Int J Gynaecol Obstet 1997 57(1):33 7 9175667
Bernstein IM, Watson M, Simmons GM, et al Maternal brain death and prolonged fetal survival Obstet Gynecol 1989 74(3 II SUPPL.):434 7
Berzosa J, Martinez-Guisasola J, Guerrero M, et al Application of prostaglandin Einf 2 gel in post-term pregnancy (> 287 days) Clin Invest Ginecol Obstet 1996 23(3):101 5
Bishop EH. Pelvic scoring for elective induction. Obstet Gynecol. 1964;24:266-8. [pmid: 14199536].
Blakemore KJ, Qin NG, Petrie RH, et al A prospective comparison of hourly and quarter-hourly oxytocin dose increase intervals for the induction of labor at term Obstet Gynecol 1990 75(5):757 61 2325960
Blanchette HA, Nayak S, Erasmus S Comparison of the safety and efficacy of intravaginal misoprostol (prostaglandin E1) with those of dinoprostone (prostaglandin E2) for cervical ripening and induction of labor in a community hospital Am J Obstet Gynecol 1999 180(6 Pt 1):1551 9 10368503
Blanco JD, Collins M, Willis D, et al Prostaglandin E2 gel induction of patients with a prior low transverse cesarean section Am J Perinatol 1992 9(2):80 3 1590872
Bobby PD, Divon MY Fetal testing in postdates Curr Opin Obstet Gynecol 1997 9(2):79 82 9204226
Bobrowski RA, Bottoms SF Underappreciated risks of the elderly multipara Am J Obstet Gynecol 1995 172(6):1764 7 7778630
Bochner CJ, Medearis AL, Davis J, et al Antepartum predictors of fetal distress in postterm pregnancy Am J Obstet Gynecol 1987 157(2):353 8 3618684
Bochner CJ, Medearis AL, Ross MG, et al The role of antepartum testing in the management of postterm pregnancies with heavy meconium in early labor Obstet Gynecol 1987 69(6):903 7 3554066
Bochner CJ, Williams J 3d, Castro L, et al The efficacy of starting postterm antenatal testing at 41 weeks as compared with 42 weeks of gestational age Am J Obstet Gynecol 1988 159(3):550 4 3421252
Bors-Koefoed R, Zylstra S, Resseguie LJ, et al A cost analysis of ambulatory antenatal testing in a tertiary care center J Matern Fetal Invest 1993 2(1):5 9
Boulvain M, Fraser WD, Marcoux S, et al Does sweeping of the membranes reduce the need for formal induction of labour? A randomised controlled trial Br J Obstet Gynaecol 1998 105(1):34 40 9442159
Boulvain M, Irion O. Stripping/sweeping the membranes for inducing labour or preventing post-term pregnancy (Cochrane Review). In: The Cochrane Library, Issue 2, 2001. Oxford: Update Software.
Boulvain M, Irion O, Lohse C, et al. Mechanical methods for inducing labour (Cochrane Protocol). In: The Cochrane Library, Issue 4, 2000. Oxford: Update Software. (withdrawn).
Boulvain M, Irion O, Marcoux S, et al Sweeping of the membranes to prevent post-term pregnancy and to induce labour: a systematic review. [Review] Br J Obstet Gynaecol 1999 106(5):481 5 10430199
Boulvain M, Stan C, Irion O. Membrane sweeping for induction of labour (Cochrane Review). In: The Cochrane Library, Issue 2, 2001. Oxford: Update Software.
Bourgeois FJ, Harbert GM, Andersen WA, et al Early versus late tocolytic treatment of preterm premature membrane rupture Am J Obstet Gynecol 1988 159(3):742 8 3421274
Boyd ME, Usher RH, McLean FH Fetal macrosomia: prediction, risks, proposed management Obstet Gynecol 1983 61(6):715 22 6843930
Boyd ME, Usher RH, McLean FH, et al Obstetric consequences of postmaturity Am J Obstet Gynecol 1988 158(2):334 8 3277431
Boylan P, McParland P Fetal assessment in postterm pregnancy. [Review] Curr Opin Obstet Gynecol 1991 3(1):41 4 1878496
Brace RA, Wolf EJ Normal amniotic fluid volume changes throughout pregnancy Am J Obstet Gynecol 1989 161(2):382 8 2764058
Bracero LA, Roshanfekr D, Byrne DW Analysis of antepartum fetal heart rate tracing by physician and computer J Matern Fetal Med 2000 9(3):181 5 10914628
Brar HS, Horenstein J, Medearis AL, et al Cerebral, umbilical, and uterine resistance using Doppler velocimetry in postterm pregnancy J Ultrasound Med 1989 8(4):187 91 2651701
Brennand JE, Calder AA, Leitch CR, et al Recombinant human relaxin as a cervical ripening agent Br J Obstet Gynaecol 1997 104(7):775 80 9236640
Bresadola M, Lo Mastro F, Arena V, et al Prognostic value of biophysical profile score in post-date pregnancy Clin Exp Obstet Gynecol 1995 22(4):330 8 8777790
Bricker L, Luckas M. Amniotomy alone for induction of labor (Cochrane Review). In: The Cochrane Library, Issue 1, 2001. Oxford: Update Software.
Bricker L, Neilson JP. Routine Doppler ultrasound in pregnancy (Cochrane Review). In: The Cochrane Library, Issue 3, 2000. Oxford: Update Software.
Bricker L, Neilson JP. Routine ultrasound in late pregnancy (after 24 weeks gestation) (Cochrane Review). In: The Cochrane Library, Issue 3, 2000. Oxford: Update Software.
Brooks GG, Lewis DF, Gallaspy JW, et al Labor in the gravida with 10 or more years between pregnancies J Reprod Med Obstet Gynecol 1992 37(4):336 8
Brost BC, Newman RB, Hendricks SK, et al Effect of hemodialysis on serum progesterone level in pregnant women Am J Kidney Dis 1999 33(5):917 9 10213649
Brown VA, Sawers RS, Parsons RJ, et al The value of antenatal cardiotocography in the management of high-risk pregnancy: a randomized controlled trial Br J Obstet Gynaecol 1982 89(9):716 22 7052117
Buser D, Mora G, Arias F A randomized comparison between misoprostol and dinoprostone for cervical ripening and labor induction in patients with unfavorable cervices Obstet Gynecol 1997 89(4):581 5 9083316
Buttino LT, Garite TJ Intracervical prostaglandin in postdate pregnancy. A randomized trial J Reprod Med 1990 35(2):155 8 2406438
Cabbad MF, Minkoff H, Faustin D Fetal heart rate decelerations after oxytocin infusion in an abdominal pregnancy Obstet Gynecol 1985 66(3 Suppl):2S 4S 4022511
Cammu H, Haitsma V Sweeping of the membranes at 39 weeks in nulliparous women: a randomised controlled trial Br J Obstet Gynaecol 1998 105(1):41 4 9442160
Campbell MK Factors affecting outcome in post-term birth Curr Opin Obstet Gynecol 1997 9(6):356 60 9425577
Campbell MK, Ostbye T, Irgens LM Post-term birth: Risk factors and outcomes in a 10-year cohort of Norwegian births Obstet Gynecol 1997 89(4):543 8 9083310
Cardozo L Is routine induction of labour at term ever justified? BMJ 1993 306(6881):840 1 8490378 1677295
Cardozo L, Fysh J, Pearce JM Prolonged pregnancy: the management debate BMJ 1986 293(6554):1059 63 3094775 1341914
Cario GM Conservative management of prolonged pregnancy using fetal heart rate monitoring only: a prospective study Br J Obstet Gynaecol 1984 91(1):23 30 6691944
Carlan SJ, Angel JL, Knuppel RA Shoulder dystocia Am Fam Physician 1991 43(4):1307 11 2008818
Carlomagno G, Candussi G, Zavino S, et al Postmaturity: How far is it a clinical entity in its own right? Clin Exp Obstet Gynecol 1996 23(1):41 7 8653934
Carr MH, Towers CV, Eastenson AR, et al Prolonged bedrest during pregnancy: Does the risk of deep vein thrombosis warrant the use of routine heparin prophylaxis? J Matern Fetal Med 1997 6(5):264 7 9360183
Castro LC, Arora CP, Roll KE, et al Perinatal factors influencing atrial natriuretic peptide levels in umbilical arterial plasma at the time of delivery [published erratum appears in Am J Obstet Gynecol 1989 Nov;161(5):1238] Am J Obstet Gynecol 1989 161(3):623 7 2528907
Antenatal ultrasound scanning Database of Abstracts of Reviews of EffectivenessIssue 1,2000
Misoprostol for cervical ripening and labor induction: a meta-analysis Database of Abstracts of Reviews of EffectivenessIssue 1,2000
Umbilical Doppler velocimetry: results of controlled trials in high risk and low risk populations Database of Abstracts of Reviews of EffectivenessIssue 1,2000
Chang CH, Chang FM Randomized comparison of misoprostol and dinoprostone for preinduction cervical ripening and labor induction J Formos Med Assoc 1997 96(5):366 9 9170825
Chang TC, Tan KT, Neow P, et al Computerised analysis of foetal heart rate variation: Prediction of adverse perinatal outcome in patients undergoing prostaglandin induction of labour at term Ann Acad Med Singapore 1997 26(6):772 5 9522978
Chari RS, Friedman SA, O'Brien JM, et al Daily antenatal testing in women with severe preeclampsia Am J Obstet Gynecol 1995 173(4):1207 10 7485321
Chatterjee MS, Ramchandran K, Ferlita J, et al Prostaglandin E2 (PGE2) vaginal gel for cervical ripening Eur J Obstet Gynecol Reprod Biol 1991 38(3):197 202 2007444
Chauhan SP, Hendrix NW, Magann EF, et al Limitations of clinical and sonographic estimates of birth weight: experience with 1034 parturients Obstet Gynecol 1998 91(1):72 7 9464724
Chauhan SP, Lutton PM, Bailey KJ, et al Intrapartum clinical, sonographic, and parous patients' estimates of newborn birth weight Obstet Gynecol 1992 79(6):956 8 1579321
Chauhan SP, Magann EF, Sullivan CA, et al Amniotic fluid index as an admission test may increase the incidence of cesarean section in a community hospital J Matern Fetal Invest 1994 4(4):233 6
Chauhan SP, Sullivan CA, Lutton TC, et al Parous patients' estimate of birth weight in postterm pregnancy J Perinatol 1995 15(3):192 4 7666266
Chauhan SP, Sullivan CA, Magann EF, et al Estimate of birthweight among post-term pregnancy: Clinical versus sonographic J Matern Fetal Med 1994 3(5):208 11
Chayen B, Tejani N, Verma U Induction of labor with an electric breast pump J Reprod Med 1986 31(2):116 8 3959016
Chervenak JL Macrosomia in the postdates pregnancy. [Review] Clin Obstet Gynecol 1992 35(1):151 5 1544240
Chervenak JL, Divon MY, Hirsch J, et al Macrosomia in the postdate pregnancy: is routine ultrasonographic screening indicated? Am J Obstet Gynecol 1989 161(3):753 6 2675605
Chez RA, Jonas WB Complementary and alternative medicine. Part I: Clinical studies in obstetrics Obstet Gynecol Surv 1997 52(11):704 8 9357044
Chi IC, Agoestina T, Harbin J Maternal mortality at twelve teaching hospitals in Indonesia-an epidemiologic analysis Int J Gynaecol Obstet 1981 19(4):259 66 6119252
Choe JK, Baggish MS Hysteroscopic treatment of septate uterus with Neodymium-YAG laser Fertil Steril 1992 57(1):81 4 1730335
Christensen KK, Ingemarsson I, Leideman T, et al Effect of ritodrine on labor after premature rupture of the membranes Obstet Gynecol 1980 55(2):187 90 6986040
Chuck FJ, Huffaker BJ Labor induction with intravaginal misoprostol versus intracervical prostaglandin E2 gel (Prepidil gel): randomized comparison Am J Obstet Gynecol 1995 173(4):1137 42 7485307
Cibils LA On prolonged pregnancy Am J Obstet Gynecol 1995 172(4 Pt 1):1321 2 7726280
Cibils LA, Votta R Clinical significance of fetal heart rate patterns during labor. IX: Prolonged pregnancy J Perinat Med 1993 21(2):107 16 8515353
Clark A, Cook V, Hill P, et al. Cervical ripening and labor induction: misoprostol vs dinoprostone. Am J Obstet Gynecol. 1998;178.
Clark MJ Use of the oxytocin challenge test in the management of postdate pregnancy J Am Osteopath Assoc 1980 79(10):632 5 7390880
Clark SL Intrapartum management of the postdate patient. [Review] Clin Obstet Gynecol 1989 32(2):278 84 2663273
Clarkson CP, Magann EF, Siddique SA, et al Hematological complications of Gaucher's disease in pregnancy Mil Med 1998 163(7):499 501 9695619
Clausson B, Cnattingius S, Axelsson O Outcomes of post-term births: the role of fetal growth restriction and malformations Obstet Gynecol 1999 94(5 Pt 1):758 62 10546724
Clement D, Schifrin BS, Kates RB Acute oligohydramnios in postdate pregnancy Am J Obstet Gynecol 1987 157(4 Pt 1):884 6 3674162
Clifford SH Postmaturity--with placental dysfunction J Pediatr 1954 44(1):1 13 13131191
Cnattingius S, Taube A Stillbirths and rate of neonatal deaths in 76,761 postterm pregnancies in Sweden, 1982-1991; a register study Acta Obstet Gynecol Scand 1998 77(5):582 3 9654188
Collins E Maternal and fetal effects of acetaminophen and salicylates in pregnancy. [Review] Obstet Gynecol 1981 58(5 Suppl):57S 62S 7031542
Combs CA, Singh NB, Khoury JC Elective induction versus spontaneous labor after sonographic diagnosis of fetal macrosomia Obstet Gynecol 1993 81(4):492 6 8459954
Cosner KR, Dougherty MC, Bishop KR Dynamic characteristics of the circumvaginal muscles during pregnancy and the postpartum J Nurse Midwifery 1991 36(4):221 5 1895170
Cotzias CS, Paterson-Brown S, Fisk NM Prospective risk of unexplained stillbirth in singleton pregnancies at term: population based analysis BMJ 1999 319(7205):287 8 28178 10426736
Cousins ME The reproductive risk potential of prolonged gestation. [Review] Issues Health Care Women 1981 3(3):139 50 7042794
Crane J, Bennett K, Young D, et al The effectiveness of sweeping membranes at term: a randomized trial Obstet Gynecol 1997 89(4):586 90 9083317
Crowley P. Interventions for preventing or improving the outcome of delivery at or beyond term (Cochrane Review). In: The Cochrane Library, Issue 2, 2000. Oxford: Update Software.
Crowley P, O'Herlihy C, Boylan P The value of ultrasound measurement of amniotic fluid volume in the management of prolonged pregnancies Br J Obstet Gynaecol 1984 91(5):444 8 6722063
Crowther CA Prevention of preterm birth in multiple pregnancy Bailliere's Clin Obstet Gynaecol 1998 12(1):67 75 9930290
Cruikshank DP Amniocentesis for determination of fetal maturity. [Review] Clin Obstet Gynecol 1982 25(4):773 85 6761028
Cruikshank DP, Linyear AS Term stillbirth: causes and potential for prevention in Virginia Obstet Gynecol 1987 69(6):841 4 3574813
Crump WJ Postdate pregnancy in a network of community hospitals: management and outcome J Fam Pract 1988 26(1):41 4 3339303
Crump WJ, Smith CW The postdate pregnancy. When to wait, when to induce labor Postgrad Med 1986 80(5):291 3, 296-7 3763531
Csapo AI, Eskola J, Ruttner Z The biological meaning of progesterone levels Prostaglandins 1980 19(2):203 11 7384540
Cucco C, Osborne MA, Cibils LA Maternal-fetal outcomes in prolonged pregnancy Am J Obstet Gynecol 1989 161(4):916 20 2801839
Cundy T, Gamble G, Townend K, et al Perinatal mortality in Type 2 diabetes mellitus Diabet Med 2000 17(1):33 9 10691157
Curtis PD, Matthews TG, Clarke TA, et al Neonatal seizures: the Dublin Collaborative Study Arch Dis Child 1988 63(9):1065 8 3178266
Davis DL, Stewart M, Harmon RJ Postponing pregnancy after perinatal death: perspectives on doctor advice J Am Acad Child Adolesc Psychiatry 1989 28(4):481 7 2768141
Davis L The use of castor oil to stimulate labor in patients with premature rupture of membranes J Nurse Midwifery 1984 29(6):366 70 6568268
Deayton JM, Young IR, Hollingworth SA, et al Effect of late hypothalamo-pituitary disconnection on the development of the HPA axis in the ovine fetus and the initiation of parturition J Neuroendocrinol 1994 6(1):25 31 8025565
Delpapa EH, Mueller-Heubach E Pregnancy outcome following ultrasound diagnosis of macrosomia Obstet Gynecol 1991 78(3 Pt 1):340 3 1876361
Dennis KJ Prolonged pregnancy: the management debate BMJ 1986 293(6559):1434 5 3099899
Devoe L, Golde S, Kilman Y, et al A comparison of visual analyses of intrapartum fetal heart rate tracings according to the new national institute of child health and human development guidelines with computer analyses by an automated fetal heart rate monitoring system Am J Obstet Gynecol 2000 183(2):361 6 10942470
Devoe LD, Sholl JS Postdates pregnancy. Assessment of fetal risk and obstetric management J Reprod Med 1983 28(9):576 80 6631843
Divon MY, Haglund B, Nisell H, et al Fetal and neonatal mortality in the postterm pregnancy: the impact of gestational age and fetal growth restriction Am J Obstet Gynecol 1998 178(4):726 31 9579434
Dizon-Townson D, Ward K The genetics of labor. [Review] Clin Obstet Gynecol 1997 40(3):479 84 9328727
Doany W, McCarty J Outpatient management of the uncomplicated postdate pregnancy with intravaginal prostaglandin E2 gel and membrane stripping J Matern Fetal Med 1997 6(2):71 8 9086420
Donker DK, van Geijn HP, Hasman A Interobserver variation in the assessment of fetal heart rate recordings Eur J Obstet Gynecol Reprod Biol 1993 52(1):21 8 8119470
Dove D, Johnson P Oral evening primrose oil: its effect on length of pregnancy and selected intrapartum outcomes in low-risk nulliparous women J Nurse Midwifery 1999 44(3):320 4 10380450
Druzin ML, Karver ML, Wagner W, et al Prospective evaluation of the contraction stress and nonstress tests in the management of post-term pregnancy Surg Gynecol Obstet 1992 174(6):507 12 1595028
Duff C, Sinclair M Exploring the risks associated with induction of labour: a retrospective study using the NIMATS database. Northern Ireland Maternity System J Adv Nurs 2000 31(2):410 7 10672100
Dunn PA, Rogers D, Halford K Transcutaneous electrical nerve stimulation at acupuncture points in the induction of uterine contractions Obstet Gynecol 1989 73(2):286 90 2783481
Dyson DC Fetal surveillance vs. labor induction at 42 weeks in postterm gestation J Reprod Med 1988 33(3):262 70 3361516
Dyson DC, Miller PD, Armstrong MA Management of prolonged pregnancy: induction of labor versus antepartum fetal testing Am J Obstet Gynecol 1987 156(4):928 34 3472467
Ecker JL, Greenberg JA, Norwitz ER, et al Birth weight as a predictor of brachial plexus injury Obstet Gynecol 1997 89(5 Pt 1):643 7 9166293
Eden RD Postdate pregnancy: antenatal assessment of fetal well-being. [Review] Clin Obstet Gynecol 1989 32(2):235 44 2663268
Eden RD, Gergely RZ, Schifrin BS, et al Comparison of antepartum testing schemes for the management of the postdate pregnancy Am J Obstet Gynecol 1982 144(6):683 92 7137253
Eden RD, Seifert LS, Kodack LD, et al A modified biophysical profile for antenatal fetal surveillance Obstet Gynecol 1988 71(3 Pt 1):365 9 3279352
Eden RD, Seifert LS, Winegar A, et al Perinatal characteristics of uncomplicated postdate pregnancies Obstet Gynecol 1987 69(3 Pt 1):296 9 3822274
Eden RD, Seifert LS, Winegar A, et al Postdate pregnancies: a review of 46 perinatal deaths Am J Perinatol 1987 4(4):284 7 3651186
Edozien LC What do maternity statistics tell us about induction of labour? J Obstet Gynaecol 1999 19(4):343 44 15512326
Eganhouse DJ Monitoring the postdate pregnancy, part I: antepartum issues Mother Baby J 2000 5(1):7 10, 26-9
Eganhouse DJ Monitoring the postdate pregnancy, part II: intrapartum issues Mother Baby J 2000 5(2):5 20
Egarter C, Kofler E, Fitz R, et al Is induction of labor indicated in prolonged pregnancy? Results of a prospective randomised trial Gynecol Obstet Invest 1989 27(1):6 9 2646187
Egarter CH, Husslein PW, Rayburn WF Uterine hyperstimulation after low-dose prostaglandin E2 therapy: tocolytic treatment in 181 cases Am J Obstet Gynecol 1990 163(3):794 6 1976296
Ekman G, Perssen PH, Ulmsten U, et al The impact on labor induction of intracervically applied PGEinf 2-gel, related to gestational age in patients with an unripe cervix Acta Obstet Gynecol Scand 1983 62(Suppl. 113):173 5
Ekman G, Persson PH, Ulmsten U Induction of labor in postterm pregnant women Int J Gynaecol Obstet 1986 24(1):47 52 2874070
El-Azeem S, Samuels P, Welch G, et al. Term labor induction with PGE1 isoprostol versus PGE2 dinoprostone. Am J Obstet Gynecol. 1997;176.
el-Damarawy H, el-Sibaie F, Tawfik TA Antepartum fetal surveillance in post-date pregnancy Int J Gynaecol Obstet 1993 43(2):145 50 7905429
El-Sherbiny MT, El-Gharieb IH, Gewely HA. Vaginal misoprostol for induction of labor: 25 vs. 50 μg dose regimen. Int J Gynecol Obstet. 2001;72:25-30.
El-Torkey M, Grant JM Sweeping of the membranes is an effective method of induction of labour in prolonged pregnancy: a report of a randomized trial Br J Obstet Gynaecol 1992 99(6):455 8 1637758
Elliott CL, Brennand JE, Calder AA The effects of mifepristone on cervical ripening and labor induction in primigravidae Obstet Gynecol 1998 92(5):804 9 9794673
Elliott JP, Flaherty JF The use of breast stimulation to prevent postdate pregnancy Am J Obstet Gynecol 1984 149(6):628 32 6377899
Elpek G, Uner M, Trak B, et al Intravaginal naproxen in preterm labour: A preliminary study J Obstet Gynaecol 1998 18(3):236 7 15512066
Engstrom JL, Sittler CP, Swift KE Fundal height measurement. Part 5 -- The effect of clinician bias on fundal height measurements J Nurse Midwifery 1994 39(3):130 41 7931692
Escudero F, Contreras H A comparative trial of labor induction with misoprostol versus oxytocin Int J Gynaecol Obstet 1997 57(2):139 43 9184950
Essel JK, Opai-Tetteh ET Macrosomia - Maternal and fetal risk factors S Afr Med J 1995 85(1):43 6 7784919
Evans MI, Dougan MB, Moawad AH, et al Ripening of the human cervix with porcine ovarian relaxin Am J Obstet Gynecol 1983 147(4):410 4 6353927
Ewigman BG, Crane JP, Frigoletto FD, et al Effect of prenatal ultrasound screening on perinatal outcome N Engl J Med 1993 329(12):821 7 8355740
Fabre E, Gonzalez de Aguero R, de Agustin JL, et al Perinatal mortality in term and post-term births J Perinat Med 1996 24(2):163 9 8773942
Facchinetti F, Neri I, Genazzani AR Factors predicting labour onset in patients treated with prostaglandin Einf 2 for cervical ripening Eur J Obstet Gynecol Reprod Biol 1995 60(2):129 32 7641963
Fairlie FM, Lang GD, Greer IA, et al Umbilical artery Doppler flow velocity waveforms and maternal prostaglandin E2 and F2 alpha metabolite concentrations during cervical ripening with prostaglandin E2 Eur J Obstet Gynecol Reprod Biol 1990 37(1):7 13 2198178
Fait G, Grisaru D, Shenhav M, et al Balloon catheter with extra-amniotic saline instillation: a method of induction in pregnancies at 41 or more gestational weeks Aust N Z J Obstet Gynaecol 1997 37(2):174 6 9222461
Farah LA, Sanchez-Ramos L, Rosa C, et al Randomized trial of two doses of the prostaglandin E1 analog misoprostol for labor induction Am J Obstet Gynecol 1997 177(2):364 9 9290452
Farmakides G, Schulman H, Ducey J, et al Uterine and umbilical artery Doppler velocimetry in postterm pregnancy J Reprod Med 1988 33(3):259 61 2966244
Farmakides G, Schulman H, Winter D, et al Prenatal surveillance using nonstress testing and Doppler velocimetry Obstet Gynecol 1988 71(2):184 7 2962024
Farooqi A, Holmgren PA, Engberg S, et al Survival and 2-year outcome with expectant management of second- trimester rupture of membranes Obstet Gynecol 1998 92(6):895 901 9840545
Feldman GB Prospective risk of stillbirth Obstet Gynecol 1992 79(4):547 53 1553174
Flamm BL Vaginal birth after cesarean section: controversies old and new Clin Obstet Gynecol 1985 28(4):735 44 4075626
Flamm BL Was the death of this baby avoidable? Birth 1990 17(4):226 7 2285443
Fleischer A, Schulman H, Farmakides G, et al Antepartum nonstress test and the postmature pregnancy Obstet Gynecol 1985 66(1):80 3 4011074
Fletcher H, Mitchell S, Frederick J, et al Intravaginal misoprostol versus dinoprostone as cervical ripening and labor-inducing agents Obstet Gynecol 1994 83(2):244 7 8290188
Fletcher HM, Mitchell S, Simeon D, et al Intravaginal misoprostol as a cervical ripening agent Br J Obstet Gynaecol 1993 100(7):641 4 8369246
Flynn AM, Kelly J, Mansfield H, et al A randomized controlled trial of non-stress antepartum cardiotocography Br J Obstet Gynaecol 1982 89(6):427 33 7044407
Forouzan I, Cohen AW Can umbilical and arcuate artery Doppler velocimetry predict fetal distress among prolonged pregnancies? J Ultrasound Med 1991 10(1):15 7 1997680
Francome C, Savage W Caesarean section in Britain and the United States 12% or 24%: is either the right rate? Soc Sci Med 1993 37(10):1199 218 8272899
Franz WB 3d Fetal assessment Prim Care 1983 10(2):173 203 6554829
Freeman RK, Garite TJ, Mondanlou H, et al Postdate pregnancy: utilization of contraction stress testing for primary fetal surveillance Am J Obstet Gynecol 1981 140(2):128 35 7234908
Friedrichs PE An active management approach to the postdate fetus with a reactive nonstress test and fetal heart rate decelerations Obstet Gynecol 1988 71(4):657 8 3353058
Friesen CD, Miller AM, Rayburn WF Influence of spontaneous or induced labor on delivering the macrosomic fetus Am J Perinatol 1995 12(1):63 6 7710582
Froen JF, Arnestad M, Frey K, et al Risk factors for sudden intrauterine unexplained death: epidemiologic characteristics of singleton cases in Oslo, Norway, 1986-1995 American Journal of Obstetrics & Gynecology 2001 184(4):694 702 11262474
Frydman R, Lelaidier C, Baton-Saint-Mleux C, et al Labor induction in women at term with mifepristone (RU 486): a double-blind, randomized, placebo-controlled study Obstet Gynecol 1992 80(6):972 5 1448266
Gabbe SG Effects of identifying a high risk population Diabetes Care 1980 3(3):486 8 7389566
Gaffney G, Flavell V, Johnson A, et al Cerebral palsy and neonatal encephalopathy Arch Dis Child Fetal & Neonatal Edition 1994 70(3):F195 200
Gardosi J, Vanner T, Francis A Gestational age and induction of labour for prolonged pregnancy Br J Obstet Gynaecol 1997 104(7):792 7 9236643
Garry D, Figueroa R, Guillaume J, et al Use of castor oil in pregnancies at term Altern Ther Health Med 2000 6(1):77 9
Gauthier RJ, Griego BD, Goebelsmann U Estriol in pregnancy. VII. Unconjugated plasma estriol in prolonged gestation Am J Obstet Gynecol 1981 139(4):382 9 7468708
Gebhart F Induced labor, along with use of labor drugs, on the rise Drug Topics 2000 144(12):
Gegor CL, Paine LL, Johnson TR Antepartum fetal assessment. A nurse-midwifery perspective. [Review] J Nurse Midwifery 1991 36(3):153 67 1856761
Gerhard I, Postneek F Auricular acupuncture in the treatment of female infertility Gynecol Endocrinol 1992 6(3):171 81 1442162
Ghidini A, Doria V, Kirn V, et al Successful outcome after antibiotic treatment of postamniocentesis membrane rupture and chorioamnionitis in multiple pregnancy Am J Perinatol 1999 16(8):403 6 10772199
Giacalone P-L, Daures J-P, Faure J-M, et al. The effects of mifepristone on uterine sensitivity to oxytocin and on fetal heart rate patterns. Eur J Obstet Gynecol Reprod Biol. 2001;97:30-4. [pmid: 11435005].
Giacalone PL, Targosz V, Laffargue F, et al Cervical ripening with mifepristone before labor induction: A randomized study Obstet Gynecol 1998 92(4 I):487 92 9764616
Gibb DM, Cardozo LD, Studd JW, et al Prolonged pregnancy: is induction of labour indicated? A prospective study Br J Obstet Gynaecol 1982 89(4):292 5 7073997
Gibbs RS, Castillo MS, Rodgers PJ Management of acute chorioamnionitis Am J Obstet Gynecol 1980 136(6):709 13 7355955
Gibbs RS, Eschenbach DA Use of antibiotics to prevent preterm birth Am J Obstet Gynecol 1997 177(2):375 80 9290454
Gichangi PB, Ndinya-Achola JO, Ombete J, et al Antimicrobial prophylaxis in pregnancy: A randomized, placebo-controlled trial with cefetamet-pivoxil in pregnant women with a poor obstetric history Am J Obstet Gynecol 1997 177(3):680 4 9322642
Gilbert L, Porter W, Brown VA Postpartum haemorrhage -- a continuing problem Br J Obstet Gynaecol 1987 94(1):67 71 3493028
Gilbert WM, Nesbitt TS, Danielsen B Associated factors in 1611 cases of brachial plexus injury Obstet Gynecol 1999 93(4):536 40 10214829
Gilby JR, Williams MC, Spellacy WN. Fetal abdominal circumference measurements of 35 and 38 cm as predictors of macrosomia. J Reprod Med. 2000;45:936-8. [pmid: 11127108].
Giles WB Vascular Doppler techniques Obstet Gynecol Clin North Am 1999 26(4):595 606 10587957
Gilson GJ, O'Brien ME, Vera RW, et al Prolonged pregnancy and the biophysical profile. A birthing center perspective J Nurse Midwifery 1988 33(4):171 7 3042930
Gimovsky ML, Bruce SL Aspects of FHR tracings as warning signals Clin Obstet Gynecol 1986 29(1):51 63 3955932
Gjessing HK, Skjaerven R, Wilcox AJ Errors in gestational age: evidence of bleeding early in pregnancy Am J Public Health 1999 89(2):213 8 9949752 1508525
Goer H Postterm pregnancy: putting the merits of a policy of induction of labor into perspective Birth 1996 23(3):180 1 8924106
Goeree R, Hannah M, Hewson S Cost-effectiveness of induction of labour versus serial antenatal monitoring in the Canadian Multicentre Postterm Pregnancy Trial CMAJ 1995 152(9):1445 50 7728693 1337908
Gohar J, Mazor M, Leiberman JR GnRH in pregnancy Arch Gynecol Obstet 1996 259(1):1 6 8933922
Goharkhay N, Stanczyk FZ, Gentzschein E, et al. Plasma prostaglandin E2 metabolite levels during labor induction with a sustained-release prostaglandin E2 vaginal insert. J Soc Gynecol Investig. 2000;7:338-42.
Goldberg J, Newman RB, Rust PF Interobserver reliability of digital and endovaginal ultrasonographic cervical length measurements Am J Obstet Gynecol 1997 177(4):853 8 9369833
Gonen O, Rosen DJ, Dolfin Z, et al Induction of labor versus expectant management in macrosomia: a randomized study Obstet Gynecol 1997 89(6):913 7 9170464
Gonen R, Spiegel D, Abend M Is macrosomia predictable, and are shoulder dystocia and birth trauma preventable? Obstet Gynecol 1996 88(4 Pt 1):526 9 8841211
Goni S, Sawhney H, Gopalan S Oxytocin induction of labor: a comparison of 20- and 60-min dose increment levels Int J Gynaecol Obstet 1995 48(1):31 6 7698380
Goodlin RC Prolongation of pregnancy and survival of second twin Am J Obstet Gynecol 1990 163(1 Pt 1):270 1 2375368
Gottschall D, Borgida AF, Feldman DM, et al. Preinduction cervical ripening comparing 50 and 100 mcg of misoprostol. Am J Obstet Gynecol. 1998;178.
Gottschall DS, Borgida AF, Mihalek JJ, et al A randomized clinical trial comparing misoprostol with prostaglandin E2 gel for preinduction cervical ripening Am J Obstet Gynecol 1997 177(5):1067 70 9396895
Granados JL Survey of the management of postterm pregnancy Obstet Gynecol 1984 63(5):651 3 6717869
Grant A, Hepburn M Merits of an individualized approach to fetal movement counting compared with fixed-time and fixed-number methods Br J Obstet Gynaecol 1984 91(11):1087 90 6498123
Grant JM The fetal heart rate trace is normal, isn't it? Observer agreement of categorical assessments Lancet 1991 337(8735):215 8 1670851
Grant JM Induction of labour confers benefits in prolonged pregnancy. [Review] Br J Obstet Gynaecol 1994 101(2):99 102 8305406
Grant JM. Induction of labour confers benefits in prolonged pregnancy. Br J Obstet Gynaecol. 1995;102:80-1.
Graves GR, Baskett TF, Gray JH, et al The effect of vaginal administration of various doses of prostaglandin E2 gel on cervical ripening and induction of labor Am J Obstet Gynecol 1985 151(2):178 81 3855601
Gregory KD, Henry OA, Ramicone E, et al Maternal and infant complications in high and normal weight infants by method of delivery Obstet Gynecol 1998 92(4 Pt 1):507 13 9764620
Griffiths M Stillbirths and rate of neonatal deaths in 76,761 postterm pregnancies in Sweden, 1982-1991; a register study Acta Obstet Gynecol Scand 1998 77(5):583 4 9669966
Grubb DK, Rabello YA, Paul RH Post-term pregnancy: fetal death rate with antepartum surveillance. [Review] Obstet Gynecol 1992 79(6):1024 6 1579300
Grünberger W, Spona J The effect of pericervical PGEinf 2 instillation on levels of maternal serum 13,14-dihydro-15-keto-PGF(2alpha) and progesterone Arch Gynecol 1986 239(2):93 9 3535695
Guidetti DA, Divon MY, Cavalieri RL, et al Fetal umbilical artery flow velocimetry in postdate pregnancies Am J Obstet Gynecol 1987 157(6):1521 3 3425656
Guidetti DA, Divon MY, Langer O Postdate fetal surveillance: is 41 weeks too early? Am J Obstet Gynecol 1989 161(1):91 3 2750826
Gunderson E Post-term pregnancy: fetal death rate with antepartum surveillance Obstet Gynecol 1992 80(4):729 30 1407905
Gupta R, Vasishta K, Sawhney H, et al Safety and efficacy of stripping of membranes at term Int J Gynaecol Obstet 1998 60(2):115 21 9509948
Gyetvai K, Hannah ME, Hodnett ED, et al Tocolytics for preterm labor: A systematic review Obstet Gynecol 1999 94(5 SUPPL. 1):869 77 10546776
Hagglund L, Christensen KK, Christensen P, et al Risk factors in cesarean section infection Obstet Gynecol 1983 62(2):145 50 6866354
Halta VE. Calendars, clocks and choices: prolonged pregnancy [discussion appears in Midwifery Today Childbirth Educ 1996;38:38]. Midwifery Today Childbirth Educ. 1996;38:36-7. [pmid: 8826384].
Halta VE Calendars, clocks and choices Midwifery Today Childbirth Educ 1996(38):36 8
Hanley ML, Vintzileos AM Biophysical testing in premature rupture of the membranes Semin Perinatol 1996 20(5):418 25 8912996
Hann L, McArdle C, Sachs B Sonographic biophysical profile in the postdate pregnancy J Ultrasound Med 1987 6(4):191 5 3295284
Hannah M. Management of post-term pregnancy. In: The Society of Obstetricians and Gynaecologists of Canada: Policy Statement, Committee Opinion, Clinical Practice Guidelines. Ottawa, ON : SOGC, 1996. 10 P.
Hannah M. Post-term pregnancy. In: The Society of Obstetricians and Gynaecologists of Canada: Policy Statement, Committee Opinion, Clinical Practice Guidelines. Ottawa, ON : SOGC, 1997. 7 P.
Hannah ME Which tests of postterm fetal well-being work? Birth 1990 17(4):228 9 2285445
Hannah ME, Hannah WJ, Caritis SN, et al Comment on the effectiveness of induction of labor for postterm pregnancy (3) Am J Obstet Gynecol 1995 172(1):240 1 7847550
Hannah ME, Hannah WJ, Hellmann J Efficacy of induced labor vs serial antenatal monitoring in postterm pregnancy J Am Osteopath Assoc 1992 92(8):
Hannah ME, Hannah WJ, Hellmann J, et al Induction of labor as compared with serial antenatal monitoring in post-term pregnancy. A randomized controlled trial. The Canadian Multicenter Post-term Pregnancy Trial Group [published erratum appears in N Engl J Med 1992 Jul 30;327(5):368] N Engl J Med 1992 326(24):1587 92 1584259
Hannah ME, Hannah WJ, Willan A Comment on the effectiveness of induction of labor for postterm pregnancy Am J Obstet Gynecol 1995 172(1 Pt 1):240 1 7847550
Hannah ME, Huh C, Hewson SA, et al Postterm pregnancy: putting the merits of a policy of induction of labor into perspective Birth 1996 23(1):13 9 8703252
Haque MN Prolonged pregnancy: Is induction of labour still necessary? J Obstet Gynaecol 1989 9(3):196 8
Harding K, Evans S, Newnham J Screening for the small fetus: a study of the relative efficacies of ultrasound biometry and symphysiofundal height Aust N Z J Obstet Gynaecol 1995 35(2):160 4 7677678
Harman JH, Kim A Current trends in cervical ripening and labor induction [published erratum appears in Am Fam Physician 1999 Nov 15;60(8):2238]. [Review] Am Fam Physician 1999 60(2):477 84 10465223
Harris B, Eden RD, Garite TJ, et al Prolonged pregnancy. Part I: Identifying the patient at risk Female Patient Pract Obstet Gynecol Med 1991 16(2):43 6, 48, 50
Harris B, Eden RD, Garite TJ, et al Prolonged Pregnancy: Part II: Monitoring and intervention Female Patient Total Health Care Women 1991 16(3):47 9, 53, 56-57, 60
Harris BA, Huddleston JF, Sutliff G, et al The unfavorable cervix in prolonged pregnancy Obstet Gynecol 1983 62(2):171 4 6866359
Harrison JM Clinical. The initiation of labour: physiological mechanisms Br J Midwifery 2000 8(5):281 6
Hart G. Far from settled... the issue of relative risks of "postdates pregnancy" is far from settled. Midwifery Today Childbirth Educ. 1996;38.
Hauth JC, Goodman MT, Gilstrap LC 3d, et al Post-term pregnancy. I Obstet Gynecol 1980 56(4):467 70 7422191
Hauth JC, Hankins GD, Gilstrap LC 3d, et al Uterine contraction pressures with oxytocin induction/augmentation Obstet Gynecol 1986 68(3):305 9 3737050
Hed?n L, Ingemarsson I, Ahlstr?m H, et al Induction of labor versus conservative management in prolonged pregnancy: Controlled study Int J Feto-Matern Med 1991 4(4):231 6
Hendricksen A Prolonged pregnancy. A literature review. [Review] J Nurse Midwifery 1985 30(1):33 42 3881570
Henriksen TB, Wilcox AJ, Hedegaard M, et al Bias in studies of preterm and postterm delivery due to ultrasound assessment of gestational age Epidemiology 1995 6(5):533 7 8562631
Herabutya Y, Prasertsawat P, Pokpirom J A comparison of intravaginal misoprostol and intracervical prostaglandin E2 gel for ripening of unfavorable cervix and labor induction J Obstet Gynaecol Res 1997 23(4):369 74 9311179
Herabutya Y, Prasertsawat PO, Tongyai T, et al Prolonged pregnancy: the management dilemma Int J Gynaecol Obstet 1992 37(4):253 8 1350540
Herbst A, Wolner-Hanssen P, Ingemarsson I Risk factors for acidemia at birth Obstet Gynecol 1997 90(1):125 30 9207826
Hilder L, Costeloe K, Thilaganathan B Prolonged pregnancy: evaluating gestation-specific risks of fetal and infant mortality Br J Obstet Gynaecol 1998 105(2):169 73 9501781
Hill WC, Fleming AD, Martin RW, et al Home uterine activity monitoring is associated with a reduction in preterm birth Obstet Gynecol 1990 76(1 SUPPL.):13S 8S 2359574
Hobart JM Post-term pregnancy. [Review] Clin Perinatol 1989 16(4):909 15 2686895
Hofmeyr GJ, Alfirevic Z, Kelly T, et al. Methods for cervical ripening and labour induction in late pregnancy (Cochrane Protocol). In: The Cochrane Library, Issue 3, 2000. Oxford: Update Software.
Hofmeyr GJ, Gulmezoglu AM. Vaginal misoprostol for cervical ripening and labour induction in late pregnancy (Cochrane Review). In: The Cochrane Library, Issue 1, 2001. Oxford: Update Software.
Holcomb WL, Smeltzer JS Cervical effacement: variation in belief among clinicians Obstet Gynecol 1991 78(1):43 5 2047066
Holst N, Jenssen TG, Burhol PG, et al Gastrointestinal regulatory peptides during oxytocin infusion in post-term pregnancies Acta Physiol Scand 1988 132(1):23 7 2906209
Hourvitz A, Alcalay M, Korach J, et al A prospective study of high- versus low-dose oxytocin for induction of labor Acta Obstet Gynecol Scand 1996 75(7):636 41 8822656
Howarth GR, Funk M, Steytler P, et al. A randomised controlled trial comparing vaginally administered misoprostol to vaginal dinoprostone gel in labour induction. J Obstet Gynaecol. 1996;16:474-8.
Hsieh TT, Hung TH, Chen KC, et al Perinatal outcome of oligohydramnios without associated premature rupture of membranes and fetal anomalies Gynecol Obstet Invest 1998 45(4):232 6 9623787
Huang DY, Usher RH, Kramer MS, et al Determinants of unexplained antepartum fetal deaths Obstet Gynecol 2000 95(2):215 21 10674582
Hughes EG, Kelly AJ, Kavanagh J Dinoprostone vaginal insert for cervical ripening and labor induction: a meta-analysis Obstet Gynecol 2001 97(5):847 55 11336776
Hulet B, Platt LD Sinusoidal heart rate pattern and face presentation in a fetus from a postterm pregnancy. A case report J Reprod Med 1987 32(3):211 2 3572904
Hunter IW Advanced extra-uterine pregnancy -- two cases and a review of the literature Ir Med J 1983 76(2):82 3 6841024
Hutchon DJ Gestational age and induction of labour for prolonged pregnancy Br J Obstet Gynaecol 1998 105(2):247 8 9501803
Hutson JM, Petrie RH Possible limitations of fetal monitoring Clin Obstet Gynecol 1986 29(1):104 13 3514021
Idrisa A, Obisesan KA, Adeleye JA Fetal membrane sweeping for stimulation of labour in prolonged pregnancy: A controlled study J Obstet Gynaecol 1993 13(4):235 7
Iffy L, Apuzzio JJ, Mitra S, et al Rates of cesarean section and perinatal outcome. Perinatal mortality Acta Obstet Gynecol Scand 1994 73(3):225 30 8122503
Imai M, Tani A, Saito M, et al. Significance of fetal fibronectin and cytokine measurement in the cervicovaginal secretions of women at term in predicting term labor and post-term pregnancy. Eur J Obstet Gynecol Reprod Biol. 2001;97:53-8. [pmid: 11435010].
Ingardia CJ Antepartum testing in postterm pregnancy Am J Obstet Gynecol 1982 143(1):113 4 7081305
Ingemarsson I, Kallen K Stillbirths and rate of neonatal deaths in 76,761 postterm pregnancies in Sweden, 1982-1991: a register study. [Review] Acta Obstet Gynecol Scand 1997 76(7):658 62 9292640
Irion O, Boulvain M. Induction of labour for suspected fetal macrosomia (Cochrane Review). In: The Cochrane Library, Issue 4, 2000. Oxford: Update Software.
Ismail AA, Khowesah MM, Shaala SA, et al Induction of labor by oral prostaglandin E2 in protracted pregnancy Int J Gynaecol Obstet 1989 29(4):325 8 2571534
Jacobsen G Prediction of fetal growth deviations by use of symphysis-fundus height measurements Internat J Tech Assess Health Care 1992 8(Suppl 1):152 9
Jarvelin MR, Hartikainen-Sorri AL, Rantakallio P Labour induction policy in hospitals of different levels of specialisation Br J Obstet Gynaecol 1993 100(4):310 5 8494831
Jazayeri A, Heffron JA, Phillips R, et al Macrosomia prediction using ultrasound fetal abdominal circumference of 35 centimeters or more Obstet Gynecol 1999 93(4):523 6 10214826
Jazayeri A, Tsibris JCM, Spellacy WN Elevated umbilical cord plasma erythropoietin levels in prolonged pregnancies Obstet Gynecol 1998 92(1):61 3 9649094
Jocums SB, Berg CJ, Entman SS, et al Postdelivery mortality in Tennessee, 1989-1991 Obstet Gynecol 1998 91(5 I):766 70 9572227
Johanson RB, Menon BKV. Vacuum extraction vs forcepts for assisted vaginal delivery (Cochrane Review). In: The Cochrane Library, Issue 2, 2001. Oxford: Update Software.
Johnson JM, Harman CR, Lange IR, et al Biophysical profile scoring in the management of the postterm pregnancy: an analysis of 307 patients Am J Obstet Gynecol 1986 154(2):269 73 3511711
Johnson JW, Longmate JA, Frentzen B Excessive maternal weight and pregnancy outcome Am J Obstet Gynecol 1992 167(2):353 70 1497038
Johnson TR, Paine LL, Strobino DM, et al Population differences affect the interpretation of fetal nonstress test results Am J Obstet Gynecol 1998 179(3 Pt 1):779 83 9757989
Johnstone MJ Prolonged pregnancy: is induction of labour indicated? A prospective study Br J Obstet Gynaecol 1982 89(9):778 9 7115644
Johnstone MJ, Downie G, Gaskell A Induction of labor for postmaturity Lancet 1982 2(8296):
Jones DC, Hayslett JP Outcome of pregnancy in women with moderate or severe renal insufficiency N Engl J Med 1996 335(4):226 32 8657238
Jongsma HW, Nijhuis JG Critical analysis of the validity of electronic fetal monitoring J Perinat Med 1991 19(1-2):33 7 1870054
Jorge CS, Artal R, Paul RH, et al Antepartum fetal surveillance in diabetic pregnant patients Am J Obstet Gynecol 1981 141(6):641 5 7315893
Jüni P, Altman DG, Egger M. Assessing the quality of controlled clinical trials. BMJ. 2001;323:42-6. [pmid: 11440947]. [pmcid: 1120670].
Jüni P, Witschi A, Bloch R, et al The hazards of scoring the quality of clinical trials for meta-analysis JAMA 1999 282(11):1054 60 10493204
Kadanali S, Küçük?zkan T, Zor N, et al Comparison of labor induction with misoprostol vs. oxytocin/prostaglandin E2 in term pregnancy Int J Gynaecol Obstet 1996 55(2):99 104 8960988
Kadar N, Tapp A, Wong A The influence of nipple stimulation at term on the duration of pregnancy J Perinatol 1990 10(2):164 6 2193123
Kanakura Y, Kometani K, Nagata T, et al Uterine reconstruction for complete septate uterus Keio J Med 1999 48(4):201 3 10638144
Kaplan B, Goldman GA, Peled Y, et al The outcome of post-term pregnancy. A comparative study J Perinat Med 1995 23(3):183 9 8568610
Karande VC, Deshmukh MA, Virkud A Management of post-term pregnancy J Postgrad Med 1985 31(2):98 101 4057120
Kassis A, Mazor M, Leiberman JR, et al Management of post-date pregnancy: a case control study Isr J Med Sci 1991 27(2):82 6 2004889
Katz VL, Farmer RM, Dean CA, et al Use of misoprostol for cervical ripening Southern Med J 2000 93(9):881 4 11005347
Katz Z, Yemini M, Lancet M, et al Non-aggressive management of post-date pregnancies Eur J Obstet Gynecol Reprod Biol 1983 15(2):71 9 6347741
Kaufmann RC, McBride P, Amankwah KS, et al The effect of minor degrees of glucose intolerance on the incidence of neonatal macrosomia Obstet Gynecol 1992 80(1):97 101 1603507
Keirse MJ Amniotomy or oxytocin for induction of labor. Re-analysis of a randomized controlled trial Acta Obstet Gynecol Scand 1988 67(8):731 5 3074604
Keirse MJ Roundtable: postterm pregnancy. Part II. In the final analysis Birth 1991 18(2):114 5 1930433
Keirse MJ Prostaglandins in preinduction cervical ripening. Meta-analysis of worldwide clinical experience J Reprod Med 1993 38(1 Suppl):89 100 8429533
Keirse MJN Postterm pregnancy: new lessons from an unresolved debate Birth 1993 20(2):102 5
Keirse MJNC New perspectives for the effective treatment of preterm labor Am J Obstet Gynecol 1995 173(2):618 28 7645643
Keith RD, Beckley S, Garibaldi JM, et al A multicentre comparative study of 17 experts and an intelligent computer system for managing labour using the cardiotocogram Br J Obstet Gynaecol 1995 102(9):688 700 7547758
Kelly AJ, Kavanagh J, Thomas J. Castor oil, bath and/or enema for cervical priming and induction of labour (Cochrane Review). In: The Cochrane Library, Issue 2, 2001. Oxford: Update Software.
Kelly AJ, Kavanagh J, Thomas J. Relaxin for cervical ripening and induction of labour (Cochrane Review). In: The Cochrane Library, Issue 2, 2001. Oxford: Update Software.
Kelly AJ, Kavanagh J, Thomas J. Vaginal prostaglandin (PGE2 and PGF2a) for induction of labour at term (Cochrane Review). In: The Cochrane Library, Issue 2, 2001. Oxford: Update Software.
Kemp B, Winkler M, Rath W. Induction of labor by prostaglandin E2 in relation to the Bishop score. Int J Gynecol Obstet. 2000;71:13-7.
Keng MTY, Eng BTS Oral contraceptives postdatism as a complication Med J Malaysia 1982 37(4):338 43 7167086
Kesmodel U, Olsen SF Smoking habits among pregnant Danish women: reliability of information recorded after delivery J Epidemiol Community Health 1999 53(4):239 42 10396551
Khan KK, Dinnes J, Kleijnen J. Systematic reviews to evaluate diagnostic tests. Eur J Obstet Gynecol Reprod Biol. 2001;95:6-11. [pmid: 11267714].
Khouzami VA, Johnson JW, Hernandez E, et al Urinary estrogens in postterm pregnancy Am J Obstet Gynecol 1981 141(2):205 11 7282795
Kidd LC, Patel NB, Smith R Non-stress antenatal cardiotocography -- a prospective randomized clinical trial Br J Obstet Gynaecol 1985 92(11):1156 9 3904818
Kilpatrick SJ, Safford KL Maternal hydration increases amniotic fluid index in women with normal amniotic fluid Obstet Gynecol 1993 81(1):49 52 8416460
Knox GE, Huddleston JF, Flowers CE Management of prolonged pregnancy: results of a prospective randomized trial Am J Obstet Gynecol 1979 134(4):376 84 453272
Kochenour NK Estrogen assay during pregnancy. [Review] Clin Obstet Gynecol 1982 25(4):659 72 6819102
Kochenour NK Other causes of fetal death. [Review] Clin Obstet Gynecol 1987 30(2):312 21 3301130
Kolderup LB, Laros RK, Musci TJ Incidence of persistent birth injury in macrosomic infants: association with mode of delivery Am J Obstet Gynecol 1997 177(1):37 41 9240580
Konje JC, Obisesan KA, Ladipo OA Obstructed labor in Ibadan Int J Gynecol Obstet 1992 39(1):17 21
Kramer M, et al The validity of gestational age estimation by menstrual dating in term, preterm, and postterm estations JAMA 1988 260(22):3306 8 3054193
Kramer RL, Gilson GJ, Morrison DS, et al A randomized trial of misoprostol and oxytocin for induction of labor: safety and efficacy Obstet Gynecol 1997 89(3):387 91 9052591
Krammer J, O'Brien WF Mechanical methods of cervical ripening. [Review] Clin Obstet Gynecol 1995 38(2):280 6 7554595
Krammer J, Williams MC, Sawai SK, et al Pre-induction cervical ripening: a randomized comparison of two methods Obstet Gynecol 1995 85(4):614 8 7898843
Kulkarni SK, Matadial L Prolonged pregnancy -- a rational approach to management West Indian Med J 1986 35(4):314 7 3564454
Kumari S, Jain S, Pruthi PK, et al Perinatal risks in postdated pregnancy Indian Pediatr 1984 21(1):21 7 6698583
Lagrew DC, Freeman RK Management of postdate pregnancy Am J Obstet Gynecol 1986 154(1):8 13 3946506
Lahteenmaki P, Rapeli T, Kaariainen M, et al Late postcoital treatment against pregnancy with antiprogesterone RU 486 Fertil Steril 1988 50(1):36 8 3384117
Landon MB, Gabbe SG Antepartum fetal surveillance in gestational diabetes mellitus Diabetes 1985 34(SUPPL. 2):50 4
Lang J, Lieberman E Prolonged pregnancy: The management debate BMJ 1988 297(6650):715 7 3147736 1834111
Langer O, Vega-Rich M, Cohen W Terminal pattern: Characteristics and management Am J Perinatol 1985 2(4):300 4 4052182
Lazor LZ, Philipson EH, Ingardia CJ, et al A randomized comparison of 15- and 40-minute dosing protocols for labor augmentation and induction Obstet Gynecol 1993 82(6):1009 12 8233251
Leaphart WL, Meyer MC, Capeless EL Labor induction with a prenatal diagnosis of fetal macrosomia J Matern Fetal Med 1997 6(2):99 102 9086425
Ledger WJ Identification of the high risk mother and fetus--does it work? [Review] Clin Perinatol 1980 7(1):125 34 6994984
Lee HY A randomised double-blind study of vaginal misoprostol vs dinoprostone for cervical ripening and labour induction in prolonged pregnancy Singapore Med J 1997 38(7):292 4 9339095
Lee NC Postmaturity and induction of labour S Afr Med J 1986 70(11):
LeFevre ML, Bain RP, Ewigman BG, et al A randomized trial of prenatal ultrasonographic screening: impact on maternal management and outcome. RADIUS (Routine Antenatal Diagnostic Imaging with Ultrasound) Study Group Am J Obstet Gynecol 1993 169(3):483 9 8372849
Leiman G, Harrison NA, Rubin A Pregnancy following conization of the cervix: complications related to cone size Am J Obstet Gynecol 1980 136(1):14 8 7352477
Lemancewicz A, Urban R, Skotnicki MZ, et al Uterine and fetal Doppler flow changes after misoprostol and oxytocin therapy for induction of labor in post-term pregnancies Int J Gynaecol Obstet 1999 67(3):139 45 10659896
Lemons JA, Vargas P, Delaney JJ Infant of the diabetic mother: Review of 225 cases Obstet Gynecol 1981 57(2):187 92 7193318
Lennox CE, Patel NB Early versus late induction of labour in post-term pregnancy BMJ 1987 294(6588):
Leppert PC Anatomy and physiology of cervical ripening Clin Obstet Gynecol 1995 38(2):267 79 7554594
Leslie GI, Gallery EDM, Arnold JD, et al Neonatal outcome in a randomized, controlled trial of low-dose aspirin in high-risk pregnancies J Paediatr Child Health 1995 31(6):549 52 8924310
Leveno KJ, Quirk JG, Cunningham FG, et al Prolonged pregnancy. I. Observations concerning the causes of fetal distress Am J Obstet Gynecol 1984 150(5 Pt 1):465 73 6388333
Levine AB, Lockwood CJ, Brown B, et al Sonographic diagnosis of the large for gestational age fetus at term: does it make a difference? Obstet Gynecol 1992 79(1):55 8 1727587
Lewis R, Mercer BM, Salama M, et al Oral terbutaline after parenteral tocolysis: A randomized, double- blind, placebo-controlled trial Am J Obstet Gynecol 1996 175(4 I):834 7 8885731
Librizzi RJ Antepartum fetal monitoring: nonstress testing in the evaluation of uteroplacental insufficiency J Am Osteopath Assoc 1980 79(10):636 40 7390881
Lidegaard O, Bottcher LM, Weber T Description, evaluation and clinical decision making according to various fetal heart rate patterns. Inter-observer and regional variability Acta Obstet Gynecol Scand 1992 71(1):48 53 1315098
Lien JM, Morgan MA, Garite TJ, et al Antepartum cervical ripening: applying prostaglandin E2 gel in conjunction with scheduled nonstress tests in postdate pregnancies Am J Obstet Gynecol 1998 179(2):453 8 9731852
Lim BH, Mahmood TA, Smith NC, et al A prospective comparative study of transvaginal ultrasonography and digital examination for cervical assessment in the third trimester of pregnancy J Clin Ultrasound 1992 20(9):599 603 1331187
Lindhard A, Nielsen PV, Mouritsen LA, et al The implications of introducing the symphyseal-fundal height-measurement. A prospective randomized controlled trial Br J Obstet Gynaecol 1990 97(8):675 80 2205286
Lipscomb KR, Gregory K, Shaw K The outcome of macrosomic infants weighing at least 4500 grams: Los Angeles County + University of Southern California experience Obstet Gynecol 1995 85(4):558 64 7898833
Losh DP, Duhring JL Management of the postdates pregnancy Am Fam Physician 1987 36(2):184 94 3303883
Luckas M, Bricker L. Intravenous prostaglandin for induction of labour (Cochrane Review). In: The Cochrane Library, Issue 1, 2001. Oxford: Update Software.
Luckas M, Buckett W, Alfirevic Z Comparison of outcomes in uncomplicated term and post-term pregnancy following spontaneous labor J Perinat Med 1998 26(6):475 9 10224605
Lumbiganon P, Laopaiboon M, Kuchaisit C, et al. Oral prostaglandins (excluding misoprostol) for cervical ripening and labour induction when the baby is alive (Cochrane Review). In: The Cochrane Library, Issue 3, 2000. Oxford: Update Software.
Lumley J, Lester A, Anderson I, et al A randomized trial of weekly cardiotocography in high-risk obstetric patients Br J Obstet Gynaecol 1983 90(11):1018 26 6357270
Lurie S, Matzkel A, Weissman A, et al Outcome of pregnancy in class A1 and A2 gestational diabetic patients delivered beyond 40 weeks' gestation Am J Perinatol 1992 9(5-6):484 8 1418162
Lurie S, Zalel Y, Hagay ZJ The evaluation of accelerated fetal growth. [Review] Curr Opin Obstet Gynecol 1995 7(6):477 81 8620083
Lydon-Rochelle M, Holt VL, Easterling TR, et al Risk of uterine rupture during labor among women with a prior cesarean delivery N Engl J Med 2001 345(1):3 8 11439945
Maccato M, McLean W, Riddle G, et al Isolation of Kingella denitrificans from amniotic fluid in a woman with chorioamnionitis. A case report J Reprod Med 1991 36(9):685 7 1774736
Macer JA, Macer CL, Chan LS Elective induction versus spontaneous labor: a retrospective study of complications and outcome Am J Obstet Gynecol 1992 166(6 Pt 1):1690 6 1615976
MacGillivray I Twins and other multiple deliveries. [Review] Clin Obstet Gynaecol 1980 7(3):581 600 7011650
MacKenzie IZ, Burns E Randomised trial of one versus two doses of prostaglandin E2 for induction of labour: 1 Clinical outcome. Br J Obstet Gynaecol 1997 104(9):1062 7
Macnaughton MC, Chalmers IG, Dubowitz V, et al Final report of the Medical Research Council/Royal College of Obstetricians and Gynaecologists Multicentre Randomised Trial of Cervical Cerclage Br J Obstet Gynaecol 1993 100(6):516 23 8334085
Magann EF, Chauhan SP, Nevils BG, et al Management of pregnancies beyond forty-one weeks' gestation with an unfavorable cervix Am J Obstet Gynecol 1998 178(6):1279 87 9662313
Magann EF, McNamara MF, Whitworth NS, et al Can we decrease postdatism in women with an unfavorable cervix and a negative fetal fibronectin test result at term by serial membrane sweeping? Am J Obstet Gynecol 1998 179(4):890 4 9790365
Mahmood TA A prospective comparative study on the use of prostaglandin E2 gel (2 mg) and prostaglandin E2 tablet (3 mg) for the induction of labour in primigravid women with unfavorable cervices Eur J Obstet Gynecol Reprod Biol 1989 33(2):169 75 2684698
Mancuso S, Ferrazzani S, De Carolis S, et al Term and postterm low-risk pregnancies: management schemes for the reduction of high rates of cesarean section Minerva Ginecol 1996 48(3):95 8 8684694
Mandelbrot L, Dommergues M, Dumez Y Prepartum transabdominal amnio-infusion for severe oligohydramnios Acta Obstet Gynecol Scand 1992 71(2):124 5 1316039
Mandelbrot L, Verspyck E, Dommergues M, et al Transabdominal amnioinfusion for the management of nonlaboring postdates with severe oligohydramnios Fetal Diagn Ther 1993 8(6):412 7 8286032
Mandouvalos H, Alkalai BK, Metallinos C, et al Considerations on the etiology of postponed labour Ther Hung 1982 30(2):83 7 6926910
Mandruzzato G, Meir YJ, D'Ottavio G, et al Computerised evaluation of fetal heart rate in post-term fetuses: long term variation Br J Obstet Gynaecol 1998 105(3):356 9 9533000
Manning FA The use of sonography in the evaluation of the high-risk pregnancy Radiol Clin North Am 1990 28(1):205 16 2404302
Mannino F Neonatal complications of postterm gestation J Reprod Med Obstet Gynecol 1988 33(3):271 6
Manolitsas T, Wein P, Beischer NA, et al Value of cardiotocography in women with antepartum haemorrhage - Is it too late for Caesarean section when the cardiotocograph shows ominous features? Aust N Z J Obstet Gynaecol 1994 34(4):403 8 7848227
Manor M, Blickstein I, Ben-Arie A, et al Case series of labor induction in twin gestations with an intrauterine balloon catheter Gynecol Obstet Invest 1999 47(4):244 6 10352385
Martin JN, Perry KG, Roberts WE, et al Plasma exchange for preeclampsia: II. Unsuccessful antepartum utilization for severe preeclampsia with or without HELLP syndrome J Clin Apheresis 1994 9(3):155 61 7706195
Martin JN, Sessums JK, Howard P, et al Alternative approaches to the management of gravidas with prolonged-postterm-postdate pregnancies J Miss State Med Assoc 1989 30(4):105 11 2657073
Mathews TJ Trends in stimulation and induction of labor 1989-1995 Stat Bull Metrop Insur Co 1997 78(4):20 6 9357077
Matijevic R Outcome of post-term pregnancy: a matched-pair case-control study Croat Med J 1998 39(4):430 4 9841946
Maymon R, Shulman A, Pomeranz M, et al Uterine rupture at term pregnancy with the use of intracervical prostaglandin E2 gel for induction of labor Am J Obstet Gynecol 1991 165(2):368 70 1872340
McColgin SW, Hampton HL, McCaul JF, et al Stripping membranes at term: can it safely reduce the incidence of post-term pregnancies? Obstet Gynecol 1990 76(4):678 80 2216203
McColgin SW, Patrissi GA, Morrison JC Stripping the fetal membranes at term. Is the procedure safe and efficacious? Journal of Reproductive Medicine 1990 35(8):811 4 2213744
McLaren M, Greer IA, Smith JR, et al. Maternal plasma bicycling PGE2 levels following vaginal administration of prostaglandin E2 pessaries in full term pregnancies. Prog Clin Biol Res. 1987;242:199-203. [pmid: 3478732].
McLean FH, Boyd ME, Usher RH, et al Postterm infants: too big or too small? Am J Obstet Gynecol 1991 164(2):619 24 1992713
McMahon MJ, Kuller JA, Yankowitz J Assessment of the post-term pregnancy Am Fam Physician 1996 54(2):631 6, 641-2 8701841
McNally OM, Turner MJ Induction of labour after 1 previous Caesarean section Aust N Z J Obstet Gynaecol 1999 39(4):425 9 10687757
Megafu U, Ozumba BC Obstetric complications of macrosomic babies in African women Int J Gynaecol Obstet 1988 26(2):197 202 2898394
Mehl-Madrona L, Madrona MM Physician- and midwife-attended home births. Effects of breech, twin, and post-dates outcome data on mortality rates J Nurse-Midwifery 1997 42(2):91 8 9107116
Mercer BM, McNanley T, O'Brien JM, et al Early versus late amniotomy for labor induction: a randomized trial Am J Obstet Gynecol 1995 173(4):1321 5 7485346
Merrill PA, Porto M, Lovett SM, et al Evaluation of the nonreactive positive contraction stress test prior to 32 weeks: The role of the biophysical profile Am J Perinatol 1995 12(4):229 31 7575821
Milchev N, Pehlivanov B, Paskaleva V, et al Prostaglandin E2 in preinduction cervical ripening in postdate pregnancy Folia Med (Plovdiv) 1999 41(3):81 5 226275 10658373
Miller DD Tocolytic therapy for the prevention of preterm labor J Intraven Nurs 1995 18(5):233 8
Miller FC, Read JA Intrapartum assessment of the postdate fetus Am J Obstet Gynecol 1981 141(5):516 20 7294078
Minaretzis D, Tsionu C, Papageorgiou I, et al Intracervical prostaglandin E2 gel for cervical ripening and labor induction: what is the appropriate dose? Gynecol Obstet Invest 1993 35(1):34 7 8449431
Minchom P, Niswander K, Chalmers I, et al Antecedents and outcome of very early neonatal seizures in infants born at or after term Br J Obstet Gynaecol 1987 94(5):431 9 3580326
Misra M, Vavre S Labour induction with intracervical prostaglandin Einf 2 gel and intravenous oxytocin in women with a very unfavourable cervix Aust N Z J Obstet Gynaecol 1994 34(5):511 5
Mittendorf R, Williams MA, Berkey CS, et al The length of uncomplicated human gestation Obstet Gynecol 1990 75(6):929 32 2342739
Miyakawa I, Ichimaru S, Tayama C, et al Effect of ACTH infusion on induction of uterine contraction in prolonged human pregnancy in association with endocrine function Int J Gynecol Obstet 1981 19(2):89 96
Miyazaki FS, Miyazaki BA False reactive nonstress tests in postterm pregnancies Am J Obstet Gynecol 1981 140(3):269 76 7246627
Mizutani S, Itakura A, Kurauchi O, et al Maternal serum oxytocinase activities in patients with poor obstetric dates Med Sci Res 1994 22(11):771 5
Moher D, Jadad AR, Tugwell P Assessing the quality of randomized controlled trials. Current issues and future directions Internat J Tech Assess Health Care 1996 12(2):195 208
Mohide PT Randomised comparison of early versus late induction of labor in post-term pregnancy BMJ 1987 295(6594):388 9 3115463
Moldin PG, Sundell G Induction of labour: a randomised clinical trial of amniotomy versus amniotomy with oxytocin infusion Br J Obstet Gynaecol 1996 103(4):306 12 8605125
Monaghan J, O'Herlihy C, Boylan P Ultrasound placental grading and amniotic fluid quantitation in prolonged pregnancy Obstet Gynecol 1987 70(3 Pt 1):349 52 3306496
Mongan PF, Fadel HE Postdatism Am Fam Physician 1981 23(3):208 12 7468410
Monincx WM, Zondervan HA, Birnie E, et al High risk pregnancy monitored antenatally at home Eur J Obstet Gynecol Reprod Biol 1997 75(2):147 53 9447367
Montan S, Malcus P Amniotic fluid index in prolonged pregnancy: A cohort study J Matern Fetal Invest 1995 5(1):4 7
Moran C, Carranza-Lira S, Ochoa R, et al Gastrin levels in mothers and neonates at delivery in various perinatal conditions Acta Obstet Gynecol Scand 1996 75(7):608 11 8822651
Moran DJ, McGarrigle HH, Lachelin GC Lack of normal increase in saliva estriol/progesterone ratio in women with labor induced at 42 weeks' gestation Am J Obstet Gynecol 1992 167(6):1563 4 1471666
Mouw RJ, Egberts J, Kragt H, et al Cervicovaginal fetal fibronectin concentrations: predictive value of impending birth in postterm pregnancies Eur J Obstet Gynecol Reprod Biol 1998 80(1):67 70 9758262
Mukherji J, Samaddar JC How safe is caesarean section J Obstet Gynaecol 1995 21(1):17 21 8591106
Muller PR, Stubbs TM, Laurent SL A prospective randomized clinical trial comparing two oxytocin induction protocols Am J Obstet Gynecol 1992 167(2):373 80 1497039
Mundle WR, Young DC Vaginal misoprostol for induction of labor: a randomized controlled trial Obstet Gynecol 1996 88(4 Pt 1):521 5 8841210
Murphy PA, Fullerton J Outcomes of intended home births in nurse-midwifery practice: a prospective descriptive study. [Review] Obstet Gynecol 1998 92(3):461 70 9721790
Nageotte MP, Freeman RK, Freeman AG, et al Short-term variability assessment from abdominal electrocardiogram during the antepartum period Am J Obstet Gynecol 1983 145(5):566 9 6829632
Nagey DA Post-term pregnancy Obstet Gynecol 1981 58(1):135 6 7243142
A clinical trial of induction of labor versus expectant management in postterm pregnancy. The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units Am J Obstet Gynecol 1994 170(3):716 23 7710467
[electronic database]. Release 6; 1997 data. Agency for Healthcare Research and Quality: Rockville, MD. Available from: http://www.ntis.gov/fcpc/cpn8834.htm. 1997.
Neerhof MG, Cravello C, Haney EI, et al Timing of labor induction after premature rupture of membranes between 32 and 36 weeks' gestation Am J Obstet Gynecol 1999 180(2 I):349 52 9988799
Neiger R Fetal macrosomia in the diabetic patient Clin Obstet Gynecol 1992 35(1):138 50 1544239
Neilson JP. Symphysis-fundal height measurement in pregnancy (Cochrane Review). In: The Cochrane Library, Issue 3, 2000. Oxford: Update Software.
Neilson JP. Ultrasound for fetal assessment in early pregnancy (Cochrane Review). In: The Cochrane Library, Issue 4, 2000. Oxford: Update Software.
Neilson JP. Mifepristone for induction of labour (Cochrane Review). In: The Cochrane Library, Issue 3, 2001. Oxford: Update Software.
Neilson JP, Alfirevic Z. Doppler ultrasound for fetal assessment in high risk pregnancies (Cochrane Review). In: The Cochrane Library, Issue 3, 2000. Oxford: Update Software.
Neri A, Kaplan B, Rabinerson D, et al The management of persistent occipito-posterior position Clin Exp Obstet Gynecol 1995 22(2):126 31 7781178
Newnham JP, Evans SF, Michael CA, et al Effects of frequent ultrasound during pregnancy: a randomised controlled trial Lancet 1993 342(8876):887 91 8105165
Nichols CW Postdate pregnancy: clinical implications... part 2 J Nurse Midwifery 1985 30(5):259 68 3913754
Nichols CW Postdate pregnancy. Part I. A literature review. [Review] J Nurse Midwifery 1985 30(4):222 39 3913753
Nocon JJ, McKenzie DK, Thomas LJ, et al Shoulder dystocia: an analysis of risks and obstetric maneuvers Am J Obstet Gynecol 1993 168(6 Pt 1):1732 7 8317515
Norman K, Pattinson RC, De SJ, et al Ampicillin and metronidazole treatment in preterm labour: A multicentre, randomised controlled trial Br J Obstet Gynaecol 1994 101(5):404 8 8018611
Novakov A, Segedi D, Milasinovic L, et al Induction of labor by endocervical application of prostaglandins and intravenous infusion of oxytocin in postterm pregnancy Med Pregl 1998 51(9-10):419 26 9863332
Novy MJ, Walsh SW Dexamethasone and estradiol treatment in pregnant rhesus macaques: Effects on gestational length, maternal plasma hormones, and fetal growth Am J Obstet Gynecol 1983 145(8):920 31 6837680
O'Brien JM, Mercer BM, Cleary NT, et al Efficacy of outpatient induction with low-dose intravaginal prostaglandin E2: a randomized, double-blind, placebo-controlled trial Am J Obstet Gynecol 1995 173(6):1855 9 8610775
O'Connor R Induction of labour at term. Evidence on outcome favours induction BMJ 1993 306(6889):1413 4 8518627
O'Leary JA, Leonetti HB Shoulder dystocia: prevention and treatment Am J Obstet Gynecol 1990 162(1):5 9 2248627
O'Reilly-Green CP, Divon MY Predictive value of amniotic fluid index for oligohydramnios in patients with prolonged pregnancies J Matern Fetal Med 1996 5(4):218 26 8796797
O'Reilly-Green CP, Divon MY Receiver operating characteristic curves of sonographic estimated fetal weight for prediction of macrosomia in prolonged pregnancies Ultrasound Obstet Gynecol 1997 9(6):403 8 9239826
Ocak V, Sen C, Demirkiran F, et al FHR monitoring and perinatal mortality in high-risk pregnancies Eur J Obstet Gynecol Reprod Biol 1992 44(1):59 63 1587369
Ohel G, Rahav D, Rothbart H, et al Randomised trial of outpatient induction of labor with vaginal PGE2 at 40-41 weeks of gestation versus expectant management Arch Gynecol Obstet 1996 258(3):109 12 8781697
Ohel G, Yaacobi N, Linder N, et al Postdate antenatal testing Int J Gynaecol Obstet 1995 49(2):145 7 7649318
Ojo A, Oronsaye U Who is the elderly primigravida in Nigeria? Int J Gynecol Obstet 1988 26(1):51 5
Olofsson P, Saldeen P The prospects for vaginal delivery in gestations beyond 43 weeks Acta Obstet Gynecol Scand 1996 75(7):645 50 8822658
Olofsson P, Saldeen P, Marsal K Association between a low umbilical artery pulsatility index and fetal distress in labor in very prolonged pregnancies Eur J Obstet Gynecol Reprod Biol 1997 73(1):23 9 9175685
Olsen K Taken to the limit Pract Midwife 1999 2(6):
Orhue AA A randomised trial of 45 minutes and 15 minutes incremental oxytocin infusion regimes for the induction of labour in women of high parity Br J Obstet Gynaecol 1993 100(2):126 9 8476802
Orhue AA A randomized trial of 30-min and 15-min oxytocin infusion regimen for induction of labor at term in women of low parity Int J Gynaecol Obstet 1993 40(3):219 25 8096473
Orhue AA Incremental increases in oxytocin infusion regimens for induction of labor at term in primigravidas: a randomized controlled trial Obstet Gynecol 1994 83(2):229 33 8290185
Otto C, Platt LD Fetal growth and development. [Review] Obstet. Gynecol. Clin. North Am 1991 18(4):907 31 1803309
Owen J, Henson BV, Hauth JC A prospective randomized study of saline solution amnioinfusion Am J Obstet Gynecol 1990 162(5):1146 9 2187344
Owen J, Winkler CL, Harris BA, et al A randomized, double-blind trial of prostaglandin E2 gel for cervical ripening and meta-analysis Am J Obstet Gynecol 1991 165(4 Pt 1):991 6 1835301
Oyarzun E, Gomez R, Rioseco A, et al Antibiotic treatment in preterm labor and intact membranes: A randomized, double-blinded, placebo-controlled trial J Matern Fetal Med 1998 7(3):105 10 9642605
Papageorgiou I, Tsionou C, Minaretzis D, et al Labor characteristics of uncomplicated prolonged pregnancies after induction with intracervical prostaglandin E2 gel versus intravenous oxytocin Gynecol Obstet Invest 1992 34(2):92 6 1398272
Park MI, Hwang JH, Cha KJ, et al. Computerized analysis of fetal heart rate parameters by gestational age. Int J Gynecol Obstet. 2001;74:157-64.
Parry E, Parry D, Pattison N Induction of labour for post term pregnancy: an observational study Aust N Z J Obstet Gynaecol 1998 38(3):275 80 9761152
Pattison N, McCowan L. Cardiotocography for antepartum fetal assessment (Cochrane Review). In: The Cochrane Library, Issue 1, 2001. Oxford: Update Software.
Pearce JM, Cardozo C. Prolonged pregnancy: the management debate. BMJ. 1988;297:715-7. [pmid: 3147736]. [pmcid: 1834111].
Peck T Electronic monitoring evidence of fetal distress in high-risk pregnancies J Reprod Med 1980 24(3):103 8 7373591
Perkins RP Sudden fetal death in labor. The significance of antecedent monitoring characteristics and clinical circumstances J Reprod Med 1980 25(6):309 14 7205798
Persson-Kjerstadius N, Forsgren H, Westgren M Intrapartum amnioinfusion in women with oligohydramniosis. A prospective randomized trial Acta Obstet Gynecol Scand 1999 78(2):116 9 10023873
Peterson LP, Kundu N. Endocrine assessment of high-risk pregnancies. Obstet Gynecol Annu. 1980;9:169-94. [pmid: 6773003].
Phelan JP Medical-legal considerations in the postdate pregnancy Clin Obstet Gynecol 1989 32(2):294 302 2663275
Phelan JP, Platt LD, Yeh SY, et al The role of ultrasound assessment of amniotic fluid volume in the management of the postdate pregnancy Am J Obstet Gynecol 1985 151(3):304 8 3881964
Phelan JP, Platt LD, Yeh SY, et al Continuing role of the nonstress test in the management of postdates pregnancy Obstet Gynecol 1984 64(5):624 8 6493655
Phelps JY, Higby K, Smyth MH, et al Accuracy and intraobserver variability of simulated cervical dilatation measurements Am J Obstet Gynecol 1995 173(3 Pt 1):942 5 7573274
Phillips K, Berry C, Mathers AM Uterine rupture during second trimester termination of pregnancy using mifepristone and a prostaglandin Eur J Obstet Gynecol Reprod Biol 1996 65(2):175 6 8730620
Piccolo AR Clinical management of postdate pregnancy in the small community hospital J Am Osteopath Assoc 1980 80(4):271 5 7239965
Plaut MM, Schwartz ML, Lubarsky SL Uterine rupture associated with the use of misoprostol in the gravid patient with a previous cesarean section Am J Obstet Gynecol 1999 180(6 Pt 1):1535 42 10368501
Pollack RN, Hauer-Pollack G, Divon MY Macrosomia in postdates pregnancies: the accuracy of routine ultrasonographic screening Am J Obstet Gynecol 1992 167(1):7 11 1442959
Porreco RP Postdates management: induction after 41 weeks, with cervical preparation Birth 1990 17(4):
Porto M The unfavorable cervix: methods of cervical priming. [Review] Clin Obstet Gynecol 1989 32(2):262 8 2663271
Ramrekersingh-White P, Farkas AG, Chard T, et al Self-selected expectant management of post dates pregnancy including the use of Doppler ultrasound J Obstet Gynaecol 1993 13(1):16 9
Ramsey P, Harris D, Ogburn P, et al. Comparative efficacy of prostaglandin analogues dinoprostone and misoprostol as labor preinduction agents. Am J Obstet Gynecol. 1998;178.
Rand L, Robinson JN, Economy KE, et al Post-term induction of labor revisited Obstet Gynecol 2000 96(5):779 83 11042317
Rasmussen S, Dalaker K, Nordbo BL, et al One-stage ultrasound screening in pregnancy. An evaluation Acta Obstet Gynecol Scand 1990 69(7-8):581 8 2094139
Rayburn W, Gosen R, Ramadei C, et al Outpatient cervical ripening with prostaglandin E2 gel in uncomplicated postdate pregnancies Am J Obstet Gynecol 1988 158(6 Pt 1):1417 23 3289398
Rayburn WF, Chang FE Management of the uncomplicated postdate pregnancy J Reprod Med 1981 26(2):93 5 7218225
Rayburn WF, Motley ME, Stempel LE, et al Antepartum prediction of the postmature infant Obstet Gynecol 1982 60(2):148 53 7155473
Reilly KEH Induction of labor Am Fam Physician 1994 49(6):1427 32 8172040
Rekwot PI, Oyedipe EO, Mukasa-Mugerwa E, et al Fertility in zebu cattle (Bos indicus) after prostaglandin administration and artificial insemination Vet J 1999 158(1):53 8 10409417
Ribbert LSM, Visser GHA, Mulder EJH, et al Changes with time in fetal heart rate variation, movement incidences and haemodynamics in intrauterine growth retarded fetuses: A longitudinal approach to the assessment of fetal well being Early Hum Dev 1993 31(3):195 208 8444138
Ries M, Beinder E, Gruner C, et al Rapid development of hydrops fetalis in the donor twin following death of the recipient twin in twin-twin transfusion syndrome J Perinat Med 1999 27(1):68 73 10343936
Rizzo N, Farina A, Santarsiero G, et al Amniotic fluid index and labor length of pregnancies induced beyond 41 weeks of gestation with unfavorable cervix Gynecol Obstet Invest 2000 49(4):244 8 10828707
Roach VJ, Rogers MS Pregnancy outcome beyond 41 weeks gestation Int J Gynaecol Obstet 1997 59(1):19 24 9359441
Roberts CL, Algert CS, March LM Delayed childbearing -- are there any risks? Med J Aust 1994 160(9):539 44 8164551
Roberts CL, Taylor L, Henderson-Smart D Trends in births at and beyond term: evidence of a change? Br J Obstet Gynaecol 1999 106(9):937 42 10492105
Roberts L, Cook E, Beardsworth SA, et al Prolonged pregnancy: two years experience of offering women conservative management J R Army Med Corps 1994 140(1):32 6 8904502
Roberts LJ Induction of labour BMJ 1993 307(6895):66 7 8343702
Roberts LJ, Young KR The management of prolonged pregnancy -- an analysis of women's attitudes before and after term Br J Obstet Gynaecol 1991 98(11):1102 6 1760421
Roberts WE, Morrison JC Has the use of home monitors, fetal fibronectin, and measurement of cervical length helped predict labor and/or prevent preterm delivery in twins? Clin Obstet Gynecol 1998 41(1):95 102
Rodriguez MH Ultrasound evaluation of the postdate pregnancy. [Review] Clin Obstet Gynecol 1989 32(2):257 61 2663270
Romero R, Sibai BM, Sanchez-Ramos L, et al An oxytocin receptor antagonist (atosiban) in the treatment of preterm labor: A randomized, double-blind, placebo-controlled trial with tocolytic rescue Am J Obstet Gynecol 2000 182(5):1173 83 10819855
Ron M, Adoni A, Hochner-Celnikier D, et al The significance of baseline tachycardia in the postterm fetus Int J Gynaecol Obstet 1980 18(1):76 7 6106609
Rooks JP, Weatherby NL, Ernst EK The National Birth Center Study. Part III. Intrapartum and immediate postpartum and neonatal complications and transfers, postpartum and neonatal care, outcomes, and client satisfaction J Nurse Midwifery 1992 37(6):361 97 1460528
Rose VL ACOG issues report on the management of post-term pregnancy. American College of Obstetricians and Gynecologists Am Fam Physician 1998 57(7):1686 7 9556652
Rosen MG, Dickinson JC Management of post-term pregnancy N Engl J Med 1992 326(24):1628 9 1584266
Rosser J, Anderson T Sweeping the membranes Pract Midwife 1998 1(3):28 9
Rouse DJ, Owen J, Goldenberg RL, et al The effectiveness and costs of elective cesarean delivery for fetal macrosomia diagnosed by ultrasound JAMA 1996 276(18):1480 6 8903259
Roussis P, Cox SM, Campbell BA, et al Survey on the management of post date pregnancy J Matern Fetal Invest 1993 2(3):155 7
Induction of labour: evidence-based clinical guideline number 9. London: Royal College of Obstetricians and Gynaecologists, 2001.
Rubinstein TH, Schifrin BS Prolonged labor with persistent occiput-posterior position in postterm pregnancy J Perinatol 1992 12(2):181 4 1522439
Ryo E, Kozuma S, Sultana J, et al Fetal size as a determinant of obstetrical outcome of post-term pregnancy Gynecol Obstet Invest 1999 47(3):172 6 10087411
Sachs BP, Friedman EA Results of an epidemiologic study of postdate pregnancy J Reprod Med 1986 31(3):162 6 3701715
Salamalekis E, Vitoratos N, Kassanos D, et al Sweeping of the membranes versus uterine stimulation by oxytocin in nulliparous women. A randomized controlled trial Gynecol Obstet Invest 2000 49(4):240 3 10828706
Salamalekis E, Vitoratos N, Loghis C, et al The predictive value of a nonstress test taken 24 h before delivery in high-risk pregnancies Int J Gynaecol Obstet 1994 45(2):105 7 7915677
Sanchez-Ramos L, Kaunitz AM, Del Valle GO, et al Labor induction with the prostaglandin E1 methyl analogue misoprostol versus oxytocin: a randomized trial Obstet Gynecol 1993 81(3):332 6 8437780
Sandmire HF, DeMott RK The Green Bay cesarean section study. IV. The physician factor as a determinant of cesarean birth rates for the large fetus Am J Obstet Gynecol 1996 174(5):1557 64 9065129
Sarkar PK, Duthie SJ The clinical significance of reduced amniotic fluid index in post-term pregnancy: a retrospective study J Obstet Gynaecol 1997 17(3):274 5 15511849
Sarkar PK, Williams J, Duthie J Fetal macrosomia (1) J Obstet Gynaecol 1994 14(4):
Sarno AP, Hinderstein WN, Staiano RA Fetal macrosomia in a military hospital: Incidence, risk factors, and outcome Mil Med 1991 156(2):55 8 1900588
Sarno AP, Polzin WJ, Feinstein SJ, et al Transabdominal amnioinfusion in preterm pregnancies complicated by fetal growth restriction, oligohydramnios and umbilical cord compression Fetal Diagn Ther 1995 10(6):408 14 8579780
Satin AJ, Hankins GD Induction of labor in the postdate fetus. [Review] Clin Obstet Gynecol 1989 32(2):269 77 2663272
Satin AJ, Hankins GD, Yeomans ER A prospective study of two dosing regimens of oxytocin for the induction of labor in patients with unfavorable cervices Am J Obstet Gynecol 1991 165(4 Pt 1):980 4 1951567
Satin AJ, Leveno KJ, Sherman ML, et al High-dose oxytocin: 20- versus 40-minute dosage interval Obstet Gynecol 1994 83(2):234 8 8290186
Sawai SK, O'Brien WF, Mastrogiannis DS, et al Patient-administered outpatient intravaginal prostaglandin E2 suppositories in post-date pregnancies: a double-blind, randomized, placebo-controlled study Obstet Gynecol 1994 84(5):807 10 7936516
Sawai SK, Williams MC, O'Brien WF, et al Sequential outpatient application of intravaginal prostaglandin E2 gel in the management of postdates pregnancies Obstet Gynecol 1991 78(1):19 23 2047061
Schan P. Why?... inter-uterine death at 42 weeks. Midwifery Matters. 1997;74.
Schreyer P, Bar-Natan N, Sherman DJ, et al Fetal breathing movements before oxytocin induction in prolonged pregnancies Am J Obstet Gynecol 1991 165(3):577 81 1892182
Schwartz RW Pregnancy in physicians: characteristics and complications Obstet Gynecol 1985 66(5):672 6 4058826
Sciscione AC, Nguyen L, Manley J, et al. A randomized comparison of transcervical Foley catheter to intravaginal misoprostol for preinduction cervical ripening. Obstet Gynecol. 2001;97:603-7. [pmid: 11275035].
Sciscione AC, Nguyen L, Manley JS, et al Uterine rupture during preinduction cervical ripening with misoprostol in a patient with a previous Caesarean delivery Aust N Z J Obstet Gynaecol 1998 38(1):96 7 9521403
Scollo P Epidemiology of cesarean sections: prolonged pregnancy. [Review] Clin Exp Obstet Gynecol 1999 26(1):22 6 10412618
Semczuk M, Lopucka M. Evaluation of cervix condition according to Bishop score in post term pregnancy. Ann Univ Mariae Curie Sklodowska [Med]. 1986;41:125-31.
Setness P Prolonged pregnancy. When to wait, when to intervene Postgrad Med 1988 84(3):61 5, 69 3045788
Seyb ST, Berka RJ, Socol ML, et al Risk of cesarean delivery with elective induction of labor at term in nulliparous women Obstet Gynecol 1999 94(4):600 7 10511367
Shapiro H, Lyons E Late maternal age and postdate pregnancy Am J Obstet Gynecol 1989 160(4):909 12 2712123
Sharma JB, Smith RJ, Wilkin DJ Induction of labour at term. Women not for waiting BMJ 1993 306(6889):
Shaw K, Clark SL Reliability of intrapartum fetal heart rate monitoring in the postterm fetus with meconium passage Obstet Gynecol 1988 72(6):886 9 3186098
Shaw KJ, Medearis AL, Horenstein J, et al Selective labor induction in postterm patients. Observations and outcomes J Reprod Med 1992 37(2):157 61 1538361
Shea KM, Wilcox AJ, Little RE Postterm delivery: a challenge for epidemiologic research Epidemiology 1998 9(2):199 204 9504291
Shearer MH, Estes M A critical review of the recent literature on postterm pregnancy and a look at women's experiences Birth 1985 12(2):95 111 3890875
Sherer DM, Onyeije CI, Binder D, et al Uncomplicated baseline fetal tachycardia or bradycardia in postterm pregnancies and perinatal outcome Am J Perinatol 1998 15(5):335 8 9643641
Sherman DJ, Frenkel E, Pansky M, et al Balloon cervical ripening with extra-amniotic infusion of saline or prostaglandin E2: a double-blind, randomized controlled study Obstet Gynecol 2001 97(3):375 80 11239640
Shime J Influence of prolonged pregnancy on infant development J Reprod Med Obstet Gynecol 1988 33(3):277 84
Shime J, Gare DJ, Andrews J, et al Prolonged pregnancy: surveillance of the fetus and the neonate and the course of labor and delivery Am J Obstet Gynecol 1984 148(5):547 52 6702916
Shime J, Librach CL, Gare DJ, et al The influence of prolonged pregnancy on infant development at one and two years of age: a prospective controlled study Am J Obstet Gynecol 1986 154(2):341 5 2418685
Sholl JS Abruptio placentae: Clinical management in nonacute cases Am J Obstet Gynecol 1987 156(1):40 51 3541621
Shy KK Roundtable: postterm pregnancy. Antenatal testing and candid reassurance... part 2 Birth 1991 18(2):
Sibai BM, Taslimi M, Abdella TN, et al Maternal and perinatal outcome of conservative management of severe preeclampsia in midtrimester Am J Obstet Gynecol 1985 152(1):32 7 3993711
Silber M, Larsson B, Uvnas-Moberg K Oxytocin, somatostatin, insulin and gastrin concentrations vis-a-vis late pregnancy, breastfeeding and oral contraceptives Acta Obstet Gynecol Scand 1991 70(4-5):283 9 1684080
Sims ME, Walther FJ Neonatal morbidity and mortality and long-term outcome of postdate infants. [Review] Clin Obstet Gynecol 1989 32(2):285 93 2663274
Skretek M, Bielecki M, Zdanowicz A, et al Prognostic value of cardiotocographic acoustic test in post-term pregnancies Ann Med Univ Bialyst Pol 1993 38(1):79 85 7922491
Small ML, Phelan JP, Smith CV, et al An active management approach to the postdate fetus with a reactive nonstress test and fetal heart rate decelerations Obstet Gynecol 1987 70(4):636 40 3627631
Smith CA, Crowther CA. Acupuncture for induction of labour (Cochrane Review). In: The Cochrane Library, Issue 1, 2001. Oxford: Update Software.
Smith GCS. Life-table analysis of the risk of perinatal death at term and post term in singleton pregnancies. Am J Obstet Gynecol. 2001;184:489-96. [pmid: 11228508].
Snyder SG, King EA Prostaglandin gel for cervical ripening J Fam Pract 1996 43(1):19 20
Soper DE, Mayhall CG, Froggatt JW Characterization and control of intraamniotic infection in an urban teaching hospital Am J Obstet Gynecol 1996 175(2):304 9 8765246
Spong CY, Beall M, Rodrigues D, et al An objective definition of shoulder dystocia: prolonged head-to-body delivery intervals and/or the use of ancillary obstetric maneuvers Obstet Gynecol 1995 86(3):433 6 7651656
Sporken JMJ, Hein PR, Gerritsen SM First experiences with Swan-Ganz measurements in patients with severe hypertension during pregnancy from an unselected population Eur J Obstet Gynecol Reprod Biol 1986 21(3):135 41 3956832
Srisomboon J, Piyamongkol W, Aiewsakul P Comparison of intracervical and intravaginal misoprostol for cervical ripening and labour induction in patients with an unfavourable cervix J Med Assoc Thai 1997 80(3):189 94 9175387
Steel SA, Pearce JM Specific therapy in severe fetal intrauterine growth retardation: failure of prostacyclin J R Soc Med 1988 81(4):214 6 3286866 1291543
Steer PJ Postmaturity -- much ado about nothing Br J Obstet Gynaecol 1986 93(2):105 8 3947588
Stenlund PM, Ekman G, Aedo A-R, et al Induction of labor with mifepristone: a randomized, double-blind study versus placebo Acta Obstet Gynecol Scand 1999 78(9):793 8 10535343
Steyn DW, Odendaal HJ Computerised cardiotocography in a high-risk unit in a developing country -- its influence on inter-observer variation and duration of recording S Afr Med J 1996 86(2):172 5 8619147
Stroup DF, Berlin JA, Morton SC, et al Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group JAMA 2000 283(15):2008 12 10789670
Stubblefield PG, Berek JS Perinatal mortality in term and post-term births Obstet Gynecol 1980 56(6):676 82 7443108
Sue-A-Quan AK, Hannah ME, Cohen MM, et al Effect of labour induction on rates of stillbirth and cesarean section in post-term pregnancies CMAJ 1999 160(8):1145 9 10234344 1230266
Suikkari AM, Jalkanen M, Heiskala H, et al Prolonged pregnancy: induction or observation Acta Obstet Gynecol Scand 1983 116(Suppl):
Sulik SM, Greenwald JL Evaluation and management of postdate pregnancy. [Review] Am Fam Physician 1994 49(5):1177 86, 1191-2 8154405
Summers L Methods of cervical ripening and labor induction. [Review] J Nurse Midwifery 1997 42(2):71 85 9107114
Surbek DV, Boesiger H, Hoesli I, et al A double-blind comparison of the safety and efficacy of intravaginal misoprostol and prostaglandin E2 to induce labor Am J Obstet Gynecol 1997 177(5):1018 23 9396885
Suzuki S, Otsubo Y, Sawa R, et al Clinical trial of induction of labor versus expectant management in twin pregnancy Gynecol Obstet Invest 2000 49(1):24 7 10629368
Tabor B, Anderson J, Stettler B, et al. Misoprostol vs prostaglandin E2 gel for cervical ripening. Am J Obstet Gynecol. 1995;172.
Tai-Seale M, Rodwin M, Wedig G Drive-through delivery: where are the "savings"? Med Care Res Rev 1999 56(1):30 46 10189775
Takahashi K, Diamond F, Bieniarz J, et al Uterine contractility and oxytocin sensitivity in preterm, term, and postterm pregnancy Am J Obstet Gynecol 1980 136(6):774 9 7355963
Tal Z, Frankel ZN, Ballas S, et al Breast electrostimulation for the induction of labor Obstet Gynecol 1988 72(4):671 4 3262208
Tam W-H, Tai SMB, Rogers MS Prediction of cervical response to prostaglandin Einf 2 using fetal fibronectin Acta Obstet Gynecol Scand 1999 78(10):861 5 10577614
Tan KH. Fetal manipulation for facilitating tests of fetal wellbeing (Cochrane Protocol). In: The Cochrane Library, Issue 3, 2000. Oxford: Update Software.
Taylor HA Induction of labor vs. antenatal monitoring in post-term pregnancy Am Fam Physician 1997 55(7):
Taylor NF Review: placental sulphatase deficiency. [Review] J Inherit Metab Dis 1982 5(3):164 76 6302391
Tchobroutsky C, Vray MM, Altman J-J Risk/benefit ratio of changing late obstetrical strategies of insulin-dependent diabetic pregnancies. A comparison between 1971-1977 and 1978-1985 periods in 389 pregnancies Diabetes Metabol 1991 17(2):287 94
Tessarolo M, Bellino R, Arduino S, et al Cervical cerclage for the treatment of patients with placenta previa Clin Exp Obstet Gynecol 1996 23(3):184 7 8894331
Thacker SB, Stroup DF. Continuous electronic heart rate monitoring for fetal assessment during labor (Cochrane Review). In: The Cochrane Library, Issue 1, 2001. Oxford: Update Software.
Thompson G, Newnham JP, Roberman BD, et al Contraction stress fetal heart rate monitoring at preterm gestational ages Aust N Z J Obstet Gynaecol 1990 30(2):120 3 2400354
Thornton YS, Yeh SY, Petrie RH Antepartum fetal heart rate testing and the post-term gestation J Perinat Med 1982 10(4):196 202 7131222
Todros T, Preve CU, Plazzotta C, et al Fetal heart rate tracings: observers versus computer assessment Eur J Obstet Gynecol Reprod Biol 1996 68(1-2):83 6 8886686
Tongsong T, Srisomboon J Amniotic fluid volume as a predictor of fetal distress in postterm pregnancy Int J Gynaecol Obstet 1993 40(3):213 7 8096472
Toppozada MK, Anwar MY, Hassan HA, et al Oral or vaginal misoprostol for induction of labor Int J Gynaecol Obstet 1997 56(2):135 9 9061387
Toth M, Rehnstrom J, Fuchs AR Prostaglandins E and F in cervical mucus of pregnant women Am J Perinatol 1989 6(2):142 4 2712911
Treacy B, Smith C, Rayburn W Ultrasound in labor and delivery. [Review] Obstet Gynecol Surv 1990 45(4):213 9 2181357
Trimmer KJ, Leveno KJ, Peters MT, et al Observations on the cause of oligohydramnios in prolonged pregnancy Am J Obstet Gynecol 1990 163(6 I):1900 3 2256502
Trofatter KF Endocervical prostaglandin E2 gel for preinduction cervical ripening. Clinical trial results J Reprod Med 1993 38(1 Suppl):78 82 8429531
Tsuei JJ, Lai Y, Sharma SD The influence of acupuncture stimulation during pregnancy: the induction and inhibition of labor Obstet Gynecol 1977 50(4):479 8 904813
Tuffnell DJ, Bryce F, Johnson N, et al Simulation of cervical changes in labour: reproducibility of expert assessment Lancet 1989 2(8671):1089 90 2478849
Tuncer R, Erkaya S, Sipahi T, et al Emergency postpartum hysterectomy J Gynecol Surg 1995 11(4):209 13 10172732
Tunon K, Eik-Nes SH, Grottum P Fetal outcome in pregnancies defined as post-term according to the last menstrual period estimate, but not according to the ultrasound estimate Ultrasound Obstet Gynecol 1999 14(1):12 6 10461332
Turner JE, Burke MS, Porreco RP, et al Prostaglandin E2 in tylose gel for cervical ripening before induction of labor J Reprod Med 1987 32(11):815 21 3480953
Turner MJ, Fox R, Gordon H Induction of labour in primiparae after 41 weeks of pregnancy using vaginal prostaglandins J Obstet Gynaecol 1988 8(Suppl. 1):S14 S15
Turnley MJ Round table: postterm pregnancy. Our moment with Courtney Birth 1990 17(4):224 6 2103112
Ugwumadu A Induction of labour confers benefits in prolonged pregnancy Br J Obstet Gynaecol 1995 102(1):79 81 7833326
Umbach DM, Wilcox AJ A technique for measuring epidemiologically useful features of birthweight distributions Stat Med 1996 15(13):1333 48 8841645
Usher RH, Boyd ME, McLean FH, et al Assessment of fetal risk in postdate pregnancies Am J Obstet Gynecol 1988 158(2):259 64 3341404
Valensise H, Dell'anna D, Menghini S, et al Computerized analysis of fetal heart rate in postterm pregnancy J Matern Fetal Invest 1994 4(4):251 6
Van de Pas PM, Nijhuis JG, Jongsma HW Fetal behaviour in uncomplicated pregnancies after 41 weeks of gestation Early Hum. Dev 1994 40(1):29 38 7712959
Van GMJC, Major AL, Scherjon SA Placental anatomy, fetal demise and therapeutic intervention in monochorionic twins and the transfusion syndrome: New hypotheses Eur J Obstet Gynecol Reprod Biol 1998 78(1):53 62 9605450
Vantanasiri C, Manassakorn J, Thitadilok W, et al False reactive nonstress tests in postterm pregnancies J Med Assoc Thai 1985 68(5):266 8 4031720
Varaklis K, Gumina R, Stubblefield PG Randomized controlled trial of vaginal misoprostol and intracervical prostaglandin E2 gel for induction of labor at term Obstet Gynecol 1995 86(4 Pt 1):541 4 7675376
Ventura SJ, Martin JA, Curtin SC, et al. Births: Final data for 1998. National Vital Statistics Report. Hyattsville, MD. National Center for Health Statistics. 2000;vol 48.
Villar J, Gulmezoglu AM, De OM Nutritional and antimicrobial interventions to prevent preterm birth: An overview of randomized controlled trials Obstet Gynecol Surv 1998 53(9):575 85 9751940
Voss DH, Cumminsky KC, Cook VD, et al Effects of three concentrations of intracervical prostaglandin Einf 2 gel for cervical ripening J Matern Fetal Med 1996 5(4):186 93 8796792
Votta RA, Cibils LA Active management of prolonged pregnancy Am J Obstet Gynecol 1993 168(2):557 63 8141857
Wald NJ, Cuckle HS, Boreham J, et al Maternal serum alpha-fetoprotein and birth weight Br J Obstet Gynaecol 1980 87(10):860 3 6158991
Waldenstrom U, Nilsson S, Fall O, et al Effects of routine one-stage ultrasound screening in pregnancy: A randomised controlled trial Lancet 1988 2(8611):585 8 2900977
Walles B, Tyden T, Herbst A, et al Maternal health care program and markers for late fetal death Acta Obstet Gynecol Scand 1994 73(10):773 8 7817727
Webb GW, Raynor BD, Huddleston JF, et al. Induction of labor with an unfavorable cervix: a randomized prospective trial. Am J Obstet Gynecol. 1997;176.
Webster LA, Daling JR, McFarlane C, et al Prevalence and determinants of caesarean section in Jamaica J Biosoc Sci 1992 24(4):515 25 1429779
Weeks JW, Pitman T, Spinnato JA 2nd Fetal macrosomia: does antenatal prediction affect delivery route and birth outcome? Am J Obstet Gynecol 1995 173(4):1215 9 7485323
Weerasekera DS, Grant JM Sweeping of the membranes is an effective method of induction of labour in prolonged pregnancy: a report of a randomised trial (2) Br J Obstet Gynaecol 1993 100(2):193 4
Weiner Z, Farmakides G, Barnhard Y, et al Doppler study of the fetal cardiac function in prolonged pregnancies Obstet Gynecol 1996 88(2):200 2 8692501
Weiner Z, Farmakides G, Schulman H, et al Central and peripheral haemodynamic changes in post-term fetuses: Correlation with oligohydramnios and abnormal fetal heart rate pattern Br J Obstet Gynaecol 1996 103(6):541 6 8645646
Weiner Z, Farmakides G, Schulman H, et al Computerized analysis of fetal heart rate variation in postterm pregnancy: prediction of intrapartum fetal distress and fetal acidosis Am J Obstet Gynecol 1994 171(4):1132 8 7943086
Weiner Z, Reichler A, Zlozover M, et al The value of Doppler ultrasonography in prolonged pregnancies Eur J Obstet Gynecol Reprod Biol 1993 48(2):93 7 8491337
Weinstein D, Ezra Y, Picard R, et al Expectant management of post-term patients: observations and outcome J Matern Fetal Med 1996 5(5):293 7 8930801
Weissman A, Yoffe N, Jakobi P, et al Management of triplet pregnancies in the 1980s - Are we doing better? Am J Perinatol 1991 8(5):333 7 1760066
Wikstrom I, Axelsson O, Bergstrom R, et al Traumatic injury in large-for-date infants Acta Obstet Gynecol Scand 1988 67(3):259 64 3176946
Wilcox AJ, Weinberg CR, Baird DD Timing of sexual intercourse in relation to ovulation. Effects on the probability of conception, survival of the pregnancy, and sex of the baby N Engl J Med 1995 333(23):1517 21 7477165
Wilcox JA, Nasrallah HA Perinatal distress and prognosis of psychotic illness Neuropsychobiology 1987 17(4):173 5 3441270
Wing DA, Fassett MJ, Mishell DR Mifepristone for preinduction cervical ripening beyond 41 weeks' gestation: a randomized controlled trial Obstet Gynecol 2000 96(4):543 8 11004356
Wing DA, Jones MM, Rahall A, et al A comparison of misoprostol and prostaglandin E2 gel for preinduction cervical ripening and labor induction Am J Obstet Gynecol 1995 172(6):1804 10 7778636
Wing DA, Lovett K, Paul RH Disruption of prior uterine incision following misoprostol for labor induction in women with previous cesarean delivery Obstet Gynecol 1998 91(5 Pt 2):828 30 9572178
Wing DA, Ortiz-Omphroy G, Paul RH A comparison of intermittent vaginal administration of misoprostol with continuous dinoprostone for cervical ripening and labor induction Am J Obstet Gynecol 1997 177(3):612 8 9322632
Wing DA, Paul RH A comparison of differing dosing regimens of vaginally administered misoprostol for preinduction cervical ripening and labor induction [published erratum appears in Am J Obstet Gynecol 1997 Jun;176(6):1423] Am J Obstet Gynecol 1996 175(1):158 64 8694043
Wing DA, Rahall A, Jones MM, et al Misoprostol: an effective agent for cervical ripening and labor induction Am J Obstet Gynecol 1995 172(6):1811 6 7778637
Wiriyasirivaj B, Vutyavanich T, Ruangsri RA A randomized controlled trial of membrane stripping at term to promote labor Obstet Gynecol 1996 87(5 Pt 1):767 70 8677083
Wischnik A, Zieger W Tocolytic therapies in development for preterm labour Expert Opin Invest Drugs 1994 3(6):621 9
Witter FR, Weitz CM A randomized trial of induction at 42 weeks gestation versus expectant management for postdates pregnancies Am J Perinatol 1987 4(3):206 11 3300672
Witter FR, Weitz CM Cervical examination prior to induction in postdate pregnancies Surg Gynecol Obstet 1989 168(3):214 6 2645665
Wood CL Postdate pregnancy update. [Review] J Nurse Midwifery 1994 39(2 Suppl):110S 22S 8035241
Wood L Induction of labour confers benefit in prolonged pregnancy Br J Obstet Gynaecol 1994 101(12):
Wu MY, Yang YS, Huang SC, et al Prolongation of pregnancy and survival of both twins after preterm premature rupture of membrane of twin A and 19 weeks' gestation Acta Obstet Gynecol Scand 1996 75(3):299 302 8607349
Xenakis EM, Piper JM, Conway DL, et al Induction of labor in the nineties: conquering the unfavorable cervix Obstet Gynecol 1997 90(2):235 9 9241300
Yates WT, Cibils LA Why not begin 'active management' of prolonged pregnancy sooner? (2) Am J Obstet Gynecol 1994 170(1 I):
Yeast JD, Jones A, Poskin M Induction of labor and the relationship to cesarean delivery: A review of 7001 consecutive inductions Am J Obstet Gynecol 1999 180(3 Pt 1):628 33 10076139
Yeh S, Huang X, Phelan JP Postterm pregnancy after previous cesarean section J Reprod Med 1984 29(1):41 4 6708020
Yeh SY, Bruce SL, Thornton YS Intrapartum monitoring and management of the postdate fetus. [Review] Clin Perinatol 1982 9(2):381 6 6749378
Yeh SY, Read JA Management of post-term pregnancy in a large obstetric population Obstet Gynecol 1982 60(3):282 7 7121907
Yeh SY, Read JA Plasma unconjugated estriol as an indicator of fetal dysmaturity in postterm pregnancy Obstet Gynecol 1983 62(1):22 5 6856218
Yoonessi M, Wieckowska W, Mariniello D, et al Cervical intra-epithelial neoplasia in pregnancy Int J Gynecol Obstet 1982 20(2):111 8
Yudkin P Risk of unexplained stillbirth in prolonged pregnancy Midwife Health Visit Community Nurse 1988 24(10):407 10 3231131
Yudkin PL, Redman CW Caesarean section dissected, 1978-1983 Br J Obstet Gynaecol 1986 93(2):135 44 3947589
Yudkin PL, Wood L, Redman CWG. Risk of unexplained stillbirth at different gestational ages. Lancet. 1987;1:1192-4. [pmid: 2883499].
Zelop CM, Shipp TD, Cohen A, et al. Trial of labor after 40 weeks' gestation in women with prior cesarean. Obstet Gynecol. 2001;97:391-3. [pmid: 11239643].
Zhao YG, Shao YL The combined tests of overnight 12-hour urine E3/C ratio and fetal heart rate in perinatal monitoring Chin Med J (Engl) 1989 102(3):188 92 2503305
Zhou W, Sorensen HT, Olsen J Induced abortion and subsequent pregnancy duration Obstet Gynecol 1999 94(6):948 53 10576181
Zuazu J, Julia A, Sierra J, et al Pregnancy outcome in hematologic malignancies Cancer 1991 67(3):703 9 1985762