# References

Acker DB, Sachs BP, Friedman EA Risk factors for shoulder dystocia Obstet Gynecol 1985 66(6):762 8 4069477
Routine ultrasound in low-risk pregnancy. 1997. [pmcid: 176006].
Fetal macrosomia. ACOG Practice Bulletin No. 22. 2000.
Alfirevic Z, Howarth G, Gaussmann A. Oral misoprostol for induction of labor (Cochrane Review). In: The Cochrane Library, Issue 2, 2000. Oxford: Update Software.
Alfirevic Z, Luckas M, Walkinshaw SA, et al A randomised comparison between amniotic fluid index and maximum pool depth in the monitoring of post-term pregnancy Br J Obstet Gynaecol 1997 104(2):207 11 9070140
Alfirevic Z, Walkinshaw SA A randomised controlled trial of simple compared with complex antenatal fetal monitoring after 42 weeks of gestation Br J Obstet Gynaecol 1995 102(8):638 43 7654642
Allott HA, Palmer CR Sweeping the membranes: a valid procedure in stimulating the onset of labour? Br J Obstet Gynaecol 1993 100(10):898 903 8217970
Anonymous ACOG practice patterns. Management of postterm pregnancy. Number 6, October 1997. American College of Obstetricians and Gynecologists Int J Gynaecol Obstet 1997 60(1):86 91
Arabin B, Snyjders R, Mohnhaupt A, et al Evaluation of the fetal assessment score in pregnancies at risk for intrauterine hypoxia Am J Obstet Gynecol 1993 169(3):549 54 8372860
Arias F Predictability of complications associated with prolongation of pregnancy Obstet Gynecol 1987 70(1):101 6 3299174
Atad J, Hallak M, Auslender R, et al A randomized comparison of prostaglandin E2, oxytocin, and the double-balloon device in inducing labor Obstet Gynecol 1996 87(2):223 7 8559528
Augensen K, Bergsjø P, Eikeland T, et al Randomised comparison of early versus late induction of labour in post-term pregnancy BMJ 1987 294(6581):1192 5 3109575 1246355
Ayres-de-Campos D, Bernardes J, Costa-Pereira A, et al Inconsistencies in classification by experts of cardiotocograms and subsequent clinical decision Br J Obstet Gynaecol 1999 106(12):1307 10 10609727
Bastian H, Keirse MJ, Lancaster PA Perinatal death associated with planned home birth in Australia: population based study BMJ 1998 317(7155):384 8 28632 9694754
Battaglia C, Larocca E, Lanzani A, et al Doppler velocimetry in prolonged pregnancy Obstet Gynecol 1991 77(2):213 6 1988884
Bell RJ, Permezel M, MacLennan A, et al A randomized, double-blind, placebo-controlled trial of the safety of vaginal recombinant human relaxin for cervical ripening Obstet Gynecol 1993 82(3):328 33 8355929
Bennett BB Uterine rupture during induction of labor at term with intravaginal misoprostol Obstet Gynecol 1997 89(5 Pt 2):832 3 9166339
Berghella V, Rogers RA, Lescale K Stripping of membranes as a safe method to reduce prolonged pregnancies Obstet Gynecol 1996 87(6):927 31 8649700
Bergsjø P, Huang GD, Yu SQ, et al Comparison of induced versus non-induced labor in post-term pregnancy. A randomized prospective study Acta Obstet Gynecol Scand 1989 68(8):683 7 2698591
Bernardes J, Costa-Pereira A, Ayres-de-Campos D, et al Evaluation of interobserver agreement of cardiotocograms Int J Gynaecol Obstet 1997 57(1):33 7 9175667
Bishop EH. Pelvic scoring for elective induction. Obstet Gynecol. 1964;24:266-8. [pmid: 14199536].
Blanchette HA, Nayak S, Erasmus S Comparison of the safety and efficacy of intravaginal misoprostol (prostaglandin E1) with those of dinoprostone (prostaglandin E2) for cervical ripening and induction of labor in a community hospital Am J Obstet Gynecol 1999 180(6 Pt 1):1551 9 10368503
Bochner CJ, Medearis AL, Ross MG, et al The role of antepartum testing in the management of postterm pregnancies with heavy meconium in early labor Obstet Gynecol 1987 69(6):903 7 3554066
Bochner CJ, Williams J 3d, Castro L, et al The efficacy of starting postterm antenatal testing at 41 weeks as compared with 42 weeks of gestational age Am J Obstet Gynecol 1988 159(3):550 4 3421252
Boulvain M, Fraser WD, Marcoux S, et al Does sweeping of the membranes reduce the need for formal induction of labour? A randomised controlled trial Br J Obstet Gynaecol 1998 105(1):34 40 9442159
Boulvain M, Irion O. Stripping/sweeping the membranes for inducing labour or preventing post-term pregnancy (Cochrane Review). In: The Cochrane Library, Issue 2, 2001. Oxford: Update Software.
Brar HS, Horenstein J, Medearis AL, et al Cerebral, umbilical, and uterine resistance using Doppler velocimetry in postterm pregnancy J Ultrasound Med 1989 8(4):187 91 2651701
Brennand JE, Calder AA, Leitch CR, et al Recombinant human relaxin as a cervical ripening agent Br J Obstet Gynaecol 1997 104(7):775 80 9236640
Brown VA, Sawers RS, Parsons RJ, et al The value of antenatal cardiotocography in the management of high-risk pregnancy: a randomized controlled trial Br J Obstet Gynaecol 1982 89(9):716 22 7052117
Buser D, Mora G, Arias F A randomized comparison between misoprostol and dinoprostone for cervical ripening and labor induction in patients with unfavorable cervices Obstet Gynecol 1997 89(4):581 5 9083316
Buttino LT, Garite TJ Intracervical prostaglandin in postdate pregnancy. A randomized trial J Reprod Med 1990 35(2):155 8 2406438
Cammu H, Haitsma V Sweeping of the membranes at 39 weeks in nulliparous women: a randomised controlled trial Br J Obstet Gynaecol 1998 105(1):41 4 9442160
Campbell MK, Ostbye T, Irgens LM Post-term birth: Risk factors and outcomes in a 10-year cohort of Norwegian births Obstet Gynecol 1997 89(4):543 8 9083310
Cardozo L, Fysh J, Pearce JM Prolonged pregnancy: the management debate BMJ 1986 293(6554):1059 63 3094775 1341914
Chang CH, Chang FM Randomized comparison of misoprostol and dinoprostone for preinduction cervical ripening and labor induction J Formos Med Assoc 1997 96(5):366 9 9170825
Chatterjee MS, Ramchandran K, Ferlita J, et al Prostaglandin E2 (PGE2) vaginal gel for cervical ripening Eur J Obstet Gynecol Reprod Biol 1991 38(3):197 202 2007444
Chauhan SP, Sullivan CA, Lutton TC, et al Parous patients' estimate of birth weight in postterm pregnancy J Perinatol 1995 15(3):192 4 7666266
Chauhan SP, Sullivan CA, Magann EF, et al Estimate of birthweight among post-term pregnancy: Clinical versus sonographic J Matern Fetal Med 1994 3(5):208 11
Chayen B, Tejani N, Verma U Induction of labor with an electric breast pump J Reprod Med 1986 31(2):116 8 3959016
Chervenak JL, Divon MY, Hirsch J, et al Macrosomia in the postdate pregnancy: is routine ultrasonographic screening indicated? Am J Obstet Gynecol 1989 161(3):753 6 2675605
Chuck FJ, Huffaker BJ Labor induction with intravaginal misoprostol versus intracervical prostaglandin E2 gel (Prepidil gel): randomized comparison Am J Obstet Gynecol 1995 173(4):1137 42 7485307
Cotzias CS, Paterson-Brown S, Fisk NM Prospective risk of unexplained stillbirth in singleton pregnancies at term: population based analysis BMJ 1999 319(7205):287 8 28178 10426736
Crane J, Bennett K, Young D, et al The effectiveness of sweeping membranes at term: a randomized trial Obstet Gynecol 1997 89(4):586 90 9083317
Crowley P. Interventions for preventing or improving the outcome of delivery at or beyond term (Cochrane Review). In: The Cochrane Library, Issue 2, 2000. Oxford: Update Software.
Crowley P, O'Herlihy C, Boylan P The value of ultrasound measurement of amniotic fluid volume in the management of prolonged pregnancies Br J Obstet Gynaecol 1984 91(5):444 8 6722063
Curtis PD, Matthews TG, Clarke TA, et al Neonatal seizures: the Dublin Collaborative Study Arch Dis Child 1988 63(9):1065 8 3178266
Devoe LD, Sholl JS Postdates pregnancy. Assessment of fetal risk and obstetric management J Reprod Med 1983 28(9):576 80 6631843
Divon MY, Haglund B, Nisell H, et al Fetal and neonatal mortality in the postterm pregnancy: the impact of gestational age and fetal growth restriction Am J Obstet Gynecol 1998 178(4):726 31 9579434
Doany W, McCarty J Outpatient management of the uncomplicated postdate pregnancy with intravaginal prostaglandin E2 gel and membrane stripping J Matern Fetal Med 1997 6(2):71 8 9086420
Donker DK, van Geijn HP, Hasman A Interobserver variation in the assessment of fetal heart rate recordings Eur J Obstet Gynecol Reprod Biol 1993 52(1):21 8 8119470
Dyson DC, Miller PD, Armstrong MA Management of prolonged pregnancy: induction of labor versus antepartum fetal testing Am J Obstet Gynecol 1987 156(4):928 34 3472467
Eden RD, Gergely RZ, Schifrin BS, et al Comparison of antepartum testing schemes for the management of the postdate pregnancy Am J Obstet Gynecol 1982 144(6):683 92 7137253
Eden RD, Seifert LS, Winegar A, et al Perinatal characteristics of uncomplicated postdate pregnancies Obstet Gynecol 1987 69(3 Pt 1):296 9 3822274
Egarter C, Kofler E, Fitz R, et al Is induction of labor indicated in prolonged pregnancy? Results of a prospective randomised trial Gynecol Obstet Invest 1989 27(1):6 9 2646187
El-Torkey M, Grant JM Sweeping of the membranes is an effective method of induction of labour in prolonged pregnancy: a report of a randomized trial Br J Obstet Gynaecol 1992 99(6):455 8 1637758
Elliott CL, Brennand JE, Calder AA The effects of mifepristone on cervical ripening and labor induction in primigravidae Obstet Gynecol 1998 92(5):804 9 9794673
Elliott JP, Flaherty JF The use of breast stimulation to prevent postdate pregnancy Am J Obstet Gynecol 1984 149(6):628 32 6377899
Escudero F, Contreras H A comparative trial of labor induction with misoprostol versus oxytocin Int J Gynaecol Obstet 1997 57(2):139 43 9184950
Evans MI, Dougan MB, Moawad AH, et al Ripening of the human cervix with porcine ovarian relaxin Am J Obstet Gynecol 1983 147(4):410 4 6353927
Farah LA, Sanchez-Ramos L, Rosa C, et al Randomized trial of two doses of the prostaglandin E1 analog misoprostol for labor induction Am J Obstet Gynecol 1997 177(2):364 9 9290452
Farmakides G, Schulman H, Winter D, et al Prenatal surveillance using nonstress testing and Doppler velocimetry Obstet Gynecol 1988 71(2):184 7 2962024
Fleischer A, Schulman H, Farmakides G, et al Antepartum nonstress test and the postmature pregnancy Obstet Gynecol 1985 66(1):80 3 4011074
Fletcher H, Mitchell S, Frederick J, et al Intravaginal misoprostol versus dinoprostone as cervical ripening and labor-inducing agents Obstet Gynecol 1994 83(2):244 7 8290188
Fletcher HM, Mitchell S, Simeon D, et al Intravaginal misoprostol as a cervical ripening agent Br J Obstet Gynaecol 1993 100(7):641 4 8369246
Flynn AM, Kelly J, Mansfield H, et al A randomized controlled trial of non-stress antepartum cardiotocography Br J Obstet Gynaecol 1982 89(6):427 33 7044407
Froen JF, Arnestad M, Frey K, et al Risk factors for sudden intrauterine unexplained death: epidemiologic characteristics of singleton cases in Oslo, Norway, 1986-1995 American Journal of Obstetrics & Gynecology 2001 184(4):694 702 11262474
Frydman R, Lelaidier C, Baton-Saint-Mleux C, et al Labor induction in women at term with mifepristone (RU 486): a double-blind, randomized, placebo-controlled study Obstet Gynecol 1992 80(6):972 5 1448266
Garry D, Figueroa R, Guillaume J, et al Use of castor oil in pregnancies at term Altern Ther Health Med 2000 6(1):77 9
Giacalone PL, Targosz V, Laffargue F, et al Cervical ripening with mifepristone before labor induction: A randomized study Obstet Gynecol 1998 92(4 I):487 92 9764616
Gilby JR, Williams MC, Spellacy WN. Fetal abdominal circumference measurements of 35 and 38 cm as predictors of macrosomia. J Reprod Med. 2000;45:936-8. [pmid: 11127108].
Gilson GJ, O'Brien ME, Vera RW, et al Prolonged pregnancy and the biophysical profile. A birthing center perspective J Nurse Midwifery 1988 33(4):171 7 3042930
Gjessing HK, Skjaerven R, Wilcox AJ Errors in gestational age: evidence of bleeding early in pregnancy Am J Public Health 1999 89(2):213 8 9949752 1508525
Goeree R, Hannah M, Hewson S Cost-effectiveness of induction of labour versus serial antenatal monitoring in the Canadian Multicentre Postterm Pregnancy Trial CMAJ 1995 152(9):1445 50 7728693 1337908
Goldberg J, Newman RB, Rust PF Interobserver reliability of digital and endovaginal ultrasonographic cervical length measurements Am J Obstet Gynecol 1997 177(4):853 8 9369833
Gonen O, Rosen DJ, Dolfin Z, et al Induction of labor versus expectant management in macrosomia: a randomized study Obstet Gynecol 1997 89(6):913 7 9170464
Gottschall DS, Borgida AF, Mihalek JJ, et al A randomized clinical trial comparing misoprostol with prostaglandin E2 gel for preinduction cervical ripening Am J Obstet Gynecol 1997 177(5):1067 70 9396895
Graves GR, Baskett TF, Gray JH, et al The effect of vaginal administration of various doses of prostaglandin E2 gel on cervical ripening and induction of labor Am J Obstet Gynecol 1985 151(2):178 81 3855601
Grünberger W, Spona J The effect of pericervical PGEinf 2 instillation on levels of maternal serum 13,14 dihydro-15-keto-PGF(2alpha) and progesterone Arch Gynecol 1986 239(2):93 9 3535695
Gupta R, Vasishta K, Sawhney H, et al Safety and efficacy of stripping of membranes at term Int J Gynaecol Obstet 1998 60(2):115 21 9509948
Hann L, McArdle C, Sachs B Sonographic biophysical profile in the postdate pregnancy J Ultrasound Med 1987 6(4):191 5 3295284
Hannah ME, Hannah WJ, Hellmann J, et al Induction of labor as compared with serial antenatal monitoring in post-term pregnancy. A randomized controlled trial. The Canadian Multicenter Post-term Pregnancy Trial Group [published erratum appears in N Engl J Med 1992 Jul 30;327(5):368] N Engl J Med 1992 326(24):1587 92 1584259
Hannah ME, Huh C, Hewson SA, et al Postterm pregnancy: putting the merits of a policy of induction of labor into perspective Birth 1996 23(1):13 9 8703252
Harris BA, Huddleston JF, Sutliff G, et al The unfavorable cervix in prolonged pregnancy Obstet Gynecol 1983 62(2):171 4 6866359
Hedén L, Ingemarsson I, Ahlström H, et al Induction of labor versus conservative management in prolonged pregnancy: controlled study Int J Feto-Matern Med 1991 4(4):231 6
Henriksen TB, Wilcox AJ, Hedegaard M, et al Bias in studies of preterm and postterm delivery due to ultrasound assessment of gestational age Epidemiology 1995 6(5):533 7 8562631
Herabutya Y, Prasertsawat P, Pokpirom J A comparison of intravaginal misoprostol and intracervical prostaglandin E2 gel for ripening of unfavorable cervix and labor induction J Obstet Gynaecol Res 1997 23(4):369 74 9311179
Herabutya Y, Prasertsawat PO, Tongyai T, et al Prolonged pregnancy: the management dilemma Int J Gynaecol Obstet 1992 37(4):253 8 1350540
Hilder L, Costeloe K, Thilaganathan B Prolonged pregnancy: evaluating gestation-specific risks of fetal and infant mortality Br J Obstet Gynaecol 1998 105(2):169 73 9501781
Hofmeyr GJ, Gulmezoglu AM. Vaginal misoprostol for cervical ripening and labour induction in late pregnancy (Cochrane Review). In: The Cochrane Library, Issue 1, 2001. Oxford: Update Software.
Holcomb WL, Smeltzer JS Cervical effacement: variation in belief among clinicians Obstet Gynecol 1991 78(1):43 5 2047066
Howarth GR, Funk M, Steytler P, et al. A randomised controlled trial comparing vaginally administered misoprostol to vaginal dinoprostone gel in labour induction. J Obstet Gynaecol. 1996;16:474-8.
Idrisa A, Obisesan KA, Adeleye JA Fetal membrane sweeping for stimulation of labour in prolonged pregnancy: a controlled study J Obstet Gynaecol 1993 13(4):235 7
Imai M, Tani A, Saito M, et al. Significance of fetal fibronectin and cytokine measurement in the cervicovaginal secretions of women at term in predicting term labor and post-term pregnancy. Eur J Obstet Gynecol Reprod Biol. 2001;97:53-8. [pmid: 11435010].
Jazayeri A, Heffron JA, Phillips R, et al Macrosomia prediction using ultrasound fetal abdominal circumference of 35 centimeters or more Obstet Gynecol 1999 93(4):523 6 10214826
Johanson RB, Menon BKV. Vacuum extraction vs forcepts for assisted vaginal delivery (Cochrane Review). In: The Cochrane Library, Issue 2, 2001. Oxford: Update Software.
Jüni P, Altman DG, Egger M. Assessing the quality of controlled clinical trials. BMJ. 2001;323:42-6. [pmid: 11440947]. [pmcid: 1120670].
Jüni P, Witschi A, Bloch R, et al The hazards of scoring the quality of clinical trials for meta-analysis JAMA 1999 282(11):1054 60 10493204
Kadanali S, Küçüközkan T, Zor N, et al Comparison of labor induction with misoprostol vs. oxytocin/prostaglandin E2 in term pregnancy Int J Gynaecol Obstet 1996 55(2):99 104 8960988
Kadar N, Tapp A, Wong A The influence of nipple stimulation at term on the duration of pregnancy J Perinatol 1990 10(2):164 6 2193123
Katz Z, Yemini M, Lancet M, et al Non-aggressive management of post-date pregnancies Eur J Obstet Gynecol Reprod Biol 1983 15(2):71 9 6347741
Kelly AJ, Kavanagh J, Thomas J. Castor oil, bath and/or enema for cervical priming and induction of labour (Cochrane Review). In: The Cochrane Library, Issue 2, 2001. Oxford: Update Software.
Kemp B, Winkler M, Rath W. Induction of labor by prostaglandin E2 in relation to the Bishop score. Int J Gynecol Obstet. 2000;71:13-7.
Keng MTY, Eng BTS Oral contraceptives postdatism as a complication Med J Malaysia 1982 37(4):338 43 7167086
Kidd LC, Patel NB, Smith R Non-stress antenatal cardiotocography -- a prospective randomized clinical trial Br J Obstet Gynaecol 1985 92(11):1156 9 3904818
Knox GE, Huddleston JF, Flowers CE Management of prolonged pregnancy: results of a prospective randomized trial Am J Obstet Gynecol 1979 134(4):376 84 453272
Kramer RL, Gilson GJ, Morrison DS, et al A randomized trial of misoprostol and oxytocin for induction of labor: safety and efficacy Obstet Gynecol 1997 89(3):387 91 9052591
Lee HY A randomised double-blind study of vaginal misoprostol vs dinoprostone for cervical ripening and labour induction in prolonged pregnancy Singapore Med J 1997 38(7):292 4 9339095
Leveno KJ, Quirk JG, Cunningham FG, et al Prolonged pregnancy. I. Observations concerning the causes of fetal distress Am J Obstet Gynecol 1984 150(5 Pt 1):465 73 6388333
Lidegaard O, Bottcher LM, Weber T Description, evaluation and clinical decision making according to various fetal heart rate patterns. Inter-observer and regional variability Acta Obstet Gynecol Scand 1992 71(1):48 53 1315098
Lien JM, Morgan MA, Garite TJ, et al Antepartum cervical ripening: applying prostaglandin E2 gel in conjunction with scheduled nonstress tests in postdate pregnancies Am J Obstet Gynecol 1998 179(2):453 8 9731852
Lumley J, Lester A, Anderson I, et al A randomized trial of weekly cardiotocography in high-risk obstetric patients Br J Obstet Gynaecol 1983 90(11):1018 26 6357270
Lydon-Rochelle M, Holt VL, Easterling TR, et al Risk of uterine rupture during labor among women with a prior cesarean delivery N Engl J Med 2001 345(1):3 8 11439945
MacKenzie IZ, Burns E Randomised trial of one versus two doses of prostaglandin E2 for induction of labour: 1. Clinical outcome Br J Obstet Gynaecol 1997 104(9):1062 7 9307536
Magann EF, Chauhan SP, Nevils BG, et al Management of pregnancies beyond forty-one weeks' gestation with an unfavorable cervix Am J Obstet Gynecol 1998 178(6):1279 87 9662313
Magann EF, McNamara MF, Whitworth NS, et al Can we decrease postdatism in women with an unfavorable cervix and a negative fetal fibronectin test result at term by serial membrane sweeping? Am J Obstet Gynecol 1998 179(4):890 4 9790365
Mahmood TA A prospective comparative study on the use of prostaglandin E2 gel (2 mg) and prostaglandin E2 tablet (3 mg) for the induction of labour in primigravid women with unfavorable cervices Eur J Obstet Gynecol Reprod Biol 1989 33(2):169 75 2684698
Mannino F Neonatal complications of postterm gestation J Reprod Med Obstet Gynecol 1988 33(3):271 6
Martin JN, Sessums JK, Howard P, et al Alternative approaches to the management of gravidas with prolonged-postterm-postdate pregnancies J Miss State Med Assoc 1989 30(4):105 11 2657073
McColgin SW, Hampton HL, McCaul JF, et al Stripping membranes at term: can it safely reduce the incidence of post-term pregnancies? Obstet Gynecol 1990 76(4):678 80 2216203
McColgin SW, Patrissi GA, Morrison JC Stripping the fetal membranes at term. Is the procedure safe and efficacious? Journal of Reproductive Medicine 1990 35(8):811 4 2213744
Mehl-Madrona L, Madrona MM Physician- and midwife-attended home births. Effects of breech, twin, and post-dates outcome data on mortality rates J Nurse-Midwifery 1997 42(2):91 8 9107116
Misra M, Vavre S Labour induction with intracervical prostaglandin Einf 2 gel and intravenous oxytocin in women with a very unfavourable cervix Aust N Z J Obstet Gynaecol 1994 34(5):511 5
Moher D, Jadad AR, Tugwell P Assessing the quality of randomized controlled trials. Current issues and future directions Internat J Tech Assess Health Care 1996 12(2):195 208
Monaghan J, O'Herlihy C, Boylan P Ultrasound placental grading and amniotic fluid quantitation in prolonged pregnancy Obstet Gynecol 1987 70(3 Pt 1):349 52 3306496
Montan S, Malcus P Amniotic fluid index in prolonged pregnancy: A cohort study J Matern Fetal Invest 1995 5(1):4 7
Mouw RJ, Egberts J, Kragt H, et al Cervicovaginal fetal fibronectin concentrations: predictive value of impending birth in postterm pregnancies Eur J Obstet Gynecol Reprod Biol 1998 80(1):67 70 9758262
Mundle WR, Young DC Vaginal misoprostol for induction of labor: a randomized controlled trial Obstet Gynecol 1996 88(4 Pt 1):521 5 8841210
A clinical trial of induction of labor versus expectant management in postterm pregnancy. The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units Am J Obstet Gynecol 1994 170(3):716 23 7710467
[electronic database]. Release 6; 1997 data. Agency for Healthcare Research and Quality: Rockville, MD. Available from: http://www.ntis.gov/fcpc/cpn8834.htm. 1997.
Neilson JP. Mifepristone for induction of labour (Cochrane Review). In: The Cochrane Library, Issue 3, 2001. Oxford: Update Software.
Nocon JJ, McKenzie DK, Thomas LJ, et al Shoulder dystocia: an analysis of risks and obstetric maneuvers Am J Obstet Gynecol 1993 168(6 Pt 1):1732 7 8317515
O'Brien JM, Mercer BM, Cleary NT, et al Efficacy of outpatient induction with low-dose intravaginal prostaglandin E2: a randomized, double-blind, placebo-controlled trial Am J Obstet Gynecol 1995 173(6):1855 9 8610775
O'Reilly-Green CP, Divon MY Predictive value of amniotic fluid index for oligohydramnios in patients with prolonged pregnancies J Matern Fetal Med 1996 5(4):218 26 8796797
O'Reilly-Green CP, Divon MY Receiver operating characteristic curves of sonographic estimated fetal weight for prediction of macrosomia in prolonged pregnancies Ultrasound Obstet Gynecol 1997 9(6):403 8 9239826
Ohel G, Rahav D, Rothbart H, et al Randomised trial of outpatient induction of labor with vaginal PGE2 at 40-41 weeks of gestation versus expectant management Arch Gynecol Obstet 1996 258(3):109 12 8781697
Papageorgiou I, Tsionou C, Minaretzis D, et al Labor characteristics of uncomplicated prolonged pregnancies after induction with intracervical prostaglandin E2 gel versus intravenous oxytocin Gynecol Obstet Invest 1992 34(2):92 6 1398272
Pattison N, McCowan L. Cardiotocography for antepartum fetal assessment (Cochrane Review). In: The Cochrane Library, Issue 1, 2001. Oxford: Update Software.
Pearce JM, Cardozo C. Prolonged pregnancy: the management debate. BMJ. 1988;297:715-7. [pmid: 3147736]. [pmcid: 1834111].
Phelan JP, Platt LD, Yeh SY, et al The role of ultrasound assessment of amniotic fluid volume in the management of the postdate pregnancy Am J Obstet Gynecol 1985 151(3):304 8 3881964
Phelan JP, Platt LD, Yeh SY, et al Continuing role of the nonstress test in the management of postdates pregnancy Obstet Gynecol 1984 64(5):624 8 6493655
Phelps JY, Higby K, Smyth MH, et al Accuracy and intraobserver variability of simulated cervical dilatation measurements Am J Obstet Gynecol 1995 173(3 Pt 1):942 5 7573274
Plaut MM, Schwartz ML, Lubarsky SL Uterine rupture associated with the use of misoprostol in the gravid patient with a previous cesarean section Am J Obstet Gynecol 1999 180(6 Pt 1):1535 42 10368501
Pollack RN, Hauer-Pollack G, Divon MY Macrosomia in postdates pregnancies: the accuracy of routine ultrasonographic screening Am J Obstet Gynecol 1992 167(1):7 11 1442959
Ramrekersingh-White P, Farkas AG, Chard T, et al Self-selected expectant management of post dates pregnancy including the use of Doppler ultrasound J Obstet Gynaecol 1993 13(1):16 9
Rayburn W, Gosen R, Ramadei C, et al Outpatient cervical ripening with prostaglandin E2 gel in uncomplicated postdate pregnancies Am J Obstet Gynecol 1988 158(6 Pt 1):1417 23 3289398
Rayburn WF, Motley ME, Stempel LE, et al Antepartum prediction of the postmature infant Obstet Gynecol 1982 60(2):148 53 7155473
Roberts LJ, Young KR The management of prolonged pregnancy -- an analysis of women's attitudes before and after term Br J Obstet Gynaecol 1991 98(11):1102 6 1760421
Rouse DJ, Owen J, Goldenberg RL, et al The effectiveness and costs of elective cesarean delivery for fetal macrosomia diagnosed by ultrasound JAMA 1996 276(18):1480 6 8903259
Induction of labour: evidence-based clinical guideline number 9. London: Royal College of Obstetricians and Gynaecologists, 2001.
Salamalekis E, Vitoratos N, Kassanos D, et al Sweeping of the membranes versus uterine stimulation by oxytocin in nulliparous women. A randomized controlled trial Gynecol Obstet Invest 2000 49(4):240 3 10828706
Sanchez-Ramos L, Kaunitz AM, Del Valle GO, et al Labor induction with the prostaglandin E1 methyl analogue misoprostol versus oxytocin: a randomized trial Obstet Gynecol 1993 81(3):332 6 8437780
Sarkar PK, Duthie SJ The clinical significance of reduced amniotic fluid index in post-term pregnancy: a retrospective study J Obstet Gynaecol 1997 17(3):274 5 15511849
Sarno AP, Hinderstein WN, Staiano RA Fetal macrosomia in a military hospital: Incidence, risk factors, and outcome Mil Med 1991 156(2):55 8 1900588
Satin AJ, Hankins GD, Yeomans ER A prospective study of two dosing regimens of oxytocin for the induction of labor in patients with unfavorable cervices Am J Obstet Gynecol 1991 165(4 Pt 1):980 4 1951567
Sawai SK, O'Brien WF, Mastrogiannis DS, et al Patient-administered outpatient intravaginal prostaglandin E2 suppositories in post-date pregnancies: a double-blind, randomized, placebo-controlled study Obstet Gynecol 1994 84(5):807 10 7936516
Sawai SK, Williams MC, O'Brien WF, et al Sequential outpatient application of intravaginal prostaglandin E2 gel in the management of postdates pregnancies Obstet Gynecol 1991 78(1):19 23 2047061
Schreyer P, Bar-Natan N, Sherman DJ, et al Fetal breathing movements before oxytocin induction in prolonged prenancies Am J Obstet Gynecol 1991 165(3):577 81 1892182
Sciscione AC, Nguyen L, Manley J, et al. A randomized comparison of transcervical Foley catheter to intravaginal misoprostol for preinduction cervical ripening. Obstet Gynecol. 2001;97:603-7. [pmid: 11275035].
Sherer DM, Onyeije CI, Binder D, et al Uncomplicated baseline fetal tachycardia or bradycardia in postterm pregnancies and perinatal outcome Am J Perinatol 1998 15(5):335 8 9643641
Shime J, Librach CL, Gare DJ, et al The influence of prolonged pregnancy on infant development at one and two years of age: a prospective controlled study Am J Obstet Gynecol 1986 154(2):341 5 2418685
Small ML, Phelan JP, Smith CV, et al An active management approach to the postdate fetus with a reactive nonstress test and fetal heart rate decelerations Obstet Gynecol 1987 70(4):636 40 3627631
Smith GCS. Life-table analysis of the risk of perinatal death at term and post term in singleton pregnancies. Am J Obstet Gynecol. 2001;184:489-96. [pmid: 11228508].
Srisomboon J, Piyamongkol W, Aiewsakul P Comparison of intracervical and intravaginal misoprostol for cervical ripening and labour induction in patients with an unfavourable cervix J Med Assoc Thai 1997 80(3):189 94 9175387
Stenlund PM, Ekman G, Aedo A-R, et al Induction of labor with mifepristone: a randomized, double-blind study versus placebo Acta Obstet Gynecol Scand 1999 78(9):793 8 10535343
Stroup DF, Berlin JA, Morton SC, et al Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group JAMA 2000 283(15):2008 12 10789670
Surbek DV, Boesiger H, Hoesli I, et al A double-blind comparison of the safety and efficacy of intravaginal misoprostol and prostaglandin E2 to induce labor Am J Obstet Gynecol 1997 177(5):1018 23 9396885
Tai-Seale M, Rodwin M, Wedig G Drive-through delivery: where are the "savings"? Med Care Res Rev 1999 56(1):30 46 10189775
Tam W-H, Tai SMB, Rogers MS Prediction of cervical response to prostaglandin Einf 2 using fetal fibronectin Acta Obstet Gynecol Scand 1999 78(10):861 51057761410577614
Tongsong T, Srisomboon J Amniotic fluid volume as a predictor of fetal distress in postterm pregnancy Int J Gynaecol Obstet 1993 40(3):213 7 8096472
Toppozada MK, Anwar MY, Hassan HA, et al Oral or vaginal misoprostol for induction of labor Int J Gynaecol Obstet 1997 56(2):135 9 9061387
Tuffnell DJ, Bryce F, Johnson N, et al Simulation of cervical changes in labour: reproducibility of expert assessment Lancet 1989 2(8671):1089 90 2478849
Varaklis K, Gumina R, Stubblefield PG Randomized controlled trial of vaginal misoprostol and intracervical prostaglandin E2 gel for induction of labor at term Obstet Gynecol 1995 86(4 Pt 1):541 4 7675376
Ventura SJ, Martin JA, Curtin SC, et al Births: Final data for 1998 National Vital Statistics Report vol 48no 3.Hyattsville, MD. National Center for Health Statistics, 2000
Voss DH, Cumminsky KC, Cook VD, et al Effects of three concentrations of intracervical prostaglandin Einf 2 gel for cervical ripening J Matern Fetal Med 1996 5(4):186 93 8796792
Weeks JW, Pitman T, Spinnato JA 2nd Fetal macrosomia: does antenatal prediction affect delivery route and birth outcome? Am J Obstet Gynecol 1995 173(4):1215 9 7485323
Weiner Z, Farmakides G, Schulman H, et al Computerized analysis of fetal heart rate variation in postterm pregnancy: prediction of intrapartum fetal distress and fetal acidosis Am J Obstet Gynecol 1994 171(4):1132 8 7943086
Weiner Z, Reichler A, Zlozover M, et al The value of Doppler ultrasonography in prolonged pregnancies Eur J Obstet Gynecol Reprod Biol 1993 48(2):93 7 8491337
Wing DA, Fassett MJ, Mishell DR Mifepristone for preinduction cervical ripening beyond 41 weeks' gestation: a randomized controlled trial Obstet Gynecol 2000 96(4):543 8 11004356
Wing DA, Jones MM, Rahall A, et al A comparison of misoprostol and prostaglandin E2 gel for preinduction cervical ripening and labor induction Am J Obstet Gynecol 1995 172(6):1804 10 7778636
Wing DA, Ortiz-Omphroy G, Paul RH A comparison of intermittent vaginal administration of misoprostol with continuous dinoprostone for cervical ripening and labor induction Am J Obstet Gynecol 1997 177(3):612 8 9322632
Wing DA, Paul RH A comparison of differing dosing regimens of vaginally administered misoprostol for preinduction cervical ripening and labor induction [published erratum appears in Am J Obstet Gynecol 1997 Jun;176(6):1423] Am J Obstet Gynecol 1996 175(1):158 64 8694043
Wing DA, Rahall A, Jones MM, et al Misoprostol: an effective agent for cervical ripening and labor induction Am J Obstet Gynecol 1995 172(6):1811 6 7778637
Wiriyasirivaj B, Vutyavanich T, Ruangsri RA A randomized controlled trial of membrane stripping at term to promote labor Obstet Gynecol 1996 87(5 Pt 1):767 70 8677083
Witter FR, Weitz CM A randomized trial of induction at 42 weeks gestation versus expectant management for postdates pregnancies Am J Perinatol 1987 4(3):206 11 3300672
Witter FR, Weitz CM Cervical examination prior to induction in postdate pregnancies Surg Gynecol Obstet 1989 168(3):214 6 2645665
Yudkin PL, Wood L, Redman CWG. Risk of unexplained stillbirth at different gestational ages. Lancet. 1987;1:1192-4. [pmid: 2883499].