# Appendixes

## Appendix 1: Data-Abstraction Form

### POST-TERM PREGNANCYARTICLE ABSTRACTING FORM

Reviewer:_________________First Author:___________________________Year:___________Procite #:___________

ARTICLE FOCUS (circle one): Testing / Management / Both

STUDY DESIGN (check one):

_______RCT - Randomization method: | ______Sealed envelope
_______RCT - Randomization method: | ______Date/Chart #
_______RCT - Randomization method: | ______Not described
_______RCT - Randomization method: | ______Other - describe:_____________________________________

______Cohort

______Case series, no controls, n = ______

______Case series, historical controls, n = ______

______Case series, concomitant controls, n = ______

______Not specified or unable to classify

REASSESSMENT:

Recode article as:____________________ | Exclude (give reason):__________________ Note: All non-RCTs should be excluded from the management review

KEY QUESTIONS ADDRESSED (check all that apply):

_____1. What are the test characteristics (reliability, sensitivity, specificity, predictive values) and costs of measures used in the management of postdates pregnancy: (a) to assess risks to the fetus of postdates pregnancy, and (b) to assess the likelihood of a successful induction?

_____2. What are the benefits, risks, and costs of currently available interventions for induction of labor?

_____3. What is the direct evidence comparing the benefits, risks, and costs of planned induction versus expectant management at various gestational ages?

_____4. Are the epidemiology and outcomes of postdates pregnancy different for women in different ethnic groups, different socioeconomic groups, or in adolescent women?

STUDY LOGISTICS:

Inclusive dates of data collection (give month and year): from________________________to_____________________

Multicenter study? (circle one): Yes / No If "Yes," no. of sites:_________

Geographic location (in US, give city and state; outside of US, give city and country. If multicenter trial or network, give name, e.g., NICHD MFM Network, RADIUS):___________________________________________________

TYPES OF PROVIDERS (check all that apply): _______Unspecified OB/GYN _______General OB/GYN _______MFM _______Family practice _______Nurse midwives _______Other midwives _______Other - describe:___________ _______Not specified | STUDY SETTING (check all that apply): _______University hospital _______Community hospital _______Unspecified hospital _______Freestanding birthing center _______Outpatient clinic/physician office _______Not specified or unable to determine _______Other - describe:_______________

GESTATIONAL AGE DETERMINED BY (check all that apply):

______LMP

______1^st^ trimester U/S

______2^nd^ trimester U/S

______Other - specify: __________________________________________________________________________

INCLUSION CRITERIA: | EXCLUSION CRITERIA:

SUBJECT CHARACTERISTICS:

1. Identify interventions A, B, and C, and indicate which (if any) served as control
2. Use "NR" to indicate "Not reported"

| Intervention A = | Intervention B = | Intervention C = | Overall
AGE (specify summary statistic [mean, median] and measure of dispersion [standard deviation, range, etc.]; if age not described in these terms, then enter as reported):
Mean:
Median:
SD:
Range:
RACE (specify distribution):
White:
  n = | / | %
  n = | / | %
  n = | / | %
  n = | / | %
Black:
  n = | / | %
  n = | / | %
  n = | / | %
  n = | / | %
Hispanic:
  n = | / | %
  n = | / | %
  n = | / | %
  n = | / | %
Other:
  n = | / | %
  n = | / | %
  n = | / | %
  n = | / | %
GESTATIONAL AGE AT ENTRY INTO STUDY (specify either summary statistic [mean, median] and measure of dispersion [SD, range] or percent in each category; indicate whether measured in days or weeks)
PARITY (specify either summary statistic [mean, median] and measure of dispersion [SD, range] or percentage in each category):
BISHOP SCORE (specify either summary statistic [mean, median] and measure of dispersion [SD, range] percentage in each category):
OTHER measure of cervical dilatation or effacement (specify):

INTERVENTIONS

Describe the testing and management interventions used in each study group. Include all information necessary to reproduce the treatment/monitoring/testing algorithms used. For example:

Sample Intervention A = Induction If cervix < 3 cm dilated and < 50% effaced and fetal heart rate normal, then pt given PGE2 gel (Prepidil) 0.5 mg intracervically - max of 3 doses at 6-hr intervals - fetus monitored continuously for min of 1 hr after insertion of gel If gel not used or did not induce labor within 12 hrs of insertion of last dose, then labor induced by IV oxytocin or amniotomy or both

Interventions to be considered include:

1. Tests of fetal well-being: No tests, nonstress test, biophysical profile, contraction stress test, amniotic fluid volume, uterine vessel Doppler flow, other, combinations of the preceding
2. Tests of fetal size: Physical exam, ultrasound, other
3. Tests of readiness for delivery: Bishop score, fetal fibronectin, other, combinations of the preceding
4. Interventions: Monitoring/conservative care, stripping of membranes, oxytocin, prostaglandin gel, misoprostil, mechanical interventions

Intervention A =

Intervention B =

Intervention C =

PATIENT NUMBERS, DROPOUTS AND LOSS TO FOLLOW-UP:

Outcome | Intervention A = | Intervention B = | Intervention C =
No. of subjects at start:
No. of subjects who did not receive allocated intervention due to:
  Spontaneous labor:
  Other complications:
  Other/unspecified causes:
  n = | / | %
  n = | / | %
  n = | / | %
No. of subjects who did not receive allocated intervention due to:
  n = | / | %
  n = | / | %
  n = | / | %
No. of subjects who did not receive allocated intervention due to:
  n = | / | %
  n = | / | %
  n = | / | %
No. of subjects at end who had received allocated intervention:
  n = | / | %
  n = | / | %
  n = | / | %
Any post-discharge follow-up? (circle one) | Yes / No | Yes / No | Yes / No
No. of subjects lost to post-discharge follow-up:
  n = | / | %
  n = | / | %
  n = | / | %

MANAGEMENT OUTCOMES:

Outcome Measured (Describe) | How measured, (e.g., scale/units used, %) | Intervention A = | Intervention B = | Intervention C = | P value
FETAL OUTCOMES (e.g., stillbirth, Apgar scores, admission to NICU, shoulder dystocia, weight, etc.):
1)
2)
3)
4)
5)
6)
7)
MATERNAL OUTCOMES (e.g., maternal trauma, C-section rate [with causes], infection, etc.):
1)
2)
3)
4)
5)
6)
7)
OTHER OUTCOMES
1)
2)

TEST PERFORMANCE OUTCOMES (Testing Articles Only):

Comparison 1
| Reference standard/outcome =
Screening test = | Ref standard result 1 = | Ref standard result 2 = | Ref standard result 3 = | Totals:
Screen test result 1 =
Screen test result 2 =
Screen test result 3 =
Totals:

Comparison 2
| Reference standard/outcome =
Screening test = | Ref standard result 1 = | Ref standard result 2 = | Ref standard result 3 = | Totals:
Screen test result 1 =
Screen test result 2 =
Screen test result 3 =
Totals:

Comparison 3
| Reference standard/outcome =
Screening test = | Ref standard result 1 = | Ref standard result 2 = | Ref standard result 3 = | Totals:
Screen test result 1 =
Screen test result 2 =
Screen test result 3 =
Totals:

Other test performance results (including sensitivity and specificity and qualitative results):

COST/CHARGES/RESOURCE UTILIZATION OUTCOMES:

Outcome Measured | How measured, (e.g., scale/units used, %) | Intervention A = | Intervention B = | Intervention C = | P value
Total costs/intervention:
Mean:
Median:
SD:
Range:
Other cost/resource outcome (specify):

QUALITY SCORE:

(Check "Yes" or "No" for each item)

Type of Article | Yes | No
MANAGEMENT ARTICLES
Randomized assignment to intervention?
Randomization method clearly described and appropriate?
Study population similar to likely patient population?
Intervention protocols clearly described or referenced?
Description provided of how decisions made about mode of delivery?
Statistical issues addressed/discussed:
Sample size?
Use of appropriate tests?
Study population characterized by:
Gestational age?
Dating criteria specified?
Bishop score or other measure of cervical ripeness?
TESTING ARTICLES
Reference standard defined?
Randomized assignment to test?
Randomization method clearly described and appropriate?
Verification bias assessed or discussed?
Test reliability/variability addressed or discussed?
Study population well characterized by:
Gestational age?
Dating criteria specified?
Absence of other risk factors (diabetes, HTN, etc.)?
Study population similar to likely patient population?
Testing protocol clearly described or referenced?
Statistical issues addressed/discussed:
Sample size?
Use of appropriate tests?

## Appendix 2: Evidence Table Templates

Template for Evidence Table 1
Study | Design and Interventions | Patient Population | Outcomes Reported | Results | Quality Score/Notes
Author and Pro-Cite # | Design: [RCT, etc., including description of method of randomization] Test(s) studied: 1) 2) 3) etc. Reference standard(s): 1) 2) etc. Dates: Location: Setting: [including whether single- or multicenter] Type(s) of providers: Length of follow-up: | No. of subjects at start: Dropouts: Loss to follow-up: No. of subjects at end: Inclusion criteria: Exclusion criteria: Age: Race: Gestational age at entry: Dating criteria: Parity: Bishop score: Other: [including other measures of cervical ripeness] | 1) 2) 3) 4) 5) 6) 7) 8) 9) 10) 11) 12) 13) 14) 15) | 1) Outcome1: 2) Outcome2: 3) Outcome3: 4) Outcome4: 5) Outcome5: 6) Outcome6: 7) Outcome7: 8) Outcome8: 9) Outcome9: 10) Outcome10: 11) Outcome11: 12) Outcome12: 13) Outcome13: 14) Outcome14: 15) Outcome15: | QUALITY SCORES: TESTING Reference standard: Randomized: Method of randomization: Verification bias: Test reliability/variability: Gestational age: Dating criteria: Other risk factors absent: Similar to likely pt pop: Testing protocol described: Sample size: Statistical tests: MANAGEMENT Randomized: Method of randomization: Similar to likely pt pop: Interventions described: Mode of delivery: Sample size: Statistical tests: Gestational age: Dating criteria: Bishop score:
Template for Evidence Tables 2 and 3
Study | Design and Interventions | Patient Population | Outcomes Reported | Results | Quality Score/Notes
Author and Pro-Cite # | Design: [RCT, etc., including description of method of randomization] Interventions: 1) 2) 3) etc. Dates: Location: Setting: [including whether single- or multicenter] Type(s) of providers: Length of follow-up: | No. of subjects at start: Dropouts: Loss to follow-up: No. of subjects at end: Inclusion criteria: Exclusion criteria: Age: Race: Gestational age at entry: Dating criteria: Parity: Bishop score: Other: [including other measures of cervical ripeness] | 1) 2) 3) 4) 5) 6) 7) 8) 9) 10) 11) 12) 13) 14) 15) | 1) Outcome1: 2) Outcome2: 3) Outcome3: 4) Outcome4: 5) Outcome5: 6) Outcome6: 7) Outcome7: 8) Outcome8: 9) Outcome9: 10) Outcome10: 11) Outcome11: 12) Outcome12: 13) Outcome13: 14) Outcome14: 15) Outcome15: | QUALITY SCORE: Randomized: Method of randomization: Similar to likely pt pop: Interventions described: Mode of delivery: Sample size: Statistical tests: Gestational age: Dating criteria: Bishop score: