# Evidence Tables

Evidence Table 1. Adult Language Disorders -- BDAE-2: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/ Duration | Quality Score (%)
Goodglass and Kaplan, 1983^43^ Instr: BDAE-2 | To provide reliability (ICR, InterR), validity (content, construct), and norms for the BDAE-2 | Cohort w/o comp grp | Inclusion:; 1. Validity/ICR, InterR -- selected for particular types of aphasia (no further info given); 2. Norms -- neuro normal and English-speaking men; Exclusion: NR | Validity: 242/242 ICR: 34/34 InterR: 90/90 w/3 judges Norms: 147/147 | Norm/Validity: NR ICR: Severity level: 0 (no communication possible) to 5(residual aphasia with subj difficulties) # of indiv w/reported severity (01/1/2/3/4/5) 90/11/6/7/6/4 Norms: M/F: 100%/0% | Setting: Boston VA Medical Center Procedures:; 1. ICR, InterR, & Validity -- NR; 2. Norms -- shortened version of BDAE-2, excluded 7 subtests in which normal subjs assumed to make no mistakes | Qcations: NR Training provided: NR | United States | Dates: 1976-1982 (InterR) Duration: N/A | M=45.5% C=31.0%
Rosselli et al., 1990^45^ Instr: BDAE (Spanish) | 1. To provide norms for a Spanish-speaking population; 2. To compare scores of English & Spanish speakers; 3. To analyze the effects of sex, age, and educ on test performance | Cohort w/o comp grp | Inclusion: NR Exclusion: No neuro or psychiatric hx | Overall: 180/180 | Sex: M/F-90/90 M/F-50%/50% Age: 16-65 y Educ: 0-13+ y Recruited from hospitals, factories, universities | Setting: NR Procedures: Spanish BDAE admin; paraphasias, music, artic agility, verbal ability subtests not admin | Qcations: NR Training provided: NR | Colombia | Dates: NR Duration: NR | M=50.0% C=66.7%
Crary et al., 1992^44^ Instr: BDAE (orig) | To compare WAB and BDAE (orig) class. of aphasic patients | Cohort w/o comp grp | Inclusion: had single, left-hemisphere thromboembolic CVA Exclusion: NR | Overall: 47/47 | Sex: NR Age (y): Mn (SD): 57.7 (11.0) Range: 26-84y Educ (y): Mn (SD): 12.0 (2.1) Range: 8-16 Time post-stroke (m): Mn (SD): 16.1 (21.9) Range: 1-80 | Setting: NR Procedures:; 1. WAB & BDAE(orig) admin; 2. Subjs. < 3 m post-onset had both w/in 2 w; subj. > 3 had both w/in 1 m; 3. Order of tests counterbalanced across subjs | Qcations: NR Training provided: NR | United States | Dates: NR Duration: 2 w- 1m | M=57.1% C=48.0%

Evidence Table 2. Adult Language Disorders -- BDAE-2: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Goodglass and Kaplan, 1983^43^ Instr: BDAE-2 | ICR: Statistical Method: Kuder-Richardson statistic (ICR) KR stat ranged from 0.68 to 0.90; 14 scores in the 0.90-0.95 range InterR: Statistical Method: Pearson's corr Corrs range from 0.78-0.90 T-RR: NR IntraR: NR | 1. KR coefficients indicate good ICR within subtests; 2. Low InterR corrs for word-finding and paraphasia subtests correspond to the subj uncertainty involved in rating; conclude that these are minimal estimates of InterR nature of rating; 3. InterR -- authors conclude that high InterR and high subtest ICRs make it acceptable to have a single rater | 1. Repeatability varies among aphasics to a high degree; thus T-RR may not be meaningful; 2. InterR corrs are from most disparate pair of ratings to serve as lower bound; may be a problem in not taking into acct inter-class corrs; 3. Insuff detail on statistical and research methods used; 4. Insuff detail on sample characteristics

Evidence Table 3. Adult Language Disorders -- BDAE-2: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Goodglass and Kaplan, 1983^43^ Instr: BDAE-2 | Statistical methods: Correlations, factor analysis w/promax rotation, discriminant analysis Content: Description of areas of deficit and how BDAE-2 tests for them Construct:; 1. Corrs -- Overall severity rating & each subtest (range: −0.24 to 0.79); Fluency of Speech Output (range: 0.59 to 0.93); Auditory Comprehension (range: 0.69 to 0.84); Word Finding (range: 0.56 to 0.90); Recitation-Repetition (range: 0.49 to 0.86); Paraphasia (range: −0.24 to −0.55); Reading (range: 0.31 to 0.78); Writing (range: 0.34 to 0.85); Visuospatial-Quantitative (range: 0.30 to 0.63); 2. Factor analysis -- 5 separate analyses conducted with diff subsets of sample and subtests. Authors note that several of the factor structures (FA1 and FA2) match that from the BDAE (orig). One analysis w/ "prototypical" patients yielded results similar to FA1; 3. Discriminant Analysis employed with selected subjs with Broca's, Wernicke's, conduction, and anomic aphasia. Most effective separation gained with body-part identification, repetition of high probability sentences, verbal aphasias, articulatory agility rating, automatized sequences. All but one subj was classified into original classification (did not meet 0.70 prob of diagnosis). Use of 6 variables resulting in misclassification of 2 of 43 subjs; Concurrent: NR Divergent: NR | 1. Intercorrelations between subtests are higher than BDAE (orig), probably due to includes of very and moderately severe mixed aphasia | 1. Authors acknowledge that sampling is limited but encourage others to vary procedures as needed.; 2. Authors indicate that scores do not objectively & automatically classify subjs.; 3. Insufficient detail provided on sample used for validity testing.; 4. Unclear whether results from a single setting and single sex are generalizable.; 5. Classification of prototypical subjs not likely to be generalizable to aphasic subjs in general.
Rosselli et al., 1990^45^ Instr: BDAE (Spanish) | Statistical Method: ANOVA and corrs; no corrections for multiple comparisons Corrs of 28 subtests and age, educ, sex:; 1. 17/28 sign neg corr w/ age (r=−0.13 to −0.44); 2. 25/28 sign pos corr w/ educ (r=0.1 to 0.64); 3. 1/28 showed sign corr w/ sex, but could have been due to chance; Comp by age and education attainment:; 1. 17/28 subtests sensitive to age with younger subjs scoring better. Largest diffs in confrontation naming, symbol discrimination, oral spelling, serial writing, and written confrontation; 2. 25/28 subtests sensitive to educ level w/ grps having more educ scoring better. Most diffs found betw low and middle educ grps, with less diff betw middle and high educ grps | 1. Spanish BDAE is sensitive to age and educ like the English version.; 2. Most important diffs w/in educ level occur betw the lowest grp and the middle grp.; 3. No sex diffs w/Spanish-BDAE.; 4. Suggest that norms could be useful in other Span-speaking, Latin-Amer countries and in the US. | 1. No corrections for multiple comparisons, but the do recognize it may be problem with corrs betw sex and test scores; 2. Corrs are modest at best (w/ educ) and weak for age; 3. Describe diffs betw grps w/in the ANOVA procedures, but provide no stats as evidence; 4. Spelling unusual task in Spanish given as expla-nations for diffs betw Engl and Span
Crary et al., 1992^44^ Instr: BDAE (orig) | Statistical Method: Cluster analysis (Q-analysis) BDAE (orig):; 1. 4 clusters of which 3 acct for 97% of the total variance (one factor contained only 1 subj). Clusters named by comp of Mn performance on BDAE w/ the orig BDAE classification; 2. BDAE (orig) classification does not agree well w/ results of the cluster analysis, with only 38% of the cases matching; WAB:; 1. 7 clusters of which 4 acct for 89% of the total variance. Clusters named by comparison of subj Mn performance on WAB w/ the WAB classification; 2. Clusters name by comparing subj Mn performance on BDA chars with the orig BDAE classification system; 3. WAB classification does not agree well w/ results of the cluster analysis, with only 30% of the cases matching | 1. Poor agr of BDAE (orig) w/ cluster analysis suggests that BDAE (orig) may not correctly classify aphasics; 2. Cluster analysis provides better support for BDAE (orig) than WAB in classifying aphasics | 1. Level of heterogeneity betw BDAE (orig) & WAB disturbing given assumption that both measure same underlying phenomenon; 2. Sample size is small with little information on subjs or setting; results may not be generalizable

Evidence Table 4. Adult Language Disorders -- BDAE-2: Normative Data Outcomes

Author (year) | Population to Which Standardized Population/Source Characteristics | Score Reported | Other Analyses
Goodglass and Kaplan, 1983^43^ Instr: BDAE-2 | Population/Source: NR Characteristics: NR | Mn, SD, %ile and cutoff score | 1. Norms derived from relatively small, geographically isolated sample, and all are men; may not be generalizable; 2. Distribution of severity is unk and may be highly skewed, thus the sig of Mn score may not be known
Rosselli et al., 1990^45^ Instr: BDAE (Spanish) | Population/Source:; 1. Spanish speakers from one country;; 2. no comp to standard sources; Characteristics: NR | Mns, SD, & range for 28 BDAE (Spanish) subtests by: Age (y): 16-30, 31-50, 51-65 Education (y): 0-5, 6-12, 13+ Suggested cut-off by educ level: Mn (for educ level)-2SD(educ level) | Norms, derived from relatively small geographically similar sample, may not be generalizable to all Spanish speakers despite claims of authors

Evidence Table 5. Adult Language Disorders -- PICA: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/ Duration | Quality Score (%)
Porch, 1967^46^ Instr: PICA | To report development and reliability (ICR, InterR, T-RR) and validity (content, construct) results of the PICA | Cohort w/o comp grp | Inclusion:; 1. Brain injury dx; 2. Referral for investigation of comm disability; 3. (T-RR) availability for retesting at 2 w; Exclusion:; 1. Subjs physically unable to take PICA,; 2. Subjs who refused | Overall: 150/150 * reliability samples taken from overall sample ICR: 30/30 T-RR: 40/40 InterR: 30/30 | Overall: Sex: M/F: 57.3%/42.7% Age (y): Mn(SD): 60.5(15) Range: 18-90 Race (Wh/AA/A)s: 74%/24.7%/1.3% Educ (y): Mn(SD): 8.22(4.19) Range: 0-17 Time post-onset (w): Mn: 29.21 (1-512) ICR: Age: Mn(SD): 59.37(11.51) Educ(y): Mn(SD): 6.53(4.31) Race: (Wh/AA) (76.7%/23.3%) Time post onset(w): Mn: 17.47 (1-200) T-RR: Sex: M/F: 60%/40% Age (y): Mn: 60 Race: (Wh/AA) (72.5%/27.5%) Educ(y): Mn: 8.45 Time post onset (w): Mn: 37.97 (1-478) InterR: Age: Mn(SD): 59.37(11.51) Educ(y): Mn(SD): 6.53(4.31) Race: (Wh/AA) 76.7%/23.3% Time post onset (w): Mn: 17.47 (1-200) | Setting: NR Procedures:; 1. PICA admin by clinicians; 2. (T-RR) PICA repeated at 2 w | Qcations: SLPs, w/ varying levels of experience Training provided: 30-40 h | United States | Dates: NR Duration: Data collected over 2-y period; T-RR 2w | M=51.6% C=52.9%
Disimoni et al., 1975;^121^ Dismoni et al., 1980^122^ Instr: PICA | To develop and test 2 shortened versions of the PICA. | Reliability/validity study | Inclusion: Aphasic subjs tx in speech pathology clinic. Exclusion: Confused or demented subjs | Development: 222/222 Test of PICA vs. Shortened PICA: 93/93 Judges: 1/1 | NR | Setting: SL clinic Procedure:; 1. PICA admin according to test man; 2. Full PICA & 2 shortened versions admin to all subjs; order varied; 3. Shortened version, 4 Subtests w/ all 6 items vs. 17 subtests for 2 items | Qcations: "Experienced PICA examiner" Training provided: NR | United States | Dates: NR Duration: 3d | (1975) M=53.8% C=50.1% (1980) M=64.3% C=46.7%
Clark et al., 1979^47^ Instr: PICA | To assess the factor structure associated w/ PICA subtests. | Validity study | Inclusion:; 1. Dx of brain insult w/ associated communication disability; 2. Willing/able to tolerate testing procedure; Exclusion: NR | Overall: 150/150 Typographical error in article does not match gender breakdown | Subjects: Sex(M/F): 86/66 Age Mn(SD): 60.5(15) Educ Mn(SD): 8.22(4.19) | Setting: NR Procedure: NR | Qcations: NR Training provided: NR | Canada | Dates: NR Duration: NR | M=71.4% C=70.6%
Hanson et al., 1982^123^ Instr: PICA | To define aphasia categories using PICA scores. | Validity study | Inclusion: Overall: PICA test < 6 mos post onset Subsample:; 1. Aphasia from a single left-hemisphere CVA; 2. Right-handed & fluent in English (pre-morbidly); Exclusion: Overall: NR Subsample (only):; 1. No hx neuro disease or inj; 2. No hx severe uncontrolled hypertension. | Overall: 118/118 Subsample: 52/52 | Subjects: Age Mn(SD): 54.2(11.9) Time post-onset (Mn): 20.4 d Dx: Vascular: 82% Traumatic: 7.6% Post-surg: 8.4% Unk: 2% | Setting: NR Procedure: Subjs selected based on completing PICA < 6 mos post onset. | Qcations: NR Training provided: NR | United States | Dates: NR Duration: NR | M=71.4% C=55.6%
Lendrem and Lincoln, 1985^48^ Instr: PICA | To identify predictors of recovery at 6 mos in untx aphasics. | Prosp cohort w/o comp grp (subset of control arm of RCT) | Inclusion: Control grp in study of SL tx. Exclusion:; 1. Minimally or severely impaired as measured by Whurr Aphasia Screening Test.; 2. Severe dysarthria as measured by Frenchay Dysarthria Assessment. | Overall: 164/52 Judges: 2/2 | Sex:(M/F): 32/20 Age (y): Mn(SD): 67.0(8.4) Range: 48-80 Dx: Broca's: 10 Wernicke's: 13 Conduction: 8 Anomic: 16 Unclassified: 5 | Setting: Hospital or Speech Therapy Department Procedure:; 1. All subjs assessed using PICA 3-4 w post-onset; 2. Subjs assessed using PICA at 6-w intervals w/ final at 34 w | Qcations: SLP Training provided: NR | England | Dates: NR Duration: 30 w | M=52.9% C=30.0%
Lincoln and McGuirk, 1986^49^ Instr: PICA | To assess accuracy of Porch's prediction methods for aphasic subjs receiving SL tx. | RCT for SL tx | Inclusion: NR Exclusion:; 1. Minimally or severely impaired as measured by Whurr Aphasia Screening Test.; 2. Severe dysarthria as measured by Frenchay Dysarthria Assessment. | Overall: 124/124 Tx Group: Expt: 68 Cntl: 56 | Age (y): Mn(SD): 66.27(9.93) Range 38-92 Dx: Broca's: 26 Wernicke's: 25 Conduction: 22 Anomic: 34 Global: 10 Unclassified: 7 | Setting: Hospital or Speech Therapy Dept Procedure:; 1. All subjs assessed w/ PICA 3-4 w post-onset; 2. Expt grp received Sp tx 2x/w from 10-34 w; 3. Expt/cntl assessed using PICA at 6-w intervals w/ final at 34 w | Qcations: NR Training provided: NR | England | Dates: NR Duration: 30 w | M=86.7% C=75.0%

Evidence Table 6. Adult Language Disorders -- PICA: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Porch, 1967^46^ Instr: PICA | ICR: Statistical Method: Spearman-Brown reliability w/split-half design, ANOVA; 1. Spearman-Brown coeffs=0.82-0.99 across judges and subtests; 2. Lowest coeffs found in gestural subtests; 3. Corrs from ANOVA results=0.88-0.99; T-RR: Statistical Method: Corr, absolute diff betw 1^st^ & 2^nd^ scores; 1. Corrs for 18 subtests=0.70-0.99; corrs for gestural modality=0.96, verbal=0.99, graphic=0.96, overall=0.98.; 2. Absolute diffs betw 1st & 2nd=0.29-1.39; 3. No sign corr betw absolute diff & time since onset; InterR: Statistical Method: ANOVA, corrs; 1. Variability betw scorers stat sign for 3 subtests (C, III, E), overall and gestural responses (p<0.05); 2. Corrs > 0.93 for subtests and > 0.97 for response modalities; 3. Interscorer diff attributed to a single scorer | 1. High ICR estimates suggest that the subtests are internally consistent wrt this data set and these scorers; 2. High T-RR coeffs and small absolute diffs suggest stability; 3. Inter R corrs relatively high suggesting adequate reliability | 1. T-RR -- not all of retests were completed by same judge; 2. No corrections for multiple comparisons (Inter R); 3. Use of statistical methods not in common practice now; 4. Insuff info on pt recruitment; not possible to determine whether data are generalizable

Evidence Table 7. Adult Language Disorders -- PICA: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Porch, 1967^46^ Instr: PICA | Construct: Statistical methods: Pearson correlation coefficients Correlations betw scores and pt chars:; 1. Age sign neg corr w/ overall (r=−0.18, p<0.05), gestural(r=−0.18, p<0.05), & graphic scores(r=−0.17, p<0.05); 2. Educ sign pos corr w/ graphic modality score (r=0.32, p<0.01); 3. Age sign neg corr w/ 8 subtests (corr=0.16-0.18, all p< 0.05); 4. Educ sign pos corr w/ 9 subtests (corr=−0.17 (verbal XII)−0.33, all p<0.05); Subtest interCorrelations: In general, corrs higher w/in modality than betw modalities.; 1. Corrs(w/in gestural)=0.39-0.92, betw gestural and other modalites=0.30-0.74; 2. Corrs(w/in verbal)=0.79-0.94, betw verbal and other modalites=0.35-0.74; 3. Corrs(w/in graphic)=0.56-0.96, betw graphic and other modalites=0.28-0.71; Subtests most highly corr w/ those of similar difficulty (corrs=0.27 to 0.96) | Higher corrs w/in modalities than betw modalities suggest construct validity | 1. No corrections for multiple comparisons; 2. Pos corr betw Graphic & educ problematic given author's explicit statement that tasks not demanding in terms of educ; suggests that this subtest may not assess stated modality; 3. Insuff info on pt recruitment; not possible to determine whether data are generalizable
Disimoni et al., 1975^121^ 1980^122^ Instr: PICA | Development of Shortened Versions Statistical methods: Stepwise regression; 1. Use of data from more than 4-7 subtests adds very little to ability to predict total PICA score; data from > 10 provides virtually no addl predictive power; 2. Shortened version (SPICA) w/ subtests I(describing fxn), VI(pointing to object by fxn), VI(reading name and position), & D (writing name, spelling dictated) predicted 98% of total variation; Comparison of Shortened Versions vs. Original PICA: Statistical methods: Correlation coefficients, ANOVA; 1. NS diffs betw Mns of any of the tests (the full PICA and the two SPICAs); 2. Corrs betw PICA &SPICA=0.95-0.96; 3. SPICAs took approx 1/3 of the time a full PICA admin required Mn(SD)=12.5(4.4) 4-subtest & 14.4(4.2) 17-subtest, 2-item vs. 43.3(13.5) PICA | The full PICA is highly redundant. Either SPICA will yield an effective estimate of the full PICA score | By author: NR By reviewer: Authors mention abnormalities in raw score agr but do not investigate
Hanson et al., 1982^123^ Instr: PICA | Construct Validity: Statistical methods: Factor analysis, cluster analysis, discriminant fxn analysis Factor Analysis:; 1. Using overall sample, 5 factors acct for 83.9% of total variance; 2. Factor 1(Speaking) incl PICA 2,4,9,& 12; Factor 2(Writing) incl A,B,C, & D; Factor 3 (Comprehension-Spoken and Written) incl 5, 6, 7, & 10; Factor 4(Gesturing) incl 2 & 3; and Factor 5(Copying) incl E & F); 3. 5 distinct categories were derived; each had sig (p<0.05) different factor scores; 4. Discriminant fxn analy using the factor scores of all subjs correctly identified 80.7% of the subsample (n=52) | Results suggest five factors underlie aphasia as assessed by the PICA | By authors: NR By reviewer: Factors 4 and 5 contain only 2 items
Clark et al., 1979^47^ Instr: PICA | Construct Validity: Statistical methods: Principal Components Analysis w/ orthogonal & oblique rotations; 1. 3 factors acct for 82.7% of the total variance.; 2. Factor1 (verbal lang) incl PICA subtests 1, 4, 9, & 12; 3. Factor 2(graphic lang) incl PICA subtests A, B, C, D, & E; 4. Factor 3(gestural lang) incl 2, 3, 5, 6, 7, 8, 10, 11, & F | Factor structure of the PICA matches Porch's initial suggestions fairly well | By author: NR By reviewer:; 1. Error in reporting sample size and sex distribution

Evidence Table 8. Adult Language Disorders -- PICA: Predictive Validity Outcomes

Author(s) (year) | Predictive Validity Results Hypotheses tested Results | Conclusions | Limitations of Study
Lendrem andn Lincoln, 1985^48^ Instr: PICA | Hypothesis: PICA scores at 4 w should accurately predict PICA scores at 34 w Statistical methods: Stepwise regression Results: 3 PICA scales (verbal, gestural, & graphic) acct for 69% of the total variance in PICA scores at 34 w | Results suggest that PICA scores at 4 w can be used to predict levels at 6 ms | By author: NR By reviewer: 4. Small sample size. 1. Assesses improv w/o tx only 2. Hierarchical regression preferred methods rather than stepwise regression
Lincoln and McGuirk, 1986^49^ Instr: PICA | Hypotheses:; 1. Both high-overall prediction (HOAP) & Porch's statistical method should accurately predict PICA scores at 6 mos once initial assessment is made; 2. PICA level predicted by either method would be sign lowered that that actually reached at 6 mos; 3. Close relation betw High-Low gap at initial assessment & amt of improv betw initial & final assessment; Statistical methods: t-tests, Spearman corr coefficients; 1. Untx subjs scored sign lower than both methods predicted (HOAP: t(55)=3.30, p=0.002; Statistical Method: t(55)=3.43, p=0.001); 2. Tx subjs scored sign lower than the statistical method (t(64)=2.24, p=0.028) but not the HOAP method; 3. The propn of subjs in each group whose predictions were accurate (predicted w/in +/− 10% of actual) are: (HOAP) -- tx=26%, Untx=58%; (Statistical method) -- tx=41%, Untx=64%; 4. Corr betw Hi-Low gap & improv=−0.02 to 0.18 (all NS) | Porch's proposed methods of predicting recovery from PICA scores are extremely poor and should not be used in the clinical setting | Suggested that findings may be due to selection of subjs, but indicate that they cannot verify info about Porch's subjs

Evidence Table 9. Adult Language Disorders -- WAB: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/Duration | Quality Score (%)
Kertesz, 1982^50^ Instr: WAB (1982) | To provide concur-rent validity data com-parable to orig WAB | Prosp cohort w/o comp grp | Inclusion:; 1. Consecutively seen subjs; 2. Stable chronic infarcts (19/20) or head injury (1/20); Exclusion: NR | Subjects: 20/20 Judges: > 1 | Sex: M/F: 11/9 Time post onset: 3mo-7y | Setting: NR Procedures; 1. Orig and new version WAB admin, alternating order; 2. Time betw tests > 1d (Mn=16 d); 3. 35/40 tests given by same judge | Qcations: NR Training provided: NR | Canada | Dates NR Duration: >=1d (Mn=16d) betw tests | M=22.7% C=13.3%
Kertesz and McCabe, 1977^54^ Instr: WAB | 1. To assess T-RR of WAB; 2. To assess pattern of recovery from aphasia. | Controlled trial, non-randomized | Inclusion: Aphasics w/ >2 exams w/in specified time period Exclusion: Subjs w/ tumors | Overall: 93/93 (note: most analyses done with CVA group, N=36/36) T-RR: Unk/22 | Sex: M/F: 58/35 Age (y): Mn: 57.4 Range: 16-85 Educ (y): Mn(SD): 9.6(3.4) Range: 2-19 Dx: Infarcts/Intracranial hemorrhage: 47 Subarachnoid hemorrhage: 12 Trauma: 7 | Setting: VA hospital & other setting NR Procedures:; 1. Initial WAB administration occurred 0-6 w post-onset; 2. Subjs reassessed at 3 mos, 6 mos, then at yearly intervals | Qcations: NR Training provided: NR | Canada | Dates: NR Duration: "a few months post onset" to 17 years after initial onset | M=64.3% C=42.9%
Shewan and Kertesz, 1980^51^ Instr: WAB (1974) | To report the reliability (ICR, T-RR, InterR, IntraR) & validity (content construct) of WAB | Cohort w/ comp grps | Inclusion:; 1. Clinical presentation as aphasic (global, Broca, conduction, Wernicke's, anomic); 2. 3 control grps -- non-brain damaged neuro subjs, subjs w/ non-dominant hemispheric lesion, brain-damaged but no aphasia; Exclusion:; 1. Subjs w/ retardation, psychiatric disturbance, English lang barrier; 2. (T-RR) acute aphasic pts (1^st^ 2 to 3 w post onset) | Subjects: unk/150 ICR: Unk/140 T-RR: Unk/38 IntraR/InterR: 10/10 Construct Validity: Factor Analysis: Unk/142 (data from another study) Concurrent/Divergent: WAB/NCCEA: Unk/15 WAB/RCPM Unk/140 WAB w/ cntl grps: Unk/235 Judges: InterR: 8 IntraR: 3 | Reliability: Sex: NR Age (y): Aphasic: Mn: 61 (19-88) Normal: Mn: 61 (31-71) Nondominant Hemispheric: Mn: 57 (42-80) Brain damaged: Mn: 59 (16-75) Educ (y): Aphasic: Mn: 8 (0-16) Normal: Mn: 10 (6-17) Nondominant Hemispheric: Mn: 10 (4-15) Brain damaged: Mn: 11.5 (4-16) SES: NR (inferred to be similar based on hosp cachement area) Dx (#): Global: 26 Broca: 24 Wernicke's: 27 Anomic: 40 Conduction: 15 Construct Validity: Factor Analysis: Etiology of cerebral infarct Concurrent/Divergent: WAB/NCCEA: Dx (#): Global: 1 Broca: 3 Wernicke's: 2 Anomic: 8 Conduction: 1 WAB/RCPM: NR WAB w/ cntl grps: Dx (#): Non-brain injured: 31 Nondominant Hemispheric: 70 Diffuse lesions: 31 Global: 24 Broca: 25 Wernicke's: 18 Anomic: 37 Conduction: 13 | Setting: Hospital Procedures:; 1. WAB admin according to protocol; 2. (T-RR) 2^nd^ test admin at 6 mo to 6-5 y; 3. (IntraR) 3 judges scored videotaped admin on 2 occasions; 4. (InterR) 8 judges independently scored 10 videotaped WAB admin | Qcations: NR Training provided: NR | Canada | Dates: NR Duration:; 1. T-RR: 6 mos-6.5y (Median 12-23 mo); 2. IntraR: "several months" | M=72.4% C=73.5%
Shewan, 1986^53^ Instr: WAB (1974) | To document the reliability & validity of the Language Quotient (LQ), a new composite WAB score | Retro cohort w/o comp grp | Inclusion:; 1. Subjs w/ single unilateral occlusive CVA; 2. Functional English speakers; 3. Passed an audiometric screening test; Exclusion: Subjs who remained in the study < 6 mos | Subjects: 94/50 ICR: Unk/140 (from prev study) T-RR: Unk/32 or 25 depending upon subtest IntraR/InterR: 10/10 Judges: InterR: 8 IntraR: 3 | Subjects: Sex: M/F: 55/39 Age (y): Mn: 65.02 Range: 29-85 Educ (y): Mean: 9.86 Range: 2-21 SES (Blishen): Mn: 38.94 Range: 24.27-72.73 Dx (orig sample): Global: 26 Broca; 24 Wernicke's: 27 Anomic: 40 Conduction: 15 Judges: "Trained examiners" | Setting: NR Procedures:; 1. WAB admin 2-4 w post-onset, then at 3, 6, and 12 mos; 2. IntraR scored at 3-mo interval; 3. InterR -- 8 judges indep scored 10 videotaped WAB admin | Qcations: NR Training provided: NR | Canada | Dates: NR Duration: 6 or 12 ms T-RR: 6 ms IntraR: "several months" | M=76.9% C=51.6%
Crary and Gonzalez Rothi, 1989^55^ Instr: WAB | 1. To evaluate the relation-ships betw the 10 WAB subtests & the Aphasia (AQ); 2. To eval the effect of time post-onset on these relation-ships | Retrospective cohort w/out comp grp | Inclusion: Aphasic secondary to single LH thromoembolytic stroke Exclusion: NR | Overall: 100/100 | Sex: NR Age (y): Mn: 63 (18-89) Time post onset (mo): Mean: 8 (3 d-84 mos) Dx (%): Broca: 22 Anomic: 21 Wernicke: 19 Global: 15 Conduction: 8 Transcortical: 12 | Setting: Teaching hospital, nursing home, and VA medical center Procedures: WAB results obtained retrospectively from charts | Qcations: NR Training provided: NR | United States | Dates: NR Duration: NR | M=64.3% C=29.2%
Lincoln et al., 1989^56^ Instr: WAB | To identify factors associated with a poor prognosis for patient recovery | Prospective cohort w/o comp grp | Inclusion: Subjs admitted to the stroke unit Exclusion:; 1. Subjs unfit for intensive rehab; 2. Subjs w/ mild disability likely to be discharged in < 2 w | Overall: 70/54 | At follow-up: Sex: M/F: 29/25 (53.7%/46.3%) Age: Mn(SD): 62.7(10.1) Range: 36-88 y Dx: RH lesions: 54% LH lesions: 42% Brainstem lesions: 2% Unk: 2% | Setting: Stroke rehab unit Procedures:; 1. WAB admin at admission w/ other standardized tests; 2. ADLs measured at discharge | Qcations: NR Training provided: NR | United Kingdom | Dates: 10/85-4/86 Duration: 9 mos | M=56.3% C=57.1%
Crary et al., 1992^44^ Instr: WAB | To compare WAB & BDAE (orig) classifications of aphasic patients | Cohort w/o comp grp | Inclusion: had single, left-hemisphere thromboembolic CVA Exclusion: NR | Overall: 47/47 | Sex: NR Age (y): Mn (SD): 57.68 (10.98) Range: 26-84y Educ (y): Mn (SD): 11.95 (2.13) Range: 8-16 Time post-stroke (m): Mn (SD): 16.08 (21.94) Range: 1-80 | Setting: NR Procedures:; 1. WAB & BDAE(orig) admin; 2. Pts < 3 mos post-onset had both w/in 2 w; pt > 3 mos had both w/in 1 mo; 3. Order of tests counterbalanced across subjs | Qcations: NR Training provided: NR | United States | Dates: NR Duration: 2 w- 1m depending upon time since onset | M=57.1% C=42.9%

Evidence Table 10. Adult Language Disorders -- WAB: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Kertesz and McCabe, 1977^54^ Instr: WAB | Statistical methods: t-test, corr T-RR: Pearson corr betw first and second test (admin after 2 y)=0.992 (p<0.01) Other Analyses:; 1. No sign corr betw sex and AQ or age and AQ.; 2. Corr betw initial severity and final outcome=0.849, p<0.01 | WAB exhibits excellent test-retest reliability in subjs w/ stable aphasia | 1. Sparse statistical results as they pertain to the reliability of the WAB; 2. Sample size small for diff grps of aphasics; results not likely generalizable to other populations; 3. Current clinical tx for aphasia may be diff from that provided in study
Shewan and Kertesz, 1980^51^ Instr: WAB (1974) | Statistical methods: Pearson's corr, Cronbach's coefficient alpha, Bentler's theta ICR:; 1. Alpha=0.905; Bentler's theta=0.974; 2. Corrs betw subtests range from .046-0.88; all but 5 of corrs >0.60; 3. Info content subtest corrs highly (0.64-0.88) w/ other test; writing and read subtest corr highly w/ each other and construction subtest; T-RR:; 1. Corrs=0.88 to 0.97, all except praxis subtests sign at p< 0.001; 2. Mn change in scores betw admin < 10% for each subtests; IntraR:; 1. Corrs (betw 3 judges) range=0.79-1.00; 2. Of 6 corr < 0.98, 5 were from info content and fluency subtests; InterR:; 1. Corrs by subtest and judge > 0.90 for all subtests except fluency; corrs for fluency=0.77-0.84); 2. Mn Corr across 8 judges range=0.984-0.999 for the subtests | 1. WAB subtests, and AQ have sufficient reliability (in terms of ICR, InterR, IntraR, T-RR); 2. Since WAB admin by 2 judges for T-RR, results represent conservative estimate of T-RR | 1. Small sample size for reliability studies; 2. Data from single institution may not be representative of all aphasic subjs
Shewan, 1986^53^ Instr: WAB (1974) | Statistical methods: Pearson's correlation, Cronbach's coefficient alpha, Bentler's theta ICR: Alpha=0.91; Bentler's theta=0.97 T-RR: Corrs=0.88 to 0.97 IntraR: Corrs (3 judges) range=0.79-1.00 InterR: Corrs (8 judges) range=0.98-0.99. | WAB subtests that contribute to the LQ demonstrate sufficient reliability (in terms of ICR, InterR, IntraR, T-RR) | 1. ICR results reported on data from diff study; 2. No statistical analyses were performed on actual LQ scores; 3. Statistical methods beyond corr would be desirable

Evidence Table 11. Adult Language Disorders -- WAB: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Kertesz, 1982^50^ Instr: WAB (1982) | Statistical methods: Pearson correlations, Student's t tests Concurrent:; 1. 2 of 20 subjs changed category after classification by new WAB. Classification change due to changes in Repetition subtest score; 2. All corrs (org vs. new WAB) stat sign, range=0.85-0.99; 3. AQ corr (orig vs. new WAB)=0.99; 4. No sign diff in Mn scores betw orig and new WAB at p=0.01, except for repetition subtests, which had sign lower test scores | 1. Since prev version extensively stdized, no effort made to test reliability; 2. No substantial diff betw new version and previously stdized version | 1. No corrections for multiple comparisons; 2. Standardization sample size small; 3. No information provided on test construction or modification; 4. t-statistics NR for comparisons betw orig and new version; 5. Info on methods, subjs, and conduct of study missing
Shewan and Kertesz, 1980^51^ Instr: WAB (1974) | Statistical methods: ANOVA, Newman-Keuls post hoc comparisons, r-type principal components analysis, Pearson corrs Content: Authors suggest that subtests assess all lang modalities and are comparable in content to other batteries assessing aphasia (including the Boston Diagnostic Aphasia Examination) Construct (Principal Components Analysis):; 1. 4 prin comps (PCs) account for 100% of total var); 2. First PC accts for 82% and loads equally on 5 AQ subtests; PC1: accts for 82% and loads equally on 5 AQ subtests PC2: accts for 9%, fluency and comprehension subtests PC3: accts for 7%, repetition and information content PC4: accts for 2%, naming Concurrent: WAB/NCCEA:; 1. Corrs betw WAB and NCCEA subtests high (r=0.817-0.915, all p< 0.01); 2. Corr betw WAB and NCCEA summed scores=0.973; Divergent/Discriminant: WAB/RCPM: Corr betw AQ and RCPM score=0.547; approx 30% of variance overlaps WAB (w/ 3 cntl groups):; 1. Sig diff betw WAB AQ scores betw diff types of aphasics and 3 cntl groups (F=369.4, p<0.001); 2. Post hoc comparisons found cntl grps sign diff from all expt'l grps, except anomics; overlap betw anomics and normals=7% if threshold set at Normal Mn-2SD; 3. Cntl grps do not diff sign from each other | 1. WAB content similar to other aphasia batteries & corrs highly w/ NCCEA; 2. WAB diverges appropriately from RCPM, a test not related to aphasia; 3. WAB reliably differentiates betw aphasics and non-aphasic subjs w/ small overlap betw highly functioning anomics and normals | 1. Sample sizes for some of aphasic groups small (<20); 2. Reports data from earlier studies, little info provided on those studies; 3. Statistics not reported for post hoc comparisons.; 4. Data from single institution may not be representative of all aphasic patients
Shewan, 1986^53^ Instr: WAB (1974) | Statistical methods: ANOVA, Newman-Keuls post hoc comparisons Content: Authors deems LQ behaviors to be representative of important aspects of aphasia Construct:; 1. Time is a sign predictor of LQ (F=43.33, p<0.00001). LQ scores increased over time (initial to last test) by 27.17 and 11.72 for tx and untx groups, respectively; 2. LQ scores of mild, moderate, and severe (based on initial AQ) increased over time. Time (F=106.64, P, 0<0.0001) and severity (F=77.25, p<0.0001) had sign main effects; 3. More severe aphasics had sign lower LQ scores, but there was no interaction between time and severity, which indicates that improvement over time in LQ scores did not vary by severity level. Moderate and severe groups improved 27.14 and 27.35 points, respectively; mild pts improved by 17.18 points | To the extent that the WAB demonstrates validity, so do the sections the LQ draws from | 1. LQ correlates 0.98 with the overall AQ, which indicates that it may not provide any new/useful info; 2. Sample sizes small (under 20 except for severe) for severity subgroups; 3. Reports data from earlier studies; difficult to determine what is original research, if any
Crary and Gonzalez Rothi, 1989^55^ Instr: WAB | Statistical methods: Corr, stepwise and maximum R^2^ regression analysis Correlations:; 1. Corrs betw subtests and AQ=0.56 (Yes-No Questions) to 0.93 (Information Content, IC). All p<0.05; 2. The inter-subtest corrs- ranged from 0.32 (Yes-No Questions and Fluency) to 0.89 (Sentence Completion and Responsive Speech); 3. Time post onset did not have a significant effect (p values NR); Regression:; 1. Information content (IC) subtest is best predictor of AQ, accounting for 87% of the total variability; 2. Next best predictor, Repetition, together with Info content acted for 95%; 3. 5 of 10 subtests acct for 99% of total var. in AQ of the total variability in AQ. 3. 2 subtests contribute NS to prediction of AQ.; 4. Results of maximum R^2^ analysis confirm stepwise analyses | 1. Changes in commun fxn over time are not suff to affect the relationships among subtests or betw subtests and AQ; 2. Results provide better understanding of how WAB evaluates aphasia but does not evaluate importance of subtests for clinical dx | 1. No correction for multiple comparisons; 2. Statistics not reported for comp of subtests and time post onset; 3. Stepwise regression used rather than preferred hierarchical regression; 4. Increase in R^2^ w/addition of subtests not tested for stat sign; R^2^ reported rather than unbiased adjusted R^2^; 5. That 1 subtest (information content) accts for 87% of variability AQ suggests that 9 subtests contribute min info; 6. Data from multiple sites in single state may not be representative of all aphasics
Crary et al., 1992^44^ Instr: WAB | Statistical Method: Cluster analysis (Q-analysis) BDAE (orig):; 1. 7 clusters, of which 4 acct for 89% of the total variance. Clusters named by comp of mn pt performance on BDAE w/ the orig BDAE classification; 2. BDAE (orig) classification does not agree well w/ results of the cluster analysis, with only 38% of the cases matching; WAB:; 1. 4 clusters, of which 3 acct for 97% of the total variance (one factor contained only 1 subj). Clusters named by comp of mn pt performance on WAB w/ the WAB classification; 2. WAB classification does not agree well w/ results of the cluster analysis, with only 30% of the cases matching | 1. Poor agr of WAB w/ cluster analysis suggests that WAB may not correctly classify aphasics; 2. Cluster analysis provides better support for BDAE (orig) than WAB in classifying aphasics | 1. Level of heterogeneity betw BDAE (orig) & WAB disturbing given assumption that both measure same underlying phenomenon; 2. Sample size is small with little information on subjs or setting; results may not be generalizable

Evidence Table 12. Adult Language Disorders -- WAB: Predictive Validity Outcomes

Author(s) (year) | Predictive Validity Results Hypotheses tested Results | Conclusions | Limitations of Study
Lincoln et al., 1989^56^ Instr: WAB | Statistical Method: stepwise multiple regression WAB Reading and Writing Quotient accounts for 7% of total variability in Extended ADL Mobility, 16% in Extended ADL Kitchen, and 34% in Extended ADL Leisure measured at 9 mos post admission | Reading and writing are important determinants of independence as measured by ADL scores | 1. Small sample from single institution may not be generalizable. Authors admit that sample may be more ill than average; 2. No comparison of admission chars of pts lost to follow-up; 3. Hierarchical regression preferred to stepwise regression

Evidence Table 13. Child Language Disorders -- CELF-3: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/ Procedures | Qualifications/Training of Examiners | Country | Date of Study/ Duration | Quality Score (%)
Semel et al., 1995^57^ Instr: CELF-3 | To update the test content, provide current norms, and test for reliability and validity | Cohort for: ICR, T-RR, InterR, content, construct, concurrent validity, develop of norms | Inclusion:; 1. Ages 6-0 to 21-11; 2. Understand & speak English or English lang dominant; Construct (Discriminant): 5. 1. English lang dominant 6. 2. Lang disordered matched to normal 3. Phono disorder ok Exclusion(except Construct/Concurrent): No dx of lang disorder or receipt of tx | Norms/ICR: Unk/2450 T-RR: Unk/152 InterR: 590-Formulated Sentences & 599-Word Assoc Construct (Discriminant) Unk/272 CELF-3/CELF-R Study1: Unk/300 Study2: Unk/ 91 CELF-3 and CELF-Preschool Unk/101 CELF-3/WISC-III Unk/203 | Norms/ICR: Sex: M/F: 50%/50% Age: 200 each in (6-0 to 6-11) through (16-0 to 16-11); 50 each in (17-0 to 17-11) through (21-0 to 21-11) Race (W/AA/H/O) 70.7%/15.3%/15.3%/ 3.7% T-RR: Sex: M/F: 52.6%/47.4% Ages: 7, 10, 13 Race (W/AA/H/O): 68%/18%/11%/3% InterR: Age: 6, 11, 16 InterR (Discriminant): Sex: M/F: 148/124 Ages: 6-0 to 16-1 Race (W/AA/H): 71%/15%/14% Concurrent: CELF-3/CELF-R Study 1: Sex: M/F: 47.3%/52.7% Age grps: 6, 8, 10, 12, 14, 16 Race (W/AA/H/O):77%/12%/7%/4% Study 2: Sex: M/F: 60.4%/39.6% Age grps: 7,11,15,16 Race (W/AA/H/O) 62%/18%/19%/1% CELF-3/CELF-Presch: Sex: M/F:53.5%/46.5% Age: 6-0 to 6-11 Race (W/AA/H/O) 59%/25%/%13%/3% CELF-3/WISC-III: Sex: M/F:47.8%/52.2% Age: 6, 9, 12, 15 Race (W/AA/H/O) 80%/12%/6%/2% | Setting: Sites in 47 states Procedures: CELF-3 admin to subjs according to standard protocol | Qcations: State licensed or ASHA certified SLPs experienced in standardized test admin Training provided: Completed practice case, received written/telephone feedback on admin & scoring issues | United States | Dates: Fall 1994-2/95 Duration: 4-5 mos (imputed from dates); T-RR 1w to 1 mo | M=91.2% C=86.1%
Wiig et al, 1992^61^ Instr: CELF-R | To test hypothesis that levels of understanding not related to standardized language tests (CELF-R). | Controlled trial, non-randomized | Inclusion:; 1. Primary lang English; 2. IQ within normal range (85-115); 3. Normal hearing; Grp 1: Learning-disabled children Grp 2: Non-learning disabled children Exclusion:; 1. Neurol, physical or emotional disorders; 2. Articulation, fluency or voice disorders | Overall Unk/45 7. Grp 1 (Learning Disabled): Unk/15 8. 9. Grp 2 (Age matched normal): Unk/15 10. Grp 3 (Reading matched normal): Unk/15 | Overall: Sex (all grps): M/F: 60%/40% Age Mn(range) in y: Grp 1: 11-2(10-2 to 13-4) Grp 2: 11-1(10-0 to 12-6) Grp 3: 9-1(8-10 to 9-11) Other: Grp 1: all received speech tx | Setting: Elem school Procedures:; 1. Exp'tl reading passage and questions admin w/ norm-ref measure of reasoning; 2. CELF-R admin | Qcations: NR Training provided: NR | United States | Dates: NR Duration: NR | M=62.5% C=66.7%
Perez et al., 1995^58^ Instr: CELF-R | 1. To test whether CELF-R scores corr w/ 2 cognitive screening tests in students w/ Central Auditory Processing (CAP) problems; 2. To identify test diffs in score and by sex | Cohort w/o comp grp | Inclusion:; 1. Evaluation for central auditory processing problems; 2. English primary lang; 3. Have learning difficulties, read/memory problems, or problems staying on task; Exclusion: NR | Overall:40/40 | Overall: Sex: M/F: 29/11 (72.5%/27.5%) Age (y): Mn (SD): 10.9 (3.3) Race: All white | Setting: Univ speech & hearing center Procedures: CELF-R, and Test of Nonverbal Intelligence (TONI), and Slosson Intelligence Test (SIT) admin | Qcations: SLP/Aud who routinely admin tests Training provided: NR | United States | Dates: NR Duration: NR | M=71.4% C=78.6%
Kotsopoulos et al., 1996^59^ Instr: CELF-R | To assess reading, spelling, lang skills of children w/ psychiatric disorders | Controlled trial, w/o comp grp | Inclusion: IQ >= 90 on verbal or performance subscales of the Wechlser Intelligence Scale for Children-Revised Exclusion: Pervasive develop disorders or early onset schizophrenia | Overall: Unk/50 | Overall: Sex: M/F: 42/8 (84%/16%) Age (y): Mn=10.22, range=8-13 Clinical Dx (%): ADHD/Agg behav: 40 Conduct disorder: 24 Adjustment disorder w/ conduct features: 14 Other: 22 | Setting: Day tx school pgm Procedures:; 1. CELF-R admin at pgm entry; 2. Reading decoding, reading comprehension and spelling subtests of Kaufman Test of Educational Achievement (KTEA) admin at entry and 3 mos; 3. Tx and education admin as part of pgm | Qcations: NR Training provided: NR | Canada | Dates: NR Duration: w/in 3 mos of initial assess | M=52.9% C=66.7%
Kotsopoulos et al., 1996^124^ Instr: CELF-R | To identify predictors academic gains | Controlled trial, w/o comp grp | Inclusion: IQ > 90 on verbal or performance subscales of the Weschlser Intelligence Scale for Children-Revised Exclusion: Pervasive develop disorders or early onset schizophrenia | Overall: Unk/46 | Overall: Sex: M/F: 39/7 (84.8%/15.2%) Age (y): Mn=11.0, range=7.75-13.3 Clinical Dx (%): ADHD/Agg behav: 28 Conduct disorder: 37 Adjustment disorder w/ conduct features: 15 Other: 20 | Setting: Day tx school pgm Procedures:; 1. CELF-R admin at pgm entry; 2. Kaufman Test of Educational Achievement (KTEA) admin at entry and outcome; 3. Tx and education admin as part of pgm | Qcations: NR Training provided: NR | Canada | Dates: NR Duration: Mn= 9 mos; range=7-15 mos | M=58.8% C=62.5%
Lewis et al., 1998^60^ Instr: CELF-R | 1. To eval whether writing skills differ betw children w/hx of early SLD differ and normal siblings; 2. To corr measures of spoken lang w/written lang in children w/hx of early SLD; 3. To predict writing skills in children w/hx of early SLD from reading, spelling or spoken lang abilities | Prospective cohort w/ comp grp | Inclusion: Groups 1 and 2:; 1. GFTA score Mn -1SD or lower, evidence for >= 3 phono error types, mod to severe rating on Khan-Lewis Phonological Analysis; 2. Normal hearing acuity & peripheral speech mechanism; 3. Received SL tx; Group 3:; 1. All siblings >= 4y; 2. No phono or lang disorder; 3. No hx of speech tx; Exclusion: Hx of neurol or develop disorders | Group1 (phono only): Unk/23 Group2 (phono & lang): Unk/13 Group3 (normal): Unk/15 | Sex: Group1: M/F: 12/11 Group2: M/F: 12/1 Group3: M/F: 7/8 Age Mn(SD) in y: Group1: 9.93(2.49) Group2: 9.41(1.90) Group3: 10.93(1.29) *nonsign (F=2.7, p=0.08) | Setting: home Procedures:; 1. Children enrolled in betw kindergarten & 1st grade; 2. Children tested in 2nd-4th grades on spoken lang (CELF-R), writing (Test of Written Language-TOWL-2), and spelling (Test of Written Spelling-TWS-3) | Qcations: NR Training provided: NR | United States | Dates: NR Duration: Enrollment in the study (between presch and 1^st^ grade) to school age (1^st^, 2^nd^, or 3^rd^ grade) | M=83.3% C=73.3%

Evidence Table 14. Child Language Disorders -- CELF-3: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Semel et al., 1995^57^ Instr: CELF-3 | ICR: Statistical Method: Cronbach's coefficient alpha, SEMs; 1. Alphas (by age) range from 0.83-0.91 for Recpt Lang, 0.84-0.94 for Express Lang, and 0.91-0.95 for total lang; 2. Alphas by age for subtests 0.54-0.91; T-RR: Statistical Method: Pearson's corr Mean corr across age grps 0.86 for express lang, 0.80 for recpt lang, and 0.91 total score InterR: Statistical Method : Corr; 1. Formulated Sentences: r=0.70-0.91; 2. Word Associations r=0.97-0.99 | 1. Low ICR for listening to paragraphs lower due to length of test; 2. High levels of InterR; lower for formulated sentences test | Typographical error for overall InterR

Evidence Table 15. Child Language Disorders -- CELF-3: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Semel et al., 1995^57^ Instr: CELF-3 | Content: Description of design of each subtest and analysis of specific item content Construct Statistical Method: Correlations, factor analysis, discriminant analysis Factor Analysis: In 6-8 yo grp (N=600); 1 factor accts for 53% of total variance; in 9+ yo grp (N=1850), 1 factor accts for 49% Subtest InterCorrelations: Generally moderate (range=0.25-0.63) Discriminant Analysis: CELF-3 (1SD below Mn) correctly classified lang disorder 71.3% of time; Sens=0.80; Spec=0.67; PPV=0.57; NPV=00.85 Concurrent: Statistical Method: Correlations Coefficient, Mn(SD) of standard scores CELF-3 and CELF-R Study 1(subsample of std sample): Corrs betw subtests range=0.42-0.75; Corrs betw Total, Recept Lang, Express Lang scores=0.72-0.79 Study 2 (language disordered): Corrs betw subtests range=0.41-0.85; Corrs betw Total, Recept Lang, Express Lang scores=0.68-0.83 CELF-3 and CELF-P: Corrs betw subtests range=0.29-0.58. Corrs betw CELF-3+CELF-P=0.49, 0.59, 0.63 for Recpt Lang, Express Lang and Total Lang, respectively CELF-3 and WISC-III: Correlations betw CELF-3 scores and WISC-III scores=0.56-0.75 | Content: lang skills sampled are well-documents in the literature Construct: CELF-3 has single general factor that measures general lang ability | NR
Wiig et al., 1992^61^ Instr: CELF-R | Statistical Method: Correlations Concurrent validity:; 1. Mn (range) of: CELF-R Total=80.33 (63-89); CELF-R Recept Lang=84.67 (70-93); CELF-R Express Lang=79.17 (60-93); 2. No corr betw levels of understanding & CELF-R Total (r=0.20, p>.05) | CELF-R scores not anticipated to be related to levels of understanding b/c they look at microstructures in text (content and form) | Small sample from one geographic region not likely to be representative
Perez et al., 1995^58^ Instr: CELF-R | Statistical Method: t-tests, ANOVA, Pearson correlation coefficients; no corrections for multiple comparisons Mn for the CELF-R Receptive Language-82.3, SD = 17.2. Mn for the CELF-R Expressive Language -75.9, SD = 14.0 and Mn for the CELF-R Total Language-77.8, SD = 14.2. Mn for the TONI-91.9, SD = 11.6 and Mn for the SIT-88.3, SD = 11.4 Corrs betw CELF-R and TONI/SIT:; 1. CELF-R Recep Lang & CELF-R Express Lang (r =0.49); CELF-R Recept Lang and CELF-R Total (r = 0.90); CELF-R Expressive and CELF-R Total Language (r =0.83); 2. CELF-R Recept lang and: TONI (r = 0.45); SIT(r = 0.59); 3. CELF-R Express lang and: TONI (r = 0.58); SIT (r =0.59); 4. CELF-R Total and: TONI (r =0.58); SIT (r =0.69) TONI and SIT (r = .52) *All tests & subscales corrs sign (p < .01); 5. r^2^ for the tests indicate that they share 20% to 35% of common variance; Diffs in scores betw CELF-R, TONI, & SIT:; 1. CELF-R Recept Lang sign higher than: CELF-R Express Lang score (t (39) = 2.36, p < .05) & CELF-R Total score (t (40) = 3.72, p < .05); 2. CELF-R Recept Lang sign lower than: TONI (t (40) = −3.84, p < .01) & SIT (t (38) = 3.38 p < .01); 3. CELF-R Express Lang not sign diff from CELF-R Total score (t (39) = −1.19, p > .05), but sign lower than TONI (t (39) = −8.25 p < .01) & SIT (t (37) = 7.15, p < .01); 4. CELF-R Total score sign lower than TONI (t (40) = −7.42, p < .01) & SIT (t (38) = 7.53, p < .01); Sex Differences:; 1. No sign sex diffs for CELF-R Recept Lang (F (1, 38) =0.05, p > .05), CELF-R Express Lang (F (1, 37) = 0.00, p > .05), CELF-R Total (F (1, 38) = 0.01, p > .05), and SIT (F (1, 36) = 0.04, p > .05). (F (1, 38) = 4.80, p < .05); 2. Sign sex diff for TONI scores: Mn(Males)=89.6 vs. Mn(Females)=98.2 | 1. Three tests are discrete, indep measures of lang fxning; 2. All tests and subscales are sign corr, lending evidence that the 3 tests can be used w/ CAP popn; 3. No sex diffs for CELF-R scores in CAP children | 1. Small sample from single institution and from disadvantaged background; results may not generalizable to other children w/CAP; 2. Subjs were heterogeneous wrt to learning problems; 3. Sex diffs based on only 11 Fs; 4. No corrections made for multiple comparisons
Lewis et al., 1998^60^ Instr: CELF-R | Statistical methods: ANOVA w/ Tukey HSD tests for post hoc comparisons, correlations, Bonferroni corrections for multiple comparisons, regression Construct Validity:; 1. Phono & lang group had sign lower scores than phono alone or normals (F=16.82, p<0.001). Mn(SD) phono & lang=87.83(NR); MN (SD) phono only=105.29(13.98); MN(SD) normals=115.27(12.76). Effect size=0.91 (large); 2. Phono & lang group scored >= 1SD below Mn for CELF-R; Concurrent Validity:; 1. CELF-R total w/ TOWL-2 Syntactic Maturity: (r=0.51, p<.01); 2. CELF-R Sentence Assembly subtest w/ TOWL-2 Syntactic Maturity subtest (r=0.51, p<.01); 3. No other sign corrs for CELF-R; 4. CELF-R accts for 15% of variance in writing score in phono only (p=0.04) and 24% phono & lang (p=0.04) | 1. Children w/ early SLD at risk of weakness in written lang expression at school age; risk might be present despite improvements in spoken lang | 1. Small sample sizes result in potential lack of power to detect sign diff; 2. Generalizability to other children with phono & lang diffs; 3. Children w/ SLDs and normals not indep; may underestimate diffs; 4. TOWL-2 may not be best or most representative test of writing skills

Evidence Table 16. Child Language Disorders -- CELF-3: Normative Data Outcomes

Author (year) | Population to Which Standardized | Score Reported | Other Analyses
Author (year) | Population/ Source Characteristics | Score Reported | Other Analyses
Semel et al., 1995^57^ Instr: CELF-3 | Population/Source: US popn ages 6-21y as defined by 1980 US Census Characteristics:; 1. Race/ethnicity; 2. Region; 3. Sex; 4. Educ of primary caregiver | Standard scores Mn(SD)=10(3); test-age equivalents | NR

Evidence Table 17. Child Language Disorders -- CELF-3: Predictive Validity Outcomes

Author(s) (year) | Predictive Validity Results Hypotheses tested Results | Conclusions | Limitations of Study
Kotsopoulos et al., 1996^59^ Instr: CELF-R | Statistical Method: Corrs Outcome #1 Reading:; 1. Sign corrs betw reading gains (outcome-initial assessment) & CELF-R Recept lang (r=−0.33, p=0.03) & CELF-R Total (r=−0.31, p=0.04); 2. No sign corrs w. CELF-R subscales; Outcomes #2 Spelling gains : No sign corrs w/ CELF-R scores or subscales Outcome #3 Math gains:; 1. Sign corrs w/ CELF-R Recept Lang (r=0.40, p=0.009), CELF-R Express Lang (r=0.42, p=0.006), CELF-R Total Lang(r=0.46, p=0.002); 2. Sign corrs w/ CELF-R Semantic Relationship (r=0.35, p=0.02), CELF-R Sentence Assembly (r=0.34, p =0.03), CELF-R Recalling Sentences (r=0.42, p=0.004), & CELF-R Formulating Sentences (r=0.38, p=0.01) | Weak neg corrs between reading and CELF-R scores may be due to ceiling effects, skewing by children w/ high scores or teacher bias (less instruct for indivs w/ high initial lang scores) | May be earlier comparison of popn in Kotsopoulus et al. 1996^59^; 1. No corrections for multiple comparisons; 2. No comparison group; 3. Lack of other measures of academic achievement; 4. Results from small sample from single institution may not be generalizable to the larger popn
Kotsopoulos et al., 1996^59^ Instr: CELF-R | Statistical methods: Correlations, t-tests, hierarchical regression modeling CELF-R Mn (SD) %ile scores:; 1. Recept lang: range=38.1(26.6) to 70.9(24.3); 2. Express lang: range=24.8(25.7) to 70.5(22.0); Predictive Validity (3 mos):; 1. CELF Sentence Assembly corr w/ Reading Decoding (r=0.67), Reading Comprehension (r=0.68), and Spelling (r=0.44); 2. CELF-R Recalling Sentences corr w/ Reading Decoding (r=0.54), Reading Comprehension (r=0.73), and Spelling (r=0.61); 3. CELF-R Formulating Sentences corr w/ Reading Decoding (r=0.61), Reading Comprehension (r=0.62), and Spelling (r=0.52); 4. Subjs w/ low (< 5%ile) scores on Reading & Spelling had low scores on CELF-R Sentence Assembly (p<0.001), Recalling Sentences (p<0.01), & Formulating Sentences (p<0.001); Hierarchical regression modeling: WISC digit span subscale, CELF-R Sentence Assembly and Recalling Sentences sign accted for 42% of variance in Reading Decoding, 63% in Reading Comprehension, & 29% in Spelling | Semi-partial corrs suggest substantial overlap in WISC digit span and CELF-R Sentence Assembly and Recalling Sentences | **May be early comparison of popn in Kotsopoulos et al. 1996^124^; 1. No corrections for multiple comparisons; 2. No comparison group; 3. Lack of other measures of academic achievement; 4. Results from small sample from single institution may not be generalizable to the larger popn

Evidence Table 18. Child Language Disorders -- CELF-3 Spanish: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/ Procedures | Qualifications/ Training of Examiners | Country | Dates of Study/ Duration | Quality Score (%)
Semel et al., 1997^68^ Instr: CELF-3 Spanish Edition | To provide reliability, validity and normative data | Reliability/ validity study | Inclusion:; 1. Ages 6-0 to 21-11 y; 2. Proficient in undstd/speak Spanish; 3. (Int'l Study) Spanish instruction only; 4. (Discrim Anal): Lang disordered matched to normal; Phono disorder ok; Exclusion:; 1. Std sample: NR; 2. Int'l study: attend US schools; 3. (Discrim Anal): dx of develop delay, hear impairment, emotional disturbance, ADHD | Overall: Unk/>1400 Int'l Study: Unk/317 ICR: 1050/1050 TRR: Unk/126 InterR: 250 completed forms from std sample Construct Validity: Factor Analysis: 1050/1050 Discriminant Analysis: 172/172 | Stdization: Sex:(M/F): 505/545 48.1%/51.9% Age: 4-0 to 13-11: 100/y 14-0 to 16-11: 50/y 17-0 to 21-11: 20/y Dialect Spoken: SW US: 141 Mexico: 535 Spain: 6 Caribbean: 226 Central America: 44 South America: 86 Unspecified: 12 TRR: Sex:(M/F):59/67 Age: 8-0 to 8-11: 45 11-0 to 11-1: 49 14-0 to 14-11: 32 InterR: Raters: 2 from total of 17 Age: 6-0 to 6-11: 100 11-0 to 11-1: 100 16-0 to 16-11: 50 Discrim Anal (SLD only) Age: 6-0 to 6-11: 28 9-0 to 9-11: 29 12-0 to 12-11: 29 Int'l Study: Sex:(M/F): 156/161 49.2%/50.8% Age: 6-0 to 16-11: 21-34/y 17-0 to 21-11: 26 | Setting: NR Procedures:; 1. CELF-Spanish admin as described in manual; 2. Exam-iners provided written and telephone feedback during study | Qcations:; 1. Experienced in test admin; 2. Proficient in Spanish; 3. Member of ASHA or state SL prof orgn (Int'l study); Training provided: NR | Stdization: United States Intl Study: Argentina, Dominican Republic, Mexico, Nicaragua, Puerto Rico | Dates: 1/1996-12/1996 (Stdization) 1/1997-5/1997 (Int'l study) Duration: TRR: (1w-1mo) | M=85.3% C=82.9%

Evidence Table 19. Child Language Disorders -- CELF-3 Spanish: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Semel et al., 1997^68^ Instr: CELF-3 Spanish Edition | ICR: Statistical methods: Cronbach's alpha, SEMs Alphas reported by age grp for subtests and composites; 1. Alphas for Estructura de oraciones (EO)=0.55-0.58; Estructura de palabras (EP)=0.81-0.85; Conceptos y direcciones(CD)=0.65-0.87; Formulaci?n de oraciones (FO)=0.77-.089; Clases de palabras (CP)=0.77-0.90; Recordando oraciones (RO)=0.91-0.96; Asociaci?n de palabras (AP)=0.71-0.89; Eschuchando a p?rrafos (EP)=0.46-0.69; 2. Alphas for Recep Lang=0.82-0.90; Express Lang=0.89-0.95; Total Lang=0.91-0.95; T-RR: Statistical methods: Corr coefficients, SEMs; 1. Mean corr across age grps for subtest scores: corr(EO)=0.77; corr(EP)=0.81; corr(CD)=0.0.66; corr(FO)=0.66, corr(CP)=0.72; corr(RO)=0.84, corr(AP)=0.55, corr(EP)=0.69; 2. Mean corr across age grps for composite and total scores: corr(Recep Lang)=0.79, corr(Express Lang)=0.85, corr(Total Lang)=0.87; 3. By Age: 8 y olds-corrs=0.52-0.89 (subtests) & 0.79-0.93 (composites); 11 y olds-corrs=0.58-0.88 (subtests) & 0.80-0.89 (composites); 14 y olds-corrs=0.57-0.87 (subtests) & 0.79-0.83 (composites); Inter-Rater: Statistical methods: Correlation coefficients; 1. FO subtest: Overall corr=0.91; for 6 y olds, corr=0.81; for 11 y olds, corr=0.82, for 16 y olds, corr=0.79; 2. AP subtest: Overall corr=0.99; for 6 y olds, corr=0.98; for 11 y olds, corr=0.98, for 16 y olds, corr=0.97 | 1. High level of InterR agreement (may be typo for FO subtest) | NR

Evidence Table 20. Child Language Disorders -- CELF-3 Spanish: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Semel et al., 1997^68^ Instr: CELF-3 Spanish Edition | Content Validity: Lang skills in CELF-3 Spanish are well documented SLD literature Construct Validity: Factor Analysis: The Enumeraci?n r?pida y autom?tica subtest was excluded In 6-8 yo grp (n=300), 1 factor accts for 44% of total variance; in 9+ yo grp (N=750), 1 factor accts for 47% Subtest InterCorrelations:; 1. For 6 to 8 yo grp: corrs=0.13-0.65. Smallest corr observed for AP subtest; 2. For 9+ yo grp: corrs=0.21-0.50; 3. Smallest corrs observed for AP subtest in both grps; Discriminant Analysis: CELF-3 Spanish (1SD below Mn) correctly classified lang disorder 71.6% of time; Sens=0.75; Spec=0.69; PPV=0.65; NPV=0.78 Age Diffs for Enumeraci?n r?pida y autom?tica:; 1. Mn number of errors decrease across ages, reflecting greater accuracy in naming skills; 2. SD decr as age incr, reflecting less variable as children become more proficient in naming skills; Comp of Parent/Teacher/Child Ratings to CELF-3 Spanish Scores:; 1. For non-SLD grp, corr betw parent & child ratings of lang skills were highest (0.59 to 0.63); corr betw teacher & child (r=0.41-0.46) and parent & teacher (r= 0.34-0.42) were similar but smaller; 2. For SLD grp, all corrs betw 0.53 and 0.81 except those betw parent/child assessments of listening and speaking difficulties; 3. For non-SLD grp corrs between CELF-3Sp total score and teacher, parent, child ratings= −0.33, −0.26, and −0.26, respectively; 4. For SLD group corrs betw total and teacher/child rating sig (-0.45 and-0.57, respectively) | NR | NR by authors Noted by reviewer: no corrections for multiple comparisons of corr coefficients for rating scales and CELF-3 scores

Evidence Table 21. Child Language Disorders --- CELF-3 Spanish: Normative Data Outcomes

Author (year) | Population to Which Standardized Population/Source Characteristics | Score Reported | Other Analyses
Semel et al., 1997^68^ Instr: CELF-3 Spanish Edition | Population/Source: 1980 & 1990 US Census Characteristics:; 1. Geographic region; 2. Sex; 3. Educ attainment of primary caregiver | 1. Std scores, %ile ranks, & age equivalents. Std scores may be converted to stanines or normal curve equivalents; 2. Std scores not available for Automatic, Rapid Naming subtest (optional) | Std scores from monolingual Spanish-speakers outside US

Evidence Table 22. Child Language Disorders --- CELF-Preschool: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/ Training of Examiners | Country | Date(s) of Study/ Duration | Quality Score (%)
Wiig et al., 1992^61^ Instr: CELF-Preschool | To extend test downward & to provide norms and reliability and validity data | Cohort for: ICR, T-RR, InterR, content, construct, concurrent validity, develop of norms | Inclusion: Children ages 3-0 to 6-11 Construct (Discriminant):; 1. English lang dominant; 2. Lang disordered matched to normal; 3. Phono disorder ok; Exclusion (except Construct/Concurrent): No dx of SL or hearing disorder | Norms/ICR/Construct: Unk/800 T-RR: Unk/57 InterR: Unk/75 w/ 3 judges Construct (Discriminant) Unk/160 CELF-Preschool/CELF-R Unk/ 80 CELF-Preschool/CELF-R Screening Test: Unk/100 CELF-Preschool/PLS-3: Unk/53 CELF-3/WPPSI-R: Unk/56 CELF-3/DAS Unk/54 | Norms/ICR: Sex: M/F: 50%/50% Age: 100 each in (3-0 to 3-5) through (6-5 to 6-11) Race (W/AA/H/O): 69.6%/14.9%/11.6%/3.9% T-RR: Sex: M/F: 49.1%/50.9% Ages: 3-6 to 4-11 Construct (Discriminant): Sex: M/F: 67.5%/32.5% Ages: 5-0 to 16-11 Concurrent: CELF-Preschool/CELF-R: Sex: M/F: 67.5%/32.5% Age grps: 5-0 to 6-11 All had dx of SLD CELF-Preschool/CELF-R Screening Test: Sex: M/F: 50%/50% Age grps: 5-0 to 6-11 PL-3/CELF-Presch: Sex: M/F:54.7%/45.3% Age: 3-0 to 3-5 and 4-0 to 4-5 CELF-Preschool/WPPSI-R: Sex: M/F:50%/50% Age: 3-6 to 3-11 and 5-0 to 5-11 0 to 5-11 CELF-Preschool/DAS: Sex: M/F:48.1%/51.9% Age: 3-6 to 3-11 and 5- | Setting: Sites in 42 states Procedures: CELF-Preschool admin to subjs according to standard protocol | Qcations: 151 SLPs Training provided: NR | United States | Dates: Fall 1991-NR Duration: NR except for T-RR: 2-4 w; Concurrent: 1d-2 w | M=85.3% C=77.1%

Evidence Table 23. Child Language Disorders --- CELF- Preschool: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Wiig et al., 1992^61^ Instr: CELF-Preschool | ICR: Statistical Method: Cronbach's coefficient alpha, SEMs; 1. Alphas (by age) range from 0.30 to 0.93 for subtests; 0.73-0.96 for Total, Express, and Recept lang scores; 2. Alphas (Express Lang)=0.82-0.94; alphas Recept Lang=0.73-0.92; alphas (Total Lang)=0.86-0.96; 3. Children 6-0 to 6-11 had lowest alphas; 4. Composite scores have higher alphas than to indiv subtests; T-RR: Statistical Method: Pearson's corr; 1. Corrs=0.60-0.92 for subtests; 2. Corrs Recept Lang=0.93 and 0.87; corrs Express Lang=0.94 and 0.92; and corr Total Lang=0.97 and 0.93, for children ages 3-6 yo to 3-11yo and 4-6 yo to 4-11yo, respectively; 3. T-RR lowest for sentence structure subtest; InterR: Statistical Method : % agr; 1. % agr=90% betw 3 raters | ICR lower at age 6 due to ceiling effect and low range of variability | Used % agr rather than Cohen's kappas for InterR

Evidence Table 24. Child Language Disorders --- CELF- Preschool: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Wiig et al., 1992^61^ Instr: CELF-Preschool | Content: Description of design of each subtest and analysis of specific item content Construct Statistical Method: Correlations, discriminant analysis Composite Score InterCorrelations:; 1. Corrs betw Express and Recept lang score range=0.60-0.84; 2. Corrs are generally lower at ages 6-6 to 6-11; Discriminant Analysis:; 1. CELF-Preschool (Mn-1SD as threshold) correctly classified lang disorder 74% of time; Sens=0.84; Spec=0.69; PPV=0.60; NPV=0.89; 2. CELF-Preschool (Mn-1.5SD as threshold) correctly classified lang disorder 72% of time; Sens=0.93; Spec=0.65; PPV=0.48; NPV=0.96; Concurrent: Statistical Method: Correlations Coefficient, Mn(SD) of standard scores, % agr CELF-Preschool/CELF-R; 1. Corrs betw subtests range=0.27-0.84; Corrs betw Total, Recept Lang, Express Lang scores=0.63-0.93; 2. Mn CELF-R Express Lang score sign lower than Mn CELF-Preschool (p<0.01 for each age group); CELF-Preschool/CELF-R Screening Test: CELF-3 (1.5SD below Mn) correctly classified lang disorder 75% of time; Sens=1.00; Spec=0.74; PPV=0.11; NPV=1.00 CELF-Preschool/PLS-3 Corrs betw PLS-3 and CELF-Preschool composite and total scores range=0.73-0.90 CELF-Preschool/WPPSI-R Corrs betw WPPSI-R and CELF-Preschool composite and total scores range=0.45-0.71 CELF-3/DAS: Corrs betw DAS and CELF-Preschool composite and total scores range=0.53-0.70 | 1. Content: lang skills sampled are well-documented in the literature; 2. Corrs of downward extended tests are higher than for other comparisons | 1. Corrs betw CELF-R and CELF-Preschool are approximate, given that the tests do not have identical subtests; 2. No corrections for multiple comparisons in construct validity assess

Evidence Table 25. Child Language Disorders -- CELF- Preschool: Normative Data Outcomes

Author (year) | Population to Which Standardized Population/Source Characteristics | Score Reported | Other Analyses
Wiig et al., 1992^61^ Instr: CELF-Preschool | Population/Source: US popn ages 3-6 y as defined by 1980 US Census (1988 update) Characteristics:; 1. Race/ethnicity; 2. Region; 3. Sex; 4. Education of primary caregiver | Standard scores Mn(SD)=10(3) for Express and Recept Lang Score; Mn(DS)=100(15) for Total Lang Score; Test-age equivalents | NR

Evidence Table 26. Child Language Disorders -- TOLD-P:3 : Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/Duration | Quality Score (%)
Hammill and Newcomer, 1997^71^ Instr: TOLD-P3 | To provide reliability/validity data and normative info | Reliability/validity study | Inclusion:; 1. Ages 4-0 to 8-11; 2. English-speaking; Exclusion: Deafness | Overall: Unk/1519 ICR: 1000/1000 TRR: Unk/33 InterR: 50 completed protocols from studied sample Content Validity: 1000/1000 Criterion Validity: 30/30 Construct Validity: Group Diff: 1000/1000 | Overall: Sex:(M/F): 490/510 49%/51% Age: 4-0 to 4-11: 107 5-0 to 5-11: 153 6-0 to 6-11: 224 7-0 to 7-11: 258 8-0 to 8-11: 258 Race (Wh/AA/O): 80%/15%/6% Ethnicity (AA/H/As/NA/O): 15%/10%/3%/2%/70% Dx: Learn disability: 3% SLD: 5% Ment retard: 1% Oth handicap: 2% Inter-R: 4-0 to 8-11y | Setting: NR Procedures: TOLD-P:3 admin as described in manual | Qcations: "experienced examiners" Training provided: NR | United States | Dates: Spring 1996 Duration: TRR-4 mos | M=90.9% C=80.6%
Fodness et al., 1991^70^ Instr: TOLD-I:2/TOLD-P:2 | To examine T-RR of TOLD-P:2 & TOLD-I:2 total and composite scales at various age levels | Cohort w/o comp grp (conven-ience sample) | Inclusion: English primary language Exclusion: NR | TOLD-P:2: Unk/60 TOLD-I:2: Unk/61 | TOLD-P:2: Sex: M/F: 37%/63% Age (#): 20 in each age group (4-0 to 4-11, 6-0 to 6-11, 8-0 to 8-11) Race: 100% Wh Income: >$35,000=38% TOLD-I:2: Sex: M/F: 25%/75% Age (#): Unk in each age group (8-0 to 8-11, 10-0 to 10-11, 12-0 to 128-11) Race (Wh/AA/O): 85%/7%/8% Income: >$35,000=48% Urban/Rural: 92%/8% | Setting: NR Procedure:; 1. Test admin consistent with manual guidelines; 2. Test repeated 12-16 d later by same examiner | Qcations: 2 female examiners; otherwise, NR Training: NR | United States | Date: NR Duration: 12-16 d | M=80.0% C=73.3%
Lewis et al., 2000^72^ Instr: TOLD-P:2 | To identify predictors of school-age lang, read, & spell skills in presch children w/ SL disorders | Prosp cohort w/o comp grp | Inclusion:; 1. In tx for mod to severe express phono disorder; 2. Normal hearing acuity.; 3. Normal peripheral speech mechanism; 4. No hx of neuro disorders/develop delays; 5. Normal intelligence (IQ >= 80); Exclusion: NR | 87/52 | Sex: M/F-33/19 M/F-63.5%/36.5% Age: Mn(SD) 9.3 (1.4) Range: 8-11 y SES (Hollingshead): 1 / 2 /3 / 4 / 5 5.8%/13.5%/19.2%/ 32.7%/28.8% | Setting: University speech research lab or at home Procedures:; 1. During preschool assess, children admin TOLD-P:2, Nonsense word Repetition test, Khan-Lewis phono process analysis, GFTA (original); 2. At school age assess, children administered CELF-R, WRMT-R (2 subtests), TWS-3, Reading Comp from WIAT; 3. All samples audiotaped and transcribed on-line using broad phonetic transcription | Qcations: NR Training provided: NR | United States | Dates: NR Duration: 4 y | M=87.5% C=81.3%

Evidence Table 27. Child Language Disorders -- TOLD-P:3: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Hammill and Newcomer, 1997^71^ Instr: TOLD-P3 | ICR: Statistical methods: Cronbach's alpha, std errors; 1. Mean alpha across age grps=0.80-0.91 (subtests) & alpha=0.91-0.96 (composites) Overall scores alphas ranged from 0.95-0.96; 2. 4 y olds: alpha=0.81-0.93 (subtests) & alpha=0.91-0.96 (composites); 3. 5 y olds: alpha=0.81-0.94 (subtests) & alpha=0.91-0.96 (composites); 4. 6 y olds: alpha=0.80-0.92 (subtests) & alpha=0.91-0.96 (composites); 5. 7 y olds; alpha=0.75-0.92 (subtests) & alpha=0.92-0.96 (composites); 6. 8 y olds: alpha=0.77-0.90 (subtests) & alpha=0.89-0.95 (composites); 7. Alphas also provided for subtest and composite scores by sex, race, ethnicity, disability status; alphas=0.80-0.97; 8. Std errors=0.9-1.3 (subtests) & Std errors=3.1-4.5 (composites); T-RR: Statistical methods: Correlation coefficients For the subtests, corrs=0.77-0.90; for composites, corrs=0.82-0.92 Inter-R: Statistical methods: Correlation coefficients For subtests & composites, all corrs were 0.99 | TOLD-P:3 has little test error and users can have confidence in the results | NR
Fodness et al., 1991^70^ Instr: TOLD-I:2; TOLD-P:2 | Statistical methods: Pearson's correlations w/Guilford and Fruchter's correction for range restriction *T-RR (Corrs>= 0.85 considered min reliab): TOLD-P2:; 1. Listening: range=0.82-0.91; 2. Speaking: range=0.89-0.94; 3. Semantics: range=0.83-0.84; 4. Syntax: range=0.87-0.91; 5. Phonology: range=0.64-0.89; low score for 8-0 to 8-11 group; 6. Overall: range=0.92-0.96 | TOLD-P:2:; 1. Total score and speaking, semantics suff reliab for all age groups; 2. Listening suff reliable for 4 & 6 yo; 3. Phono not suff reliab for 6 & 8 yo | 1. Sample size not reported by age for the TOLD-I2; 2. Limited # of 8 yo in standardization sample limits usefulness despite high T-RR

Evidence Table 28. Child Language Disorders -- TOLD-P:3: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Hammill and Newcomer, 1997^71^ Instr: TOLD-P3 | Content Validity: Statistical methods: Discriminating power, % of difficulty, (dif) Item Analysis:; 1. For 4 y olds, the median discriminating power=0.30-0.71; 0.32-0.75 for 5 y olds; 0.30-0.64 for 6 y olds; 0.32-0.56 for 7 y olds; 0.28-0.47 for 8 y olds; 2. For 4 y olds, the median % of difficulty=0.08-0.79; 0.13-0.88 for 5 y olds; 0.28-0.91 for 6 y olds; 0.45-0.94 for 7 y olds; 0.59-0.98 for 8 y olds; Differential Item Functioning:; 1. For sex: item bias found in: oral vocabulary (1 item) & grammatic understanding (2 items).; 2. For whites vs. non-whites: item bias found in oral vocabulary (3 items), sentence imitation (1 item) & word articulation (1 item); Criterion Validity: Statistical methods: Correlation coefficients, SEMs TOLD-P:3/Bankson Lang Test-2^nd^ Edition (BLT-2):; 1. Corrs betw TOLD-P:3 subtest & BLT-2 Semantic Knowledge=NS-0.97. TOLD-P:3 composite score corrs=0.89-0.96; 2. Corrs betw TOLD-P:3 subtest & BLT-2 Morphology/Syntax Rules=0.64-0.86. TOLD-P:3 composite score corrs=0.73-0.88; 3. Corrs betw TOLD-P:3 subtests & BLT-2 Overall Lang Quotient=NS-0.84; 4. Corrs betw TOLD-P:3 and BLT-2 overall scores=0.75-0.91; corr betw TOLD-P:3 and BLT-2 overall=0.89; Construct Validity: Statistical methods: correlation coefficients, SEMs Age Differentiation: The Mn subtest reported by age and incr w/ increasing age Corrs betw TOLD-P3 and 6 core subetests=0.50-0.62; Corrs betw age and 3 supplemental subtests=0.32-0.55 Group Differentiation: Mn subtest scores presented by race, sex, and disability.; 1. Means for mainstream groups higher than for minority groups; however, all scores w/in SEM and in normal range; 2. Subtest scores among groups w/ disability showed that lowest scores obtained by indivs w/ greatest disability; Subtest InterCorrelations:; 1. Subtest corrs=0.37-0.59, Median=0.44; 2. Corrs betw subtests & suppl tests=0.07-0.43, median=0.29; Factor Analysis: The 6 subtests loaded on 1 factor, accting for 96% of total var. Loadings=0.56-0.76. Validity of the Vocabulary Subtests: The median std frequency index (SFI) for the Picture Vocabulary subtest was 48; the median SFI for Relational Vocabulary was 53; and the median SFI for Oral Vocabulary was 60. The tests were in the hypothesized order of maturity from least to most mature | TOLD-P:3 is a valid measure of lang and can be used with confidence | By author: NR By reviewer: Table 7.9 may have errors in it. It does not match statements made in paragraph describing the table

Evidence Table 29. Child Language Disorders -- TOLD-P:3: Normative Data Outcomes

Author (year) | Population to Which Standardized Population/Source Characteristic | Score Reported | Other Analyses
Hammill and Newcomer, 1997^71^ Instr: TOLD-P3 | Population/Source: Statistical Abstract of the United States (U.S. Bureau of the Census, 1997) Characteristics:; 1. Geographic region; 2. Sex; 3. Race; 4. Residence; 5. Ethnicity; 6. Family Income; 7. Educational attainment of parents; 8. Disability status | Std scores, %ile ranking, and age equivalents | NR

Evidence Table 30. Child Language Disorders -- TOLD P:3: Predictive Validity Outcomes

Author(s) (year) | Predictive Validity Results Hypotheses tested Results | Conclusions | Limitations of Study
Lewis et al., 2000^72^ Instr: TOLD-P2 | Statistical methods: multiple regression, sensitivity (sens)/specificity (spec) /risk ratio (RR) for predicting school age lang, read, & spell impairments Outcome#1: Language Disorder; 1. Beta weight for TOLD-P2 as a predictor for language disorder=(0.499, P< 0.001). R-squared for model=0.599; 2. Sens=0.50, Spec=0.76, RR=1.25 (NS); Outcome #2: Reading Disorder; 1. Beta weight for TOLD-P2 as a predictor for reading disorder= (0.515, p < .05). R-squared for model=0.455; 2. Sens=0.71, Spec=0.65, RR=3.13 (NS); Outcome #3: Spelling Disorder; 1. Beta weight for TOLD-P2 as a predictor for spelling disorder= (0.252, P < 0.05). R-squared for model=0.332; 2. Sens=0.64, Spec=0.77, RR=2.25 (p=0.038) | 1. School age lang and read ability predicted by presch TOLD-P:2 scores; 2. Spelling impairment associated with presch phono impair (as measured by word discrim subtest of TOLD-P:2) | 1. No stats reported for comps of means; 2. No corrections made for multiple comparisons

Evidence Table 31. Child Language Disorders -- TOLD-I:3: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/ Duration | Quality Score (%)
Hammill and Newcomer, 1997^71^ Instr: TOLD-I:3 | To provide reliability/validity data and norm info | Rel/validity study | Inclusion:; 1. Ages 8-0 to 12-11; 2. English-speaking; Exclusion: Deafness | Overall: Unk/779 ICR: Unk/779 TRR: Unk/55 InterR: 50 completed protocols from studied sample Content Validity: Unk/779 Criterion Validity: 26/26 Construct Validity: Group Diff: 356/356 | Overall: Sex:(M/F): 405/374 52%/48% Age: 8-0 to 8-11: 104 9-0 to 9-11: 201 10-0 to 10-11: 180 11-0 to 11-11: 160 12-0 to 12-11: 134 Race (Wh/AA/O): 78%/15%/7% Ethnicity (H/NA/As/AA/O): 10%/15%/3%/1%/71% Dx: Learn disability: 43% SLD: 3% Ment retard: 2% Other handicap: 1% TRR: 12 in 4^th^ grade, 28 in 5^th^ grade, & 15 in 6^th^ grade Criterion Validity: 5^th/^6^th^ grade Construct Validity: SLD: 225 Learn disability: 92 Ment retard: 39 ADHD: 36 | Setting: NR Procedures: TOLD-I:3 admin as described in manual | Qcations: "experienced examiners" Training provided: NR | United States | Dates: Spring 1996 Duration: TRR-1 w | M=91.2% C=88.9%
Fodness et al., 1991^70^ Instr: TOLD | To examine T-RR of TOLD-P2 & TOLD-I2 total and composite scales at various age levels | Cohort w/o comp grp (conven-ience sample) | Inclusion: English primary language Exclusion: NR | T-RR: unk/61 | Sex: M/F: 25%/75% Age (#): Unk in each age group (8-0 to 8-11, 10-0 to 10-11, 12-0 to 128-11) Race (Wh/B/O): 85%/7%/8% Income: >$35,000=48% Urban/Rural: 92%/8% | Setting: NR Procedure:; 1. Tests admin consistent with manual guidelines; 2. Test repeated 12-16 d later by same examiner | Qcations: 2 F examiners; otherwise, NR Training: NR | United States | Date: NR Duration: 12-16 d | M=80.0% C=73.3%

Evidence Table 32. Child Language Disorders -- TOLD-I:3: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Hammill and Newcomer, 1997^71^ Instr: TOLD-I:3 | Internal Consistency: Statistical methods: Cronbach's coefficient alpha; 1. The Mn alphas=0.84-0.97 (subtests) & alpha=0.92-0.96 (composites); 2. 8 y olds: alpha=0.84-0.90 (subtests) & alpha=0.93-0.96 (composites); 3. 9 y olds: alpha=0.80-0.96 (subtests) & alpha=0.92-0.96 (composites); 4. 10 y olds: alpha=0.82-0.96 (subtests) & alpha=0.92-0.96 (composites); 5. 11 y olds; alpha=0.83-0.97 (subtests) & alpha=0.92-0.96 (composites); 6. 12 y olds: alpha=0.83-0.97 (subtests) & alpha=0.93-0.96 (composites); 7. Alphas provided for subtest and composite scores by sex, race, ethnicity, and disability status; alphas=0.70-0.97; T-RR: Statistical methods: Corr coefficients For the subtests, corrs=0.83-0.93; for composites, corrs=0.94-0.96 Inter-R: Statistical methods: Corr coefficients For subtests & composites, all corrs>=0.94 | TOLD-I:3 has little test error and users can have confidence in the results | NR
Fodness et al., 1991^70^ Instr: TOLD-I:2 | Statistical methods: Pearson's correlations w/ Guilford and Fruchter's correction for range restriction *T-RR (Corrs>= 0.85 considered min reliab): TOLD-I2:; 1. Listening: range=0.87-0.96; 2. Speaking: range=0.91-0.96; 3. Semantics: range=0.91-0.95; 4. Syntax: range=0.89-0.93; 5. Overall: range=0.92-0.97 | TOLD-I:2:; 1. All composite suff reliable for all 3 age grps; likely T-RR would be similar for 9 & 11 yo; 2. Limited # of 8 yo in standardization sample limits usefulness. TOLD-P:2 may provide more accurate assess for 8 yo | 1. Limited # of 8 yo in standardization sample limits usefulness despite high T-RR

Evidence Table 33. Child Language Disorders -- TOLD-I:3: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Hammill and Newcomer, 1997^71^ Instr: TOLD-I:3 | Content Validity: Statistical methods: Discriminating power, % difficulty, Delta scores (diff), Correlation coefficients Item Analysis:; 1. For 8 y olds, the median discriminating power=0.28-0.59, 0.29-0.62 for 9 y olds, 0.24-0.59 for 10 y olds, 0.33-0.67 for 11 y olds, & 0.27-0.68 for 12 y olds; 2. For 8 y olds, the median % of difficulty=0.34-0.63, 0.40-0.66 for 9 y olds, 0.54-0.71 for 10 y olds, 0.55-0.76 for 11 y olds, & 0.68-0.80 for 12 y. olds; Differential Item Functioning:; 1. Item bias found in 2.5% (sex), 3.0% (AA vs. Non-AA), 2.5% (H vs. Non-H), 5.0% (SLD vs. non-SLD), & 6.0% (LD vs. non-LD); 2. Corr betw Delta scores: 0.97-0.99 (sex), 0.96-0.99 (AA vs. Non-AA), 0.92-0.98 (H vs. Non-H), 0.93-0.97 (NA vs. non-NA), 0.82-0.95 (AS vs. non-AS), 0.97-0.99 (SLD vs. non-SLD), 0.94-0.98 (LD vs. non-NLD), 0.88-0.96 (Ment Retard vs. non-MR), & 0.95-0.97 (ADHD vs. non-ADHD). Large corrs indicate little bias in test; Concurrent: Statistical methods: Correlation coefficients TOLD-I3/TOAL-3:; 1. Corr TOLD-I:3 spoken languages composite (SLQ) and TOAL-3 SLQ=0.85; 2. Corrs betw TOLD-I:3 subtest & TOAL Gen Lang=0.65-0.86. TOLD-I:3 composite corrs=0.81-0.87; 3. Corrs betw TOLD-I:3 subtest & TOAL-3 Spoken Lang=0.64-0.85. TOLD- I:3 composite corrs=0.80-0.85; 4. Corrs betw TOLD-I3 subtest & TOAL-3 Written Lang=0.66-0.81. TOLD-I:3 composite corrs=0.78-0.86; 5. Corrs betw TOLD-I:3 subtest & TOAL-3 Vocabulary=0.65-0.84. TOLD-I:3 composite corrs=0.83-0.88; 6. Corrs betw TOLD-I:3 subtest & TOAL-3 Grammar=0.58-0.86. TOLD-I:3 composite corrs=0.74-0.83; Age Differentiation: The Mn subtest scores incr w/ increasing age. Corr betw TOLD-I:3 subtests and age=0.32-0.47 Group Differentiation: Mn subtest/composite scores presented by disability group.; 1. SLD grp Mns=7-8 (subtest) & 84-86 (composite); 2. LD grp Mns=6-7 (subtest) & 78-82 (composite); 3. MR grp Mns=3-5 (subtest) & 65-66 (composite); 4. ADHD grp Mns=7-8 (subtest) & 83-86 (composite); Subtest InterCorrelations:; 1. Subtest corrs=0.38-0.63, Median=0.54; 2. Subtest intercorrelations given for sex, race/ethnicity, SLD, and learning disabilities (corrs=0.49-0.61); TOLD-I:3/CSSA(Comprehensive Scales of Student Abilities): Corrs betw TOLD-I:3 composites and CSSA values=0.45-0.77. Highest corrs observed between CSSA & TOLD-I:3 listening composite; lowest corrs observed for TOLD-I:3 speaking and syntax composites Factor Analysis: The 6 subtests loaded on 1 factor, accting for 88% of total var. Loadings=0.59-0.79 | TOLD-I:3 is a valid measure of lang and can be used with confidence | NR

Evidence Table 34. Child Language Disorders -- TOLD-I:3: Normative Data Outcomes

Author (year) | Population to Which Standardized | Score Reported | Other Analyses
Author (year) | Population/Source Characteristics | Score Reported | Other Analyses
Hammill and Newcomer, 1997^71^ Instr: TOLD-I3 | Population/Source: Statistical Abstract of the United States (U.S. Bureau of the Census, 1990) Characteristics:; 1. Sex/Race/ethnicity; 2. Geographic region; 3. Family Income; 4. Educ attainment of parents; 5. Disability status | Std scores, %ile ranking, & age equivalents | NR

Evidence Table 35. Child Language Disorders -- PLS-3: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/ Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/Duration | Quality Score (%)
Zimmerman et al., 1992^74^ Instr: PLS-3 | To provide reliability (ICR, T-RR, InterR), validity (content, construct, con-current), and popn norms | Reliability/Validity study | Inclusion: NR Exclusion:; 1. Previously identified as lang disordered; 2. Receiving lang remediation services following lang disorder dx; 3. Age < 2 w; 4. Born at < 35 w gestation; 5. Had difficulties at birth, incl did not go home from the hospital with the mother, hospital stay >= 1w, sign birth defect, genetic defect; Concurrent (discriminant): Age, sex, race, educ matched child w/o lang disorder | Norm/ICR: Unk/1200 T-RR: Unk/85 from norm sample InterR: Unk/80 from norm sample Concurrent (discriminant): Unk/174 from norm sample PLS-3 and Denver II: Unk/28 PLS-3 and PLS-R: Unk/28 PLS-3 and CELF-R: Unk/58 | Norm/ICR: Age: 48-51 in each 3-mo interval from 0-0 to 0-11; 96-203 in 6-mo interval from 1-0 to 4-11, 100/101 in 5-0 to 6-11 Sex: M/F: 600/600 (50%/50%) Race: (Wh/AA/H/O): (69.0%/14.9%/ 11.9%/4.2%) TRR: Age: 3-0 to 3-5, 4-0 to 4-5, 5-5 to 5-11 InterR: Age: 3-0 to 6-11 Concurrent (discriminant): Age: 3-0 to 5-11 w/ matched non lang disordered children PLS-3 and Denver II: Sex: M/F 13/15 Age: 0-11y (Mn=5 mo) PLS-3 and PLS-R: Sex: M/F 18/11 Age: 3-0 to 3-11 y PLS-3 and CELF-R: Sex: M/F 25/33 Age: 5-0 to 6-11 y | Setting: sites in 40 states and District of Columbia Procedures:; 1. PLS-3 admin according to protocol; 2. (T-RR/InterR) Samples for T-RR and InterR selected randomly from entire sample; 3. (T-RR) One examiner admin both tests; 4. (InterR) Two examiners scored test; 5. (Concurrent) two tests admin by same examiner in counterbalanced order | Qcations: NR Training provided: NR | United States | Dates: 6/91-NR Duration: 2d-2w (Mn=4.7 d) for T-RR, 2 concurrent validity studies | M=90.9% C=82.9%
Berryman, 1983^76^ Instr: PLS-R | 1. To provide item-ordering data for revised scale; 2. To examine relationship betw Auditory Comprehension (AC-receptive) and Verbal Ability (VA-expressive) subtests | Controlled trial/non-randomized | Inclusion: Preschoolers in a pre-kindergarten program Exclusion: NR | 672/672 | Overall: Sex: M/F: 356/316 (53%/47%) Age (in ms): Mn(M)=52.83 Mn(F)= 53.28 Range=44-64 | Setting: Large midwestern school system Procedures: PLS-R admin by trained school personnel | Qcations: 26 school personnel certified in early childhood education or special education Training: Introductory workshop, supervised practice w/ colleagues and children | United States | Date: NR Duration: NR | M=64.3% C=64.7%
McLoughlin and Gullo, 1984^75^ Instr: PLS-R | To compare the predictive efficacy of 2 screening tests to the PLS-R (diagnostic test) | Controlled trial/non-randomized | Inclusion:; 1. Preschool children attending a university-run child development center day nursery; 2. No lang delay as determined by teacher; Exclusion: NR | 25/25 | Overall: Sex: M/F: 14/11 (56%/44%) Age Mn(range): Males: 4-2 (3-3 to 5-0) Females: 4.0 (3-3 to 5-0) All White & middle class | Setting: NR Procedures:; 1. Tests admin in 3 sessions in counterbalanced order; 2. Tests admin w/in two 3- to 4-w periods; 3. Examiner had no knowledge of study's purpose | Qcations: Examiners trained to test preschool children Training: NR | United States | Date: NR Duration: Two 3- to 4-w periods | M=73.3% C=64.7%
Pecyna Rhyner and Bracken, 1988^77^ Instr: PLS-R | To compare preschool children's perfor-mance on Bracken Basic Concept Scale (BBCS), Preschool Lang Scale (PLS-R) & Slossen Intelligence Test (SIT)?concurrent validity of BBCS | Controlled trial / non-randomized | Inclusion:; 1. Children from a Midwestern daycare center.; 2. Normal hearing; 3. No hx of SL delays; Exclusion: NR | 62/62 | Sex: M/F: 29/33 (55.8%/44.2%) Age (ms): Mn(range)=51.67(30-72) Race (Wh/AA/O): (95.2%/4.8%) Predominantly from middle class families | Setting: 2 Midwestern day care centers Procedures: Tests admin in counterbalanced order over two sessions | Qcation: Grad SLP student Training: BBCS, PLS-R, & SIT admin | United States | Date: NR Duration: NR betw sessions | M=71.4% C=70.6%
Long, 1998^83^ Instr: PLS-3 | 1. To determine if PLS-3 could validly assess lang develop skills of Native American children.; 2. To eval the PLS-3 perfor-mance of Native Ameri-cans to Whites. | Controlled trial/ non-randomized | Inclusion: Expt 1:; 1. Native American children in Head Start Pgm; 2. Have a Certificate Degree of Indian Blood card & be at least 1/8th Cherokee Indian.; 3. English speaking.; 4. Normal SL and hearing; Expt 2:; 1. Native American child or White child from Head Start Pgm; 2. English speaking; Exclusion: NR | Expt 1: 60/60 Expt 2: 40/40 | Expt 1: Sex: M/F: 30/30 (50%/50%) Age: 3-5 y * All Native Americans Expt 2: Sex: NR Age: 5 y Race: (Wh/NA) 50%/50% | Setting: Head Start Program Centers in NE Oklahoma Procedures: PLS-3 admin individually to child | Qcations: Expt 1: SLP & undergrad SLP students Expt 2: Undergrad students in Communication Disorders Training: Attendance of diagnostics course, trained by authors, 2 practice admin on normal children | United States | Date: NR Duration: NR | M=85.7% C=60.9%

Evidence Table 36. Child Language Disorders -- PLS-3: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Zimmerman et al., 1992^74^ Instr: PLS-3 | Statistical methods: Cronbach's coefficient alpha, SEM, % agr and corr (InterR) ICR:; 1. AC subscale: alphas=0.47-0.88; alphas < 0.7 for 0-0 to 0-2, 0-6 to 0-8, 0-9 to 0-11ms; alphas > 0.80 for 6 of 14 grps; 2. EC subscale: alphas=0.68-0.90; alphas < 0.7 for 0-0 to 0-2 and 0-3 to 0-5 ms; alphas > 0.81 for 8 of 14 grps; 3. Total Language score: alphas=0.74-0.94; lowest alphas for 0-0 to 0-2 and 0-6 to 0-8, all others > 0.80; T-RR:; 1. AC: stability coeffs=0.89-0.90 (across age groups); 2. EC: stability coeffs=0.82-0.92 (across age groups); 3. Total Lang: stability coeffs=0.91-0.94 (across age groups); 4. SEMs range from 3.96 to 5.74; InterR: % agr=89%, corr betw scores=0.98 | NR | NR

Evidence Table 37. Child Language Disorders -- PLS-3: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Zimmerman et al., 1992^74^ Instr: PLS-3 | Content: Lang skills tested in the PLS-3 are well documented in literature addressing lang dis, develop, and psycholinguistics Construct: Statistical Method: Discriminant analysis, corr Discriminant Analysis: PLS-3 (1.5SD below Mn Total Score) correctly classified lang disorder:; 1. 3-0 to 3-11 66% of time; Sens=0.91; Spec=0.60; PPV=0.36; NPV=0.96; 2. 4-0 to 4-11 80% of time; Sens=1.00; Spec=0.72; PPV=0.61; NPV=1.00; 3. 5-0 to 5-11 71% of time; Sens=0.93; Spec=0.64; PPV=0.45; NPV=0.97; 4. Majority of errors were PLS-3 due to not classifying previously identified lang disordered children; Correlation: Corr betw EC and AC=0.64 Concurrent: Statistical Method: corr PLS-3 and Denver II: All children earned a "normal" rating on the Denver II and scored w/in 1.5 SD of Mn on PLS-3 PLS-3 and PLS-R:; 1. Corrs betw PLS-3 and PLS-R subtests and Total Lang scores=0.66, 0.86, 0.88 for comprehension, expressive and total scores, respectively; 2. PLS-3 age-equivalents were approx 1 y younger than those for the PLS-R; PLS-3 and CELF-R: Corrs betw PLS-3 and CELF-R subtest and Total scores=0.69, 0.75 and 0.82 for comprehension, expression and total scores, respectively | 1. PLS-3 has thorough and balanced sample of lang behaviors (content validity); 2. PLS-3 differentiates lang disordered from normal children (construct); 3. PLS-3 is highly corr w/ other measures of lang ability (concurrent) | NR
Berryman, 1983^76^ Instr: PLS-R | Statistical methods: Chi-square, Phi coefficients (effect size), t-tests, point-biserial correlations Item Placement:; 1. AC subtests had progressively lower % passing scores at each successive age level; 2. For the VA subtest, % passing slightly lower for 3.5 to 4 yos compared to 4-4.5 yos; 3. For 5 of 80 items, age-level placement is questionable (% passing consistent with a higher or lower age level than the level to which the items were assigned; Sex Diffs on Items:; 1. For the AC subtest, 8 of 40 items were sign diff (p< 0.05) for boys and girls but the phi coeffs (effect size) were low (range=0.10-0.15); 2. For the VA subtest, 8 of 40 items were sign diff (p< 0.05) for boys and girls but the phi coeffs (effect size) were low (range=0.08-0.14); Mean Score Diffs; 1. Sign sex diffs for AC subtest (t=3.27, p<0.01), VA subtest (t=2.86, p<0.01) and total score (t=3.29, p<0.01); 2. Point-biserial corrs calculated from t statistics (effect size) small (0.10-0.12) for comparisons; Corrs betw subtests: Corrs betw AC & VA for boys r =0.72 (p<0.011), girls (r=0.72, p<0.001), and both (r=0.72, p<0.001) | 1. There is a clinically negligible sex effect on item performance & subtest scores; 2. Age-level placement of 5 of 80 items is questionable; 3. Corrs betw tests indicate measurement of similar aspects of lang | No corrections for multiple comparisons
McLoughlin and Gullo, 1984^75^ Instr: PLS-R | Statistical methods: Repeated measures ANOVA, Pearson Corr, Stepwise Multiple Regression Diffs betw tests; 1. No sign diff betw sex. Sex scores combined for subsequent analyses; 2. Main effect for test [F(2,96)=33.47, p<0.001]. Post-hoc analyses revealed sign higher scores (p<0.01) on PLS vs PPVT-R and TELD; 3. No sign diff betw PLS subtests; Corrs betw tests; 1. Corrs betw PLS total score &: PPVT-R=0.727; TELD =0.519; 2. Corrs betw PLS-R total and subtest scores: 0.861 (AC) and 0.931 (VA); 3. Corr betw AC and VA=0.582; 4. Corrs betw PLS-R subtests range from 0.0.421-0.692; PPVT-R & TELD as predictors of PLS-R scores; 1. PPVT-R sign pred of PLS-R Total score (b=0.662, Cum Rsq=0.727); PLS-R VA score (b=0.705, Cum Rsq=0.692); PLS-R AC score (b=0.455, Cum Rsq=0.593); 2. TELD not sign pred of PLS-R scores | 1. PPVT-R is a better predictor of PLS-R scores than the TELD and thus a better screening device for early lang delay; 2. PPVT-R & TELD predict only a portion of lang components assessed by PLS-R | 1. Restricted sample of preschoolers; may not be generalizable to children of other races or with SL disorders; 2. No correction for multiple comparisons
Pecyna Rhyner and Bracken, 1988^77^ Instr: PLS-R | Statistical methods: Correlation, ANOVA w/ Neuman-Keuls post hoc analysis Corrs betw tests:; 1. Corr betw PLS-R Total score & PLS-R AC subtest (0.85) and: PLS-R-VA (0.90). Corr betw PLS VA & AC (0.57) and Total score (0.85); 2. Corr betw PLS-R total and subtest scores and: SIT =0.22, 0.33, 0.35 for PLS-R AC, VA, and total scores, respectively; 3. Corr betw PLS-R total and subtest scores & BBCS low = 0.26, 0.39, 0.40 for PLS-R AC, VA and total scores respectively; Diffs betw test:; 1. Overall sign diff in scores betw tests F(4, 244)=15.75, p < .001; 2. PLS-R subtests and total scores not sign diff from each other or BBCS & SIT; Corrs betw age equivalents and chronological age Corr betw PLS-R total and subtest scores and chronological age moderate to high (0.78=0.86; only VA < 0.80) | 1. PLS-R measures receptive & expressive lang skills, but does not provide a comprehensive assess of basic concept development in preschool children; 2. VA and AC subtest scores contribute supplementary info for the assess of lang skills | 1. PLS-R & SIT std scores use ratio concept, but BBCS std scores use deviation concept; 2. PLS-R uses outdated norms (15 years at date of publication); 3. Sample had higher than average scores on the 3 measures-may not be representative of preschoolers; 4. Sample from single site/region with limited demographic diversity may not be generalizable to other populations; 5. Study is of concurrent validity of BBCS not PLS-R
Long, 1998^83^ Instr: PLS-3 | Statistical methods: For Expt 1, t-tests, two-way ANOVA, Repeated Measures ANOVA, Newman Keuls pairwise analysis, Means w/n cells F-tests. For Expt 2 -- NR Expt 1:; 1. No sign diff betw sample means & US pop PLS-3 norms of 100 (t\ =−1.10, p>0.05); 2. No sign diff betw sex [F(1,54)=0.0, p=0.95]. Sign main effect for age [F(2,54)=5.38, p=0.007]. No sign age-sex interactions; 3. Main effect for age [F (2, 57) = 5.318, p = .008] and main effect for subtests [F (1, 57) = 9.247, p = .004]; 4. Sign diffs among age groups & subtests (p = .01). No sign diff on subtests for 3-year-olds [F(1,57)=0.02 9, p=0.864]. 4-year olds sign lower for Expressive Comm subtest than Aud Comp subtest F(1,57)=9.080, p=0.004]. 5-year olds sign lower for Expressive Comm subtest than Aud Comp subtest F(1,57)=4.336, p=0.042]; Expt 2; 1. Native Amer children & Whites had nearly identical scores for PLS-3 subtests; 2. Cherokee Nation Native Amer children had consistently lower subtest scores than other Native Amer children and White children; 3. Both five-year-old White & Native Amer children did not perform as well as 3- and 4-year-old Cherokee Nation Native Amer children | 1. PLS-3 provided valid assessment of receptive and expressive lang skills of 3- to 40- year old Native Amer children; 2. Use of PLS-3 w/ 5 year-old Native Amer children questionable; these children will score at or below the low end of the normal range in spite of not having a lang delay or dis | 1. Means & SDs not presented-graphs must be interpolated; 2. PLS-3 has only 4 items per subtest for ages 5 and 6 (rather than 8 or more for other age groups); if one item missed, score decr by 3 mos; 3. Cultural diffs, specific to Native Amer, not taken into account by PLS-3; may result in lower scores

Evidence Table 38. Child Language Disorders -- PLS-3: Normative Data Outcomes

Author (year) | Population to Which Standardized Population/Source Characteristics | Score Reported | Other Analyses
Zimmerman et al., 1992^74^ Instr: PLS-3 | Population/Source: US popn ages 6-21y as defined by 1980 US Census Characteristics:; 1. Race/ethnicity; 2. Region; 3. Sex; 4. Educ of primary caregiver | Standard Scores, %ile ranks at 3-mo age intervals from 0-0 to 0-11, 6-mo intervals from 1-0 to 4-11, and 1 y interval from 5-0 to 6-11 test age-equivalents | NR

Evidence Table 39. Child Language Disorders -- PLS-3 Spanish: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/Duration | Quality Score (%)
Zimmerman et al., 1993^84^ Instr: PLS-3 Spanish | To adapt the PLS-3 for young Spanish-speaking children and to provide reliability/validity data | Reliability/ Validity study | Inclusion: Spanish-speaking children Exclusion:; 1. Not Spanish speakers; 2. Previously identified as lang disordered; 3. Receiving lang remediation services following lang disorder dx; 4. Age < 2 w; 5. Born at < 35 w gestation; 6. Had difficulties at birth, incl did not go home from the hospital with the mother, hospital stay 1w, sign birth defect, genetic defect | Overall: Unk/181 | Sex: M/F: 90/91 (49.7%/50.3%) Age: 22-30 in each 1-y interval from 0-0 to 6-11 | Setting: Testing sites in 7 states Procedures: PLS-3 Spanish admin according to protocol | Qcations: NR -- needed to be bilingual Training provided: NR | United States | Dates: NR Duration: NR | M=52.2% C=36.0%

Evidence Table 40. Child Language Disorders -- PLS-3 Spanish: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Zimmerman et al., 1993^84^ Instr: PLS-3 Spanish | Statistical Method: Cronbach's coefficient alpha, SEM ICR:; 1. Auditory Comprehension subscale: alphas=0.38-0.94; alphas < 0.7 for 0-0 to 0-2, 0-3 to 0-5, 1-0 to 1-5, 4-6 to 4-11; alphas>0.80 for 7 of 14 grps; 2. Expressive Communication subscale: alphas=0.33-0.92; alphas < 0.40 for age 0-0 to 0-5, alphas < 0.7 for 1-0 to 1-5 and 6-0 to 6-11; alphas > 0.80 for 10 of 14 grps; 3. Total Language score: alphas=0.39-0.92; alphas < 0.7 for 0-0 to 0-2, 0-3 to 0-5 and 1-0 to 1-5; alphas > 0.80 for 11 of 14 grps; 4. Alphas < 0.80 | NR | 1. Sample size is small (< 10) for age groups under 1-6 y.; 2. Age groups 1-6 to 4-11 have fewer than 20 in each

Evidence Table 41. Child Language Disorders -- PLS-3 Spanish: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Zimmerman et al., 1993^84^ Instr: PLS-3 Spanish | Statistical Method: Means, SDs, t-tests, % of children passing tasks at each age Construct:; 1. Raw score means for Auditory Comprehension (AC) and Express Communication (EC) subscales increase with age reflecting increased lang ability. AC Mn(SD)=2.8(1.0) for 0-0 to 0-2 to 43.5(3.5) for 6-0 to 6-11; EC Mn(SD)=3.0(1.2) for 0-0 to 0-2 to 43.4(2.4) for 6-0 to 6-11; 2. Mn standard scores for PLS-3 Spanish sign lower than for PLS-3 English (all p <0.01); 3. Sequence of lang skills acquisition in PLS-3 Spanish mirrors that in PLS-3 English; 4. Prelang skills in PLS-3 Spanish mastered at same age as PLS-3 English; 5. Lang skills mastered approx 6 mos later by PLS-3 Spanish sample | Although Spanish-speaking children learn the lang skills targeted by the PLS-3, the timing and sequence of the acquisition process may differ | 11. No corrections for multiple comparisons NR

Evidence Table 42. Child Language Disorders -- PLS-3 Spanish: Normative Data Outcomes

Author (year) | Population to Which Standardized Population/Source Characteristics | Score Reported | Other Analyses
Zimmerman et al., 1993^84^ Instr: PLS-3 Spanish | NR | NR | Examiner is referred to PLS-3 norms but cautioned that a low score does not necessarily mean that lang is disordered.

Evidence Table 43. Child Language Disorders -- TOPL: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/Duration | Quality Score (%)
Phelps-Teraski and Phelps-Gunn, 1992^85^ Instr: TOPL | To present item selection/analysis, reliability (ICR, Inter-r, validity (construct, concurrent, content), and normative scores | Cohort w/comp grp | Inclusion: NR Exclusion: NR | Overall: 1016/1016 InterR: 30/30 w/ 2 judges (authors) Concurrent V: 30/30 Item Validity: 50/50 Children w/ hx of lang difficulties: 24/24 | Sex: M/F: 488/528 (48%/52%) Age (%): 5-0 to 5-11: 16% 6-0 to 6-11: 10% 7-0 to 7-11: 12% 8-0 to 8-11: 14% 9-0 to 9-11: 13% 10-0 to 10-11: 10% 11-0 to 11-11: 11% 12-0 to 12-11: 8% 13-0 to 13-11: 6% Race (Wh/AA/O) (81%/15% /4%) Ethnicity (H/As/AI/O) (11%/2%/1%/86%) Concurrent: Age: Mn=6.7 y (range=5-9 to 7-5) Item validity: ages 5-13 (randomly selected from norm sample) | Setting: Examination sites in 24 states and Ontario, Canada Procedures: NR | Qcations: Professionals who recently purchased tests from publisher and individuals who assisted published in development of other tests Training provided: NR but provided by authors | United States, Canada | Dates: 9/1989 to 6/1990 Duration: N/A | M=83.3% C=71.9%

Evidence Table 44. Child Language Disorders -- TOPL: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Phelps-Teraski and Phelps-Gunn, 1992^85^ Instr: TOPL | Statistical methods: Cronbach's alpha, SEM (ICR); corr (InterR) ICR:; 1. Alphas (by age) range from 0.74-0.89 (Mn=0.82); 2. SEM (by age) range from 5.0-7.6 (Mn=6.3); InterR: Corr betw two judges=0.99 | All but one ICR alpha > 0.80 and show acceptable reliability | InterR (using test authors) may be higher than found in practice

Evidence Table 45. Child Language Disorders -- TOPL: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Phelps-Teraski and Phelps-Gunn, 1992^85^ Instr: TOPL | Statistical methods: Corrs (criterion, construct, discrimination,& difficulty) Item Analysis (discrimination/difficulty):; 1. Discriminating power by age range from 0.23-0.49; 2. Item difficulty by age ranges from 0.57-0.92 and incr with age; Content: presents sophisticated model linking test components to SL processes Construct:; 1. Raw Mn scores incr from age 5 (23.2) to age 13 (39.4). Corr betw score & age=0.55 (p<0.001); 2. TOPL scores of children w/ hx of lang difficulties and learning disabilities were significantly below average (Mn=87) *Reports results of other studies:; 3. TOPL & Spoken Lang: Corr betw TOPL & lang subtest of SCREEN=0.70; 4. TOPL & School Achievement: corr betw TOPL & math subtest of SCREEN=0.32.; corr betw TOPL & writing subtest of SCREEN= 0.39; corr betw TOPL & reading subtest of SCREEN=0.55.; 5. TOPL & Mental Ability: Corr betw TOPL & Scholastic Aptitude Scale=0.68 (corr for attenuation); Concurrent: Corr between teacher's ratings & TOPL scores=0.82 | 1. TOPL items have acceptable item discrimination; all exceed conservative threshold of 0.30; 2. Item difficulty falls w/in acceptable range (15%-85%) for 4 of 9 age groups, only slightly higher for others; unlikely that test does not have construct validity; 3. Uses other studies to test hypotheses about TOPL and spoken lang, math, writing, reading abilities -- correlated according to hypotheses | Insuff demog info on some of subgroups involved in testing

Evidence Table 46. Child Language Disorders -- TOPL: Normative Data Outcomes

Author (year) | Population to Which Standardized Population/Source Characteristics | Score Reported | Other Analyses
Phelps-Teraski and Phelps-Gunn, 1992^85^ Instr: TOPL | Population/Source: pop ages 2-0 to 21-11 from 1998 US Census Characteristics:; 1. Race/ethnicity; 2. Geographic region; 3. Sex; 4. Residence (urban/rural) | Quotients (Mn=100, SD=15), %ile ranking, test-age equivalent Age: by 6-m intervals for 5-0 to 5.5 y to 8-6 to 8-11, 1-y intervals for 9-0 through 13-11 | NR

Evidence Table 47. Adult Speech Disorders -- AIDS: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/ Duration | Quality Score (%)
Yorkston and Beukelman, 1984^23^ Instr: AIDS | To present reliability (InterR, IntraR), content validity, and norm for rate of intelligible speech | NR | Inclusion: for norms, "normal speakers"; otherwise NR Exclusion: NR | Single word:; 1. IntraR -- 9 voices w/ unk # judges then 12 randomly selected voices; 2. InterR -- Unk # voices w/ 5 judges; Sentences:; 1. IntraR -- NR; 2. InterR -- unk # voices w/ 4 judges; Norm (rate of intelligible speech): 20/20 | IntraR/InterR: NR M/F: 10/10 | Setting: NR Procedures:; 1. InterR (single word) -- 12 randomly selected sample of 2 50-word speech samples presented to each judge; 2. Samples audiotaped and judged under multiple choice and transcription formats | Qcations: NR Training provided: NR | NR | Dates: NR Duration: NR | M=30.8% C=48.1%

Evidence Table 48. Adult Speech Disorders -- AIDS: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Yorkston and Beukelman, 1984^23^ Instr: AIDS | Statistical methods: Pearson corr (InterR, IntraR), % agr (Intra-rater dispersion), ANOVA w/ post hoc testing (no correction for multiple comparisons reported) IntraR (single word):; 1. Corr for multiple choice and transcription formats were 0.90 and 0.87; 2. % agr reported by format for 10-, 8-, 6-, and 4-point range: Multiple choice: 10-pt =100%, 8-pt=98%, 6-pt=93%, 4-pt=80%. Transcription: 10-pt =98%, 8-pt=95%, 6-pt=92%, 4-pt=80%; InterR (single word):; 1. Corrs=0.88-0.99 for multiple choice task and corr=0.96-0.99 for transcription task; 2. No sign diff betw judges for multiple choice format (F=1.50, df=4,32, P>0.05); 3. Sign diff betw judges for transcription format (F=4.2, df=4,32, P<0.01. Sign diffs betw 2 judges in post hoc comparisons; 4. % agr reported by format for 10-, 8-, 6-, and 4-point range: Multiple choice: 10-pt =98%, 8-pt=96%, 6-pt=93%, 4-pt=82% Transcription: 10-pt =100%, 8-pt=94%, 6-pt=92%, 4-pt=78%; 5. For 12 randomly chosen voices, equivalency of samples was tested. Corrs were 0.91-0.93 depending upon type of sample; IntraR (sentence):; 1. Corr for intelligibility%=0.96-0.99; 2. Corr for rate of intelligible speech=0.99 for all judges; InterR (sentence):; 1. Corrs=0.93-0.99 for intelligibility. All corrs for rate of intelligible speech were 0.99; 2. % of judges' scores which fell w/in 20% and 10% range reported: Intelligibility%: 20% range=93%, 10% range=83% Rate of intelligible speech: 20% range=100%, 10% range=88%; 3. No sign diff betw judges for measures of intelligibility% (F=0.39. df=3,30 P>0.05) and rate of intelligible speech (F=2.69. df=3,30 P>0.05) | Multiple choice and transcription formats produce same InterR for single word | 1. Insuff info on methods and on voice and judge samples. Cannot judge whether Instr is reliable and/or valid; 2. No corrections for multiple comparisons in ANOVA reported

Evidence Table 49. Adult Speech Disorders -- AIDS: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Yorkston and Beukelman, 1984^23^ Instr: AIDS | Statistical methods: NR Content: presents discussion of factors related to dysarthric speech and intelligibility and proposed a model for measurement Construct: NR | NR | NR

Evidence Table 50. Adult Speech Disorders -- AIDS: Normative Data Outcomes

Author (year) | Population to Which Standardized Population/Source Characteristics | Score Reported | Other Analyses
Yorkston and Beukelman, 1984^23^ Instr: AIDS | Population/Source: NR Characteristics: NR | Efficiency ratio for intelligible speech | Efficiency ratio derived from sample of 20 individuals whose characteristics are unk

Evidence Table 51. Adult Speech Disorders -- DEB: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/ Duration | Quality Score (%)
Drummond, 1993^88^ Instr: DEB | To describe item selection, identify the standardization sample, estimate the test's reliability, and demonstrate its validity. | Rel/Validity study & coh w/ comp grp | Inclusion: (Stdization); 1. Dysarthric -- "mild" dysarthria; 2. Cntls -- normal (non-dysarthric/brain-damaged; 3. Addl study with pts w/ athetoid cerebral palsy (4), Parkinson's Disease (10); (InterR/IntraR): NR Exclusion: NR | Stdization: 20/20 plus 34 described in 3 other studies InterR/IntraR: Voices: 18/18 Raters: 6/6 Construct: 62/62 (Stdization, plus 38) | Stdization: Sex:(M/F): 10/10 Dx: R hemisph CVA Closed head trauma: 1 InterR/IntraR: Dx: tumors, head trauma, athetoid cerebral palsy, Parkinson's disease, CVA | Setting: University Medical Center Procedures:; 1. DEB admin in a 1-h session; 2. All elicited voices tape recorded and analyzed with Kay Elemetrics VisiPitch-Apple IIE; InterR/IntraR:; 1. All 18 voices videotaped and the responses to 10 stimuli were grouped together; 2. Raters rated same stimuli for all voices; order of voices randomly selected but is same for all stimuli | Qcations: InterR/IntraR: Grad SLP students (w/ & w/out clin exp and exp w/ DEB); otherwise NR Training provided: NR | United States | Dates: NR Duration: IntraR 1w | M=38.7% C=27.8%

Evidence Table 52. Adult Speech Disorders -- DEB: Reliability Outcomes

Author (year) | Reliability Results | Conclusions | Limitations of Study
Drummond, 1993^88^ Instr: DEB | InterR: Statistical methods: ANOVAs w/ derived corr coefficients; 1. Corrs for each of 10 rated measures= 0.61(nasality)-0.98(lingual lateralization); Mn=0.90; 2. Exp raters (corr=0.62-0.98, Mn=0.878) had higher corrs than inexp raters (corr=0.40-0.99, Mn=0.796). Lowest corrs observed for nasality and vocal quality: speech; IntraR: Statistical methods: Corr coefficients; 1. Mn corrs (exp rater)=0.78, 0.81, & 0.77. Mn corrs (inexp rater)=0.68, 0.67, & 0.69; 2. All 6 raters showed a sign corr betw ratings for 8 of the 10 measures; 3. 2 of the 3 inexp raters & 1 of the 3 exp raters showed NS corrs betw ratings for vocal quality & nasality; 4. Results were confirmed w/ of 10 indivs w/ Stage III of Parkinson's disease -- NR | NR | NR

Evidence Table 53. Adult Speech Disorders -- DEB: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Drummond, 1993^88^ Instr: DEB | Stdization: Statistical methods: t-tests; 1. Sign diff betw normal and dysarthric indivs on each of 16 measures (all p < 0.05, 5 < 0.001); 2. Dysarthric indivs had consistently inferior scores than normals though, 3 of dysarthric Mn values were not "abnormal"; 3. When compared to mildly dysarthric indivs in stdization sample, 4 moderately dysarthric indivs showed subnormal perfs for more measures; 4. When compared to indivs w/ Parkinson's disease, similar levels or severity/abnormality were observed; Construct Validity:; 1. 1dysarthric indiv showed abnorm perf on each of the 36 DEB measures; 2. Dist of the %age of dysarthric indivs abnorm perfs resembles a bell curve, w/ few indiv in lower/upper 10%ile and 2/3 in middle | Results clearly establish construct validity | By author: NR By reviewer:; 1. Reports results from other studies w/o providing information on study design; studies are not published in peer-reviewed literature; 2. No statistics provided to support validity results; 3. No correction for multiple comparisons

Evidence Table 54. Adult and Child Speech Disorders -- SSI-3: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/ Duration | Quality Score (%)
Riley, 1994^89^ Instr: SSI-3 | 1. To present reliability (InterR & IntraR), validity (construct & criterion) data; 2. To provide normative data for 3 age groups: 2-10 to 5-11, 6-0 to 16-11, and 17-0 and older | Reliability/ validity | Inclusion: Children and adults ages 2-10 y and older Exclusion: NR | IntraR: 5 speaking samples raters 7/7 InterR: Unk speaking samples 23/23 Validity/Norms: 271/271 | IntraR & InterR: NR Validity/Norms: Sex: NR Age: 2-10 to 5-11: 72 6-0 to 16-11: 139 17-0+: 60 * All from California, those under 8 had no prior tx, most >=8 had tx | Setting: NR Procedures:; 1. IntraR -- 2 raters scored 5 videotaped samples at 2 diff times; 2. InterR -- 2 raters & class of grad students scored Unk # of samples; research team used computerized scoring system; 3. Validity -- NR | Qcations: SLP ("experienced"), graduate assistant, class of graduate students, research team Training provided: NR | United States | Dates: NR Duration: NR | M=45.5% C=29.4%

Evidence Table 55. Adult and Child Speech Disorders -- SSI-3: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Riley, 1994^89^ Instr: SSI-3 | Statistical methods: %agr, scale score/class mean for InterR (class) IntraR:; 1. Frequency: 2 exp raters (E1&E2): Mn (E1)=87.1% (range=71.4% to 92.9%); Mn (E2)=86.8% (range=78.6% to 92.9%). 5 research team (RTM) members scored 17 samples twice Mn(team)=93.9% (range=84.2% to 100%); 2. Duration 2 exp raters (E1&E2): Mn (E1)=86.1% (range=75.6% to 95.3%); Mn (E2)=85.7% (range=72.1% to 96.5%). 5 research team members scored 17 samples twice Mn(team)=96.4% (range=75.0% to 96.4%); InterR:; 1. Frequency: 2 exp raters (E1&E2): Mn=86% (range=81% to 90%); 5 RTMs with computerized scoring Mn(team)=91.4% (range=54.2% to 100%); Graduate class Mn=96.0% (range=94.6% to 96.8%); 2. Duration RTM Mn=87.8% (range=60.0% to 100%); Graduate class Mn=84.8% (range=58.1% to 87.2%); 3. Physical Concomitants: 2 exp raters (E1&E2): Mn=80.9% (range=50.0% to 100%); Graduate class Mn(team)=85.7% (range=59.8% to 97.5%) | 1. Larger numbers of samples rated by very exp raters, yielded better IntraR (as expected); 2. InterR lower for physical concomitants than for freq or duration | 1. Unclear whether raters are representative of raters in general; 2. Insufficient detail provided about numbers of voice samples (InterR and IntraR); 3. Insufficient information provided about normative sample. Unclear how many do not stutter; 4. Normative sample from single state may not be representative; 5. Did not use appropriate statistical methods; offered poor explanation for calculation of % agr for class

Evidence Table 56. Adult and Child Speech Disorders -- SSI-3: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Riley, 1994^89^ Instr: SSI-3 | Statistical Method: corr (criterion), part-whole corr and (construct), Mns of corrs Content: NR Construct:; 1. Severity (total score, phys concomitants) increases with duration. Corr betw duration and total score incr preschool to school age (0.73-0.77), no incr from school age to adult; similar pattern see for phys concomitants (corr incr from 0.68, to 0.76 to 0.77). Freq shows opposite pattern: 0.83 (presch), 0.79 (school), 0.74 (adult); 2. Total SSI score incr with age; p-value sig but NR; 3. Part-whole corrs of subtests to total score range from 0.69 to 0.83 (Mn=0.76) (p<0.01 for all); Concurrent:; 1. Part-whole corr betw total score and freq=0.83 (presch), 0.795 (school age), 0.741 (adults), all p< 0.01; 2. Comp of SSI-3 part-whole corrs to max statistical validity (=max % age for InterR(freq)=0.92*0.92=0.846) | 1. Part-whole corrs indicate adequate concurrent validity; 2. 3 parameters test diff aspects of stuttering and none alone can be used to assess severity | 1. No statistics provided to determine whether correlations are stat sign diff with age; 2. No correction made for multiple comparisons; 3. No statistics reported to indicate whether Mn score diffs are sign; 4. Comp to max statistical validity may not be appropr test for concurrent validity

Evidence Table 57. Adult and Child Speech Disorders -- SSI-3: Normative Data Outcomes

Author (year) | Population to Which Standardized Population/Source Characteristics | Score Reported | Other Analyses
Riley, 1994^89^ Instr: SSI-3 | Population/Source:; 1. All from California, those under 8 had no prior tx, most 8 had tx; 2. Comparison to US stutterers not reported; Characteristics: NR | 1. Total overall score reported, w/%ile, and quality severity descriptor (very mild to very severe); 2. Results reported for 3 age groups Presch: (2-10 to 5-11), school age (6-0 to 16-11), and adults (17-0 and older) | Note: norms, derived from relatively small geographically similar samples, may not be generalizable

Evidence Table 58. Child Speech Disorders -- GFTA-2: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/Duration | Quality Score (%)
Goldman and Fristoe 2000^92^ Instr: GFTA-2 | To standardize the Sound-in-Words (S-in-W) and to develop age-based std scores for M/F | Cohort w/ comp grp *Simple random sampling based on demog chars Canadian Comp: Non-equiv. control 281 children compared to age/sex matched children from standard-ization sample | Inclusion: English-speaking Exclusion: NR | Overall: 2350/2350 Test-retest: Unk/53 Inter-rater: 30/30 Other-Can. Comparison: 281/281 | Norm Sample: Sex; M/F: 50%/50% Age: 100 each in 2-0 to 2-11 to 3-0 to 3-11, 7-0 to 7-11 through 15-0 to 21-11; 250 each in 4-0 to 4-11 to 6-0 to 6-11 Race (Wh/AA/H/O): 64.7%/15.5%/15.7%/4% Region (NE/NC/S/W): 18.4%/23.8%/34.8%/23.0% Special Education: Lrn. Dis: 2.35% SLI: 0.85% MR.: 0.5% Emot. Disturb.: 0.5% T-RR: Sex M/F: 43.3/56.6 Age: 4-6 to 7-0 y (Mdn 5-11) Race (W/AA/H/O): 54.7%/30.2%/13.2%/1.9% Region (NE/NC/S/W): 20.8%/9.4%/54.7%/15.1% InterR: M/F: 83.8/26.7 Age: 2-9 to 11-0 (Mdn 4-10) Canada sample: M/F: 50.2/49.8 Age: 3-0 to 7-10 (Mdn 5-2) | Setting: 320 sites in 44 states Procedures:; 1. GFTA admin to children as described in manual. All subtests administered; 2. T-RR admin 2 times, range same day to 34 d | Qcations: SLP familiar w/ artic testing & IPA Training provided: NR | United States, Canada (used to validate norm data) | Dates: 5/99-11/99 Duration: InterR, Mdn=14d, range=0-34d, 22/30 tested on same day | M=83.9% C=81.3%
Mullen and Whitehead, 1977^96^ Instr: GFTA (Orig) | To evaluate diff in correct initial ident of stimulus pictures betw GFTA and AAPS | Controlled trial, non-randomized | Inclusion:; 1. Normal vision; 2. IQ 90-110; 3. Normal hearing; Exclusion: NR | Group 1 (Normal speaking): NR/20 Group 2 (Articulation defective): NR/20 | Group 1 and 2: Sex: M/F -- 50%/50% Race: 100% W Age: Mn 8-2 y (range=7-9 to 8-6) | Setting: NR Procedures:; 1. GFTA(orig) & AAPS5 admin to child; 2. Initial response only recorded as correct, no response, or incorrect; 3. % of correct initial response calculated | Qcations: SLP graduate student Training provided: NR | United States | Dates: NR Duration: 24 h | M=56.3% C=73.3%
Seymour and Seymour, 1981^93^ Instr: GFTA (orig) | 1. To examine influence of black Engl on emerging phono of black children; 2. To comp artic errors betw white(W) & black (B) children | Cohort w/ comp grp | Inclusion:; 1. Black children spoke dialect characteristic of black Engl; 2. White children spoke NE dialect; Exclusion:; 1. Hearing problems; 2. Observable SL pathologies; 3. Suspected intellectual deficits | Overall: 10/160 Group1 (black): 80/80 Group2 (white): 80/80 | Overall: Age: 4-0 to 5-11 y SES: "low" Group1 (B): Sex: M/F: 45/35 (56.2%/43.8%) Group2 (Wh): M/F-43/37 M/F-53.8%/46.2% | Setting: Head Start pgms & daycares Procedures: GFTA(orig) admin to all children. Phonemic symbols used to record substitution errors. | Qcations: grad SLP students Training provided: NR | United States | Dates: NR Duration: NR | M=84.6% C=73.7%
Botting et al., 1997^95^ Instr: GFTA (Orig) | 1. To examine the level of agr between clin description and SL tests for diff types of lang dis; 2. To examine whether agr is similar between more/less complex dis.; 3. To compare test cut-off scores to teacher eval | Retrospective Cohort w/o comp grp | Inclusion: Language impaired children spending 50% or more of the school week in language units Exclusion: NR | NR/242 | Sex: M/F-186/56 M/F-76.9%/23.1% Age: Mn-7-0 ys Range 6-6 to 8-0 ys | Setting: 100 Language units in schools Procedures:; 1. GFTA(orig) & 5 other SL tests admin to child at beginning of project; 2. Teachers and SLPs asked to rate SL impair -- articulation, phonology, syntax &/or morphology, and semantics &/or pragmatics -- scored as has/has not; 3. All speech samples audiotaped | Qcations: SLPs (no other info given) Training provided: NR | Britain/United Kingdom | Dates: NR Duration: NR | M=26.7% C=85.7%
Crutchley, et al., 1997 Instr: GFTA (orig) | To report diffs in SL char of bilingual children compared to mono-lingual children | Retrospective Cohort w/o comparison grp | Inclusion:; 1. Language impaired children spending 50% or more of the school week in language units; 2. Bilingual -- those exposed to lang other than English at home; Exclusion: NR | Overall: 240/240 Group1 (bilingual): 26/26 Group2: (monolingual): 214/214 | Group1 (bilingual): Sex: M/F-22/4 M/F-84%/16% Age: 6-6 to 7-10 y Group2: (monolingual): Sex: NR Age: NR (6-6 to 8-0) for main cohort | Setting: Language units in schools Procedures:; 1. GFTA(orig) & 5 other SL tests admin to child at beginning of project | Qcations: NR Training provided: NR | Britain/United Kingdom | Dates: NR Duration: NR | M=69.2% C=26.7%
Lewis, et al, 2000^72^ Instr: GFTA (orig) | To identify predictors of school-age lang, read, & spell skills in presch children w/ SL disorders | Prosp cohort w/o comp grp | Inclusion:; 1. In tx for mod to severe express phono disorder; 2. Normal hearing acuity.; 3. Normal peripheral speech mechanism; 4. No hx of neuro disorders/develop delays; 5. Normal intelligence (IQ >= 80); Exclusion: NR | 87/52 | Sex: M/F-33/19 M/F-63.5%/36.5% Age: Mn(SD) 9.3 (1.4) Range: 8-11y SES (Hollingshead): 1/2/3/4/5 5.8%/13.5%/19.2%/ 32.7%/28.8% * No diff in GFTA(orig) score betw sample and dropout ((t=1.73, p=0.87) | Setting: Univ speech res lab or at home Procedures:; 1. During preschool assess, children admin TOLD-P2, Nonsense word repetition test, Khan-Lewis phono process analysis, GFTA (original); 2. At school age assess, children administered CELF-R, Woodcock reading Mastery tests (2 subtests), Test of Written Spelling-3, Reading Comp from Wechsler Individual Achievement Test; 3. All samples audiotaped and transcribed on-line using broad phonetic transcription | Qcations: NR Training provided: NR | United States | Dates: NR Duration: 4 y | M=88.9% C=73.7%

Evidence Table 59. Child Speech Disorders -- GFTA-2: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Seymour and Seymour, 1981^93^ Instr: GFTA (orig) | InterR=0.90 | N/A | 1. InterR statistic type not reported; 2. T-RR results taken from orig GFTA manual
Goldman and Fristoe, 2000^92^ Instr: GFTA-2 | Statistical methods: Cronbach's coeff alpha, % agr ICR: Cronbach's alpha reported for each age group based on sex.; 1. M: alphas range from 0.85-0.96 (Mdn .94); 2. F: alphas range from 0.92-0.98 (Mdn 0.96); T-RR: % agr for c and c-clus by position (init, mdl, fin) init position, % agr ranges from 89%-100% (Mdn 98%); mdl position, % agr ranges from 79%-100% (Mdn 98%); fin position, % agr ranges from 91%-100% (Mdn 98%) InterR: % agr for each c and c-clus by position (init, mdl, f) init position, % agr ranges from 63%-100% (Mdn 93%); mdl position, % agr ranges from 73%-100% (Mdn 90%); fin position, % agr ranges from 73%-100% (Mdn 90%) IntraR: NR | Has high internal consistency, test-retest, and InterR reliability | Reliability/validity data reported only for the S-in-W subtest. No data are provided for S-in-S or Stimulability subtests
Lewis et al., 2000^72^ Instr: GFTA (orig) | Statistical Method: % agr InterR: 95% agr for GFTA transcription. | NR | Reported % agr, but not kappas

Evidence Table 60. Child Speech Disorders -- GFTA-2: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Goldman and Fristoe, 2000^92^ Instr: GFTA-2 | Statistical methods: Mn(SD), paired t test Content: 23 of 25 conson sounds generally recognized as SAE are included, as are 16 of the more commonly occurring conson-clusters included in S-in W subtest Construct:; 1. Mns (SD) show a steady decrease in the # of artic errors throughout the age range with sharp decreases in early years and gradual decline in later years; 2. After age 8, most examinees made few or no errors; 3. Mastery age for each sound/position at which 85% of children in age group correctly produce c and c-clus sounds closely match accepted patterns of deviance and to NSHSD; Concurrent: NR Divergent: NR Other: Mns(SD) raw scores compared for std sample and Canadian children. Paired t-tests indicated no sign differences for children ages 3-4 and 5-7 ys | 1. GFTA-2 has good content and construct validity; 2. Canadian comps suggest that S-in-W test is appropr for use w/ Eng-speaking Canadian children. | 1. Insuff detail provided about the 320 norm sample sites; 2. Insuff info given on the demog chars of the Canadian sample
Mullen and Whitehead, 1977^96^ Instr: GFTA (Orig) | Statistical methods: % correct, arcsin transformation to normalize distribution, ANOVA Results:; 1. Mn % correct higher for AAPS than for GFTA; 2. No subj correctly identified all GFTA stimulus pictures; 8 did with the AAPS; 3. 38/40 scored higher on AAPS than on the GFTA; 4. AAPS elicited significantly more correct initial answers than GFTA (p<0.001); 5. No diff betw normals and articulation deficient wrt correct answers (p > 0.05); 6. No group by test interaction (p>0.05) | 1. By reducing the number of stimuli, the GFTA may have more ambiguous stimuli, lead to initial errors, and longer test admin time; 2. Because normal and articulation deficient children mad same % of errors, authors of artic tests may be able to stimulus picture validity only with normal speaking children | 1. Comparison of only 2 tests; results may not be generalizable; 2. Small sample size also may prevent generalizability of results
Seymour and Seymour, 1981^93^ Instr: GFTA (orig) | Statistical methods: t tests, chi-squares, regression (R-squared); no correction for multiple comparisons Number of artic errors:; 1. Bs made sign more errors than Ws (Mn-black=6.5 vs. Mn-white 4.1 t=5.24, p<0.001; 2. Using regression, dialect predicts only 7% of variation (oth factors acct for 93%); Type of artic errors:; 1. All children produced large portion error on dental, alveolar, labial-dental place feature, and fricative manner feature; 2. Sign diffs betw Ws and Bs for place error (chi-square=18.72, p< 0.01) and manner errors (chi-square=35.71, p< 0.001). Bs made more labial, labial-dental, and stop feature errors; Ws made more palatal, affricate, and liquid errors; Patterns of Phonemic Errors:; 1. Substitution errors most common (70.6% B vs. 82.8% W -- diff came in initial position substitution; 2. More common substitution patterns in Bs: /theta/ → [f] in mdl/fin; [v] → [b] in init/mdl; and /delta w/ crossed tail/ → [d] in ini/mdl positions; 3. More common substitution patterns in Ws: init position [theta] → [f], /r/ → [w], /tf/ → [t], /theta/→ [s], /f/ → [s]; 4. Total omission errors greater for B than for W (16.5% vs. 5.5%) -- Bs' omissions were usually stop consonants | 1. Possible to develop dialectical profiles for 4 and 4yo subjs; 2. B and W children produced artic errors and phono processes consistent w/ develop norms; 3. B and W children produced same types of error, but B children produced a greater # of error types characterized as black Engl; 4. May be necessary to modify bidialectical approach used for adult B Engl speakers to incl fewer dialectical diffs when assess B children | 1. Artic tests may not capture diffs that may show in spontaneous speech; 2. Sample size small and limited to one geographical region; thus, may not be generalizable; 3. Did not report stats for differences in phonemic error patterns
Botting et al., 1997^95^ Instr: GFTA (Orig) | Statistical methods: Mann-Whitney U & % agr; corrections made for multiple comparisons Agr betw teacher ratings and GFTA:; 1. GFTA discriminated the best, w/ the difference between the scores being 39 percentiles p < .0001 (articulation) and 46 percentiles p < .0001 (phonology); 2. GFTA did not discriminate for syntax/morphology; 3. GFTA discriminated children with semantics &/or pragmatic difficulties (p < .0001); Cutoff scores that are clinically useful for classification of a certain difficulty For 5th%ile articulation threshold -- 75% agr betw teacher and GFTA For 25th%ile articulation threshold -- 76% agr betw teacher and GFTA For 25th%ile phonology -- 77% agr betw teacher and GFTA Agr much lower for other thresholds and difficulties Calculated sens/spec/ PPV/NPV (employing teacher as "gold standard"); 1. 5th%ile artic -- Sens=0.35, Spec=0.93, PPV=0.69, NPV=0.76; 2. 25th%ile artic -- Sens=0.74, Spec=0.77, PPV=0.59, NPV=0.87; 3. 25th%ile phono -- Sens=0.67, Spec=0.85, PPV=0.79, NPV=0.75; Calculated sens/spec/ PPV/NPV (employing GFTA as "gold standard"); 1. 5th%ile artic -- Sens=0.69, Spec=0.76, PPV=0.35, NPV=0.93; 2. 25th%ile artic -- Sens=0.59, Spec=0.87, PPV=0.74, NPV=0.77; 3. 25th%ile phono -- Sens=0.79, Spec=0.75, PPV=0.67, NPV=0.85 | 1. Teacher/SLP rating relates strongly with results of standardized tests; 2. 25%ile thresholds more likely to achieve concordance | 1. Teacher ratings are not "gold" standard and appear to be poor indicators of whether child has an articulation disorder. Teachers misclassified children 35% of time when children did not have articulation disorder, but were able to identify correctly a child w/o a disorder much more often.; 2. It is not reasonable to expect an articulation test to capture semantics/pragmatic disorders; 3. Correction for multiple comparison made but not presented.
Crutchley et al., 1997^95^ Instr: GFTA (orig) | Statistical methods: Mann-Whitney U, chi-squares; no correction for multiple comparisons Median %ile (IQR) on GFTA=45 (20-90.5) vs. 36 (11-67) for monolinguals. Diff not stat sign | Bilinguals tend not to have articulation problems on arrival | 1. Part of Botting95; 2. Small cohort size, results not likely generalizable.

Evidence Table 61. Child Speech Disorders -- GFTA-2: Normative Data Outcomes

Author (year) | Population to Which Standardized Population/Source Characteristics^†^ | Score Reported | Other Analyses
Goldman and Fristoe, 2000^92^ Instr: GFTA-2 | Population/Source: US Census ages 2-0 to 21-11 from CPS 3/98 Characteristics:; 1. Race/ethnicity; 2. Geographic region; 3. Sex; 4. SES (maternal educ) | Std scores, 90%/95% CI, %ile rank Test-age equivalents for M/F | NR

Evidence Table 62. Child Speech Disorders -- GFTA-2: Predictive Validity Outcomes

Author(s) (year) | Predictive Validity Results Hypotheses tested Results | Conclusions | Limitations of Study
Lewis et al., 2000^72^ Instr: GFTA (orig) | Statistical methods: multiple regression to determine predictors of school age lang, read decoding, read comprehension, & spell skills Outcome #1: Language Disorder: For children w/ lang disorder Mn (SD) GFTA=58.8 (40.2) compared to 84.3 (21.8) for child w/o disorder. Beta weight for GFTA as a predictor for language disorder=(- 0.411, p> 0.05). R-squared for model=0.599 Outcome #2: Reading Disorder:: For children w/ read disorder Mn (SD) GFTA=46.9 (44.5) compared to 84.3 (21.8) for child w/o disorder. Beta weight for GFTA as a predictor for reading disorder-(- 0.358, p < .05). R-squared for model=0.455 Outcome #3: Spelling Disorder For children w/ spell disorder Mn GFTA (SD)=52.4 (37.7) compared to 84.3 (21.8) for child w/o disorder. Beta weight for GFTA as a predictor for spelling disorder-(- 0.228, p > 0.05). Regression parameter non-significant. R-squared for model=0.332 | School age read ability predicted by presch GFTA scores | 1. No stats reported for comps of means; 2. No corrections made for multiple comparisons

Evidence Table 63. Voice Disorders -- GRBAS: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/ Duration | Quality Score (%)
DeJonckere et al., 1993^100^ Instr: GRBAS (VA scale) | 1. To select parameters on Inter-R and intra-R agr; 2. To use selected para-meters to investigate relation-ships betw para-meters & compare scale profiles among voice pathologies | Cohort | Inclusion: NR Exclusion: NR | Expt 1: Voice Sample: 12/12 Expt 2: Listeners: 6 SLP/ENT Expt 2: Voice Samples 54/54 Expt 2: Listeners: 1 SLP/1 ENT | Expt 1 Voice Sample: "clearly dissimilar pathological voice" Dx: vocal fold polyps(2), noduli vocules Reinecke's edema, chronic laryngitis, carcinoma, beginning spasmodic dysphonia, vocal fold atrophy, unilateral paralysis, functional voice disorder (2) Expt 2 Voice Sample: NR Listeners: NR | Setting: NR-phoniatric consultation Procedures:; 1. GRBAS used as VA (10-cm line). A/S scored inversely and combined (called tonus/dystonia); 2. Listeners rated 5 GRBAS parameters + 10 others; 3. All samples recorded | Qcations: NR Training provided: NR -- "trained" | Netherlands | Dates: NR Duration: Expt 1 -- "few weeks" Expt-2 -- NR | M=61.1% C=20.0%
de Krom, 1994^101^ Instr: GRBAS | 1. To estimate effect of type of voice fragments on percep of voice quality; 2. To eval InterR & IntraR of G, R, & B rating for diff voice fragments | Multifactorial w/ crossover & comp grp | Inclusion: Group 1:; 1. Pts of phoniatric dept at university hospital or known to suffer chronic v disorder; 2. Some type of audible dysphonia,; Group 2:; 1. No voice problem; 2. Considered healthy wrt voice qual; Judges: Some exp in aud eval of voice qual Exclusion: NR | Voice Samples: Group 1: Voice pts 57/57 Group 2: Normal 21/21 Judges (SLPs): 6/6 | Groups 1 & 2: F/M: NR/NR but both incl. Judges: 3-yr SLP students F/M:100%/0% | Setting: NR Procedures:; 1. GRBAS measured using 10-point scale (1="not present to 10=max present) **Results reported only for G, B, & R; 2. Speech sample included sustained /a:/ (in norm conversation), reading of short text); 3. Judges rated 1000 msec whole vowel, 200 msec vowel onset segment, 200 msec post-onset, 7-word connected speech sample; 4. All samples were audiotaped | Qcations: 3^rd^ y SLP students w/ "some exp in auditory eval" Training provided: listeners presented 7 random training stimuli from set of 78 | Netherlands | Dates: NR Duration: 4 total trials, first 3 conducted w/ min time interval of 24 hs, last trial at least 6 ws later | M=58.8% C=47.4%
DeJonckere et al., 1996^102^ Instr: GRBAS (VA scale) | 1. To eval InterR and IntraR of the GRBAS scale (VA scale); 2. To eval effect of experience on IntraR; 3. To compare perception ratings to acoustical meas (MDVP) | Cohort w/ nesting by y (1^st^ v. 3^rd^) in 2 institutes (exp & MDVP only) | Inclusion: NR Exclusion: NR | Voice Sample: 943/943 IntraR: 80/80 MDVP: 257/257 Listeners: At least 1 pair of SLP/ENT per institution | Voice Sample: M/F-345/598 M/F-36.6%/63.4% Listeners: NR At least 1 pair (SLP/ENT) per institute | Setting: 5 institutes in 3 countries Procedures:; 1. GRBAS used as VA with ref marks at 0 (no dev)-3 (severe dev); 2. Sample derived from running speech during consultation -- sustained /a:/ (200 msec), short (5-6 words) phonetically selected sentence; 3. All samples digitally recorded; 4. MDVP used to examine voice samples in 2 institutes | Qcations: ENT/SLP ("experienced") Training provided: "clear defn of parameters provided" | France, Belgium, Netherlands | Dates: NR Duration: 3 y (overall) IntraR: 2-6 ms | M=50.0% C=68.8%
De Bodt et al., 1997^99^ Instr GRBAS (4-point) | 12. 1. To determine the T-RR of SLPs' & ENTs' judgments 13. 2. To investigate the influence of exp & SLP vs. ENT | Cohort w/o comp grp | Inclusion: Judges:; 1. Normal hearing; 2. Assess voice disorders on regular basis.; Voice sample:; 1. Pts in voice clinic; 2. Complaining of dysphonia; Exclusion: NR | Voice samples: 9/9 Judges: 23/23 2,070 ratings= 15 GRBAS 9 voices 23 raters at 2 diff times | Voice Samples: Sex: M/F: 3/6 (33%/67%) Age (y): 22-65 Judges: SLP/ENT: 10/5 Exp/Inexp: 12/11 *No diff in exp betw SLPs & ENTs (Chi-Sq: p=0.28) | Setting: Voice clinic Procedures:; 1. GRBAS measured using 4-point (0-3) scale; 2. Speech sample included sustained /a/ and /i/, reading of phonetically balanced text sample (115 words); 3. All samples audiotaped.; 4. Acoustic analysis (MDVP) conducted | Qcations: SLP and ENT who assessed voice disorders on regular basis Training: Theoretical clin instruction on system & scoring procedure, training tape, trials w/ 3 voices (not in study sample) | Belgium | Dates: NR Duration: 14 ds between ratings | M=72.2% C=55.6%
Millet and Dejonckere, 1998^103^ Instr: GRBAS (VA Scale) | To compare InterR on GRBAS with selected MDVP acoustical parameters | Cohort w/o comp grp | Inclusion: NR Exclusion: NR | Voice Samples: 65/65 Listeners: 2/2 | Voice Samples: Sex: NR Age: NR Dx: functional voice disorders, benign vocal fold lesions, neurological diseases of the larynx, laryngeal cancer Listeners: "experienced phoniatricians" | Setting: Voice clinic at university hospital Procedures:; 1. GRBAS used as VA (10-cm line). A/S scored inversely and combined; 2. Samples included-sustained /a:/ (> 1sec) 2 times, 6-word phonetically selected sentence; 3. All samples digitally recorded; 4. MDVP used to examine voice samples -- used only jitter%, shimmer%, harmonic emergence in spectrum (NHR) -- derived from^102^ | Qcations: Phoniatrician Training provided: NR | Netherlands | Dates: NR Duration: NR | M=47.1% C=44.4%
Wuyts et al., 1999^104^ Instr: GRBAS | To compare the reliability of the original (3-point) GRBAS with a visual analog modification GRBAS | Controlled trial, comp grp | Inclusion: Voice Samples: varying degrees of dysphonia Judges: >1 y experience assessing voice disorders Exclusion: NR | Voice Samples: 14/14 Judges: 29/29 | Voice Samples: Sex: M/F-7/7 50%/50% Age: Range =7-65 y Comorbidities: none Judges: 25 SLP/4 ENT) | Setting: NR Procedures:; 1. GRBAS measured using visual analog scale (10-cm unmarked line); 2. Speech sample included sustained /a:/, reading of phonetically balanced speech sample (~70 words); 3. All samples videotaped | Qcations: 25 SLP, 4 ENT Training: Instruction in GRBAS use (both versions) and listening to reference voices of the original GRBAS training audiotape | Belgium | Dates: NR Duration: Scoring trials separated by 2 wks | M=72.2% C=72.2%
Langeveld et al., 2000^105^ Instr: GRBAS (VA Scale) | 1. To evaluate T-RR, InterR, & IntraR of extended GRBAS (GRBAS + aphonia, diplophonia, staccato, tremor, falsetto, vocal fry) in subjs. w/ ADSD; 2. To evaluate (indirectly) construct validity | Cohort w/o comp grp | Inclusion:; 1. All subjs. had symp of ADSD for > 1 y.; 2. No previous tx w/ botulinum toxin; Exclusion:; 1. Hx of p-tric or neurologic dis (dystonias or familial tremors) | Voice Samples: 77/77 (total) 58/58 (InterR / IntraR inexp) InterR Judges (experienced): 3/3 InterR/IntraR Judges (inexper-ienced): 8/8 | Voice Samples: Sex: M/F-16/61 20.8%/79.2% Age: M: Mn=55.5y (31-74y) F: Mn=56.2 y (19-87y) Comorbidity: none InterR Judges (experienced): (1 SLP/2 ENT) InterR/IntraR Judges (inexperienced): (8 SLP/8 ENT) | Setting: NR Procedures:; 1. Extended GRBAS measured using visual analog scale (10 cm-unmarked); 2. Spontaneous speech sample (~3 min); 3. All samples videotaped | Qcations: SLP/ENT Training: Presentation of taped reference voice samples of diff parameters for inexperienced judges | Netherlands | Dates: 1993-1997 Duration: 4 wks (IntraR) | M=66.7% C=52.9%

Evidence Table 64. Voice Disorders -- GRBAS: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
de Krom, 1994^101^ Instr: GRBAS | Statistical Method: 95% CIs for betw and w/in listeners, intraclass correlation coefficients (ICC), partition of variance into judge (InterR), voice, and repetition (IntraR) components Consistency of Ratings; 1. Low/high mean ratings differ by < 1 point for G, R, & B; 2. 95% CIs for both between- and within-listener variance displayed graphically, so it is impossible to extract specific numbers. Overall, there is less variability within-listeners than between-listeners; 3. G, B, & R had somewhat similar 95% CIs; 4. More variability in the middle of these scales (moderate severity) as opposed to the ends of the scales; 5. Combined (w/in & betw listeners) effects CIs similar to the between-listener confidence intervals, suggesting high IntraR -- graphic results do not allow verification; Rating Reliability; 1. Rating rel coefs presented for voice fragment types for G, B, & R. Rating rel coefs include listener and repetition (IntraR) variance. Coefs range from 0.79 to 0.94 -- G=0.90-0.94, B=0.88-0.93, R=0.79-0.89 B and R rel plotted as a fxn of G (vocal deviance); 2. Graphic representation shows that rel of B low for nondeviant voice but acceptable (i.e., 0.70-0.80) for deviant voices; 3. Rel of R ratings as fxn of vocal deviance -- large diffs in reliability found for least deviant voices with all 4 types of speech frags. For mildly dysphonic pts, reliability was 0.70-0.80 for all speech frags. Reliability for increasing vocal deviance ranged from 0.65(post-onset sample) to >0.9 (whole vowel) | Overall rel reached acceptable levels for all 4 speech fragments and G, R, and B No difference in rating rel for diff speech fragments G rated more reliably than B or R | 1. Listeners all F, 3rd y students in same SLP program might artificially increase betw-listener agreement; 2. Only the G, R, & B of the GRBAS were studied; 3. Not possible to distinguish InterR from IntraR; 4. Graphical presentation of results does not allow for obtaining numerical results; 5. Explanation of statistical methods is confusing
DeJonckere et al., 1993^100^ Instr: GRBAS (VA scale) | Statistical Method: ANOVA to derive interR & intraR variance Expt 1 (results estimated from Fig 1):; 1. The interR variance=~11%-12% for G, 22%-24% for R, 25%-26% for B, and <10%for A/S); 2. The intraR variance=~11%-12% for G, 15%-18% for R, 11%-12%% for B, and 22%-24% for A/S); 3. % variance do not different significantly (no stats presented); Statistical Method: Cor partial corrs for relationships betw parameters; No correction for multiple comparisons Expt 2:; 1. IntraR corr=0.70 for G, 0.63 for R, 0.59 for B, and 0.48 for A/S. "All correlations significant" -- no stats presented.; 2. Partial corr betw G &: B(0.88); R (0.63) -- sign p<0.01. Partial corr betw B &: R(-.62) -- sign p<0.01.; 3. No sign corr betw A/S and G, B or R. | 1. InterR/intraR variation low for G, R, B, and A/S.; 2. Higher interR corr is for G; 3. Overall severity of dysphonia determined by B; 4. Antagonistic relationship betw B & R; 5. No relationship between A/S and B or R | 1. No description of the types of voice samples in Expt 2; 2. A/S used as single scale; 3. Unclear whether IntraR and interR variation are generalizable; 4. Methods/results reported with insuff detail; 5. No correction for multiple comparisons
DeJonckere et al., 1996^102^ Instr: GRBAS (VA scale) | Statistical Method: Spearman's corr (rho), Cohen's kappa (K) InterR:; 1. The interR agreement (rho)=0.87 for G, 0.70 for R, 0.69 for B, and 0.65 for A/S (p<0.000 for all); 2. VA scale reduced to categorical (0-3). K= 0.51 for G, 0.46 for R, 0.43 for B, and 0.41 for A/S (p<0.00 for all) **A/S considered single parameter; 3. Sign improvement in rho w/ rater exp. Rhos for G incr from 0.71-0.88(p< 0.05), B incr from 0.63 to 0.71 (p< 0.05), R incr from 0.59 to 0.72 (p< 0.05), A/S incr from 0.46 to 0.66 (p< 0.00); IntraR: IntraR investigated by comp 2 ratings of 80 voices by "more exp" investigator Intra-r agreement (rho)=0.89 for G, 0.74 for R, 0.76 for B, and 0.68 for A/S | 1. InterR/intraR agreement fair to good. Highest values found for G; 2. InterR agreement significantly improves with training/exp | 1. Used a VA scale to score GRBAS, then converted to ordinal (methods NR) to compute kappas; 2. Low kappa values for InterR (.41-.51) suggest that there may be some problems with the GRBAS measured as VA scale; 3. A/S used as single scale; 4. No exam of training effect on InterR kappas; 5. IntraR calculated only for one rater, and only for "more exp" rater". Unclear whether IntraR would be different for "less exp" rater; 6. Kappa not reported for IntraR, but likely to be lower; 7. Methods/results reported with insuff detail
De Bodt et al., 1997^99^ Instr: GRBAS (4-point) | Statistical methods: Cohen's kappa, Wilcoxon Matched-Pairs Signed Rank Test, Wilcoxon Mann-Whitney statistics T-RR: Kappas calculated results presented by GRBAS & judge experience: G (range=0.50-0.70); R (range=0.27-0.43); B (range=0.29-0.46); A (range=0.28-0.51); S (range=0.30-0.36). For the GRBAS (range=0.40-0.45) InterR:; 1. Kappas calculated results presented by GRBAS & judge experience: G (range=0.39-0.49); R (range=0.14-0.25); B (range=0.19-0.31); A (range=0.27-0.33); S (range=0.10-0.17); ENTs (range=0.12-0.45); SLPs (range=0.12-0.46); Inexp (range=0.11-0.39); exp (range=0.17-0.40); 2. No sign diff betw exp vs. inexp judges (all p>0.05) and SLP vs ENT (all p>0.05) for GRBAS parameter | 1. Overall T-RR is moderate; InterR fair at best; 2. Prof background or exp had no effect on T-RR; 3. Exp raters had best T-RR for all but A; 4. G had best InterR and T-RR of GRBAS parameters; 5. InterR for SLP vs ENT, poor to fair | No normal voices included in samples
Millet and Dejonckere, 1998^103^ Instr: GRBAS (VA Scale) | Statistical Method: Spearman's rho InterR: Spearman's rho: 0.87 for G, 0.70 for R, 0.69 for B, and 0.65 for A/S. | 1. Fluctuations in internal(w/in listener) are limiting factor for InterR; 2. Providing standard references likely would impr InterR | Number of listeners too small to be able to conclude generalizability of the InterR
Wuyts et al., 1999^104^ Instr: GRBAS | Statistical Method: Kappa(K). VA scores transformed to ordinal ORD scores (0-3) VA 0-2.5cm=0; 2.51 cm-5.0 cm=1; 5.01-7.50=2 and 7.51-10.0=3 InterR; 1. ORD version of GRBAS K= G (0.38), R (0.23), B (0.22), A (0.27), S (0.13); 2. VA (transformed to 4-point -- original: K=G (0.27), R (0.19), B (0.18), A (0.30), S (0.12); 3. VA (transformed to 6-point): K=G (0.27), R (0.16), B (0.16), A (0.23), S (0.12) | 1. Original ordinal scale is a more reliable scoring system to be used with the GRBAS than the visual analog scoring system; 2. Diff in interR of GRBAS items better reflected by the original GRBAS | GRBAS kappa values are very poor: 4 of the 5 dimensions have a "fair" kappa value; the other has a "poor" kappa value
Langeveld et al., 2000^105^ Instr: GRBAS | Statistics: Intraclass correlations (ICC) for InterR/IntraR InterR:; 1. Exp judges: ICC=0.79 (grade)-0.97 (vocal fry); 2. Inexp judges: ICC=0.36-.77 for G(0.58), R(0.30), B(0.41), A(0.41), & S(0.52) parameters; IntraR:; 1. ICC=0.77 G, 0.36 R, 0.52 B, 0.59 A, 0.75 S; 2. Mean diff +/− SD(1^st^ to 2^nd^ obs)=G(0.1 +/− 1.3), R(0.0+/− 0.8), B(0.3 +/− 1.4), A (0.1 +/− 1.9), S (0.2 +/− 1.9) | 1. High agr among the exp judges (mean ICC= 0.91, SD=0.06, min=0.79, max=0.97).; 2. The 10 parameters (6 GRBAS + 4 ext) measure indep voice chars; 3. InterR judged to be fair-moderate | 1. Use of visual analog scoring scale rather than 4-point scale justified by unpublished paper and review article; 2. IntraR/InterR ICCs for diplophonia (ext GRBAS) may be errors; 3. ICC for InterR (exp) not reported individually for R,B,A, or S

Evidence Table 65. Voice Disorders -- GRBAS: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
DeJonckere et al., 1993^100^ Instr: GRBAS (VA scale) | Statistical Method: ANOVA Expt 2:; 1. Presents Mn score for pts with fxnal vs organic disorders (estimated from figure). G-fxnal vs. G-organic p=0.004; B-fxnal vs. B-organic p=0.001; R-fxnal vs. R-organic p=0.04; A/S-fxnal vs. A/S organic p=0.008; 2. Presents Mns betw fxnal, nodules, benign tumor, paralysis, malign tumor (must be estimated from figure). Mn scores differed for G (p=0.002), R (p=0.006), and A/S (0.001) | Voice profiles diff betw diff pathol voice group, particularly functional and organic disorders | 1. No info on distribution of dx for comparisons; 2. A/S used as single scale; 3. Results reported in figures; cannot be reliably estimated; 4. No correction for multiple comparisons
Langeveld et al., 2000^105^ | Statistics: Correlations (type not specified) Construct: B, R, A, and S parameters uncorrelated w/ each other and w/ overall grade (i.e., G parameter) -- r=−0.01=0.23) Corr betw G & S= 0.74 | G, R, B, A, and S parameters are independent parameters measuring diff aspects of voice quality | Use of visual analog scoring scale rather than 4-point scale justified by unpublished paper and review article
DeJonckere et al, 1996^102^ Instr: GRBAS (VA scale) | Statistical Method: Principal components analysis (PCA) w/ varimax rotation, Spearman's correlation (rho) Perceptual ratings using the GRBAS compared to acoustical profile using the MDVP for 257 voice samples PCA; 1. Sustained /a:/--7 clusters (3 prin comps (PCs) account for 72.2% of total var): PC1: SPI, VTI, NHR(harmonic emergence in spectrum); PC2: ATRI: amplitude tremor intensity; PC3: JITA, RAP, PPW, JITT: short term pitch perturbation; PC4: NSH, DSH: subharmonics; PC5: SPPQ, PFR, VRO, sAPQ, STD: long term frequency and amplitude modulation; PC6: DUV, NUV, SHDB, SHIM, APQ: voiceless segments (aphonic moments) and short/medium term amplitude perturbation; PC7: VAM: very long term amplitude variation; 2. Sentence -- 6 clusters (3 PCs account for 72.8% of total var) PC1: JITA, RAP, PPQ, JITT: short term pitch perturbation; PC2: VFC, PFR, STD: long term frequency modulation PC3: DUV, NUV, SHDB, SHIM, APQ: voiceless segments (aphonic moments) and short/medium term amplitude perturbation; PC4: VAM: very long term amplitude variation; PC5: SPI, VTI, NHR: harmonic emergence in spectrum; PC6: NSH, DSH: subharmonics; *Num/degree of voice breaks removed due to small sample size; Corr betw GRBAS and MDVP parameter (highest values); 1. G -- w/ shimmer% (rho=0.73), w/ noise to harmonics ratio (rho=0.64); p< 0.001 for both; 2. B -- w/ jitter% (rho=0.45), w/ shimmer% (rho=0.63); p< 0.001 for both; 3. R -- w/ jitter% (rho=0.68), w/ shimmer% (rho=0.55); p< 0.001 for both; 4. A/S -- w/ jitter% (rho=0.45), w/ shimmer% (rho=0.46); p< 0.001 for both | Parameters of MDVP can be grouped into a few clusters with more/less close corr with perceptual measures (GRBAS) : (1) short term Fo perturbations (R), (2) short term amplitude perturbation (B); (3) noise-to-harmonics ratio (G), long term Fo and amplitude variations (intonation, accentuation, lack of stability, (4) subharmonics (diplophonia) (5) tremor, quivering) | 1. Methods/results reported with insuff detail
Millet and Dejonckere, 1998^103^ Instr: GRBAS (VA Scale) | Statistical Method: Spearman's Rho, no correction made for multiple comparisons *Inter-rater diffs in GRBAS values converted to absolute value; 1. G: no sign corr betw any acoustic parameter and inter-rater diff; 2. R: corr betw diff score & shimmer% (rho=0.49, p<0.001); 3. B: corr betw diff score & jitter % (rho=0.37, p<0.01); 4. A/S: corr betw diff score & NHR (rho=0.27, p<0.05) | 1. InterR is similar to those observed for conversational speech102; 2. Inter-rater diffs for G not influenced by acoustical parameters; 3. In pathological voices, shimmer% disturbs rating of R, and jitter% disturbs rating of B component | 1. No correction made for multiple comparisons; 2. Extreme values rejected w/o reason (Fig 1); 3. Number of listeners is too small to be able to conclude generalizability of results
Wuyts et al., 2000^104^ Instr: GRBAS | Statistical Method: Spearman's correlations, linear regression modeling Criterion Validity:; 1. Correlation coefficient (betw VA and ORD scores): G=0.969, R=0.959, B=0.928, A=0.961, S=0.961; 2. Regression analysis used to determine whether entire range of values used in VA scale. T-tests used to compare regression coefficients to critical slope value (plot of ORD on the horizontal axis and VA on the vertical axis a bisector slope parameter -- 3.33). Coefficients < 3.33 indicate that scorers are tending to put dashes closer to the middle of the line (VA) than towards the ends; 3. Slope parameters: G=3.06, R=2.64, B=3.02, A=3.17, S=2.83. R, B, and S slopes were all significantly lower than 3.33, indicating the tendency of scores to cluster in the middle of the VA line | Tendency for raters to score in the middle of the VA line

Evidence Table 66. Voice Disorders -- MDVP: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/ Duration | Quality Score (%)
Deliyski DD et al. (Study 1), 1999^107^ Deliyski DD (Study 2), 1999^110^ Instr: MDVP-Windows 95/98 | Study 1: To establish inter-system (concurrent) validity betw the (DOS and /Windows 95/95 Study 2: To define normative values for the acoustic voice parameters | Study 1: Cohort w/ comp grp Study 2: Cohort w/ comp grp | Inclusion: (Study 1); 1. Voice -- subjs w/ voice disorders; 2. Controls -- normal adults in good health; (Study 2); 1. Voice -- subjs w/ laryngeal disease; 2. Controls -- NR; Exclusion: (Study 1); 1. Voice subjs -- NR; 2. Controls -- no hx of neuro, speech or hearing disorder; (Study 2) -- NR | Study 1: Voice pts: 42/42 Control: 42/42 Study 2: Voice pts: 53/53 Control: 15/15 | Study 1: Age: NR Sex:(M/F): 21/21 (voice) 21/21 (control) Dx (voice): mass lesions, vocal fold paralysis, spasmodic dysphonia, tracheoesophageal speech Study 2 Age: NR Sex:(M/F): 25/28 (voice) 7/8 (controls) Dx (voice): laryngeal cancer, benign neoplasms, chronic laryngitis, functional dysphonia, paralysis of a recurrent nerve | Study Setting: NR Study 1:; 1. Subjs produced sustained /a/ for 3 seconds. Data stored directly into CSL program.; 2. Voice sample analyzed using both DOS and Windows 95/98 MDVP versions; Study 2: NR Procedures: NR | Qcations: NR Training provided: NR | NR | Dates: NR Duration: NR | M=66.7% C=27.6%
DeJonckere et al., 1996^102^ Instr: MDVP | To compare acoustical measures (MDVP) to perceptional ratings (GRBAS VA scale) | Cohort w/ nesting by y (1^st^ v. 3^rd^) | Inclusion: NR Exclusion: NR | Voice Sample: 257/257 Listeners (GRBAS): At least 1 pair of SLP/ENT per institution | Voice Sample: M/F-NR Listeners: NR At least 1 pair (SLP/ENT) per institute | Setting: 5 institutes in 3 countries Procedures:; 1. MDVP used to examine voice samples. Sampling rate 50,000 samples per sec; 2. GRBAS used as VA with ref marks at 0 (no dev)-3 (severe dev); 3. Sample derived from running speech during consultation -- sustained /a:/ (200 msec), short (5-6 words) phonetically selected sentence; 4. All samples were digitally recorded | Qcations: ENT/SLP ("experienced") Training provided: "clear defn of GRBAS parameters provided" | Belgium, Netherlands | Dates: NR Duration: 3 y | M=43.8% C=57.7%
van As et al., 1998^109^ Instr: MDVP | To investigate the relationship betw voice quality & various acoustical parameters | Prosp cohort w/ comp grp | Inclusion: (Voice):; 1. Had laryngectomy 1.5-8 y before study.; 2. Used Provox^®^ voice prosthesis.; (Control): No known voice defect Exclusion: NR | Voice: 21/21 Control: 20/20 Judges: 20/20 | Subjects: Voice: Sex:(M/F): 21/0 Age: Mn(range): 62 y (44-79 y) Controls: Sex:(M/F): 20/0 Age Mn(range): 65 (51-81) Judges: Sex: M/F: 10/10 | Setting: NR Procedures:; 1. Subjs produce sustained /a/ and counted for 3 sec w/ data stored for CSL/MDVP acoustical analysis; 2. Judges rated Each /a/ sample presented 3x; judges rated samples on 8 voice quality scales (non-GRBAS) | Qcations: Untrained indivs unfamiliar w/ transesophageal speech. Training provided: NR | Netherlands | Dates: NR Duration: NR | M=70.6% C=52.2%
Kent et al., 1999^108^ Instr: MDVP | To assess the reliability & suitability of MDVP voice disorders occurring dysarthria. | Coh w/o comp grp | Inclusion: Dysarthria Exclusion: NR | 32/32 | Subjects: Age (y): 31-82 Sex (M/F): 20/12 Dx: CVA: 14 Parkinson's Dis: 10 Multiple Sclerosis: 2 Cerebellar Dis: 2 Tumor: 1 Closed Head Inj: 1 Unk: 2 | Setting: NR Procedures:; 1. 2 trials of prolonged vowel [a]; 2. Trial 1 at beginning of session, trial 2 towards end; 3. A 3 s mid-section of sample analyzed | Qcations: N/A Training provided: N/A | United States | Dates: NR Duration: 1 session | M=70.0% C=50.0%

Evidence Table 67. Voice Disorders -- MDVP: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Deliyski DD et al. (Study 1), 1999^107^ Deliyski DD (Study 2), 1999^110^ Instr: MDVP-Windows 95/98 | Statistical Procedures (Study 1): Corr coefficients, correspondence graphs Inter-System Rel:; 1. High corr (> 0.99) betw the 2 systems for all acoustic parameters; 2. Exact correspondence or only minor discrepancies to 3rd digit after decimal place for 29 of 33 parameters; 3. Observed diffs in tremor parameters (Fftr & Fatr) (corrs>0.996) due to diff modulation components due to higher precision of MDVP-Windows, which made correct decision in all cases.; 4. ATRI (corr=0.990) influenced by Fatr due to faster attenuation of ATRI peaks; discrepancies due to diffs in Fatr for specific signals. FTRI values not similarly influenced; 5. Diffs in VTI measures (corr=0.992) due to higher precision of spectral representation of MDVP-Windows version | 1. MDVP-Windows and MDVP-DOS results demonstrate high degree of consistency; 2. MDVP-Windows results can be directly comp to MDVP-DOS results; 3. Upgrading to MDVP-Windows should not result in acoustic measurement diffs | NR
Kent, 1999^108^ Instr: MDVP | IntraR(repeated analysis of same sample): Statistical methods: % diff; 1. System able to compute analyses for all voice samples; 2. Replicate analyses were virtually identical for all but 1 voice; degree of voicelessness (DUV) exhibited errors of up to 2.1%. Same error occurred for other signal captures for this voice; IntraR (analysis of diff samples): Statistical methods: Absolute Mn discrepancy (AMD); 1. AMD=0 (length of anal sample, voice turbulence index)-8.64 (absolute jitter), suggesting highly similar results; TRR: Statistical methods: Absolute Mn discrepancy (AMD); 1. AMD=0(length of anal sample)-51.39 (absolute jitter); Likelihood of Abnormality across Parameters:; 1. Fundamental frequency variation(vFo), peak-amplitude variation (vAm), & smoothed amplitude perturbation quotient(sAPQ) had greatest frequency of discrepancy; 2. Noise to harmonics (NHR), voice turbulence index (VTI), degree of voice breaks (DVB) had lowest frequency of abnormality | 1. Repeatability of analysis is very good, w/ exception of DUV parameter; 2. Analysis results highly similar for 2 diff edits from the same samples; 3. Trial-to-trial diffs may reflect actual patient variability or problems with the MDVP system; 4. MDVP is an effective tool for analyzing voice dysfxn in neurogenic speech disorders, if high-quality recordings of sustained vowels are available | By author: NR By reviewer: 1. Small sample size 14. 2. Rudimentary statistical procedures

Evidence Table 68. Voice Disorders -- MDVP: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Deliyski DD et al. (Study 1) 1999^107^ Deliyski DD (Study 2) 1999^110^ Instr: MDVP-Windows 95/98 | Statistical Method: Correlations (type not specified) Concurrent: High corrs (all > 0.99) betw the 2 systems for all parameters | Windows and DOS versions demonstrate a high level of consistency. | NR
van As et al., 1998^109^ Instr: MDVP | Concurrent: Statistical methods: t- & Mann-Whitney tests; 1. Sign diffuse on all perceptual quality ratings betw voice & cntl grps (p-values NR); 2. No diff in perceptual ratings based on stoma type Inclusion, prosthesis size, time since surgery, & age; 3. Voice & cntl grps sign diff (p<0.05) on all MDVP params except Mn fundamental freq; 4. MDVP parameters sensitive (p<0.05) to: age (jitter) & type of stoma occlusion (shimmer); Construct: Statistical methods: Factor Analysis w/ varimax rotation, Pearson correlation coefficients; 1. 5 factors acct for 82.3% of the tot var; 2. MDVP parameters loaded on factors 1-3: Factor1 incl jitter, shimmer, and noise params, Factor 2 incl fundamental frequency params, Factor 3 included tremor, phonatory range, & amplitude variation params; Corr betw MDVP & Perceptual Ratings:; 1. Corrs=−0.41 to −0.73 (deviant voice=higher MDVP score); 2. MDP fundamental frequency & params NS corrs w/ perceptual ratings | MDVP is "suitable for rapid and reliable acoustical analysis of the TE voice." | By author: NR By Reviewer:; 1. Small sample size overall, especially within subgroups (i.e. young vs. old; follow-up duration; etc.); 2. No descrip or val data for perceptual scales; 3. Statistical results described but stats/p-values missing; 4. Questionable use of varimax rotation in factor analysis given large corrs betw MDVP params & perceptual ratings
DeJonckere et al., 1996^102^ Instr: MDVP | Statistical Method: Principal components analysis (PCA) w/ varimax rotation, Spearman's correlation (rho) Acoustical profile using the MDVP compared to perceptual ratings using the GRBAS for 257 voice samples PCA:; 1. Sustained /a:/ -- 7 clusters (3 prin comps (PCs) account for 72.2% of total var) PC1: SPI, VTI, NHR(harmonic emergence in spectrum); PC2: ATRI: amplitude tremor intensity; PC3: JITA, RAP, PPW, JITT: short term pitch perturbation; PC4: NSH, DSH: subharmonics; PC5: SPPQ, PFR, VRO, sAPQ, STD: long term frequency and amplitude modulation; PC6: DUV, NUV, SHDB, SHIM, APQ: voiceless segments (aphonic moments) and short/medium term amplitude perturbation; PC7: VAM: very long term amplitude variation; 2. Sentence -- 6 clusters (3 PCs account for 72.8% of total var) PC1: JITA, RAP, PPQ, JITT: short term pitch perturbation; PC2: VFC, PFR, STD: long term frequency modulation PC3: DUV, NUV, SHDB, SHIM, APQ: voiceless segments (aphonic moments) and short/medium term amplitude perturbation; PC4: VAM: very long term amplitude variation; PC5: SPI, VTI, NHR: harmonic emergence in;spectrum PC6: NSH, DSH: subharmonics *Num/degree of voice breaks removed due to small sample size; Corr betw GRBAS and MDVP parameter (highest values); 1. G--w/ shimmer% (rho=0.73), w/ noise to harmonics ratio (rho=0.64); p< 0.001 for both; 2. B--w/ jitter% (rho=0.45), w/ shimmer% (rho=0.63); p< 0.001 for both; 3. R--w/ jitter% (rho=0.68), w/ shimmer% (rho=0.55); p< 0.001 for both; 4. A/S --w/ jitter% (rho=0.45), w/ shimmer% (rho=0.46); p< 0.001 for both | Parameters of MDVP can be grouped into a few clusters with more/less close corr with perceptual measures (GRBAS) :; 1. short term Fo perturbations (R);; 2. short term amplitude perturbation (B);; 3. noise-to-harmonics ratio (G), long term Fo and amplitude variations (intonation, accentuation, lack of stability;; 4. subharmonics (diplophonia);; 5. tremor, quivering) | 1. No info given about range of voice disorders; 2. Methods/results reported with insuff detail. Unable to judge rigor of PCA; 3. InterR (kappa=.41-.51) and IntraR (kappas NR) of GRBAS low, suggesting GRBAS may not be reliable measure. Thus, use of GRBAS to validate MDVP may not be appropriate

Evidence Table 69. Voice Disorders -- MDVP: Normative Data Outcomes

Author (year) | Population to Which Standardized Population/Source Characteristics^†^ | Score Reported | Other Analyses
Deliyski DD et al. (Study 1), 1999^107^ Deliyski DD (Study 2), 1999^110^ Instr: MDVP-Windows 95/98 | Population Source: Study 1: N/A Study 2: Normative values may depend upon the individuals included in the study. They may be generalizable only to individuals similar to those tested in the study Characteristics: NR | Depends on acoustical parameter tested. | NR

Evidence Table 70. Voice Disorders -- VHI: Research Design Characteristics

Author (year) | Study Objective | Study Design | Subject Inclusion/Exclusion Characteristics | Sample Size Initial/End | Demographic Characteristics | Study Setting/Procedures | Qualifications/Training of Examiners | Country | Date(s) of Study/ Duration | Quality Score (%)
Jacobsen et al., 1997^26^ Instr: VHI | To develop a voice disability/handicap inventory and to test its reliability (ICR & T-RR) and validity (content, construct, concurrent) | Controlled trials w/o comp grp | Inclusion: Consecutive patients to clinic Exclusion:; 1. ICR = NR; 2. T-RR subjects did not receive tx betw administrations | ICR: 65 / 65 T-RR/Validity: 65 / 63 | ICR: Sex: M/F-25 / 40 M/F-38% / 62% Age (y): Mn(SD): 52.3 (16.3) Dx: Mass lesions 21 (32%) Neurogenic17(26%) Laryngectomy 17(26%) Musculoskeletal tension 5(8%) Inflammatory 3(5%) Atypical 2(3%) T-RR/Validity: Sex: M/F-25/38 M/F-40%/60% Age (y): Mn(SD): 49 (18) Dx: similar to ICR | Setting: Voice clinic at major hospital Procedures: ICR:; 1. Initial pool of 85 items gather from case hx interviews. Items grouped into 3 content areas: functional (25 items), emotional (31 items), physical (29 items); 2. Items scored 0 (never) to 4 (always). Items reduced from 85 to 30 based on item total corrs; T-RR: 30-item VHI administered on 2 occasions Validity: Administered self-rating of severity of voice handicap on 0 (normal) to 3(severe) | Qcations: None, subj self-report Training provided: N/A | United States | Dates: NR Duration: T-RR 6-27 d (Mn=29.3, SD-29.3) | M=81.8% C=52.0%
Benninger et al., 1998^25^ Instr: VHI | 1. To eval relationship betw VHI (total & subscales) & SF-36 domains; 2. To compare SF-36 score of voice subjs to US normals and subjs w/ oth chronic diseases | Controlled trials w/o comp grp | Inclusion: Consecutive patients to clinic Exclusion: NR | 260/260 | Sex: M/F-35.5%/64.5% Age (y): Mn: 50.3 y Range: 18-90 Dx: Neurogenic 3 (1%) Spasmodic dysphonia 11(4%) Paralysis 20 (8%) Functional 12 (5%) Masses 60 (23%) Leukoplakia 10 (4%) Cancer 5 (19%) Edema 32 (12%) Misc 10 (4%) | Setting: Voice clinic at major hospital Procedures:; 1. Subjs completed VHI and SF-36 at initial evaluation; 2. SF-36 scores transformed to 0(worst) to 100(best); 3. VHI scoring reversed and scored from 1 (never) to 5 (always). Total score 30 (severely affected) to 150(unaffected). Subscales also tabulated | Qcations: None, subj self-report Training provided: N/A | United States | Dates: NR Duration: N/A | M=73.3% C=50.0%

Evidence Table 71. Voice Disorders -- VHI: Reliability Outcomes

Author(s) (year) | Reliability Results | Conclusions | Limitations of Study
Jacobson et al., 1997^26^ Instr: VHI | Statistical Methods (ICR): Cronbach's coeff alpha, item-total corrs used to eliminate items (if < 0.60 and low face validity) ICR:; 1. Item-total corr (85-items) range= 0.17 to 0.86 and Cronbach's alpha=0.97; 2. 28 items with r < 0.60 were deleted from the VHI; 15 add'l removed because of sex differences, 16 removed b/c they were uninformative for at least 50% of the sample, or redundant; 3. Subscale corrs for 30-item VHI range 0.70 to 0.79. Each subscale correlated with the total score, these corr range 0.88 to 0.93.; 4. Cronbach's alpha (30-item)=0.95 vs.0.97 for 85-item scale; Statistical Methods (T-RR): Pearson's corrs, 95% CI, Cronbach's coefficient alpha T-RR; 1. Total scale corr=0.92; subscale corrs (functional=0.84, emotional=0.92, physical=0.86); 2. Diff in score (over time) > 18 points indicative of change above and beyond the variability of the VHI | VHI demonstrate strong ICR and T-RR2 | The researchers suggest that mention that a change in total score of at least 18 is required before you can believe with any certainty that it is due to a change in the subject's status and not variability of the measure. Table 4 (page 69) shows a smaller than 18-point difference between the mean total score of self-rated "moderate" and "severe" subjects. This indicates that the VHI would not be able to reliably detect a change in patient status from severe to moderate or vice versa. This is also true of a change of patient status from moderate to mild or vice versa

Evidence Table 72. Voice Disorders -- VHI: Validity Outcomes

Author(s) (year) | Validity Results | Conclusions | Limitations of Study
Jacobson et al., 1997^26^ Instr: VHI | Statistical methods: Corr, Mn, SD Construct: Corrs betw subscales=0.70-0.79 Corr betw total score and subscale=0.88-0.93. Concurrent:; 1. Corr betw total score and self-rating of severity=0.60; 2. Mns & SDs reported for total and subscale for severity group: mild=33.69 (5.60), moderate=44.37 (3.88), and severe=61.39 (4.21) | 1. Moderately strong subscale corrs suggest that the three subtests measure parts of the same overall construct; 2. High subscale-total corr indicate that each subtest is contributing to the overall measure of self-rated voice disorder severity | 1. Relatively low corr between self-rating of voice disorder severity and the VHI calls into question how accurately measuring the construct they intend to measure; 2. Evidence of "criterion tool's" validity and reliability not provided
Benninger et al., 1998^25^ Instr: VHI | Statistical methods: Spearman's corr, Student's t-test to compare SF-36 scores to US norms. Corrections for multiple comparisons not made. Concurrent Criterion:; 1. Highest corrs betw the SF-36 domains and the VHI was between the social function domain of the SF-36 and the VHI total score and the three subscales (r=0.51, p<0.0001); 2. Significant corr betw SF-36 mental health (p<0.01) and role functioning due to emotional problems (p<0.02) and the three subscales and total score; 3. Role functioning due to physical functioning score corr with the VHI total score and physical and functional subscales (p<0.05); 4. SF-36 vitality, general health perceptions, physical functioning, and bodily pain domains did not correlate significantly with any of the VHI scores; SF-36 of voice pts vs. US normals and pts w/ chronic disease:; 1. Dysphonia subjs had sign lower scores for physical functioning, role functioning-physical limitations, vitality, social functioning (p<0.001), mental health (p<0.04), and role functioning--emotional limitation (P<0.05) than normals; 2. Dysphonia subjs had sign lower scores for physical functioning (p<0.001) and role functioning-emotional limitation (P<0.006) than chronic sinusitis subjs; 3. Dysphonia subjs had sign lower scores for social functioning (p<0.001) compared to angina subjs, lower score for social functioning (p<0.001) and mental health (p<0.05) compared with back pain & sciatica subjs; SF-36 values of selected dysphonia pts Pts with paralysis, edema, and masses were compared.; 1. Best scores achieved by subjs with masses, worst for paralysis subjs; 2. Paralysis subjs has sign lower score for physical functioning (p<0.0004), role functioning--physical limitations (p<0.006), general health perceptions (p<0.03) than subjs w/ masses; 3. Edema subjs has sign lower score for physical functioning (p<0.02), role functioning -- physical limitations (p<0.05), general health perceptions (p<0.04) than subjs w/ masses | 1. B/c subjs w/ voice disorders do not usually have significant changes in physical symptoms, would not expect high corrs betw VHI and physical dimensions of SF-36; 2. Sign differences in perceptions of QoL betw subj w/ and w/o dysphonia (see Limitation 4); 3. QoL impact of dysphonia substantial even when compared to other chronic diseases | 1. Not all subjs completed both VHI and SF-36 in article; 2. Dx listed in Table 2 do not account for all 260 subjs; 3. Authors indicated that SF-36 does not have total score, so that they could not make an overall comparison. However, authors do not compare their subscales to either the SF-36 physical or psychosocial functioning scores; 4. Did not correct for multiple comparisons for corrs or t tests. Some/many results reported as significant may be due to chance alone