# Glossary for Evidence Tables

## Glossary of Abbreviations Other than the Names of Instruments

Abbreviation | Full Name
% agr | percent agreement
% ile | percentile
AA | African American
acct(s) | account(s)
AC | auditory comprehension (PLS only)
ADHD | attention deficit/hyperactivity disorder
ADL | Activities of Daily Living
admin | administered
ADSD | Abductor Spasmodic Dysphonia
addl | additional
agr | agreement
alpha | Cronbach's coefficient alpha
Amer | American
analy | analysis, analytic
ANOVA | analysis of variance
artic | articulation
As | Asian
assess | assessment
assoc | association
ASHA | American Speech-Language Hearing Association
AQ | Aphasia Quotient (WAB)
b/c | because
betw | between
C | clinician's rating for quality score
CI | confidence interval
class | classification
clin | clinical
cm | centimeter
cntl | control
coeff(s) | coefficients
coh | cohort
comp | comparison
corr(s) | correlation(s)
CPS | Current Population Survey
CQ | Cortical Quotient (WAB)
CVA | Cerebral vascular accident
d(s) | day(s)
decr | decreasing/decreases
defn | definition
Dept | department
diff(s) | difference(s)/different
dis | disorder/disease
dx | diagnosis
EC | Expressive Communication (PLS only)
educ | education/educational
Engl | English
ENT | otolaryngologist (ear nose throat specialist)
eval | evaluation
exp | experienced
express | expressive
expt | experiment, experimental
F | female
fa | factor analysis
fin | final
frag(s) | fragment(s)
fxn | function
grp(s) | group(s)
h(s) | hour(s)
hx | history
IADL | Instrumental activities of daily living
ICC | Intraclass correlation
ICR | Internal consistency reliability
ident | identification
impair | impairment
improv | improvement
incl | including
incr | increases/increasing
inexp | inexperienced
info | information
init | initial
inj | injury
instr(s) | instrument(s)
insuff | insufficient
int'l | international
InterR | inter-rater reliability
IntraR | intra-rater reliability
kappa | Cohen's kappa statistic
K-R stat | Kuder-Richardson statistic
lang | language
LD | learning disabled
learn disability | learning disability
LH | left hemisphere
LQ | Language Quotient (WAB)
M (quality score) | methodologist's ranking for Quality Score
M | male
m(s) | month(s)
max | maximum
mdl | middle
mdn | median
ment retard | mentally retarded/mental retardation
min | minimum
Mn | mean
msec | milliseconds
NA | not applicable
NE | New England
neg | negative
neuro | neurological/neurologically
non-AA | non-African American
non-As | non-Asian
norm(s) | normative(s)
NPV | negative predictive value
NR | not reported
NS | nonsignificant
orig | original
p-tic | pediatric
PC | principal components
PCA | principal components analysis
pgm | program
phono | phonological
phys | physical
popn | population
pos | positive
PPV | positive predictive value
pred | predictor
presch | preschool
prob | probability
propn | proportion
prosp | prospective
pts | patients
qcations | qualifications
RCT | randomized controlled trial
recept | receptive
ref | reference
rehab | rehabilitation
rel | reliability
RH | right hemisphere
SD | standard deviation
sec | seconds
SEM | standard error of the mean
sens | sensitivity
sig | significant
SL | speech language
SLD | speech language disorder
SLP | speech language pathologist
sp | speech
Span | Spanish
spec | specificity
stat(s) | statistically/statistics
std | standardization
stdized | standardized
subj(s) | subject(s)
suff | sufficient
surg | surgery
symp | symptoms
T-RR | test-retest reliability
tx | treatment
undstd | understand/understanding
unk | unknown
untx | untreated
VA | voice analog
VA | verbal ability (PLS only)
VAS | Visual Analog Scale
w/ | with
w/n | within
w/o | without
w(s) | week(s)
wrt | with respect to
y | year
y(s)o | year(s) old

## Instrument Abbreviations and Full Names

Abbreviation | Full Name
AAPS | Arizona Articulation Proficiency Scale
AIDS | Assessment of Intelligibility in Dysarthric Speech
BDAE | Boston Diagnostic Aphasia Examination
BLT-2 | Bankson Language Test, Second Edition
CELF | Clinical Evaluation of Language Fundamentals
CCSA | Comprehensive Scales of Student Abilities
DAS | Differential Abilities Scales
DEB | Dysarthria Examination Battery
GFTA | Goldman-Fristoe Test of Articulation
GRBAS | Grade/Rough/Breath/Aesthenic/Strain
KTEA | Kaufman Test of Educational Achievement.
MDVP | Multi-Dimensional Voice Program
NCCEA | Neurosensory Center Comprehensive Examination of Aphasia
PICA | Porch Index of Communicative Ability
PLS | Preschool Language Scale
PPVT-R | Peabody Picture Vocabulary Test-Revised Edition.
RCPM | Raven's Coloured Progressive Matrices
SF-36 | Medical Outcomes Study, Short Form-36
SSI | Stuttering Severity Index
TELD | Test of Early Language Development
TOAL-3 | Test of Adolescent and Adult Language, Third Edition
TOLD | Test of Language Development
TONI | Test of Nonverbal Intelligence
TOPL | Test of Pragmatic Language
TOWL-2 | Test of Written Language, Second Edition
TWS-3 | Test of Written Spelling, Third Edition
VHI | Voice Handicap Index
WAB | Western Aphasia Battery
WIAT | Wechsler Individual Achievement Test
WISC-III | Wechsler Intelligence Scale for Children, Third Edition.
WPPIS-R | Wechsler Preschool and Primary Intelligence Scale, Revised
WRMT-R | Woodcock Reading Mastery Tests, Revised