# References

1 Disability Evaluation Under Social Security. SSA Publication No. 64-039, Baltimore, Md: Social Security Administration; 1998.
2 Strategic plan: Plain language version. (no date); accessed August 8, 2001. Web Page. http://www.nidcd.nih.gov/about/director/nsrp.htm.
3 ASHA Factsheets. accessed June 1, 2000. Web Page. Available at: http://www.asha.org/marketing/bhs_factsheets.htm.
4 Ruben RJ. Redefining the survivial of the fittest: communication disorders in the 21st century. Laryngoscope. 2000;110:241-245. [pmid: 10680923].
5 Gierut JA. Treatment efficacy: Functional phonological disorders in children. J Speech Lang Hear Res. 1998;41:S85-S100. [pmid: 9493748].
6 Conture EG. Treatment efficacy: Stuttering. J Speech Hear Res. 1996;39:S18-S26. [pmid: 8898263].
7 Ramig LO, Verdolini K. Treatment efficacy: Voice disorders. J Speech Hear Lang Res. 1998;41:S101-S116.
8 Tallal P, Ross R, Curtiss S. Unexpected sex-ratios in families of language/learning-impared children. Neuropsychologia. 1989;27:987-998. [pmid: 2771037].
9 Tomblin JB. Familial concentration of developmental language impairment. J Speech Hear Disord. 1989;54:287-295. [pmid: 2468827].
10 Felsenfeld S, Plomin R. Epidemiological and offspring analyses of developmental speech disorders using data from the Colorado Adoption Project. J Speech Lang Hear Res. 1997;40:778-791. [pmid: 9263943].
11 Tomblin JB, Records NL, Buckwalter P, Zhang X, Smith E, O'Brien M. Prevalence of specific language impairment in kindergarten children. J Speech Lang Hear Res. 1997;40:1245-1260. [pmid: 9430746].
12 Gibbs DP, Cooper EB. Prevalence of communication disorders in students with learning disabilities. J Learning Disabilities. 1989;22:60-63.
13 Cohen NJ, Vallance DD, Barwick M, et al. The interface between ADHD and language impairment: An examination of language, achievement and cognitive processing. J Child Psychol Psychiatry Allied Disciplines. 2000;41:353-362.
14 Giddan JJ, Milling L. Comorbidity of psychiatric and communication disorders in children. Child Adolesc Psychiatr Clin North Am. 1999;8:19-36.
15 Tirosh E, Cohen A. Language deficit with attention-deficit disorder: A prevalent comorbidity. J Child Neurol. 1998;13:493-7. [pmid: 9796755].
16 Cohen NJ, Davine M, Horodezky N, Lipsett L, et al. Unsuspected language impairment in psychiatrically disturbed children: Prevalence and language and behavioral characteristics. J Am Acad Child Adolesc Psychiatr. 1993;32:595-603.
17 Skenes LL, McCauley RJ. Psychometric review of nine aphasia tests. J Commun Disord. 1985;18:461-474. [pmid: 4078036].
18 Kilmon CA, Barber N, Chapman K. Instruments for the screening of speech/language development in children. J Pediatr Health Care. 1991;5:61-70. [pmid: 2005543].
19 Engen E, Engen T. Rhode Island Test of Language Structure Manual. Baltimore, Md: University Park Press; 1983.
20 Westby C. Multicultural issues in speech and language assessment. In: Tomblin JD, Morris HL, Spriesterbach DC, eds. Diagnosis in Speech-Language Pathology. 2nd ed. San Diego, Calif: Singular. 2000:35-62.
21 Johnson W, Darley F, Spriestersbach D. Diagnostic Methods in Speech Pathology. New York, NY: Harper & Row; 1978.
22 ICID H-2: International Classification of Functioning, Disability and Health. 2001. accessed October 1, 1910. Web Page. Available at: http://www.who.int/icidh/. [pmcid: 369639].
23 Yorkston K, Beukelman D. The Assessment of Intelligibility of Dysarthric Speech. Austin, Tex: Pro-Ed; 1984.
24 Frattali CM, Thompson CK, Holland AL, Wohl CB, Ferketic MM. The American Speech-Language-Hearing Association Functional Assessment of Communication Skills for Adults (ASHA FACS). Rockville, Md: ASHA; 1995.
25 Benninger MS, Ahuja AS, Gardner G, Grywalski C. Assessing outcomes for dysphonic patients. J Voice. 1998;12:540-550. [pmid: 9988041].
26 Jacobson BH, Johnson A, Grywalski C, et al. The Voice Handicap Index (VHI): development and validation. Am J Speech-Lang Pathol. 1997;6:66-70.
27 Harris LG, Shelton IS. Desk Reference of Assessment Instruments in Speech and Language (Revised). San Antonio, Tex: Communication Skill Builders; 1998.
28 Standards for Educational and Psychological Testing. Washington, DC: 1999.
29 McCauley RJ, Swisher L. Psychometric review of language and articulation tests for preschool children. J Speech Hear Disord. 1984;49:34-42. [pmid: 6700200].
30 Lohr KN, Aaronson NK, Burnam MA, Patrick DL, Perrin EB, Roberts JS. Evaluating quality-of-life and health status instruments: Development of Scientific Review Criteria. Clin Ther. 1996;18:979-991. [pmid: 8930436].
31 Anastasi A. Psychological Testing. 6th ed. New York, NY: MacMillan Publishing Co.; 1988.
32 Nunnally JC, Bernstein IH. Psychometric Theory. 3rd ed. New York, NY: McGraw-Hill, Inc.; 1994.
33 Cronbach LJ. Essentials of Psychological Testing. 5th ed. New York, NY: Harper Collins Publishers, Inc.; 1990.
34 Lohr KN, Carey TS. Assessing 'best evidence': issues in grading the quality of studies for systematic reviews. Joint Commission J Qual Improvement. 1999;25:470-479.
35 Guide to Clinical Preventive Services. 2nd ed. Alexandria, Va: International Medical Publishing; 1996.
36 Cohen J. A coefficient of agreement for nominal scales. Educ Psychol Meas. 1960;20:37-46.
37 Carmines EG, Zeller RA. Reliability and Validity Assessment. Beverly Hills, Calif: Sage; 1979.
38 Domino G. Psychological Testing. An Introduction. Upper Saddle River, NJ: Prentice Hall; 2000.
39 Kuder GF, Richardson MW. The theory of estimation of test reliability. Psychometrika. 1937;2.
40 Landis JR, Koch GG. The measurement of observer agreement for categorical data. Biometrics. 1977;33:159-174. [pmid: 843571].
41 Halmstadter GG. Principles of Psychological Measurement. New York, NY: Appleton-Century-Crofts, Inc.; 1964.
42 Cohen J. Weighted kappa: Nominal scale agreement with provision for scaled disagreement or partial credit. Psychol Bull. 1968;70.
43 Goodglass H, Kaplan E. The Assessment of Aphasia and Related Disorders. Media, Pa: Williams and Wilkins; 1983.
44 Crary MA, Wertz RT, Deal JL. Classifying aphasias: cluster analysis of Western Aphasia Battery and Boston Diagnostic Aphasia Examination results. Aphasiology. 1992;6:29-36.
45 Rosselli M, Ardila A, Florez A, Castro C. Normative data on the Boston Diagnostic Aphasia Examination in a Spanish-speaking population. J Clin Exp Neuropsychol. 1990;12:313-322. [pmid: 1692843].
46 Porch B. Porch Index of Communicative Ability. Chicago, Ill: Riverside Publishing Company; 1967.
47 Clark C, Crockett D, Klonoff H. Factor analysis of the Porch Index of Communication Ability. Brain Lang. 1979;7:1-7.
48 Lendrem W, Lincoln NB. Spontaneous recovery of language in patients with aphasia between 4 and 34 weeks after stroke. J Neurol Neurosurg Psychiatry. 1985;48:743-748. [pmid: 2411876].
49 Lincoln NB, McGuirk E. Prediction of language recovery in aphasic stroke patients using the Porch Index of Communicative Ability. Br J Disord Commun. 1986;21:83-88. [pmid: 2425841].
50 Kertesz A. Western Aphasia Battery Test Manual. 2nd ed. New York, NY: Grune & Stratton; 1982.
51 Shewan CM, Kertesz A. Reliability and validity characteristics of the Western Aphasia Battery (WAB). J Speech Hear Disord. 1980;45:308-324. [pmid: 7412225].
52 Kertesz A. The Western Aphasia Battery. Orlando, Fla: Grune & Stratton; 1972.
53 Shewan CM. The language quotient (LQ): A new measure for the Western Aphasia Battery. J Commun Disord. 1986;19:427-439. [pmid: 2433314].
54 Kertesz A, McCabe P. Recovery patterns and prognosis in aphasia. Brain. 1977;100 Pt 1:1-18. [pmid: 861709].
55 Crary MA, Gonzalez Rothi LJ. Predicting the Western Aphasia Battery Aphasia Quotient. J Speech Hear Disord. 1989;54:163-166. [pmid: 2468826].
56 Lincoln NB, Blackburn M, Ellis S, et al. An investigation of factors affecting progress of patients on a stroke unit. J Neurol Neurosurg Psychiatry. 1989;52:493-496. [pmid: 2472468].
57 Semel E, Wiig EH, Secord WA. Clinical Evaluation of Language Fundamentals. 3rd ed. San Antonio, Tex: The Psychological Corporation; 1995.
58 Perez E, Slate JR, Neeley R, McDaniel M, et al. Validity of the CELF-R, TONI, and SIT for children referred for auditory processing problems. J Clin Psychol. 1995;51:540-543. [pmid: 7593675].
59 Kotsopoulos S, Walker S, Beggs K, Jones B, Kotsopoulos A, Patel P. Reading and spelling deficits among children attending a psychiatric day treatment program. Eur Child Adolesc Psychiatry. 1996;5:83-92. [pmid: 8814414].
60 Lewis BA, O'Donnell B, Freebairn LA, Taylor HG. Spoken language and written expression--interplay of delays. Am J Speech-Lang Pathol. 1998;7:77-84.
61 Wiig EH, Secord WA, Semel E. Clinical Evaluation of Language Fundamentals- Preschool. San Antonio, Tex: The Psychological Corporation; 1992.
62 Semel E, Wiig ES, Secord WA. Clinical Evaluation of Language Fundamentals. Revised. San Antonio, Tex: The Psychological Corporation; 1987.
63 Wechsler D. Wechsler Preschool and Primary Intelligence Scale. Revised. San Antonio, Tex: The Psychological Corporation; 1989.
64 Brown CL, Sherbenou RJ, Johnson SK. Test of Nonverbal Intelligence (TONI). Austin, Tex: Pro-Ed; 1982.
65 Slossen RL. Slossen Intelligence Test. East Aurora, NY: Slossen Education Publications; 1984.
66 Kaufman AS, Kaufman N. Kaufman Test of Educationial Achievement. Circle Pines, Minn: American Guidance Service; 1985.
67 Hammill DD, Larsen SC. Test of Written Language (TOWL). Austin, Tex: Pro-Ed; 1978.
68 Semel E, Wiig EH, Secord WA. Clinical Evaluation of Language Fundamentals. Spanish Version. 3rd ed. San Antonio, Tex: The Psychological Corporation; 1997.
69 Newcomer PL, Hammill DD. Test of Language Development-Primary. 3rd ed. Austin, Tex: Pro-Ed; 1997.
70 Fodness RW, McNeilly J, Bradley-Johnson S. Test-retest reliability of the Test of Language Development-2: Primary and Test of Language Development-2: Intermediate. J School Psychol. 1991;29:161-166.
71 Hammill D, Newcomer P. Test of Language Development-Intermediate. 3rd ed. Austin, Tex: Pro-Ed; 1997.
72 Lewis BA, Freebairn LA, Taylor HG. Academic outcomes in children with histories of speech sound disorders. J Commun Disord. 2000;33:11-30. 89. 92. [pmid: 10665511].
73 Hammill DD, Brown VL, Larsen SC, Winderholt JL. Test of Adolescent and Adult Language. 3rd ed. Austin, Tex: Pro-Ed; 1994.
74 Zimmerman I, Steiner V, Pond R. Preschool Language Scale. 3rd ed. San Antonio, Tex: The Psychological Corporation; 1992.
75 McLoughlin CS, Gullo DF. Comparison of three formal methods of preschool language assessment. Lang Speech Hear Serv Schools. 1984;15:146-153.
76 Berryman JD. Use of the revised Preschool Language Scale with older preschool children. Lang Speech Hear Serv Schools. 1983;14:79-85.
77 Pecyna Rhyner PM, Bracken BA. Concurrent validity of the Bracken Basic Concept Scale with language and intelligence measures. J Commun Disord. 1988;21:479-489. [pmid: 3235710].
78 Frankenburg WK, Dodds J, Archer P, et al. Denver II. Denver, Colo: Denver Developmental Materials; 1990.
79 Zimmerman IL, Steiner VG, Pond RE. Preschool Language Scale. Rev ed. San Antonio, Tex: The Psychological Corporation; 1979.
80 Hresko WP, Reid DK, Hammill DD. The Test of Early Language Development. Austin, Tex: Pro-Ed; 1981.
81 Dunn LM, Dunn LM. The Peabody Picture Vocabulary Test. Rev ed. Minneapolis, Minn: American Guidance Service; 1981.
82 Bracken BA. Bracken Basic Concept Scale: Diagnostic Scale. San Antonio, Tex: The Psychological Corporation; 1984.
83 Long EE. Native American children's performance on the Preschool Language Scale-3. J Child Commun Dev. 1998;19:43-47.
84 Zimmerman IL, Steiner VG, Pond RE. Preschool Language Scale. Spanish Version, 3rd ed. San Antonio, Tex: The Psychological Corporation; 1993.
85 Phelps-Terasaki D, Phelps-Gunn T. Test of Pragmatic Language. Austin, Tex: Pro-Ed; 1992.
86 Hresko WP, Reid DK, Hammill DD, Ginsburg HP, Baroody AJ. Screening Children for Related Early Educational Needs. Austin, Tex: Pro-Ed; 1988.
87 Bryant B, Newcomer PL. Scholastic Aptitude Scale. Austin, Tex: Pro-Ed; 1991.
88 Drummond S. Dysarthria Examination Battery. San Antonio, Tex: Communication Skills Builders; 1993.
89 Riley GD. Stuttering Severity Instrument for Children and Adults. 3rd ed. Austin, Tex: Pro-Ed; 1994.
90 Yarrus JS, Conture EG Relationship between mother-child speaking rates in adjacent fluent utterances ASHA. 1992 34(10):
91 Riley G. Stuttering Prediction Instrument for Young Children. Austin, Tex: Pro-Ed; 1981.
92 Goldman R, Fristoe M. Goldman-Fristoe Test of Articulation. Circle Pines, Minn: American Guidance Service; 2000.
93 Seymour HN, Seymour CM. Black English and standard American English contrasts in consonantal development of four and five-year old children. J Speech Hear Disord. 1981;46:274-280. [pmid: 7278171].
94 Goldman R, Fristoe M. Goldman-Fristoe Test of Articulation. Circle Pines, Minn: American Guidance Service, Inc.; 1969.
95 Botting N, Conti-Ramsden G, Crutchley A. Concordance between teacher/therapist opinion and formal language assessment scores in children with language impairment. Eur J Disord Commun. 1997;32:317-327. [pmid: 9474284].
96 Mullen PA, Whitehead RL. Stimulus picture identification in articulation testing. J Speech Hear Disord. 1977;42:113-118. [pmid: 839747].
97 Fudala JB. Arizona Articulation Proficiency Scale. Los Angeles, Calif: Western Psychological Services; 1970.
98 Hirano M. Clinical Examination of Voice. New York, NY: Springer-Verlag; 1981:100.
99 De Bodt MS, Wuyts FL, Van de Heyning PH, Croux C. Test-retest study of the GRBAS scale: influence of experience and professional background on perceptual rating of voice quality. J Voice. 1997;11:74-80. [pmid: 9075179].
100 Dejonckere PH, Obbens C, de Moor GM, Wieneke GH. Perceptual evaluation of dysphonia: reliability and relevance. Folia Phoniatrica. 1993;45:76-83. [pmid: 8325573].
101 de Krom G. Consistency and reliability of voice quality ratings for different types of speech fragments. J Speech Hear Res. 1994;37:985-1000. [pmid: 7823566].
102 Dejonckere PH, Remacle M, Fresnel-Elbaz E, Woisard V, Crevier-Buchman L, Millet B. Differentiated perceptual evaluation of pathological voice quality: reliability and correlations with acoustic measurements. Revue De Laryngologie Otologie Rhinologie. 1996;117:219-224. [pmid: 9102729].
103 Millet B, Dejonckere PH. What determines the differences in perceptual rating of dysphonia between experienced raters?. Folia Phoniatrica Et Logopedica. 1998;50:305-310.
104 Wuyts FL, De Bodt MS, Van de Heyning PH. Is the reliability of a visual analog scale higher than an ordinal scale? An experiment with the GRBAS scale for the perceptual evaluation of dysphonia. J Voice. 1999;13:508-517. [pmid: 10622517].
105 Langeveld TP, Drost HA, Frijns JH, Zwinderman AH, Baatenburg de Jong RJ. Perceptual characteristics of adductor spasmodic dysphonia. Ann Otol Rhinol Laryngol. 2000;109:741-748. [pmid: 10961807].
106 Kay Elemetrics Corporation. Multi-Dimensional Voice Program (MDVP) Model 5105: Software Instruction Manual. Lincoln, NJ: Kay Elemetrics; 1999.
107 Deliyski DD, Gress CD. Inter-system reliability of MDVP for Windows 95/98 and DOS. Kay Elemetrics Corporation. Multi-Dimensional Voice Program (MDVP) Model 5105: Software Instruction Manual. Lincoln Park, NJ: Kay Elemetrics Corporation. 1999:67-73.
108 Kent RD, Vorperian HK, Duffy JR. Reliability of the Multi-Dimensional Voice Program for the analysis of voice samples of subjects with dysarthria. Am J Speech-Lang Pathol. 1999;8:129-136.
109 van As CJ, Hilgers FJM, Verdonck-de Leeuw IM, Koopmans-van Beinum FJ. Acoustical analysis and perceptual evaluation of tracheoesophageal prosthetic voice. J Voice. 1998;12:239-248. [pmid: 9649080].
110 Deliyski DD. Acoustic model and evaluation of pathological voice production. Kay Elemetrics Corporation. Multi-Dimensional Voice Program (MDVP) Model 5105: Software Instruction Manual. Lincoln Park, NJ: Kay Elemetrics Corporation. 1999:75-83.
111 Goodglass H, Kaplan E. The Assessment of Aphasia and Related Disorders. Philadelphia, Pa: Lea & Febiger; 1972.
112 Newcomer PL, Hammill DD. Test of Language Development. Austin, Tex: Pro-Ed; 1977.
113 Newcomer PL, Hammill DD. Test of Language Development-Primary. Austin, Tex: Pro-Ed; 1982.
114 Newcomer PL, Hammill DD. Test of Language Development-Primary. 2nd Edition ed. Austin, TX: Pro-Ed; 1988.
115 Zimmerman IL, Steiner VG, Pond RE. Preschool Language Scale. Columbus, Oh: Merrill; 1969.
116 Riley GD. A stuttering severity instrument for children and adults. J Speech Hear Disord. 1972;37:314-322. [pmid: 5057250].
117 Mayo R, Grant WC. Fundamental frequency, perturbation, and vocal tract resonance characteristics in African-American and white American males. ECHO. 1995;17.
118 Baken RJ, Orlikoff RF. Clinical Measurement of Speech and Voice. 2nd ed. San Diego, Calif: Singular Publishing Group; 2000.
119 Mayo R, Watkins TR. A Cross-Linguistic Study of Female RFo Characteristics. Presented March 24, 2000: 46th Annual Convention of the North Carolina Speech, Hearing and Language Association: Raleigh, NC.
120 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: A review of the process. Am J Prev Med. 2001;20:21-35.
121 DiSimoni FG, Keith RL, Holt DL, Darley FL. Practicality of shortening the Porch Index of Communicative Ability. J Speech Hear Res. 1975;18:491-497. [pmid: 1186158].
122 DiSimoni FG, Keith RL, Darley FL. Prediction of PICA overall score by short versions of the test. J Speech Hear Res. 1980;23:511-516. [pmid: 7421154].
123 Hanson WR, Riege WH, Metter EJ, Inman VW. Factor-derived categories of chronic aphasia. Brain Lang. 1982;15:369-380. [pmid: 7074351].
124 Kotsopoulos S, Walker S, Beggs K, Jones B. A clinical and academic outcome study of children attending a day treatment program. Can J Psychiatry. 1996;41:371-378. [pmid: 8862856].