# Conclusions

This chapter begins with a summary of the evidence supporting each of the key questions reviewed in depth in Chapter 3, arrayed by the combination of age group and type of disorder: namely, adult language disorders, child language disorders, adult speech disorders, child speech disorders, and voice disorders. For Key Question No. 1 (i.e., which instruments demonstrate the salient characteristics of a good diagnostic tool), we evaluate the evidence for reliability and validity based on the criteria described in Chapter 2 on methods. We also discuss the normative data available and whether the instruments have been validated in five subpopulations of special interest to the Social Security Administration (SSA). This population-specific focus concerns (1) persons who are English-speaking and have normal hearing, both with and without normal cognition; (2) persons who are not English-speaking and have normal hearing, both with or without normal cognition; (3) persons who mentally retarded; (4) persons with learning disorders; and (5) persons who are hard of hearing. We then assess the evidence for predictive validity for future communicative impairment and performance (Key Question No. 2) and address similar population-specific issues.

We close the chapter by describing the limitations of this evidence report; we address both the constraints specific to the process of instrument selection and literature search and retrieval and the drawbacks of the literature and evidence base associated with the 18 selected instruments. We also reflect on deficiencies of this overall body of evidence for addressing SSA's main policy and programmatic concerns. In discussing the limitations of the available evidence, we first address those that are common across the instruments and then focus on issues that are peculiar to the instruments or to a given population or category of disorder. Chapter 5 builds on these discussion points to propose a research agenda that we judge important to bring to the attention of federal agencies, foundations, or other groups concerned with clinical and health services research in this area.

## Key Question No. 1: Instrument Properties

Key Question No. 1 asked, essentially, "Do the reviewed instrument(s) have demonstrated reliability, validity, and normative data?" To address this issue, we had first to establish criteria for evaluating those properties of the instruments. We then could assess instruments against a priori, scientific benchmarks in which SSA (and the Agency for Healthcare Research and Quality [AHRQ]) could have confidence, should questions arise as to how we arrived at our ultimate conclusions.

### Evaluation Criteria and Summary Results

#### Psychometric Evaluation Criteria

As described in Chapter 2, our criterion for reliability was "strictly" met if the following conditions held: (1) Internal consistency reliability, measured using either Cronbach's coefficient alpha or Kuder-Richardson statistics (K-R 20), is greater than or equal to 0.90; and (2) test-retest/intra-rater reliability is greater than or equal to 0.90 if measured using a correlation coefficient, or greater than or equal to 0.80 if measured using Cohen's Kappa; and (3) inter-rater reliability is greater than or equal to 0.90 if measured using a correlation coefficient, or greater than 0.80 if measured using Cohen's Kappa. Some might reasonably argue that the criterion for internal consistency reliability is set too high given the complexity of speech and language functioning and disorders. Additionally, the resultant variability in daily performance suggests that our criterion for test-retest reliability or intra-rater reliability also may be too high. Thus, we defined a "relaxed" criterion, which differs from the strict criterion in that internal consistency reliability may be as low as 0.80 and/or test-retest/intra-rater reliability may be as low as 0.80 (correlations) or 0.70 (Cohen's Kappa). The relaxed criterion is at a level suitable for having confidence in group, rather than individual, comparisons.

We emphasize here that the criterion of reliability (whether strict or relaxed) can be said to have greater weight than validity criteria, in that no instrument can be said to be valid if it is not demonstrably reliable. Said another way, users of an instrument cannot know for sure that the instrument is measuring what it purports to measure (i.e., is valid) if, upon multiple administrations, it produces responses or data that are unreliable according to accepted measurement standards.

We set the criterion for validity primarily on the basis of construct validity; however, we do report evidence of concurrent validity. In doing so, we required that interrelationships among subtests, composites, and total scores, measured with correlation coefficients, be statistically significant (i.e., p < 0.05), with a magnitude of at least 0.30. Information derived from principal components or factor analysis supporting the construction of composite or total scores can augment this information.

The criterion concerning availability of normative data required that (1) data be available for the population targeted by the instrument, (2) the sample size be adequate (i.e., at least 100 subjects per group), and (3) evidence be provided on how well the sample represents the population(s) of interest. We describe applicability of the evidence to the SSA's targeted populations, but we did not formally incorporate the issue of applicability into our criteria for judging normative data. We note that, for SSA's purposes, issues of normative data probably come into play only for instruments exhibiting some evidence of reliability and validity.

#### Evidence Grading Criteria

As described in Chapter 2, we separated instrument manuals from peer-reviewed literature before assigning a grade to the strength of available evidence supporting each key question. We did so because traditional evidence-based practice would dictate that we downgrade the manuals for not having been published in the peer-reviewed literature. However, because a number of the instrument manuals employed rigorous psychometric methods in the instrument development and validation process, we judged it important to reflect those efforts in our grading scheme. Reflecting the quality of the individual instruments was also important, and doing so would not be possible if we had graded using a system that assigned an "unacceptable" grade to all the manuals for reason of their not having been peer-reviewed.

For both instrument manuals and peer-reviewed literature, a body of evidence in support of the key question would be considered acceptable if the manual or the majority of the available articles reported on well-conducted analyses, had reasonably sized, representative samples; and met our psychometric evaluation criteria. Unacceptable evidence would be that for which the studies had been poorly conducted, used small or nonrepresentative samples, or had results that did not meet or only partially met the psychometric criteria discussed earlier.

#### Tabular Summaries

Table 24 summarizes the available reliability and validity data and normative information for the 18 instruments that we reviewed and indicates whether the psychometric evaluation criteria are met. We document whether each instrument (listed in alphabetical order within disorder) met either the strict or the relaxed criterion for reliability; the next two sets of columns indicate with an X whether the instrument met construct and concurrent validity criteria and whether normative data are available and demonstrably representative of the US population. Finally, the right-most columns show (with an X) whether the instrument can comfortably be said to be applicable to several special populations. (In all cases, a blank means the instrument does not meet the relevant evaluation variable.)

Table 25 summarizes for each instrument the strength of available evidence for the two key questions. We document whether the available evidence is acceptable or unacceptable. In all cases, a blank means that no evidence exists to address the key question. The following paragraphs discuss how the instruments measure up against our psychometric evaluation and evidence strength criteria.

Table 25. Strength of Available Evidence for Instruments, by Key Questiona

Instrument | Key Question No. 1 | Key Question No. 2
Adult Language
BDAE-2 | Unacceptable
PICA | Unacceptable | Unacceptable
WAB | Unacceptable (original only)
Child Language
CELF-3 | Unacceptable | Acceptable (earlier version)
CELF-P | Unacceptable
CELF-3Sp | Acceptable
PLS-3 | Acceptable (except for children 0-8 months old)
PLS-3Sp | Unacceptable
TOLD-P:3 | Acceptable | Acceptable (earlier version)
TOLD-I:3 | Acceptable
TOPL | Unacceptable
Adult Speech
AIDS | Unacceptable
DEB | Unacceptable
SSI-3 | Unacceptable
Child Speech
GFTA-2 | Unacceptable | Acceptable (earlier version)
SSI-3 | Unacceptable
Voice
GRBAS | Unacceptable
MDVP | Acceptable
VHI | Acceptable

a Blank cells indicate that we found no data on predictive validity and thus could not evaluate Key Question No. 2.

#### Adult Language Disorder Instruments

##### Reliability

Of the three adult language disorder instruments we evaluated (see the top three rows of Table 24), the Porch Index of Communicative Ability (PICA) met the relaxed reliability criterion. The original version of the Western Aphasia Battery (WAB) met strict criteria, but no information was provided for the 2^nd^ edition. The Boston Diagnostic Aphasia Examination, 2^nd^ Edition (BDAE-2), met neither criterion because internal consistency data did not meet either criterion and test-retest/intra-rater and inter-rater reliability were not measured.

##### Validity

All three adult language disorder instruments met the construct validity criterion. However, Crary et al. reported a small study that suggested that neither the WAB nor the BDAE-2 consistently classified individuals with aphasia.^44^ Only for the WAB was evidence of concurrent validity available.

##### Availability of Normative Data

Normative data of various types are available for only the BDAE-2 and the WAB. However, the instrument developers derived these data only from individuals with aphasia at single institutions and provided no information as to whether these individuals are representative of the population of typical individuals with aphasia.

##### Summary

Only the PICA and the original WAB met our a priori standards of evidence for reliability and validity; neither one met our standards for the availability of representative normative data. Overall, for strength of evidence, we assigned a grade of "unacceptable" for all three adult language disorder instruments (see Table 25).

#### Child Language Disorder Instruments

##### Reliability

Of the eight child language instruments we evaluated (see Table 24), three instruments-the Clinical Evaluation of Language Fundamentals, 3^rd^ Edition, Spanish Edition (CELF-3Sp), Test of Language Development-Primary, 3^rd^ Edition (TOLD-P:3), and the Test of Language Development-Intermediate, 3^rd^ Edition (TOLD-I:3)-met the relaxed reliability criterion for total and composite scores. The Preschool Language Scale, 3^rd^ Edition (PLS-3) Total Score met the relaxed reliability criterion for all age groups except children between 0 and 8 months of age. The CELF-3 (the basic third edition) met the relaxed criterion for total score but not for composite scores. The PLS-3Sp Total Score met the internal consistency reliability criterion only for children above 18 months of age; measures of inter-rater reliability and test-retest reliability were not reported. The developers of the Test of Pragmatic Language (TOPL) did not measure internal consistency reliability.

##### Validity

Six instruments wholly met the construct validity criterion: CELF-P, CELF-3Sp, PLS-3, TOLD-P:3, TOLD-I:3, and TOPL. CELF-3 met this criterion for composite scores only. All instruments except the PLS-3Sp had evidence of concurrent validity.

##### Availability of Normative Data

We found normative data for all instruments except the PLS-3Sp; its developers derived normative data from the English-language version (PLS-3). Of the instruments that provide normative data, all derived the data from nationally representative samples; in the case of the CELF-3Sp, the norms are representative of the US Hispanic population.

Only the developers of the TOLD-P:3 and TOLD-I:3 provided evidence of the reliability and validity for use with children who have learning disabilities, speech-language disorders or delay, mental retardation, and or who are hard of hearing. The developers of the other instruments specifically excluded children with these disabilities from their normative samples.

##### Summary

Only the CELF-3Sp, TOLD-P:3, and the TOLD-I:3 met the psychometric evaluation standards we established for reliability, validity, and the availability of representative normative data. The PLS-3 met standards for all age groups except children 8 months and younger. Only for these four instruments did we judge the strength of evidence to be "acceptable" for addressing this key question (see Table 25).

#### Adult Speech Disorder Instruments

##### Reliability

Of the three adult speech disorder instruments we evaluated (see Table 24), none met either the strict or the relaxed criterion for reliability. The Assessment of Intelligibility in Dysarthric Speech (AIDS) met the individual criteria for test-retest or intra-rater reliability and inter-rater reliability (one of two rating approaches), but its developers evidently did not measure internal consistency reliability. We found data about test-retest/intra-rater and inter-rater reliability for the Stuttering Severity Index for Children and Adults, 3^rd^ Edition (SSI-3); however, the SSI-3 developers applied inappropriate statistics to measure reliability and did not measure internal consistency reliability. We note, however, that for the AIDS and the SSI-3, how one might measure internal consistency reliability is not clear because of the underlying nature of the diagnostic tool. In the case of the Dysarthria Examination Battery (DEB), test-retest/intra-rater and inter-rater reliability did not meet the individual criteria, and internal consistency reliability was not measured.

##### Validity

Only the SSI-3 met the construct validity criterion; the DEB and AIDS did not. We also uncovered evidence of concurrent validity for the SSI-3 but not for the other two approaches.

##### Availability of Normative Data

Normative data of various types are available for the AIDS and the SSI-3. However, the instrument developers provided no information that would permit evaluators to know whether the standardization samples are representative of the population of adults with disordered speech. No information is available pertaining to the subpopulations of interest to the SSA.

##### Summary

Generally, none of the adult speech disorder instruments met the standards of evidence we established for reliability or validity; the exception is the SSI-3 for construct and concurrent validity. No instrument met normative data standards. We assigned a strength of evidence grade of "unacceptable" to these instruments (see Table 25).

#### Child Speech Disorder Instruments

##### Reliability

Neither the SSI-3 nor the Goldman-Fristoe Test of Articulation, 2^nd^ Edition (GFTA-2) met reliability thresholds (see Table 24). The GFTA-2 met the strict criterion of internal consistency reliability for all age groups of girls of all ages but not for all groups of boys; all age groups of boys met the relaxed criterion. The SSI-3's developers did not measure internal consistency reliability. Both research teams used inappropriate statistical methods to measure test-retest/intra-rater and inter-rater reliability.

##### Validity

Although only the SSI-3 met the construct validity criterion, we found some evidence of concurrent validity for the original GFTA (not GFTA-2) and the SSI-3.

##### Availability of Normative Data

Nationally representative data (by age and sex) are available for the GFTA-2. Although the GFTA-2 investigators included children with various learning disabilities, hearing impairments, and speech and language disorders in their standardization sample, they did not report individual normative data for these groups. Furthermore (and more important for SSA purposes), they indicated that the normative data cannot be used with cognitively impaired or mentally retarded children and provided no guidance on the use of GFTA-2 with non-English-speaking children. Although the SSI-3 has normative data for preschool and school-age children, its developers provided no evidence to assess whether the standardization samples represent the population of stuttering children in this country and no information pertaining to the populations of interest to the SSA.

##### Summary

Neither instrument met the psychometric evaluation standards we established for reliability, validity, or the availability of normative data. No information emerged about use of these instruments with the targeted subpopulations. The strength of evidence for both instruments was judged "unacceptable" (see Table 25).

#### Voice Disorder Instruments

The three instruments reviewed for voice disorders -- GRBAS (Grade, Rough, Breathy, Asthenic, Strain) Scale, Multi-dimensional Voice Program, Model 5105 (MDVP), and Voice Handicap Instrument (VHI) -- were extremely diverse (Table 24). For at least one of these instruments, the MDVP, traditional approaches to measuring reliability and validity likely are not appropriate. Thus, for the MDVP, we indicate which criteria may not be appropriate and have judged the instrument by only the applicable or appropriate criteria.

##### Reliability

Only the VHI met the strict criterion for reliability. The MDVP met the criterion for test-retest/intra-rater and inter-rater reliability but not for internal consistency reliability criteria. However, assessing internal consistency reliability may not be appropriate for the MDVP because it measures and reports 33 acoustical parameters that would not be compared to each other because different voice disorders would affect the score of each independently.

##### Validity

Only the VHI met the construct validity criterion; this criterion was not appropriate for the MDVP given the nature of the instrument described earlier for reliability. The VHI's developers reported detailed evidence of concurrent validity comparing results from the instrument to those from the Short-Form (SF)-36, which is considered a standard instrument for measuring health-related quality of life. We also identified problematic evidence of concurrent validity for the MDVP, although the developers compared the MDVP against the GRBAS Scale, an instrument for which we found little to no evidence of either reliability or validity.

##### Availability of Normative Data

Only the developers of the MDVP reported normative data, although they indicated that the data are representative only of individuals like those in their standardization sample. They further suggested that MDVP users should develop their own normative data based on their specific patient populations. The VHI developers provided a form of normative data by comparing SF-36 scores of voice-disordered individuals with those of normal individuals and individuals with various forms of chronic diseases.

##### Summary

Both the MDVP and the VHI met our psychometric evaluation standards for reliability, validity, and normative data. For neither instrument, however, is any information available concerning SSA's targeted subpopulations. For these instruments we judged the strength of evidence to be "acceptable" for addressing this key question (see Table 25).

## Key Question No. 2: Predictive Validity

For SSA's purposes, information on the characteristics of diagnostic tools (as presented above for the 18 instruments we reviewed) is a necessary but not sufficient body of information. Part of the requirements concerning determinations for disability eligibility involve making some assessment of future performance or lasting and significant impairment. To assist in that type of forecasting, evaluation or diagnostic instruments should also be able to provide some predictive information, and that is the realm of predictive validity.

Of the 18 instruments we reviewed, information on predictive validity was available, but of variable quality, for only four -- one for adult language disorder, two for child language disorders (but not for versions directly reviewed in this report), and one for child speech disorders. These are discussed in more detail below. No instrument we reviewed for either adult speech disorders or voice disorders had evidence of predictive validity.

### Adult Language Disorder Instruments

The two PICA studies provide limited but contradictory evidence of its ability to predict future impairment at 6 months. According to Lendrem and Lincoln,^48^ the PICA can do so, but according to a later study by Lincoln and McGuirk,^49^ it cannot. In both studies, the samples were small and derived from investigations conducted for another purpose; the investigators presented no information on whether the results could be generalized to typical adult aphasics. Further, the studies employed different methods (which were generally poorly documented). Given this picture, we cannot conclude that evidence supports predictive validity for this category of instruments.

### Child Language Disorder Instruments

We identified limited predictive validity evidence related to the revised version of the CELF (CELF-R) and the second edition of the TOLD-P (TOLD-P:2); none was found for the versions of these instruments selected for this evidence review. Kotsopoulos et al. reported data on the ability of the CELF-R instrument to predict reading, spelling, and math performance in children with severe behavioral and psychiatric disorders who were attending a day treatment program.^59^ Although the initial CELF-R performance significantly predicted the children's gains in grade-level scores for reading and math (but not spelling) across the academic year, we caution, for several reasons, that users should not conclude that CELF-R scores predict future impairment. In particular, the relatively small sample comprised children with psychiatric and behavioral disorders, so one cannot evaluate the generalizability of the results to populations beyond those having characteristics similar to the sample.

In 2000, Lewis et al. evaluated the predictive validity of the TOLD-P:2 for school-age language, reading, and spelling skills among 87 children who as preschoolers had been identified with moderate to severe speech sound disorders.^72^ School-age (elementary school) follow-up data were available for 52 of the original sample. Preschool TOLD-P:2 scores were a significant predictor of school-age language and reading skills but not spelling skills. This research group also examined the discriminative power of one subtest and several composites to predict school-age impairments in language, reading, and spelling. For the TOLD-P:2 Semantic composite score, sensitivity was 0.69 and specificity was 0.76 for discriminating between children with and without reading disorders at school age, but this version of the instrument did not discriminate between children with and without language or spelling disorders at school age. The TOLD-P:2 Syntax composite score was able to discriminate between children with and without all three types of disorders at school age. Although Lewis and colleagues conducted their analyses carefully, information remains insufficient to evaluate the generalizability of their results. Thus, we urge caution in concluding that this study supports predictive validity.

### Child Speech Disorder Instruments

Although we found no literature describing the predictive validity of the GFTA-2 (or the SSI-3), Lewis et al. also provided some evidence for the original version of the GFTA.^72^ Preschool scores on the original GFTA significantly predicted school-age reading but not language or spelling skills. Although the sample was relatively small, the research group carefully documented that differential attrition did not occur, but they did not provide sufficient information with which to evaluate the generalizability of their results. Thus, we would urge caution in concluding that this study supports the predictive validity of the GFTA (or GFTA-2).

### Summary

Limitations in the studies, including sample size and generalizability, as well as insufficient documentation of methods, weaken our ability to conclude that any of the instruments examined in this evidence report have adequate evidence of predictive validity for either communicative impairment or functioning. Of the four instruments for which we identified evidence (of any sort) of predictive validity, only the TOLD-P:3 had demonstrated "acceptable" evidence of reliability and validity (Key Question No. 1). Unfortunately, evidence to support predictive validity derived from the previous version of the instrument, the TOLD-P:2. Thus, complete and acceptable evidence on both key questions is not available for any instrument that we reviewed. Only for the TOLD-P:3 does the mixed evidence begin to reach this level of acceptability.

## Limitations of the Evidence Report

As just discussed, we encountered several challenges in conducting this systematic evidence review. Some are directly related to development of key questions, others to selection of reviewed instruments (given the key questions), and yet others to what literature turned out to be available or accessible. Additionally, most of the instruments themselves have important limitations either generally or for the subpopulations and disorder groups specified. Although some instruments hold promise for the SSA's purposes, we cannot escape the conclusion that this is a comparatively thin evidence base for addressing the important policy and clinical questions of concern to SSA (and AHRQ).

### Key Questions and Instruments

Our results and conclusions in this evidence report are, of course, heavily contingent on the structure and focus of the key questions. The original questions (posed as part of the government's request for proposal) were those judged within the SSA to be of high priority to them in assisting their later development of criteria for determining disability in individuals with speech and/or language disorders. We tailored and revised the questions to some extent in early discussions with SSA and AHRQ, to make them compatible with the nature of a systematic evidence review (one without formal recommendations) and manageable within the time and budget constraints of this work. In the end we could devise no completely satisfactory resolution to the SSA's need for a broad canvass of the field; the agency needed a review that was not restricted by patient group or disorder type, and we needed to avoid an unmanageable number of citations that would have been generated by reviewing all relevant assessment instruments.

Given the priority of including both adults and children and three major disorders (speech, language, and voice) while keeping the review within reasonable limits, we engaged in a systematic instrument selection process. Our aim was to optimize scientific and clinical appreciation of issues in diagnosing and caring for patients with these conditions and the likelihood of finding information in an evidence-based approach, while taking account of SSA's time frame and our overall budget. Within these constraints, a national panel of experts selected the 18 instruments through a formal, iterative process at a meeting early in the project. They based their selections on (a) judgments as to the extent to which instruments are already known and used in this field and assess a range of ages and types of speech and language performance and (b) knowledge or beliefs that peer-reviewed information might well exist for the instruments in question.

Thus, these instruments do not cover the universe of instruments in this field or for a population from 0 to 62 years of age; neither do they address all relevant aspects of speech or language disorders in adults and children. Furthermore, they were selected by one group of experts at a particular time. Although we have no special reason to question the selections, we are cognizant of the fact that other expert panels (or this one at some other point in time) might identify a different set of instruments to accord high priority for review.

We emphasize these points because we wish to caution readers not to assume that these particular instruments were necessarily regarded, a priori, as the "best" or "most comprehensive" for evaluating speech language disorders in children or adults. Nonetheless, we are confident that they do represent an appropriate, reasonable, timely, broad-based selection of instruments by which SSA could gain a rigorous view of the state of the science in detecting and predicting the likely outcomes from speech and language disorders.

### Generic Deficiencies in this Body of Literature

As is clear from Chapter 3 and the summary above, the peer-reviewed literature rarely yielded data on the reliability and validity for the majority of selected instruments. In comparison with many other clinical fields for which the published evidence base is extensive (and of high quality), even for screening and diagnostic tests, the peer-reviewed knowledge base about ways to identify speech and language disorders and their potential for causing disability is very small. The peer-reviewed literature is the hallmark of systematic evidence reviews, so this lack of information posed a considerable limitation for our work.

Consequently, we elected to expand our efforts to review and abstract data from instrument manuals. Instrument manuals provided reliability and validity data in varying degrees of comprehensiveness. Some very thorough manuals provided reliability and validity information for children by sex, age group, race or ethnicity, presence of speech or language disorder (or both), and similar factors. In some cases, manuals presented data on all aspects of reliability, providing information on internal consistency, test-retest or intra-rater reliability, and inter-rater reliability, and on construct and concurrent or criterion validity. Others provided information on only some aspects of either reliability or validity.

Given this heterogeneity even in non-peer-reviewed publications and to supplement the variable data in instrument manuals, we reviewed, if available, reliability and validity studies in the peer-reviewed literature for the version immediately before the selected version. For example, for child language disorders, we examined peer-reviewed literature for the revised version of the CELF,^62^ the original version of the GFTA,^94^ and the Stuttering Severity Instrument for Children and Adults, Revised.^89^ This tactic has its own limitations. First, in some cases the publications are very old (20 to 30 years in the past). Second, content may well have changed in important ways across the various versions of the instruments. Thus, although such early data may be indicative of reliability and validity of later versions, we cannot at this stage confirm that these data truly and adequately apply to today's versions of the instruments.

Finally, we note study design, conduct, and documentation difficulties in this literature. In a substantial number of reviewed studies, authors provided little information on the sample studied (e.g., demographic characteristics, information on type and severity of speech, language, or voice impairment) or on how they had recruited subjects from the larger population. Disorder-specific samples were often small, and sometimes investigators combined individuals with different types of disorders for analysis purposes without prior analyses to demonstrate that the groups did not differ from each other in any material way. Often, the research teams poorly documented their statistical methods; occasionally, they did not specify statistical approaches at all. For the most part, they did not correct p-values when making multiple statistical comparisons. Statistics not in common use today were sometimes employed, but the publications lacked reference to statistical texts or original articles; hence, we could not determine whether the choice of statistics was appropriate for the past state of knowledge and computing resources.

### Limitations Specific to the Reviewed Instruments

#### Adult and Child Language Disorder Instruments

In general, the literature reviewed for adult language disorders suffered from four problems. First, all the instruments had been standardized using patients from a single institution, thus seriously limiting the generalizability of the results. In no study did the authors provide information with which to judge how the results would compare to those for typical adult patients with language disorders.

Second, all the instruments were tested with individuals with aphasia or language disorders, with the assumption that individuals without disordered language would achieve the maximum score; said in other words, the assumption is that a ceiling effect would be observed. Such an assumption (of a ceiling effect) may not be correct, however, and only one study attempted to evaluate the effect.^43^ An associated limitation is that, when standardizing instruments, most research teams doing the aphasia studies combined stroke patients and patients with traumatic brain injury. Although this phenomenon is typical of studies evaluating neurological problems during the era in which these instruments were developed, subsequent research suggests that these individuals perform differently on language instruments. To the extent this is true, combined standardization data may not be robust (or useful). Finally, the lack of demonstrated relationship to functional performance is also a significant problem for these instruments.

Several limitations are specific to the child-oriented instruments. Of the eight tests we reviewed, only the TOPL addressed "pragmatics," a critical component in a child's ability to perform well in school. We have little information linking performance on our assessment instruments to school performance or to communication abilities in a nontesting situation. That is, all these instruments evaluated children's communicative abilities in essentially artificial settings and rarely examined their relationship to functional performance outside the testing setting.

Finally, reports on only two instruments (TOLD-P:3 and TOLD-I:3) provide reliability data for children with language disorders or delay, learning and hearing impairments, and mental retardation in a representative way. All other instruments specifically exclude these children. In our view, clinicians would regard including such children as essential, given the importance of early language development to the risk of developing learning disabilities^12^ and the high rate of comorbid psychiatric and communication disorders.^13-15^ Thus, an important advance for this field will be to test and systematically validate the other instruments for children with these conditions.

#### Adult and Child Speech Disorder Instruments

In the case of the three instruments to evaluate adult speech disorders, we found no peer-reviewed articles meeting our a priori inclusion criteria, even when we expanded the search to include literature for a previous version (e.g., Stuttering Severity Instrument for Children and Adults, Revised^89^). For the DEB, reliability data in the manual had been derived from unpublished studies and conference presentations with very small samples, and so we had excluded these materials during the abstract review phase. As already shown in this review, reliability and validity were studied with poor methods or were poorly documented (or both).

One particular characteristic of the psychometric testing of certain child speech instruments should be highlighted. Namely, for the GFTA-2, apparently no reliability or validity testing has been done on two of its three subtests (Sounds-in-Sentences and Stimulability). However, these two subtests provide important information to clinicians in evaluating articulation disorders, and standardized data would be useful. We are uncertain to what extent this inequality in how subtests are examined extends to other unreviewed instruments intended for child populations.

In short, as was true for language disorders instruments, few data are available to determine whether the reviewed speech disorder instruments can provide information about the subpopulations of patients to whom SSA accords high priority.

#### Voice Disorder Instruments

The diversity of the voice disorder instruments was problematic in certain respects. First, for all reviewed instruments, data had not been derived from representative samples. Most investigators used congregate patient samples from voice clinics, without using or providing information on selection criteria; in few cases were individuals with "normal" voices evaluated. Many studies provided no demographic information (e.g., age, sex, ethnicity/race). In general, authors did not report whether their study subjects were representative of the population of voice-disordered patients or their nosological subgroups.

Of particular concern (certainly for SSA's purposes) is the lack of data for children or for members of different racial and ethnic groups. Additionally, investigators apparently made little distinction between men's and women's voices. No developer team reported data on age or race subgroups, characteristics for which empirical and clinical studies have shown voice quality to vary.^117-119^ Thus, the available literature provides little guidance for assessing voice disorders in these populations; as regards subpopulations of particular interest to the SSA, therefore, no data are available.

Additionally, we could not obtain user or instruction manual for two of the voice evaluation instruments. For the GRBAS Scale, we were unable to locate an English-language manual; we found only reports of the scale's use and what most experts consider its introduction to the English language literature.^98^ Thus, we could not review the original reliability and validity evaluation (assuming one had been conducted). The VHI, a self-administered scale, has no manual at this time; instead, Jacobson et al. describe the instrument, provide administration instructions, and report reliability and validity evaluation.^26^

## Using Our Results to Develop Criteria for Disability

Although our results suggest that few of the reviewed instruments have desirable levels of reliability and validity, we do not mean to suggest that these instruments should not be used as part of a comprehensive evaluation of speech and language disorders in adults and children. Several are robust enough to warrant some confidence in the results they yield with respect to diagnosis for individual patients. Among these, as cases in point, are the CELF-3Sp, the PLS-3, the TOLD-P:3, the MDVP, and the VHI, and perhaps the PICA and CELF-3. Our point is that clinicians and others wishing to administer and apply them must give careful attention to the limitations that we have discussed in this report and factor that information into the ultimate conclusions they reach concerning possible diagnoses of impairment and disability for individual patients.

We emphasize, however, that no viable body of evidence exists to support the use of any of the individual instruments reviewed to predict future performance of the person assessed. For the broader evaluation needs of SSA for determining disability eligibility in terms of "long-run" disability, these instruments would not appear to provide the level of quantitative information presumably desired or required.

Assessing and diagnosing individuals with suspected speech and language disorders is a complex and multifaceted process; it requires a multidisciplinary assessment and a wide variety of tools. Among these are some of the instruments we have evaluated here. Other standardized tests and assessments similar to the ones we examined might also pass muster. Nonetheless, we caution that they can provide only one part of an appropriate disability (or diagnostic) evaluation. Whether they are the most important part remains an empirical question beyond the scope of this systematic review.