# Results

This chapter documents our findings concerning the properties of 18 instruments to diagnose or assess speech and language disorders among adults and children. As explained in Chapter 2, these instruments were those given high priority by an expert panel early in this project and confirmed as instruments of interest to the Social Security Administration (SSA) with respect to its responsibilities for determining disability eligibility. We present the evidence on instruments ordered by a combination of age and disorder, as listed in Table 2 in Chapter 2: adult language disorders, child language disorders, adult speech disorders, child speech disorders, and voice disorders.

For each instrument, we first present a profile of relevant characteristics and other information of likely interest to potential users. This includes author and publisher information, target age groups and populations, estimates of administration time, the availability and type of normative data provided, components of the instrument package if acquired or purchased, a brief description of the administration and scoring procedures, and a listing of earlier versions of the instrument. These profiles (called out in parentheses for each instrument) can be found in Tables 5 through 22 at the end of this chapter. Following the instrument-specific profile, we document information pertaining to each of our two key questions.

Briefly, Key Question No. 1 relates to evidence about basic psychometric properties of these diagnostic tools and instruments. We thus present the literature addressing different types of reliability: internal consistency reliability, test-retest or intra-rater reliability, and inter-rater reliability, in that order. Next, we describe the available evidence for construct, concurrent, and content validity, again in that order. Finally, we describe the types of normative data and the populations to whom the normative data apply and assess the generalizability of the normative data (i.e., whether they were derived from a population including normal individuals or a population of only individuals with a speech-language disorder).

Key Question No. 2 pertains more narrowly to predictive validity -- i.e., the ability of these instruments to predict or forecast future functioning of patients (or school performance, in the case of children) diagnosed with a speech, language, or voice impairment. (Strictly speaking the issue is prediction of future impairment in age-appropriate daily activities.) In addition, because the SSA must concern itself with a wide range of patient populations, we conclude each instrument-specific section by examining the applicability of available evidence to these target populations (persons who do not speak English or who are cognitively impaired, mentally retarded, or hard of hearing, or who have learning disorders).

To keep the text of this chapter manageable, we have elected not to comment in the narrative when no evidence is available on a given element of a key question for specific instruments. For example, if we identified no literature (either peer-reviewed or gray) on an evaluation criterion such as predictive validity (Key Question No. 2) or on internal consistency reliability (within Key Question No. 1), then those headings and subheadings will not appear for that particular instrument in this chapter. In short, this chapter documents what evidence is available; Table 24 (Chapter 4) and the discussion in Chapter 4 document the gaps in instrument-specific information and the deficiencies in the overall body of evidence.

Table 24. Key Clinical Question 1: Evidence for Reliability, Validity, and Normative Data, by Instrumenta

Instrument | Reliability ^b^ | Validity | | Normative Data | | Applicability to ^c^
| | Construct | Concurrent | Present | Rep ^d^ | N-Eng | CI | LD | SLD | MR | HI
Adult Language
BDAE-2 | | X | | X
PICA | Relaxed | X
WAB | Strict (original only) | X (original only) | X | X
Child Language
CELF-3 | Relaxed-total scores only | X-composite scores only for all but 1 subtest | X | X | X
CELF-P | | X | X | X | X
CELF-3Sp | Relaxed | X | X | X | ? ^e^ | X
PLS-3 | Relaxed-except 0-8 monthss | X | X | X | X
PLS-3Sp | | | | | | X
TOLD-P:3 | Relaxed | X | X | X | X | | | X | X | X | X
TOLD-I:3 | Relaxed | X | X | X | X | | | X | X | X | X
TOPL | | X | X | X | X
Adult Speech
AIDS | | | | X
DEB
SSI-3 | | X | X | X
Child Speech
GFTA-2 | | | X | X | X
SSI-3 | | X | X | X
Voice
GRBAS | | X
MDVP | Strict | N/A | X | X
VHI | Relaxed | X | X | N/A

a Blank cells indicate criteria were not met or no data were found.

b Strict: meets combined criteria of internal consistency reliability (ICR): alpha >0.90, test-retest reliability (T-RR): kappa >0.80 or correlation >0.90, and inter-rater reliability (I-RR): kappa >0.80 or correlation >0.90; Relaxed: meets combined criteria of ICR: alpha >0.80, T-RR: kappa >0.70 or correlation >0.80, and I-RR: kappa or correlation >0.90

c N-Eng = Non-English speakers, CI = cognitively impaired, SLF = speech-language disordered, LD = learning disabled, MR = mentally retarded, HI = hearing impaired.

d Rep = Representative of U.S. population.

e ? = Could not determine from information given. For instrument names, see Table 4.

Evidence Tables 1 through 72 systematically organize available information on each instrument, again following the order of instruments in this chapter. (Instrument-specific evidence tables are cited in parentheses.) Generally, each instrument has from three to five evidence tables. The first evidence table in the set gives study designs and other information about the empirical studies that we reviewed; succeeding evidence tables provide information about the outcomes of studies with respect to reliability, validity (construct, concurrent, and predictive), and the availability of normative data. Evidence tables also give the quality rating scores assigned to each article (according to the methods explained in Chapter 2).

This chapter concludes with a brief discussion of our supplemental analysis of the usability of the instruments. We defined usability to be how feasible and practical it is to use the instruments in everyday settings. Chapter 4 continues our examination of these results; Chapter 5 draws implications for future research.

## Boston Diagnostic Aphasia Examination, 2^nd^ Edition

The Boston Diagnostic Aphasia Examination, 2^nd^ Edition (BDAE-2) is an instrument for the neuropsycholinguistic evaluation of adults with aphasia for one of three purposes: (1) diagnosis of presence and type of aphasia syndrome, leading to inferences regarding site of lesion; (2) measurement of the level of language performance over a wide range of abilities; and (3) comprehensive assessment of the assets and liabilities of the patient in all language areas as a guide to therapy (Table 5 and Evidence Tables 1-4).^43^ We did not identify any evidence for this instrument on test-retest or intra-rater reliability, concurrent validity, or predictive validity (Key Question No. 2).

Table 5. Boston Diagnostic Aphasia Examination, 2nd Edition (BDAE)

Author | H. Goodglass and E. Kaplan
Publisher | Williams & Wilkins Rose Tree Corporate Center, Building II 1400 North Providence Road, Suite 5025 Media, PA 19063-2043 1-800-638-0672
Date of Publication | 1983
Ages | Adults
Administration Time | Not specified
Scores | Percentile scores for all subtests, including severity rating, fluency, auditory comprehension, naming, oral reading, repetition, paraphasia, automatic speech, reading comprehension, writing, music, and spatial and computational
Normative Data Provided | Performance on all subtests is compared to a sample of 242 men with aphasia tested at the Boston Veteran's Administration Medical Center between 1976 and 1982.
Components | H. Goodglass and E. Kaplan, The Assessment of Aphasia and Related Disorders, 2^nd^ Edition; Boston Diagnostic Aphasia Examination Booklet; 16 test stimulus cards; Boston Naming Test; Boston Naming Test scoring booklet.
Procedures | The examiner first engages the patient in conversation, incorporating suggested questions from the BDAE. The examiner also asks the patient to tell about what is happening in a stimulus picture. Following the conversational and expository speech sample, the examiner completes an aphasia severity rating scale, and a rating scale profile of speech characteristics. Then the examiner proceeds through the BDAE subtests. The subtest order can be varied. Subtests involve a variety of tasks, including asking the patient to point to pictures names by the examiner, point to body parts, follow a series of commands, respond to yes/no questions, rapidly repeat mouth movements, rapidly repeat words, recite memorized materials, imitate words and phrases, read words, respond to questions requiring names, name pictures, discriminate printed letters and words, identify spelled words, complete written sentences by choosing the correct word, and execute some writing tasks. The examiner assigns points for each response based on the directions in the manual. Total raw scores are converted to a percentile score on the subtest summary profile. The overall profile for a patient across all subtypes is used to identify aphasia type, based on guidelines in the manual.
Other | The BDAE includes supplementary language tests in both comprehension and expression, as well as The Boston Naming Test as an extended test of vocabulary naming. In addition, it included supplementary nonlanguage tests of spatial and quantitative performance and of apraxia. The BDAE, 3^rd^ Edition, was published in 2001, too late for review for this report.
Earlier Versions | The Boston Diagnostic Aphasia Examination^111^

### Key Question No. 1

Goodglass and Kaplan standardized the BDAE-2 using 242 male patients treated at the Boston Veterans Administration (VA) Medical Center between 1976 and 1982.^43^ No additional information was provided about patient demographics. They made no claim that the standardization sample is representative of individuals with aphasia in the United States; thus, we ought to take care not to generalize the results beyond this population.

#### Reliability

Only the BDAE-2 instrument manual provided reliability data.^43^ These data were limited to internal consistency and inter-rater reliability (Evidence Table 2).

##### Internal consistency reliability

Goodglass and Kaplan reported reliability statistics (Kuder-Richardson statistics [K-R 20]) ranging from 0.68 to 0.90. Only 14 of the 21 subtest scores met our "strict" criteria for validity (i.e., they are at least 0.90).^43^ These data were derived from a small (n = 34) sample of men with varying types of aphasia; no additional information was provided to judge the external validity or generalizability of the results.

##### Inter-rater reliability

Goodglass and Kaplan provided inter-rater reliability data only for The Profile of Speech Characteristics, which assesses aphasia severity.^43^ Inter-rater reliability, reported as correlations, ranged from 0.78 to 0.90. Correlations at the lower end may be attributed to the highly subjective nature of the rated behaviors. Conversely, the instrument developers, who were highly familiar with instrument items and each other's ratings, were the raters in this evaluation; thus, the inter-rater reliability coefficients may have been slightly higher than might otherwise have been expected.

#### Validity

Only construct validity data were available for both the BDAE-2^43^ and the original version (Evidence Table 3).^44^

##### Construct validity

Goodglass and Kaplan reported correlations between overall severity rating and BDAE-2 subtests but provided no a priori hypotheses about the relationships.^43^ Correlations between overall severity and the subtests ranged widely from −0.24 to 0.79. Intercorrelations of subtests ranged from −0.24 to 0.93.

Additional evidence suggests that the BDAE-2 and the original BDAE may not classify all individuals with aphasia as aphasic. Goodglass and Kaplan employed discriminant analysis with a small, highly selective sample of patients with Broca's, Wernicke's, conduction, and anomic aphasia.^43^ The discriminant analysis classified all but one patient into the original classification. Crary et al., using cluster analysis to evaluate how well the original BDAE classified aphasia patients, reported that only 38 percent of the cases matched the original classification.^44^ We are uncertain whether these results would be replicated with larger and more representative groups of adults with aphasia.

##### Content validity

Goodglass and Kaplan described the variety of deficits that occur in persons with aphasia.^43^ After explaining each area of deficit, they explained why and how the BDAE-2 addresses each deficit.

#### Available Normative Data

Goodglass and Kaplan presented a set of norms derived from a sample of 242 male patients treated in the Boston VA Medical Center (Evidence Table 4).^43^ They also evaluated the performance of neurologically normal men, developing a somewhat arbitrary cutoff score (i.e., lowest scoring normal) for aphasia. Most normal subjects scored the maximum number possible; elderly and less well-educated men were most likely not to achieve the maximum score. We are uncertain whether these norms can be generalized or used with typical aphasia patients, because they were derived from individuals for whom we know little more than sex and who were from a single institution.

#### Applicability of BDAE-2 to Target Populations

Goodglass and Kaplan provided no guidance on the instrument's use with any population of special interest to the SSA.^43^ Rosselli et al. provided thresholds, by educational attainment, for a Spanish translation of the original BDAE.^45^ However, because they derived these norms from Spanish speakers in a single region in Colombia, we may not be able to generalize them to all Spanish speakers or to Spanish-speaking aphasia patients in the United States.

## Porch Index of Communicative Ability

The Porch Index of Communicative Ability (PICA) was designed to evaluate the communicative abilities of individuals with aphasia, including aspects of their verbal, gestural, and graphic communication (Table 6 and Evidence Tables 5-7).^46^ The primary goal was to develop an instrument that would reliably and sensitively quantify a patient's communicative ability so that clinicians and researchers can assess the effect of variables such as treatment, time, surgery, and drugs on communication. We found no evidence for this instrument on concurrent validity or normative data.

Table 6. Porch Index of Communicative Ability (PICA)

Author | B.E. Porch
Publisher | Pro-Ed 8700 Shoal Creek Boulevard Austin, TX 78757-6897 512-451-3246 http://www.proedinc.com/
Date of Publication | 1981
Ages | Adults
Administration Time | Approximately 1 hour
Scores | Subtest means, representing average rated complexity level of response to items within subtest (range of 1-16); overall score, representing mean response level across all subtests; mean modality response level (writing, copying, reading pantomime, verbal, auditory, visual, gestural, and graphic modalities); high and low percentile ranks for subtest scores, modality scores, and overall score.
Normative Data Provided | Percentile ranks based on two population samples: 357 adults with left hemisphere damage and 100 adults with bilateral damage
Components | Theory and development manual; administration, scoring and interpretation manual; test format booklet; test objects; stimulus cards; graphic test sheets; score sheet.
Procedures | Examiner and patient are seated at a table. Examiner administers all 18 subtests according to instructions summarized in test format booklet. Responses elicited include verbal naming, description, pantomime and actual demonstration of object use, receptive identification of objects, reading, writing, and drawing. The examiner scores the patient's responses to each item on a scale of 1 to 16, based on criteria described in the administration, scoring, and interpretation manual.
Other | Manual indicates that approximately 40 hours of training are required to assure reliable administration and scoring of the PICA.
Earlier Versions | The volume of the PICA manual for administration, scoring and interpretation of the test is in its third edition (1981). The volume regarding theory and development was published in 1967.^46^

### Key Question No. 1

Porch standardized the PICA using 150 adults with a diagnosis of brain injury or referral for investigation of a communication disability (Evidence Tables 5-7).^46^ He described the age, race, educational attainment, and time since onset of aphasia. No information was provided with which to judge whether this sample was representative of aphasic adults in the United States.

#### Reliability

Only the instrument manual provided evidence of reliability (Evidence Table 6);^46^ data were available for internal consistency, test-retest, and inter-rater reliability. These results were based on a relatively small subsets (n = 30 to 40) of the standardization sample; no information was given on whether the sample was representative of aphasic adults in the United States.

##### Internal consistency reliability

Porch reported Spearman-Brown reliability coefficients and correlation coefficients based on 30 individuals from the standardization sample. Spearman-Brown coefficients ranged from 0.82 to 0.99 across judges and subtests, with the lowest coefficients observed for the gestural subtests.^46^ Correlation coefficients ranged from 0.88 to 0.99. Collectively, these coefficients met our "relaxed" criterion for internal consistency reliability.

##### Test-retest or intra-rater reliability

Correlations for the 18 subtests ranged from 0.70 to 0.99. Correlations for the different communication modalities were as follows: gestural, 0.96; verbal, 0.99 and graphic, 0.96. The overall correlation was 0.98.^46^ The overall score met our intra-rater/test-retest criterion; several of the subtest scores did not.

##### Inter-rater reliability

Inter-rater correlations were greater than 0.93 for the subtests and greater than 0.97 for response modalities.^46^ Thus, they met our inter-rater reliability criterion. Porch reported significant variance in three subtest scores, the overall test, and gestural responses, but he attributed them to a single scorer.^46^

#### Validity

Construct validity data were available in the instrument manual^46^ and in one peer-reviewed article (Evidence Table 7).^47^ We identified no concurrent validity data.

##### Construct validity

Porch reported correlations between modality and subtest scores and age and educational attainment.^46^ Correlations between age and overall scores and gestural and graphic modality scores were statistically significant but lower than the 0.30 threshold (r = −0.17 to −0.18). Educational level was significantly correlated with the graphic modality score and with nine subtests, but the magnitude of correlations generally fell below 0.30. Porch also reported that correlations of subtests within communication modalities were higher than those between modalities; all correlations were greater than 0.30, suggesting evidence of construct validity for his population of individuals with communication disorders attributed to brain injury or another cause.^46^ Clark et al., using principal components analysis of data from 148 brain-injured adults, provided additional evidence suggesting construct validity for use with individuals whose aphasia can be attributed to brain injury.^47^

##### Content validity

Porch discussed theory relating to aphasia and various PICA subtests.^46^

### Key Question No. 2

Two studies provide limited and contradictory evidence of the ability of the PICA to predict future impairment as measured by the PICA at 6 months (Evidence Table 8).^48,49^

Lendrem and Lincoln, using data from 52 mildly to moderately aphasic adults, found that PICA verbal, gestural, and graphic components accounted for 69 percent of the total variance in 34-week scores, suggesting that early PICA scores (at 4 weeks) could be used to predict impairment at 6 months.^48^ In a related study, Lincoln and McGuirk compared two methods (e.g., slope of improvement and a statistical t-test) for predicting impairment.^49^ Their sample differed from that of Lendrum and Lincoln in that 68 of the 124 adults received speech-language treatment. Neither prediction method fared well. The proportions of patients with accurate predictions (i.e., predicted within plus or minus 10 percent of actual score) were low for both treated and untreated patients, suggesting that PICA scores poorly predict recovery. Both studies employed relatively small samples and provided little information to allow readers to assess whether the results could be replicated with a different group of aphasic adults.

## Western Aphasia Battery, 2^nd^ Edition (WAB)

The Western Aphasia Battery (WAB) (Table 7 and Evidence Tables 9 to 11) was designed to identify aphasia syndromes and their severity through the evaluation of clinical aspects of oral language functioning as well as reading, writing, calculation ability, and nonverbal skills.^50,51^

Table 7. Western Aphasia Battery (WAB)

Author | A. Kertesz
Publisher | The Psychological Corporation 555 Academic Court San Antonio, TX 78204 Voice 1-800-872-1726 Fax 1-800-232-1223 http://www.psychcorp.com/
Date of Publication | 1982
Ages | Adults
Administration Time | Approximately 1 hour for oral language portion (yielding Aphasia Quotient)
Scores | Subtest scores for spontaneous speech, comprehension, repetition, and naming are combined to yield Aphasia Quotient; subtest scores for reading and writing, praxis, and construction are combined to yield Cortical Quotient. Patient may be classified according to aphasia type based on oral language subtest scores using taxonomic table in manual.
Normative Data Provided | None
Components | Test manual; objects; stimulus cards; blocks (for block design task); test booklet.
Procedures | Examiner and patient are seated at a table (or patient may be tested at bedside). All items are administered to each patient. Examiner first engages patient in conversation and then scores informational content and fluency of spontaneous speech according to scale provided in test booklet. Other test items used to calculate Aphasia Quotient include responding to questions; identifying objects, body parts, pictures, letters, and numbers; following directions; imitating words; and naming objects. Test items used to calculate Cortical Quotient include reading sentences, following written directions, oral spelling, writing a story, writing to dictation, copying written words, gesturing, drawing, completing mathematical calculations, block design, and completing the Raven's Colored Progressive Matrices. Examiner scores responses according to instructions provided in the test booklet.
Other | Audiotaping of the test session is recommended.
Earlier Versions | 1977 version.^51^

### Key Question No. 1

Shewan and Kertesz standardized the original WAB in Ontario, Canada, using a sample of 150 aphasic adults and 59 control subjects.^51^ The subjects included individuals with communication disorders resulting from brain injury and other causes. They provided limited demographic information (age only); therefore, we were unable to judge whether these individuals were representative of aphasic and/or "normal" adults in the United States. Kertesz did not provide formal standardization of the revised WAB; rather, he presented only a comparison between the revised and original instruments.^50^

#### Reliability

Shewan and Kertesz^51^ provided evaluations of internal consistency, test-retest, inter- and intra-rater reliability for the original WAB.^52^ Shewan presented additional data on the internal consistency reliability of the WAB language quotient subscore (Evidence Table 10).^53^

##### Internal consistency reliability

No internal consistency data were reported for the revised WAB. Shewan and Kertesz reported internal consistency reliability for the original WAB tests administered to 140 aphasic subjects from the standardization sample.^51^ Cronbach's coefficient alpha was 0.91 and Bentler's coefficient theta (for tests that combine subscores to yield a composite score) was 0.97, suggesting high internal consistency.

Shewan presented internal consistency data for the Language Quotient (LQ)using data from 94 aphasic patients from a larger study on language therapy and recovery from aphasia.^53^ These individuals were similar to the standardization sample used earlier by Shewan and Kertesz.^51^ Specifically, 55 were male and 39 were female; all were functional English speakers prior to aphasia, were on average 65 years of age (range 29 to 85), and represented a variety of different aphasic categories. Cronbach's coefficient alpha for the LQ was 0.91 and Bentler's coefficient theta was 0.97, suggesting high internal consistency. The consistency of these results with those presented earlier by Shewan and Kertesz suggests that the 1986 study may be a repetition of the earlier results; it is not possible to determine this definitively.

##### Test-retest or intra-rater reliability

Three studies reported data on test-retest reliability,^51,53,54^ although the 1986 Shewan^53^ study appears to re-report the 1980 Shewan and Kertesz data.^51^

Shewan and Kertesz examined test-retest reliability using 38 chronic aphasic subjects, who were stable at the time of initial testing;^51^ Shewan again reported the analysis of these subjects with respect to the subtests that make up the LQ.^53^ Of the 38 individuals who had completed the spoken language section of the WAB, 32 completed the Reading subtest, and 25 completed the Writing subtest on each of two test sessions separated by at least a 6-month period (range = 6 months to 6 years and 6 months; median = 12 to 23 months). Different examiners assessed 22 of the 38 individuals on retest. Pearson's correlation coefficient for the individual subtests ranged from 0.88 to 0.97 (Praxis had a correlation of 0.58 but was not reported by Shewan). Correlations for the Aphasia and Cortical Quotients were 0.97 and 0.90, respectively.^51^ The mean absolute score difference between the test and retest was less than 10 points for each subtest, indicating less than 10 percent variation.

Kertesz and McCabe, in looking at recovery patterns and prognosis for 93 persons with aphasia, administered the WAB at 45 days post-onset, and 3, 6 and 12 months and yearly thereafter.^54^ They looked at the Language Quotient (LQ) of the WAB separately in a subgroup of 22 patients who had chronic, long-term aphasia and for whom little recovery was observed. This group had a Pearson's correlation coefficient of 0.992, significant at p < 0.01, suggesting high test-retest reliability in a population with stable aphasia.

Shewan and Kertesz reported intra-rater reliability results for the eight subtests and two composites (Aphasia and Cortical Quotients) of the original WAB;^51^ Shewan reported the same results. In this investigation, three judges scored 10 videotaped administrations of the original WAB twice, with a between-test interval of several months. No data were provided on the aphasic subjects other than to indicate that they varied in severity and type of aphasia. Intra-rater correlation coefficients ranged between 0.79 and 1.00, and all but one were significant at p < 0.001. Of six correlation coefficients that were less than 0.98, five were from Information Content and Fluency subtests. Shewan and Kertesz suggested that these smaller correlations could likely be attributed to the nature of the two subtests (i.e., single-item rather than multiple-item scales and differences in weighting schemes for transforming raw scores to standard scores).^51^

##### Inter-rater reliability

Shewan and Kertesz evaluated inter-rater reliability by having eight judges score videotaped original WAB test administrations to 10 aphasic individuals;^51^ again Shewan re-reported the data for the six LQ subtests. As in their reports on intra-rater reliability, the authors gave no descriptive data about the aphasic subjects. For the Writing and Construction Subtests, the subjects' original performance was available for scoring. Correlations by subtest and judge were greater than 0.90 for all subtests except Fluency, which ranged from 0.77 to 0.84 for the eight judges.

#### Validity

The WAB-2 manual provided no information on the validity of the instrument. Instead, construct validity data for the original WAB appeared in several peer-reviewed articles (Evidence Table 11).^44,53,55^ Kertesz provided evidence of concurrent validity of the revised WAB-2.^50^

##### Construct validity

Four peer-reviewed articles addressed various aspects of the construct validity of the original WAB.^44,51,53,55^

Shewan and Kertesz employed principal components analysis to previously collected data on 142 individuals with aphasia.^51^ Four components accounted for 100 percent of the total variance, with the first factor accounting for 82 percent. The five WAB subtests contributed equally to the first factor. Additionally, they reported evidence that WAB scores differed significantly between aphasics and nonaphasics and nonaphasic subjects (F = 369.4, p < 0.001).

Crary and Gonzalez-Rothi evaluated the relationships between the 10 WAB subtests and the Aphasia Quotient (AQ).^55^ Correlation coefficients (not corrected for multiple comparisons) between the subtests and the AQ ranged from 0.56 to 0.93, all significant at p < 0.05. The inter-subtest correlation coefficients ranged from 0.32 to 0.89. One subtest, Information Content, accounted for 87 percent of variability of the AQ, suggesting that nine of the subtests contributed minimal information in comparison with the Information Content subtest. Just as the original WAB data all came from Western Ontario, these data all came from Florida, possibly limiting the generalizability of this information.

Shewan, using data from the original validation of the WAB, examined subsets of subjects to compare subsets of the WAB.^53^ She found that time is a significant predictor of the LQ (F = 43.33, p < 0.00001). LQ scores increased over testing sessions by 27.17 and 11.72 for treated and untreated groups, respectively. The LQ scores of mild, moderate, and severe aphasic patients increased over time, based on initial AQ. Time and severity had significant main effects (time, F = 106.64, p < 0.00001 and severity, F = 77.25, p < 0.00001). However, LQ correlated 0.98 with the overall AQ, suggesting that the LQ provided no new information. The sample sizes were small and Shewan was reporting data from earlier studies; these factors weaken the validity of the WAB.

Finally, Crary et al. used a cluster analysis to estimate how well the original WAB classified aphasia patients.^44^ They analyzed scores on the original WAB for 47 patients who were aphasic after having experienced a single, thromboembolic cerebrovascular accident (CVA). Patients were on average 57.7 years (range = 26-84), had completed 12 years (range, 8-16) of education, and were 16.1 months (range = 1-80) post CVA. Crary et al. used a statistical clustering technique to analyze the original WAB scores and then compared the results of the clustering to the original WAB classifications.^44^ The original WAB scores resulted in three clusters that accounted for 97 percent of the total variance. Crary et al. computed the average value of each classification variable for patients within each cluster and compared them to the original WAB classification taxonomy.^44^ They then compared the resultant classifications to those derived from the scores on the original WAB. Only 30 percent of the cases matched the original classification. Although these results may suggest that the WAB may not classify patients consistently, we urge that the results be interpreted with caution given the relatively small sample size and the lack of descriptive information about the patients in the Crary et al. study.

##### Concurrent validity

Kertesz compared original and revised WAB scores for 20 consecutive patients.^50^ Pearson correlations for all subtests ranged from 0.85 to 0.99; all correlations were significant at p < 0.001 except the Spoken Word-Written Choice subtests (p < 0.01). The AQ correlation was 0.99.

Shewan and Kertesz reported evidence of both concurrent and divergent validity.^51^ As evidence of concurrent validity, they reported correlations between WAB subtests and Neurosensory Center Comprehensive Evaluation of Aphasia (NCCEA) subtest scores ranging from 0.82 to 0.92; the correlation between total scores for both instruments was 0.97, suggesting strong evidence of concurrent validity. They also reported a correlation of 0.57 between the WAB total score and Raven's Coloured Progressive Matrices (RCPM), a test unrelated to aphasia.

##### Content validity

Shewan and Kertesz discussed the point that the WAB subtests assess all language modalities and are comparable to previous aphasia batteries, including the original BDAE.^51^

#### Available Normative Data

Normative data, per se, were not provided for either version of the WAB. However, subtest scores allow the examiner to classify aphasic patients using WAB scores derived from the original standardization sample.^51^ The members of the standardization sample may not be representative of individuals with aphasia because they were all from Western Ontario, Canada, and included both traditional aphasic (post-stroke) patients and traumatic brain injury patients. These groups performed very differently on language tests. In a follow-up article, Shewan presented data from new subjects, but all were from the state of Florida.^53^ They did include traumatic-brain-injured patients, who may be more cognitively impaired than a traditional aphasic subject pool.

### Key Question No. 2

We identified no evidence of predictive validity for the second edition of the WAB. However, Lincoln et al. examined the ability of the original WAB to predict activities of daily living (ADLs) (Evidence Table 12).^56^ They evaluated 54 patients on a stroke unit, administering the original WAB at admission, at discharge, and at 9 months after stroke. They used stepwise multiple regression to report that the WAB Reading and Writing Quotient accounted for 7 percent of the total variability in Extended ADL Mobility, 16 percent of Extended ADL Kitchen, and 34 percent of Extended ADL Leisure measured at 9 months post admission. These results, from Nottingham in the United Kingdom, may not generalize to other countries in general or to the United States in particular. Factors such as availability of home health care and rehabilitation may affect recovery and thus be very important in contributing to ADL measures.

## Clinical Evaluation of Language Fundamentals, 3^rd^ Edition (English)

The Clinical Evaluation of Language Fundamentals, 3^rd^ Edition (CELF-3) was designed to identify, diagnose, and perform follow-up evaluations of language deficits in children, adolescents, and young adults (Table 8 and Evidence Tables 13-17).^57^ It assesses receptive and expressive language abilities in the areas of verbal concepts and directions, word associations, semantic relationships, word and sentence structure, and recall of spoken language.

Table 8. Clinical Evaluation of Language Fundamentals, 3rd Edition (CELF)

Author | E.H. Wiig, W.A. Secord, and E. Semel
Publisher | Psychological Corporation P.O. Box 839954 San Antonio, TX 78283-3954 1-800-228-0752 http://www.psychcorp.com/
Date of Publication | 1995
Ages | 6-0 through 21-11 years
Administration Time | 30-45 minutes for the six subtests constituting the Receptive Language and Expressive Language composite scores, and Total Language Scores; approximately 60 minutes for all 11 subtests
Scores | Standard scores and percentile ranks with computed 68 percent and 90 percent confidence intervals, stanines, normal curve equivalents, and age equivalents
Normative Data Provided | Norms for the individual subtests, and the Receptive and Expressive Language Composite Scores, and the Total Language Scores are reported for each 1-year age group from 6-0 through 16-11 years and from 17-0 through 21-11 years.
Components | Examiner's manual, two stimulus manuals with easels containing visual stimuli, record form, and a software scoring program.
Procedures | The examiner shows the examinee the stimulus items and follows the specific instructions for the items and subtests. Correct responses are coded as 1, incorrect or no response as 0 for some subtests and by different approaches for others. Calculation of subtest totals is described in detail in the manuals and varies by subtest. Subtest raw scores are converted to norm-referenced standard scores using tables provided in the manual. The Receptive Language Composite Score is the sum of the standard scores of the age-appropriate subtests; the score then is converted to a standard score. A similar approach is used to derive a standard score for the Expressive Language Composite Score. The Total Language Score is calculated as the sum of the Receptive and Expressive Language standard composite scores and then converted to a standard score using the table in the manual.
Other | None
Earlier Versions | Clinical Evaluation of Language Fundamentals-Revised (1987)^62^

### Key Question No. 1

Semel et al. standardized the CELF-3 using 2,450 English-speaking children, adolescents, and young adults in 47 states.^57^ None of the sample was receiving language therapy or had a diagnosed or identified language disorder. The sample was representative of US children with respect to race, sex, residence (urban or rural), family income, educational attainment of parents, and geographic region

#### Reliability

Data on the CELF-3's reliability were available only in the instrument manual (Evidence Table 14).^57^

##### Internal consistency reliability

Semel et al. reported Cronbach's coefficient alphas by age ranging from 0.83 to 0.95 for Receptive Language and Expressive Language subscales and the Total Language score; all alphas for the Total Language score were above 0.90.^57^ Thus, the CELF-3 met our "relaxed" criterion.

##### Test-retest or intra-rater reliability

For the Receptive Language and Expressive Language composite scores, mean test-retest correlations across age were 0.80 and 0.86 respectively. For the Total Language Score, mean correlation was 0.91. Thus, the total score met our criterion; composite scores did not.

##### Inter-rater reliability

Semel et al. reported inter-rater reliability for the Formulated Sentences and Word Associations subtests, which require clinical judgment in scoring for three different age groups: 6-year-olds, 11-year-olds, and 16-year-olds.^57^ For Formulated Sentences, correlations ranged from 0.70 to 0.91 (lowest correlation in oldest group). For Word Associations, correlations ranged from 0.97 to 0.99. The CELF-3 met our criterion except for the Word Association subtest in older children.

#### Validity

Reports of validity data were available for the both the CELF-3^57^ and for the earlier CELF-R (Evidence Table 15).^58-60^

##### Construct validity

Construct validity data were available for both the CELF-3^57^ and the CELF-R.^58^ Semel et al. examined the relationships between the subtests for ages 6 through 8 years and for ages 9 years and older; correlations ranged from 0.25 to 0.63 with only one falling below our 0.30 threshold. They also conducted a discriminant analysis to determine the extent to which the CELF-3 would discriminate between children and adolescents with and without language disorders. They reported the overall agreement (71.3 percent) between the CELF-3 (mean minus 1 standard deviation as cut-off) and school system classification; we calculated the sensitivity (0.80), specificity (0.67), and positive and negative predictive values (0.57 and 0.85, respectively). Factor analysis using the standardization sample suggested that the CELF-3 captures a single factor measuring language.

Perez et al. reported correlations between CELF-R Total score and Receptive and Expressive Language composite scores of 0.90 and 0.93, respectively.^58^

##### Concurrent validity

Semel et al. provided evidence of concurrent validity for the CELF-3.^57^ Perez et al., Kotsopoulos et al., and Lewis et al. provided data for the CELF-R.^58-60^

Semel et al. examined the concurrent validity of the CELF-3 in relation to the CELF-Preschool (CELF-P),^61^ the CELF-Revised (CELF-R),^62^ and the Wechsler Intelligence Scale for Children, Third Edition (WISC-III).^63^ They reported correlations between the CELF-3 and the CELF-R: Expressive, Receptive, and Total Language scores ranging from 0.72 to 0.79 for a subset of the standardization sample and 0.68 to 0.83 for language-disordered children receiving therapy. In a comparison of the CELF-3 and CELF-P, they reported correlations between related subtests ranging from 0.29 to 0.58, and between composite scores ranging from 0.49 to 0.63. Correlations among CELF-3 and WISC-III composite scores ranged from 0.56 to 0.75. Taken together, these results suggest acceptable concurrent validity.

Perez et al. examined the relationships between the CELF-R and the Test of Nonverbal Intelligence (TONI),^64^ and the CELF-R and the Slossen Intelligence Test (SIT),^65^ for children with learning difficulties who had been referred for central processing evaluation.^58^ Correlations between the CELF-R and TONI composite scores ranged from 0.45 to 0.58; correlations between CELF-R and SIT composite scores ranged from 0.59 to 0.69.

Kotsopoulos et al. also reported correlations between the CELF-R subtests and scores for reading comprehension, decoding, and spelling using the Kaufman Test of Educational Achievement (KTEA)^66^ for children with severe behavioral and other psychiatric disorders.^59^ CELF-R subtests were moderately to highly correlated with the KTEA subtests as follows: Reading Decoding (0.54 to 0.67), Reading Comprehension (0.62 to 0.73), and Spelling (0.44 to 0.61).

Finally, Lewis et al. reported correlations between CELF-R scores and the Test of Written Language, Second Edition (TOWL-2) Spontaneous Writing subtest scores^67^ for children diagnosed with phonological disorders as preschoolers.^60^ They reported significant correlations for the CELF-R Sentence Assembly subtest and Total Language scores with the TOWL-2 Syntactic subtest, but only for children who had phonological disorders.

##### Content validity

Semel et al. documented content validity by developing a conceptual model and describing relationship between subtest content and the model.^57^ Additionally, they used a panel of speech-language pathology experts to review all CELF-3 materials for sex, racial/ethnic, and regional biases and employed statistical methods to identify biased items.

#### Available Normative Data

Semel et al. presented normative data for the CELF-3 (Evidence Table 16).^57^ The total standardization sample closely matched the US population with respect to geographic region, sex, mother's education, and race or ethnic group.

#### Applicability of CELF-3 to Target Populations

Semel et al. provided no guidance on the use of CELF-3 with populations of interest to the SSA.^57^ They excluded from the standardization sample children diagnosed with a language disorder or a hearing deficit.

### Key Question No. 2

We identified no evidence on the CELF-3 concerning predictive validity. Kotsopoulos et al. reported data on the predictive validity of the original CELF-R instrument, however (Evidence Table 17).^59^ CELF-R scores predicted gains in reading and math but not spelling among children receiving treatment for severe behavioral and psychiatric disorders.

## Clinical Evaluation of Language Fundamentals, 3^rd^ Edition (Spanish)

The Spanish version of Clinical Evaluation of Language Fundamentals, 3rd Edition (CELF-3Sp) was designed to identify, diagnose, and perform follow-up evaluations of language deficits in children, adolescents, and young adults.^68^ Like the CELF-3, it assesses receptive and expressive language abilities in the areas of verbal concepts and directions, word associations, semantic relationships, word and sentence structure, and recall of spoken language (Table 9). We identified no evidence of predictive validity (Key Question No. 2) for this instrument.

Table 9. Clinical Evaluation of Language Fundamentals, 3rd Spanish Edition (CELF-3Sp)

Authors | E. Semel, E.H. Wiig, and W.A. Secord
Publisher | The Psychological Corporation 555 Academic Court San Antonio, TX 78204 Voice 1-800-872-1726 Fax 1-800-232-1223 http://www.psychcorp.com/
Date of Publication | 1997
Ages | 6-0 through 21-11 years
Administration Time | 20-45 minutes for core subtests; approximately 1 hour for all subtests (core, supplemental, and optional)
Scores | Age equivalents, percentile ranks, and standard scores for subtests: Estructura de oraciones (Sentence Structure), Conceptos y direcciones (Concepts and Directions), Clases de palabras (Word Classes), Estructura de palabras (Word Structure), Formulación de oraciones (Formulated Sentences), Recordando oraciones (Recalling Sentences), Asociación de palabras (Word Association), and Escuchando párrafos (Listening to Paragraphs); and for composites: Spanish Receptive Language, Spanish Expressive Language, and Spanish Total Language. Means and standard deviations of raw scores are provided for errors and time for the optional subtest, Enumeración rápida y automática (Rapid Automatic Naming).
Normative Data Provided | Data are provided at 1-year intervals from ages 6-0 to 16-11 years, and for the 5-year interval from age 17-0 to 21-11 years, based on a standardization sample of 1,050 individuals from 19 states who spoke varying dialects of Spanish.
Other | None
Earlier Versions | None

### Key Question No. 1

Semel et al. standardized the CELF-3Sp using 1,050 Spanish-speaking children, adolescents, and young adults from 19 states (Evidence Tables 18-21).^68^ Individuals were included only if they were fluent in Spanish. Like the CELF-3 standardization sample, none had hearing deficits or diagnosed language disorders. The investigators documented that the sample was representative of the US Hispanic population with respect to educational attainment of parents and geographic region.

#### Reliability

Reports of the CELF-3Sp's reliability were available only in the instrument manual (Evidence Table 19).^68^

##### Internal consistency reliability

Semel et al. reported Cronbach's coefficient alphas by age for Receptive Language (α = 0.82-0.90), Expressive Language (α = 0.89-0.95) composite scores, and the Total Language score (α = 0.91-0.95); all alphas for the Total Language score were greater than 0.90.^68^ Thus, the CELF-3Sp met our "relaxed" criterion.

##### Test-retest or intra-rater reliability

For the Receptive Language and Expressive Language composite scores, mean test-retest coefficients across were 0.79 and 0.85, respectively. For the Total Language Score, the mean test-retest across age was 0.87. Thus, the CELF-3Sp did not meet our criterion.

##### Inter-rater reliability

Semel et al. reported inter-rater reliability only for the Formulated Sentences and Word Associations subtests in selected age groups.^68^ For Formulated Sentences, correlations ranged from 0.79 to 0.82 (lowest correlation in oldest group). For Word Associations, correlations ranged from 0.97 to 0.98.

#### Validity

Semel et al. presented CELF-3Sp data on construct, concurrent, and content validity (Evidence Table 20).^68^

##### Construct validity

Semel et al. examined the relationships between the subtests for children ages 6 through 8 years and for those ages 9 and older.^62^ Correlations ranged from 0.13 to 0.65 for the younger age group, and 0.21 to 0.50 for the older age group, with most above our 0.30 threshold. They also conducted a discriminant analysis to determine the extent to which the CELF-3Sp would discriminate between children and adolescents with and without language disorders. Semel et al. reported overall agreement was 71.6 percent; we calculated the sensitivity (0.75), specificity (0.69), and positive and negative predictive values (0.65 and 0.78, respectively). Factor analysis suggested that, like the CELF-3, the CELF-3Sp captures a single factor measuring language skills.

##### Concurrent validity

Semel et al. provided limited concurrent validity evidence, comparing the CELF-3Sp to the Spanish version of the CELF-3 Observational Rating Scales (ORS).^68^ Parents, teachers, and children with language disorders completed the ORS. Only correlations between CELF-3Sp Total score and teacher or child ratings (−0.45 and −0.57, respectively) were significant for children with speech-language disorders. Correlations were smaller in magnitude for children without speech-language disorders. Correlations in the negative direction were expected because higher ratings on the ORS are associated with more language problems..

##### Content validity

Semel et al. provided extensive evidence of the CELF-3Sp's content validity by describing the conceptual model employed and using a panel of experts in bilingual assessment or Spanish language issues to review test content for biases.^68^

#### Available Normative Data

Semel et al. documented that the total standardization sample closely matched the US population with respect to the proportion of the nation's Hispanic population located in various geographic regions, as well as for sex and educational level of the primary caregiver (Evidence Table 21).^68^ However, we found no information on how representative these data are of the US Hispanic population as a whole.

#### Applicability of CELF-3Sp to Target Populations

Semel et al. provided no guidance on the use of the CELF-3Sp with any populations of interest to the SSA.^68^ None of the individuals in the standardization sample was diagnosed with a language disorder or a hearing deficit.

## Clinical Evaluation of Language Fundamentals-Preschool

The Clinical Evaluation of Language Fundamentals-Preschool (CELF-P) was designed to identify, diagnose, and perform follow-up evaluations of language deficits in preschool children (Table 10).^61^ Like the CELF-3, it assesses receptive and expressive language abilities in the areas of word meanings, word and sentence structure, and recall of spoken language. We identified no data on predictive validity (Key Question No. 2) for this instrument.

Table 10. Clinical Evaluation of Language Fundamentals-Preschool (CELF-P)

Author | E. Semel, E.H. Wiig, and W.A. Secord
Publisher | The Psychological Corporation P.O. Box 839954 San Antonio, TX 78283-3954 1-800-228-0752 http://www.psychcorp.com/
Date of Publication | 1992
Ages | 3-0 through 6-11 years
Administration Time | 30-45 minutes depending upon the age of the child and his or her level of cooperation with the examiner
Scores | Standard scores and percentiles ranks with computed 68% and 90% confidence intervals, and age equivalents
Normative Data Provided | Norms for the individual subtests, and the Receptive, Expressive, and Total Language Scores reported for each 6-month age group from 3-0 through 6-11 years.
Components | Examiner's manual, three stimulus manuals with easels containing visual stimuli, and record form.
Procedures | The examiner shows the examinee the stimulus items and follows the specific instructions for the items and subtests. Correct responses are coded as 1, incorrect or no response as 0 for some subtests and by different approaches for others. Calculation of subtest totals is described in detail in the manuals and varies by subtest. Subtest raw scores are converted to norm-referenced standard scores using tables provided in the manual. The Receptive Language Composite Score is the sum of the standard scores for the Linguistic Concepts, Sentence Structure, and Basic Concepts subtests; the score then is converted to a standard score. A similar approach is used to derive a standard score for the Expressive Language Composite Score (Recalling Sentences in Context, Formulating Labels, and Word Structure subtests). The Total Language Score is calculated as the sum of the Receptive and Expressive Language standard composite scores and then converted to a standard score using the table in the manual.
Other | Downward (in terms of age) revision of the Clinical Evaluation of Language Fundamentals-Revised (1987)^62^
Earlier Versions | None

### Key Question No. 1

Wiig et al. standardized the CELF-P using 800 English-speaking children ages 3-0 through 6-11 years (i.e., children ages 3 years, 0 months to 6 years, 11 months), none of whom was receiving language therapy or had a diagnosed or identified language disorder (Evidence Tables 22 through 25).^61^ They documented that the sample was representative of US children with respect to race, sex, mother's educational attainment, and geographic region

#### Reliability

Reports of the CELF-P's reliability were available only in the instrument manual (Evidence Table 23).^61^

##### Internal consistency reliability

Wiig et al. reported Cronbach's coefficient alphas by age for the Receptive (r = 0.73 to 0.92) and Expressive Language (r = 0.82 to 0.94) composite scores, and for the Total Language score (r = 0.86 to 0.96).^61^ With the exception of the Receptive Language composite score for children ages 6-6 to 11-0, alphas met our relaxed criterion for acceptable internal consistency reliability.

##### Test-retest or intra-rater reliability

Wiig et al. reported test-retest reliability for two age groups: children ages 3-6 years through 3-11 years and 4-6 years through 4-11 years.^61^ For Receptive Language, test-retest reliability coefficients were 0.93 and 0.87, respectively, for the younger and older age groups. For Expressive Language, the stability coefficients were 0.94 and 0.92; for Total Language, they were 0.97 and 0.93.

##### Inter-rater reliability

Wiig et al. reported inter-rater reliability as mean percentage agreement (greater than 90 percent).^61^ Evidence of inter-rater reliability did not meet our threshold for acceptable evidence.

#### Validity

Data validating the CELF-P were available only in the instrument manual (Evidence Table 24).^61^

##### Construct validity

Wiig et al. reported correlations among the CELF-P composite scores, ranging from 0.60 to 0.84.^61^ The lowest correlation was for the oldest age group; the authors attributed this to ceiling effects. They also conducted a discriminant analysis to determine how well scores on the CELF-P identified children with or without language disorders (based on school system classification); EPC staff calculated the sensitivity, specificity, and PPV and NPV values. Overall agreement ranged from 72 percent to 74 percent depending upon the threshold used with the CELF-P. Sensitivity ranged from 0.84 to 0.93, specificity from 0.65 to 0.69, PPV from 0.48 to 0.60, and NPV from 0.89 to 0.96.

##### Concurrent validity

Wiig et al. examined the concurrent validity of the CELF-P in relation to five other instruments.^61^ All data suggested acceptable evidence of concurrent validity. They examined the relationship between the CELF-P and the CELF-R. Correlations for the parallel subtests ranged from 0.27 to 0.84; correlations for Receptive Language and Expressive Language composite scores ranged from 0.63 to 0.86; correlations for the Total Language scores ranged from 0.71 to 0.93. They also reported the overall agreement between the CELF-P and the pass/fail decision from the CELF-R Screening Test; EPC staff calculated the sensitivity, specificity, and PPV and NPV values. Overall agreement was high (75 percent); the sensitivity was 1.00, specificity was 0.74, the PPV and NPV were 0.11 and 1.00, respectively.

Correlations between the composite scores for the CELF-P and the PLS-3 ranged from 0.73 to 0.90. Correlations between the composite scores of the CELF-P and those of the WPPSI-R (i.e., Performance Score, Verbal Score, and Full Scale Score) ranged from 0.45 to 0.72. Correlations between the composite scores of the CELF-P and those of the DAS (i.e., Nonverbal Cluster, Verbal Cluster, and General Conceptual Ability) ranged from 0.53 to 0.70.

##### Content validity

Wiig et al. described the content of each subtest in terms of the specific syntactic and semantic skills measured.^61^ They did not provide an explicit model for the CELF-P, but instead stated that the model for the CELF-R served as a template for the CELF-P subtests and items.

#### Available Normative Data

Wiig et al. provided normative data for the CELF-P (Evidence Table 25).^61^ The standardization sample closely matched the US population with respect to geographic region, sex, mother's educational attainment, and race or ethnic group.

#### Applicability of CELF-P to Target Populations

Wiig et al. provided no guidance on the instrument's use with any of the populations of interest to the SSA.^61^ No individual in the standardization sample was diagnosed with a language disorder or a hearing deficit; all were described as "normal."

## Test of Language Development-Primary, 3^rd^ Edition

The Test of Language Development-Primary, Third Edition (TOLD-P:3), provides professionals with a well-constructed standardized test for assessing children's spoken language (Table 11).^69^

Table 11. Test of Language Development-Primary, 3rd edition (TOLD-P:3)

Authors | P.L. Newcomer and D.D. Hammill
Publisher | Pro-Ed 8700 Shoal Creek Boulevard Austin, TX 78757-6897 512-451-3246 http://www.proedinc.com/
Date of Publication | 1997
Ages | 4-0 through 8-11 years
Administration Time | 30 minutes to 1 hour for core subtests; additional 30 minutes for supplemental tests
Scores | Percentile ranks, age equivalents, and standard scores for core subtests: Picture Vocabulary, Relational Vocabulary, Oral Vocabulary, Grammatic Understanding, Sentence Imitation, and Grammatic Completion; for supplemental subtests: Word Discrimination, Phonemic Analysis, and Word Articulation; and for composites: Listening, Organizing, Speaking, Semantics, Syntax, and Spoken Language.
Normative Data Provided | Data provided at 6-month age intervals between 4-0 and 8-11 years based on standardization sample of 1,000 children from 28 states.
Components | Examiner's manual, picture book, profile/examiner record forms
Procedures | The examiner is seated beside the child at a table. Usually all the core subtests are administered in one session, but the test can be administered over several sessions for young or distractible children. Some items require verbal responses from the child and others require the child to point to appropriate pictures in the picture manual. All subtests are untimed, but the examiner encourages the child to work steadily. Testing begins with the first item in each subtest regardless of the child's age. For each of the core subtests, testing is terminated when the child misses five consecutive items. The examiner scores individual items according to instructions in the manual as each item is administered. The supplemental subtests, if administered, are given during a separate session from the core subtests to avoid child and examiner fatigue. The supplemental subtests are administered only to children less than 7 years of age, unless the child is having specific problems in phonological development.
Other | None
Earlier Versions | Test of Language Development (1977)^112^, Test of Language Development Primary (1982)^113^, Test of Language Development-Primary: 2^nd^ edition (1988)^114^

### Key Question No. 1

Newcomer and Hammill standardized the TOLD-P:3 using 1,000 English-speaking children, ages 4-0 through 8-11 years, in 28 states (Evidence Tables 26-30).^69^ Children with learning disabilities, speech-language disorders and delays, mental retardation, and other handicaps were purposively included to be able to provide reliability and validity information for these groups. They documented that the sample was representative with respect to race, sex, residence (urban or rural), family income, educational attainment of parents, and geographic region.

#### Reliability

Reports of the TOLD-I:3's reliability were available in the instrument manual.^69^ Fodness provides test-retest reliability data for the previous version (TOLD-P:2) (Evidence Table 27).^70^

##### Internal consistency reliability

Hammill and Newcomer reported Cronbach's alpha coefficients across age groups.^69^ Correlations (across age) for all subtests ranged from 0.80 to 0.91; for composites they ranged from 0.91 to 0.96. Overall score alphas ranged from 0.95 to 0.96 across age groups. They also reported coefficients by sex, race or ethnicity, and disability subgroups (including children with misarticulation, delayed speech and language problems, learning disabilities, mental retardation, and attention-deficit/hyperactivity disorder [ADHD]). The alphas for these subgroups ranged from 0.80 to 0.97 for subtests and composites.

##### Test-retest or intra-rater reliability

Evidence of test-retest or intra-rater reliability was available for both the TOLD-P:3^69^ and the TOLD-P:2.^70^ For the TOLD-P:3 correlations for subtests ranged from 0.77 to 0.90 and correlations for composites ranged from 0.82 to 0.92; only those for the Organizing and Spoken Language composites reached a level greater than 0.90.

Fodness reported correlations for Listening, Speaking, and overall performance composite scores all above 0.82, the level of reliability considered acceptable by the authors based on psychometric research literature.^70^ The correlations for the Semantic composite scores were below this level for all three age levels. Fodness suggested that the test-retest reliability of the Listening composite score was insufficiently reliable at age 8, and the Phonology composite score also was insufficiently reliable at ages 6 and 8.^70^ In the TOLD-P:3, Newcomer and Hammill revised all three of the subtests used to compute the Semantics composite score.^69^ The only composite score in the TOLD-P:3 unaffected by revisions compared to the TOLD-P:2 is the Syntax composite; the former does not include a Phonology composite score.

##### Inter-rater reliability

Newcomer and Hammill reported inter-rater correlations of 0.99 and higher, suggesting nearly perfect inter-rater reliability.^69^

#### Validity

Newcomer and Hammill provided evidence of content (including information on difficulty/discrimination, and test bias), construct, and concurrent validity (Evidence Table 28).^69^

##### Construct validity

Newcomer and Hammill extensively documented construct validity; all the evidence exceeds our threshold for acceptable evidence of construct validity.^69^ Additionally, they provided evidence of construct validity for specific disability groups, including speech and language problems, learning disabilities, mental retardation, and attention-deficit/hyperactivity disorder (ADHD).

First, they observed that mean raw scores were significantly correlated with age for each subtest (range of 0.50 to 0.62 for the six core subtests and 0.32 to 0.55 for the three supplemental subtests). Second, the mean standard scores on subtests for gender subgroups and race or ethnic subgroups were all within the standard error of measurement for each subtest, suggesting that test bias was minimal. Third, the rank order of the mean standard scores on TOLD-P:3 for disability subgroups was what the authors had predicted based on the degree of language disorder generally associated with each type of disability. A fourth type of evidence was that the core subtest raw scores were moderately intercorrelated, with values ranging from 0.37 to 0.59. Finally, the results of a factor analysis suggested that, as hypothesized, the six TOLD-P:3 subtests represented the domain measuring general spoken language ability.

##### Concurrent validity

Newcomer and Hammill compared TOLD-P:3 scores and Bankson Language Test -- Second Edition (BLT-2) scores.^69^ Only the TOLD-P:3 Word Articulation subtest failed to correlate with language measures, but this subtest was not used in calculating any of the TOLD-P:3 composite scores. Correlations between TOLD-P:3 subtests and BLT-2 composite scores ranged from 0.59 to 0.97; correlations between TOLD-P:3 and BLT-2 composites ranged from 0.73 to 0.95; correlations between total score was 0.89.

##### Content validity

Newcomer and Hammill provided extensive evidence of the TOLD-P:3's content validity, developing a conceptual model, testing item difficulty and discrimination, and employing item response theory to examine item bias.^69^ In doing so, they provide the most extensive evidence among the instruments we reviewed.

#### Available Normative Data

Newcomer and Hammill presented normative data for 6-month age groupings from 4-0 through 8-11 years (Evidence Table 29).^69^ The standardization sample closely matched the US population with respect to geographic region, sex, mother's educational attainment, family income, urban versus rural residence, race, ethnicity, and disability status. The standardization sample included sufficiently large (107 to 258) samples of children in each subgroup for which standardization data were reported.

#### Applicability of TOLD-P:3 to Target Populations

Newcomer and Hammill provided evidence of the applicability of the TOLD-P:3 to several of the targeted populations -- in particular, children with cognitive deficits, learning disabilities, and existing speech-language problems or delays (unlike the TOLD-I:3, the TOLD-P:3 manual does not present separate reliability data for children who are hard-of-hearing.)^69^

As indicated earlier, Newcomer and Hammill included targeted demographic groups differing in culture, race, and language abilities in the standardization sample. Children with speech-language delay, misarticulation, learning disabilities, mental retardation, and ADHD were included. Hammill and Newcomer reported Cronbach's coefficient alphas were similar for all subgroups (based on sex, racial and ethnic, and disability) and of the same magnitude as for the entire normative sample.^71^ Further, analyses of item bias indicated that a relatively small proportion of test items were potentially biased with respect to the subgroups examined. In addition, the intercorrelations between the subtest and composite scores were in the same range for demographic subgroups as for the entire normative sample. These results support the authors' position that the test is reliable and valid for each of these subgroups.

Newcomer and Hammill specifically indicated that the TOLD-P:3 should not be given to children who are "deaf" or who do not speak English.^69^ They also stated that the test should be administered only to children whose chronological ages are between 4-0 and 8-11 years because reliability and validity have not been established for any groups other than those included in the normative sample; alternatively, they suggest different instruments. Thus, mentally retarded children and/or adults not within this age group should not be evaluated using the TOLD-P:3.

### Key Question No. 2

We found no literature describing the predictive validity of the TOLD-P:3. Lewis et al. assessed the predictive validity of preschool TOLD-P:2 scores for school-age reading, language, and spelling skills in children identified with moderate to severe speech sound disorders as preschoolers.^72^ Preschool TOLD-P:2 scores predicted language scores, as measured by the CELF-R, and spelling scores.

They also evaluated the ability of the TOLD-P:2 Word Discrimination subtest and Semantic and Syntactic composite scores to predicting school-age impairments in language, reading, and spelling. The Word Discrimination subtest predicted spelling disorders; the Semantic composite predicted reading; and Syntax composite predicted all three types of disorders.

## Test of Language Development-Intermediate, 3^rd^ Edition

The Test of Language Development-Intermediate, 3^rd^ Edition (TOLD-I:3), measures the expressive and receptive language abilities of children and provide information about relative strengths and weaknesses (Table 12).^71^ We identified no evidence for Key Question No. 2 (predictive validity) for this instrument.

Table 12. Test of Language Development-Intermediate, 3rd Edition (TOLD-I:3)

Authors | D.D. Hammill and P.L. Newcomer
Publisher | Pro-Ed 8700 Shoal Creek Boulevard Austin, TX 78757-6897 512-451-3246 http://www.proedinc.com/
Date of Publication | 1997
Ages | 8-0 to 12-11 years
Administration Time | Approximately 1 hour
Scores | Percentile ranks, age equivalents, and standard scores for subtests: Sentence Combining, Picture Vocabulary, Word Ordering, Generals, Grammatic Comprehension and Malapropisms; and for composites: Listening, Speaking, Semantics, Syntax, and Spoken Language.
Normative Data Provided | Data provided at 6-month age intervals between 8-0 and 12-11 years based on standardization sample of 779 children from 23 states.
Components | Examiner's manual, picture book, profile/examiner record forms
Procedures | The examiner is seated beside the child at a table. Usually all the subtests are administered in one session, but the test can be administered over several sessions for immature or inattentive children. Most subtests require the child to listen and respond verbally to the examiner; the Picture Vocabulary subtest requires the child to listen and point to appropriate pictures in the picture manual. All subtests are untimed, but the examiner encourages the child to work steadily. Testing begins with the first item in each subtest regardless of the child's age. Testing is terminated when the child reaches the respective ceiling for each subtest according to the criteria provided in the manual. The examiner scores individual items according to instructions in the manual as each item is administered.
Other | Optional computerized scoring software available for Windows 3.1 and 95, Macintosh, and IBM DOS systems, providing menu-driven program for scoring test and generating report
Earlier Versions | The Test of Language Development -- Intermediate (1982)^113^, and The Test of Language Development -- Intermediate, 2^nd^ edition (1988)^114^

### Key Question No. 1

Hammill and Newcomer standardized the TOLD-I:3 with 779 English-speaking children, ages 8-0 through 12-11 years, in 23 states (Evidence Tables 31-34).^71^ Children with learning disabilities, speech-language disorders, mental retardation, hearing impairments, and other handicaps were purposively included to be able to provide reliability and validity information for these groups. Additionally, they documented that the sample was representative with respect to race, sex, residence (urban or rural), family income, educational attainment of parents, and geographic region.

#### Reliability

Reports of the TOLD-I:3's reliability were available only in the instrument manual.^71^ Fodness provided test-retest reliability data for the previous version (TOLD-I:2) (Evidence Table 32).^70^

##### Internal consistency reliability

Hammill and Newcomer reported Cronbach's coefficient alphas, ranging across age groups.^71^ Correlations for subtest scores ranged from 0.89 to 0.97; for composite scores alphas ranged from 0.92 to 0.96. They also reported coefficient alphas by sex subgroups, race and ethnic subgroups, and disability subgroups (including children with speech-language problems, learning disabilities, mental retardation, ADHD, and hearing impairment); these alphas ranged from 0.70 to 0.97.

##### Test-retest or intra-rater reliability

Evidence of test-retest or intra-rater reliability was available for both the TOLD-I:3^71^ and the TOLD-I:2.^70^ Hammill and Newcomer reported correlations for subtests ranging from 0.83 to 0.93; correlations for composites ranged from 0.94 to 0.96, suggesting an acceptable level of test-retest reliability.^71^ Fodness et al. reported correlations for the TOLD-I:2 ranging from 0.87 to 0.97, with those for older children (12-year-olds) at the lower end of the acceptable range.^70^

##### Inter-rater reliability

Hammill and Newcomer reported inter-rater correlations of 0.94 and higher, thus meeting our threshold of acceptable inter-rater reliability.^71^

#### Validity

Hammill and Newcomer provided data on content (including information on difficulty/discrimination, and test bias), construct, and concurrent validity for the TOLD-I:3 (Evidence Table 33).^71^

##### Construct validity

Hammill and Newcomer provided extensive documentation of construct validity; all of the evidence exceeded our threshold for acceptable evidence of construct validity.^71^ Additionally, they provided evidence of construct validity for specific disability groups, including speech and language problems, learning disabilities, mental retardation, and ADHD.

First, they observed that mean raw scores increased with each subsequent age group and were correlated with age for each subtest (range = 0.32 to 0.47). Second, mean standard scores for disability subgroups were significantly lower than those for the overall normative group, indicating that the TOLD-I:3 differentiated between groups with differing language abilities. Third, the subtest raw scores were significantly and moderately correlated, with values ranging from 0.38 to 0.63 (median = 0.54). Correlations were similar for demographic subgroups based on sex, race and ethnicity, and disability status, suggesting construct validity for the subgroups. Fourth, they reported that TOLD-I:3 performance correlated significantly with academic achievement in verbal thinking, speech, reading, and mathematics (but not writing), as measured by the Comprehensive Scales of Student Abilities. (However, the manual provides no reference to this scale.) Finally, using a factor analysis the authors suggested, as hypothesized, that the six TOLD-I:3 subtests represent the domain measuring general spoken language ability 88 percent of total variance explained by single factor.

##### Concurrent validity

Hammill and Newcomer provided evidence of the TOLD-I:3's concurrent validity, comparing TOLD-I:3 subtest and composite scores with composite scores from the Test of Adolescent and Adult Language -- Third Edition^73^ (TOAL-3). They reasoned that concurrent validity for the TOLD-I:3 would be demonstrated if the scores correlated with the subtest and composite scores from the TOAL-3 that measure spoken language. The correlations were high, ranging from 0.58 to 0.86 for TOLD-I:3 subtests and 0.74 to 0.88 for composite scores; the correlation between total scores was 0.85.

##### Content validity

Hammill and Newcomer comprehensively documented evidence of the TOLD-I:3's content validity, developing a conceptual model, surveying experts in the field, testing item difficulty and discrimination, and employing item response theory to examine item bias.^71^ In doing so, they provide the most extensive evidence among the instruments we reviewed.

#### Available Normative Data

Hammill and Newcomer presented normative data for the TOLD-I:3 for children ages 8-0 through 12-11 years (Evidence Table 34).^71^ They documented that the standardization sample closely matched the US population with respect to geographic region, sex, mother's educational attainment, family income, urban versus rural residence, race, ethnicity, and disability status. The standardization sample included sufficiently large (104 to 201) samples of children in each subgroup for which standardization data were reported.

#### Applicability of TOLD-I:3 to Target Populations

As described earlier for the TOLD-P:3, Hammill and Newcomer provided evidence of the applicability for children who are hard of hearing but not deaf or who have cognitive deficits, learning disabilities, and speech and language problems.^71^ They purposively included targeted demographic groups differing in culture, race, and language abilities in the standardization sample. Children with speech-language problems, learning disabilities, mental retardation, ADHD, and who were hard of hearing were included and reliability data provided for them. They specified that the test should not be used with children who are deaf or who do not speak English.

## Preschool Language Scale, 3^rd^ Edition (English)

The Preschool Language Scale, 3^rd^ Edition (PLS-3) is designed to evaluate the receptive and expressive language skills, as well as precursors of these skills, in infants and young children (Table 13).^74^ We identified no evidence pertaining to Key Question No. 2 (predictive validity) for this instrument.

Table 13. Preschool Language Scale, 3rd Edition (PLS-3)

Authors | I.L. Zimmerman, V.G. Steiner, R.E. Pond
Publisher | The Psychological Corporation P.O. Box 839954 San Antonio, TX 78283-3954 1-800-228-0752 http://www.psychcorp.com/
Date of Publication | 1992
Ages | Birth through 6-11 years
Administration Time | 15-30 minutes
Scores | Standard scores, percentile ranks, and age equivalents for Auditory Comprehension, Expressive Communication, and Total Language Scores
Normative Data Provided | By age (13 different age intervals), compared to general population sample
Components | Examiner's manual with picture and reading plates, record forms, toys, and objects.
Procedures | Examiner begins testing on items approximately one year below child's chronological age or expected language age. The basal is then established. Testing continues until ceiling is achieved. Behaviors are elicited as responses to pictures, objects, or verbal stimuli, or a combination. Responses are scored during test administration according to criteria provided in the examiner's manual.
Other | Supplemental measures include Articulation Screener, Language Sample Checklist, and Family Information and Suggestions Form.
Earlier Versions | Preschool Language Scale (1969),^115^ Preschool Language Scale-Revised Edition (1979)^79^

### Key Question No. 1

Zimmerman et al. standardized the PLS-3 using 1,200 English-speaking children, ages 2 weeks through 6-11 years, in 40 states and the District of Columbia (Evidence Tables 35-38).^74^ They excluded children previously identified as language disordered or receiving language remediation services following the diagnosis of a language disorder and those who had difficulties at birth, including those who did not go home from the hospital with the mother, who had a hospital stay of more than 1 week, or a significant birth or genetic defect. They documented that the standardization sample closely matched the US population with respect to geographic region, sex, mother's educational attainment, and race or ethnic group.

#### Reliability

Zimmerman et al. reported data for internal consistency, test-retest, and inter-rater reliability (Evidence Table 36).^74^ Internal consistency reliability data are reported separately for each age interval for which standard scores are provided.

##### Internal consistency reliability

Zimmerman et al. reported Cronbach's coefficient alphas of 0.47 to 0.88 for the Auditory Comprehension subscale, 0.68 through 0.90 for the Expressive Communication subscale, and 0.74 to 0.94 for the Total Language score.^74^ Alphas at the lower ends of these ranges tended to be for children less than 1 year of age, suggesting unacceptable reliability for these groups.

##### Test-retest or intra-rater reliability

Zimmerman et al. reported correlation coefficients for the Auditory Comprehension subscale ranging from 0.89 to 0.90, 0.82 to 0.92 for the Expressive Communication subscale, and 0.91 to 0.94 for the Total Language score.^74^ Test-retest reliability results are limited in that no children younger than 3 years of age were included; thus, the PLS-3's test-retest reliability for measuring the language performance of younger children is unknown.

##### Inter-rater reliability

Zimmerman et al. reported inter-rater reliability of 0.98 for the total score; they did not present data for inter-rater reliability for the two subscales.^74^ Like test-retest reliability discussed earlier, the evidence for the PLS-3's inter-rater reliability was limited to children 3 years of age and older.

#### Validity

Reports of validity data were available for the both the PLS-3^74^ and the previous version of the instrument (Evidence Table 37).^75,76^

##### Construct validity

Evidence of construct validity was available for both the PLS-3^74^ and the PLS-R.^75, 76^ Zimmerman et al. examined the correlation between the Auditory Comprehension and the Expressive Communication subscales.^74^ Across all age ranges, the correlation was 0.64, indicating that the two subscales share considerable variance, but also each measured something unique. They also compared how well the PLS-3 discriminated between 3-, 4-, and 5-year-old children with identified language disorders and those without. Using a cut-off score of 1.5 standard deviations below the mean to determine the presence of language disorder from the PLS-3 performance, Zimmerman et al. reported the overall level of agreement ranging from 66 percent to 80 percent; EPC staff calculated sensitivity, specificity, and PPV and NPV for each of the three groups.^74^ Sensitivity ranged from 0.91 to 1.00, specificity from 0.60 to 0.72, PPV from 0.36 to 0.61, and NPV from 0.96 to 1.00. For each age group, the primary type of error was a "false negative" (i.e., children diagnosed as language disordered using the criteria of their respective states but who were not classified as language disordered based on their PLS-3 performance).

Berryman presented evidence related to the construct validity of the PLS-R for a sample of 672 children, identifying five test items that appeared to have questionable age-level placements and an age grouping that yielded lower passing rates than the next older age group.^76^ To address these issues, Zimmerman et al. conducted field testing with 451 children, deleting and revising questions and reordering by difficulty within and across age levels.^74^ Berryman also correlated PLS-R auditory comprehension and verbal ability (r = 0.72); McLoughlin and Gullo reported a correlation of 0.58 between these subscales.^75^ The difference in results between these two studies may be attributed to the composition of the two study samples.

##### Concurrent validity

Evidence of concurrent validity is available for both the PLS-3^74^ and the PLS-R.^75, 77^

Zimmerman et al. conducted three evaluations of concurrent validity for the PLS-3 (results are reported in the instrument manual).^74^ They compared scores from the PLS-3 and the Denver II;^78^ all children were given a "normal" rating based on the Denver II results and fell within 1.5 standard deviation of the mean on the PLS-3. They also compared PLS-3 scores to PLS-R scores for a group of 3-year-olds.^79^ Correlations were 0.66 for comprehension subscales, 0.86 for expressive subscales, and 0.88 for total scores. Zimmerman et al. also compared the PLS-3 and the CELF-R^62^ in children aged 5-0 years to 6-11 years. They reported a correlation of 0.69 for comprehension subscales, 0.75 for expressive subscales, and 0.82 for total scores.

McLoughlin and Gullo examined intercorrelations of the PLS-R, the Test of Early Language Development (TELD),^80^ and the Peabody Picture Vocabulary Test-Revised (PPVT-R).^75, 81^ The correlation between PPVT-R and PLS-R total scores was 0.73; that between the TELD and the PLS-R total scores was 0.52.

Pecyna Rhyner and Bracken reported on moderate intercorrelations among PLS-R and the Bracken Basic Concept Scale^82^ (r = 0.40) and the Slossen Intelligence Test (SIT)^65^ (r = 0.35).^77^ Taken together, these studies suggest that the PLS-3 has acceptable concurrent validity.

##### Content validity

Zimmerman et al. document content validity by describing how the instrument samples behaviors related to attention, semantics (vocabulary and concepts), structure (morphology and syntax), integrative thinking skills, vocal development, and social communication.^74^ They indicated that the content of the PLS-3 test items is based on the literature on typical language development of young children.

#### Available Normative Data

Zimmerman et al. provided normative data by age group for children from birth through 6-11 years of age (Evidence Table 38).^74^ The standardization sample, while representative of the US population, included only 48 to 51 children in each of the four age subgroups between birth and 1 year; this may explain some of the lower reliability values for these groups.

#### Applicability of PLS-3 to Target Populations

Zimmerman et al. provided little guidance on the PLS-3's applicability to the populations of interest to the SSA.^74^ They indicated that an examiner may alter PLS-3 administration of the PLS-3 for use with children who have severe developmental delays, severe physical impairments, or hearing impairments, but they also indicate that the norms may not be applied to those children. They specifically excluded children with language disorders or birth conditions that might predispose them to cognitive impairments; thus, no data are available on the applicability of the instrument with these populations. As for non-English-speaking children, no translations or language-specific version are available other than the PLS-3 Spanish Edition, which is described in the next section.

One study evaluated the use of the PLS-3 in Native American children.^83^ Long found that standard scores for the Native American children did not differ significantly from the US population norms, but 5-year-old children attained significantly lower standardized scores than younger children. From her data, Long concluded that the PLS-3 is appropriate for use with the younger Native American children represented in her sample, but that for 5-year-old Native American children, a performance below the normal range may not indicate a language disorder or delay.

## Preschool Language Scale, 3^rd^ Edition (Spanish)

The Preschool Language Scale-3, Spanish Edition(PLS-3Sp) is an adaptation of the PLS-3 (Table 14).^84^ We identified no evidence pertaining to test-retest or intra-rater reliability, concurrent validity, current validity or predictive validity (Key Question No. 2) for this instrument.

Table 14. Preschool Language Scale-3rd Edition (Spanish) (PLS-3Sp)

Authors | I.L. Zimmerman, V.G. Steiner, and R.E. Pond
Publisher | The Psychological Corporation 555 Academic Court San Antonio, TX 78204 Voice 1-800-872-1726 Fax 1-800-232-1223 http://www.psychcorp.com/
Date of Publication | 1993
Ages | Birth through 6-11 years
Administration Time | 20 to 30 minutes
Scores | Standard scores, percentile ranks, and age equivalents for Auditory Comprehension, Expressive Communication, and Total Language Scores (based on standardization sample used for PLS-3)
Normative Data Provided | Scores are determined based on standardization sample for PLS-3 (English version). These are provided by age (13 different age intervals) based on English-speaking U.S. population sample of 1,200 children. Spanish Administration Directions manual includes summary of data from 181 Spanish-speaking children in the United States, comparing ages at which children responded correctly to tasks on PLS-3 English and Spanish editions.
Components | Spanish administration directions, record forms, PLS-3 picture book, PLS-3 examiner's manual.
Procedures | Examiner begins testing on items approximately one year below child's chronological age of expected language age. The basal is established. Testing continues until ceiling is achieved. Behaviors are elicited as responses to pictures, objects, or verbal stimuli, or a combination. Responses are scored during test administration according to criteria provided in the Spanish Administration Directions manual.
Other | None
Earlier Versions | None

### Key Question No. 1

Zimmerman et al. standardized the PLS-3Sp using 181 Spanish-speaking children ages 0-0 to 6-11 years from six states and Puerto Rico (Evidence Tables 39-42).^84^ Although the children spoke a variety of dialects, the authors indicated that the sample was not representative of Hispanic children in the United States.

#### Reliability

Zimmerman et al. presented data only for internal consistency reliability (Evidence Table 40).^84^

##### Internal consistency reliability

Zimmerman et al. reported Cronbach's coefficient alphas ranging from 0.38 to 0.94 for the Auditory Comprehension subscale, 0.33 to 0.92 for the Expressive Communication subscale, and 0.39 to 0.95 for the Total Language scale.^84^ The evidence is limited by the small sample sizes (i.e., n = 10 to 30) employed for children of different ages.

#### Validity

Zimmerman et al. provided only construct validity data (Evidence Table 41).^84^

##### Construct validity

Zimmerman et al. provided data on the age at which 50 percent, 75 percent, and 90 percent of English-speaking and Spanish-speaking children passed each item on the PLS-3 and PLS-3Sp.^74, 84^ They concluded that Spanish-speaking children acquired the language skills targeted by the test, but the timing and sequence of skill acquisition appeared to differ somewhat from children who are English-speaking.

#### Available Normative Data

Normative data from the PLS-3 were used to determine standardized scores for the PLS-3Sp (Evidence Table 42). Zimmerman et al. specified that these norms must be interpreted with caution because they were not derived from representative samples of Spanish-speaking children.^84^

#### Applicability of PLS-3Sp to Target Populations

Although the PLS-3Sp was designed for use with Spanish-speaking children, the authors advised caution when interpreting the results, given that they were not derived from a representative sample of Spanish-speaking children. Zimmerman et al. specifically indicated that test subjects must not be deaf; thus, the PLS-3Sp is unlikely to be applicable to Spanish-speaking children with hearing impairments or who are hard of hearing.^84^ They also provided no guidance on use with children with learning disabilities or mental retardation.

## Test of Pragmatic Language

The Test of Pragmatic Language (TOPL) provides an in-depth screening of the effectiveness and appropriateness of a student's pragmatic or social language skills (Table 15).^85^ We found no evidence pertaining to test-retest or intra-rater reliability or predictive validity (Key Question No. 2) for this instrument.

Table 15. Test of Pragmatic Language (TOPL)

Author | D. Phelps-Terasaki and T. Phelps-Gunn
Publisher | Pro-Ed 8700 Shoal Creek Boulevard Austin, TX 78757-6897 512-451-3246 http://www.proedinc.com/
Date of Publication | 1992
Ages | Kindergarten (age 5-0 years) through high school age, and with adult remedial populations, aphasics, and English-as-a-second language (ESL) populations.
Ages | Specifically designed to be used with children and adolescents with: learning disabilities, language delays or disorders, reading difficulties; in ESL programs in family therapy or substance abuse treatment programs; and adults with learning disabilities, aphasia, or in ESL programs.
Administration Time | 30-45 minutes
Scores | Raw scores, percentile ranks, the TOPL quotient, and age equivalents
Normative Data Provided | By age (6-month intervals from 5-0 through 13-11 years) based on examinees of persons purchasing tests from Pro-Ed and individuals who had assisted in the development of other Pro-Ed tests. Normative sample is representative of school-age children.
Components | Examiner's manual, the TOPL Picture Book, Profile/Examiner Record Form.
Procedures | Examiner reads the stimulus prompt (which may or may not require the examiner to show a picture) as written on the Record Form. The examiner scores all responses as 1 (correct) or 0 (incorrect). The Record Form provides examples of scoreable responses and examples of correct and incorrect responses. The total number of correct responses is calculated by summing across all items. This total then is used to obtain the standard score and percentile. The session may be audiotaped and transcribed/scored later.
Other | None
Earlier Versions | None

### Key Question No. 1

Phelps-Terasaki and Phelps-Gunn standardized the TOPL using a sample of 1,096 children from 24 states and one Canadian province (Evidence Tables 44-46).^85^ They documented that it was representative with respect to gender, residence (urban or rural), race, geographic region, and ethnicity of US children ages 5 through 13.

#### Reliability

The instrument manual reported data on only internal consistency and inter-rater reliability (Evidence Table 44).^85^

##### Internal consistency reliability

Cronbach's coefficient alpha ranged from 0.74 to 0.89 (overall = 0.82) across age groups. Alphas for all groups except children 6 years of age exceeded the "relaxed" threshold.

##### Inter-rater reliability

Phelps-Terasaki and Phelps-Gunn reported inter-rater reliability of 0.99.^85^

#### Validity

Reports of validity data were available in the TOPL manual (Evidence Table 45).^85^

##### Construct validity

Phelps-Terasaki and Phelps-Gunn employed principles of item response theory and tested a priori hypotheses based on common understanding of pragmatic language development to provide evidence of construct validity.^85^ Reported item discrimination coefficients fell within an acceptable range (ranging from 0.22 to 0.49) as did item difficulty for four of nine age groups, with statistics for other groups exceeding the acceptable range by only a small amount. TOPL scores increased with age as expected and can differentiate (i.e., is responsive) between children with and without language disorders. The available evidence suggests acceptable construct validity.

##### Concurrent validity

Phelps-Terasaki and Phelps-Gunn cited the results of two studies conducted by other researchers as evidence of concurrent validity language for the TOPL.^85-87^ The primary goal of these studies was to evaluate the validity of other instruments, not to validate the TOPL; thus, they were not included in this review. Both studies reported high correlations between the TOPL and other language measures (r = 0.32 [mathematics] to 0.70 [language]^86^) and general mental ability (r = 0.68).^87^ They also correlated teacher ratings with TOPL scores (r = 0.82), providing additional good evidence of concurrent validity. The available evidence suggests acceptable concurrent validity.

##### Content validity

Phelps-Terasaki and Phelps-Gunn based the instrument on a conceptual model drawn from the literature on pragmatic models of language development.^85^ They employed modern psychometric theory to select items for the instrument.

#### Available Normative Data

Phelps-Terasaki and Phelps-Gunn provided normative data and documented that the standardization sample closely matched the sex, residence (urban or rural), race and ethnicity, and geographic region of US children (Evidence Table 46).^85^

## Assessment of Intelligibility of Dysarthric Speech

The Assessment of Intelligibility of Dysarthric Speech (AIDS) measures intelligibility and speaking rate in children and adults with dysarthria, quantifying single word and sentence intelligibility and speaking rate (Table 16).^23^

Table 16. Assessment of Intelligibility of Dysarthric Speech (AIDS)

Author | K.M. Yorkston and D.R. Beukelman
Publisher | Pro-Ed 8700 Shoal Creek Boulevard Austin, TX 78757-6897 512-451-3246 http://www.proedinc.com/
Date of Publication | 1984
Ages | Not specified
Administration Time | Not specified
Scores | Percentage of words correct for single word task, speaking rate (words per minute), rate of intelligible speech (number of intelligible words per minute), and communication efficiency ratio (rate of intelligibility of the dysarthric individual compared to that of normal speakers) for sentence intelligibility task
Normative Data Provided | Efficiency ratio reported for comparison with normals
Components | Examiner's manual and picture book. A computer version, which includes a clinician manual and two computer disks, is also available.
Procedures | In the single-word task, the dysarthric individual is audiotaped as he or she produces a series of 50 single words selected randomly from a master word pool. The examiner or listener judges the sample in one of two response formats -- multiple choice or transcription. In the multiple choice format, the listener selects the word that has been spoken from a list of 12 similar sounding words. In the transcription format, the listener writes down that word that has been spoken. In both formats, the results are reported as the percentage correct.
Procedures | In the Sentence task, the dysarthric individual is audiotaped as he or she produces series of sentences (5 to 15 words long for a total of 220 words) selected randomly from a master pool of 100 sentences for each sentence length. The judging format is word-by-word transcription. The results are reported in percentage correct.
Procedures | The speaking rate (words per minute), rate of intelligible speech (number of intelligible words per minute), and communication efficiency ratio (rate of intelligibility of the dysarthric individual compared to that of normal speakers) are calculated from the Sentence Intelligibility task.
Other | None
Earlier Versions | None

### Key Question No. 1

Yorkston and Beukelman standardized the AIDS using a small sample (n = 12) of dysarthric speakers (Evidence Tables 47-49); they did not provide demographic information about the subjects.^23^ We identified no evidence on internal consistency, construct validity, concurrent validity or predictive validity (Key Question No. 2).

#### Reliability

Yorkston and Beukelman provided data on only the intra- and inter-rater reliability of the AIDS (Evidence Table 48).^23^

##### Test-retest or intra-rater reliability

Yorkston and Beukelman reported correlations for the single-word task, multiple choice, and transcription formats of 0.90 and 0.87, respectively.^23^ They also reported correlations for intelligibility percent of 0.96 to 0.99 and 0.99 for rate of intelligible speech. With the exception of the single word transcription format, the AIDS met our threshold for acceptable test-retest or intra-rater reliability.

##### Inter-rater reliability

Yorkston and Beukelman reported correlations for single-word intelligibility ranging from 0.88 to 0.99, depending upon the scoring method; for sentences, correlations ranged from 0.93 to 0.99 for intelligibility and 0.99 for rate of intelligible speech.^23^ Like the evidence for test-retest or intra-rater reliability, only the single-word transcription format did not meet our threshold for acceptable intra-rater reliability.

#### Validity

Yorkston and Beukelman reported only content validity data (Evidence Table 49). No data were reported for either construct or concurrent validity.^23^

##### Content validity

Yorkston and Beukelman argued that measurement of intelligibility of dysarthric speech has face validity: "the more understandable the speaker, the better able he is to function in communicative settings."^23^ They stated that intelligibility measures are easily communicated to family members and members of the rehabilitation team and can be easily understood.

#### Available Normative Data

Normative data per se were not available for the AIDS (Evidence Table 50). Instead, Yorkston and Beukelman provide an efficiency ratio (for comparison with "normal speech") derived from 20 subjects whose characteristics were not reported.^23^

## Dysarthria Examination Battery

The Dysarthria Examination Battery (DEB) evaluates dysarthria in adults and children (Table 17).^88^ Developed and implemented for routine clinical use at the University of Arkansas Medical Center, the DEB takes an anatomic-physiological approach to evaluating the function of five speech processes -- respiration, phonation, resonation, articulation, and prosody. We identified no evidence on internal consistency, reliability, concurrent validity, content validity, normative data or predictive validity (Key Question No. 2).

Table 17. Dysarthria Examination Battery (DEB)

Authors | S.S. Drummond
Publisher | Communication Skill Builders The Psychological Corporation 555 Academic Court San Antonio, TX 78204 Voice 1-800-872-1726 Fax 1-800-232-1223 http://www.psychcorp.com
Date of Publication | 1993
Ages | Adults and children (ages not specified, none of validation studies performed with children)
Administration Time | Approximately 1 hour
Scores | Provides thresholds for abnormality for each of the 21 quantitative tasks and 15 rating scale tasks (Table 3.3). Thresholds for abnormality for the quantitatively scored tasks are based on the literature and on data on administration to 62 dysarthric subjects. For rating scale items, responses of "2" through "5" are considered abnormal. The total number of tasks scored as abnormal is used to determine the severity and recommended treatment for dysarthria (Table 3.4). Percent measures also provided to determine severity/recommended treatment in the event that fewer than 36 tasks are administered.
Normative Data Provided | None
Components | Instructions for administration, examiner's manual, stimulus cards, scoring form. Requires the use of a stopwatch, audiotape recorder, dry spirometer, flashlight, tongue depressor, laryngeal mirror, bite block, swab and speech analysis equipment and software.
Procedures | The examiner administers the 23 tasks as described in the instrument manual, using any additional equipment required. The examiner records values for quantitative tasks and compares them to the norms described in the manual. Rating scale tasks are rated on a scale from 1 (normal) to 5 (severe abnormality according to task). The total number of abnormal performances on the 23 tasks in cumulated and compared to Table 3.4 in manual to determine severity and for treatment recommendations. Rating scale tasks may be audiotaped for later scoring.
Other | None
Earlier Versions | Three unpublished versions

### Key Question No. 1

Drummond standardized the DEB using 20 men and women who were either "mildly" dysarthric or normal (nondysarthric and not brain-damaged) and treated in a university medical center clinic (Evidence Tables 51-53).^88^ Additionally, she used data from 34 or 38 individuals described in three other studies to assess reliability and validity (determining the actual number of individuals with the information given in the other three studies is difficult). No information was provided with which to assess the generalizability of results to other dysarthric individuals.

#### Reliability

Reliability data are available only in the instrument manual; the manual briefly describes data presented at a conference, as a thesis, and in several studies, which all had been excluded from review based on small sample sizes. Reliability data (Evidence Table 52) are reported for intra- and inter-rater reliability only.

##### Test-retest or intra-rater reliability

Drummond reported mean correlations (across the measures) and examiner experience ranging from 0.67 to 0.81.^88^ Inexperienced examiners had lower intra-rater reliability with correlations ranging from 0.67 to 0.69. The evidence did not meet our threshold for acceptable test-retest or intra-rater reliability.

##### Inter-rater reliability

Drummond reported mean correlations ranging from 0.61 (nasality) to 0.98 (lingual lateralization), with a mean correlation of 0.90.^88^ Correlations generally were lower for inexperienced raters. This evidence did not meet our threshold for acceptable inter-rater reliability.

#### Validity

Drummond reported construct validity data only (Evidence Table 53).^88^

##### Construct validity

Drummond combined the results from her standardization sample with data from three studies described very briefly in the manual; little information was provided on the design of these studies and none was published in the peer-reviewed literature. She offered no statistical data to support her conclusion that the instrument has construct validity.

## Stuttering Severity Instrument for Children and Adults, 3^rd^ Edition

The Stuttering Severity Instrument for Children and Adults, 3^rd^ Edition (SSI-3) provides an objective description of stuttering severity in children and adults (Table 18).^89^ We identified no evidence for this instrument on internal consistency reliability, content validity or predictive validity (Key Question No. 2).

Table 18. Stuttering Severity Instrument, 3rd Edition (SSI-3)

Author | G.D. Riley
Publisher | Pro-Ed 8700 Shoal Creek Boulevard Austin, TX 78757-6897 512-451-3246 http://www.proedinc.com/
Date of Publication | 1994
Ages | 2 years, 10 months through adult
Administration Time | Not specified
Scores | Percentile ranks
Normative Data Provided | By age (three different age intervals) based on clinical sample of stutterers
Components | Examiner's manual with picture and reading plates, record forms.
Procedures | Examiner elicits at least two speech samples from individual consisting of at least 200 syllables per sample. One sample is recorded at home if possible. For individuals with reading level at 3^rd^ grade or above, one sample is elicited via reading. Samples are audiotaped or videotaped for later analysis. Examiner computes percentage of syllables stuttered and mean duration of three longest stuttering episodes. In addition, examiner rates physical concomitants of stuttering.
Other | Adjectives describing stuttering severity with different percentile scores
Earlier Versions | Stuttering Severity Instrument for Children and Adults (1972);^116^ Stuttering Severity Instrument for Children and Adults, Revised (1981)^91^

### Key Question No. 1

Riley standardized the SSI-3 using 271 children and adults (ages 2 to 17+) from California (Evidence Tables 54-57).^89^ Subjects under age 8 had no prior treatment for stuttering whereas most of those older than 8 had received treatment. He made no attempt to assess whether the sample was representative of US children and adults who stutter. Thus, the results he reported may not be generalizable to individuals with characteristics different from the standardization sample.

#### Reliability

Reports of reliability are available only in the instrument manual (Evidence Table 55).^89^

##### Test-retest or intra-rater reliability

Riley evaluated intra-rater reliability, reporting only percentage agreement ranging from 72 percent to 96 percent depending upon the parameter measured and the group of judges.^89^ Thus, the SSI-3 did not meet our threshold for acceptable test-retest or intra-rater reliability.

##### Inter-rater reliability

Riley evaluated inter-rater reliability, reporting percentage agreement between raters that range from 81 percent to 96 percent depending upon the parameter measured and the group of judges.^89^ These data did not meet our criterion for acceptable inter-rater reliability.

#### Validity

Riley reported data on the SSI-3's construct and concurrent validity (Evidence Table 56).^89^

##### Construct validity

Riley tested hypotheses that duration and physical concomitant scores would increase with age and that frequency would decrease with age.^89^ The correlations (all significant at p < 0.01) behaved as hypothesized; duration correlations increased from 0.73 to 0.77 and physical concomitant score correlations increased from 0.68 to 0.77. Frequency score correlations declined from 0.83 to 0.74. This evidence met our criterion for acceptable construct validity.

##### Concurrent validity

Riley provided indirect evidence of concurrent validity by comparing correlations between the SSI-3 total overall score and the SSI-3 frequency score (r = 0.74 to 0.83) and to the correlation reported by Yaruss and Conture (1992) (r = 0.072), who compared the SSI-Revised Edition to the Stuttering Prediction Instrument.^89-91^

#### Available Normative Data

Riley reported limited normative data for the SSI-3 (Evidence Table 57). These norms were derived from a relatively small, geographically similar sample, and Riley made no comparison between the standardization sample and the stuttering population in the United States. Thus, the results from the standardization and the resulting norms may not be generalizable to US children and adults who stutter.^89^

## Goldman-Fristoe Test of Articulation, 2^nd^ Edition

The Goldman-Fristoe Test of Articulation, 2^nd^ Edition (GFTA-2) evaluates an individual's articulation of the consonant sounds of the Standard American English (Table 19).^92^ Applications include screening, assessment of the severity of articulation deficit, evaluation of error patterns, and monitoring of growth or progress.

Table 19. Goldman-Fristoe Test of Articulation, 2nd Edition (GFTA-2)

Author | R. Goldman and M. Fristoe
Publisher | American Guidance Services, Inc. 4201 Woodland Road Circle Pines, MN, 55014-1796 800-328-2560 http://www.agsnet.com
Date of Publication | 2000
Ages | Ages 2-0 through 21-11 years
Administration Time | 5-15 minutes
Scores | Standard scores with 90 percent and 95 percent confidence intervals, percentile ranks, and test-age equivalents
Normative Data Provided | By age (1-month intervals from ages 2-0 through 21-11 years) and gender based on a large national sample of children for Sounds-in-Words subtest only. Normative sample is representative of gender, race/ethnicity, geographic region, socioeconomic status, and special education.
Components | Examiner's manual, easel with 43 GFTA-2 picture plates, and response form.
Procedures | During the Sounds-in-Words subtest, the examiner elicits sounds as part of words using the picture plates and the question "what is it?" Examiner records whether the child produced the sound correctly incorrectly, or did not produced the sound at all (Level 1 testing); or child substituted another sounds, omitted the sound, distorted the sound, or added a sound (Level 2 testing). The raw score is the total number of articulation errors. Raw scores are converted to standard scores with 90 percent and 95 percent confidence intervals, percentile ranks, and test-age equivalents using tables in the manual.
Procedures | During the Sounds-in-Sentences subtest, the examiner reads aloud two picture-based stories. The examinee then retells each story using the picture plates, which illustrate the gist of the story and target words. The recording procedure is similar to that for the Sounds-in-Words subtest and the results are to be compared to those from the Sounds-in-Words subtest. No score is calculated.
Procedures | During the Stimulability subtest, the examiner uses a set of picture plates in the easel and asks the examinee to watch the examiner's mouth and to listen carefully as the examiner says a syllable, word, or sentence (in that order). The examiner tests only those sounds that were misarticulated during the Sounds-in-Words and/or Sounds-in Sentences subtests and only in the position in which the misarticulation occurred.
Other | None
Earlier Versions | None

### Key Question No. 1

Goldman and Fristoe standardized the GFTA-2 using 2,350 children and adolescents ages 2 through 21 years (Evidence Tables 58-62).^92^ This sample closely matches the US population with respect to sex, race or ethnic group, geographic region, and mother's education. Additionally, they included representative proportions of students enrolled in special education under different categories of eligibility.

#### Reliability

Reports of reliability are available for the GFTA-2 and the original version of the instrument (Evidence Table 59).^92, 93^ Goldman and Fristoe reported reliability data only for the GFTA-2 Sounds-in-Words subtest.

##### Internal consistency reliability

Cronbach's coefficient alphas ranged from 0.92 to 0.98 (median = 0.96) for females and 0.85 to 0.96 (median = 0.94) for males. With the exception of one or two age groups for boys, the alphas met our "strict" criterion for internal consistency reliability.

##### Test-retest or intra-rater reliability

Goldman and Fristoe reported percentage agreement (rather than Cohen's Kappa or correlations) for the presence of errors in children age 4 through 7 years.^92^ The median agreement was 98 percent, ranging from 89 percent to 100 percent for initial position, 79 percent to 100 percent for medial position, and 91 percent to 100 percent for final position. Because they did not use appropriate statistics to measure test-retest reliability, the evidence did not meet our criterion.

##### Inter-rater reliability

As reported earlier for test-retest reliability, Goldman and Fristoe reported inter-rater reliability as percentage agreement.^92^ The median percentage agreement was 93 percent (range = 63 percent to 100 percent) on initial sounds, 90 percent (range = 73 percent to 100 percent) on medial sounds, and 90 percent (range = 73 percent to 100 percent) on final sounds.

Two studies reported inter-rater reliability for the original GFTA.^72, 93^ Seymour and Seymour reported inter-rater reliability for black and white children in Headstart programs; inter-rater reliability surpassed 0.90, but they did not indicate what statistic was used to report reliability (i.e., whether the statistic reflected percentage of agreement or inter-judge correlation).^93^ Lewis et al. reported inter-rater reliability for children with moderate to severe speech disorders who were enrolled in speech-language therapy; they reported a mean percentage agreement of more than 95 percent for the transcribed responses.^72^

None of the studies identified employed appropriate statistics to measure inter-rater reliability; thus, the evidence did not meet our criterion for inter-rater reliability.

#### Validity

Reports of validity data are available for the both the GFTA-2^92^ and the GFTA^94^ (Evidence Table 60). Goldman and Fristoe report construct, concurrent, and content validity data. Botting and colleagues and Mullen and Whitehead report concurrent validity data for the original instrument.^92,95,96^

##### Construct validity

Goldman and Fristoe demonstrated that raw scores decrease regularly with age. This pattern is consistent with what is known about the typical articulation development and closely matches other published reports.^92^

##### Concurrent validity

Two studies reported concurrent validity data for the original GFTA.^95, 96^ Mullen and Whitehead compared correct initial identification of stimulus pictures for the original GFTA and the Arizona Articulation Proficiency Scale (AAPS)^97^; they reported that children made significantly more errors in their initial identification of the pictures in the original GFTA than the AAPS.^96^ Goldman and Fristoe dropped 7 of these 20 error-prone stimulus words and revised the artwork to address these errors.^92^

Botting et al. compared teacher judgements of disability to GFTA scores in 242 British children with language impairment.^95^ They reported concordance between GFTA scores and teacher opinion; EPC staff calculated the sensitivity, specificity, and PPV and NPV using Botting et al.'s data, using the 25^th^ percentile as a threshold. Sensitivity ranged from 0.67 to 0.74, specificity from 0.77 to 0.85, PPV from 0.59 to 0.79, and NPV from 0.75 to 0.87 depending on the nature of the disorder. These results suggest that concordance between the GFTA and teacher opinion was high.

##### Content validity

Goldman and Fristoe documented that the GFTA-2 assesses 23 of the 25 recognized consonant sounds and 16 consonant clusters found in Standard American English.^92^

#### Available Normative Data

Goldman and Fristoe provided normative data by age and sex for the Sounds-in-Words subtest only (Evidence Table 61).^92^ They documented that the standardization sample closely matched the US population with respect to sex, race or ethnic group, geographic region, and mother's educational attainment. The standardization sample included sufficiently large (i.e., 100-125) samples of individuals of each sex in each age subgroup for which standardized scores are reported.

#### Applicability of GFTA-2 to Target Populations

Two studies examined whether scores from the GFTA-2 and the original GFTA differed for different groups of children.^92, 93^ Goldman and Fristoe reported little difference between Canadian and Standard American English.^92^ Seymour and Seymour concluded that black children can be successfully tested with the GFTA.^93^

Although neither of these populations exactly matches the groups of interest to the SSA, the results provide important insights. Goldman and Fristoe included children with mental retardation, speech/language impairments, learning disabilities, and emotional disturbances; reliability, validity and normative data were not provided separately for these groups.^92^ They also cautioned users that the age-based norms may not be useful with mentally retarded children and adults. Goldman and Fristoe provided no guidance about use with hard-of-hearing children; Lewis et al. required children to have normal hearing acuity.^92^

### Key Question No. 2

We identified no literature describing the predictive validity of the GFTA-2. Lewis et al. reported data on the predictive validity of the original instrument (Evidence Table 62).^72^ They found that among children identified with moderate to severe speech sound disorders, preschool GFTA scores significantly predicted school-age reading scores but not language or spelling scores.

## GRBAS (Grade, Rough, Breathy, Asthenic, Strain) Scale

The GRBAS Scale provides a system for describing vocal quality as measured by five parameters: G (overall grade of hoarseness), R (roughness), B (breathiness), A (asthenic), and S (strained quality) (Table 20 and Evidence Tables 63-65). This scale is not used widely in the United States but it does appear in the US literature and is used in some clinical settings. We found no data on predictive validity (Key Question No. 2) for this instrument.

Table 20. GRBAS (Grade, Rough, Breathy, Asthenic, Strain) Scale

Author | Japan Society of Logopaedics and Phoniatrics^98^
Publisher | Not specified
Date of Publication | 1981 (in English-language literature)
Ages | Not specified
Administration Time | Not specified
Scores | Vocal quality graded on 4-point scale -- 0 (normal), 1 (slight), 2 (moderate), and 3 (severe) -- for each of five voice parameters G (overall grade of hoarseness, R (roughness), B (breathiness), A (asthenic), and S (strained quality).
Normative Data Provided | None -- Standardized tape with typical voice samples available from Japan Society of Logopaedics and Phoniatrics
Components | GRBAS Scale, high-quality recording device, standardized tape of typical voice samples available from Japan Society of Logopaedics and Phoniatrics (we cannot determine whether this is readily available)
Procedures | Voice samples are recorded. Content of voice sample may vary, coming from spontaneous speech recorded during the session to specific vowel sounds and phonetically balanced samples of various lengths. The listener grades the five voice parameters using a 4-point scale.
Other | Different scales ranging from 10-point to visual analog scales have been employed.
Earlier Versions | None

### Key Question No. 1

We were unable to obtain a copy of the original GRBAS Scale and associated documentation. Hirano provided the first English-language description of the scale but provided no information on either reliability or validity.^98^

#### Reliability

Reports of reliability were found in seven peer-reviewed articles (Evidence Table 64).^99-105^ Reliability data were not reported by age, sex, or race; none of the studies provided information on voice disorders in children. All studies were conducted in Europe.

##### Internal consistency reliability

Two studies examined the internal consistency reliability of the GRBAS Scale.^100, 101^ However, they did not provide a clear picture of internal consistency reliability because they employed different forms of the GRBAS Scale; de Krom used the original GRBAS Scale and Dejonckere et al. a visual analog scale version.^100, 101^ Dejonckere et al. also combined two of the parameters, unlike the original version. de Krom failed to report data for two parameters.

##### Test-retest or intra-rater reliability

Several studies examined test-retest reliability^99^ and intra-rater reliability^100-102,105^ of the GRBAS Scale. These studies presented data on the original scale as well as variants, including visual analog scale and ordinal scale formats. They employed different, sometimes nonstandard, statistical methods to assess reliability. None met our threshold for acceptable test-retest or intra-rater reliability (i.e., Cohen's kappas of at least 0.80 or correlations of at least 0.90).

DeBodt et al. reported kappas of 0.40 to 0.45 for the original GRBAS Scale.^98, 99^ Dejonckere et al. reported intra-rater correlations ranging from 0.68 to 0.89.^102^ de Krom reported data in graphical displays rather than reporting correlation coefficients or kappas.^101^ Langeveld et al. reported intraclass correlations, ranging from 0.36 to 0.77.^105^

##### Inter-rater reliability

Dejonckere et al. (in two studies), De Bodt et al., de Krom, Millet and Dejonckere, Wuyts et al., and Langeveld et al. all examined inter-rater reliability.^99-104^ Like the results reported earlier for test-retest and intra-rater reliability, these studies employed different GRBAS Scale versions and applied different, sometimes nonstandard, statistical methods to assess reliability. None met our threshold for acceptable inter-rater reliability (i.e., kappas of at least 0.80 or correlations of at least 0.90).

#### Validity

We identified several studies evaluating the construct and concurrent validity of the GRBAS Scale (Evidence Table 65).^102-105^

##### Construct validity

No data on construct validity were reported in the original English-language introduction of the GRBAS Scale.^98^ Langeveld et al. presented correlations between the five parameters; the B, R, A, and S parameters were uncorrelated (r = −0.01 to 0.23) and overall grade (i.e., G) was correlated only with S (r = 0.74).^105^ They concluded that these perceptual characteristics were independent parameters, thus measuring different aspects of voice quality.

##### Concurrent validity

Two studies compared the GRBAS to acoustical measures or compared the different formats of the GRBAS Scale (ordinal scale versus visual analog scale).^102, 104^ Although these studies appeared to meet our concurrent validity criterion, they used as comparison instrument tools that have unacceptable reliability, thus negating their claim to validity.

Dejonckere et al. compared the GRBAS scale to the Kay Elemetrics Multi-Dimensional Voice Profile Program.^102^ They reported that correlations between the GRBAS Scale and MDVP parameters ranged from 0.45 to 0.73. However, their results suggested unacceptable inter-rater reliability (Cohen's kappa = 0.41) and intra-rater reliability (value not reported) for the GRBAS. Wuyts et al. compared the ordinal GRBAS with a visual analog version.^104^ Although correlations were high (ranging from 0.93 to 0.97), neither version had acceptable inter-rater reliability.

##### Content validity

Several studies discussed the concept of the difficulty of measuring perceptual data and comparing them to other types of data, but none addressed the comparison of perceptual rating for a vowel extraction sample with a sample normal conversation.

#### Available Normative Data

No normative data were provided for the GRBAS Scale. A standardized tape with typical voice samples is available from the Japan Society of Logopaedics and Phoniatrics. We were unable to determine whether this tape is readily available in the United States.

## Multi-Dimensional Voice Program

The Multi-Dimensional Voice Program (MDVP), Model 5105 is a software tool that provides clinicians and researchers an automatic speech analysis program with a multi-dimensional analysis of voice (Table 21 and Evidence Tables 66-69).^106^

Table 21. Multi-Dimensional Voice Program (MDVP)

Authors | Kay Elemetrics Corporation
Publisher | Kay Elemetrics Corporation 2 Bridgewater Lane Lincoln Park, NJ 07035-1499 USA Voice 1-800-289-5297 Fax 1-973-628-6363 http://www.kayelemetrics.com
Date of Publication | 1999
Ages | Not specified (adults used in validation)
Administration Time | Total administration time not specified; 16 seconds for the acoustical analyses only.
Scores | 33 acoustic parameters computed: average fundamental frequency, phonatory frequency range, several frequency and amplitude short- and long-term perturbation and variation measures, noise-to-harmonic ratio, voice turbulence and soft phonation indexes, quantitative measures of voice breaks, subharmonic components and voice tremors.
Normative Data Provided | Performance on all acoustic subtests compared to subjects in two descriptive appendices. Study One, the intersystem reliability study, compared 21 male and 21 female normal adult speakers with 21 male and 21 female patients with a voice disorder. Study Two evaluated 68 subjects with normal and disordered voices. A CD-ROM includes patient information, MDVP analysis, and signal profiles for 700 disordered voices.
Components | MDVP is an optional software program purchased with Multi-Speech or CSL computer hardware and software. The CSL and Multi-Speech hardware and software are not described in the MDVP manual (they have separate manuals), but the "generic" sound card is mentioned as being inferior to the "professional level" sound input/output systems of CSL.
Procedures | The sample data extraction method recommends that the subject say a sustained "ah" at a flat tone for at least 3 seconds. Later in the manual the Recommendations from the National Center for Speech and Voice are mentioned, stating that more than one "token" (trial) should be used for acoustic analyses. The "Tips" section recommends that the examiner elicit sustained voice and a reading passage. After a sound is elicited and recorded, the examiner saves the acoustic signal with Windows toolbars or computer function keys. Extracted data are displayed as numerical data for each of the acoustic parameters. Additionally, seven graphic displays are presented. Six present data on captured signal; average fundamental frequency (Fo) and peak-to-peak amplitude; long-term average spectrum; waveform (window A); Fo and amplitude modulation components; and histogram of Fo and amplitude displays (windows E and F). For 19 of the 33 parameters, a radial graph displays the patient's parameters (window D). The display is scaled so that normative thresholds for the parameters circumscribe a green circle. Patient parameters falling outside the normative threshold are indicated in red. The radial graph also can be used to compare the patient's parameters to the mean of a group of normal voice samples and against a threshold of 1SD above the normal value.
Other | A model of pathologic voice production is presented in the Appendix.
Earlier Versions | MDVP Model 4305, a DOS program used with earlier versions of the CSL.

### Key Question No. 1

#### Reliability

Reliability data for the MDVP, Model 5105 system were available from studies presented in the instrument manual.^106, 107^ One peer-reviewed article described reliability data for the previous DOS-based MDVP (Evidence Table 67).^108^

##### Internal consistency reliability

No internal consistency data were reported for the MDVP because the MDVP does not yield one score or one result. The 33 acoustic parameters are considered separately or in the independent groupings of pitch, noise, and tremor analyses or as frequency perturbation, amplitude perturbation, voice break/irregularity, and noise/tremor analyses. These are not compared to each other because different voice disorders would affect the score of each independently.

##### Test-retest or intra-rater reliability

Kent et al. reported results of repeated analysis of the same sample (i.e., intra-rater reliability) using the DOS-based MDVP; the system was able to compute analyses for all voice samples and replicate analyses were virtually identical for all but one voice.^108^ Analyses of different samples from the same voice (test-retest) and for voice samples taken at two different times during the same recording session yielded relatively small discrepancies in parameters and low frequency of discrepancy.

##### Inter-rater reliability

Inter-rater reliability does not apply to the MDVP.

#### Validity

Two studies^102, 109^ and a study reported within the MDVP manual^110^ described efforts at validating the MDVP (Evidence Table 68). Dejonckere et al.^102^ and van As et al.^109^ addressed both construct and concurrent validity and Deliyski^110^ offered evidence of content validity.

##### Construct validity

Dejonckere et al. and van As et al. employed principal components analysis to derive evidence of construct validity. Both studies were conducted in Europe using voice samples from patients seen in voice clinics; van As et al. also analyzed "normal" voices.^102, 109^ Both studies reported that the parameters "statistically" loaded on the same factors. Unlike Dejonckere et al., van As et al. reported demographic characteristics, although they evaluate only men's voices.^102, 109^ (The MDVP program can be set to measure female voices, giving different results.)

##### Concurrent validity

Deliyski and Gress compared the previous DOS version with the current Windows version; they called their analysis inter-system reliability, although it really provides evidence of concurrent validity.^107^ They reported correlation coefficients of greater than 0.99 for all measured parameters.

Two studies compared the MDVP to perceptual measures of voice quality. However, both studies suffered from important methodological deficits. Dejonckere et al. correlated MDVP parameters and the GRBAS Scale; they reported that the inter-rater reliability (Cohen's kappa = 0.41 to 0.51) and intra-rater reliability (value not reported) of the GRBAS were low.^102^ van As et al. compared MDVP parameters to an undescribed set of "seven semantic scales" describing voice in a perceptual task, providing no evidence of the reliability and validity of the perceptual rating scale.^109^

Thus, evidence of concurrent validity of the MDVP compared to the previous version was excellent, but no evidence exists when the MDVP was compared with perceptual rating scales.

##### Content validity

Deliyski presented an acoustic model of disordered voice production and used it to justify the 33 computed acoustic parameters and the subsequent grouping of the parameters into pitch, noise, and tremor analyses.^110^

#### Available Normative Data

Deliyski presented normative values for the MDVP parameters (Evidence Table 69).^110^ However, he cautioned MDVP users that normative values may depend upon the individuals included in the study, and thus they may be generalizable only to individuals similar to those tested in the study.

#### Applicability of MDVP to Target Populations

We identified no studies that address the applicability of the MDVP to populations of interest to the SSA. Of particular importance is that none of the studies or the test manual reported analyses of children's voices; thus, no data are available on the applicability of the MDVP to children with voice disorders.^106^

## Voice Handicap Index

The Voice Handicap Index (VHI) provides clinicians and researchers an instrument for measuring the impact on everyday functioning and health-related quality of life of voice disorders as perceived by the individual with the voice disorder (Table 22).^25, 26^

Table 22. Voice Handicap Index (VHI)

Author | B.H. Jacobson, A. Johnson, C. Grywalski, A. Silbergleit, G. Jacobson, M.S. Benninger, C.W. Newman
Publisher | B.H. Jacobson Division of Speech-Language Sciences and Disorders Department of Neurology Henry Ford Hospital 2799 W. Grand Boulevard Detroit, MI 48202
Date of Publication | 1997
Ages | Not specified (adults used in validation)
Administration Time | Not specified
Scores | Three 10-item subscales (functional, emotional, and physical) with scores from 0 to 40 points. Total score is the sum of the three subscales (range 0 to 120).
Normative Data Provided | None
Components | Voice Handicap Index
Procedures | Subjects read each of the 30 items and rate their response as "never," "almost never," "sometimes," "almost always," and "always" to indicate how they frequently have the same experience. Responses are scored on an equal-appearing 5-point scale from "never" scored as 0 to "always" scored as 4. Functional, emotional, and physical subscales are calculated as the sum of the responses to the 10 items in each scale. Total Voice Handicap Index is the sum of the scores on the three subscales.
Other | None
Earlier Versions | None

### Key Question No. 1

Benninger et al and Jacobson et al. standardized the VHI using a population of patients attending a voice clinic in a major hospital.^25, 26^ Although they provided detailed demographic and clinical information about their populations, they made no claim as to whether their populations were representative of US voice patients (Evidence Tables 70-72).

#### Reliability

Jacobson et al. provided data on the development and evaluation of internal consistency and test-retest reliability for the VHI.^26^ Because the VHI is a self-administered instrument, no examiner is needed and thus inter- and intra-rater reliability are not relevant. This fact, coupled with the relatively recent development of the instrument, likely are responsible for there being no manual available for review (Evidence Table 71).

##### Internal consistency reliability

Jacobson et al. documented their use of modern psychometric test theory to develop the VHI, providing a detailed description of the item selection and reduction process.^26^ They reported a Cronbach's coefficient alpha equal to 0.95 and thus met our "strict" criterion. When correlations between the total VHI score and three subscales (i.e., physical, emotional, functional) are considered (r = 0.88 to 0.93), the VHI met our "relaxed" internal consistency reliability criterion.

##### Test-retest or intra-rater reliability

Jacobson et al. reported test-retest reliability for the total scale and the three subscales.^26^ Only the correlations for total score (r = 0.92) and emotional subscale (r = 0.92) exceeded our threshold for test-retest reliability. The functional (r = 0.84) and physical subscales (r = 0.86) did not.

#### Validity

Two peer-reviewed articles provided data on the VHI's construct and concurrent validity (Evidence Table 72).^25, 26^

##### Construct validity

Jacobson et al. reported moderately strong correlations between the functional, emotional, and physical subscales (r = 0.70 to 0.79), suggesting that these subscales measure parts of the same overall construct.^26^ High correlations between the total VHI score and the subscales (r = 0.88 to 0.93) suggested that each subscale contributes to the overall measure of self-rated voice disorder severity.

##### Concurrent validity

Both Benninger et al. and Jacobson et al. compared the VHI with different measures of voice disorder severity.^25, 26^ Jacobson et al. correlated the VHI total and subscale scores to a self-rating of severity of voice handicap (r = 0.60 for total score comparison). Benninger et al. evaluated the relationship between the VHI (total and subscales) and the Medical Outcomes Study Short Form-36 (SF-36). They observed moderately high correlations between the VHI total and subscale scores and the SF-36 social and emotional functioning and mental health domains. VHI total score correlated significantly with SF-36 physical and functional subscales.

Although not direct evidence of concurrent validity, Benninger et al. provided evidence that the health-related quality of life (HRQOL) for voice patients is significantly different from individuals without voice disorders and for individuals with selected chronic diseases.^25^ Additionally, they provide evidence HRQOL varies among selected subgroups of dysphonia patients.

Taken together, these two studies provide evidence of acceptable concurrent validity.

## Supplemental Analyses -- Usability Analysis

This section describes the results of an additional analysis to shed some light on how feasible or practical it is to use these instruments in everyday settings. When deciding which instrument to use, a clinician must evaluate whether the manual provides sufficient information on how to administer and score the instrument. Two reviewers rated the usability of instrument manuals on the following eight criteria:

1. Instrument administration procedures can be duplicated;
2. Scoring procedures can be duplicated;
3. Examiner qualifications are specified;
4. Required examiner training is documented;
5. Environmental and equipment requirements are described;
6. Raw score scale meaning and interpretation are described;
7. Derived score scale meaning and interpretation are described; and
8. Scale construction is described.

We described these methods in Chapter 2; supplemental information appears in Appendix D. Table 23 summarizes the population and disorder results.

Table 23. Usability Evaluation Results, by Instrument

Instrument | Usability Criterion ^a^ | | | | | | | | Total Met ^b^
Instrument | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | No. | %
Adult Language
BDAE-2 | + | + | − | − | + | + | +/− | + | 5.5 | 68.8
PICA | + | + | + | + | + | + | + | + | 8 | 100
WAB | + | + | − | − | + | +/− | − | − | 3.5 | 43.8
Child Language
CELF-3 | + | +/− | + | + | + | +/− | + | + | 7 | 87.5
CELF-P | + | + | +/− | + | + | + | + | + | 7.5 | 93.8
CELF-3Sp | + | + | + | + | + | + | + | + | 8 | 100
PLS-3 | + | + | +/0 | − | + | + | + | + | 6.5 | 81.2
PLS-3Sp | + | + | +/− | +/− | + | + | + | + | 7 | 87.5
TOLD-P:3 | + | + | + | + | + | + | + | + | 8 | 100
TOLD-I:3 | + | + | + | + | + | + | + | + | 8 | 100
TOPL | + | + | + | + | + | + | + | + | 8 | 100
Adult Speech
AIDS | + | + | + | + | + | + | + | + | 8 | 100
DEB | + | + | − | − | + | +/− | +/− | +/− | 4.5 | 56.2
SSI-3 | +/− | +/− | − | − | − | + | + | + | 4 | 50.0
Child Speech
GFTA-2 | + | + | + | + | + | + | + | + | 8 | 100
SSI-3 | +/− | +/− | − | − | − | + | + | + | 4 | 50.0
Voice^c^
MDVP | + | +/− | +/− | + | + | − | − | − | 4 | 50.0
% agreement | 94.1 | 82.4 | 81.2 | 94.1 | 100 | 76.5 | 82.4 | 88.2
Kappa | --- ^d^ | --- | 0.60 | 0.87 | 1 | --- | 0.34 | 0.45

a + = Reviewers agreed that manual met criterion;-= Reviewers agreed that manual did not meet criterion; +/− = Reviewers disagreed; 0 = Reviewer did not assess this criterion.

b Calculated as sum, where + = 1, +/− or +/0 = 0.5 points, and-= 0.

c Manual not available for GRBAS scale or VHI.

d SAS could not calculate kappa because of missing cells. When the missing values were replaced with 0.001, kappa values were 0.002, 0.0004, and 0.0002 for criteria 1, 2, and 6, respectively.

For full name of instruments, see Table 4.

### Adult Language Disorder Instruments

User manuals varied widely in how well they met our usability criteria. The PICA manual was particularly user-friendly, meeting all eight criteria. Both reviewers agreed that the WAB manual met the least number of criteria of all instruments examined, not just those for adult language. This result is not surprising given the brevity of this manual (seven pages inclusive of references). The BDAE-2 manual ratings were intermediate; both reviewers agreed that information on examiner requirements and training (Criteria 3 and 4) was insufficient for the expected user. The two reviewers disagreed as to whether the derived aphasia classifications and their interpretations were well explained.

### Child Language Disorder Instruments

Our reviewers rated the child language instrument manuals as quite user-friendly. In general, these manuals met the majority of the criteria (ranging from 6.6 to 8). Our raters scored the two Preschool Language Scale-3 manuals in similar ways, disagreeing on whether they described examiner qualifications and training (Criteria 3 and 4) in sufficient detail. In a similar vein, the raters disagreed on the examiner qualification criterion for the CELF-P.

### Adult Speech Disorder Instruments

The AIDS manual met all eight criteria as evaluated by both reviewers. The SSI-3 met three of the criteria completely (both reviewers agreed) and two partially (i.e., one reviewer rated that the criterion had been met, the other did not). The reviewer who indicated that the SSI-3 manual did not meet Criterion 1 (description of procedures allows duplication of administration) and Criterion 2 (description allows duplication of scoring procedures) noted that procedures in the manual allowed the examiner to interrupt the stutterer to simulate normal conversation; her concern was that this instruction might be interpreted differently by each examiner and during each administration. Thus, the scores obtained might vary. Both reviewers indicated that the SSI-3 manual lacked information on examiner qualifications and training and on environmental and equipment requirements (Criteria 3, 4, and 5) for instrument administration. The DEB fared only slightly better than the SSI-3. Our reviewers disagreed in their assessments for half of the criteria. Both agreed that the administration procedures and scoring instructions could be easily followed and that examiner training had been adequately described. However, one reviewer was very concerned about the fact that many of the measures are subjective and might lead "different examiners to assign ratings differently based purely on their subjection impressions."

### Child Speech Disorder Instruments

The GFTA-2 manual met all eight criteria as evaluated by both reviewers. The SSI-3 met three criteria completely (both reviewers agreed) and two partially (i.e., one reviewer rated that the criterion had been met, the other did not). As above, the rater who indicated that the SSI-3 manual did not meet Criteria 1 and 2 was concerned about examiner interruptions. Both raters indicated that the SSI-3 manual lacked information on examiner qualifications and training (Criteria 3 and 4) and on environmental and equipment requirements for instrument administration (Criterion 5).

### Voice Disorder Instruments

Our usability reviewers scored only the MDVP instrument manual for the eight criteria. We were unable to rate the usability for the GRBAS Scale because we could not obtain an English-language manual. No manual was available for the VHI; all data on development and evaluation of reliability and validity were reported in the peer-reviewed literature.

The MDVP manual met three criteria (1, 4, and 5) as assessed by both reviewers. Our reviewers disagreed about Criteria 2 and 3. The reviewer who indicated that Criterion 2 was not met noted that although the manual does not report standardized scores, many different authorities claim various standard scores for the parameters tested by the MDVP system. The other reviewer made no comments to shed light on her rating of Criterion 3.