# Methodology

This chapter documents the procedures that the RTI-University of North Carolina at Chapel Hill Evidence-based Practice Center (RTI-UNC EPC) employed to develop a comprehensive evidence report for the Agency for Healthcare Research and Quality (AHRQ) and the Social Security Administration (SSA) on the criteria for determining disability in individuals with speech and/or language disorders. This report evaluates the reliability and validity of 18 instruments commonly employed by speech and language clinicians to diagnose the presence and severity of speech and language disorders. Furthermore, we present available evidence of the predictive validity for future communicative functioning for these instruments.

To establish a context for the evidence report, we first describe the key questions addressed by the report, the causal or clinical pathway that underpins these questions, and the process by which we selected the 18 diagnostic instruments for review. We then describe our literature review and retrieval process. This process included identifying appropriate electronic databases, developing appropriate search terms or key words, searching the gray literature (limited to instrument manuals), defining inclusion and exclusion criteria, and reviewing abstracts and complete articles for inclusion. Next, we describe the process by which we abstracted relevant data using one of two data extraction forms (one for peer-reviewed literature, the other for instrument manuals) and compiled relevant data into evidence tables used to summarize the information.

We also describe our process for evaluating the quality of the reviewed articles and instrument manuals and the evidence they yield. Because the contents of the instrument manuals and the articles from the peer-reviewed literature vary tremendously, we could not create a single quality rating form; thus, we outline our process for developing two forms (one for manuals, the other for peer-reviewed literature). Also discussed in this section is the process by which we assured quality control in selecting articles for review, abstracting data and creating evidence tables, and for evaluating quality. The chapter closes with a discussion of the peer review process and a supplemental analysis of the usability of the selected instruments and their manuals. The Methods Appendix supplements this description of the methods we employed.

## Key Questions, Causal Pathway, and Selected Instruments

We developed preliminary key questions and a causal pathway in response to the initial AHRQ/SSA request for proposal. We refined these conceptual issues and selected instruments for review during a one-day meeting (September 18, 2000, in Rockville, Maryland). Meeting participants (Appendix D), included members of our Technical Expert Advisory Group (TEAG) (described more fully in Appendix B), individuals with clinical expertise in speech, language, or voice disorders and relevant medical specialties, and representatives of professional societies and health care systems. They provided input on the utility and appropriateness of the causal pathway, refined the key questions, and identified and prioritized evaluation tools to be included in the evidence analysis.

### Key Questions

Final key questions are as follows:

1. What evaluation procedures for child and adult speech (voice, articulation/intelligibility, fluency) and language disorders have been demonstrated to have the salient characteristics of a good diagnostic tool (e.g., reliability, validity, appropriate normative data, responsiveness) for individuals who are/have:
  - English-speaking, have normal hearing, with or without normal cognition?
  - Non-English-speaking, have normal hearing, with or without normal cognition?
  - Mentally retarded?
  - Learning disorders?
  - Hearing impaired?
2. Are there evaluation procedures that have been demonstrated to have predictive validity for the individual's communicative impairment, performance, or both?

### Causal Pathway

Figure 1, our final causal pathway (i.e., analytical framework or conceptual model), depicts the scope of our evidence report. It begins with referral of an individual with a suspected disorder for evaluation. The subsequent evaluation of the individual yields a diagnosis, a determination of the severity of the disability or impairment, and an estimation of prognosis (prediction of duration of impairment and the expected level of functional communicative skills that will ultimately be gained or regained). These, in turn, serve as input to the determination of disability according to SSA guidelines.

Figure 1. Causal Pathway for Determining Disability in Speech and Language Disorders

Our evidence report begins with the speech-language evaluation and stops short of the SSA determination of disability per se (which may involve consideration of other impairments coexisting with the speech and/or language impairment). We focus on speech and language evaluation procedures and prediction of outcomes based on these procedures. In particular, we have evaluated the following:

- Reliability (internal consistency, test-retest, inter-rater, and intra-rater);
- Validity (content, construct, concurrent [convergent and divergent/discriminant], and predictive for future communicative functioning);
- Clinical test parameters (sensitivity, specificity, positive predictive value, negative predictive value), where available;
- Responsiveness; and
- Availability of normative data for the evaluation instruments.

In the causal pathway, an individual with suspected speech or language disorder is evaluated using selected evaluation procedures. Clinicians today use many different evaluation procedures to evaluate speech and language disorders in adults and children. Decisions regarding which procedure(s) to employ are now left to the discretion of the health care professional(s) conducting the evaluation.

The choice of evaluation instrument(s) will be determined by five sets of factors:

1. Whether the individual is a child or an adult;
2. The type of disorder (speech sound production, voice, stuttering, or language -- including consideration of semantics, syntax, pragmatics, comprehension, production, and language modality);
3. The presence of other impairments (e.g., cognitive impairments, hearing loss, physical disability); and
4. Whether the individual is from a non-English-speaking cultural environment;
5. Contextual factors, including examiner training and expertise, and setting for evaluation and/or treatment.

Characteristics of these instruments are critical to a successful disability determination process. Evaluation instruments must be reliable and valid for the purposes for which they are employed. If the clinical decisions based on their use are to be sound and objective, then evaluation instruments must be reliable and valid for the purposes for which they are employed. Such purposes include making a diagnosis, determining degree of impairment, and/or having predictive validity for short-term and long-term impairment and/or functional communicative outcomes.

Clinicians and technical experts synthesize information gained from the various procedures and instruments employed in the speech and language evaluation. In this process, they also may incorporate information from other evaluations not directed at the speech and language disorder per se. On the basis of all this information, they will arrive at conclusions regarding diagnosis, severity level, prognosis, and treatment recommendations.

At the final step in the causal pathway, conclusions from the speech-language evaluation are considered in light of the SSA rules for determination of disability (cited in Chapter 1). For all individuals applying for disability benefits under Title II, and for adults applying under Title XVI, disability is defined as the inability to engage in any gainful activity by reason of any medically determinable physical or mental impairment(s) that can be expected to result in death or that has lasted or can be expected to last for a continuous period of not less than 12 months. Children under the age of 18 applying under Title XVI are considered disabled if they have a medically determinable physical or mental impairment that causes marked and severe functional limitations that can be expected to cause death or that have lasted or can be expected to last for a continuous period of not less than 12 months. An individual may be considered disabled on the basis of severe speech-language impairment alone, or the individual's speech-language impairment may be considered in combination with other impairments in determining disability status.

## Selection of Instruments

Because of the diversity of speech and language disorders being considered, many evaluation tools/procedures provisionally fall within the scope of the key questions. We know of no single source that enumerates all speech and language evaluation instruments. The 140 commercially available speech and language instruments represent only a subset of all the evaluation tools available.^27^ The task of synthesizing the available evidence on all speech and language evaluation procedures was clearly too large an undertaking to complete within the scope of this project. Thus, a critical step in this evidence review was to select and then set priorities for instruments in such a way as to address the important informational needs of the SSA while also limiting the scope to fall within the contractual boundaries of the project.

During the September 18, 2000 meeting, we asked participants to select instruments and to set priorities for this review. We provided meeting participants with a list of speech-language diagnostic instruments as a reference during the selection process. We reminded participants that, because evidence-based medicine considers evidence from the peer-reviewed literature to be of paramount value or importance, they should suggest only instruments for which this type of evidence would be available. Thus, instruments that might otherwise be considered standards in the field (e.g., the American Speech-Language-Hearing Association [ASHA] Functional Assessment of Communication Skills^24^) and for which reliability and validity data are not published in the peer-reviewed literature would be excluded from further consideration.

Using this criterion, participants nominated 39 tools in each of five categories adult language, child language, adult speech, child speech, and voice disorders. Because we could not have conducted systematic literature reviews and evidence analyses for each of the 39 tools elicited given the project timeline and resources, we asked meeting participants to set priorities for the tools within the five categories, selecting three tools in each. Meeting participants set priorities based on the following guiding principles: (1) tools must assess disorders broadly rather than selecting a single aspect of the disorder, (2) for children, instruments must be useful with a broad age range, and (3) there should be a balance between instruments elicited and observed behaviors.

From these 39 instruments, participants selected a total of 20 instruments for literature review and evidence analysis (Table 2) -- three each for adult language, adult speech, child speech, and voice, and eight for child language disorders. One instrument selected covers both adult and child speech disorders and thus is counted twice. After consultation with TEAG members in December 2000 and with colleagues in the Division of Speech and Hearing Sciences at UNC, we excluded phonological process analysis because it is not a single instrument. Rather, it is an approach to conducting a more comprehensive clinical analysis of phonological patterns for which standard "diagnostic test characteristics" would be difficult to determine.

Table 2. Instruments Selected for Review, by Disorder Category

Disorder and Instrument
Adult Language
Boston Diagnostic Aphasia Examination, 2^nd^ Edition (BDAE-2) Porch Index of Communicative Ability (PICA) Western Aphasia Battery (WAB)
Child Language
Clinical Evaluation of Language Fundamentals, 3^rd^ Edition (CELF-3) CELF-3 Spanish Edition (CELF-3Sp) CELF-3 Preschool (CELF-P) Test of Language Development-Primary, 3^rd^ Edition (TOLD-P:3) Test of Language Development-Intermediate, 3^rd^ Edition (TOLD-I:3) Preschool Language Scale-3 (PLS-3) Preschool Language Scale-3 Spanish Edition (PLS-3Sp) Test of Pragmatic Language (TOPL)
Adult Speech
Assessment of Intelligibility in Dysarthric Speech (AIDS) Dysarthria Examination Battery (DEB) Stuttering Severity Instrument for Children and Adults, 3^rd^ Edition (SSI-3)
Child Speech
Goldman-Fristoe Test of Articulation, 2^nd^ Edition (GFTA-2) Stuttering Severity Instrument for Children and Adults, 3^rd^ Edition (SSI-3) Phonological process analysis (PPA)
Voice
GRBAS (grade, rough, breathy, asthenic, strain) Scale Multi-Dimensional Voice Profile (MDVP) Voice Handicap Index (VHI)

## Literature Search

This section describes the literature search procedures, specifying inclusion/exclusion criteria utilized to select literature for review, search terms and strategies, electronic databases employed, and our limited gray literature search. We document the steps used to identify the articles and instrument manuals that we ultimately reviewed.

### Inclusion and Exclusion Criteria

Inclusion/exclusion criteria (Table 3) were developed for and revised slightly during the September 18, 2000, meeting. Essentially, we included all research on the selected instruments in children and adults (ages 18 through 62) in which the study evaluated the instrument's reliability, validity, or its ability to predict future communicative impairment and/or functioning (i.e., predictive validity).

Table 3. Criteria for Determining Disability in Speech and Language Disorders: Study Inclusion/Exclusion Criteria

Category | Criteria
Study Population | Humans, Children, Adolescents, and Adults (ages 18 to 62)
Evaluation Tools | Adult Language: Boston Diagnostic Aphasia Examination, 2^nd^ Edition; Porch Index of Communicative Ability; Western Aphasia Battery Child Language: Clinical Evaluation of Language Fundamentals, 3^rd^ Edition (CELF-3); CELF-3 Spanish Edition; CELF-3 Preschool; Test of Language Development-Primary, 3^rd^ Edition; Test of Language Development-Intermediate, 3^rd^ Edition; Preschool Language Scale, 3^rd^ Edition (English); Preschool Language Scale, 3^rd^ Edition (Spanish); Test of Pragmatic Language Adult Speech: Assessment of Intelligibility; Dysarthria Examination Battery; Stuttering Severity Instrument for Children and Adults, 3^rd^ Edition Child Speech: Goldman-Fristoe Test of Articulation, 2^nd^ Edition; Stuttering Severity Instrument for Children and Adults, 3^rd^ Edition; Phonological Process Analysis Voice: GRBAS (Grade, Rough, Breathy, Aesthenic, Strain) Scale; Multidimensional Voice Profile; Voice Handicap Index
Study Setting | Inpatient and outpatient settings, communities, schools
Outcomes Measured | Reliability (internal consistency, test-retest, inter- and intra-rater) Validity (content, construct, concurrent [convergent and divergent/discriminant] Predictive validity (for future communicative functioning), and normative data for particular populations (children or adults ages 18-62) Cognitive impairments (normal, borderline normal, mentally retarded, learning disabled) Hearing impairments, language, or cultural issues (English- versus non-English speaking) Exclude studies evaluating the efficacy or effectiveness of interventions/treatment of speech and/or language disorders
Time Period | Depends on when the evaluation tool(s) were developed and validated
Geographic Site of Study | Exclude based on language of publication. Normative data must be from the United States
Publication Languages | English only
Admissible Evidence (Study Design and Other Criteria) | Randomized controlled trial (RCT) -- double, single-blinded, and cross-over Non-RCT -- nonequivalent control group designs, cohort studies (prospective and retrospective), case-control studies, psychometric evaluations Other designs (meta-analysis, meta-regression, cross-design synthesis, review article for reference list searches) Sample size: >20 subjects per analysis group

We included studies of individuals older than 62 years if the majority of the study sample was age 62 and younger. We excluded studies that: (1) concerned solely elderly adults (i.e., individuals > 62 years of age); (2) were published in languages other than English; and (3) did not report information related to the key questions (except to the extent that they are used to provide background information).

We excluded articles reporting the efficacy or effectiveness of speech or language therapy that did not provide information relevant to the key questions. We also excluded articles providing normative data from populations other than the United States because of our need to address issues facing the SSA in establishing disability criteria in the United States.

### Search Terms and Databases

The EPC's information specialist, in consultation with EPC staff, developed search terms based on the names of the selected instruments. Preliminary searches were conducted using broad Medical Subject Headings (MeSH) relating to study design, disorders, and outcomes in combination with the names of the instruments (Table D3 in Appendix D). These searches yielded enormous numbers of citations; very few were relevant. Consequently, we revised our searches to use the names of the instruments as key words, sometimes searching on only the most important term (e.g., Goldman-Fristoe). This strategy, while producing large numbers of citations, was most likely to ensure that we did not miss possibly relevant citations.

We employed a multifaceted approach to identify relevant studies, including use of standard electronic (literature) databases, reference lists of relevant articles, and Cochrane Collaboration resources. We searched electronic data sources, including the MEDLINE, CINAHL, PsycLIT^®^, ERIC, Health and Psychosocial Instruments (HAPI), and the Cochrane Collaboration databases. The PsycLIT^®^ database, produced by the American Psychological Association, covers the professional and academic literature in psychology and related disciplines including medicine, psychiatry, nursing, sociology, education, pharmacology, physiology, linguistics, and other areas. ERIC, produced by the Educational Resource Information Center, indexes and abstracts journal and report literature (1966 to the present) in education and related disciplines. HAPI provides information on measurement instruments (i.e., questionnaires, interview schedules, checklists, index measures, coding schemes/manuals, rating scales, projective techniques, vignettes/scenarios, tests) in the health fields, psychosocial sciences, organizational behavior, and library and information science.

We also reviewed the reference lists of all included articles and instrument manuals to identify additional studies. Finally, we conducted searches of the Cochrane Collaboration Database, a family of electronic databases providing reference information on randomized and other controlled clinical trials and systematic reviews conducted by various Cochrane Collaborative Review Groups. These studies were reviewed for quality, and in some cases we obtained additional information from the original authors or through hand-searches of the literature.

## Gray Literature Search

We initially excluded all gray literature for two reasons: (1) the large number of selected instruments and the substantial literature for each of these tools, and (2) the time and resource constraints of this project. An additional issue was the danger that including gray literature studies would tend to identify studies with "memorable findings," which are more likely to be either very positive or very negative relative to studies that were not as well remembered. Incomplete sampling of the gray literature would introduce the possibility of bias in study selection.

However, review of abstracts for eligibility (see "Literature Retrieval" below) made it clear that, for many instruments, data on reliability and validity could be found only in the instrument manuals. In most cases, instrument developers had not published their validation or standardization results. Thus, we expanded our efforts to include instrument manuals in the evidence review process. For several instruments, we identified some reliability and validity data in doctoral dissertations (via a search of Dissertation Abstracts International). Unless the dissertations were later published either as instrument manuals or as peer-reviewed articles, we excluded them from the evidence analysis because of their relative inaccessibility or obscurity.

## Literature Retrieval

Either the study director or the scientific director reviewed all abstracts for a single test, using the Abstract Review Form (Figure D1 in Appendix D). If the first reviewer judged an abstract to meet inclusion criteria, we included it in our review. The second reviewer independently reviewed all abstracts excluded by the first reviewer. If both reviewers excluded an abstract, we dropped the abstract from further consideration. If the reviewers disagreed, they met to reconcile differences between their reviews. The scientific director's decision stood when differences remained after reconciliation. Generally speaking, for all abstracts, we erred on the side of inclusion rather than exclusion, sending questionable abstracts to the other reviewer for further consideration.

Initially, we planned to re-review a randomly selected 20-percent subset of abstracts marked for inclusion. However, because the number of articles included was quite small, the clinical experts re-reviewed all the abstracts selected for inclusion.

## Results of Article Selection

We combined the search results from the five databases for each instrument. This yielded 1,238 citations summing across all parts of Table 4. The number of citations sent for abstract review ranged from three (for the Dysarthria Examination Battery [DEB] and Voice Handicap Index [VHI]) to 256 for the Test of Language Development (TOLD). Of these citations, the reviewers judged that 92 met study inclusion criteria.

Table 4. Results of Literature Searches, Abstract Review, and Data Abstraction Processes, by Instrument

Steps in Literature Review Process | Adult Language Instruments
Steps in Literature Review Process | BDAE-2 | PICA | | WAB
Total unduplicated records | 211 | 80 | | 152
Sent for Abstract Review | 211 | 80 | | 152
Include | 3 | 9 | | 10
Exclude | 208 | 71 | | 142
Sent for Data Abstraction | 3 | 9 | | 10
Excluded at Data Abstraction | 1 | 5 | | 4
Sent for Evidence Table Creation | 2 | 4 | | 6
Peer-reviewed articles | 2 | 4 | | 6
Manuals | 1 | 1 | | 1
Evidence Tables Created | 3 | 5 | | 1
| Child Language Instruments
| CELF-3/ CELF-3Sp/ CELF-P | TOLD-I:3/ TOLD-P:3/ TOLD-P:2/ TOLD-I:2 | TOPL | PLS-3/ PLS-3Sp/ PLS-R
Total unduplicated records | 72 | 256 | 10 | 112
Sent for Abstract Review | 72 | 256 | 10 | 112
Include | 9 | 17 | 0 | 6
Exclude | 63 | 239 | 10 | 106
Sent for Data Abstraction | 9 | 17 | 0 | 6
Excluded at data abstraction | 4 | 15 | 0 | 2
Sent for Evidence Table Creation | 5 | 2 | 0 | 4
Peer-reviewed articles | 5 | 2 | 0 | 4
Manuals | 3 | 2 | 1 | 2
Evidence Tables Created | 8 | 4 | 1 | 6
| Adult Speech Instruments
| AIDS | DEB | | SSI-3^a^
Total unduplicated records | 21 | 3 | | 36
Sent for Abstract Review | 21 | 3 | | 36
Include | 1 | 0 | | 1
Exclude | 20 | 3 | | 35
Sent for Data Abstraction | 1 | 0 | | 1
Excluded at data abstraction | 1 | 0 | | 1
Sent for Evidence Table Creation | 0 | 0 | | 0
Peer-reviewed articles | 0 | 0 | | 0
Manuals | 1 | 1 | | 1
Evidence Tables Created | 1 | 1 | | 1
| Child Speech Instruments
| GFTA-2/GFTA | PPA | | SSI-3^a^
Total unduplicated records | 137 | 84 | | 36
Sent for Abstract Review | 137 | 84 | | 36
Include | 9 | 12 | | 1
Exclude | 128 | 72 | | 35
Sent for Data Abstraction | 9 | 72 | | 1
Excluded at data abstraction | 5 | --- ^b^ | | 1
Sent for Evidence Table Creation | 4 | 0 | | 0
Peer-reviewed articles | 4 | 0 | | 0
Manuals | 1 | 0 | | 1
Evidence Tables Created | 5 | 0 | | 1
| Voice Instruments
| GRBAS | MDVP | | VHI
Total unduplicated records | 12 | 13 | | 3
Sent for Abstract Review | 12 | 13 | | 3
Include | 8 | 3 | | 3
Exclude | 4 | 10 | | 0
Sent for Data Abstraction | 8 | 3 | | 3
Excluded at data abstraction | 1 | 0 | | 1
Sent for Evidence Table Creation | 7 | 3 | | 2
Peer-reviewed articles | 7 | 3 | | 2
Manuals | 0 | 1 | | 0
Evidence Tables Created | 7 | 4 | | 2

a Stuttering Severity Instrument for Adults and Children-3^rd^ Edition selected for both adults and children.

b Phonological Process Analysis excluded at data abstraction.

nd AIDS = Assessment of Intelligibility of Dysarthric Speech; BDAE-2 = Boston Diagnostic Aphasia Examination, 2 Edition; CELF-3 = Clinical Evaluation of Language Fundamentals-3^rd^ Edition; CELF-3Sp = CELF-3 Spanish Edition, CELF-3 Pre = CELF-3 Preschool; DEB = Dysarthria Examination Battery; GFTA = Goldman-Fristoe Test of Articulation, 2 Edition; GRBAS = GRBAS (Grade, Rough, Breathy, Aesthenic, Strain) Scale; MDVP = Kay Elemetrics Multidimensional Voice Profile; PICA = Porch Index of Communicative Ability (PICA); PPA = Phonological process analysis; PLS-3 = Preschool Language Scale-3^rd^ Edition; PLS-3Sp = Preschool Language Scale-3^rd^ Edition (Spanish); SSI-3 = Stuttering Severity Instrument for Adults and Children, 3^rd^ Edition; TOLD-P:3 = Test of Language Development-Primary: 3^rd^ Edition; TOLD-I:3 = Test of Language Development-Intermediate: 3^rd^ Edition; TOLD-P:2 = Test of Language Development-Primary: 2 Edition; TOLD-I:2 = Test of Language Development-Intermediate: 2 Edition; TOPL = Test of Pragmatic Language; VHI = Voice Handicap Index; WAB = Western Aphasia Battery

Of the articles that we excluded at the abstract review phase, we eliminated a substantial number because they were citations of non-peer-reviewed publications, dissertations, test reviews/critiques, manuals, or materials from the Mental Measurements Yearbook Series published by the Buros Institute in Nebraska. We excluded more than 75 citations because they did not describe one of the selected tests.

Of the 92 articles whose abstracts met inclusion criteria, we eliminated 53 at the data abstraction phase. Of these, 12 addressed the phonological process analysis. We dropped the remaining 41 because they did not meet the study inclusion criteria or did not address the version of the instrument selected by TEAG members. In cases where no peer-reviewed articles existed for the selected version, we included articles, but not manuals, from the version just prior to the one we had originally selected.

## Data Abstraction Process

The data abstraction process included developing data extraction forms, training abstractors, and instituting a quality control process.

### Data Extraction Forms

The study director worked with a psychometrician to develop the two data extraction forms needed to review the peer-reviewed literature and the instrument manuals. Because the selected instruments are for both adults and children and encompass language, speech, and voice disorders, we could not develop a single extraction form that would gather all necessary data. Rather than create a form for each combination of population and disorder (i.e., one each for adult speech, child speech, adult language, child language, voice) for a total of five forms or one for each instrument (20 forms), we opted to create two modular extraction forms that we could use with all instruments and for each population and disorder combination. The modular approach allowed abstractors to use only the portions that were relevant for a specific article or manual.

The forms collect information on study design, population studied, examiner qualifications and training, results (validity, reliability, predictive validity, and normative data), and limitations. The forms also provide essential instructions to abstractors and a description of designs used in the reliability testing and validation of instruments, the appropriate statistics, and benchmarks for evaluating whether an instrument had good reliability and validity. We tested our extraction forms to be sure that the instructions were clear and that abstractors would find the forms easy to use; we made changes as needed. We present the final forms in Figures D2 and D3 in Appendix D.

### Abstractors and Training

Two quantitative psychology doctoral students conducted all data abstraction because we were unable to find abstractors who had appropriate methodological skills and speech and language clinical expertise. Both abstractors had course work in quantitative methods and in both classical test and modern test theory (as well as item response theory), and both had experience in the validation and standardization of educational tests. Each article or instrument was reviewed by one abstractor only. We did not blind the abstractor to journal, authors, or institutions.

Both abstractors received training from the study director and a psychometrician. This training included a question-by-question review of the data extraction form and practice abstraction of a manual and an article. The study director and psychometrician reviewed the extraction forms, correcting any errors in the forms and making certain that the abstractors understood the task. The study director monitored progress of the abstraction process and provided feedback to the abstractors, as did the psychometrician.

### Quality Control Process

Although evidence-based medicine "best practices" require that two abstractors independently review each article, we were unable to conduct dual abstraction because we could not find enough reviewers with appropriate skills. Instead, the study director, a health services researcher with expertise in quantitative methods and systematic review, reviewed all data extraction forms and evidence tables. EPC clinical experts re-reviewed evidence tables in their areas of expertise to ensure that all information was reproduced accurately. Because the abstractors and EPC staff did not complete data extraction forms independently, we could not check the inter-rater reliability of the data abstraction process, as previous reports have done.

## Quality and Strength of Evidence Evaluation

### Rating the Quality of Individual Articles and Manuals

Quality rating items previously used by the RTI-UNC EPC are tailored to randomized and nonrandomized clinical trials, designs seldom used in psychometric evaluation; furthermore, these items do not address reliability and validity testing. Thus, we sought guidance from the educational and psychological testing literature for criteria and standards to use in our quality evaluation. The American Educational Research Association (AERA), American Psychological Association, and the National Council on Measurement in Education regularly publish standards for test construction, evaluation, and documentation. The most recent version, 1999 Standards for Educational and Psychological Testing, hereafter known as the 1999 Standards, forms the basis for our quality rating scales.^28^ Our use of the 1999 Standards is not precedent-setting. In 1984, McCauley and Swisher had adapted an earlier edition to evaluate the psychometric properties of preschool language and articulation instruments.^29^

Figures D4 and D5 in Appendix D present the quality rating items and scoring. The individual article quality rating forms compare 35 criteria (for a maximum score of 35 points) in seven main categories. They are research design and conduct, the measurement of reliability, validity, and development of instrument norms, justifications for conclusions, and external validity concerns. The manual rating form includes six additional criteria addressing aspects of instrument development or revision; the total score for this form is 41 points. We rescaled the quality score, reporting it as a percentage. Because some items on the forms did not apply to a particular article or manual, we subtracted the points for that item from both the numerator and the denominator when calculating the percentage score.

The EPC study director and clinical experts completed a quality form for each manual and article. The clinical experts evaluated instruments in their areas of expertise; the study director evaluated all manuals and articles from a methodological standpoint. We report the quality rating scores separately for the clinical and methodological experts rather than averaging the scores across the quality reviewers. We did not use quality scores for inclusion/exclusion decisions.

### Evaluating the Psychometric Properties of the Instruments

Even when we examined the psychometric literature, we found it particularly difficult to identify thresholds for reliability and validity. Although the 1999 Standards ^28^ has reliability, validity, and normative data criteria, it does not venture to set thresholds for them.^28^ The Scientific Advisory Committee (SAC) of the Medical Outcomes Trust cited some standards for reliability coefficients,^30^ which generally match those found in seminal educational and psychological testing texts,^31-33^ but the SAC did not provide them for validity. Anastasi^31^ and Cronbach^33^ provide limited information for setting validity thresholds; we use what they presented in creating our criteria and thresholds. For normative data, we use the 1999 Standards ^28^ and the criteria employed by McCauley and Swisher.^29^

The criteria selected are those usually used to make individual comparisons, or in this case, decisions about individuals. It is important to minimize the possibility that a patient is misdiagnosed -- that is, to make certain that patients with true impairments are not missed and that "normal" individuals not be labeled as having an impairment. This is particularly important in the context of disability determination, where incorrect decisions can result in individuals being wrongly kept off or struck from SSA disability eligibility rolls or conversely in healthy individuals inappropriately being covered within the disability program.

From these various sources, we established the following criteria:

- Reliability -- the criterion for reliability is "strictly" met if the following three conditions are all met:
  - Internal consistency reliability, measured using either Cronbach's coefficient alpha or Kuder-Richardson statistics (K-R 20), is greater than or equal to 0.90;
  - Test-retest/intra-rater reliability is greater than or equal to 0.90 if measured using a correlation coefficient, or greater than or equal to 0.80 if measured using Cohen's Kappa; and
  - Inter-rater reliability is greater than or equal to 0.90 if measured using a correlation coefficient, or greater than 0.80 if measured using Cohen's Kappa.

Some might reasonably argue that the criterion for internal consistency reliability is set too high given the complexity of speech and language functioning and disorders. Additionally the resultant variability in daily performance suggests that our criterion for test-retest reliability or intra-rater reliability also may be too high. Thus, we defined a "relaxed" criterion, which differs from the strict criterion in that internal consistency reliability may be as low as 0.80 and/or test-retest/intra-rater reliability may be as low as 0.80 (correlations) or 0.70 (Cohen's Kappa). The relaxed criterion is at a level suitable for having confidence in group, rather than individual, comparisons.

- Validity -- the criterion for validity is met if the following conditions are all met:
  - Instrument developers examine relationships between subtests, composite scores, and total scores, establishing hypotheses a priori for these relationships and for patterns of scores for individuals belonging to various groups of import;
  - These relationships all are statistically significant at p < 0.05; and
  - In the case of correlation coefficients, the magnitude of the relationship is at least 0.30, thus providing evidence of a moderate correlation.
- Normative Data -- the criterion for normative data is met if the following conditions are all met:
  - Data are available for the population targeted by the instrument;
  - An adequate sample size is used (i.e., at least 100 per group); and
  - Evidence is provided on how well the sample represents the population.

## Grading the Strength of Available Evidence

Various systems for rating the strength of evidence have been developed for clinical topics and pathways.^34^ To date no consensus exists about which system, if any, is best or most appropriate. Evidence grading schemes previously used by the RTI-UNC EPC and the US Preventive Services Task Force (1996), although recognized for their utility for the projects for which they had been developed, provided little guidance for this particular topic.^35^

The type of literature that EPCs normally review, and upon which existing evidence grading scales are based, is substantially different than the literature available to address issues of diagnosing speech and language disorders and predicting the level and duration of disability from such conditions. The existing schemes are used with peer-reviewed literature and would not typically be applicable to the instrument manuals on which the majority of this report is based.

We have separated instrument manuals from peer-reviewed literature, emphasizing here that only two manuals were published in the peer-reviewed literature. Today's methods for conducting systematic reviews would dictate that we downgrade the manuals for not having been peer reviewed. However, several manuals documented that the development teams employed rigorous psychometric methods in the instrument development and validation process, and we wanted to reflect those efforts in our grading scheme. Also important was to be able to comment on the quality of the individual instruments, which would not have been possible if we graded using a system that assigned an "unacceptable" grade to all the manuals for reason of their not being peer-reviewed.

To provide some consistent basis for indicating the strength of the overall body of evidence for groups of instruments identified by age group and disorder, we set out the following definitions for both instrument manuals and peer-reviewed literature.

- Acceptable: research or analyses were well conducted, had representative samples of reasonable size, and met our psychometric evaluation criteria discussed earlier.
- Unacceptable: studies were poorly conducted, used small or nonrepresentative samples, or had results that did not meet or only partially met the psychometric criteria.

## Development of Evidence Tables

To balance providing enough information to allow the reader to judge the quality of the literature against the volume and complexity of the literature, we developed a series of five evidence tables for each instrument. These tables provide what we considered the essential information to address the key questions. The first of these tables gives information on the study design and conduct and the quality scores assigned by the methodologist and the expert clinicians. The subsequent four tables describe the reliability, validity, predictive validity for future communicative functioning, and available normative data found in the reviewed articles and manuals.

The format and basic content of the evidence tables are similar across the instruments. When articles or instrument manuals presented multiple studies, we documented details of the different designs, samples, and results in the evidence tables. Where we reviewed different editions or versions (e.g., Spanish vs. English) of an instrument, we grouped data together by edition or version in the evidence tables. For example, we present all literature pertaining to the Test of Language Development:3 (TOLD:3) together. If we found no data for a particular outcome (e.g., reliability, validity, predictive validity, or normative data), we did not create an evidence table.

To conserve space in the evidence tables, we used numerous abbreviations. Although most of these abbreviations are self-explanatory, we provide a glossary of abbreviations and commonly used terms to assist the reader in reviewing the evidence tables.

## Supplemental Analysis -- Usability Analysis

When deciding which instrument to use, a clinician must evaluate whether the manual provides sufficient information on how to administer and score the instrument. As part of our analyses, we evaluated the usability of the instrument manuals (additional details are provided in the Methods Appendix). Two speech and language pathology graduate students independently evaluated manuals using the Usability Evaluation Form (Figure D6 in Appendix D). In Chapter 3, we report the results of the analysis.

To assess inter-rater reliability, we computed Cohen's Kappa statistic^36^ and percentage agreement between the raters for the individual criterion (Table D4 in Appendix D). Kappa values for the individual criterion ranged from 0.34 to 1.00, suggesting poor to almost perfect agreement.^37^ Inter-rater agreement ranged from 76.5% (13/17) to 100% (17/17). The reviewers agreed most often on administration procedures, examiner training, and equipment and environmental needs, and least often on interpretation of raw scale scores.

## Peer Review Process

A group of 18 clinicians, methodologists, representatives of professional societies, and potential users of the report, including TEAG members, were sent the draft evidence report. Of these 18, 10 returned a review. These peer reviewers provided comments on the content, structure, and format of the evidence report, paying particular attention the inclusion/exclusion of literature for the selected instruments, to the analysis and interpretation of study results and evidence, and to the discussion of gaps and areas that should be targeted for future research. Appendix C describes the selection process for peer reviewers and lists the names of all peer reviewers.

## Methods Appendix: Explanation of Reliability and Validity

Reliability and validity are important properties of instruments, especially those used to assess speech and language disorders for disability determination. Every instrument must yield consistent measurement (i.e., it must be reliable) and must measure what it is intended to measure (i.e., it must be valid).^31-33,38^ Thus, an instrument measuring language disorders in children must consistently measure expressive and receptive language each time the instrument is administered. The questions that measure expressive language ability must indeed measure aspects of expressive language and not measure receptive language abilities.

Both reliability and validity are required of an instrument, but reliability takes precedence over validity. Specifically, an instrument that is valid but is not reliable (i.e., it does not produce consistent measurement) is not useful. Moreover, reliability and validity are not absolute concepts. Thus, it is correct to say that an instrument is reliable and valid for use with a particular population; it is not correct to say broadly that an instrument is reliable and valid. If it is important that an instrument be reliable and valid for use with a particular population (e.g., children who are mentally retarded or hard of hearing), then the instrument developers must test the instrument with these populations and report reliability and validity data separately for them.

This chapter appendix describes the forms of reliability and validity considered in this evidence report, documenting the types of statistics typically used to measure reliability and validity and the thresholds typically used to assess "acceptability."

### Reliability

Reliability of measurement refers to the extent to which the observed variation in scores is due to variation in the "true" score (i.e., the "true" value of an underlying construct such as expressive language or articulation) rather than random error. Thus, the scores on an instrument, such as the TOLD-P:3 should not change unless underlying expressive or receptive language ability change. That an instrument is reliable is a necessary condition for use; an instrument that does not produce consistent results has little utility. When instrument developers measure reliability, they generally consider several types: internal consistency (or inter-item consistency), test-retest, intra-rater, and inter-rater (or inter-observer) reliability.

#### Internal Consistency Reliability

Internal consistency (inter-item consistency) reliability measures how well the individual items (or questions) within a scale or scales relate to composite scores (e.g., the individual questions that make up the various TOLD-P:3 subtests or the relationship of various subtests to the composite scores). Typically, internal consistency is reported as coefficient alpha^33^ or as Kuder-Richardson formula 20 (K-R 20)^39^ if the instrument items are scored on a 5-point scale (e.g., 5 = never, 4 = occasionally) or dichotomously (e.g., correct-incorrect), respectively. For scales or items measured on a continuous scale, instrument developers employ correlation coefficients (both the K-R 20 and coefficient alpha are correlation coefficients).

Some experts consider coefficients of 0.90 or greater acceptable for individual comparisons like those made in the evaluation of speech and language disorders; others suggest that 0.80 is an appropriate threshold for coefficient alpha.^37,38,40,41^ However, setting the threshold for coefficient alpha at 0.80 may be too strict for shorter scales because alpha increases as the number of items in the scale increases.^38^

##### Test-retest or Intra-rater Reliability

Test-retest reliability measures the consistency of scores obtained at two separate times. Intra-rater reliability measures whether, upon repeated administration, the examiner or instrument assigns the same scores to an individual. Both are reported as either correlation coefficients or as Cohen's Kappa^42^ depending upon how the scale is measured (e.g., as a continuous or dichotomous variable). Typically, instrument developers report test-retest or intra-rater reliability as Cohen's Kappa^42^ for dichotomous scales or as a correlation coefficient for continuous scales. Landis and Koch suggest that kappa values of less than 0.4 indicate poor agreement, 0.4 to 0.6 indicate moderate agreement, 0.61 to 0.8 suggest substantial agreement, and greater than 0.8 suggest almost perfect agreement.^40^

#### Inter-rater Reliability

Inter-rater reliability measures whether two observers or examiners score an individual, in this case an adult or child with a speech or language disorder, in the same way. Typically, instrument developers report inter-rater reliability as Cohen's Kappa^42^ for dichotomous scales or as a correlation coefficient for continuous scales. Thresholds similar to those described for test-retest and intra-rater reliability are used with inter-rater reliability.

### Validity

The validity of an instrument refers to "how well it measures what it purports to measure"(p. 83).^32^ When a test developer validates or examines the validity of an instrument, she or he broadly examines the relationships between an individual's performance on the instrument and particular observable facts about the behaviors studied. In the case of a patient's expressive language abilities, the instrument items that are designed to measure expressive language should indeed measure the individual's ability. The procedures for evaluating validity have been given a variety of names over the years. We employ the names given in the 1999 Standards -- content-related, construct-related, and criterion-related validation.^28^

As we described earlier for reliability, validity should not be couched in terms of whether an instrument is "valid or not." Rather, the correct way to think about it is whether the instrument is valid for a particular purpose, population, and situation.

#### Content-related Validity

When evaluating content validity, test developers typically examine whether the items in the instrument adequately cover and represent the dimension(s) to be measured. As such, the evaluation of content validity is a subjective assessment, often conducted by experts, of how appropriate the items included in the instrument are. Typically, content validity assessment involves an organized review to make certain that relevant items are included and that inappropriate items are not.

#### Construct-related Validity

Construct validity is defined as "the extent to which the test may be said to measure a theoretical construct or trait"(p. 153).^31^ Construct validity involves the gradual accumulation of information from a variety of sources and studies, where test developers look for correspondence between the theory and available data.^31,33,38^

Convergent and divergent (or discriminant) validation are important aspects of construct validation activities.^31,33,38^ With convergent validity, test developers are interested in whether a particular instrument correlates highly with variables or characteristics that it should correlate highly with. For example, an instrument measuring articulation should correlate highly with other instruments that measure articulation. Divergent (or discriminant) validity is present when an instrument does not correlate significantly with variables from which it should differ. Typically, instrument developers report construct validity in the form of correlation coefficients between items on the instrument (or composite measures) representing a particular theoretical construct and other characteristics of the instrument. Factor analysis is often employed to identify underlying behavioral traits. In practice, instrument developers use factor analysis to identify items or subscales that are related to each other and to a particular traits of interest (e.g., verbal comprehension as measured by subscales addressing vocabulary, sentence completion skills).^31^

#### Criterion-related Validity

Criterion-related validity is a measure of how effective an instrument is in predicting an individual's performance in specific activities, such as performance on another similar instrument or future behaviors. In evaluating criterion validity, performance on an instrument "is checked against a criterion, that is, a direct and independent measure of that which the test is designed to predict"(p. 145).^31^ In the case of evaluation for speech, language, or voice disorders, the criterion might be performance on another instrument (concurrent validity) or future communicative function or performance (predictive validity).

##### Concurrent Validity

With concurrent validity, test developers are interested in the individual's performance on two instruments given simultaneously or after a short interval.^28,31^ The main purpose of concurrent validity testing is to develop an instrument as a substitute for a more time- and/or resource-intensive assessment procedure.^31^ Concurrent validity is measured as a correlation between the instrument and the criterion instrument; high correlation indicates concurrent validity. For concurrent validity testing, a critical factor is that the criterion instrument be a "gold standard," that is, an instrument that is relevant and well-known with demonstrated psychometric properties.^31^ Both concurrent and predictive validity are typically presented as correlation coefficients between the instrument and the criterion instrument or behavior; a high correlation.

##### Predictive Validity

With predictive validity, test developers are interested in whether the individual's performance on a particular instrument can be used to predict future events or performance. Predictive validity differs from concurrent validity primarily in that the interval between the administration of the instrument of interest and the latter measurement of behavior or performance is much longer. As with concurrent validity, instrument developers report predictive validity in terms of correlation coefficients.