# Introduction

The purpose of this report is to assist the Social Security Administration (SSA) in reviewing its criteria for determining disability in individuals with speech disorders, language disorders, or both. The statutory definition of disability in adults is "an inability to engage in any substantial gainful activity by reason of any medically determinable physical or mental impairment which can be expected to result in death or which has lasted or can be expected to last for a continuous period of not less than twelve months.''^1^ For children and adolescents, the definition is "(i) An individual under the age of 18 shall be considered disabled for the purposes of this title if that individual has a medically determinable physical or mental impairment, which results in marked and severe functional limitations, and which can be expected to result in death or which has lasted or can be expected to last for a continuous period of not less than 12 months. (ii) Notwithstanding clause (i), no individual under the age of 18 who engages in substantial gainful activity may be considered to be disabled."^1^

These definitions make clear that across the age span considered for disability claims (i.e., birth to 62 years of age), disability determination depends on the functional limitations that an individual experiences, with respect to either employment in adults or major life activities of children or adolescents (for example, school or play). Therefore, in evaluations of individuals with speech and language disorders, the SSA is concerned with the concurrent relationship between the degree of impairment as measured by the assessment instrument and functional limitations associated with the speech or language impairment.

Another commonality in the definitions of disability in children and adults is that the disability must be expected to last for at least 12 months or to result in death during that period. This criterion leads to a second important concern for the SSA, which is to know what evidence is available for various speech and language assessment instruments regarding their predictive power for future functioning of an individual. Based on concerns related to the criteria and process for determining disability in children and adults, the SSA nominated two key questions as the basis for this report. Table 1 provides full specification of the key questions.

Table 1. Key Questions

Key Question | Core Elements
- What evaluation procedures for child and adult speech (voice, articulation/intelligibility, fluency) and language disorders have been demonstrated to have the salient characteristics of a good diagnostic tool (e.g., reliability, validity, appropriate normative data, responsiveness) for individuals who are/have:; - Are there evaluation procedures that have been demonstrated to have predictive validity for the individual's communicative impairment, performance, or both? | - English-speaking, have normal hearing, with or without normal cognition?; - Non-English-speaking, have normal hearing, with or without normal cognition?; - Mentally retarded?; - Learning disorders?; - Hearing impaired (i.e., hard of hearing)?

## Disability Associated with Speech and Language Disorders

### Epidemiology and Costs of Speech and Language Disorders

According to the National Institute on Deafness and Other Communication Disorders (NIDCD), approximately 42 million people (1 in 6) in the United States have some type of communication disorder.^2^ Of these, 28 million have communication disorders associated with hearing loss, and 14 million have disorders of speech, voice, and/or language not associated with hearing loss.

The personal and societal costs of these disorders are high. On a personal level, such disorders may affect nearly every aspect of daily life. Estimates of annual societal costs in the United States range from $30 billion^3^ to $154 billion^4^ in lost productivity, special education, and medical care.

### Speech Disorders

A speech disorder is a disorder affecting the articulation of speech sounds, the fluency with which speech is produced, or the quality of the voice. Articulation disorders (also called phonological disorders) include motor speech disorders and functional articulation disorders. Motor speech disorders result from damage to the central or peripheral nervous system. Damage may occur as the result of strokes, traumatic brain injury, or neurogenic diseases including Parkinson's disease, Huntington's disease, and amyotrophic lateral sclerosis; among children, the problems can arise from any of a range of prenatal, perinatal, and postnatal conditions, particularly those resulting in cerebral palsy.

Functional articulation disorders are those that either have no known cause or result from causes other than known neurological insults or physical abnormalities. In the majority of cases in children, articulation disorders fall into this category.^5^ They may stem from problems with the motoric component of speech production or from an internal representation of the phonological rule system of the target language that is immature or disordered. Among preschool and school-age children, articulation disorders are the most prevalent communication disorders, affecting approximately 10 percent of the population, and they are of sufficient severity to require treatment in 8 percent of the population. Among children with articulation disorders, 50 percent to 70 percent exhibit academic difficulties throughout the primary and secondary grades, reflecting at least in part the demonstrated relationship between early phonological disorders and later reading, writing, spelling, and mathematical achievement.

Long-term consequences can persist throughout the lifespan. Studies of adults who were diagnosed and treated for articulation disorders as children have revealed continuing difficulties in processing linguistic information, even though they seldom continued to show overt difficulties with speech sound production. These individuals are less likely to attend college and more likely to hold jobs that involve unskilled labor than their peers without a history of phonological disorder.^5^

Fluency disorders, also referred to as stuttering, involve an interruption in the flow of speaking manifested as an atypical rate, rhythm, repetitions in sounds, syllables, words, and phrases, or some combination of these. Secondary symptoms can include excessive tension, struggle behaviors, and odd behavioral mannerisms.^3^ Approximately 1 percent of the population (more than 3 million Americans) exhibits a fluency disorder that has persisted beyond 6 years of age.^6^ Children who stutter have a poorer educational adjustment and lower achievement than their peers who do not stutter. The disorder likely is vocationally handicapping as well, given the negative stereotypes of people who stutter and the fact that employers believe that stuttering decreases employability.^6^

Voice disorders are characterized by abnormal pitch, loudness, resonance, quality, or duration of voice, or by an inability to use one's voice, or some combinations of these factors. These disorders result from abnormal laryngeal, respiratory, or vocal tract functioning. They may be caused by habits of vocal misuse and hyperfunction (e.g., repeated clearing of one's throat, or prolonged talking over background noise) that produce physical changes in the vocal folds, by medical conditions (e.g., trauma, neurological disorders, allergies, or cancer), by psychological disorders (e.g., stress or personality disorders), or by a combination of these factors.^7^

Between 3 percent and 9 percent of the population of the United States has a voice disorder. Of the total working population in the United States, approximately 25 percent have jobs that critically require voice use.^3^ The majority of individuals diagnosed with voice disorders report that their voice problems have negatively affected past, current, and future job performance. Individuals in certain vocations and avocations, including teachers, singers, actors, cheerleaders, and aerobic exercise instructors, are particularly susceptible to voice disorders.^7^

### Language Disorders

A language disorder is the impaired comprehension and/or use of spoken, written, and/or other symbol systems used for communication. Between 6 and 8 million individuals in the United States have some form of language impairment.^3^ Approximately 1 million of these are adults with aphasia, an acquired impairment of language comprehension and/or expression caused by brain damage, usually secondary to strokes. A large proportion of the 2 million adults with progressive dementing diseases (e.g., Alzheimer's disease, Parkinson's disease) have significant language impairments. In addition, language impairments persist among adults who failed to develop normal language skills because of developmental or acquired disorders in childhood (e.g., specific language impairment, autistic disorder, hearing impairment). Approximately 8 percent to 12 percent of preschool children have some form of language impairment.

Specific language impairment (SLI) is defined as a significant deficit in language functioning that is not accompanied by any deficits in hearing, intelligence, or motor functioning that would explain the language deficit. Developmental language disorders tend to concentrate within families,^8,9^ and genetic factors have been implicated.^10^ The overall prevalence of SLI among kindergarten students is estimated at approximately 7 percent.^11^

Persistence of language impairment across time is more likely among children initially diagnosed with both receptive and expressive language impairments (65 percent to 100 percent with persisting disorders, as reported across studies) than among children initially diagnosed with expressive language impairments only (0 percent to 54 percent with persisting problems, as reported across studies). Children identified with language disorders as preschoolers are at great risk for learning disabilities at school age, and the vast majority of children identified at school age as learning disabled have concomitant language disorders. One study reported a prevalence rate of 90.5 percent for language disorders among 242 children between 8 and 12 years of age who had learning disabilities.^12^

The rate of comorbidity of psychiatric and communication disorders in children is high, particularly for children diagnosed with attention-deficit/hyperactivity disorder (ADHD).^13-15^ The comorbidity of these two types of disorders is frequently unsuspected. Cohen and colleagues found that of 399 children referred for psychiatric outpatient treatment, 25 percent had language impairments that were previously unsuspected, almost equal to the number with previously identified language impairments.^16^ The children with previously unsuspected language impairments had the most severe externalizing behavior problems (problems with adverse effects on property or other people), compared to children with identified language disorders or those without language disorders.

## Technical and Measurement Issues for Evaluation Tools

Important clinical decisions follow from the assessment of a person with a communication disorder. This assessment includes the nature of the disorder, the degree of impairment, the impact of the disorder on the individual's daily functioning and quality of life, the medical necessity of treatment, and the long-term prognosis for the individual's functional level. These clinical decisions affect an individual's access to services and funding (e.g., third-party payer coverage of treatment, eligibility for special education services, Social Security disability income). Thus, the quality of the evaluation procedures on which such decisions are based is an important issue for individuals with a communication disorder, the clinicians involved in their evaluation and treatment, and the policymakers with fiscal responsibilities for services to individuals with these disorders. This evidence report is directed to audiences who must grapple with this set of issues.

Previous reports on the quality of speech and language evaluation procedures are limited.^17,18^ The lack of evaluations of the quality of these procedures is understandable when the complexities and realities of speech and language disorders are considered.

### Technical Issues Related to Speech and Language Disorders

First, speech and language disorders are apparent across the lifespan, but in many cases the manifestations of the disorders vary at different ages or stages of development. These changes require clinicians and others to apply different evaluation procedures appropriate to the assessment of the disorders at different developmental and chronological stages.

Second, speech and language disorders are diverse in terms of both affected functions and etiology. With respect to affected functions, for instance, broad categories include disorders of speech sound production, voice, fluency, and language, as described above. Within the broad category of language, interrelated subcomponents including semantics (language meaning and vocabulary), syntax (phrase and sentence structure), and pragmatics (appropriate use of language in context) may be differentially affected.

Finally, language comprehension and production abilities will not necessarily be commensurate in a single individual. In addition, communication disorders will differentially affect abilities in different communication and language modalities, such as gesture or sign language, spoken language, and written language.

For etiology, clinicians distinguish between developmental and acquired disorders of speech and language. Developmental communication disorders are those apparent from early on in a child's life, such that speech or language (or both) do not develop as expected. Although these developmental disorders first appear in childhood, impaired communication affects many individuals with these disorders throughout their lives.

Acquired disorders are those that affect an individual (either child or adult) who already has an intact speech and language system or who was progressing normally in the development of such a system. These disorders usually result from neurological damage following such events as strokes or closed head injury, although they also can arise from other types of disease or events (e.g., laryngeal cancer, accidents affecting oral motor structures).

Other factors contribute to the complexity of evaluating speech and language disorders as well. First, speech and language impairments often coexist with and are related to other problems, such as hearing loss, mental retardation, ADHD, autism, cerebral palsy, Parkinson's disease, dementia, hemiplegia, and many others. These coexisting conditions often require that clinicians adapt standard speech and language evaluation procedures. In some cases, speech and language evaluation instruments have been developed specifically for individuals with particular coexisting disorders; a case in point is the Rhode Island Test of Language Structure developed for children with hearing impairments by Engen and Engen.^19^

Another major factor, which is increasingly important with the changing demographics in the United States, is that individuals being evaluated for speech and language disorders may speak a nonstandard dialect of English, or they may not be from an English-speaking cultural environment. For example, 24.4 percent of children in kindergarten to grade 3 had limited English proficiency in 1990.^20^ An estimated 6.2 million culturally and linguistically diverse Americans representing different minority groups in the United States have a communication disorder. To determine the presence, nature, and severity of a speech and language disorder, these individuals must undergo an evaluation that is appropriate for both their language and their culture. However, the task of identifying valid and reliable speech and language assessment instruments and procedures for people from different linguistic and cultural environments is a challenging one for clinicians.

### Measurement Issues

Assessment and diagnosis of individuals with suspected speech and language disorders is a process that involves posing a series of clinical questions and choosing the appropriate procedures and instruments to help answer those questions. Rarely, if ever, will a single assessment procedure or instrument be sufficient to ascertain a diagnosis, severity level, prognosis, and treatment recommendations for a speech or language disorder.

Posing clinical questions and choosing assessment procedures and instruments require clinical expertise and often will call for multidisciplinary assessments to clarify the nature of the speech or language disorder, its impact on functioning, and the long-term prognosis for the patient. Findings on standardized measures must be interpreted in light of other important clinical information. For example, two patients who have suffered from traumatic brain injuries may show similar performance profiles on a language measure, but their long-range prognoses could be very different depending on the variable such as the elapsed time interval since injury, the presence or absence of a seizure disorder, or the possible impact of medication on language functioning. Ultimately at issue is the reliability and validity of the entire clinical process in yielding accurate results and sound conclusions pertaining to the possible speech or language disorder.

During the assessment process, clinicians can use a wide variety of procedures and instruments. In almost every case, the assessment will involve an interview and a written questionnaire to obtain the clinical history of the patient. The interview may follow a structured format, or it may have a dynamic format that depends on the patient's responses. Standardized written questionnaires are available to aid in the evaluation of some disorders. In some cases, the patient completes the questionnaires; in others, an informant who is knowledgeable about the patient completes it.

Many standardized instruments are available to assess disorders of speech sound production and of language. In these instruments, the individual is asked to respond to a series of questions or tasks designed to elicit particular speech or language targets or to test perception or comprehension of particular targets. The examiner scores responses against standardized criteria for accuracy or appropriateness.

Another widely used procedure is observation of the patient's communication behaviors and the physiological or neurophysiological structures that underlie those behaviors. The observation may be recorded in some way (e.g., audio- or video-recording) for later analysis. The observed behavior can be analyzed in numerous ways, depending on the nature of the suspected disorder. For instance, if a child is suspected of having a disorder of speech sound production, then a sample of the child's conversational speech might be analyzed for percentage of correct consonants or evaluated for the percentage of speech that is intelligible to an unfamiliar listener. If an individual is suspected of having a fluency disorder, his or her spontaneous speech may be rated using an observational scale such as the Iowa Scale for Rating Severity of Stuttering.^21^ For someone who seems to have a problem with language production, the sample might be analyzed for variables such as mean length of utterance, diversity of vocabulary, or use of a variety of linguistic structures.

In some cases observing the structures or functions of interest is difficult, if not impossible, without the use of special instrumentation. For example, a computer-based system might be used to determine fundamental frequency, shimmer, and jitter for the voice of an individual who is being evaluated for a possible voice disorder. For the same individual, videostroboscopy might be used to observe the structure and function of the vocal folds. For an individual with a language disorder, structural or functional brain imaging (or both) may be a valuable tool for clarifying etiology, severity, and prognosis.

Measurement strategies and instruments will vary depending on the levels at which the disability is being evaluated. The recent terminology drafted by the World Health Organization (WHO) uses "impairment" to refer to problems in body function or structure, including psychological or linguistic functioning.^22^ "Activity limitations" refer to difficulties an individual may have in executing activities, and "participation restrictions" refer to problems an individual may experience in involvement in life situations. Traditionally, the focus of measurement has been the level of impairment of speech or language functions.

Contemporary practice, however, emphasizes assessment at the level of activity limitations and participation restrictions associated with speech and language impairments. Some standardized instruments have been developed to measure disability at these levels. For example, the Assessment of Intelligibility of Dysarthric Speech by Yorkston and Beukelman^23^ and the Functional Assessment of Communication Skills for Adults^24^ are measures that largely address speech or language disabilities at the level of activity limitations, whereas the Voice Handicap Index^25,26^ measures aspects of impairment, activity limitations, and participation restrictions.

The range of disorders, ages, and cultural or linguistic factors described above has prompted the development of a vast array of assessment instruments for speech, voice, and language. One source reviewing commercially available assessment instruments includes more than 140 tools in its most recent edition.^27^ Given the multiplicity of tools and the complexity of factors involved, the lack of a clear understanding of which speech and language evaluation procedures yield reliable and valid results is not surprising. Assessing individuals from English-speaking cultural environments who have no coexisting disorders is difficult; assessing individuals who have coexisting disorders or who come from non-English-speaking cultural environments is even more challenging.

Nevertheless, the quality of the speech and language evaluation procedures is of paramount importance for sound clinical decisionmaking and robust policies related to services for individuals with speech and language disorders. This report will clarify the existing knowledge base for a representative selection of speech, language, and voice assessment instruments used with children and adults, and it also will point the directions for future research.

## Organization of the Report

The remainder of this evidence report is organized in the following sections. Chapter 2 provides details about the process we used to select the instruments and our literature search and review methodology. Specifically discussed are the development and modification of key questions; the process for selection of the 18 instruments reviewed; our literature review and retrieval process, including electronic searches and abstract review, data abstraction from articles, and quality control procedures; and the application of a scheme of quality rating. Chapter 3 presents the results of our analyses by population and disorder (i.e., adult language disorders, child language disorders, adult speech disorders, child speech disorders, and voice disorders). Chapter 4 reflects on the results of our review and the conclusions that can validly be drawn to answer the SSA questions. It also includes an analysis of the usability of the selected instruments. Chapter 5 offers our recommendations for a research agenda on the development and validation of instruments to evaluate speech and language disorders in adults and children. References and Evidence Tables 1-72 with supporting information and a glossary follow the main text.

The appendices provide acknowledgments (Appendix A), information on our technical expert advisory group (TEAG) (Appendix B), the peer reviewers for this report (Appendix C), and a detailed description of our methodology (Appendix D).