# Appendix A: Acknowledgments

This study was supported by Contract No. 290-97-0011 Task No. 8 from the Agency for Healthcare Research and Quality (AHRQ). We acknowledge the assistance of Jacqueline Besteman, J.D., M.A., the AHRQ Task Order Officer for the Evidence-Based Practice Center Program, and Ernestine (Tina) Murray, R.N., M.A., the AHRQ Task Order Officer for this task. We also appreciate the cooperation and support of Sandra Z. Salan, M.D., the Social Security Administration liaison with AHRQ.

The Technical Expert Advisory Group (TEAG listed in Appendix B) played an integral and active role in shaping and producing the report. The following individuals from the SSA provided input to the investigators and the TEAG into the development of key clinical questions and the selection of the instruments reviewed: Janet Bendann; E. Lucinda Cassett-James, Ph.D; Paul Burgan, M.D.; Marquita Rand, Ph.D.; Roberta A. Schulman, Ph.D.; and Frank Schuster, M.D. We also appreciate the additional guidance provided by the 10 peer reviewers listed in Appendix C.

The investigators appreciate the time and efforts of our data abstractors. The methodologic abstractors were Michael Edwards, B.A., and Kelly Kandra, B.A., Anna Norwood, M.S., and Misty Raasch, M.S., evaluated the clinical usability of the instruments. Lynn Whitener, Dr.P.H., M.S.L.S., provided expert electronic search expertise to the data collection phase, and Joy R. Harris, B.A., and Christian J. Setzer, B.A., provided fundamental assistance during the data collection and abstraction phases of the project. Christopher J. Wiesen, Ph.D., and Carla M. Bann, Ph.D., provided invaluable assistance in the development of data abstraction forms and the psychometrically-based scheme for grading the evidence in this report. We are greatly indebted to Anne Jackman, M.S.W., for her capable project management and for the support of Timothy S. Carey, M.D., M.P.H., Co-Director of the RTI-UNC Evidence-based Practice Center.

Finally, we are grateful for the guidance and assistance we received from Jessica Nelson, B.A., for her project management support; Philib Salib, B.A. and Linda Lux, M.P.A., in preparing this report; Loraine Monroe for her outstanding word processing support; and Richard Strowd, J.D., for exceptional contracting support.