# Evidence Tables

Evidence Table 1. Basic characteristics of studies on training for public health events relevant to bioterrorism preparedness

Key question: | 1. Training clinicians to detect and manage a bioterrorist attack or other public health event
Public health model: | 1. Infectious disease outbreaks

Author, year, location | Type of health care professional | Clinician specialty | Training level | Participation | Objectives/goals | Conclusion
Author, year, location | Type of health care professional | Clinician specialty | Training level | Participation | Objectives/goals | Conclusion
Harrison, 2000 Africa | Nurse, clinic personnel, pharmacist | Not applicable | Professional | Not specified | To study the impact of health care worker training and sexually transmitted disease (STD) syndrome packets on the quality of STD case management in primary care clinics. | Overall improvement
Kemppainen, 1996 USA | Nurse | Not applicable | Professional | Voluntary | To educate about HIV and universal precautions. To improve willingness to care for patients with HIV. To test if different training methods increase nurses' willingness to provide care to patients with AIDS. | No improvement
Garcia, 1998 Mexico | Pharmacist, licensed pharmaceutical salesperson | Not applicable | Professional | Voluntary | To improve recognition of STD syndromes. To improve knowledge of recommended algorithms for management of these syndromes. To increase physician referral for management of STDs. To increase frequency of counseling to reduce high-risk behaviors. | Some change
Gerbert, 1991 USA | Dentist | Not applicable | Professional | Voluntary | To evaluate the medical response to the AIDS epidemic using proven methods. | Overall improvement
Zimmerman, 1997 USA | Physician, medical students | Family medicine, pediatrics | Graduate, resident | Not specified | To develop and evaluate case-based curriculum materials on immunizations that promote preventive medicine skills in order to improve vaccination rates. To address general knowledge about vaccine-preventable diseases, indications for vaccination, known barriers to vaccination, and methods to improve vaccination rates. | Overall improvement
Umble, 2000 USA | Nurse, physician, public health professional | Not applicable | Professional | Not specified | To increase health care workers' adherence to immunization based on new guidelines (focusing on new polio vaccine). | Overall improvement
Maetz, 1998 USA | Nurse, public health department employee | Not applicable | Professional | Not specified | To enhance the effectiveness of tuberculosis control personnel by providing instruction on tuberculosis transmission and pathogenesis, epidemiology, diagnosis, treatment, and infection control. | Overall improvement
Russell, 1991 USA | Physician | Internal medicine, obstetrics and gynecology, general practitioners | Professional | Incentive-based | To have physician self-reports of HIV/STD counseling validated by a standardized-patient evaluator. To reinforce STD/HIV prevention skills of primary care physicians in office-based practices. | Unclear
Epstein, 2001 USA | Physician | Family medicine, internal medicine, pediatrics | Professional | Voluntary | To evaluate two different office-based educational programs, using feedback from standardized patients to improve doctors' HIV communication skills. | Overall improvement
Lewis, 2000 Europe | Dentist, dental hygienist | Not applicable | Professional | Voluntary | To educate dental staff about the care and clinical management of people living with HIV. | Overall improvement
Bowman, 1992 USA | Physician | Family medicine, internal medicine, obstetrics and gynecology | Professional | Voluntary | To improve the STD/HIV prevention skills of practicing physicians through educational materials. | Unclear
Armstrong-Esther, 1989 Canada | Nurse | Not applicable | Undergraduate | Mandatory | To examine whether an intense education program changes knowledge and/or attitudes among nurses. | Overall improvement
Bennett, 1997 Europe | Midwives | Midwives | Professional | Voluntary | To facilitate midwives offering voluntary HIV testing of women attending antenatal clinics. | No improvement
Paauw, 1995 USA | Physician | Family medicine, internal medicine | Professional | Voluntary | To assess the ability of the primary care physician to identify three common physical findings associated with HIV. | Unclear
Talan, 1990 USA | Nurse | Emergency medicine | Professional | Not specified | To increase knowledge of HIV occupational risk and compliance with universal precautions. | Mixed
Lewis, 1993 USA | Physician | Family medicine, internal medicine, obstetrics and gynecology | Professional | Mandatory | To help practitioners recognize and overcome discomfort associated with taking sexual history when interviewing HIV-infected patients. To underline importance of affective domain in determining competency in dealing with HIV patients. To review prevention and control of nosocomial transmission of HIV. | Mixed
Green, 1998 Jamaica | Nurse, physician, other health care providers | Internal medicine, pediatrics, general practice, gynecology, public health, dermatology, other | Graduate, professional | Voluntary | To improve STD case management, specifically reporting and notification to reduce the transmission of HIV. | ?Mixed
Zell, 1997 Thailand | Physician | Internal medicine, pediatrics, psychiatry, infectious diseases, obstetrics and gynecology | Resident, professional | Voluntary | To examine the efficacy of medical education methods in improving the knowledge base and clinical skills of participants regarding HIV infection. | Overall improvement
Osborn, 1999 USA | Physician | Not applicable | Graduate | Mandatory | To teach universal precautions and exposure prevention. To teach essentials of bedside clinical procedures (i.e. phlebotomy, intravenous catheter insertion, arterial blood sampling, and blood cultures). | Unclear
Fischer, 2000 USA | Dentist, nurse, physician, clinic manager, medical chief, other health care providers | Primary care | Professional | Incentive-based, voluntary, continuing education | To provide basic information about the diagnosis and treatment of hepatitis C to primary care physicians and nurses (both registered nurses and licensed practical nurses). | Overall improvement
Ofori-Adjei, 1996 Africa | Community health worker | Not applicable | Professional | Not specified | To educate medical assistants on the clinical features, diagnosis, and treatment of malaria. To ensure proper management of disease at health centers. To determine if a didactic teaching approach to inservice training will change treatment practices. | Overall improvement
Soudarssanane, 1994 Asia | Medical students | | Graduate | Mandatory | To improve teaching about acute diarrheal diseases. | Partial improvement
Cohen, 1996 USA | Dentist, dental hygienist and assistant, office staff | Not applicable | Professional | Not specified | To determine the impact of a series of traditional 1-day AIDS continuing education courses. | Overall improvement
Tuladhar, 1998 Asia; Nepal | Pharmacist | Not applicable | Professional | Not specified | To learn to recognize the most common STD symptoms and treat according to national STD syndromic management guidelines. To dispense drugs according to national STD syndromic management guidelines. To communicate to clients the importance of completing drug regimens, referring sexual partners for treatment, using condoms, and consulting physicians if symptoms persist. | Overall improvement
Sowell, 1998 USA | Nurse | Not applicable | Professional | Incentive-based, voluntary | To provide HIV/AIDS specific continuing education to nurse practitioners and nurses working in rural communities. | Overall improvement
Hartnett, 1987 USA | Nurse | Not applicable | Professional | Not specified | To increase nurses' knowledge about AIDS and confidence about caring for AIDS patients. | Overall improvement
Delacollette, 1996 Africa | Community health worker | Not applicable | Not specified | Voluntary, symbolic monetary reimbursement | To train community health workers to use a simple treatment algorithm to recognize and locally manage patients with fever (malaria). | Unclear
O'Donnell, 1987 USA | Nurse, physician, social worker, technician | Not applicable | Resident, professional | Voluntary | To evaluate the extent to which attendance at an inservice program is associated with improvements in AIDS-related knowledge and with decreases in negative attitudes. | Overall improvement
Anderson, 1997 USA | Medical student | Not applicable | Graduate | Not specified | To evaluate whether the amount HIV-related didactic and clinical training alters a willingness to treat HIV-infected individuals. | Unclear
Breman, 1977 Africa | Medical and paramedical personnel | Not applicable | Professional | Not specified | To eradicate smallpox from one of the world's major smallpox foci. | Overall improvement
Ray, 1991 Asia | Physician, epidemiologist | Pediatrics, pathology, epidemiology, public health | Professional | Not specified | To prevent deaths from malaria by training community-based physicians. | Overall improvement
Inglesby, 2001 USA | Medical and public health personnel | Emergency medicine internal medicine, health department officers, emergency management professionals, Federal health agencies, infectious disease specialists | Professional | Mandatory | To test the medical and public health system and infrastructure. To conduct an exercise engaging key personnel in the management of mock chemical, biological, or cyber attacks. To test the readiness of top government officials to respond to terrorist attacks at multiple geographic locations. | Unclear
Lieb, 1996 USA | Nurse, ancillary personnel | Not applicable | Not specified | Mandatory | To develop an efficient and effective training program that provides both initial and annual training for tuberculosis prevention and control. | Overall improvement
Kaur, 1998 Asia | Nurse | Not applicable | Graduate | Not specified | To educate nurses about HIV transmission and AIDS prevention. To address misconceptions regarding AIDS/HIV. | Overall improvement
Kark, 1973 Asia | Nurse, physician, undergraduates, health educators | Not applicable | Graduate | Not specified | To use an epidemiologic, practical approach to planning, providing and evaluating a community approach in primary health care. To become acquainted with different forms of personal health care and the possibility of developing a community orientation for any primary health service. To have experience in practical implementation of a community approach in primary health care. To incorporate field work. | Overall improvement
Katsufrakis, 1992 USA | Physician, physician assistant | Not applicable | Professional | Voluntary | To supply primary care physicians with the knowledge and skills necessary to manage the complications of HIV infection commonly seen in an outpatient setting. To increase the number of clinicians working with HIV-infected patients in the community. | Unclear
Pandit, 1991 India | Physician | Family medicine | Resident | Mandatory | To judge the knowledge of medical interns about immunization guidelines. | Overall improvement
Cydulka, 1991 USA | First responder | Not applicable | Professional | Not specified | To educate first responders about hepatitis B and AIDS transmission and prevention. | Overall improvement
Novick, 1985 USA | Medical student | Not applicable | Graduate | Mandatory | To improve medical student satisfaction with epidemiology and public health courses. | Unclear
Simoes, 1997 Ethiopia | Community health worker | Not applicable | Professional | Not specified | To use a novel course to teach management of sick infants and young children in primary care settings that have limited resources. | Overall improvement
Lloyd, 1999 Africa | Physician | Not specified | Professional | Not specified | To educate physicians to recognize, isolate, diagnose, and report patients with suspected viral hemorrhagic fever. To implement viral hemorrhagic fever isolation procedures. To provide physicians with equipment to obtain postmortem skin specimens which provide laboratory confirmation of viral hemorrhagic fever infection. To train physicians to begin followup investigations of suspected and laboratory-confirmed cases of viral hemorrhagic fever infection. | Overall improvement
Dorman, 1990 USA | Nurse, allied health?student (or professional), premedical student | Not applicable | Undergraduate | Voluntary | To provide comprehensive HIV education to health care and other students in professional preparation programs. | Overall improvement
Hixon, 1990 USA | Nurse | Infection control/ infectious disease | Professional, other (11% of participants) not specified | Mandatory: Florida State nursing regulations | To determine if nursing education and quality assurance change clinical nursing practice and knowledge of HIV/AIDS. To improve knowledge of HIV/AIDS. | Overall improvement
Roos, 1995a Asia | Community health worker | Not applicable | Professional | Not specified | To prepare health workers to manage leprosy in an integrated fashion. | Overall improvement
Millward, 1993 Europe | Nurse | Not applicable | Professional | Not specified | To determine whether staff on wards with infection control link nurses are more knowledgeable about infection control than on wards without link nurses. To examine the relationship between the knowledge of nurses and their ward audit score. | Unclear
Kidd, 1999 USA | Nurse, physician, hospital staff | Not applicable | Resident, professional | Mandatory | To implement the Centers for Disease Control and Prevention guidelines for isolation, standard precautions, and transmission-based precautions. | Overall improvement
Brown, 1990 USA | Nurse, physician, social worker, physical therapist | Not applicable | Professional | Incentive-based | To train health care workers about AIDS and meet State educational requirements. | Unclear
Meisenhelder, 1994 USA | Nurse | Not applicable | Professional | Not specified | To teach about HIV disease and treatment and to decrease fear of HIV contagion. | Mixed results
Jacobson, 1986 USA | Nurse, physician, clerk | Not applicable | Resident, professional | Mandatory | To improve ordering of isolation, through use of a hospital computerized information system using Centers for Disease Control and Prevention guidelines for disease-specific isolation. | Overall improvement
All, 1997 USA | Nurse | Not applicable | Undergraduate, graduate | Not specified | To teach about HIV, including transmission of HIV, high-risk populations, concepts in managing cases, and prevention and control strategies. | Overall improvement
Odhacha, 1998 Africa | Health care worker | Not applicable | Professional | Not specified | To train non-physician health workers to evaluate sick children presenting to a first-level health facility with respiratory infections, diarrhea, malaria, measles, and malnutrition. | Unclear
Boskovich, 1994 USA | Community health worker, social worker | Not applicable | Professional | Not specified | To train community workers to read and report reactive tuberculin skin tests. | Unclear
Roos, 1995b Nepal | Community health worker | Not applicable | Professional | Not specified | To prepare, train, and evaluate training of community-based health care workers for an integrated approach to leprosy care. To evaluate the training according to facility-based assessment. | Unclear

Key question: | 1. Training clinicians to detect and manage a bioterrorist attack or other public health event
Public health model: | 2. Toxidromes and mass poisonings

Anderson, 1984 USA | First responder | Not applicable | Not specified | Voluntary | To highlight elements that improve the diagnosis and management of the poisoned patient using teleconferencing. | Unclear

Key question: | 1. Training clinicians to detect and manage a bioterrorist attack or other public health event
Public health model: | 4. Events that call for a hospital disaster plan

Cook, 1990 USA | Nurse, physician, technologist (e.g., radiology or emergency room technician), clerk | Emergency medicine, surgery, radiology | Not specified | Mandatory | To convert a disaster drill to a game in order to train hospital staff more effectively. | Overall improvement
Tur-Kaspa, 1999 Asia | Nurse, physician | Hospital staff | Professional | Mandatory | To train hospital employees and improve hospital preparedness for patient management under mass casualty conditions involving hazardous chemicals. | Overall improvement
Gofrit, 1997 Middle East | Physician | Emergency medicine, surgery, military | Professional | Not specified | To evaluate the effectiveness and applicability of the written disaster preparedness programs that use specially trained simulated casualties to enhance training for and evaluation of hospital disaster drills. To assess the availability of supplies, equipment, and personnel. | Overall improvement
Naggan, 1976 Israel | Physician | Emergency medicine, military medicine, surgery | Professional | Mandatory | To prepare hospitals for an emergency medical crisis. | Overall improvement
Levi, 1998 Asia | Hospital management staff | Not applicable | Professional | Not specified | To evaluate the hospital's disaster plan without activating the system. To train the decisionmakers about disaster plan implementation. To assist in managing real situations by identifying bottlenecks and evaluating possible solutions. | Unclear

Key question: | 3. Training clinicians to report events to a central agency
Public health model: | 1. Infectious disease outbreaks

Durrheim, 2001 Africa | Nurse | Infection control | Professional | Regulatory | To determine the contribution of infection control nurses to improving surveillance for infectious syndromes that require an immediate public health response in Mpumalanga province. | Overall improvement

Evidence Table 2. Characteristics of educational programs and evaluation methods used in training for public health events relevant to bioterrorism preparedness

Key question: | 1. Training clinicians to detect and manage a bioterrorist attack or other public health event
Public health model: | 1. Infectious disease outbreaks

Author, year | Group | Description of groups | Educational methods | Intervention design | Contact time (T) and intervention duration (D) | Followup time | Evaluation methods
Author, year | Group | Description of groups | Educational methods | Intervention design | Contact time (T) and intervention duration (D) | Followup time | Evaluation methods
Harrison, 2000 | Intervention | Five clinics with an intervention that included education and infrastructure development (N=not specified). | Workshop, standardized patients | Groups | T=>20 hours D=not specified | Not specified | Performance audits, patient questionnaires, simulated patients
Harrison, 2000 | Control | Five clinics with no intervention (N=not specified). | Workshop, standardized patients | Groups | T=>20 hours D=not specified | Not specified | Performance audits, patient questionnaires, simulated patients
Kemppainen, 1996 | Intervention | Nurses given training sessions and group discussion (N=12). | Clinical experiences, discussions, lectures | Groups | T=2-10 hours D=1-29 days | 1-12 months | Participant questionnaires
Kemppainen, 1996 | Intervention | Nurses given training session and patient contact (N=12). | Clinical experiences, discussions, lectures | Groups | T=2-10 hours D=1-29 days | 1-12 months | Participant questionnaires
Kemppainen, 1996 | Control | Nurses given training session only (N=not specified). | Clinical experiences, discussions, lectures | Groups | T=2-10 hours D=1-29 days | 1-12 months | Participant questionnaires
Garcia, 1998 | Intervention | Ninety pharmacies received intervention. | Lectures, readings, role plays | Groups | T=2-10 hours D=1-12 months | 1-12 months | Performance audits, audits by standardized simulated patients
Garcia, 1998 | Control | Ninety pharmacies received no intervention. | Lectures, readings, role plays | Groups | T=2-10 hours D=1-12 months | 1-12 months | Performance audits, audits by standardized simulated patients
Gerbert, 1991 | Intervention | Pilot: Dentists had individualized feedback, comparing participant's pretest results with those of fellow participants and with an ideal; informative bulletins; and telephone conference calls with experts (N=36). | Individualized feedback of the pre-intervention scores, AIDS information line and bulletin | Individuals, groups | T=not specified D=>1 year | >1 year | Participant questionnaires, surveys
Gerbert, 1991 | Control | Pilot: Dentists given no intervention (N=66). | Individualized feedback of the pre-intervention scores, AIDS information line and bulletin | Individuals, groups | T=not specified D=>1 year | >1 year | Participant questionnaires, surveys
Gerbert, 1991 | Intervention | Nationwide: One group received individualized feedback, information telephone line, and bulletin (N=30); second group received feedback and bulletins (N=30); third group received only bulletins (N=70). | Individualized feedback of the pre-intervention scores, AIDS information line and bulletin | Individuals, groups | T=not specified D=>1 year | >1 year | Participant questionnaires, surveys
Gerbert, 1991 | Control | Nationwide: Randomly selected dentists who did not receive any training (N=244). | Individualized feedback of the pre-intervention scores, AIDS information line and bulletin | Individuals, groups | T=not specified D=>1 year | >1 year | Participant questionnaires, surveys
Zimmerman, 1997 | Intervention | Medical students and physicians participated in multi-station clinical teaching scenarios: small group sessions with questions about scenarios (N=767). | Audio-visual, discussions, programmed learning, readings | Groups | T=3 hours D=<1 day | Not specified | Performance audits, participant questionnaires
Zimmerman, 1997 | Intervention | Medical students and physicians given problem-based learning: small group sessions (6-12 students) with cases (N=355). | Audio-visual, discussions, programmed learning, readings | Groups | T=3 hours D=<1 day | Not specified | Performance audits, participant questionnaires
Umble, 2000 | Intervention | Health care professionals who received classroom course (N=196). | Audio-visual, discussions, lectures, problem-based learning | Groups | T=11-20 hours D=1-12 months | 1-12 months | Participant questionnaires
Umble, 2000 | Intervention | Health care professionals who received satellite broadcast (N=116). | Audio-visual, discussions, lectures, problem-based learning | Groups | T=11-20 hours D=1-12 months | 1-12 months | Participant questionnaires
Maetz, 1998 | Intervention | Enrollees viewed a "satellite primer" and received written material (N=3,452). | Audio-visual, discussions, satellite conferences, self-study print modules, lectures, programmed learning, readings, drill/practice exercises | Groups | T=2-10 hours D=1-12 months | 1-12 months | Participant questionnaires
Russell, 1991 | Intervention | Physicians visited by standardized patient evaluator following a disease prevention continuing education program (N=194). | Standardized patients | Individuals | T=<2 hours D=1-12 months | <1 day | Performance audits, standardized patient evaluators
Epstein, 2001 | Intervention | Physicians randomly assigned to an announced standardized patient visit (N=12). | Audio-visual, manual, lectures, role plays, standardized patients | Groups | T=2-10 hours D=1-12 months | 1-12 months | Performance audits, participant questionnaires test/feedback
Epstein, 2001 | Control | Physicians randomly assigned to an unannounced standardized patient visit (N=11). | Audio-visual, manual, lectures, role plays, standardized patients | Groups | T=2-10 hours D=1-12 months | 1-12 months | Performance audits, participant questionnaires test/feedback
Lewis, 2000 | Intervention | Senior dental staff attended intensive training course (N=10). | Audio-visual, discussions, forums with infected patients, lectures, role plays, drill/practice exercises | Groups | T=11-20 hours D=1-29 days | >1 year | Participant questionnaires
Bowman, 1992 | Intervention | Physicians received education materials (N=317). | Readings, standardized patients | Individuals | T=not specified D=1-12 months | 1-12 months | Individual interviews, performance audits
Bowman, 1992 | Intervention | Physicians received education materials and an office visit by a simulated patient (N=321). | Readings, standardized patients | Individuals | T=not specified D=1-12 months | 1-12 months | Individual interviews, performance audits
Bowman, 1992 | Control | Not described (N=323). | Readings, standardized patients | Individuals | T=not specified D=1-12 months | 1-12 months | Individual interviews, performance audits
Armstrong-Esther, 1989 | Intervention | Student nurses enrolled in an epidemiology class (N=60). | Audio-visual, lectures | Groups | T=not specified D=1-12 months | 1-12 months | Participant questionnaires, written exam
Armstrong-Esther, 1989 | Control | Student nurses from the same institution given a comparable test in previous years (N=not specified). | Audio-visual, lectures | Groups | T=not specified D=1-12 months | 1-12 months | Participant questionnaires, written exam
Bennett, 1997 | Intervention | Randomly sampled midwives received training (N=33). | Not specified | Groups | T=not specified D=not specified | >1 year | Participant questionnaires
Bennett, 1997 | Control | Randomly sampled midwives received no training (N=32). | Not specified | Groups | T=not specified D=not specified | >1 year | Participant questionnaires
Paauw, 1995 | Intervention | Randomly selected physicians, 50% in primary care, graduated in or after 1967 (N=134). | Standardized patients | Groups | T=2-10 hours D=not specified | Not specified | Performance audits
Talan, 1990 | Intervention | Emergency department nurses given an inservice lecture (N=24). | Lectures | Groups | T=<2 hours D=<1 day | 1-12 months | Performance audits, participant questionnaires
Lewis, 1993 | Intervention | Physicians given educational materials and workshop (N=54). | Audio-visual, discussions, interaction with HIV-infected physicians, lectures, role plays | Groups | T=2-10 hours D=1-12 months | 1-12 months | Individual interviews, performance audits, participant questionnaires
Lewis, 1993 | Intervention | Physicians given printed materials only (N=106). | Audio-visual, discussions, interaction with HIV-infected physicians, lectures, role plays | Groups | T=2-10 hours D=1-12 months | 1-12 months | Individual interviews, performance audits, participant questionnaires
Lewis, 1993 | Control | Physicians given no material or intervention (N=93). | Audio-visual, discussions, interaction with HIV-infected physicians, lectures, role plays | Groups | T=2-10 hours D=1-12 months | 1-12 months | Individual interviews, performance audits, participant questionnaires
Green, 1998 | Intervention | Comprehensive continuing medical education seminars (N=628). | Discussions, lectures, readings | Groups | T=>20 hours D=1-29 days | 1-12 months | Participant questionnaires
Zell, 1997 | Intervention | Interested physicians solicited from Ministry of Public Health hospitals (4-8 per course) (N=57). | Audio-visual, clinical experiences, bedside teaching rounds, meet-the-professor sessions, lectures | Groups | T=11-20 hours D=1-29 days | Not specified | Participant questionnaires, written exam
Osborn, 1999 | Intervention | Third and fourth year medical students over 6 years, who received education and skill labs (N=1,022). | Audio-visual, demonstrations, discussions, lectures | Groups | T=not specified D=1-29 days | Not specified | Hotline reports
Fischer, 2000 | Intervention | 68% of health care workers at four clinics of a health maintenance organization attended (N=597) a seminar, and 84% were screened for infection (N=501). | Audio-visual, lectures, readings | Groups | T=<2 hours D=<1 day | <1 day | Participant questionnaires
Fischer, 2000 | Intervention | 61% of health care workers attended from 13 staff model and affiliated clinics (N=534). | Audio-visual, lectures, readings | Groups | T=<2 hours D=<1 day | <1 day | Participant questionnaires
Ofori-Adjei, 1996 | Intervention | Medical assistants given early training (N=26). | Clinical experiences, discussions, lectures | Groups | T=2-10 hours D=>1 year | > 1 year | Group interviews, performance audits, participant questionnaires, focus group discussions
Ofori-Adjei, 1996 | Intervention | Medical assistants given late training (N=12). | Clinical experiences, discussions, lectures | Groups | T=2-10 hours D=>1 year | > 1 year | Group interviews, performance audits, participant questionnaires, focus group discussions
Ofori-Adjei, 1996 | Control | Medical assistants given no training (N=2). | Clinical experiences, discussions, lectures | Groups | T=2-10 hours D=>1 year | > 1 year | Group interviews, performance audits, participant questionnaires, focus group discussions
Soudarssanane, 1994 | Intervention | Medical students in the first clinical year learned epidemiology using detailed lesson plan (N=165). | Audio-visual, discussions, samples, lectures, readings | Groups | T=<2 hours D=<1 day | ?Not specified | Written exam
Cohen, 1996 | Intervention | Dentists, hygienists, dental assistants, receptionists, and others enrolled in a course (N=843). | Lectures | Groups | T=2-10 hours D=1-12 months | 1-12 months | Participant questionnaires
Tuladhar, 1998 | Intervention | Received a curriculum on case management guidelines (N=160). | Not specified | Not specified | T=not specified D=1-12 months | 1-12 months | Simulated patient
Sowell, 1998 | Intervention | Nurses and nurse practitioners in rural areas received continuing education program (52% of 173 questionnaires returned; N=90). | Clinical experiences, discussions, lectures | Groups | T=>20 hours D=>1 year | >1 year | Participant questionnaires
Hartnett, 1987 | Intervention | Nurses on multiple units (N=68 [47 registered nurses, 21 licensed practical nurses]). | Posters, lectures | Groups | T=not specified D=not specified | Not specified | Participant questionnaires
Delacollette, 1996 | Intervention | Community health workers received inservice training on use of a simple algorithm for disease management (N=12). | Not specified | Not specified | T=>20 hours D=>1 year | >1 year | Morbidity and mortality statistics
Delacollette, 1996 | Control | No intervention (N=not specified). | Not specified | Not specified | T=>20 hours D=>1 year | >1 year | Morbidity and mortality statistics
O'Donnell, 1987 | Control | Employees responding before intervention (71% response rate, N=227). | Discussions, others (unclear) | Groups | T=not specified D=1-12 months | Not specified | Participant questionnaires
O'Donnell, 1987 | Intervention | Employees responding after intervention (65% response rate, N=208). | Discussions, others (unclear) | Groups | T=not specified D=1-12 months | Not specified | Participant questionnaires
Anderson, 1997 | Intervention | Training at a school of medicine (73% of 128 surveys completed, N=94). | Clinical experiences, lectures | Not specified | T=not specified D=not specified | Not specified | Participant questionnaires
Anderson, 1997 | Intervention | Training at a school of medicine (54% of 76 surveys completed, N=41). | Clinical experiences, lectures | Not specified | T=not specified D=not specified | Not specified | Participant questionnaires
Anderson, 1997 | Intervention | Training at a school of medicine (50% of 80 surveys completed, N=40). | Clinical experiences, lectures | Not specified | T=not specified D=not specified | Not specified | Participant questionnaires
Breman, 1977 | Intervention | Medical and paramedical personnel assigned to a vaccination program (N=not specified). | 11-day training course, drill/practice exercises | Groups | T=11 days D=1-29 days | >1 year | Performance audits, surveillance of smallpox cases
Ray, 1991 | Intervention | Participants in an orientation course for medical officers (N=20). | Drill/practice exercises | Individuals, groups | T=>20 hours D=>1 year | Not specified | Group interviews
Ray, 1991 | Intervention | Participants in "workshops" for management of severe disease (N=20). | Drill/practice exercises | Individuals, groups | T=>20 hours D=>1 year | Not specified | Group interviews
Inglesby, 2001 | Intervention | Selected medical and public health personnel (N=not specified). | Role plays, drill/practice exercises | Groups | T=not specified D=1-29 days | Not specified | Individual interviews performance audits, observer/rater questionnaire
Lieb, 1996 | Intervention | Training of nurses, respiratory care professionals, dietitians, social workers, housekeepers, phlebotomists, medical laboratory technicians (N=167). | Self-paced learning stations | Groups | T=<2 hours D=not specified | 1-29 days | Participant questionnaires, written exam
Kaur, 1998 | Intervention | First/second/third year nursing students attended a satellite regional workshop (N=150). | Lectures | Groups | T=not specified D=not specified | Not specified | Participant questionnaires
Kark, 1973 | Intervention | Masters of Public Health (MPH) students taking a field workshop on community medicine and primary health care (N=not specified). | Clinical experiences, discussions, tour of facilities, group projects, lectures, readings, problem-based learning | Groups | T=>20 hours D=1-12 months | <1 day | Participant questionnaires, self-assessment, evaluation of project reports
Katsufrakis, 1992 | Intervention | Physicians and physician assistants taking a clinical preceptorship on HIV care (N=21). | Clinical experiences, readings | Individuals | T=>20 hours D=1-29 days | 1-12 months | Individual interviews, followup assessment of knowledge and practice patterns (not otherwise specified)
Pandit, 1991 | Intervention | Four groups of 25 resident physicians (9 non-completers); 3&#8209;month clinical rotation in community medicine (N=91). | Not specified | Groups | T=not specified D=1-12 months | Not specified | Participant questionnaires
Cydulka, 1991 | Intervention | Paramedics attending an AIDS educational module (N=420). | Lectures | Groups | T=not specified D=not specified | <1 day | Participant questionnaires
Novick, 1985 | Intervention | Third year medical students taking an epidemiology course (N=90). | Lectures, drill/practice exercises | Groups | T=>20 hours D=1-29 days | Not specified | Not specified
Simoes, 1997 | Intervention | Primary health workers trained to use integrated management of childhood illness guidelines chart (N=6). | Audio-visual, clinical experiences, discussions, counseling cards for the illiterate, lectures, readings, role plays, drill/practice exercises | Groups | T=>20 hours D=1-12 months | 1-29 days | Performance audits
Lloyd, 1999 | Intervention | Physicians from 17 (of 22) health zones in the area (N=28). | 3-day workshop | Groups | T=not specified D=1-12 months | 1-12 months | Individual interviews, participant questionnaires
Dorman, 1990 | Intervention | Students in an elective undergraduate course (N~120). | Audio-visual, discussions, lectures | Groups | T=>20 hours D=1-12 months | 1-12 months | Essays
Hixon, 1990 | Intervention | Nurses who received an educational program, 22 sessions (N=800). | Audio-visual, discussions, question-and-answer sessions, interactive game, lectures | Groups | T=2-10 hours D=1-12 months | Not specified | Performance audits, participant questionnaires, observer/rater questionnaire, written exam
Roos, 1995a | Intervention | Basic health services staff received a comprehensive training course (N=not specified). | Not specified | Groups | T=not specified D=1-29 days | 1-12 months | Individual interviews, performance audits, participant questionnaires, observer/rater questionnaire, self-assessment, patient interviews, inventory of equipment and supplies
Roos, 1995a | Control | Staff in a neighboring district that did not receive the training course (N=not specified). | Not specified | Groups | T=not specified D=1-29 days | 1-12 months | Individual interviews, performance audits, participant questionnaires, observer/rater questionnaire, self-assessment, patient interviews, inventory of equipment and supplies
Millward, 1993 | Intervention | Nurses from wards staffed with a "link" nurse (with higher training in infection control) (N=not specified). | Not specified | Not specified | T=not specified D=not specified | Not specified | Performance audits, written exam
Millward, 1993 | Control | Nurses from wards without a "link" nurse (N=not specified). | Not specified | Not specified | T=not specified D=not specified | Not specified | Performance audits, written exam
Kidd, 1999 | Intervention | Hospital employees who received training (N=not specified). | Audio-visual, customized inservices, lectures, readings | Individuals, groups | T=not specified D=1-12 months | Not specified? | Performance audits
Brown, 1990 | Intervention | Employees and medical staff of a non-profit hospital and members of the community taking a course (N=not specified). | Audio-visual, lectures | Groups? | T=7 hours D=<1 day | <1 day | Participant questionnaires
Meisenhelder, 1994 | Intervention | Employees received training at a 1-day conference (N=39). | Discussions, lectures | Groups | T=11-20 hours D=1-29 days | 1-29 days | Participant questionnaires
Meisenhelder, 1994 | Intervention | Received a once-a-week class (N=15). | Discussions, lectures | Groups | T=11-20 hours D=1-29 days | 1-29 days | Participant questionnaires
Jacobson, 1986 | Intervention | Hospital staff received inservice training using hospital computerized information systems (N=not specified). | Instruction cards placed at terminals, not specified | Not specified | T=not specified D=not specified | Not specified | Prevalence survey (before and after)
All, 1997 | Intervention | Received presentation (N=39). | Not specified | Groups | T=not specified D=not specified | <1 day | Participant questionnaires
Odhacha, 1998 | Intervention | Health workers trained in the Integrated Management of Childhood Illness guidelines (N=not specified). | Not specified | Not specified | T=not specified D=not specified | 1-12 months | Individual interviews, performance audits, observer/rater questionnaire
Boskovich, 1994 | Intervention | Community workers receiving training in how to read and report tuberculin skin tests (N=20). | Audio-visual, discussions, readings | Groups | T=not specified D=not specified | 1-12 months | Performance audits
Roos, 1995b | Intervention | Pilot district community health workers received comprehensive training course to prepare health care workers for integrated, disease-specific work (N=not specified). | Not specified | Groups | T=6 days D=not specified | 1-12 months | Performance audits, participant questionnaires, assessment of infrastructure
Roos, 1995b | Control | Neighboring district health workers had no course (N=not specified). | Not specified | Groups | T=6 days D=not specified | 1-12 months | Performance audits, participant questionnaires, assessment of infrastructure

Key question: | 1. Training clinicians to detect and manage a bioterrorist attack or other public health event
Public health model: | 2. Toxidromes and mass poisonings

Anderson, 1984 | Intervention | Emergency medical service volunteers underwent teleconferencing education program (N=1,200). | Audio-visual, discussions, teleconference, lectures | Groups | T=<2 hours D=<1 day | <1 day | Participant questionnaires

Key question: | 1. Training clinicians to detect and manage a bioterrorist attack or other public health event
Public health model: | 4. Events that call for a hospital disaster plan

Cook, 1990 | Intervention | Hospital underwent a disaster drill (N=not specified). | Outlines/checklists, readings, standardized patients, drill/practice exercises | Groups | T=not specified D=<1 day | Not specified | Group interviews, observer/rater questionnaire
Tur-Kaspa, 1999 | Intervention | Hospitals underwent full practice drills (N=21). | Drill/practice exercises | Groups, hospital | T=not specified D=not specified | Not specified | Observer/rater questionnaire
Gofrit, 1997 | Intervention | Military doctors at eight hospitals (senior level), completing an advanced trauma life support course; eight full scale hospital disaster drills using military physicians as "smart casualties" (N=178). | Simulated smart casualties, drill/practice exercises | Groups | T=not specified D=not specified | Not specified | Group interviews, performance audits, hospital debriefing session
Naggan, 1976 | Intervention | Hospitals (N=not specified). | Drill/practice exercises | Groups | T=not specified D=not specified | Not specified | Mortality rates, other evaluation methods not specified
Levi, 1998 | Intervention | Hospital staff participated in limited scale drill using simulation software. | Computer models, computer simulation | Groups | T=<2 hours D=not specified | <1 day | Performance audits

Key question: | 3. Training clinicians to report events to a central agency
Public health model: | 1. Infectious disease outbreaks

Durrheim, 2001 | Intervention | Eleven full-time and 21 part-time nurses (infection control) in 32 hospitals (private and public) (N=32). | Lectures, readings | Individuals, groups | T=not specified D=>1 year | Not specified | Performance audits

Evidence Table 3. Quality of studies evaluating training programs for public health events relevant to bioterrorism preparedness (in percent)

Key question: | 1. Training clinicians to detect and manage a bioterrorist attack or other public health event
Public health model: | 1. Infectious disease outbreaks

Author, year | Representativeness ^a^ | Bias ^b^ | Description ^c^ | Outcomes ^d^ | Statistics ^e^ | Total score ^f^
Harrison, 2000 | 62.5 | 100.0 | 75.0 | 100.0 | 100.0 | 87.5
Kemppainen, 1996 | 66.7 | 90.0 | 66.7 | 100.0 | 100.0 | 84.7
Garcia, 1998 | 62.5 | 100.0 | 50.0 | 100.0 | 62.5 | 75.0
Gerbert, 1991 | 62.5 | 80.0 | 75.0 | 100.0 | 37.5 | 71.0
Zimmerman, 1997 | 50.0 | 40.0 | 100.0 | 80.0 | 50.0 | 64.0
Umble, 2000 | 62.5 | 25.0 | 75.0 | 100.0 | 50.0 | 62.5
Maetz, 1998 | 87.5 | 0.0 | 58.3 | 90.0 | 75.0 | 62.2
Russell, 1991 | 62.5 | 0.0 | 58.3 | 90.0 | 100.0 | 62.2
Epstein, 2001 | 50.0 | 40.0 | 66.7 | 100.0 | 50.0 | 61.3
Lewis, 2000 | 62.5 | 0.0 | 100.0 | 90.0 | 50.0 | 60.5
Bowman, 1992 | 87.5 | 0.0 | 58.3 | 80.0 | 75.0 | 60.2
Armstrong-Esther, 1989 | 100.0 | 10.0 | 58.3 | 80.0 | 50.0 | 59.7
Bennett, 1997 | 75.0 | 40.0 | 41.7 | 90.0 | 50.0 | 59.3
Paauw, 1995 | 62.5 | 0.0 | 100.0 | 70.0 | 50.0 | 56.5
Talan, 1990 | 87.5 | 0.0 | 50.0 | 70.0 | 75.0 | 56.5
Lewis, 1993 | 62.5 | 50.0 | 75.0 | 80.0 | 12.5 | 56.0
Green, 1998 | 62.5 | 0.0 | 66.7 | 70.0 | 66.7 | 53.2
Zell, 1997 | 62.5 | 0.0 | 83.3 | 70.0 | 50.0 | 53.2
Osborn, 1999 | 100.0 | 0.0 | 50.0 | 80.0 | 33.3 | 52.7
Fischer, 2000 | 87.5 | 0.0 | 91.7 | 80.0 | 0.0 | 51.8
Ofori-Adjei, 1996 | 50.0 | 55.0 | 58.3 | 80.0 | 12.5 | 51.2
Soudarssanane, 1994 | 100.0 | 0.0 | 83.3 | 70.0 | 0.0 | 50.7
Cohen, 1996 | 37.5 | 0.0 | 50.0 | 90.0 | 50.0 | 49.5
Tuladhar, 1998 | 62.5 | 0.0 | 33.3 | 90.0 | 50.0 | 47.2
Sowell, 1998 | 62.5 | 0.0 | 75.0 | 80.0 | 16.7 | 46.8
Hartnett, 1987 | 50.0 | 25.0 | 75.0 | 80.0 | 0.0 | 46.0
Delacollette, 1996 | 50.0 | 25.0 | 16.7 | 100.0 | 37.5 | 45.8
O'Donnell, 1987 | 50.0 | 0.0 | 33.3 | 70.0 | 50.0 | 40.7
Anderson, 1997 | 75.0 | 50.0 | 16.7 | 60.0 | 0.0 | 40.3
Breman, 1977 | 50.0 | 0.0 | 50.0 | 100.0 | 0.0 | 40.0
Ray, 1991 | 50.0 | 0.0 | 66.7 | 80.0 | 0.0 | 39.3
Inglesby, 2001 | 62.5 | 0.0 | 58.3 | 70.0 | 0.0 | 38.2
Lieb, 1996 | 50.0 | 0.0 | 66.7 | 70.0 | 0.0 | 37.3
Kaur, 1998 | 50.0 | 0.0 | 33.3 | 50.0 | 50.0 | 36.7
Kark, 1973 | 50.0 | 0.0 | 91.7 | 40.0 | 0.0 | 36.3
Katsufrakis, 1992 | 50.0 | 0.0 | 75.0 | 50.0 | 0.0 | 35.0
Pandit, 1991 | 50.0 | 0.0 | 8.3 | 50.0 | 66.7 | 35.0
Cydulka, 1991 | 50.0 | 0.0 | 41.7 | 80.0 | 0.0 | 34.3
Novick, 1985 | 100.0 | 0.0 | 41.7 | 30.0 | 0.0 | 34.3
Simoes, 1997 | 37.5 | 0.0 | 50.0 | 80.0 | 0.0 | 33.5
Lloyd, 1999 | 75.0 | 0.0 | 41.7 | 50.0 | 0.0 | 33.3
Dorman, 1990 | 50.0 | 0.0 | 75.0 | 30.0 | 0.0 | 31.0
Hixon, 1990 | 25.0 | 0.0 | 50.0 | 80.0 | 0.0 | 31.0
Roos, 1995a | 12.5 | 10.0 | 50.0 | 80.0 | 0.0 | 30.5
Millward, 1993 | 25.0 | 10.0 | 25.0 | 50.0 | 25.0 | 27.0
Kidd, 1999 | 37.5 | 0.0 | 66.7 | 30.0 | 0.0 | 26.8
Brown, 1990 | 37.5 | 0.0 | 83.3 | 10.0 | 0.0 | 26.2
Meisenhelder, 1994 | 12.5 | 10.0 | 16.7 | 40.0 | 50.0 | 25.8
Jacobson, 1986 | 37.5 | 0.0 | 8.3 | 80.0 | 0.0 | 25.2
All, 1997 | 37.5 | 0.0 | 16.7 | 50.0 | 16.7 | 24.2
Odhacha, 1998 | 25.0 | 0.0 | 16.7 | 70.0 | 0.0 | 22.3
Boskovich, 1994 | 25.0 | 0.0 | 50.0 | 30.0 | 0.0 | 21.0
Roos, 1995b | 0.0 | 10.0 | 0.0 | 70.0 | 0.0 | 16.0

Key question: | 1. Training clinicians to detect and manage a bioterrorist attack or other public health event
Public health model: | 2. Toxidromes and mass poisonings

Anderson, 1984 | 37.5 | 0.0 | 58.3 | 10.0 | 0.0 | 21.2

Key question: | 1. Training clinicians to detect and manage a bioterrorist attack or other public health event
Public health model: | 4. Events that call for a hospital disaster plan

Cook, 1990 | 37.5 | 0.0 | 50.0 | 80.0 | 0.0 | 33.5
Tur-Kaspa, 1999 | 37.5 | 0.0 | 50.0 | 60.0 | 0.0 | 29.5
Gofrit, 1997 | 25.0 | 0.0 | 50.0 | 60.0 | 0.0 | 27.0
Naggan, 1976 | 25.0 | 0.0 | 33.3 | 30.0 | 0.0 | 17.7
Levi, 1998 | 0.0 | 0.0 | 33.3 | 12.5 | 0.0 | 9.2

Key question: | 3. Training clinicians to report events to a central agency
Public health model: | 1. Infectious disease outbreaks

Durrheim, 2001 | 66.7 | 0.0 | 83.3 | 100.0 | 0.0 | 50.0

a Representativeness: The total maximum for this section was 8 points. This included setting and population described and start and end date specified (maximum 2 points), detailed description of inclusion and exclusion criteria or statement that all potential trainees enrolled (maximum 2 points), information about extended training or learning (maximum 2 points), and specific profession, specialty within profession and education level specified (maximum 2 points).

b Bias (and confounding): The total maximum score was 10 points. This included the appropriate comparison group described (maximum 2 points), whether study groups were randomized (maximum 2 points), important differences of study groups at baseline (maximum 2 points), masking of educational outcomes (maximum 2 points), and whether an intervention other than education was specified (maximum 2 points).

c Description (of intervention): The total maximum score was 12 points. This included stating the objectives of the intervention (maximum 2 points), consideration of knowledge, beliefs/ attitudes, skills, behaviors, or clinical outcomes (maximum 2 points), usage of complete description of the educational methods (maximum 2 points), adequate description of required resources (maximum 2 points), sufficient description of curriculum content (maximum 2 points), and description of organization and administration of the educational intervention (maximum 2 points).

d Outcomes (of the educational intervention): The total maximum score was 10 points. This included the relative evaluation of the outcomes (maximum 2 points), sufficient description of evaluation methods (maximum 2 points), congruence between objectives and evaluation methods (maximum 2 points), use of objective methods in evaluating outcomes (maximum 2 points), and whether there was followup after completion of the intervention (maximum 2 points).

e Statistics (quality and interpretation): The total maximum score was 8 points. This included whether magnitude of difference between groups and an index variability was stated (maximum 2 points), whether appropriate analyses and statistical tests were performed (maximum 2 points), whether adjustment of potential confounders were multi-variate or stratified analyses and coding of confounders (maximum 2 points), and appropriate handling of crossovers and/or dropouts in the analysis (maximum 2 points).

f Total score: Mean of the percent scores from the previous five categories.

Evidence Table 4. Results of studies evaluating training programs for public health events relevant to bioterrorism preparedness

Key question: | 1. Training clinicians to detect and manage a bioterrorist attack or other public health event
Public health model: | 1. Infectious disease outbreaks

Author, year | Type of health care professional | Description of objective(s) | How objective(s) were met | Summary
Harrison, 2000 | Nurse, clinic personnel, pharmacist | K: To train in a comprehensive approach to sexually transmitted disease (STD) syndromic case management. A: To improve staff attitude. S: To teach correct syndromic drug treatment. S: To teach appropriate counseling of STD patients. B: To increase privacy during consultations. | K: 88% of simulated patients were correctly treated (up from 50%); 83% (vs. 12%) of simulated patients were appropriately case managed. A: Proportion of patients reporting good staff attitude increased (84% vs. 58%). S: Counseling improved (68 vs. 46%) in intervention clinics. B: There was a minimal increase (92% vs. 86%) in counseling in privacy. An increase in health seeking behavior occurred primarily at one clinic. C: Not applicable. | A simple health service intervention achieved substantial improvements in STD case management.
Kemppainen, 1996 | Nurse | K: To educate on universal precautions with emphasis on HIV protection. A: To improve nurses' willingness to care for patients with AIDS. | K: No results reported. A: No significant change occurred in Nursing Willingness Questionnaire scores in any group. S: Not applicable. B: Not applicable. C: Not applicable. | None of the interventions had a significant impact on the nurses' attitudes.
Garcia, 1998 | Pharmacist, licensed, pharmaceutical salesperson | K: To recognize STD symptoms. K: To identify correct medication for treatment. B: To appropriately offer medication for STDs. B: To offer counseling and education. B: To refer to a physician. | K: No change occurred in recognizing STD symptoms. No change occurred in knowledge of correct treatment. A: Not applicable. S: Not applicable. B: No change occurred in physician referrals. Frequency of preventive counseling by pharmacists increased. C: Not applicable. | Pharmacy workers were more likely to recognize STD symptoms in males than females. Many pharmacies used incorrect STD treatments. Educational interventions improved counseling.
Gerbert, 1991 | Dentist | K: To increase general knowledge about HIV. K: To increase knowledge and practice of infection control protocols. A: To increase willingness to treat persons with HIV disease. A: To provide accurate perception of the risk of contagion. B: To be able to identify the oral manifestations of HIV infection. B: To perform intraoral examinations. | K: Statistically significant change occurred between pretest and posttest on all activities. Knowledge of AIDS mean score (on 14 questions) increased from 5.0 to 9.5 for the intervention group; HIV-associated lesion identification mean score increased from 4.9 to 5.8 (of a maximum possible 8). A: Willingness to treat HIV positive patients mean score decreased from 40 to 36.7 (on a scale from 9 to 63). Perceived risk mean score decreased from 40.9 to 36.1 (on a scale from 7 to 70). S: Intraoral exam mean score increased from 22.3 to 24.2 (on a scale from 4 to 28). B: Infection control mean score increased from 42.2 to 46.6 (on a scale from 8 to 56). C: Not applicable. | The nationwide AIDS educational intervention for dentists was a qualified success. There was a pretest to posttest improvement in risk perception, knowledge, and practice. Willingness to treat AIDS patients, however, actually declined somewhat. This intervention showed that knowledge and behavior changes can be effected through the use of a nationwide intervention without face-to-face contact.
Zimmerman, 1997 | Physician, medical students | K: To improve immunization practices of current and future physicians through two teaching methods. A: To address perceptions of risk of contracting disease, severity, vaccine efficacy, and barriers to vaccination. | K: Total score increased with both problem-based learning (PBL) and multi-station clinical teaching scenarios (MCTS) for all vaccinations. The percentage of learners achieving mastery at posttest with MCTS ranged from 64% (for childhood vaccinations) to 99% (for influenza). The percentage of learners achieving mastery at posttest with PBL ranged from 77% (for pertussis) to 100% (for influenza). A: Posttest indicated change in health beliefs and showed significant gains with both teaching methods. S: Not applicable. B: Not applicable. C: Not applicable. | Educational programs increased knowledge about immunization, an essential step to improving vaccination of future clinicians.
Umble, 2000 | Nurse, physician, public health professional | K: To improve vaccine knowledge. A: To improve agreement with vaccine schedule. A: To improve self-efficacy regarding implementation of the polio vaccine recommendations. B: To improve adherence with polio vaccination recommendations. | K: Knowledge scores (5 point scale) improved significantly for both classroom (3.82 to 4.48, p<0.001) and broadcast groups (2.68 to 4.19, p<0.0001). A: There was significant improvement in agreement with new recommendations (mean score on a scale from 8 to 40) for both classroom group (from 33.80 to 38.38, p<0.001) and broadcast group (from 32.37 to 37.37, p<0.001). Improvement was seen in mean self-efficacy scores (on a scale from 2 to 8) for both classroom group (from 4.68 to 6.93, p<0.001) and broadcast group (from 3.53 to 6.55, p<0.001). S: Not applicable. B: Mean scores for adherence to general recommendations (3 to 15 point scale) improved in both classroom group (from 11.50 to 12.38, p<0.05) and broadcast group (from 9.50 to 11.84, p<0.25). Mean scores for adherence to the polio schedule (4 to 20 point scale) improved in both classroom group (from 9.30 to 16.25, p<0.001) and broadcast group (from 11.96 to 14.42, p=0.084). C: Not applicable. | Both the classroom and the broadcast course significantly improved knowledge and implementation of vaccination schedule for polio. There was no significant difference between the two groups.
Maetz, 1998 | Nurse, public health department employee | K: To improve knowledge of the transmission, pathogenesis, epidemiology, diagnosis, treatment, and infectiousness of tuberculosis. A: To increase confidence in applying knowledge for transmission and pathology, diagnosis, treatment, and infection control. | K: Mean pretest and posttest scores increased from 80.8% to 91.8%. A: 80% felt more confident they could apply knowledge in treatment, diagnosis, transmission, infection control,. and pathology. S: Not applicable. B: Not applicable. C: Not applicable. | Satellite conferences enhance print based module; allow transmission of consistent information; immediate feedback for experts; facilitate instructions. Distance learning technology represents an important avenue for addressing both training program quality and access issues. Educational intervention resulted in videotapes for future instructions.
Russell, 1991 | Physician | B: To increase risk assessment for patients. B: To improve counseling, provision of written materials, and diagnostic testing recommendations. | K: Not applicable. A: Not applicable. S: Not applicable. B: The rates of practice (i.e., risk assessment) measured by physician self-reports tended to be higher than evaluator-observed rates. Across all tasks, the mean percentage difference between physician-reported rates of practice and evaluator-observed rates of practice was 17.5% (SD=20.5). C: Not applicable. | The majority of physicians are amenable to unannounced standardized patient evaluator visits. The rates of practice measured by physician self-reports were higher than rates observed by standardized patient evaluators.
Epstein, 2001 | Physician | K: To improve physicians' HIV risk communication skills. A: To obtain information in "nonjudgmental" fashion. S: To increase Rochester HIV Interview Rating Scale scores. S: To evaluate communication skills to obtain HIV risk factors: general interviewing skills, process skills, content skills. B: To appropriately order HIV tests. | K: Not applicable. A: Not applicable. S: Mean Rochester HIV Interview Rating Scale scores improved 7.5 points (30.4 to 37.9, p<0.05). B: HIV test ordering significantly increased compared with baseline HIV test ordering (McNemar's test, p<0.02). C: Not applicable. | A novel program using standardized patient instructors providing on-site assessment of and feedback on doctor HIV risk assessment skills was feasible, inexpensive, convenient, fun, and well accepted by physicians. Both groups displayed learning with increased Rochester HIV Interview Rating Scale scores and HIV test ordering.
Lewis, 2000 | Dentist, dental hygienist | K: To improve knowledge regarding HIV, including diagnosis and management of oral manifestations of HIV. K: To improve knowledge of infection control procedures. A: To address fears and anxieties about HIV. S: To improve confidence in diagnosis and management of oral manifestations of HIV. S: To improve confidence in communicating with HIV patients. S: To acquire related teaching skills to pass on to junior staff. | K: General knowledge of HIV improved (mean 6.0 to 7.5 [p<0.03] postcourse). Knowledge about diagnosis of oral manifestations of HIV improved (mean 6.0 to 8.0 [p<0.02] postcourse). Knowledge about management of oral manifestations of HIV improved (mean 5.5 to 7.5 [p<0.01] postcourse). Knowledge about infection control practices improved (mean 7.5 to 8.0 [p<0.17] postcourse). All knowledge gains persisted at 2-year followup. A: There was no significant change in how anxious or at ease participants felt about treating a patient with AIDS (mean 4.0 versus 2.5 [p<0.20] postcourse, and 2 years later). S: Likelihood of discussing with a patient that their oral condition could be a symptom of HIV increased (mean 4.5 to 7.0 [p<0.005] postcourse). Confidence in taking histories from suspected HIV symptomatic (oral lesions) patients improved (mean 5.5 to 7.0 [p<0.03] postcourse). Confidence in talking to reticent staff increased significantly; skill gains persisted at 2-year followup. B: There was an increase in participants' rating of how practical it was to use infection control procedures on a daily basis (mean 6.5 to 8.0 [p<0.007] post-course, to 7.5 [p<0.128] 2 years later). C: Not applicable. | Participants felt more confident in their knowledge, in their ability to communicate with patients who may be infected with HIV, and in talking to staff who are unwilling to treat HIV patients; these results were maintained 2 years later. The course was well received and had long-term perceived benefits.
Bowman, 1992 | Physician | B: To increase sexual risk assessment and counseling practices. | K: Not applicable. A: Not applicable. S: Not applicable. B: 85% of those who received a simulated patient said they would change how they assess and counsel patients with STD/HIV. Physicians who prepared for the simulated patient by reading the educational materials performed better than those who did not. Physicians who used the study risk assessment questionnaire performed better; performance was better for general patient interaction than for sexual practices history taking and counseling; 24 to 39% of simulated patients indicated that they did not believe the physicians met the goals of the visit. C: Not applicable. | Most community physicians accepted the simulated patient visit and found it enjoyable and effective. Nearly all physicians reviewed materials either before or after the simulated patient visit. Physicians who prepared before the visit performed better on every dimension, eliciting more information, displaying better patient interaction skills, and meeting more educational goals. Even with educational preparation, many physicians were not perceived as effective counselors by simulated patients.
Armstrong-Esther, 1989 | Nurse | K: To teach knowledge of selected AIDS symptoms. K: To teach knowledge of AIDS transmission modes. K: To teach recognition of high-risk behaviors. K: To teach proper procedures for handling contaminated blood. A: To decrease concerns about providing care to AIDS patients. A: To identify the attitudes toward professional conduct of HIV-infected workers. A: To identify beliefs about social policies for preventing AIDS. | K: Recognition of symptoms associated with AIDS increased (5 of 8 symptoms). "Misidentifying" symptoms as AIDS symptoms also increased (2 of 4 nonsymptoms). Knowledge of transmission improved for 4 of 11 items. Correct assignment of risk to high- and low-risk behaviors improved. A: Fewer nurses expressed concerns about caring for patients with AIDS. Three concerns about attitudes improved with education, as did four measures of attitudes toward patients, attitudes about social policies, and attitudes toward education. S: Not applicable. B: Not applicable. C: Not applicable. | Direct nurse education can lead to increased knowledge and understanding of AIDS and contribute to more liberal attitudes about the disease and patient care. There is no evidence that direct education that affects knowledge and attitudes will also alter nurses' behavior.
Bennett, 1997 | Midwives | K: To increase knowledge regarding HIV in general and obstetric/pediatric HIV in etiology and transmission. A: To minimize additional bias regarding HIV and midwives' role in antenatal HIV testing. A: To demonstrate more positive attitudes toward antenatal testing and people who are HIV positive. B: To proactively raise the issue of HIV with expectant mothers. | K: No significant difference between groups in knowledge of etiology of HIV (71% vs. 67% had correct answers; p>0.05). No significant difference between groups in knowledge of transmission of HIV (>80% in both groups; p>0.05). No significant difference between groups in knowledge of obstetric and pediatric HIV (62% vs. 59%; p>0.05). A: No significant difference was noted between groups in attitudes (45% vs. 46% positive or strongly positive); 18% of participants reported that the training program increased anxiety and 58% reported that it decreased anxiety. S: Not applicable. B: No significant difference between groups in the percent that reported they actually did or would raise the issue of HIV testing at antenatal booking. Participants cited lack of depth, lack of counseling practice, and lack of followup training as deficits of the training. C: Not applicable. | The short training program did not effect in change in knowledge, attitudes, or behavior.
Paauw, 1995 | Physician | K: To improve the ability of physicians in correctly identifying and diagnosing HIV-related clinical findings. S: To determine the ability of physicians to detect the physical findings associated with HIV infection. | K: Kaposi's sarcoma was correctly identified by 25.8% of physicians participating. Oral hairy leukoplakia was correctly identified by 22.7% of physician participants. A: Not applicable. S: Kaposi's sarcoma was detected by 47.2% of physician participants. Oral hairy leukoplakia was detected by 55.7% of physician participants. Diffuse lymphadenopathy was detected by 17.3%. B: Not applicable. C: Not applicable. | Physicians frequently missed three HIV-related physical findings and did not make associated diagnoses. One-half of the physicians did not detect lesions as abnormalities. One-half of the physicians did not correctly identify lesions. The data indicate deficiencies in HIV-related physical diagnosis skills of primary care physicians.
Talan, 1990 | Nurse | K: To increase knowledge of HIV occupational risk. B: To increase compliance with universal precautions. | K: No significant difference was seen between mean correct answers to any of the knowledge questions before and after education. A: Not applicable. S: Not applicable. B: Glove use (67% vs. 88%, p<0.025) and protective eyewear use (0% vs. 17%, p<0.05) among initial trauma patients increased significantly after instruction. No significant change occurred after instruction in glove use for noncritical patients (53% vs. 65%, p<0.70), gown use for critical patients (25% vs. 40%, p<0.20), or mask use for critical patients (0% vs. 0%). C: Not applicable. | The inservice was associated with a modest increase in compliance of emergency department nursing personnel with universal precautions. No long-term effect was shown on general knowledge of HIV risk.
Lewis, 1993 | Physician | A: To help physicians overcome hesitancy in taking care of patients with HIV. S: To improve sexual history taking. | K: Not applicable. A: Not applicable. S: Percent of internists asking sexual history increased; no change in control group. Sexual history taking decreased among obstetricians and gynecologists in intervention group, but increased in comparison group. Sexual history taking by internists in the experimental group increased (26% to 42.3%). Sexual history taking by all specialists at the control site decreased. Obstetricians and gynecologists were more consistent in sexual history taking, but showed no improvement with educational intervention. B: Not applicable. C: Not applicable. | Physicians were reluctant to attend mandatory sessions. Sexual history taking varied across sites and among and between groups. A medical education program that went beyond standard lectures and incorporated interactive formats changed physician behavior.
Green, 1998 | Nurse, physician, other health care providers | K: To improve knowledge about STD diagnosis, management, counseling, and partner notification and reporting. B: To improve STD case management practices in counseling, diagnosis, and treatment. | K: STD knowledge scores increased (66.4% to 83.2%, p=0.002). A: Not applicable. S: Not applicable. B: Diagnostics/screening (57.2% to 71%; p=0.04) and obtaining syphilis serologies during pregnancy (38.3% to 83.8%; p=0.001) improved. Effective treatment for gonorrhea improved (57.8% to 81.1%; p=0.002). Counseling/education and treatment did not improve significantly (69.8% to 73.3%, p>0.05; 68.3% versus 74.5%, p>0.05, respectively). Overall rate of health providers prescribing (74%) care and regimens did not change. C: Not applicable. | Continuing medical education program for private practitioners on STD management modestly improved self-reported management practices. Some weaknesses still persisted in STD management and counseling. Treatment was improved after the intervention. Efforts are needed to reach the providers that did not participate.
Zell, 1997 | Physician | K: To compare precourse and postcourse test scores on exam about HIV. S: To improve case management skills of signs, symptoms, diagnosis, recognition, and treatment of opportunistic infections. | K: Overall/global assessment score increased 17.9%. Diagnostic decisionmaking score increased 19.9%. Basic science knowledge increased 29.8%. Recognition of physical signs did not significantly improve after the course. A: No postcourse re-evaluation of attitudes/belief survey was performed. S: Case management (skill) did not improve significantly (13.0% increase, p=0.086). B: Not applicable. C: Not applicable. | A 2-day course in HIV was able to produce significant increases in basic knowledge regarding HIV/AIDS and diagnosis decisionmaking abilities in course physicians.
Osborn, 1999 | | C: To decrease the number of needlestick exposures. | K: Not applicable. A: Not applicable. S: Not applicable. B: Not applicable. C: 119 of 1,022 medical students sustained 129 exposures. Percentage of exposures reported increased from 45% to 65% over the 7-year period. | Despite training and targeted prevention interventions, medical students remained at risk for needlestick exposures.
Fischer, 2000 | Dentist, nurse, physician, clinic manager, medical chief, other health care providers | K: To identify risk factors for hepatitis C. K: To diagnose hepatitis C disease. | K: Substantial improvement in hepatitis C related knowledge. Improvement in identifying tests needed to confirm hepatitis C infection (25% to 87%). Correct identification of adverse side effects increased (66% to 91%). Correct evaluation of treatment response increased (66% to 89%). A: Not applicable. S: Not applicable. B: Not applicable. C: Not applicable. | Participation was high, indicating staff interest. Satisfaction evaluations were very positive. Pretests and posttests showed substantial improvements in all areas.
Ofori-Adjei, 1996 | Community health worker | K: To teach the clinical management of malaria. | K: Some improvement in knowledge occurred. A: Not applicable. S: Average number of drugs prescribed decreased slightly after the intervention on paper but not in actual practice. B: The educational intervention did not change prescribing practices in the long term. C: Not applicable. | Group inservices can change/improve knowledge about malaria but are not an effective means of changing prescribing decisions or habits, long-term. A discrepancy between knowledge and practice was noted, shown by over-prescribing, under-prescribing, incorrect prescribing, and multiple prescriptions. Motivating reasons for inappropriate treatments are sociocultural (e.g., patient demand stemming from belief in the potency of injections).
Soudarssanane, 1994 | Medical students | K: To list common organisms causing diarrhea. K: To list environmental agents that cause diarrhea. K: To identify physical exam findings suggestive of dehydration in children. K: To differentiate degree of dehydration. K: To identify risk factors for developing diarrhea. A: To appreciate issues in short- and long-term prevention and control. A: To appreciate the need for education. | K: Test scores were not interpreted. A: No comparison of pretesting and posttesting. S: Not applicable. B: Not applicable. C: Not applicable. | Modified method of teaching (including handouts, participatory discussion of studies and audio-visual feedback) helped involve students. Active participation assists with learning.
Cohen, 1996 | Dentist, dental hygienist and assistant, office staff | K: To estimate the percent of patients in a practice that are at risk for HIV/AIDS. A: To foster belief that private practice was the best place to treat healthy HIV positive patients. S: To be able to use the following procedures to screen patients for HIV/AIDS: mental history, sexual history, drug-use history, oral exam, etc. S: To be able to take an appropriate patient history. B: To increase use of gloves, masks, and protective eyewear when working. B: To increase barrier use. C: To increase immunization rates for hepatitis B. | K: The percentage of at-risk patients in their practice increased from 11.9 to 21.9%. A: The belief that private practice was the best place to treat HIV positive patients increased from 35.1% pretest to 58.7% posttest. Percentage of dentists and hygienists intending to be immunized increased from 56 to 79% for dentists and from 76 to 96% for hygienists. S: Use of screening and barrier procedures improved for those with good pretest scores and declined for those with poor pretest scores. B: Percent of respondents who reported using gloves increased 2% and masks increased 7%. C: Not applicable. | The traditional lecture approach to providing continuing education related to AIDS for dental professions can be helpful. Improvements were maintained for 6 months.
Tuladhar, 1998 | Pharmacist | K: To recognize the most common STD syndromes. B: To refer client to physician. B: To counsel regarding HIV, partner treatment, and condom use. B: To dispense correct drug. | K: No significant differences were found in percentages of pharmacists who suggested or dispensed medication. A: Not applicable. S: Not applicable. B: No significant differences were found in the percentage of pharmacists that recommended medications to treat STD symptoms or in the percentage that dispensed medications; no change in referrals to physician. The percentage of pharmacists that dispensed the correct drug regimens for syndromic treatment of urethral discharge increased from 0.8% to 45%. The percentage of pharmacists that dispensed correct drug regimens was 26% in the subgroup that was studied 7-9 months after the intervention. Counseling increased regarding HIV, partner treatment, and condom use. C: Not applicable. | STD services provided by pharmacists can be significantly improved through a short-term training intervention, but many of these improvements are modest, and in the face of no further interventions, are likely to be time limited.
Sowell, 1998 | Nurse | K: To improve knowledge base regarding HIV/AIDS. A: To improve willingness to care for patients with HIV/AIDS. S: To improve general level of preparedness in caring for patients with AIDS. | K: All knowledge scores improved between 17% and 42%. A: Willingness to care for HIV/AIDS patients scores improved between 2% and 23% for the 13 items score. S: Nurses' sense of professional preparedness in caring for HIV/AIDS patients improved (mean score improved from 3.31 to 2.39 on a scale from 1 [completely prepared] to 5 [completely unprepared]). B: Not applicable. C: Not applicable. | A rural-based HIV/AIDS continuing education model was successful in positively changing both knowledge about HIV/AIDS and attitudes toward people with HIV/AIDS.
Hartnett, 1987 | | K: To increase scores on an AIDS knowledge test (including presenting symptoms, high-risk groups, and requirements for isolation). A: To increase self-reported confidence in caring for AIDS patients. | K: Average AIDS knowledge increased from 3.0 to 4.3 (of 5) questions answered correctly. A: Average confidence caring for AIDS patients increased from 3.4 to 6.3 (10-point scale). S: Not applicable. B: Not applicable. C: Not applicable. | The educational program helped calm fears and increase confidence in nurses who interact with AIDS patients.
Delacollette, 1996 | Community health worker | C: To decrease malaria mortality and morbidity (prevalence and incidence). | K: Not applicable. A: Not applicable. S: Not applicable. B: Not applicable. C: Malaria-related morbidity and mortality decreased (50% decline in prevalence/incidence of malaria). Treatment increased in the community by 16%. Morbidity decreased two-fold. Parasitemia decreased six-fold. | The study indicates that introduction of dedicated community health workers can lead to improved access to and utilization of health care for malaria, and result in a decline of malaria morbidity.
O'Donnell, 1987 | Nurse, physician, social worker, technician | K: To increase knowledge of the biology and epidemiology of AIDS (transmission), clinical course and treatment, and infection control. A: To decrease how stressed or at-risk respondents felt while working with AIDS patients. | K: The number of health care workers reporting they had sufficient knowledge to deal with AIDS patients' physical needs increased 13%. The number of health care workers reporting they had sufficient knowledge to deal with AIDS patients' emotional needs increased 10%. A: The number of health care workers reporting that dealing with AIDS patients was one of the most stressful parts of their job decreased 13.4%. The number of health care workers reporting discomfort with HIV patients decreased 9.5%. S: Not applicable. B: Not applicable. C: Not applicable. | Staff members' knowledge about AIDS transmission improved significantly, they perceived less stress while providing AIDS-related care, despite twice as many AIDS admissions. Inservice training made a difference in how staff members responded to the demands of AIDS patient care.
Anderson, 1997 | Medical student | K: To increase knowledge of HIV. A: To improve willingness to treat HIV-infected patients. A: To decrease fear of treating HIV-infected patients. | K: 1994 students scored better than 1991 students on the knowledge variable (p< 0.0001) but article does not report whether knowledge differed between schools. A: 1994 students scored better than 1991 students on the three attitude variables (p<0.0001) and students in New Mexico had less fear of treating HIV patients than the students from the other two schools. S: Not applicable. B: Not applicable. C: Not applicable. | Differences in HIV prevalence did not affect the schools' training programs. Difference in HIV prevalence indirectly affected the students' knowledge and attitudes. Students' knowledge and attitudes were related to the numbers of HIV-infected individuals known personally by the students. All three medical schools' responses were similar, though located in States reporting unequal number of cases.
Breman, 1977 | Medical and paramedical personnel | S: To successfully train personnel in vaccination program protocols. B: To achieve a high rate of vaccination coverage. C: To achieve a high rate of major reaction rates in primary vaccines. C: To eliminate the occurrence of smallpox. | K: Not applicable. A: Not applicable. S: Not applicable. B: 2,250,000 persons, representing 60% of the population (19 of 29 regions), were vaccinated by January 1969 (13 months after beginning of field activities). C: Smallpox was eradicated in Guinea 13 months after the beginning of field activities, with the last known case of smallpox in January 1969. Overall major reaction rate among primary vaccines was 98%. | This comprehensive eradication strategy (based on use of mobile teams trained for mass vaccination, assessment, surveillance, and epidemic investigation) succeeded in interrupting smallpox transmission in Guinea.
Ray, 1991 | Physician, epidemiologist | K: To increase knowledge of malaria, clinical manifestations and treatment. S: To improve efficiency in reading smears. B: To understand concepts of control in order to effectively supervise public health operations. | K: 60% received an "A" for parasitology; 72% received an "A" for laboratory services; 73% received an "A" for basic epidemiology. Orientation: 82% received an "A" for passive case detection. Orientation: 82% received an "A" for treatment. Workshop: 85-100% received an "A" for questions about treatment, 35% received an "A" for pathology. A: Not applicable. S: 73% received an "A" for treatment of severe cases. B: 60-77% received an "A" for understanding policy, planning, and role in operations. C: Not applicable. | Training courses were highly successful in updating knowledge on malaria management and control.
Inglesby, 2001 | Medical and public health personnel | None described. | K: Not applicable. A: Not applicable. S: Not applicable. B: Not applicable. C: Not applicable. | Systems in place would be hard pressed to successfully manage a bioweapons attack; problematic issues of leadership and decisionmaking were illuminated. There were difficulties with prioritizing and distributing scarce resources (i.e., antibiotics); contagious epidemics would cause crisis in health care facilities. Need to formulate sound principles of disease containment. Flow of information and communication was a major concern.
Lieb, 1996 | Nurse, ancillary personnel | K: To teach the intended uses of the respirator. K: To identify two situations in which the respirator must be worn. K: To identify the proper means of storing the respirator and the location in the work area where the respirator will be stored. S: To don the tuberculosis respirator correctly. S: To check whether a tuberculosis respirator was fitted correctly. | K: Average score of 2-week posttraining knowledge test was 88% (with item-specific correct responses ranging from 56% to 98%, and participant average scores ranging from 78% to 100%). A: Not applicable. S: 97.1% of all participants reported they were fully able to attain the learning objectives. Greater than 99% believed the training format was effective. B: Not applicable. C: Not applicable. | Self-paced learning stations are an effective and time-efficient method of educating health care workers about respiratory protection against tuberculosis.
Kaur, 1998 | Nurse | K: To assess awareness of AIDS among general nursing students before and after the workshop. K: To compare awareness of AIDS between nursing students from the "arts group" and those from the "science group." | K: The mean score on the questionnaire about transmission of and misconceptions about AIDS increased from 29.48 (SD 5.32) to 37.13 (SD 6.03) with p <0.001. Students with a science background scored higher than students with an arts background on both the pretest (mean 30.8 versus 28.2; p<0.001) and posttest (mean 40.5 versus 34.8; p <0.001). A: Not applicable. S: Not applicable. B: Not applicable. C: Not applicable. | The HIV/AIDS education program improved the posttest knowledge scores. Science students performed better than arts students before and after the workshop.
Kark, 1973 | Nurse, physician, undergraduates, health educators | None described. | K: Faculty seemed to think that the group project reports reflected acquisition of the desired body of knowledge; otherwise not directly reported. A: Students gave high ratings to the learning sessions based on importance and usefulness of subject, interest of session, and knowledge gained but ratings not broken down by these criteria. S: Group project reports seemed to reflect acquisition of targeted skills but specific skills not directly assessed. B: Group project reports were completed. C: Not applicable. | The workshop was favorably appraised by students and staff and succeeded in introducing Master of Public Health students to basic knowledge and skills in application of community medicine principles to primary health care (one component involved surveillance of infectious diseases).
Katsufrakis, 1992 | Physician, physician assistant | B: To provide appropriate initial evaluation of HIV-infected patients and subsequent health surveillance. B: To counsel patients regarding maintaining their health and reducing the risk of transmission to others. B: To recognize and treat common minor complications of HIV infection. B: To recognize early signs and symptoms of major complications and appropriately treat patients or refer them for definitive treatment. B: To serve as a resource to other clinicians for managing HIV-infected patients. | K: Not applicable. A: Trainees were satisfied with the preceptorship and rated as most useful the knowledge and skills acquired during the intake experiments within the AIDS clinic; 43% had a much higher level of comfort for caring for HIV positive patients; 48% indicated a higher level of comfort; and 9% indicated the level of comfort did not change. Level of confidence regarding care they provided to HIV patients changed similarly. S: Not applicable. B: 90% of the trainees provided care for the HIV positive patients until symptoms of AIDS developed and most referred their patients to specialists only when major AIDS complications developed. Participants recommended HIV testing for an average of 74 patients over the 6-month period following training. C: An average of 84 patients at risk for HIV were identified by physicians who had completed training (over a 6-month period). | The training program increased the level of confidence on the part of the participants in treating HIV-infected patients. After training, participants screened and tested high-risk patients in their practices and devoted a substantial proportion of their practices to caring for HIV-infected patients.
Pandit, 1991 | Physician | K: To increase immunization knowledge. | K: Each of the four groups showed significant (p<0.01) increases in knowledge between pretesting and posttesting; 90.1% of interns showed performance improvement from 67% to 75%; 6.5% of interns decreased performance level; 3.3% of interns showed no improvement. A: Not applicable. S: Not applicable. B: Not applicable. C: Not applicable. | Training in Department of Community Medicine improved immunization knowledge of interns.
Cydulka, 1991 | First responder | K: To increase knowledge base regarding AIDS and hepatitis B. A: To decrease fear of contracting AIDS. | K: Not applicable. A: 89% of paramedics indicated their work significantly increased their chances of contracting AIDS. S: Not applicable. B: Not applicable. C: Not applicable. | Fear of contracting AIDS is widespread among paramedics. Educational program improved paramedics' knowledge base regarding AIDS. Educational program did not change attitudes and fears regarding AIDS.
Novick, 1985 | Medical student | A: To analyze the epidemiologic evidence on outbreaks of disease. A: To develop study designs and to test hypotheses about public health issues. A: To appraise evidence from published studies to enhance clinical management. | K: Not applicable. A: Overall assessment of the epidemiology course as average or above increased from 54% in 1982 to 98% in 1983 and 93% in 1984. Regarding the outbreak investigation component of the course, 1% of participants rated it highly helpful, 50% helpful, 43% somewhat helpful, and 1% not helpful. S: Not applicable. B: Not applicable. C: Not applicable. | The Vermont experience has shown that combining health department and clinical faculty resources can result in a useful format for teaching epidemiology to medical students.
Simoes, 1997 | Community health worker | B: To use case management charts appropriately to assess, classify, treat, and refer sick children. | K: Not applicable. A: Not applicable. S: Not applicable. B: Health workers performed well with training in treatment and illness classification guidelines. Health workers encountered problems with referrals after training: for commonly seen signs and symptoms they had 67% to 91% agreement with physicians, and for uncommonly seen signs there was 20% to 45% agreement with physicians. C: Not applicable. | Training in the use of integrated management of childhood illness guidelines with supervised clinic time improves health workers' ability to assess, classify, and treat sick children and counsel the mother.
Lloyd, 1999 | Physician | K: To increase awareness of how to recognize Ebola hemorrhagic fever (EHF). S: To increase skills in recognizing EHF. | K: 15 of 15 participants that completed evaluation interviews reported understanding the risk for EHF. A: Not applicable. S: 10 of the 15 participants that completed evaluation interviews reported improved recognition of EHF. B: Not applicable. C: Not applicable. | It is possible to implement a surveillance system that has minimal maintenance costs and does not require constant reporting.
Dorman, 1990 | Nurse, allied health student (or professional), premedical student | K: To provide accurate knowledge regarding HIV/AIDS. A: To engender attitudes that acknowledge personal risk for HIV infection. A: To reduce unreasonable fears about HIV transmission. S: To provide skills for reducing high-risk behaviors. | K: Students indicated a better understanding of the scope and complexity of problems related to AIDS/HIV. A: Students reported more willingness to acknowledge and speak openly about diseases. Students reported less fear and more compassion toward people living with AIDS. S: Students were more willing to openly discuss sexual behavior, STDs, and AIDS. B: Not applicable. C: Not applicable. | The course increased students' understanding of HIV and AIDS, and improved attitudes toward patients with AIDS.
Hixon, 1990 | Nurse | B: To increase use of protective barriers with venopuncture, emptying urinals, tracheotomy care, suctioning, dressing changes, procedures involving blood, and sharps disposals. | K: Not applicable. A: Not applicable. S: Not applicable. B: Nurses increased their use of protective barriers (83 to 92%), handwashing (66 to 97%), prioritizing patient care (72 to 99%), supplies properly obtained (78 to 94%), and isolation protocols followed (92 to 97%). C: Not applicable. | The educational intervention improved the use of protective barriers, handwashing, prioritizing of patient care assignments, obtaining of supplies prior to procedures, and following isolation protocols.
Roos, 1995a | Community health worker | K: To make a clinical leprosy diagnosis and classify patients to the proper treatment categories. K: To treat leprosy patients with multidrug therapy. K: To perform basic recording on the leprosy patient card, the daily register, and the clinical register (log). S: To make arrangements to collect skin smears as appropriate. S: To do basic nerve function assessment. B: To recognize leprosy complications and refer them to a referral center or district leprosy supervisor. B: To give health education in leprosy to target groups. | K: About half of staff intervention group had classified patients competently for a treatment, compared to very few in the control group. Staff responded that the clinical diagnosis content of the course was too short. Interviewed staff in both groups reported diagnosing new leprosy patients in the last 3 months, but patients rarely mentioned hearing about leprosy from clinic staff. A: Not applicable. S: Only 50% of staff in the intervention group competently obtained skin smears. Basic nerve function assessment was done competently by most intervention staff. B: Patient satisfaction was better for the intervention group than for the control group. Basic nerve function assessment was done by most intervention staff. Most basic recording was done properly except for smear results and late patients. Most referrals were done properly. Treatment for complications was not done properly in almost half of intervention group. Specific health education to leprosy patients was observed during most visits. C: Not applicable. | Most aspects of leprosy care were observed to be properly carried out after course. Dressing and skin smear taking were performed less competently. Diagnosis, classification, and nerve function assessment were often mentioned as inadequately addressed in the course. Drugs were more often available in the sites where staff had been trained.
Millward, 1993 | Nurse | K: To increase knowledge of infection control principles and develop nurses with infection control knowledge (link nurses). B: To increase ward audit scores for infection control. | K: Link nurses had higher knowledge scores than non-link nurses (mean 69.3 vs. 52.8; p<0.008), but it is unclear how the groups differed in baseline knowledge and characteristics. A: Not applicable. S: Not applicable. B: Wards with link nurses had higher ward audits scores than wards without link nurses (79.0 vs. 66.1; p<0.001), but it is unclear how groups differed in baseline performance and other characteristics. C: Not applicable. | Training of infection control link nurses was effective.
Kidd, 1999 | Nurse, physician, hospital staff | K: To relate the past history of infection control practices to CDC guidelines. K: To describe the elements needed for spread of infection. K: To define standard precautions. K: To identify the categories of transmission of infections using CDC transmission-based precautions. B: To utilize the guidelines for appropriate practice of standard and transmission-based precautions. | K: Not applicable. A: Not applicable. S: Not applicable. B: After 2 months of preparatory education, proper posting of precautionary signs was 0.0%. Seven months after fully implementing the CDC standard and transmission-based precautions, compliance with isolation practice increased to 70.2%. C: Not applicable. | Initial broad-based lectures were ineffective in improving compliance with isolation practices. Smaller, customized (by department) inservices proved more effective. Therefore intensive, individualized education is the key to compliance.
Brown, 1990 | Nurse, physician, social worker, physical therapist | K: To discuss major implications of the Omnibus AIDS Law for health care workers in the State of Washington. K: To describe the etiology, epidemiology, pathophysiology, and social impact of AIDS. K: To list three ways HIV can be transmitted. K: To describe the natural course of AIDS including clinical manifestations. K: To describe at least five methods that can be used to prevent transmission of HIV. K: To describe requirements for informed consent and counseling associated with HIV testing. K: To discuss diagnostic and treatment measures for HIV infection/AIDS. K: To name three community resources available to address the needs of people with AIDS. A: To explore personnel attitudes related to caring for people with AIDS. | K: The article does not report any results regarding the stated knowledge objectives. A: The article does not report any results regarding the stated attitude objectives. S: Not applicable. B: Not applicable. C: Not applicable. | It is unclear if AIDS education for health care workers should be mandated by law. If mandated, greater participation should be required of professionals who could have the greatest involvement in and control over management of AIDS patients. The early planning of any education requirement should involve representatives from professional associations, health care administrations, practitioners, and educators. To ensure educational quality, a process for programs should be developed. Educators must be given adequate preparation time for carrying out programs, and should be given a core curriculum to standardize content and decrease preparation time. A clear message should be sent to health care professionals that a mass education program is being undertaken and experts are expected to cooperate.
Meisenhelder, 1994 | Nurse | A: To decrease fear of contagion regarding HIV. | K: Not applicable. A: Significant decreases in levels of fear were noted after the 1-day course, but not after the 6-week course. Fear decreased from mean score of 1.83 to 1.61 (p<0.0004) after the 1-day course. Fear decreased from 1.58 to 1.38 (p<0.33) after the 6-week course. S: Not applicable. B: Not applicable. C: Not applicable. | Significant decreases in levels of fear occurred with a 1-day program but not with a 6-week course. Willingness to care for HIV patients was unchanged by either intervention.
Jacobson, 1986 | Nurse, physician, clerk | None described. | K: Not applicable. A: Not applicable. S: Not applicable. B: Not applicable. C: Not applicable. | Proper ordering of isolation improved from 21% to 81% following institution of the hospital computerized information system which included CDC guidelines.
All, 1997 | Nurse | A: To reduce anxiety about HIV. | K: Not applicable. A: The course decreased the anxiety level regarding HIV among nursing students. Mean difference for trait anxiety was -1.97, p<0.0004; mean difference for state anxiety was -5.86, p<0.0002. Mean state anxiety scores decreased from 44.92 to 39.08. Mean trait anxiety scores decreased from 38.00 to 36.03. S: Not applicable. B: Not applicable. C: Not applicable. | The educational program reduced anxiety about working with AIDS.
Odhacha, 1998 | Health care worker | None described. | K: Not applicable. A: Not applicable. S: Not applicable. B: Overall scores for performance of assessment tasks were 81% (8,781 of 10,896) at end of training and 75% (1,988 of 2,662) at 1 to 3 months posttraining. Classification scores were 79% (1,535 correct of 1,939) at end of training and 78% (394 correct of 505) at a posttest. Treatment scores were 72% (680 of 951) at end of training and 67% (172 of 258) at a posttest. Scores for counseling were 69% (3,480 of 5,069) at end of training and 67% (829 of 1,237) at a posttest. Performance scores for classification and treatment of severe disease were much lower: 31% correctly classified and 32% correctly treated at end of training and 24% correctly classified and 26% correctly treated at a posttest. C: Not applicable. | Non-physician health workers achieved reasonably high performance levels managing ill children with mild and moderate disease classifications but performed much worse when managing severely ill children.
Boskovich, 1994 | Community health worker, social worker | K: To learn how to notify the health service if they observed a reactive tuberculin test. S: To learn how to recognize a "possible" reactive tuberculin test. B: To increase the percent of clients receiving tuberculin skin tests and to maximize returns for a followup reading. | K: Not applicable. A: Not applicable. S: Not applicable. B: The percentage of clients that returned for a reading of their tuberculin skin test was 68% during the 3 months after the intervention compared to 49% 1 year before the intervention. C: Not applicable. | The client return rate after the tuberculin skin testing was slightly greater after the intervention than before it, but the investigators could not determine whether the increased followup return rate could be attributed to the educational intervention.
Roos, 1995b | Community health worker | None described. | K: Not applicable. A: Not applicable. S: Not applicable. B: Not applicable. C: Not applicable. | Health post staff can be trained in comprehensive leprosy care, but followup and supervision are required to keep patient care up to standard.

Key question: | 1. Training clinicians to detect and manage a bioterrorist attact or other public health event
Public health model: | 2. Toxidromes and mass poisonings

Anderson, 1984 | First responder | None described. | K: Not applicable. A: Not applicable. S: Not applicable. B: Not applicable. C: Not applicable | Teleconferencing can be an acceptable continuing education technique for emergency personnel. Teleconferencing is economic and efficient.

Key question: | 1. Training clinicians to detect and manage a bioterrorist attack or other public health event
Public health model: | 4. Events that call for a hospital disaster plan

Cook, 1990 | Nurse, physician, technologist (e.g., radiology or emergency room technician), clerk | C: To improve assessment of victims and movement of patient flow through system. | K: Not applicable. A: Not applicable. S: Not applicable. B: Not applicable. C: Patient assessment and flow through the system improved. | Disaster drill in game format proceeded with less confusion due to clearly defined expectations in the observer checklist. Data could be shared with other departments through observer checklists. Most departments now have one person with in-depth knowledge of the disaster plan.
Tur-Kaspa, 1999 | Nurse, physician | None described. | K: Not applicable. A: Not applicable. S: Not applicable. B: Not applicable. C: Not applicable. | Lessons were learned from the drill and incorporated into a revised hospital deployment plan.
Gofrit, 1997 | Physician | K: To implement effective triage based on level of injury in a simulated disaster. S: To establish airway, apply dressings, put in intravenous lines in a simulated disaster. | K: Over-triage occurred in 9% of cases (not life threatening injury determined but not present), under-triage in 4% of cases (should have been triaged to more emergent care level). Treatment was delayed due to lack of leadership. Patients with post-traumatic stress disorder were mismanaged. A: Not applicable. S: Physicians were not familiar with crush syndrome after trauma. Arterial rubber arterial tourniquets were used too frequently for minor hemorrhage. Patients were transferred without medical escort and/or retaliation support. B: Not applicable. C: Not applicable. | Integrating physicians among simulated casualties in a hospital disaster drill may contribute to achieving the objectives and add to disaster education.
Naggan, 1976 | Physician | S: To check the ability of hospitals to implement a written disaster procedure in mass casualty exercises. B: To assess how hospitals performed during the October 1973 war. C: To assess the rate of total mortality, rate of killed in action, or rate of died of wounds in the war. | K: Not applicable. A: Not applicable. S: Not applicable. B: An orderly and controlled evacuation was achieved. Wounded were distributed to hospitals in the country using good communication and a centralized control system. The concept of one hospital becoming the triage center of other hospitals in the area was practical and successful. C: Mortality from war injuries decreased approximately 10-25% from having medical officers at the front. Total mortality was 20% higher than Six Day War but not higher than the 1st part of the War of Attrition. "Died of wounds" rate was 2.3% compared to 1.9% in Six Day War, 3.0% and 3.7% in 1st and 2nd parts (respectively) of the War of Attrition. Mortality of those who reached the hospital alive was only 1.2%. No preventable shock was seen and four successful limb grafts were performed. | Repeated training and exercises in planning for a disaster enabled hospitals to operate smoothly and efficiently and may help to reduce mortality.
Levi, 1998 | Hospital management staff | B: To identify personnel or lack of specific reinforcement personnel during a hospital multi-casualty drill. B: To identify specific medical equipment/medications and electromechanical system problems. B: To identify crowding within hospital departments during a multi-casualty disaster drill. B: To identify security problems. | K: Not applicable. A: Not applicable. S: Not applicable. B: The animation tool was useful in describing bottlenecks in the emergency departments, diagnostic departments, and operating rooms. C: Not applicable. | The simulation techniques used in preparing a limited scale drill had advantages in evaluating and improving preparedness of hospitals, and they could manage a multi-casualty event before a full-scale drill trial.

Key question: | 3. Training clinicians to report events to a central agency
Public health model: | 1. Infectious disease outbreaks

Durrheim, 2001 | Nurse | K: To identify syndromes designated for immediate reporting. S: To increase completeness of reporting. B: To increase completeness and timeliness of weekly zero reporting. C: To report occurrence of cholera and meningococcal disease. C: To report cases of acute flaccid paralysis. | K: Symptoms/signs were noted in 14 of 14 cases of meningitis. Symptoms/signs were noted in 1 of 1 cholera case. Symptoms/signs were noted in 7 of 11 polio cases. Six unreported cases were thought to be appropriately unreported. A: Not applicable. S: 14 of 14 meningitis cases were reported within 48 hours; 1of 1 case of cholera was reported. B: In 1998, 12 (38%) of hospitals provided 80% of reports on time. In 1999 100% of reports were timely. Completeness of reporting improved from 75% of hospitals (first quarter 1998) to 100% of hospitals at first quarter 1999. C: One case of cholera was reported within hours; 100% of meningococcal cases were reported within 48 hours; 7 of 11 cases of flaccid paralysis were discovered. | Infection control nurses excelled in timely, accurate weekly reporting, participating at monthly training and feedback sessions, detecting priority clinical syndromes and prompting appropriate responses.

* Key for "Description of objective(s)": A = Attitude; B = Behavior; C = Clinical outcome; K = Knowledge; S = Skill.