# References

1 Simon JD Biological terrorism. Preparing to meet the threat JAMA 1997 Aug 6 278(5):428 30 9244336
2 Henderson DA. The looming threat of bioterrorism. Science. 1999 Feb 26;283:1279-82. [pmid: 10037590].
3 Recommendations of the CDC Strategic Planning Workgroup MMWR Morb Mortal Wkly Rep 2000 Apr 21 49(RR-4):1 14
4 Henderson DA, Inglesby TV, Bartlett JG, et al Smallpox as a biological weapon: medical and public health managementWorking Group on Civilian Biodefense.JAMA 1999 Jun 9 281(22):2127 37
5 Eitzen D, Pavlin J, Cieslak T, et al. Medical Management of Biological Casualties. (3d ed. .) Fort Detrick, Frederick (MD): U.S. Army Medical Research Institute of Infectious Diseases. 1998. [pmcid: 325579].
6 Inglesby TV, Henderson DA, Bartlett JG, et al Anthrax as a biological weapon: medical and public health managementWorking Group on Civilian Biodefense.JAMA 1999 May 12 281(18):1735 45
7 Inglesby TV, Dennis DT, Henderson DA, et al Plague as a biological weapon: medical and public health managementWorking Group on Civilian Biodefense.JAMA 2000 May 3 283(17):2281 90
8 Arnon SS, Schechter R, Inglesby TV, et al Botulinum toxin as a biological weapon: medical and public health management JAMA 2001 Feb 28 285(8):1059 70
9 Dennis D, Inglesby T, Henderson D, et al Tularemia as a Biological weapon: medical and public health management JAMA 2001 Jun 6 285(21):2763 73
10 Inglesby TV. The germs of war, how biological weapons could threaten civilian populations. The Washington Post. 1998 Dec 6. [pmcid: 325579].
11 McCormick JB, Fisher-Hoch SP. Arenaviruses and other hemorrhagic fever viruses. In: Gorbach SL, Barlett, JG, Blacklow, NR, Eds. Infectious Diseases. Philadelphia: Saunders. 1992:pp. 1842-68.
12 Christopher GW, Cieslak TJ, Pavlin JA, et al Biological warfare. A historical perspective JAMA 1997 Aug 6 278(5):412 7
13 Zilinskas RA Iraq's biological weapons. The past as future? JAMA 1997 Aug 6 278(5):418 24 9244334
14 Alibek K. Biohazard. New York: Random House. 1999. [pmcid: 325679].
15 Torok TJ, Tauxe RV, Wise RP, et al A large community outbreak of salmonellosis caused by intentional contamination of restaurant salad bars JAMA 1997 Aug 6 278(5):389 95
16 Suzuki J, Kohno T, Tsukagosi M, et al Eighteen cases exposed to sarin in Matsumoto, Japan Intern Med 1997 Jul 36(7):466 70 9240494
17 Okumura T, Takasu N, Ishimatsu S, et al Report on 640 victims of the Tokyo subway sarin attack Ann Emerg Med 1996 Aug 28(2):129 35 8759575
18 Sidel VW, Cohen HW, Gould RM Good intentions and the road to bioterrorism preparedness Am J Public Health 2001 May 91(5):716 18 11344877 1446690
19 Geiger HJ Terrorism, biological weapons, and bonanzas: assessing the real threat to public health Am J Public Health 2001 May 91(5):708 9 11344875 1446684
20 Tenet as prepared for delivery before the Senate Armed Services Committee Hearing on Current and Projected National Security Threats. 1999 Feb 2. [pmcid: 325679].
21 Pavlin JA Epidemiology of bioterrorism Emerg Infect Dis 1999 Jul-Aug 5(4):528 30 10458958
22 O'Toole T. Hearing on terrorism preparedness: Medical first response. Testimony to the House of Representatives Committee on Government Reform, Subcommittee on National Security, Veterans Affairs, and International Relations. 1999 Sept 22. [pmcid: 325679].
23 Henretig F Biological and chemical terrorism defense: a view from the "front lines" of public health Am J Public Health 2001 May 91(5):718 20 11344878 1446658
24 Pesik N, Keim M, Sampson TR Do US emergency medicine residency programs provide adequate training for bioterrorism? Ann Emerg Med 1999 Aug 34(2):173 6 10424918
25 Developing objectives, content, and competencies for the training of emergency medical technicians, emergency physicians, and emergency nurses to care for casualties resulting from nuclear, biological, or chemical (NBC) incidents. Final Report. Irving (TX): American College of Emergency Physicians. 2001 Apr. [pmcid: 369639].
26 Centers for Disease Control and Prevention.MMWR Morb Mortal Wkly Rep 1997 May 2 46(RR-10):1 55
27 Kern DE, Thomas PA, Howard DM, et al. Curriculum Development for Medical Education: A Six-Step Approach. Baltimore: The Johns Hopkins University Press. 1998. [pmcid: 325579].
28 Berlin JA. Randomized trial comparing masked/unmasked meta analysis. Technical Report prepared for the Agency for Health Care Policy and Research, Rockville (MD); 1996. Available from the National Technical Information Service (NTIS accession number PB98-109382).
29 Jampel HD, Lubomski LH, Friedman DS, et al. Treatment of Coexisting Cataract and Glaucoma. Evidence Report/Technology Assessment No. 38. Rockville (MD): Agency for Healthcare Research and Quality (forthcoming).
30 Schein OD, Friedman DS, Fleisher LA, et al. Anesthesia Management During Cataract Surgery. Evidence Report/Technology Assessment No. 16 (AHRQ Pub. No. 01-E017). Rockville (MD): Agency for Healthcare Research and Quality. 2001. [pmcid: 369639].
31 Harrison A, Karim SA, Floyd K, et al Syndrome packets and health worker training improve sexually transmitted disease case management in rural South Africa: randomized controlled trial AIDS 2000 Dec 1 14(17):2769 79
32 Kemppainen JK, Dubbert PM, McWilliams P Effects of group discussion and guided patient care experience on nurses' attitudes towards care of patients with AIDS J Adv Nurs 1996 Aug 24(2):296 302 8858433
33 Garcia PJ, Gotuzzo E, Hughes JP, et al Syndromic management of STDs in pharmacies: evaluation and randomised intervention trial Sex Transm Infect 1998 Jun 74Suppl 1:S153 8 10023367
34 Gerbert B, Sumser J, Maguire BT, et al Planning, implementation, and evaluation of AIDS education programs for dentists J Dent Educ 1991 Feb 55(2):138 44 1990025
35 Zimmerman RK, Barker WH, Strikas RA, et al Developing curricula to promote preventive medicine skills. The Teaching Immunization for Medical Education (TIME) Project. TIME Development Committee JAMA 1997 Sep 3 278(9):705 11
36 Umble KE, Cervero RM, Yang B, et al Effects of traditional classroom and distance continuing education: a theory-driven evaluation of a vaccine-preventable diseases course Am J Public Health 2000 Aug 90(8):1218 24 10937000 1446344
37 Maetz HM, Walton W, Smith M, et al "A satellite primer on tuberculosis:" a collaboration in distance education J Public Health Manag Pract 1998 Sep 4(5):46 55 10187066
38 Russell NK, Boekeloo BO, Rafi IZ, et al Using unannounced simulated patients to evaluate sexual risk assessment and risk reduction skills of practicing physicians Acad Med 1991 Sep 66(9 Suppl):S37 9 1930522
39 Epstein RM, Levenkron JC, Frarey L, et al Improving physicians' HIV risk-assessment skills using announced and unannounced standardized patients J Gen Intern Med 2001 Mar 16(3):176 80 11318913 1495186
40 Lewis DA, Brain G, Cushing AM, et al Description and evaluation of an education and communication skills training course in HIV and AIDS for dental consultants Eur J Dent Educ 2000 May 4(2):65 70 11168465
41 Bowman MA, Russell NK, Boekeloo BO, et al The effect of educational preparation on physician performance with a sexually transmitted disease-simulated patient Arch Intern Med 1992 Sep 152(9):1823 8 1520049
42 Armstrong-Esther C, Hewitt WE The effect of education on nurses' perception of AIDS J Adv Nurs 1990 Jun 15(6):638 51 2365906
43 Bennett C, Weale A HIV and AIDS awareness: an evaluation of a short training programme for midwives J Adv Nurs 1997 Aug 26(2):273 82 9292360
44 Paauw DS, Wenrich MD, Curtis JR, et al Ability of primary care physicians to recognize physical findings associated with HIV infection JAMA 1995 Nov 1 274(17):1380 2
45 Talan DA, Baraff LJ Effect of education on the use of universal precautions in a university hospital emergency department Ann Emerg Med 1990 Nov 19(11):1322 6 2240732
46 Lewis CE, Bursch B, Klau M, et al Continuing medical education for AIDS: an organizational response AIDS Educ Prev 1993 Fall 5(3):263 71 8217478
47 Green M, Hoffman IF, Brathwaite A, et al Improving sexually transmitted disease management in the private sector: the Jamaica experience AIDS 1998 12Suppl 2:S67 72 9792363
48 Zell SC An evaluation of teaching methods utilized during an HIV miniresidency course for Thai physicians AIDS Educ Prev 1997 Feb 9(1):70 82 9083592
49 Osborn EH, Papadakis MA, Gerberding JL Occupational exposures to body fluids among medical students. A seven-year longitudinal study Ann Intern Med 1999 Jan 5 130(1):45 51
50 Fischer LR, Conboy KS, Tope DH, et al Educating health professionals: a hepatitis C educational program in a health maintenance organization Am J Manag Care 2000 Sep 6(9):1029 36 11184064
51 Ofori-Adjei D, Arhinful DK Effect of training on the clinical management of malaria by medical assistants in Ghana Soc Sci Med 1996 Apr 42(8):1169 76 8737435
52 Soudarssanane MB, Singh MC Teaching epidemiology of acute diarrheal diseases to medical undergraduates--a new approach Indian J Pediatr 1994 May-Jun 61(3):277 80 7525475
53 Cohen LA, Grace EG, DePaola LG Evaluation of a one-day AIDS continuing education course MSDA J 1996 Spring 39(1):31 6 9569873
54 Tuladhar SM, Mills S, Acharya S, et al The role of pharmacists in HIV/STD prevention: evaluation of an STD syndromic management intervention in Nepal AIDS 1998 12Suppl 2:S81 7
55 Sowell R, Seals G, Wilson B, et al Evaluation of an HIV/AIDS continuing education program J Contin Educ Nurs 1998 Mar-Apr 29(2):85 93 9582777
56 Hartnett SM A hospital-wide AIDS education program J Contin Educ Nurs 1987 Mar-1987 Apr 30 18(2):64 7 3104425
57 Delacollette C, Van der Stuyft P, Molima K Using community health workers for malaria control: experience in Zaire Bull World Health Organ 1996 74(4):423 30 8823965
58 O'Donnell L, O'Donnell CR Hospital workers and AIDS: effect of in-service education on knowledge and perceived risks and stresses N Y State J Med 1987 May 87(5):278 80 3473332
59 Anderson DG, Vojir C, Johnson M Three medical schools' responses to the HIV/AIDS epidemic and the effect on students' knowledge and attitudes Acad Med 1997 Feb 72(2):144 6 9040257
60 Breman JG, Alecaut AB, Malberg DR, et al Smallpox in the Republic of Guinea, West Africa. II. Eradication using mobile teams Am J Trop Med Hyg 1977 Jul 26(4):765 74 889016
61 Ray AP, Narasimham MV Evaluation of training programme J Commun Dis 1991 Dec 23(4):231 9 1842803
62 Inglesby T, Grossman R, O'Toole T A plague on your city: observations from TOPOFF Clin Infect Dis 2001 Feb 1 32(3):436 45
63 Lieb VA, Kozinn WP, Baxter P Self-paced learning stations for tuberculosis respirator training: report of a pilot program Am J Infect Control 1996 Aug 24(4):299 303 8870913
64 Kaur J Awareness effect on nursing students of planned teaching programmes on AIDS Nurs J India 1998 Jun 89(6):128 9, 138 10670375
65 Kark SL, Mainemer N, Abramson JH, et al Community medicine and primary health care: field workshop on the use of epidemiology in practice Int J Epidemiol 1973 Winter 2(4):419 26 4773238
66 Katsufrakis PJ, Radecki SE Clinical training in human immunodeficiency virus disease for community physicians. The Los Angeles experience West J Med 1992 Jun 156(6):619 23 1615654 1003346
67 Pandit K, Kumar S, Aggarwal OP Knowledge of fresh medical graduates about immunization: impact of posting in community medicine Indian J Pediatr 1991 May-1991 Jun 30 58(3):345 8
68 Novick LF, Greene C, Vogt RL Teaching medical students epidemiology: utilizing a state health department Public Health Rep 1985 Jul-1985 Aug 31 100(4):401 5
69 Cydulka RK, Mathews JJ, Born M, et al Paramedics: knowledge base and attitudes towards AIDS and hepatitis J Emerg Med 1991 Jan-1991 Apr 30 9(1-2):37 43
70 Simoes EA, Desta T, Tessema T, et al Performance of health workers after training in integrated management of childhood illness in Gondar, Ethiopia Bull World Health Organ 1997 75Suppl 1:43 53 9529717
71 Lloyd ES, Zaki SR, Rollin PE, et al Long-term disease surveillance in Bandundu region, Democratic Republic of the Congo: a model for early detection and prevention of Ebola hemorrhagic fever J Infect Dis 1999 Feb 179Suppl 1:S274 80 9988195
72 Dorman SM, Collins ME, Brey RA A professional preparation course on AIDS/HIV infection J Sch Health 1990 Aug 60(6):266 9 2232730
73 Hixon AK, Thomason SS, Lohmann Nodhturft V Evaluating quality and ongoing improvement of clinical practice following HIV/AIDS education J Nurs Qual Assur 1990 Nov 5(1):61 72 2211951
74 Roos BR, van Brakel WH Use of facility-based assessment in the evaluation of a comprehensive leprosy training program in Nepal Int J Lepr Other Mycobact Dis 1995a Dec 63(4):552 8 8642219
75 Millward S, Barnett J, Thomlinson DA Clinical infection control audit programme: evaluation of an audit tool used by infection control nurses to monitor standards and assess effective staff training J Hosp Infect 1993 Jul 24(3):219 32 8104212
76 Kidd F, Heitkemper P, Kressel AB A comprehensive educational approach to improving patient isolation practice Clin Perform Qual Health Care 1999 Apr-Jun 7(2):74 6 10747569
77 Brown JM, Bradshaw E Meeting the challenge of mandatory AIDS education for health care workers J Contin Educ Health Prof 1990 10(2):137 52 10145316
78 Meisenhelder JB, Rice L Evaluating interventions for fear of contagion J Assoc Nurses AIDS Care 1994 Sep-1994 Oct 31 5(5):48 55
79 Jacobson JT, Johnson DS, Ross CA, et al Adapting disease-specific isolation guidelines to a hospital information system Infect Control 1986 Aug 7(8):411 8 3017880
80 All AC, Sullivan L The effects of an HIV/AIDS educational programme on the anxiety level of nursing students J Adv Nurs 1997 Oct 26(4):798 803 9354994
81 Odhacha A, Orone H, Pambala M, et al Health worker performance after training in integrated management of childhood illness--Western Province, Kenya, 1996-1997 MMWR Morb Mortal Wkly Rep 1998 Nov 27 47(46):998 1001
82 Boskovich SJ New concepts in nursing management of the TB patient: a community training program J Community Health Nurs 1994 11(1):45 9 8201368
83 Roos BR, van Brakel WH, Chaurasia AK Integration of leprosy control into basic health services; an example from Nepal Int J Lepr Other Mycobact Dis 1995b Sep 63(3):422 9 7594926
84 Anderson P, Emerson D, Robertson WO Delivering educational programs via telephone: teleconferencing Vet Hum Toxicol 1984 26Suppl 2:14 5 6523720
85 Cook L Hospital disaster drill game: a strategy for teaching disaster protocols to hospital staff J Emerg Nurs 1990 Jul-Aug 16(4):269 73 2385061
86 Tur-Kaspa I, Lev EI, Hendler I, et al Preparing hospitals for toxicological mass casualties events Crit Care Med 1999 May 27(5):1004 8 10362427
87 Gofrit ON, Leibovici D, Shemer J, et al The efficacy of integrating "smart simulated casualties" in hospital disaster drills Prehospital Disaster Med 1997 Apr-1997 Jun 30 12(2):97 101
88 Naggan L Medical planning for disaster in Israel. Evaluation of the military surgical experience in the October 1973 War, and implications for the organization of the civilian disaster services Injury 1976 May 7(4):279 85 1278989
89 Levi L, Bregman D, Geva H, et al Hospital disaster management simulation system Prehospital Disaster Med 1998 Jan-1998 Mar 31 13(1):29 34
90 Durrheim DN, Harris BN, Speare R, et al The use of hospital-based nurses for the surveillance of potential disease outbreaks Bull World Health Organ 2001 79(1):22 7 11217663
91 Green LW, Kreuter MW, Deeds SG, et al. Selection of educational strategies. In: Health Education Planning: A Diagnostic Approach. Palo Alto (CA): Mayfield Publishing. 1980:pp. 86-115.
92 Medical preparedness for terrorism and other disasters. Report 11 of the Council on Scientific Affairs (No. I-00). Chicago (IL): American Medical Association. 2000. [pmcid: 384376].
93 Computer-related tools for training and operations. In: Chemical and Biological Terrorism. Washington (DC): National Academy Press. 1999:pp. 174-83.