# Acknowledgments

The Johns Hopkins University Evidence-based Practice Center expresses its appreciation to Saba Syed, B.A., Kirk A. Harris, Jr., B.A., Xiaoyan Song, M.D., M.S., Neel Patel, and Neil R. Powe, M.D., M.B.A., M.P.H., for their contributions to this project.