# Future Research

As discussed in Chapters 3 and 4, the literature relating to the most effective way to train clinicians to respond to a bioterrorist attack or other public health event was scant and limited by heterogeneity and methodological issues. The most glaring limitation revealed by this review was the paucity of data that directly addressed how to effectively train clinicians to respond to a bioterrorist attack. Only one article was identified that described and evaluated an educational intervention pertaining to bioterrorism.^ 62 ^ This deficiency should be a high priority area for future research.

To meet the need for education in bioterrorism preparedness, more attention should to be given to evaluating the effectiveness of relevant training programs in a scientifically rigorous manner. Few studies to date have used comparative methods to determine the best techniques for educating clinicians on issues pertinent to bioterrorism preparedness and other public health events. Studies need to be initiated to address this deficiency and should employ appropriate evaluation methods, including pretesting and posttesting, at least one comparison group, and a clear description of the representativeness of the target group. Study designs that use measurable outcomes will be critical to assure fair and unbiased determination of the efficacy of new educational methods. In addition, targeted outcomes need to be linked to well-defined objectives. The validity and usefulness of such evaluation efforts will depend on how well educators address the methodologic issues highlighted in this report.

Since bioterrorism preparedness will require training of many different types of clinicians, and widespread training will require an extraordinary investment of resources, some attention is needed regarding the costs of implementing educational programs. Ultimately, programs that are effective and evaluated as cost-efficient are the most useful. For instance, while use of standardized patients seemed to be an effective educational technique, this technique generally requires one-on-one contact and may not be cost-efficient for training large numbers of clinicians.

Because the literature represented a broad spectrum of health care providers, settings and geographic locations, the EPC team could not determine whether the efficacy of specific training methods varied among different types of clinicians or settings. Future studies should seek to determine which educational models are best for which professions (e.g., physician, nurse, or community health worker), practice settings (e.g., hospital, urban clinic, or rural clinic), and geographic locales (e.g., North America, Africa, or Asia). Such studies will need to pay particular attention to the comparability of study groups and statistical adjustment for baseline differences between groups.

Given the increasing use of computer and telecommunication technology, this is a ripe area of research on training for bioterrorism preparedness. (Indeed, AHRQ recently has funded projects on this very topic; see www.ahrq.gov.) We found only four eligible studies that evaluated the use of telecommunication ^36, 37, 64, 84^ and none that evaluated Web-based education. Furthermore, only one study addressed computer simulations.^ 89 ^ Given the weak evidence on the effectiveness of relevant educational programs, it will be particularly important to evaluate the effectiveness of new programs emerging from the AHRQ-funded work and other projects.

A comprehensive report generated by the Institute of Medicine and the National Research Council also addressed the importance of developing computer-related training tools.^ 93 ^ The report included discussion of three main roles for computer programs in bioterrorism preparedness. First is the role of surveillance systems, which use epidemiologic methods to detect and track the spread of emerging infections and other diseases. Second, computer programs may assist in identifying the source of an outbreak and modeling the vectors of dispersion, thereby predicting the pattern of exposures. The third important role for computer models is as a training tool for clinicians and first responders. Computer simulations can address training in bioterrorism preparedness while allowing for adjustments in environmental conditions (e.g., wind patterns), infrastructure limitations (e.g., availability of hospitals and pharmaceuticals), and communication interruptions. The report suggested that these tools will "decrease the need for frequent participation in large exercises that can be disruptive, logistically complicated, expensive, and unproductive."^ 93 ^ It called for the development of training software that is "user friendly, easy to learn, [able to] run on networks that can be accessed at multiple locations, and used frequently by all levels of the first-responder community."^ 93 ^

Finally, only one article evaluated the effectiveness of tabletop exercises as a training tool for use in bioterrorism preparedness. Some experts believe that tabletop exercises may be the most effective way to raise awareness about biological warfare (personal communication, Tara O'Toole, M.D.). Unfortunately, the EPC group was unable to find strong evidence about the effectiveness of tabletop exercises in training clinicians on how to respond to public health events such as a bioterrorist attack. This too could be a priority for future research.

The following specific questions describe important areas for future research that remain unresolved by the existing literature:

- What are the most effective and efficient educational methods to enhance knowledge about bioterrorism preparedness and other public health events among physicians, nurses, and other health care providers?
- How often does knowledge of clinicians about preparedness for bioterrorism or other public health events need to be reinforced?
- What is the most effective technique to train clinicians to use Web- or telephone-based central information resources in response to a public health event?
- What is the most effective technique to train clinicians to notify a central agency about reportable diseases or other events?
- What is the most effective technique to train clinicians to communicate with other health care professionals during a public health event?
- How can Web-based educational programs enhance the training of clinicians for bioterrorism preparedness and other public health events?
- Is teleconferencing a cost-effective method of training clinicians for bioterrorism preparedness and other public health events?
- Are computer simulations a cost-effective method for bioterrorism preparedness and other public health events?
- Are disaster drills and tabletop exercises cost-effective educational methods for training clinicians in how to respond to a bioterrorist attack or other public health event?
- To what extent will clinicians' preparedness for bioterrorism be strengthened by training in how to manage public health events such as infectious disease outbreaks?

Although the above suggestions for future research represent some interesting pedagogical questions, the EPC group recognizes that the time and effort required to scientifically investigate these topics is incongruent with the urgent need for bioterrorism preparedness. In view of the recent terrorist attacks in the United States, public representatives most likely will demand a reassessment of domestic preparedness efforts. Experts on bioterrorism preparedness will emphasize the importance of strengthening the public health infrastructure, enhancing disease surveillance systems, and stockpiling vaccines and drugs. Support will also be needed to continue to develop and implement better ways of preparing clinicians for the roles they would play in responding to a bioterrorist attack. Some innovative projects have been launched through the Bioterrorism Initiative of the AHRQ. More work is needed. Increased support for such work could come from professional societies and foundations in addition to Federal and State governmental agencies. By increasing support for training of clinicians in bioterrorism preparedness, the United States should be able to address this gap in domestic preparedness in addition to strengthening the Nation's ability to manage other types of public health events such as infectious disease outbreaks.