# Conclusions

## Principal Findings

Despite an extensive literature and Web site search that identified over 1,900 articles, only 60 articles were found that described and evaluated an educational intervention involving one of the key questions and a relevant pubic health event model. The majority of identified studies pertained to the training of clinicians for detection and management of an infectious disease outbreak (key question 1, public health model 1).

These studies combined a variety of educational techniques, such as lectures, discussion, audiovisual aids, and written material. Drawing comparisons among the studies was challenging because of differences in the educational topics, educational techniques, audiences, contact times, evaluation methods, and outcomes. Hence, it was difficult to form definitive conclusions regarding training of clinicians for bioterrorism preparedness from this disparate body of literature.

Nonetheless, common themes were identified in some of the articles. For example, standardized patients were employed as part of an educational intervention in seven studies.^31, 33, 38, 39, 41, 44, 53^ The literature suggested that this technique was acceptable to physicians, who usually prepared ahead of time using self-study materials. Because this technique was generally used for one-on-one educational encounters, it is unclear how useful this educational method would be for widespread training of clinicians about bioterrorism preparedness. In addition, costs for standardized patients were not discussed in the studies reviewed. This educational method may be cost prohibitive for widespread training.

Teleconferencing, or satellite broadcasting, was used in four studies.^36, 37, 64, 84^ This technique appeared to be an effective way to reach large numbers of learners and may be as effective as classroom learning.

A tabletop exercise was used in one article.^ 62 ^ Interestingly, this was the only article to directly address the training of clinicians in bioterrorism preparedness. The article suggested that tabletop exercises or theoretical drills may be useful in educating clinicians about bioterrorism response.

Only one article studied training of clinicians using the public health model of toxidromes or mass poisonings.^ 84 ^ Unfortunately, this article had a weak study design and did not adequately support the conclusion that teleconferencing is an acceptable, economic, and efficient method for educating clinicians on toxicology. No studies were identified that applied to the training of clinicians using the public health model of events that incite fear and anxiety. Five articles were identified that described and evaluated educational interventions pertaining to the use of hospital disaster plans.^85-89^ The literature suggested that disaster drill training improved knowledge of the disaster plan and allowed identification of problems in plan execution that may then be addressed. One of these articles described the use of a computer simulation in disaster drill training. The article concluded that simulation can replace expensive large scale drills and allow identification of deficiencies in staffing, equipment, medications, electromechanical systems, crowd control, and security.

Only one study evaluated methods for training clinicians to report events to a central agency.^ 90 ^ In this study, an educational intervention involving monthly structured education, networking, and feedback was effective in training infection control nurses to report certain infectious disease symptom complexes to a central agency.

Three of the key questions went unanswered. No literature specifically addressed the updating and reinforcing of clinicians' training. No literature was identified that addressed the training of clinicians to use Web- or telephone-based central information sources. Also, no information was found on the topic of training clinicians to communicate with other health care professionals during a public health event. Thus, the lack of these important bodies of literature highlights the need for future research into the most effective way to train clinicians in areas that will improve clinicians' ability to respond to a bioterrorist attack or other public health event.

## Limitations

This EPC report has several important limitations. The most obvious limitation is the paucity of studies that directly evaluated the effectiveness of training clinicians to detect and manage a bioterrorist attack. We recognize that our search was limited to published English language articles and Web sites; there may be classified or other unpublished material on bioterrorism training that is not included in this report. For example, theU.S. Army Medical Research Institute of Infectious Diseases offers both an in-house training course called the Medical Management of Chemical and Biological Casualties, as well as satellite distance learning courses. In 4 years, these courses trained over 58,000 personnel. Posttesting occurs for both courses, but the data have yet to be published (personal communication, Col. Edward Eitzen) (see Appendix K).

Of the selected public health event models that are relevant to the training of clinicians in bioterrorism preparedness, the infectious disease outbreak model is the only one that had a substantial body of literature evaluating educational methods. However, even the literature on this model provided very little information on three of the key questions. Thus, little is known about effective methods for training clinicians to use Web- or telephone-based central information resources, to report events to a central agency, or to communicate with other health care professionals in the event of a bioterrorist attack.

Another important limitation of this report stems from the marked heterogeneity of the studies on this topic. Because of the differences in the educational interventions, objectives, targeted learners, and evaluation methods, it is difficult to draw conclusions about the overall effectiveness of clinical training programs relevant to bioterrorism preparedness. This problem is aggravated by the small size of the studies and their methodologic limitations. For example, few studies used comparative evaluation methods, and some of the studies did not link well-defined objectives and specific measurable outcomes.

Other significant limitations in the literature have been identified. For example, we were unable to locate any studies that specifically addressed how to update and reinforce knowledge and skills related to the public health models most relevant to bioterrorism preparedness. Clinicians frequently need to retain rarely used information; yet there is little evidence base for understanding how to efficiently update and sustain such knowledge. Furthermore, our literature search did not reveal any studies that evaluated how the effectiveness of educational methods might differ among different types of clinicians. Clinicians in different fields with different responsibilities (e.g., public health nurses versus hospital-based infectious disease specialists) most likely will need different types of training in how to respond to public health events such as a bioterrorist attack (e.g., symptom recognition and reporting versus diagnosis and treatment). Finally, the studies provided very little information about the costs of the educational interventions.

## Implications

The recent terrorist attacks in New York City, Washington DC, and Pennsylvania have increased concerns about the risk of future terrorist attacks, including use of biological agents. Policymakers throughout the United States are in the midst of reassessing priorities for efforts needed to protect the country from further terrorist attacks, such as strengthening the public health infrastructure, enhancing disease surveillance systems, and stockpiling vaccines and drugs. While it is likely that the government will assign high priority to these vitally important components of bioterrorism preparedness, it will also be necessary to better prepare the Nation's clinicians for the roles they will play in responding to a bioterrorist attack. This evidence report clearly indicates that the lack of strong evidence on how to train clinicians for public health events represents an important gap in bioterrorism preparedness. Since Federal and State governmental agencies may not be able to fully fund all of the work that is needed to prevent and/or minimize the effects of a bioterrorist attack, other entities such as professional societies, foundations, and academic medical centers, may need to take responsibility for developing and evaluating appropriate educational programs for clinicians. A recent report by the American Medical Association (AMA) stated that, "local, state, and specialty medical societies and the AMA can play crucial roles in preparing the medical community to deal with the challenges presented by such disasters."^ 92 ^

Because of the limitations discussed in the previous section of this report, professional groups and governmental agencies should exercise caution in applying the existing evidence to specific guidelines on how to train clinicians to respond to public health events such as a bioterrorist attack. Instead of developing specific guidelines, it may be more important to call for development of new training programs and encourage appropriate evaluation of each educational intervention so that policymakers can identify the types of programs that are most effective. This evidence report should help to provide direction for such efforts by highlighting weaknesses and gaps in previous work.

As a final aspect of its comprehensive report (discussed in Chapter 1), the ACEP Nuclear, Biological and Chemical Task Force offered general recommendations for the education of clinicians in bioterrorism preparedness.^ 25 ^ Its recommendations are summarized below:

- Recruitment of related organizations to assure integration of education on the response to biological weapons into curricula.
- Development of free, technology-based self-study materials.
- Development of free instructor/learner teaching materials.
- Development of self-study programs for continuing medical education credit.
- Development of materials to be presented at conferences and meetings.

The American Medical Association echoed these requests at the 2000 AMA Interim Meeting.^ 92 ^ The AMA called for:

- Development of audience-specific medical education curricula on bioterrorism.
- Development of information resources on the medical response to bioterrorism.
- Encouragement of cooperation between State and specialty societies and Federal agencies to develop model plans for community medical responses to terrorism.
- Encouragement of timely, reliable, and adequate reporting of dangerous diseases to public health authorities.

The comprehensive summary provided by this evidence report may serve as a basis for responding to these recommendations by generating ideas for development of educational methods and stimulating efforts to better evaluate the programs that are being developed. These educational endeavors will be particularly important for those clinicians most likely to be involved in responding to a bioterrorist attack or other public health event, including emergency physicians, specialists in intensive care, and infectious disease and primary care practitioners.