# Results

## Literature Search and Abstract Review

The literature search process identified 1,942 unique potentially relevant citations. A summary of the literature search results through electronic databases and handsearching is provided in Appendix I. The bulk of the searching was completed in March and April 2001, with final searches of PubMed completed in June of 2001.

Through the review of titles of the identified citations, 357 citations were determined eligible for abstract review. Of these 75.9 percent (271 articles) did not meet the criteria for article review. Abstracts were excluded for the following reasons: the article did not report on health care professionals (55); the article did not include training and education (204); the article did not include any of the defined public health or bioterrorist attack models (111); or the article did not meet our criteria, including no evaluation information (76). The total number of reasons for exclusion exceeded the number of abstracts reviewed because the paired reviewers did not have to agree on the reason for exclusion, only that the abstract was excluded.

## Web Site Search and Review of Eligibility

The Web site search identified 39 unique addresses for review (see Appendix J). Each Web site was reviewed independently by investigators using the eligibility form (see Appendix F). None of the 39 Web sites revealed new information that met the eligibility criteria for the evidence report.

## Article Review

On review of the 86 articles, 60 (69.8 percent) were determined to be eligible for data abstraction. The other 26 articles were excluded for the following reasons: did not include health care professionals (1), did not include training or education (12), did not include evaluation of training or education (12), did not include one of the relevant public health models (12), and did not contain original information (1). The total number of reasons for exclusion exceeded the number of articles reviewed because reviewers did not have to agree on the main reason for exclusion, only that the article should be excluded.

## Focus and Design of the Reviewed Studies

Of the 60 articles that were reviewed, 59 (98.3 percent) addressed the key question on training of clinicians to detect and manage a bioterrorist attack or other public health event (key questions 1a and 1b); none addressed effective methods for training clinicians to use Web- or telephone-based central information resources in the event of a bioterrorist attack or other public health event (key question 2); one addressed effective methods for training clinicians to report events to a central agency in the event of a bioterrorist attack or public health event (key question 3); and none addressed effective methods for training clinicians to communicate with other health care professionals in the event of a bioterrorist attack or public health event (key question 4).^31-90^ (See Evidence Table 1.)

As shown in the evidence tables, almost all of the studies (54 of 60; 90 percent) focused on infectious disease outbreaks. Of these 54 articles, the most common infectious diseases addressed were human immunodeficiency virus/acquired immune deficiency syndrome (HIV/AIDS), sexually transmitted diseases (STDs), malaria, leprosy, and tuberculosis. Only three studies specifically addressed one of the CDC Category A agents (Ebola hemorrhagic fever, smallpox, and plague).^60, 62,71^ Six studies focused on the other public health event models: one focused on toxidromes and mass poisonings,^ 84 ^ and five focused on events that call for use of a hospital disaster plan.^85-89^ No studies addressed training for catastrophic events that incite fear. Only two studies addressed more than one question or more than one type of public health event model.^43, 88^

Six of the 60 studies were randomized controlled trials (RCTs), and all of these were focused on training related to management of infectious disease outbreaks.^31-34, 38, 51^ Besides these RCTs, there were 13 controlled studies. Three of these had a concurrent comparison group^46, 57, 59^ and 10 had a nonconcurrent comparison group.^35, 36, 42, 43, 49, 56, 74, 75, 78, 83^ (See Evidence Table 2.) Again, all of these focused on infectious disease outbreaks. The remaining 41 studies reported on an educational intervention without any comparison group. Thus, the majority of studies reviewed had weak study designs, thereby limiting the strength of conclusions that can be drawn from this literature.

Evidence Table 3 summarizes the assessment of the quality of the studies that pertain to each of the key questions. Within each section of the table, the studies are listed in order from highest to lowest total quality score.

Among the 53 studies that addressed the training of clinicians to detect and manage an infectious disease outbreak, the total quality score ranged from 16.0 to 87.5 percent on a scale from zero (none of criteria met) to 100 percent (all criteria met) (Evidence Table 3). This indicates substantial variation in overall study quality. Thus, it is important to consider how study quality was rated in each of the categories. The representativeness score for these studies ranged from zero to 100 percent, with a mean of 55.7 percent, median of 50 percent, and interquartile range from 50 to 62.5 percent. The bias score ranged from zero to 100 percent, with a mean of 14.5 percent, median of zero, and interquartile range from zero to 10 percent. The description score ranged from zero to 100 percent, with a mean score of 55.2 percent, median of 58.3 percent, and interquartile range from 41.7 to 75 percent. The outcome score ranged from 10 to 100 percent, with a mean score of 71.9 percent, median of 80 percent, and interquartile range from 60.0 to 90.0 percent. The statistics score ranged from zero to 100 percent, with a mean score of 29.5 percent, median score of 16.7 percent, and interquartile range from zero to 50 percent.

For the five studies that addressed training of clinicians on use of hospital disaster plans, the total quality scores were all low, ranging from 9.2 to 33.5 percent.^85-89^ The bias and statistical scores for these studies were all zero percent.

The one study on training of clinicians to detect and manage toxidromes had a low total quality score of 21.2 percent.^ 84 ^ The study on training clinicians to report events to a central agency had a total quality score of 50 percent.^ 90 ^

Of note, only 53 of the 60 studies (88.3 percent) reported specific measurable objectives. Of these 53 studies, 38 included knowledge objectives, 22 included attitudinal objectives, 18 included skill objectives, 24 included behavioral objectives, and 7 included clinical outcome objectives. (See Evidence Table 4.)

## Evidence Grades

After reviewing the studies, the EPC team decided that the evidence was too heterogeneous and the quality of studies generally too poor to justify formal grading of the level of evidence on each key question. The team felt that it was more important to simply identify the questions for which no evidence exists in the literature and identify the limitations in study quality found in the literature on the other key questions.

## Results of Key Questions

Each key question is individually addressed in this section. The evidence is reported for each question based on the public health event model represented.

### Questions 1a and 1b

What are effective methods for the initial training of clinicians for detection and management of a bioterrorist attack, using the infrequent public health event models? What are effective methods for updating and reinforcing the training of clinicians?

Sustaining knowledge following an educational intervention is important and remains a challenge, especially when the topic is uncommon and the clinician is unlikely to use the knowledge on a regular basis. Twenty of the articles initially met criteria for question 1b (i.e., methods of updating or reinforcing the training of clinicians).^31, 34, 38, 39, 41, 42, 44, 46-48, 50, 51, 53, 58, 61, 62, 66, 74, 77, 85^ Thirteen of these 20 studies were educational programs on HIV/AIDS or STDs and could be construed as refresher courses if the targeted learners had already learned about these topics in previous training.^31, 34, 38, 39, 41, 42, 44, 46-48, 53, 58, 66^ However, these courses also could be viewed as providing initial training for clinicians that had not previously received adequate training on the topic. Since it was therefore difficult to distinguish studies on initial training from those on updating training, questions 1a and b were combined in this section.

#### Model 1: Training of Clinicians for Infectious Disease Outbreaks

Almost all of the reviewed studies (53 out of 60, 88.3 percent) addressed this particular question: how does one train clinicians for bioterrorism preparedness, using the model of infectious disease outbreaks? This body of literature differed widely in educational topics, target audiences, contact times, educational goals, educational methods, outcomes measured, evaluation styles, and results, making it difficult to make strong conclusions regarding which methods of training clinicians for bioterrorism would be most effective. However, information based on trends or similarities in the studies is presented.

##### Standardized patients

The use of standardized patients is an educational technique that appeared in seven articles (see Evidence Table 2).^31, 33, 38, 39, 41, 44, 53^ Standardized patients are trained to simulate a disease process in order to assess the clinician's ability to diagnose and treat the condition. This technique was most commonly used in the setting of training for evaluation and treatment of STDs and HIV and for sexual history taking and risk assessment. In these seven studies, the standardized patients were used to train physicians, community health workers, and pharmacists. Control groups were used in three out of seven of the studies.^31, 33, 39^

Studies employing simulated patients tended to use more than one measurable objective. Four of the studies had the objective of improving clinicians' knowledge.^31, 33, 39, 44^ In addition, the simulated patient could assess the skills or behaviors of the clinician and/or address attitudes and beliefs held by the clinician. None of the studies looked directly at clinical outcomes (see Evidence Table 4).

These studies generally were designed well with appropriate evaluation; all but one study had a total quality score of more than 55 percent. The studies scored the highest in the categories of representativeness of the clinician learners, outcomes of the educational intervention, and statistical quality and interpretation (see Evidence Table 3).

From the seven studies these conclusions were drawn: the use of standardized patients for this type of training was acceptable to physicians;^ 38 ^ most clinicians prepared for the simulated visit ahead of time using self-study materials provided;^ 41 ^ and simulated patients had the advantage of providing onsite feedback to the clinicians.^ 39 ^

##### Satellite broadcasting

Three articles described and evaluated educational interventions on management of infectious disease outbreaks that involved satellite broadcasting (see Evidence Table 2).^36, 37, 64^ Participants in this modality typically were based at larger academic centers that have access to the technology required to broadcast via satellite. The educational topics included tuberculosis, the polio vaccine, and HIV/AIDS. Only one of these four studies used a control group.^ 36 ^ The measurable objectives differed in each report (see Evidence Table 4). None of these studies looked at clinical outcomes. Total study quality scores ranged from 36.7 to 62.5 percent; the highest scores were in the categories of representativeness of clinician learners and outcomes of the educational intervention, and the lowest scores were in bias/confounding and statistical quality and interpretation (see Evidence Table 3).

From these reports, the evidence suggested the following conclusions (see Evidence Table 4): satellite broadcasting enhanced print-based materials about management of infectious diseases; this educational technique improved knowledge as evidenced by postintervention test scores; and it allowed for questions and answers as well as feedback. Most importantly, satellite broadcasting appeared to be an effective way to reach large numbers of people and may be as effective as classroom teaching for this type of training.

##### Tabletop exercises

One article addressed the use of a "tabletop" exercise or theoretical drill.^ 62 ^ The TOPOFF (Top Officials) exercise involved a hypothetical release of Yersinia pestis (plague) in Denver, Colorado, and was designed to test the medical and public health infrastructure in the event of an attack. This educational intervention did not report any specific measurable outcomes, and did not use a control group. The total quality score was 38.2 percent, with the highest scores in the categories of representativeness of clinician learners and outcomes, and scores of zero in bias/confounding and statistical quality and interpretation.

Due to the design of the study, the EPC team was unable to draw conclusions about the overall effectiveness of tabletop exercises as an educational tool. However, it is interesting that this is the only article identified in the literature search that directly addressed and evaluated a training program in bioterrorism response.

##### Other educational methods

In the educational literature, strictly didactic interventions generally have not produced any significant enduring change in clinician performance or health care outcomes. In contrast, educational interventions generally have been more effective when they have combined techniques, including interactive methods such as case discussion, simulated patients, and hands-on workshops, as well as didactic methods.^27, 91^

Thus, it is noteworthy that the vast majority of studies that applied to the question of training regarding infectious disease outbreaks combined a variety of educational methods (see Evidence Table 2). The most commonly used educational techniques were as follows: lecture (31 studies)^32, 33, 36, 37, 39, 40, 42, 45-53, 55, 56, 59, 64, 65, 68-70, 72, 73, 76, 77, 78, 84, 90^; discussion (19 studies)^32, 35-37, 40, 46, 47, 49, 51, 52, 55, 58, 65, 70, 72, 73, 78, 82, 84^; audiovisual aids (18 studies)^35-37, 39, 40, 42, 46, 48-50, 52, 70, 72, 73, 76, 77, 82, 84^; and readings or written material (14 studies).^33, 35, 37, 41, 47, 50, 52, 65, 66, 70, 74, 82, 85, 90^ The least common educational intervention techniques reported were programmed learning (3 studies)^35, 37, 65^; problem-based learning (2 studies)^35, 36^; demonstrations (1 study)^ 49 ^; and computer models (1 study).^ 89 ^ Over half the studies combined more than one educational method; 15 out of 55 of the studies used four or more educational methods for their intervention.^35, 36, 37, 39, 40, 46, 48, 49, 52, 65, 70, 73, 74, 84, 85^

Due to disparity in the literature, the team was unable to draw a direct correlation between the combination of techniques applied and the effectiveness of the combinations based on study outcomes.

#### Model 2: Initial Training for Toxidromes or Mass Poisonings

The literature search identified one article that described and evaluated a training program regarding toxicology and toxidromes.^ 84 ^ The article described a satellite broadcast that was received by 1,200 emergency medical service volunteers. The study had no control group, and the educational intervention had no measurable outcomes. The total study quality score was 21.2 percent, scoring the highest for representativeness of clinician learners and description of intervention and scoring zero for bias/confounding and statistical quality and interpretation (see Evidence Table 3). The authors drew the conclusion that teleconferencing is an acceptable method of continuing education for emergency personnel and is economic and efficient (see Evidence Table 4).

#### Model 3: Training for Events That Incite Fear and Anxiety

No studies described and evaluated an educational intervention on the topic of training of clinicians using this public health event model.

#### Model 4: Training for Events That Use a Hospital Disaster Plan

Five articles described and evaluated educational interventions pertaining to the use of hospital disaster plans (see Evidence Table 1).^85-89^ In four of these studies, disaster drills served as the educational technique used to train clinicians to use their hospital disaster plans. None of the four studies used a control group to evaluate the impact of the intervention. One article had no measurable outcomes.^ 86 ^ The total quality scores received by this body of literature were low, ranging from 17.7 to 33.5 percent. The studies scored modestly in the categories of representativeness of clinician learners, description of intervention, and outcomes of the educational intervention. The studies uniformly scored poorly on bias/confounding and statistical quality and interpretation (see Evidence Table 3).

One article was located in the literature search that described and evaluated an educational intervention using computer simulation.^ 89 ^ In Israel, simulation models were developed as planning and training tools for preparing hospitals for multi-casualty disasters. During the simulation (or "limited scale drill"), computer input data included information regarding theoretical trauma victims. An animation tool was used to visually illustrate bottlenecks in the emergency department, operating room, and ancillary departments. The educational intervention's measurable outcomes addressed clinician behavior. The total quality score for the article was only 9.20 percent. It scored poorly in the categories of description of intervention and outcomes, and scored zeroes for representativeness, bias/confounding, and statistical quality and interpretation. The authors concluded that the simulation techniques used in preparing a limited scale drill had advantages in evaluating and improving preparedness of hospitals. The simulation allowed identification of deficiencies in staffing, equipment, medications, electro-mechanical systems, crowd control, and security.

Given the paucity of well designed trials regarding this topic, it was difficult to draw conclusions regarding the efficacy of teaching methods in this setting. The literature weakly supported the conclusion that disaster drill training improves clinicians' knowledge of the disaster plan and allows identification of problems in plan execution that may then be addressed (see Evidence Table 4).

### Question 2

What are effective methods for training clinicians to use Web- or telephone-based central information resources in the event of a bioterrorist attack, using the public health event models?

The search did not reveal any eligible articles that addressed and evaluated the training of clinicians to use Web- or telephone-based central information resources during a bioterrorist attack or any of the defined public health event models.

### Question 3

What are effective methods for training clinicians to report events to a central agency in the event of a bioterrorist attack, using the public health event models?"

#### Model 1: Training of Clinicians for Infectious Disease Outbreaks

For this topic, one article met the eligibility criteria.^ 90 ^ The article described and evaluated a training program instituted to teach infection control nurses to report nine infectious syndromes that could herald a disease outbreak in South Africa. The nurses were initially trained with a user-oriented outbreak manual; maintenance of knowledge was ensured through regularly scheduled update training and networking. The measurable outcomes addressed clinician knowledge, skills, behaviors, and clinical outcomes (see Evidence Table 4). The study did not have a control group. It received a quality score of 50.0 percent, scoring highest in categories of representativeness of clinician learners, description of intervention, and outcomes of the intervention, and scoring lowest in the categories of bias/confounding and statistical quality and interpretation (see Evidence Table 3).

The authors concluded that a surveillance system may be developed by training infection control nurses to report certain infectious disease symptom complexes to a central agency. Furthermore, they noted that the educational intervention was sustainable through monthly structured education, networking, and feedback (see Evidence Table 4).

#### Models 2, 3, and 4

The search identified no studies that addressed the issue of training clinicians to report events to a central agency using the public health models of toxidromes or mass poisonings, events that incite fear and anxiety, or events that call for use of a hospital disaster plan.

### Question 4

What are effective methods for training clinicians to communicate with other health care professionals (within and across institutions) in the event of a bioterrorist attack, using the infrequent public health event models?

The search found no articles on how to train clinicians to communicate with other health care professionals using the defined public health models.

## Articles Pertaining to CDC Category A Biological Agents

Of note, three articles described educational programs focusing specifically on one of the CDC Category A biological agents.^60, 62, 71^ The first article described a 3-day workshop in which clinicians in the Congo learned to diagnose Ebola hemorrhagic fever, institute barrier precautions, make post-mortem diagnoses, and initiate contact tracing.^ 71 ^ The educational program, which was given in order to establish a long-term surveillance system for Ebola hemorrhagic fever in Bandundu, was considered cost effective and successful. Unfortunately, the article did not provide details about the educational techniques used in the workshop.

The second article pertaining to one of the Category A agents described the efforts to eradicate smallpox in Guinea, West Africa in 1967.^ 60 ^ Clinicians underwent an 11-day training course on clinical recognition of smallpox, administration of vaccinations, logistics of running a vaccination station, disease surveillance, and epidemiologic investigation. The training sessions included a written program guide and a practical field exercise. Within 13 months of implementation of the program, smallpox was eradicated from Guinea.

The final article was an evaluation of a tabletop exercise involving a theoretical plague release in Denver, Colorado.^ 62 ^ This is the only article that described and evaluated an intervention that specifically pertained to bioterrorism. The TOPOFF drill was designed to test the medical and public health infrastructure and was the largest exercise of its kind to date, costing $3 million. The exercise took place over 4 days and involved participants from State and county health departments and Federal health agencies as well as experts in emergency medicine, emergency management, and hospital infection control. Participants were given new information verbally or by memo, and all media communication was transmitted through a virtual news agency. Communication between participants was accomplished largely via conference calls. Evaluation of the educational intervention occurred through interviews with drill participants, controllers, and observers following the exercise. The drill revealed many important vulnerabilities and challenges in bioterrorism response that the medical and public health care system must overcome if it is to effectively care for victims of a bioterrorist attack.