# Introduction

On September 11, 2001, terrorists hijacked four commercial U.S. airplanes and used them in devastating attacks on New York City's World Trade Center and the Pentagon. Thousands perished. As a result, this country's eyes are now wide open to the vulnerability of its citizens. The President has declared a "state of war" against terrorism. As the Nation prepared for a military strike, the possibility of further retaliatory terrorist attacks moved into the foreground of American consciousness.

The unforseen and horrific nature of these attacks as well as the extraordinary coordination and funding required to launch such an assault have heightened awareness of the possibility of an impending biological attack on our country. Because the need for bioterrorism preparedness is now greater than ever before, this evidence report has taken on a new sense of urgency. Indeed, questions are being raised about the allocation of government resources for preventing and/or minimizing the consequences of further terrorist attacks. This report is therefore relevant to all policymakers in the United States who must reassess priorities for domestic preparedness against terrorism.

## Biological Agents: Background

Risk assessment expert J.D. Simon, M.D., wrote in August 1997, "Since biological weapon terrorist attacks could have catastrophic effects in terms of lives lost, and create a medical, political, and social crisis unparalleled in our history, it is important to prepare now for this new age of terrorism."^ 1 ^

Preparation for the new age of terrorism is a daunting task for our Nation as government and military agencies, public health advocates, and health care professionals all are seeking to determine the best ways to minimize the risk and potential impact of a bioterrorist attack.^ 2 ^ To help focus the monumental effort required to prepare the United States for a biological weapons attack, a working group led by the Centers for Disease Control and Prevention (CDC) has identified six pathogens (Category A agents) that are most likely to be used in such an attack. Category A agents pose the most significant threat due to ease of dissemination and transmission, projected high mortality rates, ability to cause public panic, and need for special public health preparedness.^ 3 ^ We will briefly describe the Category A agents to provide background information.

### Smallpox

Smallpox, or Variola major, is perhaps the most feared biological weapon due to its contagiousness, high mortality (30 percent), and waning human immunity resulting from cessation of immunization almost 30 years ago.^ 4 ^ Following an incubation period of about 12 days, this viral infection presents with flu-like symptoms including fever, malaise, vomiting, headache, and backache. The characteristic lesions (macules to papules to pustular vesicles) appear simultaneously, primarily on the extremities and face. Treatment is supportive. Vaccination offers protection if given early after exposure but is available in very limited quantities.^4,5^

### Anthrax

Anthrax, caused by Bacillus anthracis, is a primarily zoonotic disease with three human forms: cutaneous, gastrointestinal, and inhalational. The inhalational form is the anticipated route for weaponization. Anthrax also causes a flu-like illness following an incubation period of 1 to 6 days. The patient initially complains of fever, malaise, cough, and chest pain. The symptoms progress to respiratory distress, cyanosis, shock, and death within 24 to 36 hours of onset. The fatality rate for inhalational anthrax approaches 100 percent if untreated; however, the patient may respond to treatment with high doses of penicillin, ciprofloxacin, or doxycycline.^5, 6^

### Plague

Plague is caused by Yersinia pestis (Y. pestis), a rod-shaped, gram negative bacterium. The disease has three forms: bubonic plague, passed from rodents to humans via fleas; primary septicemic plague, a progression of bubonic plague; and pneumonic plague, the result of inhalation of Y. pestis. Following aerosol release of the bacterium, the most likely mode of attack in terrorism, victims would present 2 to 4 days later with high fever, headache, myalgias, shortness of breath, hemoptysis, and sepsis. The pneumonia can be rapidly progressive, culminating in stridor, cyanosis, and death. The mortality of pneumonic plague approaches 100 percent if not treated within 24 hours with doxycycline.^5, 7^

### Botulism

Botulism is caused by a neurotoxin produced by Clostridium botulinum, a gram-positive spore-forming rod. Botulinum toxin is the most toxic substance known. The toxin causes three forms of naturally occurring disease: foodborne, wound, and intestinal. The most likely route of exposure to be used by terrorists would be as an aerosol, which would cause inhalational botulism. The hallmark of intoxication in all forms of botulism is prominent bulbar findings (diplopia, dysphonia, dysarthria, and dysphagia) with descending, symmetric flaccid paralysis 12 to 72 hours after exposure. The treatment is supportive, with intensive nursing care and prolonged ventilatory support. An antitoxin is available that may lessen the severity of the disease but supplies are limited.^5, 8^

### Tularemia

Tularemia is caused by Francisella tularensis (F. tularensis), an infectious gram-negative coccobacillus. Tularemia is a zoonotic disease acquired by humans through contact with infected animals, ingestion, or inhalation. There are many forms of tularemia, including ulceroglandular, glandular, typhoidal, oculoglandular, pharyngeal, and pneumonic. Following release of aerosolized F. tularensis, victims would present 3 to 5 days later with a nonspecific febrile illness, complaining of headache, malaise, chest pain, and cough. Mortality after treatment with streptomycin or gentamicin is low.^5, 9^

### Viral Hemorrhagic Fevers

Viral hemorrhagic fevers (VHFs) include at least 10 related (but diverse) illnesses caused by ribonucleic acid (RNA) viruses. The CDC Category A VHFs include those that cause Ebola, Marburg, and Lassa fevers; Argentine hemorrhagic fever; and Bolivian hemorrhagic fever. The most common presentation of VHFs includes fever, myalgias, headache, vomiting, and diarrhea. The disease is complicated by petechial hemorrhages, hypotension, hemorrhaging of the mucous membranes, and shock. The treatment is supportive with intensive care, but the mortality rate is moderate to high. The antiviral agent ribavirin decreases illness severity for some VHFs.^5, 10, 11^

## The Threat of Bioterrorism

Despite ratification of the Biological and Toxin Weapons Convention in 1972 prohibiting the development, production, and stockpiling of biological weapons, many countries have continued to covertly develop such weapons.^ 12 ^ For example, following the Gulf War, investigators discovered that Iraq had weaponized and deployed anthrax, botulinum toxin, and aflatoxin.^ 13 ^ Recently, a Russian defector described an extensive and sophisticated offensive biological weapons program in the former Soviet Union. The program supported the mass production of smallpox and the development of genetically engineered biological agents.^ 14 ^

Why have biological agents become a potential weapon for terrorists? The bacteria, viruses, and toxins have been chosen for several reasons. They have the potential to produce devastating illness even in small amounts and could incapacitate cities or even nations. Many of the agents are easy to procure as one could obtain recipes from the Internet, consult a microbiology book, hire a scientist, or order an agent from a biological supply house. These agents can be disseminated fairly easily, and aerosolization (the most likely method) could be achieved with such vehicles as crop dusters, fumigating trucks, or aerosol cans. Furthermore, the agents are difficult to detect, most being colorless and odorless. Finally, these agents have the ability to produce utter terror and panic. Even a perceived attack could incapacitate a city and its health care system with "worried well" (i.e., persons who were potentially exposed but are without clinical illness) seeking information or reassurance.^ 10 ^

The actual risk of a biological terrorist event is difficult to quantify and controversial. In the last 25 years, there have been only three successful terrorist attacks with biological or chemical agents. In 1984, a religious commune in Oregon inoculated salad bars with Salmonella, sickening 751 people and hospitalizing 45 people.^ 15 ^ In 1994, the Aum Shinrikyo, a Japanese doomsday cult, used the nerve gas sarin in Matsumoto, Japan, exposing 250 people and killing 7 people.^ 16 ^ A year later, the same cult released sarin in a Tokyo subway, killing 11 people and sending more than 5,000 to area hospitals.^ 17 ^

Some health experts argue that given the rarity of relevant events, bioterrorism should not be considered a major public health threat in comparison to other public health issues such as tuberculosis, pollution, and increasing strain on the health care system.^18, 19^ However, most experts believe that given the potentially high consequences (albeit low probability) of a bioterrorist attack, bioterrorism does indeed pose a significant security and public health threat. The last two decades have seen an accelerated pattern of terrorist attacks on United States property around the world, including some on domestic soil. Examples include: the New York City World Trade Center bombing in 1993; the bombing of the Murrah Federal Building in Oklahoma City in 1995; the attacks on the United States embassies in Kenya and Tanzania in 1998; and the attack on the U.S.S. Cole, an American warship refueling in Yemen, in 2000. In his statement before the Senate Armed Services Committee, the Director of Central Intelligence, George Tenet, stated, "On terrorism, Mr. Chairman, I must be frank in saying that Americans increasingly are the favored targets. United States citizens and facilities suffered more than 35 percent of the total number of international terrorist attacks in 1998."^ 20 ^ His comment was prophetic as on September 11, 2001, the United States experienced the most devastating attack yet recorded. Over 3,000 people died as a result of a far reaching and well coordinated attack in New York City and Washington, DC. This attack revealed the vulnerability of the United States and its citizens and heightened concerns regarding bioterrorism.

## Education: Key to Preparation

With the growing number of terrorist attacks, the United States has come to realize it is no longer possible to anticipate or thwart all terrorist activity. However, it is possible and prudent to undertake a campaign to improve bioterrorism response in order to minimize the consequences of any attack. Until recently, preparatory efforts focused on the military, government personnel, and first responders. Ironically, the health care system, which would bear the brunt of an attack, had been excluded from bioterrorism response-planning activities. It is well recognized that in a covert attack, victims will appear at hospitals, doctors' offices, urgent care facilities, and health departments rather than being located at one disaster scene. If health care professionals are unprepared to be first responders and lack knowledge of the syndromes caused by biological agents, the attack could go unrecognized until it is too late, with disastrous results.^21, 22^

The CDC Strategic Planning Workgroup has identified the major components of domestic preparedness, including improved ability to identify and detect agents, enhanced communication systems, stockpiled antibiotics and vaccines, enhanced epidemiologic surveillance, and continued research in and development of diagnostic tests, vaccines, and drugs. The CDC Workgroup states that "fundamental to these efforts is comprehensive, integrated training designed to ensure core competency in public health preparedness and the highest levels of scientific expertise among local, state, and federal partners."^ 3 ^ A physician with the Institute for Environmental Studies at the University of Pennsylvania states that we can "mitigate considerably the severity of such a catastrophe, and certainly its spread in the context of contagious agents, by careful, cost-effective training and consciousness-raising in the emergency medical services and medical communities." ^ 23 ^ Clearly, education of health care professionals is a key component of our Nation's response efforts.^21, 22, 23^

Yet there appears to be a gap between the recognition of the role of education and the actual implementation of educational programs. Emergency medicine clinicians, who are likely to be first responders in a biological attack, have reported a lack of relevant training in bioterrorism. In a 1999 study report, 86 percent of the responding emergency physicians felt training was necessary, but only 53 percent indicated that formal training on biological weapons was included in their residency program.^ 24 ^

So why has there been delay or hesitation in educating this nation's clinicians? The American College of Emergency Physicians (ACEP) has formed a Nuclear, Biological and Chemical Task Force to evaluate the status of bioterrorism training in the United States, identify barriers to this training, and offer recommendations for effective education.^ 25 ^ The Task Force has identified and described six major training programs that are available nationally. These programs are sponsored by such agencies as the U.S. Army Medical Research Institute of Infectious Diseases, Centers for Disease Control and Prevention, Food and Drug Administration, Federal Emergency Management Agency, Department of Defense, Federal Bureau of Investigation, and Bureau of Justice Assistance. The educational techniques are mixed formats with combinations of written material, case studies, audiovisual aids, group discussions, and lectures. The target audiences include military and civilian medical care providers, public health professionals, and first responders.

In addition to identifying the major weapons of mass destruction (WMD) educational programs in the United States, the CDC Task Force has identified three major groups of barriers to training on response to bioterrorism. First, it acknowledges the difficulty of integrating WMD-specific content into medical school and residency curricula. Existing programs are busy and time-restricted; and no approved body of information exists to integrate. Second, it is difficult to develop and maintain effective training materials for curricula. This is exacerbated by the lack of standardized content and a lack of funding and expertise for material development. Third, there is a lack of funding for continuing education and lack of priority given to such education, resulting in substantial barriers to educating clinicians on bioterrorism.

It is reassuring to know that education of clinicians in bioterrorism has been initiated in the United States despite the barriers to training discussed above. However, it is unclear if these programs have been effective. Nor is it known if there are other relevant and effective educational programs available. Finally, the availability of effective programs specifically designed to update and reinforce training for clinicians to prepare for bioterrorism events is unknown.

## Purpose of This Evidence Report

To this end, the Johns Hopkins University (JHU) Evidence-based Practice Center (EPC) has prepared this evidence report, the purpose of which is to summarize existing evidence on the effectiveness of training clinicians for public health events relevant to bioterrorism preparedness. In 2000, the Agency for Healthcare Research and Quality (AHRQ) was allocated $5 million for bioterrorism research. The AHRQ proposed a pipeline of research on issues related to bioterrorism. The proposed focus included research on a variety of related health issues, development of tools and procedures for identifying and managing a bioterrorist incident, and ultimately translating this research into practice. The development the JHU EPC evidence report is one aspect of AHRQ's Bioterrorism Initiative.

Unfortunately, little information exists about preparing clinicians for such an unusual public health emergency as bioterrorism. To prepare the evidence report, public health models were needed as proxies from which the JHU EPC team could extrapolate useful information on how to train clinicians. For this reason, the team chose to examine the following types of public health events that would pose challenges to the health care system similar to a bioterrorist event: infectious disease outbreaks, toxidromes or mass poisoning events, catastrophic events that incite fear and mass hysteria, and incidents that require use of hospital disaster plans (see Chapter 2, Public Health Models for Training Clinicians).

Although a myriad of agencies and personnel groups must be trained in bioterrorism preparedness, this evidence report focuses on the training of clinicians. In this report, we define "clinicians" as all clinical health care professionals, including physicians, physician assistants, nurse practitioners, nurses, and community health workers.