# Appendix I. Literature Search Summary

Source | Search strategy | Date completed | Number of citations
Source | Search strategy | Date completed | Retrieved | Unique (included in abstract review process) | Eligible for article review process
PubMed | PubMed core | Mar. 19, 2001 | 1,288 | 1,288 | 304
HealthSTAR via Gateway | Gateway core | Mar. 22, 2001 | 0 | 0 | 0
ERIC^®^ | ERIC^®^ core | Mar. 26, 2001 | 48 | 48 | 4
EPOC | EPOC core | Mar. 27, 2001 | 66 | 66 | 2
SPECTR | SPECTR core | Mar. 26, 2001 | 0 | 0 | 0
RDRB/CME^®^ | RDRB^®^ core | Mar. 23, 2001 | 48 | 42 | 0
PsycINFO^®^ | PsycINFO^®^ core | Mar. 26, 2001 | 385 | 374 | 4
PubMed | PubMed core "what's new" feature | June 6, 2001 | 81 | 79 | 6
Handsearch | Table of contents of priority journals | June 30, 2001 | 18 | 11 | 5
Handsearch | Reference lists of reviews | June 30, 2001 | 61 | 34 | 32
| | TOTAL | 1,995 | 1942 | 357