# Appendix H. Content Review and Abstraction Form

EPC Bioterrorism Team Article Content Review Form

1. Article ID: ___________________________ | 2. First author:________________________________
3a. Primary Reviewer (initials): ______________ | 3b. Secondary reviewer (initials)__________________

4 Type of health care Professional (Check all that apply)
  [image] Community health worker [image] Dentist [image] First Responder (e.g EMT) [image] Nurse [image] Pharmacist [image] Physician [image] Other (specify): ___________________ [image] Not specified
5 Clinician specialty (Check all that apply)
  [image] Emergency Medicine [image] Family Medicine [image] Internal Medicine [image] Military Medicine [image] Pediatrics [image] Psychiatry [image] Surgery [image] Toxicology [image] Other (specify):_________________________________________________________________ [image] Not specified [image] N/A (for EMTs, pharmacists, dentists, nurses)
6 Training level (Check all that apply)
  [image] Undergraduate student [image] Graduate/medical/nursing student [image] Resident [image] Post-doctoral fellow [image] Practicing professional (i.e., completed training) [image] Other (specify):_________________________________________________________________ [image] Not specified
7 Please check the relevant intervention groups and provide a brief description of each group (NS=not specified).
  Group | Intervention | Control | # in group | Description of groups
  A
  B
  C
  D
  Total | | | | Total in study, N=
8 Participation of clinician learners in this intervention was (check all that apply):
  [image] Incentive-based (monetary gain, licensure) [image] Mandatory (job requirement) [image] Voluntary [image] Other (specify): ___________________________________________________________ [image] Not specified
9 In what part of the world was the intervention mainly performed (check all that apply):
  [image] Africa [image] Asia [image] Australia [image] Canada [image] Europe [image] Mexico, South or Central America [image] U.S [image] Other, (specify): ___________________________ [image] Not specified
10 Mark the setting(s) where the educational intervention took place. Check all that apply
  [image] Classroom, eg, any enclosed space: lecture hall, community center [image] Clinical office [image] Field [image] Hospital [image] Laboratory [image] Military [image] Pharmacy [image] Web [image] Other (specify)_______________________________________ [image] Not specified

Complete EITHER item 11 OR item 12 below

11 If the overall goals of the educational intervention are stated in this article, write the broad goals verbatim in the spaces provided. If the overall goals are not explicitly stated go to question 12.
  1._______________________________________________________________________________ ________________________________________________________________________________ 2._______________________________________________________________________________ _________________________________________________________________________________ 3._______________________________________________________________________________ _________________________________________________________________________________ 4._______________________________________________________________________________ _________________________________________________________________________________
12 If the overall goals were alluded to but not explicitly stated, briefly summarize the broad educational goals:
  1._______________________________________________________________________________ ________________________________________________________________________________ 2._______________________________________________________________________________ ________________________________________________________________________________ 3._______________________________________________________________________________ ________________________________________________________________________________ 4._______________________________________________________________________________ ________________________________________________________________________________
13 What are the measurable objectives of the educational intervention in this article:
  Measurable Objectives [image] all that apply | Briefly describe the measurable objectives for each item checked in the spaces below [image] here [image] if no measurable objective stated
  Knowledge [image]
  Attitudes/Beliefs [image]
  Skills [image]
  Behaviors [image]
  Clinical Outcomes [image]
14 What educational methods were used in the intervention? (Check all that apply)
  [image] Audio/Visual (eg. videotapes) [image] Clinical experiences [image] Computer models [image] Demonstration [image] Discussion [image] Drill/Practice exercise [image] Other (specify): ______________________________ [image] Not specified | [image] Lectures [image]Programmed learning (sequential, controlled instruction) [image] Readings [image] Role play [image] Standardized patient [image] Problem based learning
15 Was the intervention designed for individuals or groups? Check all that apply.
  [image] Individuals [image] Groups [image] Other (specify): [image] Not specified
16 Average total amount of contact time spent by learners in actual training
  [image] <2 hours [image] 2-10 hours [image] 11-20 hours [image] >20 hours [image] Not specified
17 Average duration of educational intervention (over what length of time administered) including initial education and feedback period?
  [image] <1 day [image] 1-29 days [image] 1 - 12 months [image] >1 year [image] Not specified
18 Length of time to last follow up
  [image] <1 day (includes immediate post test) [image] 1-29 days [image] 1-12 months [image] >1 year [image] Not specified
19 Measurement methods used in evaluation of this intervention (check all that apply):
  [image] Essays [image] Group interviews [image] Individual interviews [image] Oral exams [image] Performance audits [image] Participant Questionnaires [image] Observer/Rater questionnaire | [image]Self Assessment forms [image] Written exams [image] Computer interactive tests [image] Other (Specify): __________________________ [image] Not specified
20 How well were the learning objectives met? [image] No measurable objectives
  Outcomes Measures (check all that apply) | Were the learning objectives met? | Briefly describe the measured outcomes in the space provided.
  Knowledge | yes no unclear N/A
  Attitudes/Beliefs | yes no unclear N/A
  Skills | yes no unclear N/A
  Behaviors | yes no unclear N/A
  Clinical Outcomes | yes no unclear N/A
21 Author conclusion/summary:
  [image] Overall improvement after educational intervention [image] Partial improvement or mixed results [image] No improvement after educational intervention [image] Unclear [image] Other ____________________________________________________________________
22 Briefly summarize the main conclusions:
  1______________________________________________________________________ ______________________________________________________________________ 2______________________________________________________________________ ______________________________________________________________________ 3______________________________________________________________________ ______________________________________________________________________ 4______________________________________________________________________ ______________________________________________________________________