# Appendix G. Quality Assessment Form

EPC Bioterrorism Team Article Quality Review Form

1. Article ID: ___________________________ | 2. First author:______________________________
3a. Primary Reviewer (initials): ______________ | 3b. Secondary reviewer (initials)________________

4 Basic Features (check one if applicable)
  [image] Not in English [image] Does not include human data [image] No original data [image] Meetings abstract (no full article to review) [image] Does not include healthcare professionals [image] Does not include public health, bioterrorist attack models [image] Does not include training or education [image] Does not include evaluation of training or education [image] Other (specify) _______________________________________________

IF ANY OF THE ABOVE ITEMS IS CHECKED, STOP: DO NOT COMPLETE FORM

5 Does article relate to Key Questions? (check all that apply)
  [image] The initial training of clinicians (Q1a) [image] Methods for updating and reinforcing the training of clinicians (Q1b) [image] Training clinicians to use web or telephone based central information (Q2) [image] Training clinicians to report events to a central agency (Q3) [image] Training clinicians to communicate with other health care professionals (Q4) [image] Does not apply →stop review here; do not continue
6 Which public health event model corresponds to topic discussed in article?
  [image] Infectious disease outbreaks (includes reportable diseases) [image] Toxidromes and mass poisonings [image] Catastrophic events that incite fear [image] Events that call for use of hospital disaster plan [image] Does not apply →stop review here; do not continue

Representativeness of Clinician Learners/Trainees: For each question, indicate your response by circling one response

7 Were the setting and population from which the learners drawn described and calendar dates of training reported?
  a. | adequate (setting and population described and start and end date specified) | 2
  b. | fair (one or more of these NOT reported OR poor descriptions) | 1
  c. | inadequate (not specified) | 0
  d. | not applicable | N/A
8 Were detailed inclusion/exclusion criteria provided (so that groups could be reassembled)?
  a. | adequate (Detailed description of specific inclusion and exclusion criteria OR statement that all potential trainees enrolled) | 2
  b. | fair (Some description of inclusion OR exclusion criteria) | 1
  c. | inadequate (Minimal description or none at all) | 0
  d. | not applicable | N/A
9 Was there information about excluded trainees or learners?
  a. | adequate (all reasons for exclusion and # excluded OR no exclusions) | 2
  b. | fair (only one of above criteria specified OR information not sufficient to allow replication) | 1
  c. | inadequate (none of the above criteria specified) | 0
  d. | not applicable | N/A
10 Does the article adequately describe the clinician participants (e.g., Specific profession, specialty and education level)?
  a. | adequate (Specific profession and speciality within profession; education level specified) | 2
  b. | fair (One or more of these not reported OR poor descriptions) | 1
  c. | inadequate (not specified) | 0
  d. | not applicable | N/A

Bias and Confounding: For each question, circle one response

11 Was there an appropriate comparison group?
  a. | adequate (concurrent and similar group) | 2
  b. | fair (non-concurrent OR non-similar) | 1
  c. | inadequate (non-concurrent and non-similar) | 0
  d. | none →Skip to item 16 | 0
  e. | not applicable | N/A
12 Was assignment of study groups randomized?
  a. | yes | 2
  b. | no | 0
  c. | unclear | 0
  d. | not applicable | N/A
13 Did the groups have any important differences on key factors at baseline?
  Key Characteristics
  Educational level (e.g., undergraduate, graduate/professional school, post-graduate level)
  Profession (e.g., nurses, EMT, MD)
  Specialty (e.g., Emergency Medicine, Internal Medicine, Pediatrics)
  a. | Groups equivalent in all key factors | 2
  b. | Groups have minor difference in 1 factor | 1.5
  c. | Groups have major difference in 1 factor or minor differences in more than 1 factor | 1
  d. | No information about groups' characteristics or inadequate to compare | 0
  e. | Not applicable | N/A
14 Were the key people measuring the educational outcomes appropriately masked?
  a. | yes | 2
  b. | no | 0
  c. | can't tell | 0
  d. | not applicable | N/A
15 Was there any intervention other than the educational intervention of interest that differed between groups?
  a. | yes | 0
  b. | no | 2
  c. | can't tell | 0
  d. | not applicable | N/A

Description of Intervention: For each question, circle one letter

16 Are the objectives of the intervention clearly stated in specific measurable terms?
  a. | adequate (objectives clearly stated in measurable terms) | 2
  b. | fair (objectives stated but not stated in specific measurable terms) | 1
  c. | inadequate (objectives not stated) | 0
  d. | not applicable | N/A
17 Did the objectives of the intervention specifically take into consideration knowledge, beliefs/attitudes, skills, behaviors, or clinical outcomes?
  a. | adequate (considers any 3 of 5) | 2
  b. | fair (considers 1 or 2 of 5) | 1
  c. | inadequate (considers none of the above) | 0
  d. | not applicable | N/A
18 Was there a complete description of the educational methods, eg, audio-visuals, lectures, discussion, etc, used in the study?
  a. | adequate (intervention could be replicated given the completeness and detail of educational methods) | 2
  b. | fair (some detail but insufficient to ensure replication) | 1
  c. | inadequate (no detail) | 0
  d. | not applicable | N/A
19 Are the required resources adequately described in sufficient detail (e.g. faculty, facility, equipment)?
  a. | adequate (resources clearly described in detail sufficient to be replicated) | 2
  b. | fair (some detail but insufficient to ensure replication) | 1
  c. | inadequate (no detail) | 0
  d. | not applicable | N/A
20 Was the curriculum content described in sufficient detail to be replicated?
  a. | adequate (curriculum materials described in sufficient detail to be replicated | 2
  b. | fair (some detail but insufficient to ensure replication) | 1
  c. | inadequate (no detail) | 0
  d. | not applicable | N/A
21 Was the organization and administration of the educational intervention described in sufficient detail?
  a. | adequate (administrative structure and operational details described in detail sufficient to be replicated) | 2
  b. | fair (some detail but insufficient to ensure replication) | 1
  c. | inadequate (no detail) | 0
  d. | not applicable | N/A

Outcomes of the Educational Intervention: For each question, circle one response

22 Outcomes of the educational intervention were based upon
  a. | pre- and post-intervention evaluation | 2
  b. | post-intervention evaluation | 1
  c. | neither pre- nor post-intervention evaluation | 0
  d. | not applicable | N/A
23 Are the evaluation methods described in sufficient detail?
  a. | adequate (evaluation methods described in detail sufficient to be replicated) | 2
  b. | fair (some detail but insufficient to ensure replication) | 1
  c. | inadequate (no detail) | 0
  d. | not applicable | N/A
24 Are the evaluation methods congruent with the stated objectives of the curriculum?
  a. | adequate (evaluation methods congruent with the stated objectives of the curriculum) | 2
  b. | fair (evaluation methods related to but not completely congruent with the stated objectives of the curriculum) | 1
  c. | inadequate (evaluation methods either poorly defined OR incongruous with program objectives) | 0
  d. | not applicable | N/A
25 Were objective methods used to evaluate outcomes?
  a. | adequate (objective methods were used to evaluate outcomes) | 2
  b. | fair (methods to evaluate outcomes defined but objectivity of methods is questionable) | 1
  c. | inadequate (no objective methods used to evaluate outcomes) | 0
  d. | not applicable | N/A
26 Was there any follow-up after completion of the intervention?
  a. | yes | 2
  b. | no | 0
  c. | not applicable | N/A

Statistical Quality and Interpretation: Please circle one response for each question

27 For primary endpoints, is the magnitude of difference between groups AND an index of variability (e.g test statistic, p value, standard error, confidence interval) stated?
  a. | adequate (both reported with index of variability using standard error or confidence intervals) | 2
  b. | fair (both reported with index of variability using only test statistic or p value) | 1
  c. | inadequate (one or both not reported) | 0
  d. | no comparison group | 0
28 Were the appropriate analyses and statistical tests performed?
  a. | adequate (yes for all analyses) | 2
  b. | fair (yes for only some of the analyses) | 1
  c. | inadequate (not for any of the analyses or can't tell) | 0
  d. | not applicable | N/A
29 If groups were not comparable at study onset, was there adjustment of potential confounders with multi-variate or stratified analyses AND were confounders coded in a way to make such control adequate?
  a. | adequate (adjustment done AND confounders appropriately coded) | 2
  b. | fair (adjustment done BUT confounders not coded appropriately OR coding unclear OR can't tell) | 1
  c. | inadequate (adjustment not done OR comparability not previously reported) | 0
  d. | not applicable | N/A
30 Were crossovers and/or dropouts handled appropriately in analysis?
  a. | sensitivity analysis | 2
  b. | by intention to teach (analogous to intention to treat) | 2
  c. | by 'intervention received' analysis only | 1
  d. | by none of the above | 0
  e. | unknown | 0
  f | not applicable | N/A

Any comments for us: __________________________________________________________________________

_____________________________________________________________________________________________

_____________________________________________________________________________________________

THANK YOU! For completing this form. Please return to Mollie Jenckes