# Appendix F. Web Site Eligibility Form

<print date> | EPC Bioterrorism Training Project Website Screening Form | Reviewer: __< >____ Data Entry: _________
<Record #>
<title>
<address/URL>

Exclude website from further consideration because (check one):
[image]no material in English [image]personal page [image]unable to identify source (website author or organization) [image]no relevant content: no description or evaluation of educational programs or models Do not continue if any item above is checked | [image]purpose is to promote or advocate violence [image]no original material (i.e., all links are to other sites) [image]this URL/address is not home page specify home page URL, if known: ______________________________ [image]Uncertain/ other: (specify) _____________________________________ _____________________________________

Publications or reports to be considered for review are located at: [image]Home page [image]Links to (please list links to review; write in the name of each link you select as it appears on the web page):
Homepage address: www.________________________ www.________________________ www.________________________ www.________________________ www.________________________ www.________________________ | Specific Reports (links form home page): _______________________________ _______________________________ _______________________________ _______________________________ _______________________________ _______________________________
[image]Other comments:__________________________________________________________________ ______________________________________________________________________________________ ______________________________________________________________________________________ [image]Useful as reference only