# Appendix E. Search Terms and Details of Web Site Search

Search terms | Results after validation | Number of sites reviewed | Record IDs
detection+bioterrorist+attack | 28 | 7 | 3, 5, 7, 10, 17, 24, 32
recognition+bioterrorist+attack | 31 | 3 | 15, 30, 39
revealing+bioterrorist+attack | 35 | 2 | 19, 37
managing+"bioterorrist attack" | 24 | 4 | 2, 17, 18, 25
methods+training+clinicians+"bioterrorist attack" | 18
educating+clinicians+"bioterrorist attack" | 13
responding+"bioterrorist attack" | 23 | 1 | 36
detecting+"bioterrorist attack" | 24
detecting+"toxidromes" | 23 | 2 | 11, 31
detecting+"mass hysteria" | 30
detecting+events+"hospital disaster plans" | 16 | 2 | 8, 29
teaching+clinicians+"bioterrorist attack" | 20
teaching+clinicians+"infectious diseases" | 25 | 2 | 21, 22
training+education+evaluation+bioterrorism | 28 | 3 | 6, 23, 40
training+education+evaluation+"infectious disease outbreaks" | 18
training+education+evaluation+"reportable disease" | 22
training+education+evaluation+"STD" | 36 | 1 | 26
training+education+evaluation+toxidromes | 30 | 2 | 1, 16
training+education+evaluation+"mass hysteria" | 28
training+education+evaluation+"hospital disaster plans" | 9
training+education+evaluation+clinicians+bioterrorism | 15
training+education+evaluation+clinicians+"infectious disease outbreak" | 14
training+education+evaluation+clinicians+"reportable disease" | 21
training+education+evaluation+clinicians+"STD" | 28 | 1 | 20