# Appendix D. Literature Abstract Review Form

Record Number: | EPC Bioterrorism Training Project | Reviewer: __< >____
First Abstract Review: | Abstract review Form | Data Entry: _________
Title:

Do not review, because article (check 1 or more) [image]not in English [image]does not include human data [image]no original data [image]meeting abstract (no full article for review) [image]does not include healthcare professionals [image]does not include public health, bioterrorist attack models [image]does not include training or education [image]no evaluation [image]other: (specify)___________ [image]unclear: get article to decide Do not continue if any item above is checked. Otherwise, continue to next column and check at least one box in each in each section | Article relates to Key Questions (check all that apply) [image]initial training (Q1a) [image]updating and reinforcing training (Q1b) [image]training for use of central information (Q2) [image]training for reporting events to central agency (Q3) [image]training to communicate with other healthcare professionals (Q4) [image]does not apply _________________________________________ [image]infectious disease outbreaks (includes reportable diseases) [image]toxidromes or mass poisonings [image]catastrophic events that incite anxiety, fear, and mass hysteria [image]events that use hospital disaster plan [image]does not apply

[image] Article for reference only