# Appendix C. Literature Search Strategy

## PubMed Core Strategy

(biological warfare[mh] OR biological warfare[tw] OR bioterrorism[tw] OR (biological[tw] AND (threat*[tw] OR weapon*[tw] OR terrorism[tw]))) OR (communicable disease control[mh] OR communicable diseases[mh] OR disease outbreaks[mh] OR epidemic[tw] OR outbreak[tw] OR bacillaceae infections[mh] OR botulism[mh] OR botulinum toxins[mh] OR botulism[tw] OR anthrax[tw] OR smallpox[mh] OR smallpox[tw] OR influenza[mh] OR influenza[tw] OR plague[mh] OR plague[tw] OR salmonella infections[mh] OR salmonella[tw] OR tularemia[mh] OR tularemia[tw] OR ebola virus[mh] OR ebola[tw] OR Acquired immunodeficiency syndrome[mh] OR brucellosis[mh] OR syphilis[mh] OR chancroid[mh] OR gonorrhea[mh] OR chlamydia trachomatis[mh] OR cholera[mh] OR coccidioidomycosis[mh] OR rubella[mh] OR cryptosporidiosis[mh] OR diphtheria[mh] OR encephalitis, california[mh] OR encephalitis, St. Louis[mh] OR encephalomyelitis, equine[mh] OR escherichia coli o157[mh] OR haemophilus influenzae[mh] OR leprosy[mh] OR hantavirus pulmonary syndrome[mh] OR hemolytic-uremic syndrome[mh] OR hepatitis,viral,human[mh] OR HIV[mh] OR lyme disease[mh] OR malaria[mh] OR measles[mh] OR meningitis, meningococcal[mh] OR mumps[mh] OR poliomyelitis[mh] OR rabies[mh] OR rocky mountain spotted fever[mh] OR streptococcal infections[mh] OR tetanus[mh] OR shock,septic[mh] OR trichinosis[mh] OR tuberculosis[mh] OR typhoid fever[mh] OR yellow fever[mh] OR salmonella infections[mh] OR dysentery,bacillary[mh] OR legionellosis[mh] OR ornithosis[mh] OR whooping cough[mh] OR hemorrhagic fevers,viral[mh] OR Acquired immunodeficiency syndrome[tw] OR AIDS[tw] OR brucellosis[tw] OR syphilis[tw] OR chancroid[tw] OR gonorrhea[tw] OR chlamydia trachomatis[tw] OR cholera[tw] OR coccidioidomycosis[tw] OR rubella[tw] OR cryptosporidiosis[tw] OR diphtheria[tw] OR encephalitis[tw] OR encephalomyelitis[tw] OR escherichia coli[tw] OR haemophilus influenzae[tw] OR leprosy[tw] OR hantavirus pulmonary syndrome[tw] OR hemolytic-uremic syndrome[tw] OR hepatitis[tw] OR HIV[tw] OR lyme disease[tw] OR malaria[tw] OR measles[tw] OR meningococcal meningitis[tw] OR mumps[tw] OR poliomyelitis[tw] OR rabies[tw] OR rocky mountain spotted fever[tw] OR streptococcal infections[tw] OR tetanus[tw] OR septic shock[tw] OR trichinosis[tw] OR tuberculosis[tw] OR typhoid fever[tw] OR yellow fever[tw] OR salmonella infections[tw] OR bacillary dysentery[tw] OR legionellosis[tw] OR ornithosis[tw] OR whooping cough[tw]) OR (disaster planning[mh] OR disaster planning[tw] OR disaster[tw] OR catastroph*[tw]) OR (toxins[mh] OR toxidromes[tw] OR toxin[tw] OR poisoning[mh] OR poison*[tw]) AND ((disease notification[mh] OR surveillance[tw] OR response[tw] OR report[tw] OR manage[tw] OR prepare*[tw] OR plan[tw] OR plann*[tw] OR detect*[tw] OR recogn*[tw] OR communicat*[tw]) AND (education[mh] OR ed[sh] OR educat*[tw] OR train*[tw] OR curriculum[tw])) AND (evaluation[mh] OR evaluat*[tw] OR measure[tw] OR assess[tw] OR performance[tw])AND eng[la] AND journal article[pt] NOT (animal[mh] NOT human[mh]) NOT (health education[mh] OR review[pt] OR meta-analysis[pt])

## ERIC^®^ Core Strategy

(poison,poisoning,"communicable disease","disease control",bioterrorism,"biological warfare",disaster,catastroph*) + ("health personnel","allied health personnel","health services") + ("program evaluation","course evaluation")

## PsycINFO^®^ Core Strategy

#1 | ((biological warfare) or (bioterrorism) or (biological weapon*) or (biological threat*) or (biological terrorism))
#2 | (communicable disease*) or (infectious disease*) or (disease outbreak*) or (epidemic)
#3 | (poison*) or (toxin*) or (toxidrome*)
#4 | (disaster*) or (catastroph*)
#5 | (((biological warfare) or (bioterrorism) or (biological weapon*) or (biological threat*) or (biological terrorism)) and (English in la)) or ((communicable disease*) or (infectious disease*) or (disease outbreak*) or (epidemic)) or ((poison*) or (toxin*) or (toxidrome*)) or ((disaster*) or (catastroph*))
#6 | (educat*) or (train*) or (curriculum)
#7 | (surveillance) or (plan*) or (detect*) or (response) or (recogn*) or (report) or (manage) or (prepare*) or (communicat*)
#8 | ((educat*) or (train*) or (curriculum)) and ((surveillance) or (plan*) or (detect*) or (response) or (recogn*) or (report) or (manage) or (prepare*) or (communicat*))
#9 | (((educat*) or (train*) or (curriculum)) and ((surveillance) or (plan*) or (detect*) or (response) or (recogn*) or (report) or (manage) or (prepare*) or (communicat*))) and ((((biological warfare) or (bioterrorism) or (biological weapon*) or (biological threat*) or (biological terrorism)) or ((communicable disease*) or (infectious disease*) or (disease outbreak*) or (epidemic)) or ((poison*) or (toxin*) or (toxidrome*)) or ((disaster*) or (catastroph*)))
#10 | (((educat*) or (train*) or (curriculum)) and ((surveillance) or (plan*) or (detect*) or (response) or (recogn*) or (report) or (manage) or (prepare*) or (communicat*))) and ((((biologi cal warfare) or (bioterrorism) or (biological weapon*) or (biological threat*) or (biological terrorism)) or ((communicable disease*) or (infectious disease*) or (disease outbreak*) or (epidemic)) or ((poison*) or (toxin*) or (toxidrome*)) or ((disaster*) or (catastroph*))) and (English in la)

## EPOC Core Strategy

infectious [or] communicable [or] epidemic [or] outbreak OR poison* [or] toxin* [or] toxidrome* [or] toxic OR disaster [or] catastroph* OR bioterrorism [or] 'biological warfare' [or] 'biological threat' [or] 'biological weapon*'

## RDRB^®^ Core Strategy

- selected indexed and non-indexed fields
- OR'd terms together unless otherwise noted

Bioterrorism bioterrorism biological warfare biological threat

Infectious Diseases infectious communicable epidemic outbreak

Poisons/Toxins toxin poison toxic

Disaster Planning disaster catastrophe

## SPECTR Core Strategy

#1 | SPECTR
#2 | MEDLINE
#3 | (#1 not #2)
#4 | ((BIOTERRORISM or (BIOLOGICAL next WARFARE)) OR (BIOLOGICAL NEXT THREAT))
#5 | (((((COMMUNICABLE next DISEASE*) or (DISEASE next CONTROL)) OR OUTBREAK) OR EPIDEMIC) OR (INFECTIOUS NEXT DISEASE*))
#6 | ((((POISON* or POISONING) or TOXIC) or TOXIDROME*) or TOXIN*)
#7 | (DISASTER or CATASTROPH*)
#8 | (((#4 or #5) or #6) or #7)
#9 | ((EDUCAT* or TRAIN*) or CURRICULUM)
#10 | (#8 and #9)
#11 | (#10 and #3)
#12 | ERIC
#13 | (#11 not #12)

## EPC BIO Gateway Core Strategy

### Searched for each model combined with

(("disease notification"[mh] OR surveillance[tw] OR response[tw] OR report[tw] OR manage[tw] OR prepare[tw] OR plan[tw] OR planning[tw] OR detect[tw] OR recognition[tw] OR recognize[tw] OR communicate[tw] OR communication[tw]) AND (education[mh] OR ed[sh] OR educate[tw] OR education[tw] OR train[tw] OR training[tw] OR curriculum[tw])) AND (evaluation[mh] OR evaluate[tw] OR evauluation[tw] OR measure[tw] OR assess[tw] OR performance[tw]) NOT (animal[mh] NOT human[mh]) NOT "health education"[mh]

### Models

#### Bioterrorism

("biological warfare"[mh] OR "biological warfare"[tw] OR bioterrorism[tw] OR (biological[tw] AND (threat[tw] OR weapon[tw] OR terrorism[tw])))

#### Infectious Diseases

("communicable disease control"[mh] OR "communicable diseases"[mh] OR "disease outbreaks"[mh] OR epidemic[tw] OR outbreak[tw])

#### Poisons/Toxins

(toxins[mh] OR toxidromes[tw] OR toxin[tw] OR poisoning[mh] OR poison[tw])

#### Disaster Planning

("disaster planning"[mh] OR "disaster planning"[tw] OR disaster[tw] OR catastrophe[tw]) OR AND