# Appendix B. Priority Journals for Handsearching

Journals published monthly, bimonthly, and quarterly (searched Nov. 1, 2000 to May 31, 2001)

Priority journal titles | Frequency
AIDS | Monthly
AIDS Care | 5 per year
AIDS Education and Prevention | Bimonthly
American Journal of Infection Control | Quarterly
Bulletin of the World Health Organization | Bimonthly
Infection Control Hospital Epidemiology | Bimonthly
International Journal STD AIDS | Monthly
Journal of Advanced Nursing | Bimonthly
Military Medicine | Monthly
Prehospital and Disaster Medicine | Quarterly
Public Health Reports | Quarterly
Social Science and Medicine | Bimonthly
Academic Medicine | Monthly
American Association of Occupational Health Nurses | Monthly
American Journal of Tropical Medicine and Hygiene | Bimonthly
Annals of Emergency Medicine | Monthly
Journal of Biocommunication | Quarterly
Journal of Family Practice | Monthly
Journal of General Internal Medicine | Monthly
Leprosy Review | Quarterly
Veterinary and Human Toxicology | Quarterly

Journals published weekly and semimonthly (searched Nov. 1, 2000 to May 31, 2001)

Priority journal titles | Frequency
American Journal of Epidemiology | Semimonthly
Journal of the American Medical Association | Weekly
Annals of Internal Medicine | Semimonthly
British Medical Journal | Weekly
Journal of Infectious Disease | Semimonthly