# Appendix J. Web Sites Reviewed and Reasons for Exclusion

Web site URL | Reason for exclusion
http://dev.asmusa.org/pasrc/bioterrorismdef.htm | No relevant content: no description or evaluation of educational programs or models
http://emedicine.com/EMERG/topic718.htm | No relevant content: no description or evaluation of educational programs or models
http://ftp.cdc.gov/pub/EID/vol5no5/ascii/vol5no5.txt | Does not include human data
http://home.coqui.net/myrna/toxic.htm | No relevant content: no description or evaluation of educational programs or models
http://hopkins.med.jhu.edu/press/2000/OCTOBER/001018.HTM | No relevant content: no description or evaluation of educational programs or models
http://msnbc.com/news/242173.asp?cp1=1 (http://msnbc.com/news/242173.asp?cp1=/hstatImg/3700/1) | No relevant content: no description or evaluation of educational programs or models
http://web.aafp.org/fpr/990400fr/2.html | No relevant content: no description or evaluation of educational programs or models; no original material
http://www.accet.org | No relevant content: no description or evaluation of educational programs or models
http://www.ama-assn.org/special/hiv/support/training/cdc.htm | No relevant content: no description or evaluation of educational programs or models Does not include public health, bioterrorist attack models
http://www.cdc.gov/epo/mmwr/preview/mmwrhtml/rr4904a1.htm | No original material
http://www.cdc.gov/nchstp/dstd/MMWRs/HIV_Prevention_Through_Early_Detection.htm | No relevant content: no description or evaluation of educational programs or models
http://www.cdc.gov/ncidod/EID/vol3no2/kaufman.htm | No relevant content: no description or evaluation of educational programs or models
http://www.cdc.gov/ncidod/EID/vol4no1/newsnote.htm | No original material
http://www.cdc.gov/ncidod/EID/vol5no4/pavlin.htm | No relevant content: no description or evaluation of educational programs or models
http://www.cdc.gov/ncidod/eid/vol5no4/tucker.htm | No relevant content: no description or evaluation of educational programs or models
http://www.cyinfo.com | No relevant content: no description or evaluation of educational programs or models
http://www.dhmh.state.md.us/eis6501/biotbiot.htm | No original material (i.e., all links are to other sites); no relevant content: no description or evaluation of educational programs or models
http://www.fas.org/bwc/papers/scorpro.htm | No relevant content: no description or evaluation of educational programs or models
http://www.heritage.org/library/backgrounder/bg1182es.html | No relevant content: no description or evaluation of educational programs or models
http://www.house.gov/reform/ns/press/testimony_2.htm | No relevant content: no description or evaluation of educational programs or models
http://www.humanitarian.net/biopreparedness.html | No relevant content: no description or evaluation of educational programs or models
http://www.nap.edu/html/networking_health/notice.html | No relevant content: no description or evaluation of educational programs or models No original data (i.e., all links are to other sites) No actual article
http://www.newscientist.com/nsplus/insight/bioterrorism/allfall.html | No relevant content: no description or evaluation of educational programs or models Does not include training or education Does not include public health, bioterrorist attack models
http://www.newscientist.com/nsplus/insight/bioterrorism/nowhere.html | No relevant content: no description or evaluation of educational programs or models Does not include public health, bioterrorist attack models Does not include training or education
http://www.newscientist.com/nsplus/insight/bioterrorism/strike.html | No relevant content: no description or evaluation of educational programs or models Unable to identify source (website author or organization)
http://www.newswise.com/articles/1999/8/NUCLEAR.CEP.html | No relevant content: no description or evaluation of educational programs or models
http://www.nurseweek.com/news/features/00-07/terror.html | No relevant content: no description or evaluation of educational programs or models
http://www.nursingceu.com/NCEU/courses/smallpox/ | No relevant content: no description or evaluation of educational programs or models
http://www.popsci.com/news/02171999.bioterror.html | No relevant content: no description or evaluation of educational programs or models
http://www.postgradmed.com/issues/1999/08_99/osterholm.htm | No relevant content: no description or evaluation of educational programs or models
http://www.postgradmed.com/issues/1999/08_99/symp_int.htm | No relevant content: no description or evaluation of educational programs or models
http://www.smbs.buffalo.edu/med/imrp/resources/intmed.html | No original material (i.e., all links are to other sites) No relevant content: no description or evaluation of educational programs or models Other: link page
http://www.stg.brown.edu/projects/emc/curriculum/g.for.toxicology.html | No original material (i.e., all links are to other sites)
http://www.uomhs.edu/cohs/dhm/mph/mphintro.htm | No relevant content: no description or evaluation of educational programs or models
http://www.usamriid.army.mil/education/index.html | No relevant content: no description or evaluation of educational programs or models
http://www.virology.net/garryfavwebbw.html | No relevant content: no description or evaluation of educational programs or models; no original material (i.e., all links are to other sites)
http://www1.pitt.edu/~ghdnet/GHDNet/CPR/organization.html | No relevant content: no description or evaluation of educational programs or models
http://www1.pitt.edu/~martint/pages/emrescur.htm | No relevant content: no description or evaluation of educational programs or models, no original material (i.e., all links are to other sites)
http://www.ntis.gov | No relevant content: no description or evaluation of educational programs or models