# Appendix A. Core Technical Experts and Peer Reviewers

Johns Hopkins University Bioterrorism Evidence Report - Core Technical Experts Training of Health Professionals for Rare Public Health Events
Organization | Last name | First name | Location and position
Professional Societies
American College of Physicians-American Society of Internal Medicine | Alguire | Patrick | Director, Education and Career Development, American College of Physicians-American Society of Internal Medicine
American Academy of Family Physicians | Temte | Jonathan | University of Wisconsin
American College of Emergency Physicians | White | Suzanne | Departments of Emergency Medicine and Pediatrics, Wayne State University, Detroit. Medical Director, Regional Poison Control Center at Children's Hospital of Michigan, Detroit
Society for Healthcare Epidemiology of America | Gerding | Dale | President, Society for Healthcare Epidemiology of America, Northwestern University Medical School
Governmental Agencies
Health Resources and Services Administration | Diamond | Richard | Medical Officer, Policy and Special Projects Branch, Division of Medicine and Dentistry, Bureau of Health Professions, Health Resources and Services Administration.
United States Army | Eitzen | Edward | United States Army Medical Research Institute of Infectious Diseases (USAMRIID), Fort Detrick, Maryland
Academic Organizations
Johns Hopkins Center for Civilian Biodefense Studies | O'Toole | Tara | Associate Director, Johns Hopkins Center for Civilian Biodefense
Research Triangle Institute | Kizakevich | Paul | Program manager for research and development in medical training, medical modeling, and patient simulation, Research Triangle Institute, North Carolina
University of Alabama | Terndrup | Thomas | Director, Center for Disaster Preparedness, University of Alabama at Birmingham
Johns Hopkins University Bioterrorism Evidence Report - Peer Reviewers Training of Health Professionals for Rare Public Health Events
Organization | Last name | First name | Location and position
Association for Professionals in Infection Control | English | Judith | Association for Professionals in Infection Control and Epidemiology
Maryland Department of Health and Mental Hygiene | Benjamen | Georges | Maryland Department of Health and Mental Hygiene
Harvard University, Children's Hospital | Shannon | Michael | Harvard University Children's Hospital
University of California at San Francisco - Stanford Evidence-based Practice Center | Bravata | Dena | Primary Care and Outcomes Research, Stanford University School of Medicine
Joint Commission on Accreditation of Health Organizations | Cappiello | Joe | Accreditation Field Operations
Uniformed Services University Department of Psychiatry | Norwood | Ann | Uniformed Services University