# Appendixes

Appendix A. Core Technical Experts and Peer Reviewers

Appendix B. Priority Journals for Handsearching

Appendix C. Literature Search Strategy

Appendix D. Literature Abstract Review Form

Appendix E. Search Terms and Details of Web Site Search

Appendix F. Web Site Eligibility Form

Appendix G. Quality Assessment Form

Appendix H. Content Review and Abstraction Form

Appendix I. Literature Search Summary

Appendix J. Web Sites Reviewed and Reasons for Exclusion

Appendix K. U.S. Army Medical Research Institute of Infectious Diseases Bioterrorism Training Courses